# 8 STUDY OBJECTIVES

The aims of this study were:

1. To determine the persistence of the effect of sodium nitroprusside (SNP) on blood pressure during stable infusion regimens lasting at least 12 hours
2. To assess the potential for rebound hypertension during the Blinded Phase following administration of sodium nitroprusside for 12 hours or more.

To meet these study aims, the different study phases, defined in Section 9.1, had the following objectives:

1. Open-Label Study Drug Administration (Dose-Titration) Phase
  The objective during this phase of the study was to determine the effectiveness and safety of SNP for controlling blood pressure during stable infusion lasting at least 12 hours.
2. Blinded Study Drug Administration Phase
  - The primary endpoint for the study was determined during this phase of the study. The primary endpoint was the change in mean arterial pressure (MAP) recorded during the Blinded Study Drug Administration Phase in the absence of other stimuli. The primary objective was to determine the persistence of SNP versus placebo for reducing blood pressure in pediatric subjects.
  - The secondary objectives during this phase of the study were as follows:
    - To compare the proportion of subjects randomized to receive either sodium nitroprusside or placebo that experienced offset during the blinded study drug period.
    - To compare the proportion of subjects randomized to receive either sodium nitroprusside or placebo that experienced rebound hypertension during the blinded study drug period.
    - To compare the proportion of subjects randomized to receive either sodium nitroprusside or placebo that experienced a serious adverse event during the blinded study drug period.
    - To compare the distribution of subjects randomized to receive either sodium nitroprusside or placebo that experienced a treatment-emergent and related adverse event, by maximum severity grade, during the blinded study drug period.
    - To compare the changes (values recorded during the Blinded Study Drug Administration Phase minus values recorded during the Pre-Study Drug Period) in vital signs (systolic blood pressure, diastolic blood pressure, MAP, and heart rate) between subjects randomized to receive either sodium nitroprusside or placebo.
3. Follow-up Phase
  The objectives that were evaluated during this phase of the study are as follows:
  - To compare the proportion of subjects randomized to receive either sodium nitroprusside or placebo that experienced a serious adverse event during the Follow-up Period.
  - To compare the distribution of subjects randomized to receive either sodium nitroprusside or placebo that experienced a treatment-emergent and related adverse event, by maximum severity grade, during the Follow-up Period.
  - To compare the proportion of subjects randomized to receive either sodium nitroprusside or placebo who experienced changes in individual physical examination parameters represented as either normal or abnormal from the Pre-Study Period to the end of the Follow-up Period.
  - To compare the changes (values recorded during the end of the Follow-up Period minus values recorded during the Pre-Study Drug Period) in vital signs (systolic blood pressure, diastolic blood pressure, MAP, and heart rate) between subjects randomized to receive either sodium nitroprusside or placebo.
  - To compare the changes (values obtained during the two-hour period immediately following the stop of blinded study drug minus values obtained during the Pre-Study Drug Period) in individual laboratory parameters between subjects randomized to receive either sodium nitroprusside or placebo.