# 7 INTRODUCTION

## 7.1 Background and Rationale

Blood pressure control in children is a significant concern in the intensive care unit (ICU), where management of arterial pressure is often necessary during periods of acute physiologic stress such as occurs after certain surgical and medical procedures. Examples of surgical procedures that require blood pressure control in the intensive care unit following surgery include aortic coarctation repair, Ross procedure (pulmonary valve autograft), and solid organ transplantation. Medical conditions requiring control of systemic arterial pressure include renal disease, drug therapy (corticosterioids and immunosuppression agents), and procedures such as extracorporeal membrane oxygenation (ECMO).

A wide variety of drugs of various therapeutic classes have been utilized for either controlled hypotension in the operating room or prevention of hypertension in the pediatric ICU. These drug classes include calcium channel blockers (Tobias et al, 1996), beta-adrenergic antagonists (Kay et al, 2001), ganglionic blockers (DuToit, 1970 and Gallagher and Milliken, 1979), inhalation anesthetics (Tobias, 1998) and direct acting vasodilators such as nitroglycerin and sodium nitroprusside (SNP) (Kaplan, 1980, and Tinker, 1976 Groshong, 1996, and Sinaiko, 1996). Although many vasodilator agents are available to lower blood pressure in the operating room and intensive care unit setting, few have been systematically studied in children.

SNP is a direct acting vasodilator commonly used for blood pressure control. It produces vascular smooth muscle relaxation when its metabolism in the red blood cell results in the liberation of nitric oxide (NO). NO activates the enzyme guanylyl cyclase, which results in the formation of increased intracellular levels of cyclic guanosine monophosphate (cGMP). The result is vasodilation.

## 7.2 Metabolism

Five molecules of cyanide (CN^-^) are released when SNP is metabolized in the red blood cell. The major metabolic pathway for CN^-^ is conversion to thiocyanate (SCN). This conversion occurs enzymatically via two sulfur transferase systems: 1) rhodenase (the primary pathway) and 2) beta-mercaptopyruvate-cyanide sulfurtransferase. Rhodenase is ubiquitous throughout the body, but it is highly concentrated in the liver. Rhodenase catalyzes the transfer of sulfur from a sulfur donor molecule such as thiosulfate (Na_2_SO_3_) to cyanide and thereby the formation of thiocyanate (SCN). SCN is subsequently eliminated in the urine and can therefore serve as a marker of cyanide exposure.

The ability of rhodenase to catalyze the conversion of cyanide to thiocyanate (SCN) is limited by the availability of sulfur donors in the body. Thus the provision of exogenous sulfur donors such as thiosulfate (Na_2_SO_3_) in the setting of acute cyanide intoxication is a potentially life-saving intervention (Pasch et al, 1983, Cole and Vesey, 1987).

One out of every five CN^-^ ions liberated by the metabolism of SNP binds to methemoglobin to form the non-toxic cyanomethemoglobin. The creation of additional quantities of methemoglobin by the intravenous infusion of sodium nitrite can thus provide additional CN^-^ buffering capacity. The resultant methemoglobinemia can then be treated with the administration of intravenous methylene blue.

Additional metabolic pathways for CN^-^ include the conversion of hydroxycobalamine (vitamin B12a) to cyanocobalamine, and conversion to 2-aminothiazoline 4-carboxylic acid.

If the above three pathways (rhodenase, methemoglobin, hydroxycobolamine) are overwhelmed, cyanide will bind to mitochondrial cytochrome oxidases and poison cellular oxidative phosphorylation. Cellular hypoxia is induced when cyanide inhibits the electron transport chain at cytochrome a_3_. Oxygen cannot be utilized, mixed venous oxygen tension rises and the generation of high-energy adenosine triphosphate (ATP) is blocked. The cell reverts from aerobic to anaerobic metabolism, with the subsequent generation of pyruvate and lactate. Acidosis ensues, and with it, deterioration in the organ systems most dependent on oxidative metabolism: the central nervous system and heart.

Clinical manifestations of cyanide toxicity to the central nervous system include headache, anxiety, agitation, confusion, lethargy, convulsions and coma. Cardiovascular manifestations include progressive heart failure with both loss of contractile force (negative inotropy) and slowing of rate (negative chronotropy). Bradycardia and hypotension are commonly observed pre-morbid events associated with cyanide toxicity.

In subjects receiving SNP, the earliest, most sensitive signs of cyanide toxicity are acidosis, elevated mixed venous oxygen tension, and rising blood lactate levels. Venous blood that appears “bright” red due to the inability of the tissues to extract oxygen should suggest cyanide toxicity. Arterial and mixed venous blood gas analysis with co-oximetry can help confirm the diagnosis.

## 7.3 Previous Studies

SNP was first discovered in 1850. Its hypotensive effects were noticed in 1929, and its first therapeutic use was reported by Page et al. in 1955. Moraca et al, 1962, first described the clinical use of SNP for deliberate hypotension during surgical procedures in 1962. Since then, it has been widely used to control blood pressure in infants and children in the perioperative period.

Despite its widespread use, there is a paucity of information on its safety, efficacy, and pharmacokinetic/pharmacodynamic relationships in children. Davies et al (1975) and Bennett and Abbott (1977) described their retrospective experience with SNP used to induce deliberate hypotension in small cohorts of children. Both authors observed that younger subjects required more SNP than older ones to achieve comparable degrees of blood pressure control. In their small retrospective cohort, Bennett and Abbott recommended that doses of 10 micrograms/kilogram/minute were necessary to achieve satisfactory blood pressure response. Davies et al described three possible responses to SNP administration in children: 1) a constant response to “conventional” doses < 3 mg/kg; 2) a tachyphylactic response characterized by continuously escalating dose requirement (> 3 mg/kg) to achieve a satisfactory blood pressure; and 3) resistance to the blood pressure lowering effects of the drug. They cautioned against using total doses that exceeded 3 mg/kg or continuing administration of SNP in the latter two scenarios. Firm conclusions cannot be drawn because these small case series were not randomized controlled trials with specific pharmacodynamic endpoints.

Yaster et al (1986) compared SNP to nitroglycerin (NTG) for inducing hypotension in a group of 14 adolescents. They found doses of SNP between 6-8 micrograms/kg/minute superior to NTG at any dose in the reliable induction of hypotension for children and adolescents undergoing scoliosis, craniofacial or hepatic surgery.

Hersey et al (1997) performed a randomized trial comparing SNP to the dihydropyridine calcium channel antagonist nicardipine in 20 healthy adolescents with idiopathic scoliosis undergoing spinal fusion. Target blood pressures were easily obtainable in both groups and operating conditions were comparable. The time to restoration of baseline blood pressure after termination of the infusion was significantly longer in the nicardipine group. Interestingly, blood loss was significantly greater in the SNP group. Details on SNP dose requirements were not provided.

Przybylo et al (1995) described CN^-^ and SCN blood levels in ten children who received SNP at doses up to 10 micrograms/kg/min (mean infusion rate 6 microgram/kg/min) while undergoing cardiopulmonary bypass for repair of complex congenital cardiac defects. CN^-^ levels rose as a function of time while SNP was infused, and rapidly fell when SNP was discontinued. Despite the fact that some children demonstrated serum CN^-^ levels above the generally accepted threshold of 0.5 micrograms/ml, no subject developed clinically apparent toxicity. Kazim et al (1996) questioned the validity of the results of this study because of the CN^-^ assay methods utilized.

Linakis et al (1991) retrospectively examined physician-ordering practice as it pertained to blood cyanide levels in children receiving SNP. They sought to determine how the laboratory determinations were used to monitor subjects and if there was clinically apparent toxicity in children found to have cyanide concentrations exceeding the “normal” limit of 500 micrograms/liter. They found poor correlation between blood cyanide concentration and dose or duration of therapy in subjects whose cyanide levels were “toxic.” Thiocyanate determinations were normal and no child manifested signs or symptoms of cyanide toxicity. They concluded that further pediatric studies were needed.