# 6 INVESTIGATORS AND STUDY ADMINISTRATIVE STRUCTURE

## 6.1 Principal Investigators

This multi-center study was conducted at 5 study sites in the United States which were a part of the Pediatric Off-Patent Drug Studies (PODS) network. A list of principal investigators and their affiliations, roles in the study, and curriculum vitae are provided in Appendix 16.1.4. The signatures of the sponsor’s responsible medical officer, medical monitor, and coordinating investigator for this study appear in Appendix 16.1.5.

## 6.2 Administrative Structure

The following is a list of organizations that were critical to the conduct of the study:

Sponsor | Eunice Kennedy Shriver National Institutes of Child Health and Human Development; National Institutes of Health; Building 31, Room 2A32, MSC 2425; 31 Center Drive; Bethesda, MD 20892
PODS Center | Scott Schulman, MD, MHS; Duke University Medical Center; Box 3094 DUMC; Durham, NC 27705; 919-668-4208; 919-681-8357 (Fax); 919-970-2375 (Pager); aschul003@mc.duke.edu
PODS Center | Gregory Hammer, MD; Stanford University Medical Center; 300 Pasteur Drive, H3580; Stanford, CA 94305-5640; 650-723-7835; 650-725-8544 (Fax); 650-723-8222 #13612 (Pager); ham@stanford.edu
PODS Center | ▬, MD; Stanford Medical Center; 300 Pasteur Drive, H3580; Stanford, CA 94305-5640; ▬ (Fax); ▬@stanford.edu
BPCA-CC | Premier Research Group Limited; 1500 Market Street, Suite 3500; Philadelphia, PA 19102
BPCA DCC as of 29 July 2009 | The EMMES Corporation; 401 N. Washington Street, Suite 700; Rockville, MD 20850