# 15 REFERENCES

Agresti, Alan. A Survey of Exact Inference for Contingency Tables. Statistical Science. 1992; 7 (1), 131–153.
Aitken D, West D, Smith F, : Cyanide toxicity following nitroprusside induced hypotension. Canad. Anaesth. Soc. J. 1977; 24: 651–660.
Bennett NR, Abbott TR: The use of sodium nitroprusside in children. Anaesthesia, 1977; 32: 456–463.869145
Berlin CM: The treatment of cyanide poisoning in children. Pediatrics, 1970; 46: 793–796.4320419
Boeckman AJ, Sheiner LB, Beal SL: NONMEM Users Guide – Part V: Introductory Guide (1994).
Cole PV, Vesey CJ: Sodium thiosulphate decreases blood cyanide concentrations after the infusion of sodium nitroprusside. Br. J. Anaesth, 1987; 59: 531–535.3580232
Davies DW, Greiss L, Kadar D, : Sodium nitroprusside in children: Observations on metabolism during normal and abnormal responses. Canad. Anaesth. Soc J. 1975; 22(5): 553–560.1156939
Davies DW, Kadar D, Steward DJ, : A sudden death associated with the use of sodium nitroprusside for induction of hypotension during anaesthesia. Canad. Anaesth. Soc. J. 1975; 22(5): 547–552.1156938
DuToit JR: Hypertension: the general practitioner’s approach to the problem with special reference to the use of methyldopa. S. Afr Ped J. 1970; 44: 924–926.
Ette EI, Sun H, Ludden TM. Balanced designs in longitudinal population pharmacokinetic studies: J. Clin. Pharmacol. 1998; 38(5): 4127–423.
Ette EI, Sun H, Ludden TM: Ignorability and parameter estimation in longitudinal pharmacokinetic studies. J. Clin. Pharmacol. 1998; 38(3): 221–226.9549660
Gallagher DM, Milliken RA: Induced hypotension for orthognathic surgery. J Oral Surg, 1979; 47: 47–51.
Gobburu JV, Lawrence J: Application of resampling techniques to estimate exact significance levels for covariate selection during nonlinear mixed effects model building: some inferences. Pharm. Res. 2002; 19(1): 92–98.11841044
Groshong T. Hypertensive crisis in children. Pediatr Ann, 1996. 25(7): 368–371, 375–376.8827760
Guilbault, GC, Kramer DN. Ultra sensitive specific method for cyanide using 4-Nitrobenzaldehyde and o-Dinitrobenzene, Anal. Chem 1966; 38: 843–836.
Hersey SL, O’Dell NE, Lowe S, : Nicardipine versus nitroprusside for controlled hypotension during spinal surgery in adolescents. Anesth & Analg 1997; 84: 1239–1244.
Jack RD: Toxicity of sodium nitroprusside. Brit J of Anaesth 1974; 46(12): 952.
Jones GOM, Cole P: Sodium nitroprusside as a hypotensive agent. Brit J of Anaesth 1968; 49(10): 804–805.
Kaplan AJ, Finlayson DC, Woodward S: Vasodilator therapy after cardiac surgery: a review of the efficacy and toxidity of nitroglycerin and nitroprusside. Can Anaesth Soc J. 1980; 27(3): 254–259.6769567
Kay JD, Sinaiko AR, Daniels SR: Pediatric hypertension. Amer Hlth J Sept. 2001; 142: 422–432.
Kazim R, Whittington, RA, Sun LS: Sodium nitroprusside metabolism in children. Anesth & Analg 1996; 82: 1301–1302.
Kuczmarski RJ, Ogden CL, Guo SS . 2000 CDC growth chart for the United States:Methods and development. Vital Health Stat– Ser 11: Data From the Natl Health Surv 2002; 246: 1–190.
Lerman J: Pharmacokenetics & pharmacodynamcis of inhalational anesthesia in infants & children. Anesth Clin North Am 1991; 9: 764.
Linakis JG, Lacouture PG, Woolf A: Monitoring cyanide and thiocyanate concentrations during infusion of sodium nitroprusside in children. Pediatr Cardiol 1991; 12: 214–218.1946009
Moraco PP, Elmars MB, Hale DE, : Clinical evaluation of sodium nitroprusside as a hypotensive agent. Anesthesiology 1962; 32: 193.
Page IH, Corcoran AC, Dustan HP, : Cardiovascular actions of sodium nitroprusside in animals and hypertensive subjects. Circulation 11. 1955; 188–198.13231256
Pasch T, Schulz V, Hoppelshäuser G: Nitroprusside-induced formation of cyanide and its detoxication with thiosulfate during deliberate hypotension. J of Cardio Pharmacol 1983; 5: 77–85.
Pershau RA, Modell JH, Bright RW, : Suspected sodium nitroprusside-induced cyanide intoxication. Anesthesia and Analgesia 1977; 56: 533–537.560140
Pocock, SJ (1977): Group sequential methods in the design and analysis of clinical trials, Biometrika 1977; 64(2): 191–199.
Przybylo HJ, Stevenson GW, Schanbacher P, : Sodium nitroprusside metabolism in children during hypothermic cardiopulmonary bypass. Anesth & Analg 1995; 81(5): 952–956.
Rieders, “Cyanide,” Methodology for Analytical Toxicology, ed. Irving Sunshine (Cleveland: CRC Press, 1971), 118–122.
Schulz V. Clinical pharmacokinetics of nitroprusside, syanide, thiosulphate and thiocyanate. Clin. Pharmakinet. 1984; 9: 239–251.
Sinaiko AR: Hypertension in children. N Engl J Med, 1996. 335(26): 1968–1973.8960478
Staessen JA, Bieniaszewski L, O’Brien E, : Nocturnal blood pressure fall on ambulatory monitoring in a large international database. The “Ad Hoc” Working Group. Hypertension 1997; 29: 30–39.9039076
Taylor TH, Styles M, Lamming AJ: Sodium nitroprusside as a hypotensive agent in general anaesthesia. Brit J Anaesth. 1970; 42: 859–864.5475441
Tinker JH, Michenfelder JD: Sodium nitroprusside: pharmacology, toxicology and therapeutic. Anesthesiology, 1976; 45(3): 340–354.962181
Tobias JD: Sevoflurane for controlled hypotension during spinal surgery: preliminary experience in five adolescents. Paediatr Anaesth, 1998; 8(3): 167–170.9549747
Tobias JD, Hersey GA, Mencio, Green NE: Nicardipine for controlled hypotension during spinal surgery. J Pediatr Orthop, 1996; 16(3): 370–373.8728640
Vesey CJ, Cole PV, Simpson PJ. Cyanide and thiocyanate concentrations following sodium nitroprusside infusion in man. Br. J. Anaesth. 1976; 48: 651–660.797397
Vogel SN, Sultan TR, Teneyck RP. Cyanide poisoning. Clin. Toxicol. 1981; 18: 367–383.7016420
Wahlby U, Jonsson EN, Karlsson MO: Assessment of Actual significance levels for covariate effects in NONMEN. J. Pharmacokinet. Pharmacodyn. 2001; 28(3): 231–252.11468939
Williams, DA: A test for differences between treatment means when several dose levels are compared with a zero dose control. Biometrics 1971; 27: 103–117.5547548
Williams, DA: The comparison of several dose levels with a zero dose control. Biometrics 1972; 28: 519–531.5037867
Wilson J, Vesey CJ, Cole PV: Nitroprusside revisited. Brit. Med. J. 1971; 9: 116.
Yaster M, Simmons RS, Tolo VT, : A comparison of nitroglycerin and nitroprusside for inducing hypotension in children: A double-blind study. Anesthesiology 1986; 65: 175–179.3090906