# 14 TABLES, FIGURES AND NARRATIVES

## 14.1 Demographic and Baseline Tables

Table Number | Population | Table Title / Summary
14.1.1.1 | All Enrolled Subjects | Subject Accounting and Final Study Disposition Across All Phases by Age Classification
14.1.1.2 | All Enrolled Subjects | Subject Enrollment by Site and Age Classification
14.1.1.3 | All Enrolled Subjects | Subject Status by Site
14.1.1.4 | ITT | Number of Subjects Receiving Blinded Treatment by Site and Treatment
14.1.2.1 | ITT | Demographic Summary by Treatment Group
14.1.2.2 | Safety | Demographic Summary by Age Classification
14.1.2.3 | Safety | Demographic Comparison of Randomized and Nonrandomized Enrollments
14.1.3 | Safety | Summary of Prior Medications by Age Classification and WHO Drug Class
14.1.4 | Safety | Summary of Protocol Deviations by Site
14.1.5 | Enrolled Subjects not included in safety population | Demographic Summary of Age Classification
14.1.6.1 | Safety | Operative Information Summary by Age Classification
14.1.6.2 | ITT | Operative Information Summary by Treatment Group
14.1.7.1 | Safety | Summary of Abnormal Baseline Physical Examinations by Age Classification
14.1.7.2 | ITT | Summary of Abnormal Baseline Physical Examinations by Treatment Group
14.1.8.1 | Safety | Descriptive Statistics for Infusion Rate (mcg/kg/min) by Time and Age Group (Open-Label Phase)
14.1.8.2 | ITT | Descriptive Statistics for Infusion Rate (mcg/kg/min) by Time and Treatment (Blinded Phase)

## 14.2 Efficacy Tables

Table Number | Population | Table Title / Summary
14.2.1.1.1–3 | Safety | Descriptive Statistics for MAP (Value, Change, and % Change) by Time and Age Classification (Open-Label Phase)
14.2.1.2 | ITT | Descriptive Statistics for MAP Scores by Time and Treatment Group (Blinded Phase)
14.2.1.3 | ITT | Descriptive Statistics for MAP Scores by Time and Treatment Group (Follow-Up Phase)
14.2.2 | ITT | Summary of Treatment Success by Treatment
14.2.3 | ITT | Summary of Treatment Success by Treatment and Site

## 14.3 Safety Tables

Table Number | Population | Table Title / Summary
14.3.1.1.1 | ITT | Summary of Adverse Events by Severity and Relationship to Treatment for Each Treatment Group (Open-label, Blinded and Follow-up Phases)
14.3.1.1.2 | Safety | Summary of Adverse Events by Severity and Relationship to Treatment for ITT Population and Subjects Who Did Not Receive Blinded Treatment (Open-Label Phase)
14.3.1.1.3 | ITT | Summary of Adverse Events by Severity and Relationship to Treatment by Treatment Group (Blinded Phase)
14.3.1.1.4 | ITT | Summary of Adverse Events by Severity and Relationship to Treatment by Treatment Group (Follow-Up Phase)
14.3.1.2.1 | Safety | Summary of Adverse Events by Severity and Relationship to Treatment by Age Classification (Open-label, Blinded and Follow-up Phases)
14.3.1.2.2 | Safety | Summary of Adverse Events by Severity and Relationship to Treatment by Age Classification (Open-Label Phase)
14.3.1.2.3 | ITT | Summary of Adverse Events by Severity and Relationship to Treatment by Age Classification (Blinded Phase)
14.3.1.2.4 | Safety | Summary of Adverse Events by Severity and Relationship to Treatment by Age Classification (Follow-Up Phase)
14.3.1.2.5 | Safety | Summary of Adverse Events by Severity and Relationship to Treatment by Age Classification (Pre-Study Phase)
14.3.1.3 | Safety | Summary of Adverse Events by Relationship to Study Product (Open-label, Blinded and Follow-up Phases)
14.3.1.4 | Safety | Summary of Adverse Events by System Organ Class, Preferred Term, and Age Classification (Across All Phases)
14.3.1.5 | Safety | Adverse Events by Age Classification Ordered by Most Frequent Preferred Terms (Open-label, Blinded and Follow-up Phases)
14.3.1.6.1 | Safety | Serious Adverse Events by System Organ Class, Preferred Term, and Age Classification (Open-label, Blinded and Follow-up Phases)
14.3.1.6.2 | Safety | Summary of Serious Adverse Events by Age Classification (Open-Label Phase)
14.3.1.6.3 | Safety | Summary of Serious Adverse Events by Age Classification (Follow-Up Phase)
14.3.1.7.1 | Safety | Summary of Selected Adverse Events (Rebound Hypertension, Hypotension, Lactic Acidosis, Blood and Erythrocyte Cyanide Toxicity) by Age Classification (Open-label, Blinded and Follow-up Phases)
14.3.1.7.2 | Safety | Summary of Selected Adverse Events by Age Classification (Open-Label Phase)
14.3.1.7.3 | ITT | Summary of Selected Adverse Events by Blinded Treatment (Blinded and Follow-Up Phases)
14.3.1.7.4 | Safety | Summary of Selected Adverse Events by Age Classification (Pre-Dose Phase)
14.3.1.7.5 | Safety | Summary of Worsening from Baseline of Selected Adverse Events by Age Classification (Open-Label, Blinded, and Follow-Up Phases)
14.3.1.8.1 | Safety | Summary of Adverse Events by Severity and Relationship to Treatment by Age Classification for Subjects with Severely High Cyanide Levels (whole blood) (Open-Label, Blinded, and Follow-Up Phases)
14.3.1.8.2 | Safety | Summary of Adverse Events by Severity and Relationship to Treatment by Severely High Cyanide Level (whole blood) Status (Open-Label, Blinded, and Follow-Up Phases)
14.3.2.1 | ITT | Summary of Concomitant Medications and Procedures by Treatment Group and WHO Drug Class
14.3.2.2 | Safety | Summary of Concomitant Medications and Procedures by Age Classification and WHO Drug Class
14.3.3.1.1–7 | Safety | Summary of Each Type of Quantitative Clinical Laboratory Evaluation by Time (Baseline and Post-Baseline)
14.3.3.2.1–7 | ITT | Summary of Each Type of Quantitative Clinical Laboratory Evaluation by Time for Each Treatment Group (Baseline and Post-Baseline)
14.3.3.3.1–6 | Safety | Summary of Each Type of Categorical Clinical Laboratory Evaluation by Time (Baseline and Post-Baseline)
14.3.3.4.1–6 | ITT | Summary of Each Type of Categorical Clinical Laboratory Evaluation by Time for Each Age Classification (Baseline and Post-Baseline)
14.3.4.1.1–3 | Safety | Summary of Vital Signs by Time for each Age Classification (Open-Label Phase)
14.3.4.2.1–3 | ITT | Summary of Vital Signs by Time for each Treatment Group (Blinded Phases)
14.3.4.3.1–4 | ITT | Summary of Vital Signs by Time for each Treatment Group (Follow-Up Phase)

## 14.4 Figures

Figure Number | Population | Figure Title / Summary
14.1.1 | ITT | Kaplan-Meier Probability of Treatment Failure Over Time in Blinded Phase by Treatment
14.1.2 | Safety | Vital Signs Over Time by Subject (Open-Label and Blinded Phases)
14.1.3 | Safety | Clinical Outcomes and Adverse Events Over Time by Subject
14.1.4.1.1 | Safety | MAP over Time (Open-Label Phase)
14.1.4.1.2 | ITT | MAP over Time by Treatment (Blinded Phase)
14.1.4.2.1 | Safety | Blood Pressure (Systolic) Over Time (Open-Label Phase)
14.1.4.2.2 | ITT | Blood Pressure (Systolic) Over Time by Treatment Group (Blinded Phase)
14.1.4.3.1 | Safety | Blood Pressure (Diastolic) Over Time (Open-Label Phase)
14.1.4.3.2 | ITT | Blood Pressure (Diastolic) Over Time by Treatment Group (Blinded Phase)
14.1.4.4.1 | Safety | Pulse Over Time (Open-Label Phase)
14.1.4.4.2 | ITT | Pulse Over Time by Treatment Group (Blinded Phase)
14.1.5 | Safety | Selected Clinical Laboratory Outcomes over Time
14.1.6.1 | Safety | Hour Dose Response Model of Lactate and the AUC for Administered SNP
14.1.6.2 | Safety | Hour Dose Response Model of HCO3 and the AUC for Administered SNP
14.1.6.3 | Safety | Hour Dose Response Model of Whole Blood Cyanide and the AUC for Administered SNP

## 14.5 Narratives – Death and Other Serious Adverse Events

Table 14.1.1.1 Subject Accounting and Final Study Disposition Across All Phases by Age Classification All Enrolled^1^ Subjects

| Age Strata | | | | | Total
| 0 - < 30 days | 30 days - < 2 yrs | 2 yrs - < 6 yrs | 6 yrs - TS II^2^ | TS III - 17 yrs | Total
Number of Subjects
Enrolled | 4 | 21 | 10 | 18 | 10 | 63
Entered open-label phase | 3 (75.0%) | 20 (95.2%) | 7 (70.0%) | 12 (66.7%) | 9 (90.0%) | 51 (81.0%)
Randomized | 2 (50.0%) | 19 (90.5%) | 7 (70.0%) | 11 (61.1%) | 8 (80.0%) | 47 (74.6%)
Received blind treatment (ITT population) | 2 (50.0%) | 19 (90.5%) | 7 (70.0%) | 9 (50.0%) | 8 (80.0%) | 45 (71.4%)
Early Termination | 2 (50.0%) | 2 (9.5%) | 3 (30.0%) | 9 (50.0%) | 2 (20.0%) | 18 (28.6%)
Reported Reasons for Early Termination
Investigator judgment | 0 | 1 (4.8%) | 0 | 2 (11.1%) | 1 (10.0%) | 4 (6.3%)
Other | 2 (50.0%) | 1 (4.8%) | 3 (30.0%) | 5 (27.8%) | 1 (10.0%) | 12 (19.0%)

Note:

1 Enrolled - Subjects that provided informed consent and had at least one study procedure performed and/or received open-label Sodium Nitroprusside.

2 TS II: Tanner Stage II.

One subject was enrolled twice. The second enrollment is not included in this table.

Table 14.1.1.2 Subject Enrollment by Site and Age Classification All Enrolled Subjects

Site | Age Strata | | | | | Total; (N=63)
Site | 0 - < 30 days; (N=4) | 30 days - < 2 yrs; (N=21) | 2 yrs - < 6 yrs; (N=10) | 6 yrs - TS II^1^; (N=18) | TS III - 17 yrs; (N=10) | Total; (N=63)
01 | 0 | 0 | 2 (50.0%) | 2 (50.0%) | 0 | 4 (100%)
02 | 0 | 3 (27.3%) | 3 (27.3%) | 4 (36.4%) | 1 (9.1%) | 11 (100%)
03 | 4 (10.0%) | 15 (37.5%) | 3 (7.5%) | 11 (27.5%) | 7 (17.5%) | 40 (100%)
04 | 0 | 1 (25.0%) | 1 (25.0%) | 0 | 2 (50.0%) | 4 (100%)
05 | 0 | 2 (50.0%) | 1 (25.0%) | 1 (25.0%) | 0 | 4 (100%)

Note: N’s in the column header represent number of enrolled subjects in each age stratum for all sites.

1 TS II: Tanner Stage II.

Table 14.1.1.3 Subject Status by Site All Enrolled Subjects

Site | Did Not Enter Open-Label Phase | Entered Open-Label Phase | Randomized | Randomized, Received Blind Treatment | Early Termination | Total; (N=63)
01 | 0 | 4 (100%) | 4 (100%) | 4 (100%) | 0 | 4 (100%)
02 | 6 (54.5%) | 5 (45.5%) | 5 (45.5%) | 4 (36.4%) | 7 (63.6%) | 11 (100%)
03 | 5 (12.5%) | 35 (87.5%) | 32 (80.0%) | 31 (77.5%) | 9 (22.5%) | 40 (100%)
04 | 1 (25.0%) | 3 (75.0%) | 2 (50.0%) | 2 (50.0%) | 2 (50.0%) | 4 (100%)
05 | 0 | 4 (100%) | 4 (100%) | 4 (100%) | 0 | 4 (100%)

Note: N in the header of ‘Total’ column represents number of enrolled subjects for all sites.

Table 14.1.1.4 Number of Subjects Receiving Blinded Treatment by Site and Treatment ITT Population

Site | Treatment | | Total; (N=45)
Site | SNP; (N=24) | Placebo; (N=21) | Total; (N=45)
01 | 2 (50.0%) | 2 (50.0%) | 4 (100%)
02 | 2 (50.0%) | 2 (50.0%) | 4 (100%)
03 | 17 (54.8%) | 14 (45.2%) | 31 (100%)
04 | 2 (100%) | 0 | 2 (100%)
05 | 1 (25.0%) | 3 (75.0%) | 4 (100%)

Note: N’s in the column header represent number of ITT population in each treatment arm for all sites.

Table 14.1.2.1 Demographic Summary by Treatment ITT Population

| Treatment | | P Value
| SNP; (N=24) | Placebo; (N=21) | P Value
Age at Baseline (year)
N | 24 | 21 | 0.649
Mean (SD) | 5.94 (6.34) | 5.44 (5.92)
Median (Min, Max) | 2.92 (0.03, 16.80) | 2.83 (0.09, 16.08)
Height at Baseline (cm)
N | 24 | 21 | 0.495
Mean (SD) | 104.7 (47.9) | 95.9 (40.4)
Median (Min, Max) | 86.8 (49.0, 184.0) | 83.8 (49.5, 170.0)
Weight at Baseline (kg)
N | 24 | 21 | 0.524
Mean (SD) | 28.1 (30.1) | 22.0 (25.9)
Median (Min, Max) | 14.2 (2.7, 107.2) | 12.3 (3.2, 90.1)
Height Z Score
N | 24 | 21 | 0.158
Mean (SD) | −0.5 (1.6) | −1.6 (2.4)
Median (Min, Max) | −0.6 (−2.9, 2.9) | −1.0 (−6.0, 1.5)
Weight Z Score
N | 24 | 21 | 0.172
Mean (SD) | −0.4 (1.9) | −1.3 (2.2)
Median (Min, Max) | −0.4 (−4.8, 3.0) | −0.8 (−6.1, 1.9)
Gender
Male | 14 (58.3%) | 13 (61.9%) | 1.000
Female | 10 (41.7%) | 8 (38.1%)
Ethnicity
Hispanic or Latino | 1 (4.2%) | 1 (4.8%) | 1.000
Not Hispanic or Latino | 23 (95.8%) | 19 (90.5%)
Not reported | 0 | 1 (4.8%)
Race
Black or African American | 0 | 1 (4.8%) | 0.467
White or Caucasian | 24 (100%) | 20 (95.2%)

Note: The demographic variables are tested for significant differences in distributions between the treatment groups.

Non-parametric Kruskal-Wallis test is used for quantative variables and Fisher’s Exact test for categorical variables.

Table 14.1.2.2 Demographic Summary by Age Classification Safety Population

| Age Strata | | | | | Total; (N=52)
| 0 - < 30 days; (N=3) | 30 days - < 2 yrs; (N=21) | 2 yrs - < 6 yrs; (N=7) | 6 yrs - TS II^1^; (N=12) | TS III - 17 yrs; (N=9) | Total; (N=52)
Age at Baseline (year)
N | 3 | 21 | 7 | 12 | 9 | 52
Mean (SD) | 0.03 (0.01) | 0.51 (0.46) | 4.06 (1.34) | 10.36 (2.20) | 15.28 (1.44) | 5.79 (6.02)
Median (Min, Max) | 0.03 (0.03, 0.04) | 0.35 (0.09, 1.45) | 3.97 (2.01, 5.83) | 10.57 (6.29, 13.59) | 15.82 (12.32, 16.80) | 3.33 (0.03, 16.80)
Height at Baseline (cm)
N | 3 | 21 | 7 | 12 | 9 | 52
Mean (SD) | 51.7 (0.6) | 61.5 (10.4) | 100.0 (17.0) | 130.6 (14.7) | 168.5 (9.5) | 100.6 (44.0)
Median (Min, Max) | 52.0 (51.0, 52.0) | 59.0 (49.0, 83.8) | 105.5 (77.5, 124.5) | 129.4 (104.1, 152.4) | 167.6 (152.0, 184.0) | 87.9 (49.0, 184.0)
Weight at Baseline (kg)
N | 3 | 21 | 7 | 12 | 9 | 52
Mean (SD) | 3.8 (0.4) | 6.0 (2.7) | 16.7 (5.2) | 32.7 (16.5) | 75.0 (19.7) | 25.4 (27.7)
Median (Min, Max) | 3.7 (3.5, 4.2) | 5.3 (2.7, 12.3) | 18.0 (9.9, 24.0) | 26.1 (15.0, 64.9) | 76.4 (47.0, 107.2) | 13.7 (2.7, 107.2)
Height Z Score
N | 3 | 21 | 7 | 12 | 9 | 52
Mean (SD) | 0.6 (0.2) | −1.7 (1.9) | −0.7 (2.4) | −1.4 (2.2) | 0.1 (1.1) | −1.0 (2.0)
Median (Min, Max) | 0.8 (0.4, 0.8) | −1.7 (−6.0, 1.0) | −0.7 (−4.8, 2.9) | −1.0 (−5.7, 1.5) | 0.5 (−1.6, 1.2) | −0.7 (−6.0, 2.9)
Weight Z Score
N | 3 | 21 | 7 | 12 | 9 | 52
Mean (SD) | 0.5 (0.7) | −1.8 (1.3) | −0.4 (1.7) | −1.2 (2.7) | 1.1 (1.4) | −0.8 (2.0)
Median (Min, Max) | 0.3 (−0.1, 1.3) | −1.9 (−4.8, 0.5) | 0.4 (−3.3, 1.2) | −0.5 (−6.1, 2.0) | 1.6 (−1.9, 3.0) | −0.7 (−6.1, 3.0)
Gender
Male | 3 (100%) | 10 (47.6%) | 5 (71.4%) | 6 (50.0%) | 6 (66.7%) | 30 (57.7%)
Female | 0 | 11 (52.4%) | 2 (28.6%) | 6 (50.0%) | 3 (33.3%) | 22 (42.3%)
Ethnicity
Hispanic or Latino | 0 | 1 (4.8%) | 1 (14.3%) | 0 | 0 | 2 (3.8%)
Not Hispanic or Latino | 3 (100%) | 20 (95.2%) | 6 (85.7%) | 11 (91.7%) | 9 (100%) | 49 (94.2%)
Not reported | 0 | 0 | 0 | 1 (8.3%) | 0 | 1 (1.9%)
Race
Black or African American | 0 | 0 | 0 | 1 (8.3%) | 1 (11.1%) | 2 (3.8%)
White or Caucasian | 3 (100%) | 21 (100%) | 7 (100%) | 11 (91.7%) | 8 (88.9%) | 50 (96.2%)

Note:

1 TS II: Tanner Stage II.

Table 14.1.2.3 Demographic Comparison of ITT and Non-ITT Enrollments Safety Population

| Subject Status | | P Value^1^
| Non-ITT; (N=6) | ITT; N=46) | P Value^1^
Age at Baseline (year)
N | 6 | 46 | 0.841
Mean (SD) | 7.33 (6.00) | 5.59 (6.06)
Median (Min, Max) | 9.37 (0.03, 12.75) | 2.42 (0.03, 16.80)
Height at Baseline (cm)
N | 6 | 46 | 0.954
Mean (SD) | 106.9 (46.0) | 99.8 (44.1)
Median (Min, Max) | 120.8 (50.0, 152.0) | 83.2 (49.0, 184.0)
Weight at Baseline (kg)
N | 6 | 46 | 0.797
Mean (SD) | 29.7 (28.1) | 24.9 (27.9)
Median (Min, Max) | 20.9 (3.5, 64.9) | 11.9 (2.7, 107.2)
Height Z Score
N | 6 | 46 | 0.345
Mean (SD) | −1.5 (1.7) | −1.0 (2.0)
Median (Min, Max) | −1.1 (−3.5, 0.4) | −0.7 (−6.0, 2.9)
Weight Z Score
N | 6 | 46 | 0.667
Mean (SD) | −0.7 (2.4) | −0.8 (2.0)
Median (Min, Max) | −0.8 (−4.4, 2.0) | −0.7 (−6.1, 3.0)
Gender
Male | 2 (33.3%) | 28 (60.9%) | 0.382
Female | 4 (66.7%) | 18 (39.1%)
Ethnicity
Hispanic or Latino | 0 | 2 (4.3%) | 1.000
Not Hispanic or Latino | 6 (100%) | 43 (93.5%)
Not reported | 0 | 1 (2.2%)
Race
Black or African American | 1 (16.7%) | 1 (2.2%) | 0.219
White or Caucasian | 5 (83.3%) | 45 (97.8%)

Note:

1 The demographic variables are tested for significant differences in distributions between groups.

Non-parametric Kruskal-Wallis test is used for quantative variables and Fisher’s Exact test for categorical variables.

Table 14.1.3 Summary of Prior Medications by WHO Drug Class and Age Classification Safety Population

WHO Drug Class; Medication Name | Age Strata | | | | | | | | | | All Enrollments; (N=52)
WHO Drug Class; Medication Name | ≥ 0 - < 30 days; (N=3) | | ≥ 30 days - < 2 yrs; (N=21) | | ≥ 2 yrs - < 6 yrs; (N=7) | | ≥ 6 yrs - TS II^1^; (N=12) | | ≥ TS III - 17 yrs; (N=9) | | All Enrollments; (N=52)
WHO Drug Class; Medication Name | Enrollments With Medication N (%) | Total Medications N | Enrollments With Medication N (%) | Total Medications N | Enrollments With Medication N (%) | Total Medications N | Enrollments With Medication N (%) | Total Medications N | Enrollments With Medication N (%) | Total Medications N | Enrollments With Medication N (%) | Total Medications N
ALIMENTARY TRACT AND METABOLISM | 2 (66.7%) | 2 | 5 (23.8%) | 7 | 2 (28.6%) | 5 | 5 (41.7%) | 12 | 0 | 0 | 14 (26.9%) | 26
BISACODYL | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
CALCIUM CHLORIDE | 0 | 0 | 2 (9.5%) | 2 | 1 (14.3%) | 1 | 2 (16.7%) | 2 | 0 | 0 | 5 (9.6%) | 5
CALCIUM GLUCONATE | 2 (66.7%) | 2 | 2 (9.5%) | 2 | 1 (14.3%) | 1 | 2 (16.7%) | 2 | 0 | 0 | 7 (13.5%) | 7
DOCUSATE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
GLYCOPYRRONIUM BROMIDE | 0 | 0 | 1 (4.8%) | 1 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2
MACROGOL | 0 | 0 | 0 | 0 | 0 | 0 | 2 (16.7%) | 2 | 0 | 0 | 2 (3.8%) | 2
MAGNESIUM SULFATE | 0 | 0 | 1 (4.8%) | 1 | 1 (14.3%) | 1 | 1 (8.3%) | 1 | 0 | 0 | 3 (5.8%) | 3
ONDANSETRON | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
PANTOPRAZOLE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
POTASSIUM CHLORIDE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
SODIUM BICARBONATE | 0 | 0 | 1 (4.8%) | 1 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2
ANTIINFECTIVES FOR SYSTEMIC USE | 0 | 0 | 2 (9.5%) | 2 | 1 (14.3%) | 1 | 2 (16.7%) | 4 | 0 | 0 | 5 (9.6%) | 7
CEFAZOLIN | 0 | 0 | 2 (9.5%) | 2 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 3 (5.8%) | 3
CLINDAMYCIN | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
OSELTAMIVIR | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
PIP/TAZO | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
VANCOMYCIN | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
BLOOD AND BLOOD FORMING ORGA | 0 | 0 | 3 (14.3%) | 6 | 1 (14.3%) | 1 | 2 (16.7%) | 2 | 1 (11.1%) | 1 | 7 (13.5%) | 10
ELECTROLYTE | 0 | 0 | 3 (14.3%) | 4 | 0 | 0 | 1 (8.3%) | 1 | 1 (11.1%) | 1 | 5 (9.6%) | 6
ELECTROLYTES WITH CARBOHYDRATES | 0 | 0 | 1 (4.8%) | 2 | 1 (14.3%) | 1 | 1 (8.3%) | 1 | 0 | 0 | 3 (5.8%) | 4
BLOOD AND BLOOD FORMING ORGANS | 1 (33.3%) | 1 | 6 (28.6%) | 19 | 4 (57.1%) | 11 | 3 (25%) | 6 | 0 | 0 | 14 (26.9%) | 37
ACETYLSALICYLIC ACID | 0 | 0 | 2 (9.5%) | 2 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 3 (5.8%) | 3
ALBUMIN | 1 (33.3%) | 1 | 2 (9.5%) | 2 | 2 (28.6%) | 2 | 0 | 0 | 0 | 0 | 5 (9.6%) | 5
AMINOCAPROIC ACID | 0 | 0 | 2 (9.5%) | 2 | 1 (14.3%) | 1 | 2 (16.7%) | 2 | 0 | 0 | 5 (9.6%) | 5
EPINEPHRINE | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
FACTOR VIII (ANTIHAEMOPHILIC FACTOR) | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
HEPARIN | 0 | 0 | 2 (9.5%) | 3 | 1 (14.3%) | 1 | 1 (8.3%) | 1 | 0 | 0 | 4 (7.7%) | 5
HEPARIN SODIUM | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
MANNITOL | 0 | 0 | 2 (9.5%) | 2 | 2 (28.6%) | 2 | 0 | 0 | 0 | 0 | 4 (7.7%) | 4
PLASMA | 0 | 0 | 3 (14.3%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (5.8%) | 3
PLASMA-LYTE | 0 | 0 | 2 (9.5%) | 2 | 1 (14.3%) | 1 | 1 (8.3%) | 1 | 0 | 0 | 4 (7.7%) | 4
PLATELETS | 0 | 0 | 1 (4.8%) | 1 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2
RED BLOOD CELLS | 0 | 0 | 1 (4.8%) | 1 | 1 (14.3%) | 1 | 1 (8.3%) | 1 | 0 | 0 | 3 (5.8%) | 3
CARDIOVASCULAR SYSTEM | 3 (100%) | 11 | 17 (81%) | 74 | 6 (85.7%) | 13 | 11 (91.7%) | 35 | 6 (66.7%) | 12 | 43 (82.7%) | 145
ALPROSTADIL | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
AMIODARONE | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
AMLODIPINE | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 2 (16.7%) | 2 | 0 | 0 | 3 (5.8%) | 3
ATENOLOL | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
ATROPINE | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
CAPTOPRIL | 0 | 0 | 4 (19%) | 4 | 0 | 0 | 0 | 0 | 0 | 0 | 4 (7.7%) | 4
CARVEDILOL | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
CHLOROTHIAZIDE | 1 (33.3%) | 1 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2
CLONIDINE | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 2 (3.8%) | 2
DEXTROSE W/DOPAMINE | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
DIGOXIN | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
DOPAMINE | 3 (100%) | 4 | 12 (57.1%) | 12 | 2 (28.6%) | 2 | 5 (41.7%) | 5 | 3 (33.3%) | 3 | 25 (48.1%) | 26
ENALAPRIL | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
EPHEDRINE | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 2 (3.8%) | 2
EPINEPHRINE | 1 (33.3%) | 1 | 9 (42.9%) | 9 | 1 (14.3%) | 1 | 5 (41.7%) | 5 | 1 (11.1%) | 1 | 17 (32.7%) | 17
ESMOLOL | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (22.2%) | 2 | 2 (3.8%) | 2
FUROSEMIDE | 2 (66.7%) | 2 | 10 (47.6%) | 11 | 2 (28.6%) | 2 | 4 (33.3%) | 4 | 0 | 0 | 18 (34.6%) | 19
GLYCERYL TRINITRATE | 0 | 0 | 5 (23.8%) | 5 | 0 | 0 | 1 (8.3%) | 1 | 1 (11.1%) | 1 | 7 (13.5%) | 7
HYDRALAZINE | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 1 (8.3%) | 1 | 0 | 0 | 2 (3.8%) | 2
HYDROCHLOROTHIAZIDE | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
LABETALOL | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 2 (3.8%) | 2
LISINOPRIL | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 1 (1.9%) | 1
LOSARTAN | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
MAGNESIUM SULFATE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
METOLAZONE | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
METOPROLOL SUCCINATE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 1 (1.9%) | 1
MILRINONE | 2 (66.7%) | 2 | 13 (61.9%) | 13 | 0 | 0 | 6 (50%) | 6 | 2 (22.2%) | 2 | 23 (44.2%) | 23
NICARDIPINE | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 1 (8.3%) | 1 | 0 | 0 | 2 (3.8%) | 2
NITROPRUSSIDE | 0 | 0 | 3 (14.3%) | 3 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 4 (7.7%) | 4
NOREPINEPHRINE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
OTHER VASODILATORS USED IN CARDIAC DISEASES | 0 | 0 | 3 (14.3%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (5.8%) | 3
PAPAVERINE | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
PHENYLEPHRINE | 0 | 0 | 2 (9.5%) | 2 | 1 (14.3%) | 1 | 2 (16.7%) | 2 | 0 | 0 | 5 (9.6%) | 5
PROPRANOLOL | 0 | 0 | 2 (9.5%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2
SPIRONOLACTONE | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 2 (3.8%) | 2
DERMATOLOGICALS | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
EMLA | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
MUSCULO-SKELETAL SYSTEM | 0 | 0 | 6 (28.6%) | 9 | 2 (28.6%) | 3 | 4 (33.3%) | 5 | 2 (22.2%) | 2 | 14 (26.9%) | 19
CISATRACURIUM BESILATE | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 2 (3.8%) | 2
PANCURONIUM | 0 | 0 | 3 (14.3%) | 3 | 1 (14.3%) | 1 | 1 (8.3%) | 1 | 1 (11.1%) | 1 | 6 (11.5%) | 6
PANCURONIUM BROMIDE | 0 | 0 | 1 (4.8%) | 1 | 1 (14.3%) | 2 | 0 | 0 | 0 | 0 | 2 (3.8%) | 3
ROCURONIUM | 0 | 0 | 3 (14.3%) | 4 | 0 | 0 | 1 (8.3%) | 1 | 1 (11.1%) | 1 | 5 (9.6%) | 6
VECURONIUM | 0 | 0 | 0 | 0 | 0 | 0 | 2 (16.7%) | 2 | 0 | 0 | 2 (3.8%) | 2
NERVOUS SYSTEM | 3 (100%) | 12 | 19 (90.5%) | 106 | 6 (85.7%) | 25 | 12 (100%) | 61 | 9 (100%) | 49 | 49 (94.2%) | 253
BUPIVACAINE | 0 | 0 | 1 (4.8%) | 1 | 2 (28.6%) | 2 | 1 (8.3%) | 1 | 0 | 0 | 4 (7.7%) | 4
BUPIVACAINE W/FENTANYL | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
CHLORAL HYDRATE | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 2 (3.8%) | 2
DESFLURANE | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 1 (8.3%) | 1 | 1 (11.1%) | 1 | 3 (5.8%) | 3
DEXMEDETOMIDINE | 1 (33.3%) | 1 | 12 (57.1%) | 12 | 0 | 0 | 5 (41.7%) | 5 | 6 (66.7%) | 6 | 24 (46.2%) | 24
DEXMEDETOMIDINE HYDROCHLORIDE | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
DIAZEPAM | 0 | 0 | 3 (14.3%) | 3 | 0 | 0 | 1 (8.3%) | 1 | 2 (22.2%) | 2 | 6 (11.5%) | 6
DIPHENHYDRAMINE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 2 (22.2%) | 2 | 3 (5.8%) | 3
DIPHENHYDRAMINE HYDROCHLORIDE | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 2 (3.8%) | 2
FENTANYL | 3 (100%) | 3 | 8 (38.1%) | 9 | 5 (71.4%) | 6 | 8 (66.7%) | 8 | 1 (11.1%) | 1 | 25 (48.1%) | 27
FENTANYL CITRATE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (22.2%) | 2 | 2 (3.8%) | 2
GALENIC/PARACETAMOL/CODEINE/ | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
HYDROMORPHONE | 0 | 0 | 1 (4.8%) | 1 | 1 (14.3%) | 1 | 4 (33.3%) | 4 | 5 (55.6%) | 5 | 11 (21.2%) | 11
ISOFLURANE | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 2 (3.8%) | 2
KETAMINE | 0 | 0 | 6 (28.6%) | 6 | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 7 (13.5%) | 7
LIDOCAINE | 0 | 0 | 2 (9.5%) | 2 | 0 | 0 | 3 (25%) | 3 | 1 (11.1%) | 1 | 6 (11.5%) | 6
LORAZEPAM | 1 (33.3%) | 1 | 4 (19%) | 4 | 2 (28.6%) | 2 | 4 (33.3%) | 5 | 0 | 0 | 11 (21.2%) | 12
LORTAB | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
METHADONE | 0 | 0 | 6 (28.6%) | 6 | 0 | 0 | 3 (25%) | 3 | 4 (44.4%) | 4 | 13 (25%) | 13
MIDAZOLAM | 2 (66.7%) | 2 | 12 (57.1%) | 12 | 4 (57.1%) | 5 | 6 (50%) | 6 | 3 (33.3%) | 3 | 27 (51.9%) | 28
MORPHINE | 1 (33.3%) | 1 | 11 (52.4%) | 12 | 3 (42.9%) | 3 | 7 (58.3%) | 7 | 2 (22.2%) | 2 | 24 (46.2%) | 25
MORPHINE HYDROCHLORIDE | 1 (33.3%) | 1 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2
NALBUPHINE HYDROCHLORIDE | 0 | 0 | 2 (9.5%) | 2 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 3 (5.8%) | 3
NEOSTIGMINE | 0 | 0 | 1 (4.8%) | 1 | 2 (28.6%) | 2 | 0 | 0 | 0 | 0 | 3 (5.8%) | 3
NITROUS OXIDE | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
OXCARBAZEPINE | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
PARACETAMOL | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
PREGABALIN | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 1 (1.9%) | 1
PROPOFOL | 1 (33.3%) | 1 | 13 (61.9%) | 13 | 1 (14.3%) | 1 | 5 (41.7%) | 5 | 7 (77.8%) | 7 | 27 (51.9%) | 27
REMIFENTANIL | 1 (33.3%) | 1 | 9 (42.9%) | 9 | 0 | 0 | 2 (16.7%) | 2 | 4 (44.4%) | 4 | 16 (30.8%) | 16
ROPIVACAINE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 2 (22.2%) | 2 | 3 (5.8%) | 3
SEVOFLURANE | 0 | 0 | 4 (19%) | 4 | 1 (14.3%) | 2 | 2 (16.7%) | 2 | 0 | 0 | 7 (13.5%) | 8
THIOPENTAL SODIUM | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 2 (3.8%) | 2
VALIUM | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 1 (8.3%) | 1 | 2 (22.2%) | 2 | 4 (7.7%) | 4
RESPIRATORY SYSTEM | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 1 (8.3%) | 3 | 0 | 0 | 2 (3.8%) | 4
FLUTICASONE PROPIONATE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
MOMETASONE FUROATE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
MONTELUKAST SODIUM | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
SALBUTAMOL | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
SENSORY ORGANS | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
CIPROFLOXACIN HYDROCHLORIDE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
SYSTEMIC HORMONAL PREP.,EXCL.SEX HORM.AND INSULIN | 0 | 0 | 6 (28.6%) | 7 | 1 (14.3%) | 2 | 2 (16.7%) | 4 | 0 | 0 | 9 (17.3%) | 13
DEXAMETHASONE | 0 | 0 | 4 (19%) | 5 | 1 (14.3%) | 2 | 1 (8.3%) | 1 | 0 | 0 | 6 (11.5%) | 8
LEVOTHYROXINE SODIUM | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
LIOTHYRONINE | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
METHYLPREDNISOLONE | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 2 (3.8%) | 2
PREDNISONE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
VARIOUS | 0 | 0 | 2 (9.5%) | 2 | 2 (28.6%) | 2 | 2 (16.7%) | 2 | 0 | 0 | 6 (11.5%) | 6
GLUCOSE | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
PROTAMINE | 0 | 0 | 2 (9.5%) | 2 | 1 (14.3%) | 1 | 1 (8.3%) | 1 | 0 | 0 | 4 (7.7%) | 4
PROTAMINE SULFATE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1

Note:

1 TS II: Tanner Stage II.

Table 14.1.4 Summary of Protocol Deviations by Site All Enrolled Subjects

Site | Study Medication Administration | Protocol Procedure/Assessment | Other | Total
Total | 10 | 67 | 4 | 81
01 | 1 | 18 | 0 | 19
02 | 2 | 23 | 3 | 28
03 | 2 | 7 | 1 | 10
04 | 4 | 6 | 0 | 10
05 | 1 | 13 | 0 | 14

Table 14.1.5 Demographic Summary by Age Classification Enrolled Subjects Not Included in Safety Population

| Age Strata | | | | | Total; (N=12)
| 0 - < 30 days; (N=1) | 30 days - < 2 yrs; (N=1) | 2 yrs - < 6 yrs; (N=3) | 6 yrs - TS II^1^; (N=6) | TS III - 17 yrs; (N=1) | Total; (N=12)
Age at Baseline (year)
N | 1 | 1 | 3 | 6 | 1 | 12
Mean (SD) | 0.02 | 0.79 | 4.22 (1.07) | 10.86 (1.36) | 15.10 | 7.81 (4.94)
Median (Min, Max) | 0.02 | 0.79 | 4.01 (3.27, 5.39) | 10.99 (8.56, 12.21) | 15.10 | 9.41 (0.02, 15.10)
Height at Baseline (cm)
N | 1 | 1 | 3 | 4 | 1 | 10
Mean (SD) | 48.1 | 72.0 | 108.2 (16.3) | 145.8 (11.7) | 165.0 | 119.3 (38.7)
Median (Min, Max) | 48.1 | 72.0 | 101.9 (96.0, 126.7) | 147.5 (130.0, 158.2) | 165.0 | 128.4 (48.1, 165.0)
Weight at Baseline (kg)
N | 1 | 1 | 3 | 4 | 1 | 10
Mean (SD) | 3.6 | 7.5 | 22.4 (11.3) | 49.1 (14.4) | 70.8 | 34.5 (24.0)
Median (Min, Max) | 3.6 | 7.5 | 16.0 (15.8, 35.4) | 47.1 (34.2, 67.9) | 70.8 | 34.8 (3.6, 70.8)
Height Z Score
N | 1 | 1 | 3 | 4 | 1 | 10
Mean (SD) | −0.7 | 0.5 | 1.0 (1.8) | 0.6 (1.3) | −0.7 | 0.4 (1.3)
Median (Min, Max) | −0.7 | 0.5 | 0.2 (−0.3, 3.0) | 0.5 (−0.8, 2.1) | −0.7 | 0.0 (−0.8, 3.0)
Weight Z Score
N | 1 | 1 | 3 | 4 | 1 | 10
Mean (SD) | 0.1 | −1.3 | 1.2 (1.6) | 1.3 (1.7) | 1.1 | 0.9 (1.5)
Median (Min, Max) | 0.1 | −1.3 | 0.6 (0.0, 2.9) | 2.0 (−1.2, 2.5) | 1.1 | 0.9 (−1.3, 2.9)
Gender
Male | 1 (100%) | 0 | 1 (33.3%) | 4 (66.7%) | 1 (100%) | 7 (58.3%)
Female | 0 | 1 (100%) | 2 (66.7%) | 2 (33.3%) | 0 | 5 (41.7%)
Ethnicity
Not Hispanic or Latino | 1 (100%) | 1 (100%) | 3 (100%) | 6 (100%) | 1 (100%) | 12 (100%)
Race
Black or African American | 0 | 0 | 0 | 1 (16.7%) | 0 | 1 (8.3%)
White or Caucasian | 1 (100%) | 1 (100%) | 3 (100%) | 5 (83.3%) | 1 (100%) | 11 (91.7%)

Note:

1 TS II: Tanner Stage II.

Table 14.1.6.1 Operative Information Summary by Age Classification Safety Population

| Age Strata | | | | | Total; (N=52)
| 0 - < 30 days; (N=3) | 30 days - < 2 yrs; (N=21) | 2 yrs - < 6 yrs; (N=7) | 6 yrs - TS II^1^; (N=12) | TS III - 17 yrs; (N=9) | Total; (N=52)
Anesthesia Length (hour)
N | 3 | 16 | 4 | 7 | 8 | 38
Mean (SD) | 4.80 (2.20) | 5.07 (1.39) | 5.72 (2.63) | 7.05 (2.30) | 6.86 (2.34) | 5.86 (2.09)
Median (Min, Max) | 3.82 (3.27, 7.32) | 5.26 (2.75, 7.48) | 4.85 (3.68, 9.50) | 7.02 (4.00, 11.45) | 5.89 (4.50, 12.00) | 5.73 (2.75, 12.00)
Incision Length (hour)
N | 3 | 17 | 5 | 7 | 7 | 39
Mean (SD) | 2.7 (2.2) | 2.8 (1.2) | 8.8 (12.0) | 5.2 (2.2) | 3.5 (0.9) | 4.1 (4.6)
Median (Min, Max) | 1.5 (1.4, 5.2) | 2.9 (1.0, 5.4) | 3.5 (1.1, 30.1) | 5.0 (3.0, 9.7) | 3.2 (2.8, 5.4) | 3.2 (1.0, 30.1)
Estimated Blood Loss (mL)
N | 3 | 16 | 4 | 5 | 7 | 35
Mean (SD) | 65.7 (51.7) | 104.8 (87.8) | 154.3 (117.4) | 598.0 (816.4) | 207.9 (231.0) | 198.1 (349.3)
Median (Min, Max) | 42.0 (30.0, 125.0) | 102.5 (1.0, 250.0) | 178.5 (10.0, 250.0) | 300.0 (40.0, 2000) | 200.0 (5.0, 700.0) | 107.0 (1.0, 2000)
Estimated Fluid Intake (mL)
N | 3 | 17 | 5 | 7 | 8 | 40
Mean (SD) | 126.3 (83.0) | 346.7 (346.2) | 968.4 (876.0) | 1906 (3453) | 2215 (833.4) | 1055 (1667)
Median (Min, Max) | 92.0 (66.0, 221.0) | 220.0 (44.0, 1371) | 1037 (24.0, 2130) | 670.0 (204.0, 9689) | 2401 (500.0, 2963) | 395.0 (24.0, 9689)
Estimated Fluid Output (mL)
N | 3 | 17 | 5 | 7 | 8 | 40
Mean (SD) | 75.0 (86.7) | 163.6 (142.5) | 366.8 (273.1) | 1027 (832.4) | 1581 (679.4) | 617.0 (739.5)
Median (Min, Max) | 30.0 (20.0, 175.0) | 132.0 (0.0, 495.0) | 322.0 (70.0, 747.0) | 822.0 (150.0, 2600) | 1730 (350.0, 2500) | 234.5 (0.0, 2600)
Type of Surgical Procedure
No Surgery | 0 | 3 (15.0%) | 2 (28.6%) | 5 (41.7%) | 1 (11.1%) | 11 (21.6%)
Repair of coarctation of the aorta | 2 (66.7%) | 4 (20.0%) | 1 (14.3%) | 1 (8.3%) | 4 (44.4%) | 12 (23.5%)
Other | 1 (33.3%) | 13 (65.0%) | 4 (57.1%) | 6 (50.0%) | 4 (44.4%) | 28 (54.9%)

Note:

1 TS II: Tanner Stage II.

Table 14.1.6.2 Operative Information Summary by Treatment Group ITT Population

| Treatment | | P Value
| SNP; (N=24) | Placebo; (N=21) | P Value
Anesthesia Length (hour)
N | 15 | 17 | 0.692
Mean (SD) | 5.97 (2.11) | 5.51 (1.83)
Median (Min, Max) | 5.62 (3.53, 12.00) | 5.72 (2.75, 9.50)
Incision Length (hour)
N | 16 | 17 | 0.773
Mean (SD) | 4.8 (6.9) | 3.4 (1.5)
Median (Min, Max) | 3.2 (1.0, 30.1) | 3.3 (1.1, 6.4)
Estimated Blood Loss (mL)
N | 14 | 16 | 0.297
Mean (SD) | 141.6 (182.0) | 173.6 (145.4)
Median (Min, Max) | 75.0 (10.0, 700.0) | 166.5 (1.0, 600.0)
Estimated Fluid Intake (mL)
N | 17 | 17 | 1.000
Mean (SD) | 927.8 (1052) | 879.4 (890.0)
Median (Min, Max) | 300.0 (24.0, 2963) | 440.0 (44.0, 2500)
Estimated Fluid Output (mL)
N | 17 | 17 | 0.513
Mean (SD) | 514.3 (665.6) | 643.4 (758.5)
Median (Min, Max) | 175.0 (20.0, 1980) | 183.0 (0.0, 2500)
Type of Surgical Procedure
No Surgery | 7 (29.2%) | 4 (19.0%) | 0.729
Repair of coarctation of the aorta | 5 (20.8%) | 5 (23.8%)
Other | 12 (50.0%) | 12 (57.1%)

Note: The demographic variables are tested for significant differences in distributions between the treatment groups.

Non-parametric Kruskal-Wallis test is used for quantative variables and Fisher’s Exact test for categorical variables.

Table 14.1.7.1 Summary of Abnormal Baseline Physical Examination Findings by Age Classification Safety Population

| Age Strata | | | | | Total; (N=52)
| 0 - < 30 days; (N=3) | 30 days - < 2 yrs; (N=21) | 2 yrs - < 6 yrs; (N=7) | 6 yrs - TS II^1^; (N=12) | TS III - 17 yrs; (N=9) | Total; (N=52)
Body System
ENT (Ears, nose, throat) | 1 (33.3%) | 12 (57.1%) | 2 (28.6%) | 4 (33.3%) | 3 (33.3%) | 22 (42.3%)
Eyes | 0 | 3 (14.3%) | 0 | 3 (25%) | 1 (11.1%) | 7 (13.5%)
Respiratory system | 3 (100%) | 13 (61.9%) | 4 (57.1%) | 8 (66.7%) | 6 (66.7%) | 34 (65.4%)
Cardiovascular system | 3 (100%) | 19 (90.5%) | 3 (42.9%) | 11 (91.7%) | 6 (66.7%) | 42 (80.8%)
Gastrointestinal system | 1 (33.3%) | 13 (61.9%) | 4 (57.1%) | 8 (66.7%) | 5 (55.6%) | 31 (59.6%)
Urinary system | 2 (66.7%) | 15 (71.4%) | 3 (42.9%) | 6 (50%) | 5 (55.6%) | 31 (59.6%)
Reproductive system | 0 | 0 | 2 (28.6%) | 3 (25%) | 0 | 5 (9.6%)
Blood & lymphatic system | 0 | 5 (23.8%) | 0 | 2 (16.7%) | 2 (22.2%) | 9 (17.3%)
Endocrine/metabolic | 2 (66.7%) | 5 (23.8%) | 1 (14.3%) | 3 (25%) | 0 | 11 (21.2%)
Musculoskeletal system | 0 | 1 (4.8%) | 2 (28.6%) | 3 (25%) | 3 (33.3%) | 9 (17.3%)
Dermatologic system | 0 | 10 (47.6%) | 3 (42.9%) | 5 (41.7%) | 4 (44.4%) | 22 (42.3%)
Neurological system | 0 | 12 (57.1%) | 4 (57.1%) | 8 (66.7%) | 5 (55.6%) | 29 (55.8%)
Psychiatric | 1 (33.3%) | 2 (9.5%) | 2 (28.6%) | 1 (8.3%) | 1 (11.1%) | 7 (13.5%)
Other | 0 | 2 (9.5%) | 0 | 2 (16.7%) | 1 (11.1%) | 5 (9.6%)

Note:

1 TS II: Tanner Stage II

Enrollments are counted once at each body system level.

Table 14.1.7.2 Summary of Abnormal Baseline Physical Examination Findings by Treatment Group ITT Population

Body System | Treatment Group | | Total; (N=45) | P Value
Body System | SNP; (N=24) | Placebo; (N=21) | Total; (N=45) | P Value
ENT (Ears, nose, throat) | 12 (50%) | 8 (38.1%) | 20 (44.4%) | 0.550
Eyes | 5 (20.8%) | 1 (4.8%) | 6 (13.3%) | 0.193
Respiratory system | 16 (66.7%) | 12 (57.1%) | 28 (62.2%) | 0.552
Cardiovascular system | 20 (83.3%) | 16 (76.2%) | 36 (80%) | 0.713
Gastrointestinal system | 14 (58.3%) | 13 (61.9%) | 27 (60%) | 1.000
Urinary system | 14 (58.3%) | 12 (57.1%) | 26 (57.8%) | 1.000
Reproductive system | 2 (8.3%) | 3 (14.3%) | 5 (11.1%) | 0.652
Blood & lymphatic system | 5 (20.8%) | 3 (14.3%) | 8 (17.8%) | 0.705
Endocrine/metabolic | 5 (20.8%) | 3 (14.3%) | 8 (17.8%) | 0.705
Musculoskeletal system | 4 (16.7%) | 4 (19%) | 8 (17.8%) | 1.000
Dermatologic system | 7 (29.2%) | 13 (61.9%) | 20 (44.4%) | 0.038
Neurological system | 13 (54.2%) | 10 (47.6%) | 23 (51.1%) | 0.768
Psychiatric | 4 (16.7%) | 2 (9.5%) | 6 (13.3%) | 0.670
Other | 3 (12.5%) | 2 (9.5%) | 5 (11.1%) | 1.000

Note:

1 TS II: Tanner Stage II

Subjects are counted once at each body system level.

Equivalence of abnormality rates between treatment groups calculated using Fisher’s Exact test.

Table 14.1.8.1 Descriptive Statistics for Infusion Rate (mcg/kg/min) By Time and Age Group (Open-Label Phase) Safety Population

Assessments/Statistics | Age Strata | | | | | Total; (N=52)
Assessments/Statistics | 0 - < 30 days; (N=3) | 30 days - < 2 yrs; (N=21) | 2 yrs - < 6 yrs; (N=7) | 6 yrs - TS II^1^; (N=12) | TS III - 17 yrs; (N=9) | Total; (N=52)
0 or 1 min (first record in open-label phase)
N | 3 | 21 | 7 | 12 | 9 | 52
Mean (SD) | 0.3 (0.0) | 0.5 (0.3) | 0.4 (0.2) | 0.6 (0.8) | 0.4 (0.2) | 0.5 (0.4)
Median (Min, Max) | 0.3 (0.3, 0.3) | 0.3 (0.3, 1.0) | 0.3 (0.1, 0.5) | 0.3 (0.3, 3.0) | 0.3 (0.3, 1.0) | 0.3 (0.1, 3.0)
5 mins
N | 3 | 21 | 7 | 12 | 9 | 52
Mean (SD) | 0.3 (0.0) | 0.6 (0.3) | 0.6 (0.3) | 1.1 (1.0) | 0.7 (0.3) | 0.7 (0.6)
Median (Min, Max) | 0.3 (0.3, 0.3) | 0.5 (0.3, 1.0) | 0.5 (0.1, 1.0) | 0.6 (0.3, 3.0) | 0.5 (0.3, 1.0) | 0.5 (0.1, 3.0)
10 mins
N | 3 | 21 | 7 | 12 | 9 | 52
Mean (SD) | 0.3 (0.1) | 0.9 (0.6) | 0.8 (0.6) | 1.5 (1.2) | 0.8 (0.4) | 1.0 (0.8)
Median (Min, Max) | 0.3 (0.3, 0.4) | 0.6 (0.3, 2.0) | 0.5 (0.1, 2.0) | 1.0 (0.3, 4.0) | 1.0 (0.3, 1.5) | 0.8 (0.1, 4.0)
15 mins
N | 3 | 21 | 7 | 12 | 9 | 52
Mean (SD) | 0.5 (0.1) | 1.2 (1.0) | 0.7 (0.6) | 1.7 (1.1) | 0.9 (0.5) | 1.2 (1.0)
Median (Min, Max) | 0.5 (0.4, 0.6) | 1.0 (0.3, 5.0) | 0.5 (0.1, 2.0) | 1.3 (0.3, 3.5) | 1.0 (0.3, 1.5) | 1.0 (0.1, 5.0)
20 mins
N | 3 | 21 | 7 | 12 | 9 | 52
Mean (SD) | 0.5 (0.1) | 1.3 (0.8) | 0.7 (0.6) | 1.7 (1.2) | 0.9 (0.5) | 1.2 (0.9)
Median (Min, Max) | 0.5 (0.4, 0.6) | 1.0 (0.3, 3.0) | 0.5 (0.1, 2.0) | 1.3 (0.2, 3.5) | 1.0 (0.3, 1.5) | 1.0 (0.1, 3.5)
25 mins
N | 3 | 21 | 7 | 12 | 8 | 51
Mean (SD) | 0.5 (0.1) | 1.5 (1.0) | 0.9 (0.6) | 1.6 (1.2) | 1.1 (0.6) | 1.3 (1.0)
Median (Min, Max) | 0.5 (0.4, 0.6) | 1.0 (0.5, 4.0) | 0.8 (0.1, 2.1) | 1.0 (0.2, 3.5) | 1.0 (0.3, 2.0) | 1.0 (0.1, 4.0)
30 mins
N | 3 | 21 | 7 | 12 | 8 | 51
Mean (SD) | 0.5 (0.1) | 1.7 (1.1) | 0.9 (0.7) | 1.6 (1.4) | 1.2 (0.6) | 1.4 (1.1)
Median (Min, Max) | 0.5 (0.5, 0.6) | 1.5 (0.5, 4.5) | 0.8 (0.1, 2.1) | 1.0 (0.2, 4.0) | 1.3 (0.3, 2.0) | 1.0 (0.1, 4.5)
1 hour
N | 3 | 21 | 7 | 12 | 8 | 51
Mean (SD) | 1.6 (0.8) | 2.3 (1.6) | 1.3 (1.1) | 1.9 (1.7) | 1.4 (1.0) | 1.9 (1.4)
Median (Min, Max) | 2.0 (0.7, 2.0) | 2.0 (0.2, 6.0) | 0.8 (0.1, 3.0) | 1.0 (0.3, 5.0) | 1.2 (0.3, 3.5) | 1.5 (0.1, 6.0)
2 hours
N | 3 | 20 | 7 | 12 | 8 | 50
Mean (SD) | 1.9 (1.9) | 3.0 (1.9) | 1.7 (1.2) | 2.0 (1.6) | 1.6 (1.0) | 2.3 (1.7)
Median (Min, Max) | 1.5 (0.3, 4.0) | 2.8 (0.5, 6.5) | 1.5 (0.1, 3.5) | 1.0 (0.3, 4.5) | 1.4 (0.3, 3.5) | 2.0 (0.1, 6.5)
3 hours
N | 3 | 20 | 7 | 12 | 8 | 50
Mean (SD) | 3.0 (2.9) | 3.2 (1.9) | 2.1 (1.6) | 1.9 (1.7) | 1.8 (1.3) | 2.5 (1.8)
Median (Min, Max) | 2.8 (0.3, 6.0) | 3.0 (0.5, 6.5) | 2.0 (0.2, 5.0) | 1.0 (0.3, 5.0) | 1.2 (0.5, 4.5) | 2.0 (0.2, 6.5)
4 hours
N | 2 | 20 | 7 | 11 | 8 | 48
Mean (SD) | 6.5 (0.0) | 3.3 (1.9) | 2.3 (1.4) | 2.0 (1.4) | 1.9 (1.5) | 2.7 (1.9)
Median (Min, Max) | 6.5 (6.5, 6.5) | 3.0 (0.5, 6.5) | 3.0 (0.2, 4.0) | 2.0 (0.3, 4.6) | 1.4 (0.4, 5.0) | 2.5 (0.2, 6.5)
5 hours
N | 2 | 20 | 7 | 11 | 8 | 48
Mean (SD) | 6.8 (0.4) | 3.3 (1.8) | 2.6 (1.8) | 1.9 (1.4) | 1.9 (1.6) | 2.8 (1.9)
Median (Min, Max) | 6.8 (6.5, 7.0) | 3.0 (1.2, 7.0) | 3.0 (0.2, 5.0) | 1.5 (0.3, 4.7) | 1.5 (0.4, 5.5) | 2.5 (0.2, 7.0)
6 hours
N | 2 | 20 | 7 | 10 | 8 | 47
Mean (SD) | 6.5 (0.7) | 3.4 (1.7) | 3.1 (2.0) | 2.1 (1.5) | 2.1 (1.7) | 3.0 (1.9)
Median (Min, Max) | 6.5 (6.0, 7.0) | 3.0 (1.2, 7.0) | 3.5 (0.2, 6.0) | 2.5 (0.3, 4.7) | 1.8 (0.4, 5.5) | 2.5 (0.2, 7.0)
7 hours
N | 2 | 20 | 7 | 9 | 8 | 46
Mean (SD) | 6.5 (0.7) | 3.4 (1.8) | 3.4 (2.5) | 2.2 (1.3) | 2.0 (1.7) | 3.1 (2.0)
Median (Min, Max) | 6.5 (6.0, 7.0) | 3.5 (1.2, 7.0) | 3.5 (0.2, 7.5) | 2.0 (0.5, 4.7) | 1.5 (0.4, 5.5) | 2.8 (0.2, 7.5)
8 hours
N | 2 | 20 | 7 | 9 | 8 | 46
Mean (SD) | 6.5 (0.7) | 3.4 (1.8) | 3.2 (2.0) | 2.0 (1.4) | 2.1 (1.7) | 3.0 (1.9)
Median (Min, Max) | 6.5 (6.0, 7.0) | 3.5 (1.0, 7.0) | 3.5 (0.2, 5.0) | 2.0 (0.5, 4.9) | 1.5 (0.4, 6.0) | 2.5 (0.2, 7.0)
9 hours
N | 2 | 20 | 7 | 9 | 8 | 46
Mean (SD) | 6.5 (0.7) | 3.5 (2.0) | 3.3 (2.2) | 2.0 (1.5) | 2.4 (1.8) | 3.1 (2.0)
Median (Min, Max) | 6.5 (6.0, 7.0) | 3.6 (0.7, 7.0) | 3.5 (0.2, 6.0) | 2.0 (0.5, 5.2) | 1.8 (0.4, 6.0) | 2.5 (0.2, 7.0)
10 hours
N | 2 | 20 | 7 | 9 | 8 | 46
Mean (SD) | 6.5 (0.7) | 3.6 (2.1) | 3.4 (2.3) | 2.0 (1.5) | 2.4 (2.0) | 3.2 (2.1)
Median (Min, Max) | 6.5 (6.0, 7.0) | 3.6 (0.7, 7.0) | 3.5 (0.2, 7.0) | 2.0 (0.5, 5.3) | 1.8 (0.4, 6.5) | 2.5 (0.2, 7.0)
11 hours
N | 2 | 20 | 7 | 9 | 8 | 46
Mean (SD) | 6.5 (0.7) | 3.5 (2.1) | 3.4 (2.4) | 2.7 (1.9) | 2.4 (1.9) | 3.3 (2.1)
Median (Min, Max) | 6.5 (6.0, 7.0) | 2.9 (0.7, 7.0) | 3.5 (0.2, 7.0) | 2.5 (0.8, 6.0) | 2.0 (0.4, 6.5) | 2.8 (0.2, 7.0)
12 hours
N | 2 | 20 | 7 | 9 | 8 | 46
Mean (SD) | 4.5 (3.5) | 3.6 (2.0) | 3.2 (2.1) | 2.5 (1.5) | 2.5 (1.9) | 3.2 (2.0)
Median (Min, Max) | 4.5 (2.0, 7.0) | 3.1 (0.7, 7.0) | 3.5 (0.2, 6.0) | 2.5 (0.9, 5.4) | 2.0 (0.4, 6.5) | 2.5 (0.2, 7.0)
13 hours
N | 2 | 20 | 7 | 9 | 8 | 46
Mean (SD) | 4.5 (3.5) | 3.6 (2.0) | 2.9 (1.7) | 2.1 (1.0) | 2.6 (2.2) | 3.1 (1.9)
Median (Min, Max) | 4.5 (2.0, 7.0) | 3.4 (0.7, 7.0) | 3.5 (0.2, 5.0) | 2.0 (0.9, 3.5) | 1.8 (0.4, 7.0) | 2.5 (0.2, 7.0)
14 hours
N | 2 | 14 | 4 | 6 | 6 | 32
Mean (SD) | 4.0 (4.2) | 4.0 (1.9) | 3.4 (1.8) | 2.2 (1.4) | 2.9 (2.6) | 3.4 (2.1)
Median (Min, Max) | 4.0 (1.0, 7.0) | 4.3 (1.2, 7.0) | 3.9 (0.9, 5.0) | 1.8 (1.0, 4.0) | 1.8 (0.4, 7.5) | 3.5 (0.4, 7.5)
15 hours
N | 2 | 10 | 4 | 6 | 6 | 28
Mean (SD) | 4.0 (4.2) | 3.8 (2.3) | 3.3 (1.6) | 2.2 (1.3) | 3.0 (2.7) | 3.2 (2.2)
Median (Min, Max) | 4.0 (1.0, 7.0) | 4.8 (0.5, 7.0) | 4.0 (0.9, 4.5) | 1.9 (1.0, 4.0) | 1.8 (0.4, 7.5) | 3.0 (0.4, 7.5)
16 hours
N | 2 | 8 | 3 | 5 | 4 | 22
Mean (SD) | 4.0 (4.2) | 3.9 (2.6) | 4.3 (0.3) | 2.6 (1.5) | 3.7 (3.2) | 3.6 (2.3)
Median (Min, Max) | 4.0 (1.0, 7.0) | 4.8 (0.5, 7.0) | 4.5 (4.0, 4.5) | 3.0 (1.0, 4.5) | 3.5 (0.4, 7.5) | 4.3 (0.4, 7.5)
17 hours
N | 1 | 7 | 3 | 5 | 3 | 19
Mean (SD) | 1.0 | 4.3 (2.4) | 4.3 (0.3) | 2.6 (1.5) | 2.6 (2.6) | 3.4 (2.1)
Median (Min, Max) | 1.0 | 4.5 (0.5, 7.0) | 4.5 (4.0, 4.5) | 3.0 (1.0, 4.5) | 2.0 (0.4, 5.5) | 4.0 (0.4, 7.0)
18 hours
N | 1 | 6 | 3 | 5 | 3 | 18
Mean (SD) | 1.0 | 5.0 (2.0) | 4.8 (0.3) | 2.7 (1.7) | 2.6 (2.6) | 3.7 (2.1)
Median (Min, Max) | 1.0 | 5.3 (1.6, 7.0) | 5.0 (4.5, 5.0) | 3.0 (1.0, 5.0) | 2.0 (0.4, 5.5) | 4.5 (0.4, 7.0)
19 hours
N | 1 | 6 | 3 | 4 | 3 | 17
Mean (SD) | 4.0 | 5.0 (2.2) | 4.8 (0.3) | 3.1 (0.9) | 2.8 (2.6) | 4.1 (1.9)
Median (Min, Max) | 4.0 | 5.5 (1.2, 7.0) | 5.0 (4.5, 5.0) | 3.3 (1.8, 4.0) | 2.5 (0.4, 5.5) | 4.5 (0.4, 7.0)
20 hours
N | 0 | 6 | 2 | 2 | 3 | 13
Mean (SD) | | 5.2 (2.5) | 5.3 (1.1) | 2.4 (0.8) | 2.8 (2.6) | 4.2 (2.4)
Median (Min, Max) | | 5.8 (0.8, 7.5) | 5.3 (4.5, 6.0) | 2.4 (1.8, 3.0) | 2.5 (0.4, 5.5) | 4.5 (0.4, 7.5)
21 hours
N | 0 | 6 | 2 | 1 | 3 | 12
Mean (SD) | | 5.2 (2.5) | 7.3 (3.9) | 1.6 | 3.0 (2.8) | 4.7 (3.0)
Median (Min, Max) | | 5.8 (0.8, 7.5) | 7.3 (4.5, 10.0) | 1.6 | 2.5 (0.4, 6.0) | 4.5 (0.4, 10.0)
22 hours
N | 0 | 4 | 1 | 1 | 3 | 9
Mean (SD) | | 4.1 (2.7) | 3.5 | 1.6 | 2.8 (2.6) | 3.3 (2.3)
Median (Min, Max) | | 4.5 (0.4, 7.0) | 3.5 | 1.6 | 2.5 (0.4, 5.5) | 3.5 (0.4, 7.0)
23 hours
N | 0 | 2 | 1 | 0 | 3 | 6
Mean (SD) | | 2.5 (2.9) | 3.5 | | 2.8 (2.6) | 2.8 (2.1)
Median (Min, Max) | | 2.5 (0.4, 4.5) | 3.5 | | 2.5 (0.4, 5.5) | 3.0 (0.4, 5.5)
24 hours
N | 0 | 1 | 1 | 0 | 2 | 4
Mean (SD) | | 4.5 | 3.5 | | 1.5 (1.5) | 2.7 (1.8)
Median (Min, Max) | | 4.5 | 3.5 | | 1.5 (0.4, 2.5) | 3.0 (0.4, 4.5)

Note:

1 TS II: Tanner Stage II

Table 14.1.8.2 Descriptive Statistics for Infusion Rate (mcg/kg/min) By Time and Treatment (Blinded Phase) ITT Population

Assessments/Statistics | Treatment | | Total; (N=45) | P Value
Assessments/Statistics | SNP; (N=24) | Placebo; (N=21) | Total; (N=45) | P Value
Infusion Rate (mcg/kg/min)
N | 24 | 21 | 45 | 0.375
Mean (SD) | 2.9 (2.3) | 3.5 (2.6) | 3.2 (2.4)
Median (Min, Max) | 2.5 (0.4, 7.5) | 2.5 (0.2, 9.9) | 2.5 (0.2, 9.9)

Table 14.2.1.1.1 Descriptive Statistics for MAP Scores (mmHg) By Time and Age Classification (Open-Label Phase) Safety Population

Assessments/Statistics | Age Strata | | | | | Total; (N=51)
Assessments/Statistics | 0 - < 30 days; (N=3) | 30 days - < 2 yrs; (N=20) | 2 yrs - < 6 yrs; (N=7) | 6 yrs - TS II^1^; (N=12) | TS III - 17 yrs; (N=9) | Total; (N=51)
B1
N | 3 | 20 | 7 | 12 | 9 | 51
Mean (SD) | 70.3 (6.5) | 86.9 (14.0) | 102.0 (18.5) | 106.1 (13.5) | 100.2 (9.8) | 94.8 (16.7)
Median (Min, Max) | 70.0 (64.0, 77.0) | 82.0 (70.0, 118.0) | 104.0 (79.0, 134.0) | 108.0 (84.0, 138.0) | 102.0 (88.0, 118.0) | 92.0 (64.0, 138.0)
0 or 1 min (first record in open-label phase)
N | 3 | 20 | 7 | 12 | 9 | 51
Mean (SD) | 68.3 (7.5) | 82.6 (17.5) | 94.7 (18.0) | 107.3 (16.7) | 91.8 (13.8) | 90.8 (19.4)
Median (Min, Max) | 64.0 (64.0, 77.0) | 79.0 (50.0, 120.0) | 94.0 (70.0, 124.0) | 107.0 (82.0, 140.0) | 90.0 (70.0, 118.0) | 88.0 (50.0, 140.0)
5 mins
N | 3 | 19 | 7 | 12 | 9 | 50
Mean (SD) | 64.3 (11.7) | 74.3 (17.3) | 91.4 (22.0) | 102.5 (17.7) | 86.7 (10.0) | 85.1 (20.3)
Median (Min, Max) | 62.0 (54.0, 77.0) | 72.0 (32.0, 112.0) | 94.0 (66.0, 116.0) | 98.0 (78.0, 144.0) | 86.0 (70.0, 106.0) | 82.5 (32.0, 144.0)
10 mins
N | 3 | 19 | 7 | 12 | 9 | 50
Mean (SD) | 61.3 (13.0) | 75.5 (13.4) | 86.6 (27.6) | 88.2 (15.5) | 80.8 (13.2) | 80.2 (17.3)
Median (Min, Max) | 62.0 (48.0, 74.0) | 74.0 (46.0, 110.0) | 79.0 (50.0, 118.0) | 91.0 (62.0, 108.0) | 78.0 (68.0, 112.0) | 77.0 (46.0, 118.0)
15 ± 2 mins
N | 3 | 19 | 7 | 12 | 9 | 50
Mean (SD) | 61.0 (8.9) | 73.9 (13.2) | 80.0 (20.6) | 83.6 (12.7) | 76.6 (13.3) | 76.8 (14.7)
Median (Min, Max) | 58.0 (54.0, 71.0) | 74.0 (50.0, 110.0) | 80.0 (58.0, 118.0) | 86.0 (56.0, 102.0) | 76.0 (59.0, 106.0) | 76.5 (50.0, 118.0)
30 ± 5 mins
N | 3 | 20 | 7 | 12 | 8 | 50
Mean (SD) | 58.0 (3.5) | 69.1 (12.6) | 85.3 (15.4) | 81.4 (11.9) | 76.5 (6.9) | 74.8 (13.7)
Median (Min, Max) | 56.0 (56.0, 62.0) | 69.0 (47.0, 94.0) | 80.0 (69.0, 116.0) | 81.0 (56.0, 98.0) | 76.0 (66.0, 88.0) | 76.0 (47.0, 116.0)
1 hour ± 20 mins
N | 3 | 19 | 7 | 12 | 8 | 49
Mean (SD) | 56.7 (8.3) | 65.4 (11.2) | 82.4 (19.5) | 81.5 (14.9) | 76.4 (10.5) | 73.0 (15.4)
Median (Min, Max) | 54.0 (50.0, 66.0) | 68.0 (42.0, 90.0) | 78.0 (54.0, 110.0) | 81.0 (60.0, 103.0) | 74.0 (64.0, 99.0) | 72.0 (42.0, 110.0)
2 hours ± 20 mins
N | 3 | 19 | 7 | 12 | 8 | 49
Mean (SD) | 54.7 (11.4) | 69.7 (15.5) | 79.9 (19.7) | 79.6 (11.6) | 76.8 (9.6) | 73.8 (15.3)
Median (Min, Max) | 58.0 (42.0, 64.0) | 66.0 (50.0, 119.0) | 74.0 (62.0, 120.0) | 79.5 (62.0, 98.0) | 78.0 (62.0, 90.0) | 71.0 (42.0, 120.0)
3 hours ± 20 mins
N | 2 | 19 | 7 | 11 | 8 | 47
Mean (SD) | 62.5 (0.7) | 69.7 (15.2) | 74.7 (16.6) | 79.8 (17.1) | 75.8 (8.2) | 73.5 (14.9)
Median (Min, Max) | 62.5 (62.0, 63.0) | 66.0 (51.0, 100.0) | 72.0 (56.0, 102.0) | 82.0 (58.0, 117.0) | 75.0 (64.0, 87.0) | 70.0 (51.0, 117.0)
4 hours ± 20 mins
N | 2 | 19 | 7 | 11 | 8 | 47
Mean (SD) | 58.5 (0.7) | 66.4 (17.7) | 80.9 (16.6) | 79.5 (10.3) | 74.8 (9.2) | 72.7 (15.6)
Median (Min, Max) | 58.5 (58.0, 59.0) | 62.0 (52.0, 121.0) | 76.0 (60.0, 110.0) | 78.0 (64.0, 103.0) | 73.0 (62.0, 91.0) | 70.0 (52.0, 121.0)
5 hours ± 20 mins
N | 2 | 19 | 7 | 10 | 8 | 46
Mean (SD) | 59.0 (4.2) | 64.4 (11.6) | 79.7 (23.1) | 79.2 (8.1) | 77.5 (7.3) | 72.0 (14.3)
Median (Min, Max) | 59.0 (56.0, 62.0) | 62.0 (48.0, 97.0) | 76.0 (60.0, 128.0) | 82.0 (66.0, 90.0) | 76.0 (70.0, 90.0) | 70.0 (48.0, 128.0)
6 hours ± 20 mins
N | 2 | 19 | 7 | 9 | 8 | 45
Mean (SD) | 63.0 (4.2) | 69.9 (17.4) | 78.0 (16.0) | 76.2 (14.0) | 72.3 (5.7) | 72.6 (14.6)
Median (Min, Max) | 63.0 (60.0, 66.0) | 64.0 (52.0, 125.0) | 76.0 (60.0, 106.0) | 76.0 (58.0, 102.0) | 72.0 (62.0, 78.0) | 70.0 (52.0, 125.0)
7 hours ± 20 mins
N | 2 | 19 | 7 | 9 | 7 | 44
Mean (SD) | 56.0 (0.0) | 63.9 (14.2) | 77.0 (14.2) | 82.7 (17.9) | 75.9 (4.6) | 71.4 (15.7)
Median (Min, Max) | 56.0 (56.0, 56.0) | 64.0 (42.0, 111.0) | 74.0 (58.0, 98.0) | 82.0 (62.0, 108.0) | 76.0 (68.0, 83.0) | 68.0 (42.0, 111.0)
8 hours ± 20 mins
N | 2 | 19 | 7 | 9 | 7 | 44
Mean (SD) | 60.0 (2.8) | 65.2 (11.3) | 80.1 (14.6) | 77.9 (11.8) | 78.4 (9.9) | 72.0 (13.2)
Median (Min, Max) | 60.0 (58.0, 62.0) | 64.0 (50.0, 96.0) | 76.0 (67.0, 110.0) | 84.0 (62.0, 93.0) | 84.0 (60.0, 89.0) | 71.0 (50.0, 110.0)
9 hours ± 20 mins
N | 2 | 19 | 7 | 8 | 7 | 43
Mean (SD) | 55.0 (4.2) | 65.5 (16.0) | 78.7 (16.9) | 80.1 (15.3) | 77.1 (7.3) | 71.8 (16.0)
Median (Min, Max) | 55.0 (52.0, 58.0) | 60.0 (48.0, 116.0) | 74.0 (58.0, 104.0) | 76.0 (62.0, 111.0) | 78.0 (64.0, 86.0) | 70.0 (48.0, 116.0)
10 hours ± 20 mins
N | 2 | 19 | 7 | 8 | 7 | 43
Mean (SD) | 52.5 (2.1) | 65.9 (16.6) | 77.7 (12.8) | 80.8 (12.0) | 72.0 (4.1) | 71.0 (14.9)
Median (Min, Max) | 52.5 (51.0, 54.0) | 62.0 (48.0, 111.0) | 74.0 (62.0, 100.0) | 83.0 (62.0, 100.0) | 72.0 (66.0, 78.0) | 71.0 (48.0, 111.0)
11 hours ± 20 mins
N | 2 | 19 | 7 | 8 | 7 | 43
Mean (SD) | 62.0 (8.5) | 60.5 (10.5) | 75.9 (14.7) | 80.4 (14.1) | 78.0 (10.3) | 69.6 (14.5)
Median (Min, Max) | 62.0 (56.0, 68.0) | 60.0 (44.0, 84.0) | 76.0 (57.0, 104.0) | 76.5 (62.0, 106.0) | 80.0 (58.0, 90.0) | 70.0 (44.0, 106.0)
12 hours ± 20 mins
N | 2 | 19 | 7 | 9 | 7 | 44
Mean (SD) | 57.0 (4.2) | 63.1 (13.2) | 74.1 (13.8) | 75.3 (16.3) | 77.1 (5.5) | 69.3 (14.1)
Median (Min, Max) | 57.0 (54.0, 60.0) | 62.0 (46.0, 98.0) | 72.0 (60.0, 100.0) | 78.0 (47.0, 102.0) | 80.0 (68.0, 82.0) | 68.0 (46.0, 102.0)
13 hours ± 20 mins
N | 2 | 13 | 4 | 7 | 5 | 31
Mean (SD) | 58.0 (2.8) | 59.5 (8.0) | 77.5 (20.0) | 81.6 (10.1) | 71.4 (6.8) | 68.6 (13.7)
Median (Min, Max) | 58.0 (56.0, 60.0) | 58.0 (46.0, 72.0) | 75.0 (56.0, 104.0) | 82.0 (70.0, 98.0) | 72.0 (62.0, 80.0) | 68.0 (46.0, 104.0)
14 hours ± 20 mins
N | 2 | 10 | 4 | 6 | 5 | 27
Mean (SD) | 57.0 (4.2) | 61.7 (12.6) | 72.5 (15.4) | 78.5 (6.3) | 73.8 (10.5) | 68.9 (12.9)
Median (Min, Max) | 57.0 (54.0, 60.0) | 62.0 (42.0, 84.0) | 74.0 (54.0, 88.0) | 79.5 (68.0, 86.0) | 73.0 (60.0, 86.0) | 68.0 (42.0, 88.0)
15 hours ± 20 mins
N | 2 | 8 | 3 | 5 | 4 | 22
Mean (SD) | 59.0 (4.2) | 68.5 (21.4) | 78.7 (7.0) | 74.8 (9.4) | 80.3 (6.7) | 72.6 (14.9)
Median (Min, Max) | 59.0 (56.0, 62.0) | 63.0 (48.0, 113.0) | 78.0 (72.0, 86.0) | 72.0 (62.0, 86.0) | 80.5 (74.0, 86.0) | 73.0 (48.0, 113.0)
16 hours ± 20 mins
N | 1 | 7 | 3 | 5 | 3 | 19
Mean (SD) | 60.0 | 64.6 (14.4) | 83.3 (6.4) | 77.0 (11.9) | 76.7 (4.0) | 72.5 (13.0)
Median (Min, Max) | 60.0 | 62.0 (48.0, 94.0) | 86.0 (76.0, 88.0) | 74.0 (66.0, 94.0) | 76.0 (73.0, 81.0) | 73.0 (48.0, 94.0)
17 hours ± 20 mins
N | 1 | 6 | 3 | 5 | 3 | 18
Mean (SD) | 56.0 | 71.3 (9.4) | 78.7 (8.1) | 77.6 (10.5) | 78.0 (3.5) | 74.6 (9.6)
Median (Min, Max) | 56.0 | 71.0 (56.0, 82.0) | 80.0 (70.0, 86.0) | 76.0 (62.0, 90.0) | 76.0 (76.0, 82.0) | 76.0 (56.0, 90.0)
18 hours ± 20 mins
N | 1 | 6 | 3 | 4 | 3 | 17
Mean (SD) | 68.0 | 71.3 (13.7) | 81.3 (8.1) | 70.8 (11.5) | 82.7 (12.0) | 74.8 (11.9)
Median (Min, Max) | 68.0 | 72.0 (50.0, 91.0) | 80.0 (74.0, 90.0) | 70.5 (58.0, 84.0) | 82.0 (71.0, 95.0) | 74.0 (50.0, 95.0)
19 hours ± 20 mins
N | 0 | 6 | 3 | 2 | 3 | 14
Mean (SD) | | 69.5 (9.5) | 92.7 (9.9) | 75.0 (18.4) | 77.0 (9.5) | 76.9 (13.2)
Median (Min, Max) | | 71.0 (52.0, 80.0) | 88.0 (86.0, 104.0) | 75.0 (62.0, 88.0) | 76.0 (68.0, 87.0) | 75.5 (52.0, 104.0)
20 hours ± 20 mins
N | 0 | 6 | 2 | 1 | 3 | 12
Mean (SD) | | 73.2 (17.3) | 77.0 (4.2) | 78.0 | 79.3 (8.5) | 75.8 (12.6)
Median (Min, Max) | | 70.5 (56.0, 105.0) | 77.0 (74.0, 80.0) | 78.0 | 76.0 (73.0, 89.0) | 75.0 (56.0, 105.0)
21 hours ± 20 mins
N | 0 | 3 | 2 | 1 | 3 | 9
Mean (SD) | | 62.7 (13.0) | 78.0 (14.1) | 72.0 | 80.3 (9.1) | 73.0 (12.4)
Median (Min, Max) | | 62.0 (50.0, 76.0) | 78.0 (68.0, 88.0) | 72.0 | 84.0 (70.0, 87.0) | 72.0 (50.0, 88.0)
22 hours ± 20 mins
N | 0 | 2 | 1 | 0 | 3 | 6
Mean (SD) | | 80.5 (3.5) | 106.0 | | 73.0 (5.6) | 81.0 (13.4)
Median (Min, Max) | | 80.5 (78.0, 83.0) | 106.0 | | 74.0 (67.0, 78.0) | 78.0 (67.0, 106.0)
23 hours ± 20 mins
N | 0 | 1 | 1 | 0 | 2 | 4
Mean (SD) | | 70.0 | 108.0 | | 106.0 (8.5) | 97.5 (19.0)
Median (Min, Max) | | 70.0 | 108.0 | | 106.0 (100.0, 112.0) | 104.0 (70.0, 112.0)
24 hours ± 20 mins
N | 0 | 1 | 0 | 0 | 1 | 2
Mean (SD) | | 64.0 | | | 77.0 | 70.5 (9.2)
Median (Min, Max) | | 64.0 | | | 77.0 | 70.5 (64.0, 77.0)
B2
N | 2 | 19 | 7 | 9 | 8 | 45
Mean (SD) | 63.0 (1.4) | 61.7 (7.9) | 75.0 (15.2) | 78.1 (6.9) | 74.4 (7.1) | 69.4 (11.2)
Median (Min, Max) | 63.0 (62.0, 64.0) | 61.0 (48.0, 75.0) | 72.0 (60.0, 104.0) | 78.0 (66.0, 88.0) | 73.5 (66.0, 86.0) | 68.0 (48.0, 104.0)

Note:

1 TS III: Tanner Stage II.

Table 14.2.1.1.2 Descriptive Statistics for Change in MAP Scores (mmHg) from B1 By Time and Age Classification (Open-Label Phase) Safety Population

Assessments/Statistics | Age Strata | | | | | Total; (N=51)
Assessments/Statistics | 0 - < 30 days; (N=3) | 30 days - < 2 yrs; (N=20) | 2 yrs - < 6 yrs; (N=7) | 6 yrs - TS II^1^; (N=12) | TS III - 17 yrs; (N=9) | Total; (N=51)
0 or 1 min (first record in open-label phase)
N | 3 | 20 | 7 | 12 | 9 | 51
Mean (SD) | −2.0 (3.5) | −4.3 (10.5) | −7.3 (8.4) | 1.3 (9.7) | −8.4 (14.2) | −4.0 (10.7)
Median (Min, Max) | 0.0 (−6.0, 0.0) | 0.0 (−40.0, 6.0) | −2.0 (−19.0, 0.0) | −1.0 (−11.0, 28.0) | 0.0 (−39.0, 0.0) | 0.0 (−40.0, 28.0)
5 mins
N | 3 | 19 | 7 | 12 | 9 | 50
Mean (SD) | −6.0 (8.7) | −11.3 (15.2) | −10.6 (17.6) | −3.6 (12.5) | −13.6 (12.2) | −9.4 (14.1)
Median (Min, Max) | −2.0 (−16.0, 0.0) | −4.0 (−58.0, 3.0) | −13.0 (−42.0, 8.0) | −7.0 (−14.0, 32.0) | −12.0 (−39.0, 0.0) | −7.0 (−58.0, 32.0)
10 mins
N | 3 | 19 | 7 | 12 | 9 | 50
Mean (SD) | −9.0 (11.3) | −10.1 (14.9) | −15.4 (18.1) | −17.9 (16.1) | −19.4 (10.1) | −14.3 (14.8)
Median (Min, Max) | −3.0 (−22.0, −2.0) | −4.0 (−46.0, 8.0) | −16.0 (−38.0, 12.0) | −18.0 (−44.0, 4.0) | −17.0 (−39.0, −6.0) | −11.5 (−46.0, 12.0)
15 ± 2 mins
N | 3 | 19 | 7 | 12 | 9 | 50
Mean (SD) | −9.3 (5.8) | −11.7 (12.1) | −22.0 (5.1) | −22.5 (11.5) | −23.7 (9.3) | −17.7 (11.6)
Median (Min, Max) | −6.0 (−16.0, −6.0) | −8.0 (−40.0, 2.0) | −20.0 (−30.0, −16.0) | −23.5 (−40.0, −2.0) | −25.0 (−41.0, −12.0) | −17.5 (−41.0, 2.0)
30 ± 5 mins
N | 3 | 20 | 7 | 12 | 8 | 50
Mean (SD) | −12.3 (3.8) | −17.8 (16.5) | −16.7 (11.8) | −24.7 (9.2) | −25.0 (11.5) | −20.1 (13.3)
Median (Min, Max) | −14.0 (−15.0, −8.0) | −15.0 (−50.0, 8.0) | −20.0 (−30.0, 7.0) | −22.5 (−40.0, −10.0) | −25.5 (−37.0, 0.0) | −20.0 (−50.0, 8.0)
1 hour ± 20 mins
N | 3 | 19 | 7 | 12 | 8 | 49
Mean (SD) | −13.7 (2.5) | −20.2 (16.4) | −19.6 (13.5) | −24.6 (10.2) | −25.1 (10.7) | −21.6 (13.2)
Median (Min, Max) | −14.0 (−16.0, −11.0) | −17.0 (−58.0, 4.0) | −22.0 (−34.0, −1.0) | −25.0 (−40.0, −8.0) | −24.0 (−42.0, −6.0) | −22.0 (−58.0, 4.0)
2 hours ± 20 mins
N | 3 | 19 | 7 | 12 | 8 | 49
Mean (SD) | −15.7 (11.2) | −17.5 (13.3) | −22.1 (6.9) | −26.5 (12.2) | −24.8 (8.3) | −21.4 (11.7)
Median (Min, Max) | −13.0 (−28.0, −6.0) | −16.0 (−40.0, 8.0) | −24.0 (−30.0, −12.0) | −27.5 (−46.0, −8.0) | −25.0 (−36.0, −12.0) | −21.0 (−46.0, 8.0)
3 hours ± 20 mins
N | 2 | 19 | 7 | 11 | 8 | 47
Mean (SD) | −8.0 (8.5) | −17.5 (12.9) | −27.3 (5.6) | −27.7 (8.0) | −25.8 (9.1) | −22.4 (11.3)
Median (Min, Max) | −8.0 (−14.0, −2.0) | −20.0 (−44.0, 9.0) | −26.0 (−36.0, −20.0) | −28.0 (−38.0, −10.0) | −24.0 (−37.0, −15.0) | −24.0 (−44.0, 9.0)
4 hours ± 20 mins
N | 2 | 19 | 7 | 11 | 8 | 47
Mean (SD) | −12.0 (8.5) | −20.8 (15.1) | −21.1 (9.9) | −28.0 (6.6) | −26.8 (12.1) | −23.2 (12.3)
Median (Min, Max) | −12.0 (−18.0, −6.0) | −20.0 (−52.0, 10.0) | −20.0 (−32.0, −3.0) | −30.0 (−36.0, −18.0) | −28.0 (−42.0, −11.0) | −22.0 (−52.0, 10.0)
5 hours ± 20 mins
N | 2 | 19 | 7 | 10 | 8 | 46
Mean (SD) | −11.5 (4.9) | −22.8 (12.9) | −22.3 (9.0) | −29.1 (10.2) | −24.0 (14.5) | −23.8 (12.0)
Median (Min, Max) | −11.5 (−15.0, −8.0) | −19.0 (−52.0, −6.0) | −26.0 (−32.0, −6.0) | −28.0 (−51.0, −16.0) | −28.0 (−40.0, 2.0) | −23.0 (−52.0, 2.0)
6 hours ± 20 mins
N | 2 | 19 | 7 | 9 | 8 | 45
Mean (SD) | −7.5 (4.9) | −17.3 (12.6) | −24.0 (8.9) | −32.1 (17.1) | −29.3 (6.9) | −23.0 (13.7)
Median (Min, Max) | −7.5 (−11.0, −4.0) | −19.0 (−44.0, 14.0) | −26.0 (−32.0, −5.0) | −32.0 (−64.0, −6.0) | −29.0 (−40.0, −18.0) | −24.0 (−64.0, 14.0)
7 hours ± 20 mins
N | 2 | 19 | 7 | 9 | 7 | 44
Mean (SD) | −14.5 (9.2) | −23.3 (17.0) | −25.0 (8.8) | −25.7 (13.2) | −24.6 (9.5) | −23.9 (13.6)
Median (Min, Max) | −14.5 (−21.0, −8.0) | −18.0 (−60.0, 0.0) | −22.0 (−36.0, −11.0) | −26.0 (−48.0, −8.0) | −24.0 (−42.0, −10.0) | −22.0 (−60.0, 0.0)
8 hours ± 20 mins
N | 2 | 19 | 7 | 9 | 7 | 44
Mean (SD) | −10.5 (12.0) | −22.1 (13.6) | −21.9 (10.0) | −30.4 (12.2) | −22.0 (10.6) | −23.2 (12.6)
Median (Min, Max) | −10.5 (−19.0, −2.0) | −21.0 (−54.0, 0.0) | −24.0 (−32.0, −1.0) | −28.0 (−46.0, −14.0) | −24.0 (−34.0, −4.0) | −22.0 (−54.0, 0.0)
9 hours ± 20 mins
N | 2 | 19 | 7 | 8 | 7 | 43
Mean (SD) | −15.5 (13.4) | −21.7 (16.4) | −23.3 (12.8) | −27.8 (15.3) | −23.3 (7.8) | −23.1 (14.1)
Median (Min, Max) | −15.5 (−25.0, −6.0) | −22.0 (−42.0, 30.0) | −28.0 (−38.0, −5.0) | −33.5 (−46.0, 3.0) | −25.0 (−32.0, −8.0) | −25.0 (−46.0, 30.0)
10 hours ± 20 mins
N | 2 | 19 | 7 | 8 | 7 | 43
Mean (SD) | −18.0 (11.3) | −21.3 (17.4) | −24.3 (10.7) | −27.1 (6.7) | −28.4 (9.8) | −23.9 (13.4)
Median (Min, Max) | −18.0 (−26.0, −10.0) | −22.0 (−52.0, 18.0) | −27.0 (−36.0, −7.0) | −26.0 (−38.0, −20.0) | −27.0 (−46.0, −14.0) | −24.0 (−52.0, 18.0)
11 hours ± 20 mins
N | 2 | 19 | 7 | 8 | 7 | 43
Mean (SD) | −8.5 (17.7) | −26.7 (12.6) | −26.1 (11.0) | −27.5 (18.5) | −22.4 (13.2) | −25.2 (13.9)
Median (Min, Max) | −8.5 (−21.0, 4.0) | −22.0 (−46.0, 0.0) | −30.0 (−38.0, −10.0) | −26.0 (−61.0, −2.0) | −21.0 (−42.0, −8.0) | −22.0 (−61.0, 4.0)
12 hours ± 20 mins
N | 2 | 19 | 7 | 9 | 7 | 44
Mean (SD) | −13.5 (13.4) | −24.2 (14.6) | −27.9 (5.7) | −33.0 (25.3) | −23.3 (12.1) | −25.9 (16.1)
Median (Min, Max) | −13.5 (−23.0, −4.0) | −24.0 (−54.0, 1.0) | −30.0 (−34.0, −19.0) | −32.0 (−91.0, −3.0) | −21.0 (−44.0, −6.0) | −25.0 (−91.0, 1.0)
13 hours ± 20 mins
N | 2 | 13 | 4 | 7 | 5 | 31
Mean (SD) | −12.5 (12.0) | −28.6 (11.8) | −24.8 (11.2) | −26.0 (17.7) | −29.6 (6.7) | −26.6 (12.6)
Median (Min, Max) | −12.5 (−21.0, −4.0) | −24.0 (−46.0, −10.0) | −26.5 (−36.0, −10.0) | −24.0 (−63.0, −10.0) | −30.0 (−38.0, −20.0) | −24.0 (−63.0, −4.0)
14 hours ± 20 mins
N | 2 | 10 | 4 | 6 | 5 | 27
Mean (SD) | −13.5 (4.9) | −26.5 (11.5) | −29.8 (17.2) | −24.0 (9.5) | −27.2 (6.6) | −25.6 (11.0)
Median (Min, Max) | −13.5 (−17.0, −10.0) | −22.5 (−46.0, −15.0) | −27.0 (−52.0, −13.0) | −25.0 (−36.0, −7.0) | −32.0 (−32.0, −20.0) | −24.0 (−52.0, −7.0)
15 hours ± 20 mins
N | 2 | 8 | 3 | 5 | 4 | 22
Mean (SD) | −11.5 (4.9) | −19.8 (14.6) | −28.3 (25.1) | −27.0 (10.1) | −23.0 (9.3) | −22.4 (13.7)
Median (Min, Max) | −11.5 (−15.0, −8.0) | −22.5 (−40.0, 2.0) | −22.0 (−56.0, −7.0) | −30.0 (−37.0, −12.0) | −23.0 (−32.0, −14.0) | −22.0 (−56.0, 2.0)
16 hours ± 20 mins
N | 1 | 7 | 3 | 5 | 3 | 19
Mean (SD) | −17.0 | −25.3 (14.6) | −23.7 (21.5) | −24.8 (7.7) | −31.7 (10.5) | −25.5 (12.6)
Median (Min, Max) | −17.0 | −21.0 (−54.0, −12.0) | −22.0 (−46.0, −3.0) | −24.0 (−35.0, −17.0) | −32.0 (−42.0, −21.0) | −22.0 (−54.0, −3.0)
17 hours ± 20 mins
N | 1 | 6 | 3 | 5 | 3 | 18
Mean (SD) | −21.0 | −21.2 (14.0) | −28.3 (19.5) | −24.2 (11.1) | −30.3 (5.1) | −24.7 (12.2)
Median (Min, Max) | −21.0 | −20.0 (−38.0, −2.0) | −28.0 (−48.0, −9.0) | −28.0 (−34.0, −8.0) | −29.0 (−36.0, −26.0) | −27.0 (−48.0, −2.0)
18 hours ± 20 mins
N | 1 | 6 | 3 | 4 | 3 | 17
Mean (SD) | −9.0 | −21.2 (11.9) | −25.7 (23.6) | −29.5 (9.0) | −25.7 (16.2) | −24.0 (13.7)
Median (Min, Max) | −9.0 | −22.0 (−40.0, −8.0) | −34.0 (−44.0, 1.0) | −30.5 (−38.0, −19.0) | −34.0 (−36.0, −7.0) | −25.0 (−44.0, 1.0)
19 hours ± 20 mins
N | 0 | 6 | 3 | 2 | 3 | 14
Mean (SD) | | −23.0 (15.2) | −14.3 (19.1) | −27.5 (9.2) | −31.3 (14.4) | −23.6 (14.8)
Median (Min, Max) | | −20.5 (−48.0, −4.0) | −20.0 (−30.0, 7.0) | −27.5 (−34.0, −21.0) | −37.0 (−42.0, −15.0) | −21.5 (−48.0, 7.0)
20 hours ± 20 mins
N | 0 | 6 | 2 | 1 | 3 | 12
Mean (SD) | | −19.3 (18.9) | −29.5 (34.6) | −31.0 | −29.0 (14.7) | −24.4 (18.4)
Median (Min, Max) | | −16.0 (−56.0, −4.0) | −29.5 (−54.0, −5.0) | −31.0 | −32.0 (−42.0, −13.0) | −17.0 (−56.0, −4.0)
21 hours ± 20 mins
N | 0 | 3 | 2 | 1 | 3 | 9
Mean (SD) | | −26.3 (7.8) | −28.5 (24.7) | −37.0 | −28.0 (11.3) | −28.6 (11.6)
Median (Min, Max) | | −24.0 (−35.0, −20.0) | −28.5 (−46.0, −11.0) | −37.0 | −34.0 (−35.0, −15.0) | −34.0 (−46.0, −11.0)
22 hours ± 20 mins
N | 0 | 2 | 1 | 0 | 3 | 6
Mean (SD) | | −16.0 (17.0) | −28.0 | | −35.3 (6.4) | −27.7 (12.8)
Median (Min, Max) | | −16.0 (−28.0, −4.0) | −28.0 | | −38.0 (−40.0, −28.0) | −28.0 (−40.0, −4.0)
23 hours ± 20 mins
N | 0 | 1 | 1 | 0 | 2 | 4
Mean (SD) | | −12.0 | −26.0 | | 2.5 (6.4) | −8.3 (14.2)
Median (Min, Max) | | −12.0 | −26.0 | | 2.5 (−2.0, 7.0) | −7.0 (−26.0, 7.0)
24 hours ± 20 mins
N | 0 | 1 | 0 | 0 | 1 | 2
Mean (SD) | | −18.0 | | | −28.0 | −23.0 (7.1)
Median (Min, Max) | | −18.0 | | | −28.0 | −23.0 (−28.0, −18.0)
B2
N | 2 | 19 | 7 | 9 | 8 | 45
Mean (SD) | −7.5 (10.6) | −25.5 (14.6) | −27.0 (7.2) | −30.2 (14.7) | −27.1 (10.5) | −26.2 (13.1)
Median (Min, Max) | −7.5 (−15.0, 0.0) | −26.0 (−54.0, 0.0) | −30.0 (−32.0, −11.0) | −31.0 (−63.0, −8.0) | −27.0 (−43.0, −10.0) | −28.0 (−63.0, 0.0)

Note:

1 TS II: Tanner Stage II.

Table 14.2.1.1.3 Descriptive Statistics for Percentage of Change in MAP Scores from B1 By Time and Age Classification (Open-Label Phase) Safety Population

Assessments/Statistics | Age Strata | | | | | Total; (N=51)
Assessments/Statistics | 0 - < 30 days; (N=3) | 30 days - < 2 yrs; (N=20) | 2 yrs - < 6 yrs; (N=7) | 6 yrs - TS II^1^; (N=12) | TS III - 17 yrs; (N=9) | Total; (N=51)
0 or 1 min (first record in open-label phase)
N | 3 | 20 | 7 | 12 | 9 | 51
Mean (SD) | −2.9% (5.0%) | −4.9% (11.8%) | −7.0% (8.6%) | 1.1% (8.8%) | −8.0% (13.2%) | −4.2% (10.9%)
Median (Min, Max) | 0.0% (−8.6%, 0.0%) | 0.0% (−44.4%, 6.6%) | −1.9% (−21.4%, 0.0%) | −0.9% (−10.1%, 25.0%) | 0.0% (−35.8%, 0.0%) | 0.0% (−44.4%, 25.0%)
5 mins
N | 3 | 19 | 7 | 12 | 9 | 50
Mean (SD) | −8.7% (12.4%) | −12.7% (17.0%) | −10.1% (16.4%) | −3.4% (11.3%) | −13.0% (11.2%) | −9.9% (14.5%)
Median (Min, Max) | −3.1% (−22.9%, 0.0%) | −4.0% (−64.4%, 4.0%) | −13.4% (−37.5%, 7.4%) | −7.2% (−12.5%, 28.6%) | −10.2% (−35.8%, 0.0%) | −7.2% (−64.4%, 28.6%)
10 mins
N | 3 | 19 | 7 | 12 | 9 | 50
Mean (SD) | −12.8% (16.1%) | −10.7% (15.4%) | −16.0% (18.9%) | −16.4% (14.6%) | −19.4% (9.4%) | −14.5% (14.7%)
Median (Min, Max) | −3.9% (−31.4%, −3.1%) | −5.4% (−48.9%, 10.3%) | −11.9% (−43.2%, 11.5%) | −17.5% (−40.0%, 4.0%) | −18.9% (−35.8%, −5.1%) | −11.7% (−48.9%, 11.5%)
15 ± 2 mins
N | 3 | 19 | 7 | 12 | 9 | 50
Mean (SD) | −13.3% (8.3%) | −13.0% (12.9%) | −22.3% (6.8%) | −21.0% (10.3%) | −23.8% (9.2%) | −18.2% (11.3%)
Median (Min, Max) | −9.4% (−22.9%, −7.8%) | −8.0% (−44.4%, 2.9%) | −21.4% (−34.1%, −11.9%) | −22.4% (−37.0%, −2.2%) | −23.8% (−37.6%, −10.2%) | −18.8% (−44.4%, 2.9%)
30 ± 5 mins
N | 3 | 20 | 7 | 12 | 8 | 50
Mean (SD) | −17.3% (4.2%) | −19.0% (17.0%) | −15.6% (12.0%) | −23.2% (7.6%) | −24.1% (10.5%) | −20.3% (12.9%)
Median (Min, Max) | −19.5% (−20.0%, −12.5%) | −16.6% (−48.4%, 10.4%) | −17.9% (−27.8%, 8.9%) | −22.8% (−33.9%, −9.4%) | −26.0% (−33.9%, 0.0%) | −20.8% (−48.4%, 10.4%)
1 hour ± 20 mins
N | 3 | 19 | 7 | 12 | 8 | 49
Mean (SD) | −19.7% (4.7%) | −22.2% (16.3%) | −19.1% (13.9%) | −23.3% (9.4%) | −24.6% (9.1%) | −22.2% (12.6%)
Median (Min, Max) | −21.9% (−22.9%, −14.3%) | −21.1% (−49.2%, 5.7%) | −19.6% (−38.6%, −1.3%) | −24.7% (−39.0%, −7.6%) | −26.1% (−35.6%, −5.7%) | −22.5% (−49.2%, 5.7%)
2 hours ± 20 mins
N | 3 | 19 | 7 | 12 | 8 | 49
Mean (SD) | −22.1% (16.0%) | −19.7% (13.1%) | −22.1% (7.1%) | −24.6% (9.9%) | −24.3% (7.4%) | −22.1% (10.8%)
Median (Min, Max) | −16.9% (−40.0%, −9.4%) | −19.5% (−44.4%, 7.2%) | −23.6% (−29.6%, −10.5%) | −25.4% (−41.1%, −7.6%) | −25.4% (−32.6%, −11.8%) | −23.4% (−44.4%, 7.2%)
3 hours ± 20 mins
N | 2 | 19 | 7 | 11 | 8 | 47
Mean (SD) | −10.7% (10.7%) | −19.8% (13.6%) | −27.1% (5.0%) | −26.3% (8.7%) | −25.1% (7.6%) | −22.9% (11.0%)
Median (Min, Max) | −10.7% (−18.2%, −3.1%) | −23.7% (−42.2%, 11.4%) | −28.9% (−33.3%, −17.9%) | −26.8% (−39.6%, −9.4%) | −24.6% (−34.3%, −14.7%) | −25.5% (−42.2%, 11.4%)
4 hours ± 20 mins
N | 2 | 19 | 7 | 11 | 8 | 47
Mean (SD) | −16.4% (9.9%) | −23.8% (14.0%) | −20.6% (9.2%) | −25.9% (4.9%) | −25.9% (10.4%) | −23.9% (10.9%)
Median (Min, Max) | −16.4% (−23.4%, −9.4%) | −23.7% (−44.1%, 9.0%) | −20.5% (−30.8%, −3.4%) | −25.4% (−32.1%, −18.8%) | −29.9% (−35.8%, −10.8%) | −24.1% (−44.1%, 9.0%)
5 hours ± 20 mins
N | 2 | 19 | 7 | 10 | 8 | 46
Mean (SD) | −16.0% (4.9%) | −25.5% (11.0%) | −22.7% (9.2%) | −26.5% (6.6%) | −22.7% (13.1%) | −24.4% (10.1%)
Median (Min, Max) | −16.0% (−19.5%, −12.5%) | −24.1% (−45.6%, −7.3%) | −25.0% (−32.6%, −4.5%) | −26.1% (−37.0%, −15.1%) | −28.3% (−35.8%, 2.3%) | −25.0% (−45.6%, 2.3%)
6 hours ± 20 mins
N | 2 | 19 | 7 | 9 | 8 | 45
Mean (SD) | −10.3% (5.7%) | −19.9% (12.6%) | −23.4% (8.9%) | −29.1% (12.9%) | −28.6% (5.0%) | −23.4% (11.7%)
Median (Min, Max) | −10.3% (−14.3%, −6.3%) | −20.3% (−40.0%, 12.6%) | −25.0% (−32.6%, −6.3%) | −31.0% (−46.4%, −5.6%) | −29.3% (−33.9%, −20.5%) | −25.0% (−46.4%, 12.6%)
7 hours ± 20 mins
N | 2 | 19 | 7 | 9 | 7 | 44
Mean (SD) | −19.9% (10.5%) | −25.7% (15.4%) | −24.3% (7.2%) | −23.8% (12.0%) | −24.0% (7.3%) | −24.5% (12.0%)
Median (Min, Max) | −19.9% (−27.3%, −12.5%) | −24.3% (−58.0%, 0.0%) | −24.7% (−34.1%, −13.9%) | −23.8% (−43.6%, −7.1%) | −23.5% (−35.6%, −11.4%) | −23.9% (−58.0%, 0.0%)
8 hours ± 20 mins
N | 2 | 19 | 7 | 9 | 7 | 44
Mean (SD) | −13.9% (15.2%) | −24.4% (12.8%) | −20.9% (9.4%) | −27.7% (9.7%) | −21.6% (10.2%) | −23.6% (11.3%)
Median (Min, Max) | −13.9% (−24.7%, −3.1%) | −26.6% (−45.8%, 0.0%) | −23.2% (−29.6%, −1.3%) | −25.0% (−41.1%, −16.7%) | −25.0% (−34.8%, −4.6%) | −24.9% (−45.8%, 0.0%)
9 hours ± 20 mins
N | 2 | 19 | 7 | 8 | 7 | 43
Mean (SD) | −20.9% (16.3%) | −24.3% (17.3%) | −22.5% (11.7%) | −25.4% (12.7%) | −22.9% (7.1%) | −23.8% (13.8%)
Median (Min, Max) | −20.9% (−32.5%, −9.4%) | −26.6% (−46.7%, 34.9%) | −25.4% (−35.2%, −6.3%) | −30.6% (−35.4%, 2.8%) | −25.0% (−30.4%, −9.1%) | −26.3% (−46.7%, 34.9%)
10 hours ± 20 mins
N | 2 | 19 | 7 | 8 | 7 | 43
Mean (SD) | −24.7% (12.8%) | −23.6% (17.4%) | −23.2% (8.8%) | −25.1% (4.7%) | −27.8% (7.2%) | −24.6% (12.6%)
Median (Min, Max) | −24.7% (−33.8%, −15.6%) | −26.8% (−46.7%, 20.9%) | −25.4% (−33.3%, −8.9%) | −26.9% (−30.3%, −18.5%) | −28.3% (−39.0%, −15.9%) | −26.8% (−46.7%, 20.9%)
11 hours ± 20 mins
N | 2 | 19 | 7 | 8 | 7 | 43
Mean (SD) | −10.5% (23.7%) | −29.8% (12.1%) | −25.2% (9.5%) | −24.7% (14.1%) | −21.9% (12.0%) | −25.9% (12.8%)
Median (Min, Max) | −10.5% (−27.3%, 6.3%) | −27.0% (−51.1%, 0.0%) | −23.1% (−36.0%, −11.4%) | −24.0% (−44.2%, −1.9%) | −20.6% (−37.0%, −9.1%) | −26.3% (−51.1%, 6.3%)
12 hours ± 20 mins
N | 2 | 19 | 7 | 9 | 7 | 44
Mean (SD) | −18.1% (16.7%) | −26.9% (14.3%) | −27.3% (2.7%) | −28.9% (18.6%) | −22.5% (9.9%) | −26.3% (13.4%)
Median (Min, Max) | −18.1% (−29.9%, −6.3%) | −29.3% (−48.0%, 1.3%) | −26.8% (−30.8%, −24.1%) | −28.6% (−65.9%, −3.6%) | −20.6% (−37.3%, −6.8%) | −28.2% (−65.9%, 1.3%)
13 hours ± 20 mins
N | 2 | 13 | 4 | 7 | 5 | 31
Mean (SD) | −16.8% (14.9%) | −31.6% (10.1%) | −24.1% (9.6%) | −23.1% (11.7%) | −29.1% (4.3%) | −27.4% (10.4%)
Median (Min, Max) | −16.8% (−27.3%, −6.3%) | −30.8% (−46.5%, −13.5%) | −25.8% (−33.3%, −11.4%) | −24.8% (−45.7%, −9.3%) | −31.4% (−32.6%, −22.7%) | −26.6% (−46.5%, −6.3%)
14 hours ± 20 mins
N | 2 | 10 | 4 | 6 | 5 | 27
Mean (SD) | −18.9% (4.6%) | −29.7% (11.0%) | −28.1% (12.3%) | −22.9% (8.3%) | −26.9% (6.0%) | −26.6% (9.5%)
Median (Min, Max) | −18.9% (−22.1%, −15.6%) | −23.1% (−46.7%, −19.5%) | −28.6% (−38.8%, −16.5%) | −23.4% (−32.1%, −8.3%) | −27.1% (−34.8%, −19.6%) | −22.7% (−46.7%, −8.3%)
15 hours ± 20 mins
N | 2 | 8 | 3 | 5 | 4 | 22
Mean (SD) | −16.0% (4.9%) | −22.9% (15.3%) | −23.7% (16.7%) | −26.2% (9.0%) | −21.8% (7.0%) | −22.9% (11.6%)
Median (Min, Max) | −16.0% (−19.5%, −12.5%) | −29.0% (−37.4%, 1.8%) | −20.4% (−41.8%, −8.9%) | −26.8% (−35.4%, −14.3%) | −21.5% (−28.6%, −15.7%) | −22.2% (−41.8%, 1.8%)
16 hours ± 20 mins
N | 1 | 7 | 3 | 5 | 3 | 19
Mean (SD) | −22.1% | −27.5% (11.9%) | −19.5% (15.3%) | −24.4% (7.0%) | −28.9% (7.6%) | −25.3% (10.1%)
Median (Min, Max) | −22.1% | −26.6% (−45.8%, −15.3%) | −20.4% (−34.3%, −3.8%) | −22.2% (−32.1%, −16.1%) | −30.5% (−35.6%, −20.6%) | −22.2% (−45.8%, −3.8%)
17 hours ± 20 mins
N | 1 | 6 | 3 | 5 | 3 | 18
Mean (SD) | −27.3% | −21.6% (11.7%) | −24.4% (12.3%) | −23.4% (10.4%) | −27.9% (2.5%) | −23.9% (9.5%)
Median (Min, Max) | −27.3% | −24.3% (−34.2%, −2.4%) | −25.9% (−35.8%, −11.4%) | −25.0% (−35.4%, −9.5%) | −27.6% (−30.5%, −25.5%) | −25.7% (−35.8%, −2.4%)
18 hours ± 20 mins
N | 1 | 6 | 3 | 4 | 3 | 17
Mean (SD) | −11.7% | −22.3% (10.7%) | −21.0% (19.3%) | −29.3% (8.1%) | −23.3% (14.2%) | −23.3% (11.8%)
Median (Min, Max) | −11.7% | −23.3% (−33.9%, −9.8%) | −31.5% (−32.8%, 1.3%) | −27.5% (−39.6%, −22.6%) | −30.5% (−32.4%, −6.9%) | −28.6% (−39.6%, 1.3%)
19 hours ± 20 mins
N | 0 | 6 | 3 | 2 | 3 | 14
Mean (SD) | | −23.6% (12.2%) | −10.7% (17.0%) | −27.3% (11.4%) | −28.5% (12.0%) | −22.4% (13.4%)
Median (Min, Max) | | −24.4% (−40.7%, −5.1%) | −18.5% (−22.4%, 8.9%) | −27.3% (−35.4%, −19.3%) | −35.2% (−35.6%, −14.7%) | −21.6% (−40.7%, 8.9%)
20 hours ± 20 mins
N | 0 | 6 | 2 | 1 | 3 | 12
Mean (SD) | | −19.9% (15.6%) | −23.3% (24.0%) | −28.4% | −26.3% (12.0%) | −22.8% (14.1%)
Median (Min, Max) | | −18.6% (−47.5%, −5.1%) | −23.3% (−40.3%, −6.3%) | −28.4% | −30.5% (−35.6%, −12.8%) | −21.9% (−47.5%, −5.1%)
21 hours ± 20 mins
N | 0 | 3 | 2 | 1 | 3 | 9
Mean (SD) | | −29.5% (4.4%) | −24.1% (14.4%) | −33.9% | −25.6% (9.7%) | −27.5% (8.1%)
Median (Min, Max) | | −31.5% (−32.4%, −24.4%) | −24.1% (−34.3%, −13.9%) | −33.9% | −28.8% (−33.3%, −14.7%) | −31.5% (−34.3%, −13.9%)
22 hours ± 20 mins
N | 0 | 2 | 1 | 0 | 3 | 6
Mean (SD) | | −15.1% (14.4%) | −20.9% | | −32.5% (4.5%) | −24.8% (11.2%)
Median (Min, Max) | | −15.1% (−25.2%, −4.9%) | −20.9% | | −33.9% (−36.2%, −27.5%) | −26.3% (−36.2%, −4.9%)
23 hours ± 20 mins
N | 0 | 1 | 1 | 0 | 2 | 4
Mean (SD) | | −14.6% | −19.4% | | 2.4% (6.1%) | −7.3% (11.9%)
Median (Min, Max) | | −14.6% | −19.4% | | 2.4% (−2.0%, 6.7%) | −8.3% (−19.4%, 6.7%)
24 hours ± 20 mins
N | 0 | 1 | 0 | 0 | 1 | 2
Mean (SD) | | −22.0% | | | −26.7% | −24.3% (3.3%)
Median (Min, Max) | | −22.0% | | | −26.7% | −24.3% (−26.7%, −22.0%)
B2
N | 2 | 19 | 7 | 9 | 8 | 45
Mean (SD) | −9.7% (13.8%) | −27.8% (13.3%) | −26.4% (6.4%) | −27.0% (10.0%) | −26.3% (8.5%) | −26.4% (11.2%)
Median (Min, Max) | −9.7% (−19.5%, 0.0%) | −32.6% (−45.8%, 0.0%) | −27.8% (−31.8%, −13.9%) | −28.6% (−45.7%, −9.5%) | −27.3% (−39.5%, −10.4%) | −28.6% (−45.8%, 0.0%)

Note:

1 TS II: Tanner Stage II.

Table 14.2.1.2 Descriptive Statistics for MAP Scores By Time and Treatment (Blinded Phase) ITT Population

Assessments/Statistics | SNP; (N=24) | | | Placebo; (N=21) | | | Total; (N=45)
Assessments/Statistics | MAP (mmHg) | Change from B2 | Percentage of Change from B2 | MAP (mmHg) | Change from B2 | Percentage of Change from B2 | MAP (mmHg) | Change from B2 | Percentage of Change from B2
B2
N | 24 | ▬ | ▬ | 21 | ▬ | ▬ | 45 | ▬ | ▬
Mean (SD) | 69.5 (12.4) | ▬ | ▬ | 69.2 (10.1) | ▬ | ▬ | 69.4 (11.2) | ▬ | ▬
Median (Min, Max) | 69.0(48.0,104.0) | ▬ | ▬ | 68.0(50.0,88.0) | ▬ | ▬ | 68.0(48.0,104.0) | ▬ | ▬
1 min
N | 24 | 24 | 24 | 19 | 19 | 19 | 43 | 43 | 43
Mean (SD) | 68.7 (15.7) | −0.8 (7.1) | −1.7% (11.5%) | 71.6 (12.5) | 1.2 (4.8) | 1.3% (6.7%) | 70.0 (14.3) | 0.0 (6.2) | −0.4% (9.7%)
Median (Min, Max) | 70.0(31.0,106.0) | 0.0(−24.0,12.0) | 0.0%(−43.6%,17.7%) | 68.0(52.0,96.0) | 2.0(−7.0,13.0) | 2.5%(−11.5%,17.1%) | 70.0(31.0,106.0) | 0.0(−24.0,13.0) | 0.0%(−43.6%,17.7%)
2 mins
N | 24 | 24 | 24 | 19 | 19 | 19 | 43 | 43 | 43
Mean (SD) | 70.8 (18.2) | 1.3 (8.8) | 1.0% (13.3%) | 72.8 (12.8) | 2.3 (6.6) | 3.1% (8.9%) | 71.7 (15.9) | 1.8 (7.8) | 1.9% (11.5%)
Median (Min, Max) | 70.0(33.0,124.0) | 1.0(−22.0,20.0) | 1.5%(−40.0%,26.5%) | 72.0(52.0,92.0) | 0.0(−6.0,16.0) | 0.0%(−8.6%,21.1%) | 70.0(33.0,124.0) | 0.0(−22.0,20.0) | 0.0%(−40.0%,26.5%)
3 mins
N | 24 | 24 | 24 | 19 | 19 | 19 | 43 | 43 | 43
Mean (SD) | 73.5 (18.4) | 4.0 (8.7) | 4.8% (12.1%) | 76.4 (16.7) | 5.9 (9.5) | 7.7% (12.1%) | 74.8 (17.5) | 4.8 (9.0) | 6.1% (12.1%)
Median (Min, Max) | 72.0(44.0,124.0) | 3.0(−12.0,20.0) | 3.6%(−16.4%,26.5%) | 76.0(50.0,116.0) | 4.0(−6.0,28.0) | 5.1%(−9.1 %,31.8%) | 74.0(44.0,124.0) | 4.0(−12.0,28.0) | 5.1%(−16.4%,31.8%)
4 mins
N | 24 | 24 | 24 | 19 | 19 | 19 | 43 | 43 | 43
Mean (SD) | 75.1 (17.4) | 5.6 (8.9) | 7.6% (12.6%) | 78.8 (17.5) | 8.4 (10.7) | 11.1% (13.7%) | 76.8 (17.4) | 6.8 (9.7) | 9.2% (13.1%)
Median (Min, Max) | 76.0(46.0,120.0) | 2.0(−12.0,20.0) | 3.4%(−16.0%,27.0%) | 76.0(50.0,116.0) | 6.0(−6.0,33.0) | 9.4%(−9.1%,44.0%) | 76.0(46.0,120.0) | 4.0(−12.0,33.0) | 6.5%(−16.0%,44.0%)
5 mins
N | 24 | 24 | 24 | 18 | 18 | 18 | 42 | 42 | 42
Mean (SD) | 74.5 (16.8) | 5.0 (9.3) | 6.9% (13.3%) | 78.8 (14.9) | 9.3 (10.2) | 13.2% (13.5%) | 76.3 (16.0) | 6.8 (9.8) | 9.6% (13.6%)
Median (Min, Max) | 77.0(48.0,116.0) | 1.5(−12.0,22.0) | 2.1%(−16.0%,30.0%) | 76.0(52.0,106.0) | 9.5(−6.0,31.0) | 14.7%(−7.3%,41.3%) | 76.0(48.0,116.0) | 5.0(−12.0,31.0) | 7.3%(−16.0%,41.3%)
6 mins
N | 24 | 24 | 24 | 17 | 17 | 17 | 41 | 41 | 41
Mean (SD) | 72.9 (15.9) | 3.4 (10.0) | 5.0% (14.4%) | 78.0 (14.2) | 9.1 (10.2) | 13.2% (13.9%) | 75.0 (15.3) | 5.8 (10.3) | 8.4% (14.6%)
Median (Min, Max) | 70.0(48.0,114.0) | 2.0(−18.0,24.0) | 3.0%(−22.5%,36.7%) | 78.0(52.0,99.0) | 10.0(−8.0,23.0) | 17.7%(−9.8%,30.6%) | 74.0(48.0,114.0) | 5.0(−18.0,24.0) | 6.8%(−22.5%,36.7%)
7 mins
N | 24 | 24 | 24 | 17 | 17 | 17 | 41 | 41 | 41
Mean (SD) | 71.8 (14.7) | 2.3 (8.8) | 3.6% (13.5%) | 79.2 (13.9) | 10.3 (10.4) | 15.1% (14.9%) | 74.9 (14.7) | 5.6 (10.2) | 8.3% (15.0%)
Median (Min, Max) | 71.0(48.0,106.0) | 1.0(−11.0,24.0) | 1.0%(−14.7%,40.0%) | 80.0(50.0,98.0) | 12.0(−6.0,23.0) | 19.7%(−7.7%,35.5%) | 74.0(48.0,106.0) | 2.0(−11.0,24.0) | 3.1%(−14.7%,40.0%)
8 mins
N | 24 | 24 | 24 | 15 | 15 | 15 | 39 | 39 | 39
Mean (SD) | 72.2 (15.2) | 2.7 (9.0) | 4.1% (14.0%) | 80.1 (14.4) | 11.5 (11.0) | 17.0% (15.7%) | 75.2 (15.2) | 6.1 (10.6) | 9.1% (15.8%)
Median (Min, Max) | 70.0(52.0,114.0) | 0.0(−10.0,28.0) | 0.0%(−13.5%,46.7%) | 77.0(52.0,104.0) | 16.0(−8.0,29.0) | 20.6%(−9.8%,38.7%) | 74.0(52.0,114.0) | 4.0(−10.0,29.0) | 6.1%(−13.5%,46.7%)
9 mins
N | 23 | 23 | 23 | 15 | 15 | 15 | 38 | 38 | 38
Mean (SD) | 72.0 (15.3) | 2.1 (9.2) | 3.3% (14.1%) | 81.3 (15.3) | 12.7 (11.8) | 18.7% (16.8%) | 75.6 (15.8) | 6.3 (11.4) | 9.4% (16.8%)
Median (Min, Max) | 70.0(50.0,114.0) | 0.0(−11.0,30.0) | 0.0%(−14.7%,50.0%) | 78.0(52.0,114.0) | 14.0(−6.0,39.0) | 20.6%(−7.3%,52.0%) | 74.0(50.0,114.0) | 2.0(−11.0,39.0) | 3.6%(−14.7%,52.0%)
10 mins
N | 22 | 22 | 22 | 14 | 14 | 14 | 36 | 36 | 36
Mean (SD) | 72.0 (15.3) | 1.7 (7.2) | 2.4% (10.4%) | 81.1 (16.2) | 12.4 (12.5) | 18.3% (17.5%) | 75.5 (16.1) | 5.9 (10.8) | 8.6% (15.5%)
Median (Min, Max) | 70.0(50.0,110.0) | 3.5(−10.0,20.0) | 5.3%(−13.5%,27.0%) | 79.0(52.0,117.0) | 15.0(−6.0,42.0) | 20.6%(−7.3%,56.0%) | 74.5(50.0,117.0) | 4.5(−10.0,42.0) | 5.8%(−13.5%,56.0%)
11 mins
N | 22 | 22 | 22 | 12 | 12 | 12 | 34 | 34 | 34
Mean (SD) | 73.0 (15.1) | 2.7 (8.2) | 4.1% (12.3%) | 77.3 (13.0) | 10.0 (10.2) | 15.4% (15.4%) | 74.5 (14.4) | 5.3 (9.5) | 8.1% (14.3%)
Median (Min, Max) | 72.0(52.0,112.0) | 1.5(−11.0,20.0) | 2.3%(−14.9%,27.0%) | 78.0(50.0,98.0) | 13.0(−8.0,22.0) | 18.6%(−9.8%,35.5%) | 72.5(50.0,112.0) | 4.5(−11.0,22.0) | 6.7%(−14.9%,35.5%)
12 mins
N | 22 | 22 | 22 | 11 | 11 | 11 | 33 | 33 | 33
Mean (SD) | 73.0 (14.0) | 2.7 (8.0) | 4.3% (12.1%) | 78.1 (13.0) | 10.2 (9.2) | 15.5% (13.6%) | 74.7 (13.7) | 5.2 (9.0) | 8.0% (13.5%)
Median (Min, Max) | 70.0(54.0,104.0) | 2.5(−10.0,20.0) | 3.9%(−13.3%,29.4%) | 80.0(52.0,98.0) | 12.0(−6.0,21.0) | 17.7%(−7.3%,32.7%) | 74.0(52.0,104.0) | 4.0(−10.0,21.0) | 5.7%(−13.3%,32.7%)
13 mins
N | 22 | 22 | 22 | 10 | 10 | 10 | 32 | 32 | 32
Mean (SD) | 72.6 (13.8) | 2.4 (7.5) | 3.8% (11.4%) | 77.4 (11.7) | 10.7 (8.9) | 16.7% (13.8%) | 74.1 (13.2) | 5.0 (8.8) | 7.8% (13.4%)
Median (Min, Max) | 69.0(50.0,102.0) | 3.0(−13.0,18.0) | 4.2%(−17.3%,29.2%) | 79.0(52.0,96.0) | 14.0(−4.0,22.0) | 20.9%(−4.9%,35.5%) | 74.0(50.0,102.0) | 4.0(−13.0,22.0) | 5.9%(−17.3%,35.5%)
14 mins
N | 21 | 21 | 21 | 9 | 9 | 9 | 30 | 30 | 30
Mean (SD) | 72.2 (13.4) | 2.7 (8.1) | 4.4% (12.6%) | 77.8 (10.4) | 11.0 (9.1) | 17.6% (14.1%) | 73.9 (12.7) | 5.2 (9.1) | 8.4% (14.2%)
Median (Min, Max) | 67.0(48.0,100.0) | 4.0(−10.0,18.0) | 6.1%(−17.2%,33.3%) | 82.0(58.0,94.0) | 14.0(−6.0,20.0) | 20.6%(−7.3%,34.6%) | 75.0(48.0,100.0) | 6.0(−10.0,20.0) | 8.1%(−17.2%,34.6%)
15 mins
N | 20 | 20 | 20 | 9 | 9 | 9 | 29 | 29 | 29
Mean (SD) | 71.0 (12.7) | 2.4 (6.8) | 4.0% (11.3%) | 76.7 (11.7) | 9.9 (8.5) | 15.5% (13.6%) | 72.8 (12.5) | 4.7 (8.1) | 7.5% (13.0%)
Median (Min, Max) | 70.0(46.0,106.0) | 2.5(−12.0,14.0) | 4.3%(−20.7%,29.2%) | 80.0(52.0,92.0) | 8.0(−2.0,20.0) | 11.8%(−2.4%,32.3%) | 72.0(46.0,106.0) | 4.0(−12.0,20.0) | 5.6%(−20.7%,32.3%)
16 mins
N | 20 | 20 | 20 | 9 | 9 | 9 | 29 | 29 | 29
Mean (SD) | 70.2 (14.8) | 1.6 (8.3) | 2.4% (12.9%) | 75.4 (12.8) | 8.8 (6.7) | 13.3% (10.0%) | 71.8 (14.2) | 3.8 (8.4) | 5.8% (12.9%)
Median (Min, Max) | 69.5(44.0,112.0) | 4.0(−16.0,12.0) | 5.7%(−24.2%,20.8%) | 82.0(52.0,92.0) | 6.0(0.0,18.0) | 11.1%(0.0%,28.1%) | 74.0(44.0,112.0) | 6.0(−16.0,18.0) | 7.7%(−24.2%,28.1%)
17 mins
N | 20 | 20 | 20 | 9 | 9 | 9 | 29 | 29 | 29
Mean (SD) | 69.3 (13.6) | 0.7 (7.3) | 1.2% (11.4%) | 74.2 (15.0) | 7.6 (9.2) | 11.3% (14.0%) | 70.8 (13.9) | 2.8 (8.4) | 4.3% (12.9%)
Median (Min, Max) | 71.0(44.0,104.0) | 0.0(−14.0,16.0) | 0.0%(−24.1%,27.6%) | 84.0(54.0,91.0) | 6.0(−8.0,20.0) | 8.0%(−12.9%,31.3%) | 72.0(44.0,104.0) | 2.0(−14.0,20.0) | 3.0%(−24.1%,31.3%)
18 mins
N | 20 | 20 | 20 | 8 | 8 | 8 | 28 | 28 | 28
Mean (SD) | 69.3 (14.3) | 0.7 (8.2) | 1.0% (13.1%) | 76.4 (13.3) | 9.1 (8.0) | 13.9% (11.8%) | 71.3 (14.1) | 3.1 (8.9) | 4.7% (13.8%)
Median (Min, Max) | 71.0(42.0,104.0) | 0.0(−14.0,22.0) | 0.0%(−24.1%,37.9%) | 82.0(54.0,92.0) | 6.5(−2.0,22.0) | 10.5%(−2.4%,34.4%) | 72.0(42.0,104.0) | 3.0(−14.0,22.0) | 4.8%(−24.1%,37.9%)
19 mins
N | 20 | 20 | 20 | 8 | 8 | 8 | 28 | 28 | 28
Mean (SD) | 70.6 (14.7) | 2.0 (9.1) | 2.9% (15.1%) | 76.6 (13.4) | 9.4 (8.2) | 14.3% (11.8%) | 72.3 (14.4) | 4.1 (9.3) | 6.1% (15.0%)
Median (Min, Max) | 73.0(38.0,102.0) | 0.0(−10.0,30.0) | 0.0%(−20.8%,51.7%) | 81.0(54.0,91.0) | 7.0(−2.0,22.0) | 11.4%(−2.4%,32.4%) | 74.0(38.0,102.0) | 3.0(−10.0,30.0) | 4.9%(−20.8%,51.7%)
20 mins
N | 20 | 20 | 20 | 8 | 8 | 8 | 28 | 28 | 28
Mean (SD) | 72.0 (16.3) | 3.4 (10.9) | 4.9% (17.0%) | 76.5 (12.7) | 9.3 (7.6) | 14.2% (11.4%) | 73.3 (15.3) | 5.0 (10.3) | 7.6% (16.0%)
Median (Min, Max) | 71.0(40.0,110.0) | 1.5(−11.0,32.0) | 2.2%(−16.7%,55.2%) | 82.0(54.0,91.0) | 7.0(0.0,20.0) | 13.3%(0.0%,31.3%) | 75.0(40.0,110.0) | 3.5(−11.0,32.0) | 4.8%(−16.7%,55.2%)
21 mins
N | 20 | 20 | 20 | 8 | 8 | 8 | 28 | 28 | 28
Mean (SD) | 72.2 (16.0) | 3.6 (10.8) | 5.3% (16.6%) | 76.5 (13.3) | 9.3 (8.3) | 14.2% (12.2%) | 73.4 (15.1) | 5.2 (10.3) | 7.8% (15.8%)
Median (Min, Max) | 72.0(44.0,106.0) | 0.0(−10.0,32.0) | 0.0%(−12.8%,55.2%) | 82.0(54.0,91.0) | 7.0(−2.0,22.0) | 11.4%(−2.4%,34.4%) | 75.0(44.0,106.0) | 3.5(−10.0,32.0) | 5.6%(−12.8%,55.2%)
22 mins
N | 20 | 20 | 20 | 8 | 8 | 8 | 28 | 28 | 28
Mean (SD) | 71.3 (13.6) | 2.7 (6.7) | 4.0% (10.1%) | 76.4 (13.5) | 9.1 (7.8) | 13.8% (11.8%) | 72.8 (13.5) | 4.5 (7.5) | 6.8% (11.3%)
Median (Min, Max) | 72.5(48.0,106.0) | 0.5(−6.0,18.0) | 0.9%(−7.7%,31.0%) | 83.0(52.0,91.0) | 7.5(0.0,22.0) | 12.2%(0.0%,34.4%) | 73.5(48.0,106.0) | 2.0(−6.0,22.0) | 3.4%(−7.7%,34.4%)
23 mins
N | 19 | 19 | 19 | 8 | 8 | 8 | 27 | 27 | 27
Mean (SD) | 69.8 (13.6) | 1.5 (5.2) | 2.1% (7.4%) | 76.6 (13.4) | 9.4 (8.4) | 14.3% (12.5%) | 71.8 (13.7) | 3.8 (7.2) | 5.7% (10.6%)
Median (Min, Max) | 70.0(48.0,108.0) | 2.0(−10.0,10.0) | 2.8%(−12.8%,13.5%) | 82.0(52.0,91.0) | 8.0(−2.0,22.0) | 13.1%(−2.4%,34.4%) | 72.0(48.0,108.0) | 2.0(−10.0,22.0) | 3.9%(−12.8%,34.4%)
24 mins
N | 20 | 20 | 20 | 8 | 8 | 8 | 28 | 28 | 28
Mean (SD) | 69.0 (13.9) | 0.4 (5.2) | 0.4% (7.2%) | 77.4 (13.2) | 10.1 (7.6) | 15.4% (11.3%) | 71.4 (14.0) | 3.2 (7.4) | 4.7% (10.8%)
Median (Min, Max) | 68.0(48.0,110.0) | 0.5(−10.0,12.0) | 0.9%(−12.8%,16.2%) | 82.0(54.0,94.0) | 9.5(0.0,22.0) | 15.3%(0.0%,34.4%) | 70.5(48.0,110.0) | 2.0(−10.0,22.0) | 3.2%(−12.8%,34.4%)
25 mins
N | 20 | 20 | 20 | 8 | 8 | 8 | 28 | 28 | 28
Mean (SD) | 68.5 (13.7) | −0.1 (5.1) | −0.3% (7.3%) | 77.3 (13.4) | 10.0 (8.5) | 15.3% (12.6%) | 71.0 (13.9) | 2.8 (7.7) | 4.1% (11.4%)
Median (Min, Max) | 69.0(46.0,106.0) | 1.0(−11.0,8.0) | 1.0%(−14.7%,11.1%) | 83.0(54.0,93.0) | 9.5(−2.0,22.0) | 15.3%(−2.4%,34.4%) | 70.0(46.0,106.0) | 2.0(−11.0,22.0) | 3.0%(−14.7%,34.4%)
26 mins
N | 20 | 20 | 20 | 8 | 8 | 8 | 28 | 28 | 28
Mean (SD) | 68.1 (13.3) | −0.6 (5.8) | −0.8% (8.5%) | 76.4 (13.0) | 9.1 (8.3) | 14.1% (12.4%) | 70.4 (13.5) | 2.2 (7.8) | 3.4% (11.7%)
Median (Min, Max) | 68.0(48.0,104.0) | 0.0(−14.0,8.0) | 0.0%(−18.7%,11.8%) | 81.0(54.0,93.0) | 8.5(−2.0,22.0) | 14.2%(−2.4%,34.4%) | 70.5(48.0,104.0) | 2.0(−14.0,22.0) | 2.7%(−18.7%,34.4%)
27 mins
N | 20 | 20 | 20 | 7 | 7 | 7 | 27 | 27 | 27
Mean (SD) | 69.8 (14.4) | 1.2 (6.7) | 1.6% (9.6%) | 76.0 (12.9) | 6.9 (9.0) | 10.3% (13.4%) | 71.4 (14.0) | 2.7 (7.6) | 3.9% (11.1%)
Median (Min, Max) | 72.0(48.0,106.0) | 1.0(−12.0,18.0) | 1.6%(−17.2%,24.3%) | 78.0(52.0,91.0) | 2.0(−2.0,22.0) | 4.0%(−2.4%,34.4%) | 74.0(48.0,106.0) | 1.0(−12.0,22.0) | 1.8%(−17.2%,34.4%)
28 mins
N | 20 | 20 | 20 | 7 | 7 | 7 | 27 | 27 | 27
Mean (SD) | 71.3 (15.0) | 2.7 (9.3) | 3.9% (12.9%) | 78.4 (12.6) | 9.3 (8.7) | 13.9% (13.0%) | 73.1 (14.5) | 4.4 (9.5) | 6.5% (13.5%)
Median (Min, Max) | 70.0(50.0,108.0) | 0.0(−9.0,34.0) | 0.0%(−12.0%,46.0%) | 80.0(56.0,90.0) | 10.0(−2.0,24.0) | 12.8%(−2.4%,37.5%) | 72.0(50.0,108.0) | 1.0(−9.0,34.0) | 1.8%(−12.0%,46.0%)
29 mins
N | 20 | 20 | 20 | 8 | 8 | 8 | 28 | 28 | 28
Mean (SD) | 69.9 (14.1) | 1.3 (9.5) | 2.1% (12.7%) | 78.0 (11.8) | 9.9 (8.0) | 15.0% (12.1%) | 72.2 (13.8) | 3.8 (9.7) | 5.8% (13.7%)
Median (Min, Max) | 69.5(48.0,108.0) | 1.0(−12.0,34.0) | 1.6%(−14.7%,46.0%) | 83.0(56.0,89.0) | 9.5(0.0,24.0) | 14.6%(0.0%,37.5%) | 73.0(48.0,108.0) | 2.0(−12.0,34.0) | 2.6%(−14.7%,46.0%)
30 mins
N | 20 | 20 | 20 | 8 | 8 | 8 | 28 | 28 | 28
Mean (SD) | 70.1 (13.2) | 1.5 (8.9) | 2.5% (12.1%) | 77.8 (11.5) | 9.6 (7.2) | 14.6% (10.9%) | 72.3 (13.0) | 3.8 (9.1) | 6.0% (12.8%)
Median (Min, Max) | 69.0(50.0,104.0) | 0.0(−12.0,30.0) | 0.0%(−13.3%,40.5%) | 82.0(56.0,90.0) | 9.5(0.0,22.0) | 15.0%(0.0%,34.4%) | 72.0(50.0,104.0) | 2.0(−12.0,30.0) | 3.3%(−13.3%,40.5%)

Table 14.2.1.3 Descriptive Statistics for MAP Scores By Time and Treatment (Follow-Up Phase) ITT Population

Assessments/Statistics | SNP; (N=24) | | | Placebo; (N=21) | | | Total; (N=45)
Assessments/Statistics | MAP (mmHg) | Change from B1 | Percentage of Change from B1 | MAP (mmHg) | Change from B1 | Percentage of Change from B1 | MAP (mmHg) | Change from B1 | Percentage of Change from B1
Study Drug D/C
N | 23 | 23 | 23 | 21 | 21 | 21 | 44 | 44 | 44
Mean (SD) | 74.1 (14.5) | −18.9 (11.9) | −19.6% (12.4%) | 72.0 (10.6) | −25.8 (16.9) | −24.9% (14.4%) | 73.1 (12.7) | −22.2 (14.7) | −22.1% (13.5%)
Median (Min, Max) | 73.0(46.0,104.0) | −23.0(−38.0,6.0) | −23.5%(−37.8%,8.6%) | 71.0(56.0,90.0) | −26.0(−56.0,6.0) | −26.0%(−49.1%,7.1%) | 72.0(46.0,104.0) | −25.0(−56.0,6.0) | −25.5%(−49.1%,8.6%)
8 Hours Post Blinded Study Drug
N | 23 | 23 | 23 | 21 | 21 | 21 | 44 | 44 | 44
Mean (SD) | 77.2 (12.5) | −15.7 (13.9) | −15.6% (13.0%) | 73.5 (11.7) | −24.3 (18.1) | −23.1% (16.5%) | 75.4 (12.1) | −19.8 (16.5) | −19.2% (15.1%)
Median (Min, Max) | 75.0(54.0,101.0) | −18.0(−43.0,12.0) | −18.0%(−38.7%,13.6%) | 74.0(51.0,100.0) | −24.0(−54.0,9.0) | −24.1%(−44.0%, 11.4%) | 74.0(51.0,101.0) | −19.5(−54.0,12.0) | −20.9%(−44.0%,13.6%)
24 Hours Post Blinded Study Drug
N | 23 | 23 | 23 | 21 | 21 | 21 | 44 | 44 | 44
Mean (SD) | 76.1 (18.5) | −16.7 (12.3) | −17.9% (13.1%) | 78.0 (14.0) | −19.8 (15.5) | −19.1% (14.6%) | 77.0 (16.3) | −18.2 (13.9) | −18.5% (13.7%)
Median (Min, Max) | 70.0(51.0,121.0) | −18.0(−37.0,6.0) | −18.6%(−42.1%,5.9%) | 78.0(48.0,103.0) | −18.0(−50.0,6.0) | −18.5%(−47.3%,7.6%) | 74.5(48.0,121.0) | −18.0(−50.0,6.0) | −18.5%(−47.3%,7.6%)

Table 14.2.2 Summary of Treatment Success by Treatment ITT Population

| Treatment | | Total; (N=45) | P Value^2^
| SNP; (N=24) | Placebo; (N=21) | Total; (N=45) | P Value^2^
Number of Subjects
Treatment Success | 11 (55.0%) | 4 (21.1%) | 15 (38.5%) | 0.048
Treatment Failure | 9 (45.0%) | 15 (78.9%) | 24 (61.5%)
Treatment Failure Rate by Time in Blinded Phase (mins)^1^
5 | 20.0% | 33.3% | 26.3% | 0.028
10 | 25.0% | 66.7% | 44.7%
15 | 40.0% | 77.8% | 57.9%
20 | 45.0% | 77.8% | 60.5%

Note:

1 Treatment failure rate is derived from the Product-Limit Survival Estimates.

2 The equality of treatment success proportions is tested using Fisher’s exact test. The time to treatment failure is compared between treatment groups using the log-rank test.

Table 14.2.3 Summary of Treatment Success by Treatment and Site ITT Population

| Site | | | | P Value
| West Virginia | | Other | | P Value
| SNP | Placebo | SNP | Placebo | Treatment^1^
Number of Subjects
Treatment Success | 7 (46.7%) | 3 (21.4%) | 4 (80.0%) | 1 (20.0%) | 0.049
Treatment Failure | 8 (53.3%) | 11 (78.6%) | 1 (20.0%) | 4 (80.0%)

Note

1 The equality of treatment success proportions is tested using exact conditional logistic regression stratified by treatment site.

Table 14.3.1.1.1 Summary of Adverse Events by Severity and Relationship to Treatment for Each Treatment Group (Open-Label, Blinded, and Follow-Up Phases) ITT Population

| Treatment | | Total; (N=46) | P Value^1^
| SNP; (N=25) | Placebo; (N=21) | Total; (N=46) | P Value^1^
Number of Events/Enrollments
Number of Adverse Events | 44 | 44 | 88
Enrollments with at least one AE | 15 (60.0%) | 14 (66.7%) | 29 (63.0%) | 0.762
Number of SAEs | 4 | 4 | 8
Enrollments with at least one SAE | 3 (12.0%) | 4 (19.0%) | 7 (15.2%) | 0.686
Severity (All AEs)
Mild | 38 | 36 | 74
Moderate | 2 | 5 | 7
Severe | 1 | 1 | 2
Life threatening | 2 | 1 | 3
Death | 1 | 1 | 2
Highest Severity Per Enrollment
Mild | 10 (40.0%) | 8 (38.1%) | 18 (39.1%)
Moderate | 2 (8.0%) | 3 (14.3%) | 5 (10.9%)
Severe | 0 | 1 (4.8%) | 1 (2.2%)
Life threatening | 2 (8.0%) | 1 (4.8%) | 3 (6.5%)
Death | 1 (4.0%) | 1 (4.8%) | 2 (4.3%)
Relationship (All AEs)
Unrelated | 28 | 32 | 60
Possibly related | 13 | 7 | 20
Probably related | 3 | 4 | 7
Definitely related | 0 | 1 | 1
Strongest Relationship Per Enrollment
Unrelated | 7 (28.0%) | 8 (38.1%) | 15 (32.6%)
Possibly related | 5 (20.0%) | 2 (9.5%) | 7 (15.2%)
Probably related | 3 (12.0%) | 3 (14.3%) | 6 (13.0%)
Definitely related | 0 | 1 (4.8%) | 1 (2.2%)
Severity (All SAEs)
Moderate | 0 | 1 | 1
Severe | 1 | 1 | 2
Life threatening | 2 | 1 | 3
Death | 1 | 1 | 2
Relationship (All SAEs)
Unrelated | 2 | 4 | 6
Possibly related | 1 | 0 | 1
Probably related | 1 | 0 | 1
Type of SAE (All SAEs)
System Organ Class
Preferred Term
Cardiac disorders | 1 | 1 | 2
Pericardial effusion | 0 | 1 | 1
Ventricular fibrillation | 1 | 0 | 1
Infections and infestations | 1 | 0 | 1
Sepsis | 1 | 0 | 1
Investigations | 1 | 0 | 1
Blood cyanide increased | 1 | 0 | 1
Nervous system disorders | 0 | 1 | 1
Intracranial hypotension | 0 | 1 | 1
Respiratory, thoracic and mediastinal disorders | 1 | 2 | 3
Apnoea | 0 | 1 | 1
Respiratory depression | 1 | 0 | 1
Respiratory failure | 0 | 1 | 1

Note:

1 The difference of percentage of enrollments who experenced at least one AEs or SAEs between treatment groups is tested using Fisher’s exact test.

Table 14.3.1.1.2 Summary of Adverse Events by Severity and Relationship To Treatment For ITT Population and Subjects Who Did Not Receive Blinded Treatment (Open-Label Phase) Safety Population

| Not Received Blind Treatment; (N=6) | ITT Population; (N=46) | Total; (N=52) | P Value^1^
Number of Events/Enrollments
Number of Adverse Events | 3 | 50 | 53
Enrollments with at least one AE | 3 (50.0%) | 23 (50.0%) | 26 (50.0%) | 1.000
Number of SAEs | 0 | 2 | 2
Enrollments with at least one SAE | 0 | 2 (4.3%) | 2 (3.8%) | 1.000
Severity (All AEs)
Mild | 2 | 43 | 45
Moderate | 1 | 5 | 6
Severe | 0 | 1 | 1
Life threatening | 0 | 1 | 1
Highest Severity Per Enrollment
Mild | 2 (33.3%) | 16 (34.8%) | 18 (34.6%)
Moderate | 1 (16.7%) | 5 (10.9%) | 6 (11.5%)
Severe | 0 | 1 (2.2%) | 1 (1.9%)
Life threatening | 0 | 1 (2.2%) | 1 (1.9%)
Relationship (All AEs)
Unrelated | 1 | 31 | 32
Possibly related | 1 | 15 | 16
Probably related | 1 | 4 | 5
Strongest Relationship Per Enrollment
Unrelated | 1 (16.7%) | 12 (26.1%) | 13 (25.0%)
Possibly related | 1 (16.7%) | 7 (15.2%) | 8 (15.4%)
Probably related | 1 (16.7%) | 4 (8.7%) | 5 (9.6%)
Severity (All SAEs)
Severe | 0 | 1 | 1
Life threatening | 0 | 1 | 1
Relationship (All SAEs)
Unrelated | 0 | 1 | 1
Probably related | 0 | 1 | 1
Type of SAE (All SAEs)
System Organ Class
Preferred Term
Investigations | 0 | 1 | 1
Blood cyanide increased | 0 | 1 | 1
Respiratory, thoracic and mediastinal disorders | 0 | 1 | 1
Apnoea | 0 | 1 | 1

Note:

1 Fisher’s exact test is used to compare the percentage of enrollments who experenced at least one AEs or SAEs between ITT population and subjects who did not receive blind treatment.

Table 14.3.1.1.3 Summary of Adverse Events by Severity and Relationship to Treatment for Each Treatment Group (Blinded Phase) ITT Population

| Treatment | | Total; (N=46) | P Value^1^
| SNP; (N=25) | Placebo; (N=21) | Total; (N=46) | P Value^1^
Number of Events/Enrollments
Number of Adverse Events | 2 | 1 | 3
Enrollments with at least one AE | 2 (8.0%) | 1 (4.8%) | 3 (6.5%) | 1.000
Number of SAEs | 0 | 0 | 0
Severity (All AEs)
Mild | 2 | 1 | 3
Highest Severity Per Enrollment
Mild | 2 (8.0%) | 1 (4.8%) | 3 (6.5%)
Relationship (All AEs)
Unrelated | 1 | 0 | 1
Possibly related | 1 | 0 | 1
Probably related | 0 | 1 | 1
Strongest Relationship Per Enrollment
Unrelated | 1 (4.0%) | 0 | 1 (2.2%)
Possibly related | 1 (4.0%) | 0 | 1 (2.2%)
Probably related | 0 | 1 (4.8%) | 1 (2.2%)

Note:

1 Fisher’s exact test is used to compare the percentage of enrollments who experenced at least one AEs or SAEs between treatment groups.

Table 14.3.1.1.4 Summary of Adverse Events by Severity and Relationship to Treatment by Treatment Group (Follow-up Phase) ITT Population

| Treatment | | Total; (N=46) | P Value^1^
| SNP; (N=25) | Placebo; (N=21) | Total; (N=46) | P Value^1^
Number of Events/Enrollments
Number of Adverse Events | 17 | 18 | 35
Enrollments with at least one AE | 7 (28.0%) | 10 (47.6%) | 17 (37.0%) | 0.380
Number of SAEs | 3 | 3 | 6
Enrollments with at least one SAE | 3 (12.0%) | 3 (14.3%) | 6 (13.0%) | 1.000
Severity (All AEs)
Mild | 14 | 14 | 28
Moderate | 0 | 2 | 2
Severe | 0 | 1 | 1
Life threatening | 2 | 0 | 2
Death | 1 | 1 | 2
Highest Severity Per Enrollment
Mild | 4 (16.0%) | 6 (28.6%) | 10 (21.7%)
Moderate | 0 | 2 (9.5%) | 2 (4.3%)
Severe | 0 | 1 (4.8%) | 1 (2.2%)
Life threatening | 2 (8.0%) | 0 | 2 (4.3%)
Death | 1 (4.0%) | 1 (4.8%) | 2 (4.3%)
Relationship (All AEs)
Unrelated | 13 | 15 | 28
Possibly related | 3 | 1 | 4
Probably related | 1 | 1 | 2
Definitely related | 0 | 1 | 1
Strongest Relationship Per Enrollment
Unrelated | 4 (16.0%) | 8 (38.1%) | 12 (26.1%)
Possibly related | 2 (8.0%) | 0 | 2 (4.3%)
Probably related | 1 (4.0%) | 1 (4.8%) | 2 (4.3%)
Definitely related | 0 | 1 (4.8%) | 1 (2.2%)
Severity (All SAEs)
Moderate | 0 | 1 | 1
Severe | 0 | 1 | 1
Life threatening | 2 | 0 | 2
Death | 1 | 1 | 2
Relationship (All SAEs)
Unrelated | 2 | 3 | 5
Possibly related | 1 | 0 | 1
Type of SAE (All SAEs)
System Organ Class
Preferred Term
Cardiac disorders | 1 | 1 | 2
Pericardial effusion | 0 | 1 | 1
Ventricular fibrillation | 1 | 0 | 1
Infections and infestations | 1 | 0 | 1
Sepsis | 1 | 0 | 1
Nervous system disorders | 0 | 1 | 1
Intracranial hypotension | 0 | 1 | 1
Respiratory, thoracic and mediastinal disorders | 1 | 1 | 2
Respiratory depression | 1 | 0 | 1
Respiratory failure | 0 | 1 | 1

Note: There are no AEs or SAEs reported for subjects who did not receive blind treatment in the follow-up phase.

1 The difference of percentage of enrollments who experenced at least one AEs or SAEs between treatment groups is tested using Fisher’s exact test.

Table 14.3.1.2.1 Summary of Adverse Events by Severity and Relationship to Treatment by Age Classification (Open-Label, Blinded, and Follow-Up Phases) Safety Population

| Age Strata | | | | | Total; (N=52)
| 0 - < 30 days; (N=3) | 30 days - < 2 yrs; (N=21) | 2 yrs - < 6 yrs; (N=7) | 6 yrs - TS II^1^; (N=12) | TS III - 17 yrs; (N=9) | Total; (N=52)
Number of Events/Enrollments
Number of Adverse Events | 6 | 40 | 15 | 18 | 15 | 94
Enrollments with at least one AE | 2 (66.7%) | 13 (61.9%) | 4 (57.1%) | 8 (66.7%) | 5 (55.6%) | 32 (61.5%)
Number of SAEs | 2 | 2 | 2 | 2 | 0 | 8
Enrollments with at least one SAE | 1 (33.3%) | 2 (9.5%) | 2 (28.6%) | 2 (16.7%) | 0 | 7 (13.5%)
Severity (All AEs)
Mild | 4 | 35 | 11 | 15 | 14 | 79
Moderate | 0 | 3 | 3 | 1 | 1 | 8
Severe | 1 | 0 | 1 | 0 | 0 | 2
Life threatening | 1 | 2 | 0 | 0 | 0 | 3
Death | 0 | 0 | 0 | 2 | 0 | 2
Highest Severity Per Enrollment
Mild | 1 (33.3%) | 8 (38.1%) | 2 (28.6%) | 5 (41.7%) | 4 (44.4%) | 20 (38.5%)
Moderate | 0 | 3 (14.3%) | 1 (14.3%) | 1 (8.3%) | 1 (11.1%) | 6 (11.5%)
Severe | 0 | 0 | 1 (14.3%) | 0 | 0 | 1 (1.9%)
Life threatening | 1 (33.3%) | 2 (9.5%) | 0 | 0 | 0 | 3 (5.8%)
Death | 0 | 0 | 0 | 2 (16.7%) | 0 | 2 (3.8%)
Relationship (All AEs)
Unrelated | 2 | 35 | 13 | 11 | 3 | 64
Possibly related | 3 | 1 | 0 | 6 | 11 | 21
Probably related | 1 | 4 | 2 | 1 | 0 | 8
Definitely related | 0 | 0 | 0 | 0 | 1 | 1
Strongest Relationship Per Enrollment
Unrelated | 1 (33.3%) | 9 (42.9%) | 2 (28.6%) | 4 (33.3%) | 0 | 16 (30.8%)
Possibly related | 0 | 1 (4.8%) | 0 | 3 (25.0%) | 4 (44.4%) | 8 (15.4%)
Probably related | 1 (33.3%) | 3 (14.3%) | 2 (28.6%) | 1 (8.3%) | 0 | 7 (13.5%)
Definitely related | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 (1.9%)
Severity (All SAEs)
Moderate | 0 | 0 | 1 | 0 | 0 | 1
Severe | 1 | 0 | 1 | 0 | 0 | 2
Life threatening | 1 | 2 | 0 | 0 | 0 | 3
Death | 0 | 0 | 0 | 2 | 0 | 2
Relationship (All SAEs)
Unrelated | 0 | 2 | 2 | 2 | 0 | 6
Possibly related | 1 | 0 | 0 | 0 | 0 | 1
Probably related | 1 | 0 | 0 | 0 | 0 | 1
Type of SAE (All SAEs)
System Organ Class
Preferred Term
Cardiac disorders | 0 | 1 | 1 | 0 | 0 | 2
Pericardial effusion | 0 | 0 | 1 | 0 | 0 | 1
Ventricular fibrillation | 0 | 1 | 0 | 0 | 0 | 1
Infections and infestations | 0 | 0 | 0 | 1 | 0 | 1
Sepsis | 0 | 0 | 0 | 1 | 0 | 1
Investigations | 1 | 0 | 0 | 0 | 0 | 1
Blood cyanide increased | 1 | 0 | 0 | 0 | 0 | 1
Nervous system disorders | 0 | 0 | 1 | 0 | 0 | 1
Intracranial hypotension | 0 | 0 | 1 | 0 | 0 | 1
Respiratory, thoracic and mediastinal disorders | 1 | 1 | 0 | 1 | 0 | 3
Apnoea | 0 | 1 | 0 | 0 | 0 | 1
Respiratory depression | 1 | 0 | 0 | 0 | 0 | 1
Respiratory failure | 0 | 0 | 0 | 1 | 0 | 1

Note:

1 TS II: Tanner Stage II

Table 14.3.1.2.2 Summary of Adverse Events by Severity and Relationship to Treatment by Age Classification (Open-Label Phase) Safety Population

| Age Strata | | | | | Total; (N=52)
| 0 - < 30 days; (N=3) | 30 days - < 2 yrs; (N=21) | 2 yrs - < 6 yrs; (N=7) | 6 yrs - TS II^1^; (N=12) | TS III - 17 yrs; (N=9) | Total; (N=52)
Number of Events/Enrollments
Number of Adverse Events | 3 | 19 | 8 | 11 | 12 | 53
Enrollments with at least one AE | 2 (66.7%) | 10 (47.6%) | 3 (42.9%) | 6 (50.0%) | 5 (55.6%) | 26 (50.0%)
Number of SAEs | 1 | 1 | 0 | 0 | 0 | 2
Enrollments with at least one SAE | 1 (33.3%) | 1 (4.8%) | 0 | 0 | 0 | 2 (3.8%)
Severity (All AEs)
Mild | 2 | 15 | 6 | 10 | 12 | 45
Moderate | 0 | 3 | 2 | 1 | 0 | 6
Severe | 1 | 0 | 0 | 0 | 0 | 1
Life threatening | 0 | 1 | 0 | 0 | 0 | 1
Highest Severity Per Enrollment
Mild | 1 (33.3%) | 6 (28.6%) | 1 (14.3%) | 5 (41.7%) | 5 (55.6%) | 18 (34.6%)
Moderate | 0 | 3 (14.3%) | 2 (28.6%) | 1 (8.3%) | 0 | 6 (11.5%)
Severe | 1 (33.3%) | 0 | 0 | 0 | 0 | 1 (1.9%)
Life threatening | 0 | 1 (4.8%) | 0 | 0 | 0 | 1 (1.9%)
Relationship (All AEs)
Unrelated | 1 | 17 | 7 | 4 | 3 | 32
Possibly related | 1 | 0 | 0 | 6 | 9 | 16
Probably related | 1 | 2 | 1 | 1 | 0 | 5
Strongest Relationship Per Enrollment
Unrelated | 1 (33.3%) | 8 (38.1%) | 2 (28.6%) | 2 (16.7%) | 0 | 13 (25.0%)
Possibly related | 0 | 0 | 0 | 3 (25.0%) | 5 (55.6%) | 8 (15.4%)
Probably related | 1 (33.3%) | 2 (9.5%) | 1 (14.3%) | 1 (8.3%) | 0 | 5 (9.6%)
Severity (All SAEs)
Severe | 1 | 0 | 0 | 0 | 0 | 1
Life threatening | 0 | 1 | 0 | 0 | 0 | 1
Relationship (All SAEs)
Unrelated | 0 | 1 | 0 | 0 | 0 | 1
Probably related | 1 | 0 | 0 | 0 | 0 | 1
Type of SAE (All SAEs)
System Organ Class
Preferred Term
Investigations | 1 | 0 | 0 | 0 | 0 | 1
Blood cyanide increased | 1 | 0 | 0 | 0 | 0 | 1
Respiratory, thoracic and mediastinal disorders | 0 | 1 | 0 | 0 | 0 | 1
Apnoea | 0 | 1 | 0 | 0 | 0 | 1

Note: N’s in the column header represent number of subjects who experienced open-label phase in each age stratum.

1 TS II: Tanner Stage II

Table 14.3.1.2.3 Summary of Adverse Events by Severity and Relationship to Treatment by Age Classification (Blinded Phase) ITT Population

| Age Strata | | | | | Total; (N=46)
| 0 - < 30 days; (N=2) | 30 days - < 2 yrs; (N=20) | 2 yrs - < 6 yrs; (N=7) | 6 yrs - TS II^1^; (N=9) | TS III - 17 yrs; (N=8) | Total; (N=46)
Number of Events/Enrollments
Number of Adverse Events | 0 | 1 | 1 | 0 | 1 | 3
Enrollments with at least one AE | 0 | 1 (5.0%) | 1 (14.3%) | 0 | 1 (12.5%) | 3 (6.5%)
Number of SAEs | 0 | 0 | 0 | 0 | 0 | 0
Severity (All AEs)
Mild | 0 | 1 | 1 | 0 | 1 | 3
Highest Severity Per Enrollment
Mild | 0 | 1 (5.0%) | 1 (14.3%) | 0 | 1 (12.5%) | 3 (6.5%)
Relationship (All AEs)
Unrelated | 0 | 0 | 1 | 0 | 0 | 1
Possibly related | 0 | 0 | 0 | 0 | 1 | 1
Probably related | 0 | 1 | 0 | 0 | 0 | 1
Strongest Relationship Per Enrollment
Unrelated | 0 | 0 | 1 (14.3%) | 0 | 0 | 1 (2.2%)
Possibly related | 0 | 0 | 0 | 0 | 1 (12.5%) | 1 (2.2%)
Probably related | 0 | 1 (5.0%) | 0 | 0 | 0 | 1 (2.2%)

Note: N’s in the column header represent number of subjects who experienced blinded phase in each age stratum.

1 TS II: Tanner Stage II

Table 14.3.1.2.4 Summary of Adverse Events by Severity and Relationship to Treatment for Each Age Group (Follow-Up Phase) Safety Population

| Age Strata | | | | | Total; (N=52)
| 0 - < 30 days; (N=3) | 30 days - < 2 yrs; (N=21) | 2 yrs - < 6 yrs; (N=7) | 6 yrs - TS II^1^; (N=12) | TS III - 17 yrs; (N=9) | Total; (N=52)
Number of Events/Enrollments
Number of Adverse Events | 3 | 20 | 6 | 7 | 2 | 38
Enrollments with at least one AE | 1 (33.3%) | 8 (38.1%) | 4 (57.1%) | 5 (41.7%) | 1 (11.1%) | 19 (36.5%)
Number of SAEs | 1 | 1 | 2 | 2 | 0 | 6
Enrollments with at least one SAE | 1 (33.3%) | 1 (4.8%) | 2 (28.6%) | 2 (16.7%) | 0 | 6 (11.5%)
Severity (All AEs)
Mild | 2 | 19 | 4 | 5 | 1 | 31
Moderate | 0 | 0 | 1 | 0 | 1 | 2
Severe | 0 | 0 | 1 | 0 | 0 | 1
Life threatening | 1 | 1 | 0 | 0 | 0 | 2
Death | 0 | 0 | 0 | 2 | 0 | 2
Highest Severity Per Enrollment
Mild | 0 | 7 (33.3%) | 2 (28.6%) | 3 (25.0%) | 0 | 12 (23.1%)
Moderate | 0 | 0 | 1 (14.3%) | 0 | 1 (11.1%) | 2 (3.8%)
Severe | 0 | 0 | 1 (14.3%) | 0 | 0 | 1 (1.9%)
Life threatening | 1 (33.3%) | 1 (4.8%) | 0 | 0 | 0 | 2 (3.8%)
Death | 0 | 0 | 0 | 2 (16.7%) | 0 | 2 (3.8%)
Relationship (All AEs)
Unrelated | 1 | 18 | 5 | 7 | 0 | 31
Possibly related | 2 | 1 | 0 | 0 | 1 | 4
Probably related | 0 | 1 | 1 | 0 | 0 | 2
Definitely related | 0 | 0 | 0 | 0 | 1 | 1
Strongest Relationship Per Enrollment
Unrelated | 0 | 6 (28.6%) | 3 (42.9%) | 5 (41.7%) | 0 | 14 (26.9%)
Possibly related | 1 (33.3%) | 1 (4.8%) | 0 | 0 | 0 | 2 (3.8%)
Probably related | 0 | 1 (4.8%) | 1 (14.3%) | 0 | 0 | 2 (3.8%)
Definitely related | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 (1.9%)
Severity (All SAEs)
Moderate | 0 | 0 | 1 | 0 | 0 | 1
Severe | 0 | 0 | 1 | 0 | 0 | 1
Life threatening | 1 | 1 | 0 | 0 | 0 | 2
Death | 0 | 0 | 0 | 2 | 0 | 2
Relationship (All SAEs)
Unrelated | 0 | 1 | 2 | 2 | 0 | 5
Possibly related | 1 | 0 | 0 | 0 | 0 | 1
Type of SAE (All SAEs)
System Organ Class
Preferred Term
Cardiac disorders | 0 | 1 | 1 | 0 | 0 | 2
Pericardial effusion | 0 | 0 | 1 | 0 | 0 | 1
Ventricular fibrillation | 0 | 1 | 0 | 0 | 0 | 1
Infections and infestations | 0 | 0 | 0 | 1 | 0 | 1
Sepsis | 0 | 0 | 0 | 1 | 0 | 1
Nervous system disorders | 0 | 0 | 1 | 0 | 0 | 1
Intracranial hypotension | 0 | 0 | 1 | 0 | 0 | 1
Respiratory, thoracic and mediastinal disorders | 1 | 0 | 0 | 1 | 0 | 2
Respiratory depression | 1 | 0 | 0 | 0 | 0 | 1
Respiratory failure | 0 | 0 | 0 | 1 | 0 | 1

Note: N’s in the column header represent number of subjects who experienced the double-blind phase in each age stratum.

There are no AEs or SAEs reported in the follow-up phase for subjects who did not receive blind treatment.

1 TS II: Tanner Stage II

Table 14.3.1.2.5 Summary of Adverse Events by Severity and Relationship to Treatment by Age Classification (Pre-Study Phase) Safety Population

| Age Strata | | | | | Total; (N=52)
| 0 - < 30 days; (N=3) | 30 days - < 2 yrs; (N=21) | 2 yrs - < 6 yrs; (N=7) | 6 yrs - TS II^1^; (N=12) | TS III - 17 yrs; (N=9) | Total; (N=52)
Number of Events/Enrollments
Number of Adverse Events | 1 | 12 | 1 | 4 | 3 | 21
Enrollments with at least one AE | 1 (33.3%) | 4 (19.0%) | 1 (14.3%) | 2 (16.7%) | 1 (11.1%) | 9 (17.3%)
Number of SAEs | 0 | 0 | 0 | 0 | 1 | 1
Enrollments with at least one SAE | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 (1.9%)
Severity (All AEs)
Mild | 1 | 11 | 1 | 4 | 1 | 18
Moderate | 0 | 1 | 0 | 0 | 1 | 2
Severe | 0 | 0 | 0 | 0 | 1 | 1
Highest Severity Per Enrollment
Mild | 1 (33.3%) | 3 (14.3%) | 1 (14.3%) | 2 (16.7%) | 0 | 7 (13.5%)
Moderate | 0 | 1 (4.8%) | 0 | 0 | 0 | 1 (1.9%)
Severe | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 (1.9%)
Relationship (All AEs)
Unrelated | 1 | 11 | 1 | 3 | 2 | 18
Possibly related | 0 | 1 | 0 | 0 | 1 | 2
Probably related | 0 | 0 | 0 | 1 | 0 | 1
Strongest Relationship Per Enrollment
Unrelated | 1 (33.3%) | 3 (14.3%) | 1 (14.3%) | 1 (8.3%) | 0 | 6 (11.5%)
Possibly related | 0 | 1 (4.8%) | 0 | 0 | 1 (11.1%) | 2 (3.8%)
Probably related | 0 | 0 | 0 | 1 (8.3%) | 0 | 1 (1.9%)
Severity (All SAEs)
Severe | 0 | 0 | 0 | 0 | 1 | 1
Relationship (All SAEs)
Unrelated | 0 | 0 | 0 | 0 | 1 | 1
Type of SAE (All SAEs)
System Organ Class
Preferred Term
Vascular disorders | 0 | 0 | 0 | 0 | 1 | 1
Haemorrhage | 0 | 0 | 0 | 0 | 1 | 1

Note:

1 TS II: Tanner Stage II

Table 14.3.1.3 Summary of Adverse Events by Relationship to Study Product (Open-Label, Blinded, and Follow-Up Phases) Safety Population

| Relationship to Study Product^1^ | | Total; (N=94)
| Related; (N=30) | Not-related; (N=64) | Total; (N=94)
Severity (All AEs)
Mild | 23 (76.7%) | 56 (87.5%) | 79 (84.0%)
Moderate | 5 (16.7%) | 3 (4.7%) | 8 (8.5%)
Severe | 1 (3.3%) | 1 (1.6%) | 2 (2.1%)
Life threatening | 1 (3.3%) | 2 (3.1%) | 3 (3.2%)
Death | 0 | 2 (3.1%) | 2 (2.1%)

Note: N’s in the column header represent number of adverse events in each relationship group.

1 Related: AEs are those considered to be definitely, probably, or possibly related to treatment.

Not-related: AEs are those considered to be unrelated to treatment.

Table 14.3.1.4 Adverse Events by System Organ Class, Preferred Term, and Age Classification (Open-Label, Blinded, and Follow-Up Phases) Safety Population

System Organ Class; Preferred Term | Age Strata | | | | | | | | | | Total; (N=52)
System Organ Class; Preferred Term | 0 - < 30 days; (N=3) | | 30 days - < 2 yrs; (N=21) | | 2 yrs - < 6 yrs; (N=7) | | 6 yrs - TS II^1^; (N=12) | | TS III - 17 yrs; (N=9) | | Total; (N=52)
System Organ Class; Preferred Term | Enrollments with Event N (%) | Total Events | Enrollments with Event N (%) | Total Events | Enrollments with Event N (%) | Total Events | Enrollments with Event N (%) | Total Events | Enrollments with Event N (%) | Total Events | Enrollments with Event N (%) | Total Events
Cardiac disorders | 1 (33.3%) | 1 | 3 (14.3%) | 3 | 1 (14.3%) | 1 | 1 (8.3%) | 1 | 3 (33.3%) | 4 | 9 (17.3%) | 10
Bradycardia | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Pericardial effusion | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Tachycardia | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 3 (33.3%) | 4 | 5 (9.6%) | 6
Ventricular fibrillation | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Ventricular tachycardia | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Gastrointestinal disorders | 0 | 0 | 1 (4.8%) | 1 | 1 (14.3%) | 1 | 4 (33.3%) | 5 | 3 (33.3%) | 4 | 9 (17.3%) | 11
Nausea | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 1 (11.1%) | 1 | 2 (3.8%) | 2
Pancreatitis | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Vomiting | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 4 (33.3%) | 4 | 3 (33.3%) | 3 | 8 (15.4%) | 8
General disorders and administration site conditions | 0 | 0 | 4 (19%) | 4 | 0 | 0 | 2 (16.7%) | 2 | 2 (22.2%) | 2 | 8 (15.4%) | 8
Oedema peripheral | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Pain | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 1 (8.3%) | 1 | 1 (11.1%) | 1 | 3 (5.8%) | 3
Pyrexia | 0 | 0 | 2 (9.5%) | 2 | 0 | 0 | 1 (8.3%) | 1 | 1 (11.1%) | 1 | 4 (7.7%) | 4
Infections and infestations | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
Sepsis | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
Injury, poisoning and procedural complications | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
Procedural pain | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
Investigations | 2 (66.7%) | 2 | 6 (28.6%) | 16 | 3 (42.9%) | 8 | 2 (16.7%) | 2 | 1 (11.1%) | 2 | 14 (26.9%) | 30
Blood albumin decreased | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Blood cyanide increased | 1 (33.3%) | 1 | 2 (9.5%) | 2 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 4 (7.7%) | 4
Blood lactic acid increased | 0 | 0 | 2 (9.5%) | 2 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 3 (5.8%) | 3
Blood magnesium decreased | 0 | 0 | 2 (9.5%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2
Blood potassium decreased | 0 | 0 | 2 (9.5%) | 2 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 3 (5.8%) | 3
Body temperature decreased | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Body temperature increased | 0 | 0 | 1 (4.8%) | 1 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2
Calcium ionised decreased | 0 | 0 | 2 (9.5%) | 2 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 3 (5.8%) | 3
Gastric occult blood positive | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Haematocrit decreased | 0 | 0 | 1 (4.8%) | 1 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2
Haemoglobin decreased | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Urine analysis abnormal | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 1 (1.9%) | 1
Urine output decreased | 0 | 0 | 1 (4.8%) | 1 | 1 (14.3%) | 1 | 1 (8.3%) | 1 | 1 (11.1%) | 1 | 4 (7.7%) | 4
White blood cell count increased | 1 (33.3%) | 1 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2
Metabolism and nutrition disorders | 1 (33.3%) | 1 | 4 (19%) | 4 | 1 (14.3%) | 1 | 1 (8.3%) | 1 | 0 | 0 | 7 (13.5%) | 7
Hyperglycaemia | 0 | 0 | 1 (4.8%) | 1 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2
Hypocalcaemia | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 2 (3.8%) | 2
Hypoglycaemia | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Hypokalaemia | 0 | 0 | 2 (9.5%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2
Nervous system disorders | 1 (33.3%) | 1 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2
Convulsion | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Intracranial hypotension | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Psychiatric disorders | 0 | 0 | 1 (4.8%) | 1 | 1 (14.3%) | 1 | 0 | 0 | 1 (11.1%) | 1 | 3 (5.8%) | 3
Agitation | 0 | 0 | 1 (4.8%) | 1 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2
Anxiety | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 1 (1.9%) | 1
Renal and urinary disorders | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 1 (1.9%) | 1
Urinary retention | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 1 (1.9%) | 1
Respiratory, thoracic and mediastinal disorders | 1 (33.3%) | 1 | 5 (23.8%) | 9 | 1 (14.3%) | 1 | 2 (16.7%) | 2 | 0 | 0 | 9 (17.3%) | 13
Apnoea | 0 | 0 | 2 (9.5%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2
Atelectasis | 0 | 0 | 2 (9.5%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2
Hypercapnia | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Pleural effusion | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Pneumothorax | 0 | 0 | 2 (9.5%) | 2 | 1 (14.3%) | 1 | 1 (8.3%) | 1 | 0 | 0 | 4 (7.7%) | 4
Rales | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Respiratory depression | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Respiratory failure | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
Skin and subcutaneous tissue disorders | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 1 (8.3%) | 1 | 0 | 0 | 2 (3.8%) | 2
Pruritus | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
Rash | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Vascular disorders | 0 | 0 | 2 (9.5%) | 2 | 0 | 0 | 2 (16.7%) | 2 | 1 (11.1%) | 1 | 5 (9.6%) | 5
Hypertension | 0 | 0 | 2 (9.5%) | 2 | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 3 (5.8%) | 3
Hypotension | 0 | 0 | 0 | 0 | 0 | 0 | 2 (16.7%) | 2 | 0 | 0 | 2 (3.8%) | 2

Note:

1 TS II: Tanner Stage II

Table 14.3.1.5 Adverse Events by Age Classification Ordered by Most Frequent Preferred Terms (Open-Label, Blinded, and Follow-Up Phases) Safety Population

System Organ Class | Preferred Term | Age Strata | | | | | | | | | | Total; (N=52)
System Organ Class | Preferred Term | 0 - < 30 days; (N=3) | | 30 days - < 2 yrs; (N=21) | | 2 yrs - < 6 yrs; (N=7) | | 6 yrs - TS II^1^; (N=12) | | TS III - 17 yrs; (N=9) | | Total; (N=52)
System Organ Class | Preferred Term | Enrollments with Event N (%) | Total Events | Enrollments with Event N (%) | Total Events | Enrollments with Event N (%) | Total Events | Enrollments with Event N (%) | Total Events | Enrollments with Event N (%) | Total Events | Enrollments with Event N (%) | Total Events
Gastrointestinal disorders | Vomiting | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 4 (33.3%) | 4 | 3 (33.3%) | 3 | 8 (15.4%) | 8
Cardiac disorders | Tachycardia | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 3 (33.3%) | 4 | 5 (9.6%) | 6
Investigations | Blood cyanide increased | 1 (33.3%) | 1 | 2 (9.5%) | 2 | 1 (14.3%) | 1 | 0 | | 0 | 0 | 4 (7.7%) | 4
Respiratory, thoracic and mediastinal disorders | Pneumothorax | 0 | 0 | 2 (9.5%) | 2 | 1 (14.3%) | 1 | 1 (8.3%) | 1 | 0 | 0 | 4 (7.7%) | 4
General disorders and administration site conditions | Pyrexia | 0 | 0 | 2 (9.5%) | 2 | 0 | 0 | 1 (8.3%) | 1 | 1 (11.1%) | 1 | 4 (7.7%) | 4
Investigations | Urine output decreased | 0 | 0 | 1 (4.8%) | 1 | 1 (14.3%) | 1 | 1 (8.3%) | 1 | 1 (11.1%) | 1 | 4 (7.7%) | 4
Investigations | Blood lactic acid increased | 0 | 0 | 2 (9.5%) | 2 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 3 (5.8%) | 3
Investigations | Blood potassium decreased | 0 | 0 | 2 (9.5%) | 2 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 3 (5.8%) | 3
Investigations | Calcium ionised decreased | 0 | 0 | 2 (9.5%) | 2 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 3 (5.8%) | 3
Vascular disorders | Hypertension | 0 | 0 | 2 (9.5%) | 2 | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 3 (5.8%) | 3
General disorders and administration site conditions | Pain | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 1 (8.3%) | 1 | 1 (11.1%) | 1 | 3 (5.8%) | 3

Note:

1 TS II: Tanner Stage II

Events occurred in 5% or more subjects are included.

Table 14.3.1.6.1 Summary of Serious Adverse Events by Age Classification (Open-Label, Blinded, and Follow-Up Phases) Safety Population

System Organ Class; Preferred Term | Age Strata | | | | | | | | | | Total; (N=52)
System Organ Class; Preferred Term | 0 - 30 days; (N=3) | | 30 days - 2 yrs; (N=21) | | 2 yrs - 6 yrs; (N=7) | | 6 yrs - TS III^1^; (N=12) | | TS III - 17 yrs; (N=9) | | Total; (N=52)
System Organ Class; Preferred Term | Enrollments with Event N (%) | Total Events | Enrollments with Event N (%) | Total Events | Enrollments with Event N (%) | Total Events | Enrollments with Event N (%) | Total Events | Enrollments with Event N (%) | Total Events | Enrollments with Event N (%) | Total Events
Cardiac disorders | 0 | 0 | 1 (4.8%) | 1 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2
Pericardial effusion | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Ventricular fibrillation | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Infections and infestations | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
Sepsis | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
Investigations | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Blood cyanide increased | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Nervous system disorders | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Intracranial hypotension | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Respiratory, thoracic and mediastinal disorders | 1 (33.3%) | 1 | 1 (4.8%) | 1 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 3 (5.8%) | 3
Apnoea | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Respiratory depression | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Respiratory failure | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1

Note:

1 TS II: Tanner Stage II

Table 14.3.1.6.2 Summary of Serious Adverse Events by Age Classification (Open-Label Phase) Safety Population

System Organ Class; Preferred Term | Age Strata | | | | | | | | | | Total; (N=52)
System Organ Class; Preferred Term | 0 - 30 days; (N=3) | | 30 days - 2 yrs; (N=21) | | 2 yrs - 6 yrs; (N=7) | | 6 yrs - TS III^1^; (N=12) | | TS III - 17 yrs; (N=9) | | Total; (N=52)
System Organ Class; Preferred Term | Enrollments with Event N (%) | Total Events | Enrollments with Event N (%) | Total Events | Enrollments with Event N (%) | Total Events | Enrollments with Event N (%) | Total Events | Enrollments with Event N (%) | Total Events | Enrollments with Event N (%) | Total Events
Investigations | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Blood cyanide increased | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Respiratory, thoracic and mediastinal disorders | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Apnoea | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1

Note:

1 TS II: Tanner Stage II

Table 14.3.1.6.3 Summary of Serious Adverse Events by Age Classification (Follow-Up Phase) Safety Population

System Organ Class; Preferred Term | Age Strata | | | | | | | | | | Total; (N=52)
System Organ Class; Preferred Term | 0 - 30 days; (N=3) | | 30 days - 2 yrs; (N=21) | | 2 yrs - 6 yrs; (N=7) | | 6 yrs - TS III^1^; (N=12) | | TS III - 17 yrs; (N=9) | | Total; (N=52)
System Organ Class; Preferred Term | Enrollments with Event N (%) | Total Events | Enrollments with Event N (%) | Total Events | Enrollments with Event N (%) | Total Events | Enrollments with Event N (%) | Total Events | Enrollments with Event N (%) | Total Events | Enrollments with Event N (%) | Total Events
Cardiac disorders | 0 | 0 | 1 (4.8%) | 1 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2
Pericardial effusion | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Ventricular fibrillation | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Infections and infestations | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
Sepsis | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
Nervous system disorders | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Intracranial hypotension | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Respiratory, thoracic and mediastinal disorders | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 2 (3.8%) | 2
Respiratory depression | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
Respiratory failure | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1

Note:

1 TS II: Tanner Stage II

Table 14.3.1.7.1 Summary of Selected Adverse Events by Age Classification (Open-Label, Blinded, and Follow-Up Phases) Safety Population

| Age Strata | | | | | Total; (N=52)
| 0 - < 30 days; (N=3) | 30 days - < 2 yrs; (N=21) | 2 yrs - < 6 yrs; (N=7) | 6 yrs - TS II^1^; (N=12) | TS III - 17 yrs; (N=9) | Total; (N=52)
Rebound Hypertension (during blinded phase)
Mild (MAP>10% above MAP_B1_) | 0 | 1 (4.8%) | 1 (14.3%) | 1 (8.3%) | 0 | 3 (5.8%)
Hypotension
Mild (MAP>20% below target) | 2 (66.7%) | 4 (19.0%) | 2 (28.6%) | 4 (33.3%) | 3 (33.3%) | 15 (28.8%)
MAP>25% below target | 0 | 5 (23.8%) | 1 (14.3%) | 3 (25.0%) | 0 | 9 (17.3%)
MAP>30% below target | 0 | 2 (9.5%) | 1 (14.3%) | 3 (25.0%) | 0 | 6 (11.5%)
Severe (MAP>30% below target, IV and repeated/continuous pharmacological therapy required) | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 (1.9%)
Lactic acidosis
2.5-<5 mmol/L | 2 (66.7%) | 3 (14.3%) | 2 (28.6%) | 4 (33.3%) | 2 (22.2%) | 13 (25.0%)
Mild (5-7.5 mmol/L) | 0 | 0 | 0 | 1 (8.3%) | 0 | 1 (1.9%)
Metabolic Acidosis
HCO_3_<18.5 mEq/L or Administered Bicarbonate | 0 | 2 (9.5%) | 1 (14.3%) | 0 | 0 | 3 (5.8%)
Cyanide toxicity (whole blood)
Mild (0.5-1.0 mcg/mL) | 0 | 2 (9.5%) | 0 | 0 | 0 | 2 (3.8%)
Severe (>1.5 mcg/mL) | 2 (66.7%) | 6 (28.6%) | 1 (14.3%) | 2 (16.7%) | 1 (11.1%) | 12 (23.1%)

Note:

1 TS II: Tanner Stage II

Table 14.3.1.7.2 Summary of Selected Adverse Events by Age Classification (Open-Label Phase) Safety Population

| Age Strata | | | | | Total; (N=52)
| 0 - < 30 days; (N=3) | 30 days - < 2 yrs; (N=21) | 2 yrs - < 6 yrs; (N=7) | 6 yrs - TS II^1^; (N=12) | TS III - 17 yrs; (N=9) | Total; (N=52)
Hypotension
Mild (MAP>20% below target) | 2 (66.7%) | 5 (23.8%) | 2 (28.6%) | 4 (33.3%) | 2 (22.2%) | 15 (28.8%)
MAP>25% below target | 0 | 3 (14.3%) | 1 (14.3%) | 3 (25.0%) | 0 | 7 (13.5%)
MAP>30% below target | 0 | 1 (4.8%) | 1 (14.3%) | 3 (25.0%) | 0 | 5 (9.6%)
Severe (MAP>30% below target, IV and repeated/continuous pharmacological therapy required) | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 (1.9%)
Lactic acidosis
2.5-<5 mmol/L | 1 (33.3%) | 2 (9.5%) | 1 (14.3%) | 3 (25.0%) | 0 | 7 (13.5%)
Metabolic Acidosis
HCO_3_<18.5 mEq/L or Administered Bicarbonate | 0 | 1 (4.8%) | 1 (14.3%) | 0 | 0 | 2 (3.8%)
Cyanide toxicity (whole blood)
Mild (0.5-1.0 mcg/mL) | 0 | 1 (4.8%) | 0 | 0 | 0 | 1 (1.9%)
Moderate (>1.0-1.5 mcg/mL) | 1 (33.3%) | 1 (4.8%) | 1 (14.3%) | 0 | 0 | 3 (5.8%)
Severe (>1.5 mcg/mL) | 1 (33.3%) | 5 (23.8%) | 0 | 2 (16.7%) | 1 (11.1%) | 9 (17.3%)

Note:

1 TS II: Tanner Stage II

Table 14.3.1.7.3 Summary of Selected Adverse Events by Blinded Treatment (Blinded and Follow-Up Phases) Safety Population

| Treatment | | | Total; (N=52)
| SNP2; (N=25) | Placebo; (N=21) | None^1^; (N=6) | Total; (N=52)
Rebound Hypertension (during blinded phase)
Mild (MAP>10% above MAP_B1_) | 0 | 3 (14.3%) | 0 | 3 (5.8%)
Hypotension
Mild (MAP>20% below target) | 3 (11.1%) | 1 (4.8%) | 0 | 4 (7.7%)
MAP>25% below target | 2 (7.4%) | 0 | 0 | 2 (3.8%)
MAP>30% below target | 1 (3.7%) | 0 | 0 | 1 (1.9%)
Lactic acidosis
2.5-<5 mmol/L | 7 (25.9%) | 1 (4.8%) | 1 (25.0%) | 9 (17.3%)
Mild (5-7.5 mmol/L) | 1 (3.7%) | 0 | 1 (25.0%) | 2 (3.8%)
Metabolic Acidosis
HCO_3_<18.5 mEq/L or Administered Bicarbonate | 1 (3.7%) | 0 | 0 | 1 (1.9%)
Cyanide toxicity (whole blood)
Mild (0.5-1.0 mcg/mL) | 0 | 1 (4.8%) | 0 | 1 (1.9%)
Severe (>1.5 mcg/mL) | 7 (25.9%) | 5 (23.8%) | 0 | 12 (23.1%)

Note:

1 Subjects who did not receive the blinded drug and are not assessed for hypotension or rebound hypertension during the blinded phase.

Table 14.3.1.7.4 Summary of Selected Adverse Events by Age Classification (Pre-Dose Phase) Safety Population

| Age Strata | | | | | Total; (N=52)
| 0 - < 30 days; (N=3) | 30 days - < 2 yrs; (N=21) | 2 yrs - < 6 yrs; (N=7) | 6 yrs - TS II^1^; (N=12) | TS III - 17 yrs; (N=9) | Total; (N=52)
Lactic acidosis
2.5-<5 mmol/L | 0 | 3 (14.3%) | 2 (28.6%) | 3 (25.0%) | 0 | 8 (15.4%)
Mild (5-7.5 mmol/L) | 0 | 1 (4.8%) | 0 | 1 (8.3%) | 0 | 2 (3.8%)
Metabolic Acidosis
HCO_3_<18.5 mEq/L or Administered Bicarbonate | 0 | 1 (4.8%) | 1 (14.3%) | 0 | 0 | 2 (3.8%)

Note:

1 TS II: Tanner Stage II

Table 14.3.1.7.5 Summary of Worsening from Baseline of Selected Adverse Events by Age Classification (Open-Label, Blinded, and Follow-Up Phases) Safety Population

| Age Strata | | | | | Total; (N=51)
| 0 - < 30 days; (N=3) | 30 days - < 2 yrs; (N=21) | 2 yrs - < 6 yrs; (N=7) | 6 yrs - TS II^1^; (N=12) | TS III - 17 yrs; (N=9) | Total; (N=51)
Lactic acidosis
2.5-<5 mmol/L | 2 (66.7%) | 2 (9.5%) | 1 (14.3%) | 1 (8.3%) | 2 (22.2%) | 8 (15.4%)
Metabolic Acidosis
HCO_3_<18.5 mEq/L or Administered Bicarbonate | 0 | 2 (9.5%) | 1 (14.3%) | 0 | 0 | 3 (5.8%)
Cyanide toxicity (whole blood)
Mild (0.5-1.0 mcg/mL) | 0 | 2 (9.5%) | 0 | 0 | 0 | 2 (3.8%)
Severe (>1.5 mcg/mL) | 2 (66.7%) | 6 (28.6%) | 1 (14.3%) | 2 (16.7%) | 1 (11.1%) | 12 (23.1%)

Note:

1 TS II: Tanner Stage II

Table counts subjects with post-infusion conditions that declined from the baseline condition.

Table includes subjects with no baseline measurement.

Table 14.3.1.8.1 Summary of Adverse Events by Severity and Relationship to Treatment by Age Classification (Open-Label, Blinded, and Follow-Up Phases) Subjects with Severely High Cyanide Levels (Whole Blood) Safety Population

| Age Strata | | | | | Total; (N=12)
| 0 - < 30 days; (N=2) | 30 days - < 2 yrs; (N=6) | 2 yrs - < 6 yrs; (N=1) | 6 yrs - TS II^1^; (N=2) | TS III - 17 yrs; (N=1) | Total; (N=12)
Number of Events/Enrollments
Number of Adverse Events | 6 | 7 | 3 | 5 | 2 | 23
Enrollments with at least one AE | 2 (100%) | 4 (66.7%) | 1 (100%) | 2 (100%) | 1 (100%) | 10 (83.3%)
Number of SAEs | 2 | 0 | 1 | 1 | 0 | 4
Enrollments with at least one SAE | 1 (50.0%) | 0 | 1 (100%) | 1 (50.0%) | 0 | 3 (25.0%)
Severity (All AEs)
Mild | 4 | 5 | 1 | 4 | 2 | 16
Moderate | 0 | 2 | 1 | 0 | 0 | 3
Severe | 1 | 0 | 1 | 0 | 0 | 2
Life threatening | 1 | 0 | 0 | 0 | 0 | 1
Death | 0 | 0 | 0 | 1 | 0 | 1
Highest Severity Per Enrollment
Mild | 1 (50.0%) | 2 (33.3%) | 0 | 1 (50.0%) | 1 (100%) | 5 (41.7%)
Moderate | 0 | 2 (33.3%) | 0 | 0 | 0 | 2 (16.7%)
Severe | 0 | 0 | 1 (100%) | 0 | 0 | 1 (8.3%)
Life threatening | 1 (50.0%) | 0 | 0 | 0 | 0 | 1 (8.3%)
Death | 0 | 0 | 0 | 1 (50.0%) | 0 | 1 (8.3%)
Relationship (All AEs)
Unrelated | 2 | 3 | 2 | 3 | 1 | 11
Possibly related | 3 | 1 | 0 | 2 | 1 | 7
Probably related | 1 | 3 | 1 | 0 | 0 | 5
Strongest Relationship Per Enrollment
Unrelated | 1 (50.0%) | 1 (16.7%) | 0 | 1 (50.0%) | 0 | 3 (25.0%)
Possibly related | 0 | 1 (16.7%) | 0 | 1 (50.0%) | 1 (100%) | 3 (25.0%)
Probably related | 1 (50.0%) | 2 (33.3%) | 1 (100%) | 0 | 0 | 4 (33.3%)
Severity (All SAEs)
Severe | 1 | 0 | 1 | 0 | 0 | 2
Life threatening | 1 | 0 | 0 | 0 | 0 | 1
Death | 0 | 0 | 0 | 1 | 0 | 1
Relationship (All SAEs)
Unrelated | 0 | 0 | 1 | 1 | 0 | 2
Possibly related | 1 | 0 | 0 | 0 | 0 | 1
Probably related | 1 | 0 | 0 | 0 | 0 | 1
Type of SAE (All SAEs)
System Organ Class
Preferred Term
Investigations | 1 | 0 | 0 | 0 | 0 | 1
Blood cyanide increased | 1 | 0 | 0 | 0 | 0 | 1
Nervous system disorders | 0 | 0 | 1 | 0 | 0 | 1
Intracranial hypotension | 0 | 0 | 1 | 0 | 0 | 1
Respiratory, thoracic and mediastinal disorders | 1 | 0 | 0 | 1 | 0 | 2
Respiratory depression | 1 | 0 | 0 | 0 | 0 | 1
Respiratory failure | 0 | 0 | 0 | 1 | 0 | 1
Maximum Dose before Cyanide Toxicity Was Experienced or 8 hours in Open-Label Phase (Whichever is Earlier)
N | 2 | 6 | 1 | 2 | 1 | 12
Mean (SD) | 6.8 (0.4) | 5.6 (0.9) | 4.0 | 4.7 (0.3) | 6.0 | 5.5 (1.0)
Median (Min, Max) | 6.8 (6.5, 7.0) | 5.5 (4.5, 7.0) | 4.0 | 4.7 (4.5, 4.9) | 6.0 | 5.5 (4.0, 7.0)

Note:

1 TS II: Tanner Stage II

Table 14.3.1.8.2 Summary of Adverse Events by Severity and Relationship to Treatment by Treatment by Severely High Cyanide Levels (Whole Blood) Status (Open-Label, Blinded, and Follow-Up Phases) Safety Population

| Experienced Cyanide Toxicity | | Total; (N=52)
| Toxicity; (N=12) | No Toxicity; (N=40) | Total; (N=52)
Number of Events/Enrollments
Number of Adverse Events | 23 | 71 | 94
Enrollments with at least one AE | 10 (83.3%) | 22 (55.0%) | 32 (61.5%)
Number of SAEs | 4 | 4 | 8
Enrollments with at least one SAE | 3 (25.0%) | 4 (10.0%) | 7 (13.5%)
Severity (All AEs)
Mild | 16 | 63 | 79
Moderate | 3 | 5 | 8
Severe | 2 | 0 | 2
Life threatening | 1 | 2 | 3
Death | 1 | 1 | 2
Highest Severity Per Enrollment
Mild | 5 (41.7%) | 15 (37.5%) | 20 (38.5%)
Moderate | 2 (16.7%) | 4 (10.0%) | 6 (11.5%)
Severe | 1 (8.3%) | 0 | 1 (1.9%)
Life threatening | 1 (8.3%) | 2 (5.0%) | 3 (5.8%)
Death | 1 (8.3%) | 1 (2.5%) | 2 (3.8%)
Relationship (All AEs)
Unrelated | 11 | 53 | 64
Possibly related | 7 | 14 | 21
Probably related | 5 | 3 | 8
Definitely related | 0 | 1 | 1
Strongest Relationship Per Enrollment
Unrelated | 3 (25.0%) | 13 (32.5%) | 16 (30.8%)
Possibly related | 3 (25.0%) | 5 (12.5%) | 8 (15.4%)
Probably related | 4 (33.3%) | 3 (7.5%) | 7 (13.5%)
Definitely related | 0 | 1 (2.5%) | 1 (1.9%)
Severity (All SAEs)
Moderate | 0 | 1 | 1
Severe | 2 | 0 | 2
Life threatening | 1 | 2 | 3
Death | 1 | 1 | 2
Relationship (All SAEs)
Unrelated | 2 | 4 | 6
Possibly related | 1 | 0 | 1
Probably related | 1 | 0 | 1
Type of SAE (All SAEs)
System Organ Class
Preferred Term
Investigations | 1 | 0 | 1
Blood cyanide increased | 1 | 0 | 1
Nervous system disorders | 1 | 0 | 1
Intracranial hypotension | 1 | 0 | 1
Respiratory, thoracic and mediastinal disorders | 2 | 1 | 3
Respiratory depression | 1 | 0 | 1
Respiratory failure | 1 | 0 | 1

Note: Only types of SAEs recorded in subjects with cyanide toxicity are summarized.

Table 14.3.2.1 Summary of Concomitant Medications by WHO Class and Treatment ITT Population

WHO Class; Medication Name | Treatment | | | | Total; (N=46)
WHO Class; Medication Name | SNP; (N=25) | | Placebo; (N=21) | | Total; (N=46)
WHO Class; Medication Name | Enrollments With Medication N (%) | Total Medications | Enrollments With Medication N (%) | Total Medications | Enrollments With Medication N (%) | Total Medications
ALIMENTARY TRACT AND METABOLISM | 9 (36%) | 26 | 11 (52.4%) | 19 | 20 (43.5%) | 45
ALUDROX | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
ALUMINIUM W/MAGNESIUM HYDROXIDE/SIMETICONE | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
BENZOCAINE | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
CALCIUM CHLORIDE | 2 (8%) | 2 | 2 (9.5%) | 2 | 4 (8.7%) | 4
CALCIUM GLUCONATE | 5 (20%) | 5 | 4 (19%) | 4 | 9 (19.6%) | 9
DOCUSATE | 0 | 0 | 1 (4.8%) | 2 | 1 (2.2%) | 2
INSULIN | 1 (4%) | 1 | 1 (4.8%) | 1 | 2 (4.3%) | 2
MACROGOL | 0 | 0 | 1 (4.8%) | 1 | 1 (2.2%) | 1
MAGNESIUM SULFATE | 1 (4%) | 2 | 1 (4.8%) | 1 | 2 (4.3%) | 3
METOCLOPRAMIDE | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
MULTIVITAMINS WITH IRON | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
ONDANSETRON | 3 (12%) | 3 | 2 (9.5%) | 2 | 5 (10.9%) | 5
PANTOPRAZOLE | 0 | 0 | 1 (4.8%) | 1 | 1 (2.2%) | 1
POTASSIUM CHLORIDE | 3 (12%) | 4 | 4 (19%) | 4 | 7 (15.2%) | 8
RANITIDINE | 1 (4%) | 3 | 0 | 0 | 1 (2.2%) | 3
SODIUM BICARBONATE | 1 (4%) | 1 | 1 (4.8%) | 1 | 2 (4.3%) | 2
ANTIINFECTIVES FOR SYSTEMIC USE | 2 (8%) | 4 | 2 (9.5%) | 4 | 4 (8.7%) | 8
CEFAZOLIN | 2 (8%) | 2 | 1 (4.8%) | 1 | 3 (6.5%) | 3
MEROPENEM | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
OSELTAMIVIR | 0 | 0 | 1 (4.8%) | 1 | 1 (2.2%) | 1
PIP/TAZO | 0 | 0 | 1 (4.8%) | 1 | 1 (2.2%) | 1
VANCOMYCIN | 1 (4%) | 1 | 1 (4.8%) | 1 | 2 (4.3%) | 2
BLOOD AND BLOOD FORMING ORGANS | 6 (24%) | 26 | 8 (38.1%) | 19 | 14 (30.4%) | 45
ACETYLSALICYLIC ACID | 3 (12%) | 3 | 1 (4.8%) | 1 | 4 (8.7%) | 4
ALBUMIN | 3 (12%) | 3 | 1 (4.8%) | 1 | 4 (8.7%) | 4
ALTEPLASE | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
AMINOCAPROIC ACID | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
ELECTROLYTE | 1 (4%) | 3 | 1 (4.8%) | 1 | 2 (4.3%) | 4
ELECTROLYTES WITH CARBOHYDRATES | 2 (8%) | 4 | 4 (19%) | 6 | 6 (13%) | 10
EPINEPHRINE | 0 | 0 | 1 (4.8%) | 1 | 1 (2.2%) | 1
FACTOR VIII (ANTIHAEMOPHILIC FACTOR) | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
FAT EMULSIONS | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
HEPARIN | 1 (4%) | 2 | 1 (4.8%) | 1 | 2 (4.3%) | 3
HEPARIN SODIUM | 0 | 0 | 1 (4.8%) | 1 | 1 (2.2%) | 1
MANNITOL | 0 | 0 | 1 (4.8%) | 1 | 1 (2.2%) | 1
Other blood products | 0 | 0 | 2 (9.5%) | 2 | 2 (4.3%) | 2
PLASMA | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
PLASMA-LYTE | 0 | 0 | 1 (4.8%) | 1 | 1 (2.2%) | 1
PLATELETS | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
RED BLOOD CELLS | 3 (12%) | 4 | 3 (14.3%) | 3 | 6 (13%) | 7
SOLUTIONS FOR PARENTERAL NUTRITION | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
CARDIOVASCULAR SYSTEM | 21 (84%) | 84 | 19 (90.5%) | 56 | 40 (87%) | 140
ACETAZOLAMIDE | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
AMLODIPINE | 2 (8%) | 2 | 0 | 0 | 2 (4.3%) | 2
ATENOLOL | 2 (8%) | 2 | 0 | 0 | 2 (4.3%) | 2
ATROPINE | 1 (4%) | 1 | 1 (4.8%) | 1 | 2 (4.3%) | 2
CAPTOPRIL | 6 (24%) | 6 | 3 (14.3%) | 3 | 9 (19.6%) | 9
CHLOROTHIAZIDE | 3 (12%) | 4 | 0 | 0 | 3 (6.5%) | 4
CLONIDINE | 4 (16%) | 4 | 0 | 0 | 4 (8.7%) | 4
DEXTROSE W/DOPAMINE | 0 | 0 | 1 (4.8%) | 1 | 1 (2.2%) | 1
DIGOXIN | 2 (8%) | 2 | 0 | 0 | 2 (4.3%) | 2
ENALAPRIL | 1 (4%) | 1 | 2 (9.5%) | 2 | 3 (6.5%) | 3
ENALAPRIL MALEATE | 0 | 0 | 1 (4.8%) | 1 | 1 (2.2%) | 1
EPINEPHRINE | 2 (8%) | 2 | 1 (4.8%) | 2 | 3 (6.5%) | 4
ESMOLOL | 3 (12%) | 3 | 2 (9.5%) | 2 | 5 (10.9%) | 5
FUROSEMIDE | 16 (64%) | 16 | 15 (71.4%) | 16 | 31 (67.4%) | 32
HYDRALAZINE | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
LABETALOL | 2 (8%) | 2 | 2 (9.5%) | 2 | 4 (8.7%) | 4
LISINOPRIL | 1 (4%) | 1 | 2 (9.5%) | 2 | 3 (6.5%) | 3
LOSARTAN | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
METOLAZONE | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
METOPROLOL SUCCINATE | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
MILRINONE | 7 (28%) | 9 | 6 (28.6%) | 6 | 13 (28.3%) | 15
NICARDIPINE | 1 (4%) | 1 | 1 (4.8%) | 1 | 2 (4.3%) | 2
NITROPRUSSIDE | 14 (56%) | 15 | 8 (38.1%) | 8 | 22 (47.8%) | 23
NITROPRUSSIDE SODIUM | 0 | 0 | 4 (19%) | 5 | 4 (8.7%) | 5
OTHER VASODILATORS USED IN CARDIAC DISEASES | 3 (12%) | 3 | 0 | 0 | 3 (6.5%) | 3
PAPAVERINE | 1 (4%) | 1 | 1 (4.8%) | 1 | 2 (4.3%) | 2
PROPRANOLOL | 1 (4%) | 1 | 3 (14.3%) | 3 | 4 (8.7%) | 4
SPIRONOLACTONE | 3 (12%) | 3 | 0 | 0 | 3 (6.5%) | 3
MUSCULO-SKELETAL SYSTEM | 2 (8%) | 2 | 3 (14.3%) | 3 | 5 (10.9%) | 5
IBUPROFEN | 0 | 0 | 1 (4.8%) | 1 | 1 (2.2%) | 1
KETOROLAC | 0 | 0 | 1 (4.8%) | 1 | 1 (2.2%) | 1
KETOROLAC TROMETHAMINE | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
ROCURONIUM | 1 (4%) | 1 | 1 (4.8%) | 1 | 2 (4.3%) | 2
NERVOUS SYSTEM | 23 (92%) | 85 | 21 (100%) | 83 | 44 (95.7%) | 168
BUPIVACAINE | 1 (4%) | 1 | 1 (4.8%) | 1 | 2 (4.3%) | 2
BUPIVACAINE W/FENTANYL | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
CHLORAL HYDRATE | 0 | 0 | 1 (4.8%) | 1 | 1 (2.2%) | 1
CLONIDINE | 1 (4%) | 1 | 4 (19%) | 4 | 5 (10.9%) | 5
DEXMEDETOMIDINE | 6 (24%) | 8 | 6 (28.6%) | 6 | 12 (26.1%) | 14
DEXMEDETOMIDINE HYDROCHLORIDE | 0 | 0 | 1 (4.8%) | 1 | 1 (2.2%) | 1
DIPHENHYDRAMINE | 0 | 0 | 1 (4.8%) | 1 | 1 (2.2%) | 1
FENTANYL | 8 (32%) | 8 | 8 (38.1%) | 8 | 16 (34.8%) | 16
FENTANYL CITRATE | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
GALENIC/PARACETAMOL/CODEINE/ | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
HYDROMORPHONE | 5 (20%) | 5 | 5 (23.8%) | 5 | 10 (21.7%) | 10
ISOFLURANE | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
LIDOCAINE | 0 | 0 | 1 (4.8%) | 1 | 1 (2.2%) | 1
LORAZEPAM | 9 (36%) | 10 | 8 (38.1%) | 9 | 17 (37%) | 19
LORTAB | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
METHADONE | 4 (16%) | 4 | 1 (4.8%) | 1 | 5 (10.9%) | 5
MIDAZOLAM | 8 (32%) | 9 | 9 (42.9%) | 9 | 17 (37%) | 18
MIDAZOLAM HYDROCHLORIDE | 0 | 0 | 1 (4.8%) | 1 | 1 (2.2%) | 1
MIRTAZAPINE | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
MORPHINE | 11 (44%) | 13 | 11 (52.4%) | 14 | 22 (47.8%) | 27
MORPHINE HYDROCHLORIDE | 2 (8%) | 2 | 0 | 0 | 2 (4.3%) | 2
MORPHINE SULFATE | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
NALBUPHINE | 0 | 0 | 1 (4.8%) | 1 | 1 (2.2%) | 1
NALBUPHINE HYDROCHLORIDE | 4 (16%) | 4 | 5 (23.8%) | 5 | 9 (19.6%) | 9
OXYCODONE | 0 | 0 | 1 (4.8%) | 2 | 1 (2.2%) | 2
PANADEINE CO | 0 | 0 | 2 (9.5%) | 2 | 2 (4.3%) | 2
PARACETAMOL | 4 (16%) | 4 | 3 (14.3%) | 3 | 7 (15.2%) | 7
PHENOBARBITAL | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
PREGABALIN | 0 | 0 | 1 (4.8%) | 1 | 1 (2.2%) | 1
PROPOFOL | 6 (24%) | 6 | 5 (23.8%) | 5 | 11 (23.9%) | 11
ROPIVACAINE | 1 (4%) | 1 | 2 (9.5%) | 2 | 3 (6.5%) | 3
TRAZODONE | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
RESPIRATORY SYSTEM | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
PHENYLEPHRINE | 1 (4%) | 1 | 0 | 0 | 1 (2.2%) | 1
SYSTEMIC HORMONAL PREP.,EXCL.SEX HORM.AND INSULIN | 2 (8%) | 3 | 2 (9.5%) | 2 | 4 (8.7%) | 5
DEXAMETHASONE | 2 (8%) | 3 | 1 (4.8%) | 1 | 3 (6.5%) | 4
METHYLPREDNISOLONE | 0 | 0 | 1 (4.8%) | 1 | 1 (2.2%) | 1
VARIOUS | 1 (4%) | 1 | 2 (9.5%) | 2 | 3 (6.5%) | 3
GLUCOSE | 0 | 0 | 1 (4.8%) | 1 | 1 (2.2%) | 1
SODIUM THIOSULFATE | 1 (4%) | 1 | 1 (4.8%) | 1 | 2 (4.3%) | 2

Note: The percentages are based on the total number of enrollments in the blinded phase in each treatment arm.

Enrollments are counted once at each concomitant procedure/medication name level.

Table 14.3.2.2 Summary of Concomitant Medications by WHO Class and Age Classification Safety Population

WHO Class; Medication Name | Age Strata | | | | | | | | | | Total; (N=52)
WHO Class; Medication Name | ≥ 0 - < 30 days; (N=3) | | ≥ 30 days - < 2 yrs; (N=21) | | ≥ 2 yrs - < 6 yrs; (N=7) | | ≥ 6 yrs - TS II^1^; (N=12) | | ≥ TS III - 17 yrs; (N=9) | | Total; (N=52)
WHO Class; Medication Name | Enrollments With Medication N (%) | Total Medications | Enrollments With Medication N (%) | Total Medications | Enrollments With Medication N (%) | Total Medications | Enrollments With Medication N (%) | Total Medications | Enrollments With Medication N (%) | Total Medications | Enrollments With Medication N (%) | Total Medications
ALIMENTARY TRACT AND METABOLISM | 2 (66.7%) | 2 | 8 (38.1%) | 27 | 3 (42.9%) | 6 | 7 (58.3%) | 12 | 2 (22.2%) | 3 | 22 (42.3%) | 50
ALUDROX | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
ALUMINIUM W/MAGNESIUM HYDROXIDE/SIMETICONE | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
BENZOCAINE | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
CALCIUM CHLORIDE | 0 | 0 | 3 (14.3%) | 3 | 1 (14.3%) | 1 | 1 (8.3%) | 1 | 0 | 0 | 5 (9.6%) | 5
CALCIUM GLUCONATE | 2 (66.7%) | 2 | 3 (14.3%) | 3 | 1 (14.3%) | 1 | 3 (25%) | 3 | 0 | 0 | 9 (17.3%) | 9
DOCUSATE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 2 | 0 | 0 | 1 (1.9%) | 2
GLYCOPYRRONIUM BROMIDE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 1 (1.9%) | 1
INSULIN | 0 | 0 | 2 (9.5%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2
MACROGOL | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
MAGNESIUM SULFATE | 0 | 0 | 2 (9.5%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (3.8%) | 3
METOCLOPRAMIDE | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
MULTIVITAMINS WITH IRON | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
ONDANSETRON | 0 | 0 | 1 (4.8%) | 1 | 1 (14.3%) | 1 | 3 (25%) | 3 | 2 (22.2%) | 2 | 7 (13.5%) | 7
PANTOPRAZOLE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
POTASSIUM CHLORIDE | 0 | 0 | 5 (23.8%) | 6 | 2 (28.6%) | 2 | 0 | 0 | 0 | 0 | 7 (13.5%) | 8
RANITIDINE | 0 | 0 | 1 (4.8%) | 3 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 2 (3.8%) | 4
SODIUM BICARBONATE | 0 | 0 | 2 (9.5%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2
ANTIINFECTIVES FOR SYSTEMIC USE | 0 | 0 | 2 (9.5%) | 4 | 1 (14.3%) | 1 | 2 (16.7%) | 4 | 0 | 0 | 5 (9.6%) | 9
CEFAZOLIN | 0 | 0 | 2 (9.5%) | 2 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 3 (5.8%) | 3
CLINDAMYCIN | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
MEROPENEM | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
OSELTAMIVIR | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
PIP/TAZO | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
VANCOMYCIN | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 2 (3.8%) | 2
BLOOD AND BLOOD FORMING ORGANS | 0 | 0 | 6 (28.6%) | 33 | 4 (57.1%) | 8 | 4 (33.3%) | 8 | 3 (33.3%) | 7 | 17 (32.7%) | 56
ACETYLSALICYLIC ACID | 0 | 0 | 2 (9.5%) | 2 | 1 (14.3%) | 1 | 1 (8.3%) | 1 | 0 | 0 | 4 (7.7%) | 4
ALBUMIN | 0 | 0 | 2 (9.5%) | 2 | 1 (14.3%) | 1 | 1 (8.3%) | 1 | 2 (22.2%) | 3 | 6 (11.5%) | 7
ALTEPLASE | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
AMINOCAPROIC ACID | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 1 (8.3%) | 1 | 0 | 0 | 2 (3.8%) | 2
ELECTROLYTE | 0 | 0 | 2 (9.5%) | 4 | 0 | 0 | 1 (8.3%) | 1 | 1 (11.1%) | 1 | 4 (7.7%) | 6
ELECTROLYTES WITH CARBOHYDRATES | 0 | 0 | 4 (19%) | 8 | 2 (28.6%) | 2 | 1 (8.3%) | 1 | 1 (11.1%) | 1 | 8 (15.4%) | 12
EPINEPHRINE | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
FACTOR VIII (ANTIHAEMOPHILIC FACTOR) | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
FAT EMULSIONS | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
HEPARIN | 0 | 0 | 2 (9.5%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (3.8%) | 3
HEPARIN SODIUM | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
MANNITOL | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 1 (1.9%) | 1
Other blood products | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 2 (3.8%) | 2
PLASMA | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
PLASMA-LYTE | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 2 (3.8%) | 2
PLATELETS | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
RED BLOOD CELLS | 0 | 0 | 4 (19%) | 5 | 2 (28.6%) | 2 | 1 (8.3%) | 1 | 1 (11.1%) | 1 | 8 (15.4%) | 9
SOLUTIONS FOR PARENTERAL NUTRITION | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
CARDIOVASCULAR SYSTEM | 3 (100%) | 10 | 18 (85.7%) | 76 | 6 (85.7%) | 17 | 11 (91.7%) | 26 | 7 (77.8%) | 20 | 45 (86.5%) | 149
ACETAZOLAMIDE | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
AMLODIPINE | 0 | 0 | 0 | 0 | 0 | 0 | 2 (16.7%) | 2 | 0 | 0 | 2 (3.8%) | 2
ATENOLOL | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (33.3%) | 3 | 3 (5.8%) | 3
ATROPINE | 1 (33.3%) | 1 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2
BUMETANIDE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
CAPTOPRIL | 1 (33.3%) | 1 | 7 (33.3%) | 7 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 9 (17.3%) | 9
CHLOROTHIAZIDE | 1 (33.3%) | 1 | 2 (9.5%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (5.8%) | 4
CLONIDINE | 0 | 0 | 2 (9.5%) | 2 | 1 (14.3%) | 1 | 1 (8.3%) | 1 | 0 | 0 | 4 (7.7%) | 4
DEXTROSE W/DOPAMINE | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
DIGOXIN | 0 | 0 | 2 (9.5%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2
DOPAMINE | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
ENALAPRIL | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 2 (16.7%) | 2 | 0 | 0 | 3 (5.8%) | 3
ENALAPRIL MALEATE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 1 (1.9%) | 1
EPINEPHRINE | 0 | 0 | 3 (14.3%) | 4 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (5.8%) | 4
ESMOLOL | 0 | 0 | 2 (9.5%) | 2 | 0 | 0 | 1 (8.3%) | 1 | 3 (33.3%) | 3 | 6 (11.5%) | 6
FUROSEMIDE | 2 (66.7%) | 2 | 15 (71.4%) | 15 | 5 (71.4%) | 6 | 8 (66.7%) | 8 | 3 (33.3%) | 3 | 33 (63.5%) | 34
HYDRALAZINE | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
LABETALOL | 0 | 0 | 1 (4.8%) | 1 | 1 (14.3%) | 1 | 1 (8.3%) | 1 | 1 (11.1%) | 1 | 4 (7.7%) | 4
LISINOPRIL | 0 | 0 | 0 | 0 | 0 | 0 | 2 (16.7%) | 2 | 1 (11.1%) | 1 | 3 (5.8%) | 3
LOSARTAN | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
METOLAZONE | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
METOPROLOL SUCCINATE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 1 (1.9%) | 1
MILRINONE | 2 (66.7%) | 2 | 10 (47.6%) | 12 | 0 | 0 | 3 (25%) | 3 | 0 | 0 | 15 (28.8%) | 17
NICARDIPINE | 0 | 0 | 1 (4.8%) | 1 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2
NITROPRUSSIDE | 1 (33.3%) | 1 | 12 (57.1%) | 12 | 3 (42.9%) | 4 | 2 (16.7%) | 2 | 4 (44.4%) | 4 | 22 (42.3%) | 23
NITROPRUSSIDE SODIUM | 0 | 0 | 2 (9.5%) | 3 | 0 | 0 | 1 (8.3%) | 1 | 1 (11.1%) | 1 | 4 (7.7%) | 5
OTHER VASODILATORS USED IN CARDIAC DISEASES | 0 | 0 | 3 (14.3%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (5.8%) | 3
PAPAVERINE | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 1 (11.1%) | 1 | 2 (3.8%) | 2
PROPRANOLOL | 0 | 0 | 3 (14.3%) | 3 | 0 | 0 | 1 (8.3%) | 1 | 1 (11.1%) | 1 | 5 (9.6%) | 5
SPIRONOLACTONE | 0 | 0 | 2 (9.5%) | 2 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 3 (5.8%) | 3
MUSCULO-SKELETAL SYSTEM | 0 | 0 | 2 (9.5%) | 2 | 2 (28.6%) | 2 | 1 (8.3%) | 1 | 2 (22.2%) | 2 | 7 (13.5%) | 7
IBUPROFEN | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
KETOROLAC | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 1 (1.9%) | 1
KETOROLAC TROMETHAMINE | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 1 (8.3%) | 1 | 0 | 0 | 2 (3.8%) | 2
ROCURONIUM | 0 | 0 | 2 (9.5%) | 2 | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 3 (5.8%) | 3
NERVOUS SYSTEM | 3 (100%) | 13 | 19 (90.5%) | 82 | 6 (85.7%) | 24 | 12 (100%) | 42 | 9 (100%) | 24 | 49 (94.2%) | 185
BUPIVACAINE | 0 | 0 | 1 (4.8%) | 1 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2
BUPIVACAINE W/FENTANYL | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
CHLORAL HYDRATE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
CLONIDINE | 0 | 0 | 2 (9.5%) | 2 | 0 | 0 | 1 (8.3%) | 1 | 2 (22.2%) | 2 | 5 (9.6%) | 5
DEXMEDETOMIDINE | 1 (33.3%) | 1 | 9 (42.9%) | 11 | 0 | 0 | 3 (25%) | 3 | 0 | 0 | 13 (25%) | 15
DEXMEDETOMIDINE HYDROCHLORIDE | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
DIPHENHYDRAMINE | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
FENTANYL | 3 (100%) | 3 | 6 (28.6%) | 6 | 3 (42.9%) | 3 | 4 (33.3%) | 4 | 2 (22.2%) | 2 | 18 (34.6%) | 18
FENTANYL CITRATE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (22.2%) | 2 | 2 (3.8%) | 2
GALENIC/PARACETAMOL/CODEINE/ | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
HYDROMORPHONE | 0 | 0 | 1 (4.8%) | 1 | 1 (14.3%) | 1 | 4 (33.3%) | 4 | 6 (66.7%) | 6 | 12 (23.1%) | 12
ISOFLURANE | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
LIDOCAINE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
LORAZEPAM | 1 (33.3%) | 1 | 7 (33.3%) | 8 | 5 (71.4%) | 5 | 4 (33.3%) | 5 | 0 | 0 | 17 (32.7%) | 19
LORTAB | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
METHADONE | 1 (33.3%) | 1 | 2 (9.5%) | 2 | 0 | 0 | 2 (16.7%) | 2 | 0 | 0 | 5 (9.6%) | 5
MIDAZOLAM | 2 (66.7%) | 2 | 12 (57.1%) | 13 | 3 (42.9%) | 3 | 2 (16.7%) | 2 | 1 (11.1%) | 1 | 20 (38.5%) | 21
MIDAZOLAM HYDROCHLORIDE | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
MIRTAZAPINE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
MORPHINE | 1 (33.3%) | 1 | 13 (61.9%) | 17 | 4 (57.1%) | 5 | 4 (33.3%) | 4 | 2 (22.2%) | 2 | 24 (46.2%) | 29
MORPHINE HYDROCHLORIDE | 1 (33.3%) | 1 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2
MORPHINE SULFATE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 1 (1.9%) | 1
NALBUPHINE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 1 (1.9%) | 1
NALBUPHINE HYDROCHLORIDE | 0 | 0 | 6 (28.6%) | 6 | 0 | 0 | 3 (25%) | 3 | 1 (11.1%) | 1 | 10 (19.2%) | 10
NEOSTIGMINE METILSULFATE | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 1 (1.9%) | 1
OXYCODONE | 0 | 0 | 0 | 0 | 1 (14.3%) | 2 | 0 | 0 | 0 | 0 | 1 (1.9%) | 2
PANADEINE CO | 0 | 0 | 2 (9.5%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2
PARACETAMOL | 0 | 0 | 2 (9.5%) | 2 | 3 (42.9%) | 3 | 3 (25%) | 3 | 0 | 0 | 8 (15.4%) | 8
PHENOBARBITAL | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
PREGABALIN | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (11.1%) | 1 | 1 (1.9%) | 1
PROPOFOL | 1 (33.3%) | 1 | 6 (28.6%) | 6 | 0 | 0 | 4 (33.3%) | 4 | 2 (22.2%) | 2 | 13 (25%) | 13
REMIFENTANIL | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
ROPIVACAINE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 2 (22.2%) | 2 | 3 (5.8%) | 3
TRAZODONE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
RESPIRATORY SYSTEM | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 2 (3.8%) | 2
FLUTICASONE PROPIONATE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
PHENYLEPHRINE | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
SYSTEMIC HORMONAL PREP.,EXCL.SEX HORM.AND INSULIN | 0 | 0 | 2 (9.5%) | 3 | 0 | 0 | 3 (25%) | 3 | 0 | 0 | 5 (9.6%) | 6
DEXAMETHASONE | 0 | 0 | 2 (9.5%) | 3 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 3 (5.8%) | 4
LEVOTHYROXINE SODIUM | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
METHYLPREDNISOLONE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (8.3%) | 1 | 0 | 0 | 1 (1.9%) | 1
VARIOUS | 0 | 0 | 1 (4.8%) | 1 | 2 (28.6%) | 2 | 0 | 0 | 0 | 0 | 3 (5.8%) | 3
GLUCOSE | 0 | 0 | 0 | 0 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1
SODIUM THIOSULFATE | 0 | 0 | 1 (4.8%) | 1 | 1 (14.3%) | 1 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2

Note:

1 TS II: Tanner Stage II

Table 14.3.3.1.1 Summary of Quantitative Clinical Laboratory Evaluations by Time (Baseline and Post-Baseline) Safety Population Hematology Panel

Laboratory Test | Pre-Dose | Study Drug D/C | | P Value^1^
Laboratory Test | Result | Result | Change from Pre-Dose | P Value^1^
WBC (10^3^/mm^3^)
N | 50 | 48 | 47 | 0.006
Mean (SD) | 10.7 (5.6) | 12.9 (6.0) | 2.4 (5.9)
Median (Min, Max) | 8.6 (4.3, 30.8) | 11.9 (4.0, 33.0) | 2.3 (−8.7, 24.7)
HGB (g/dL)
N | 50 | 48 | 47 | 0.012
Mean (SD) | 12.3 (2.0) | 11.4 (2.0) | −0.8 (2.4)
Median (Min, Max) | 12.9 (7.9, 16.2) | 11.2 (8.2, 16.8) | −1.3 (−4.9, 5.1)
HCT (%)
N | 50 | 48 | 47 | 0.008
Mean (SD) | 36.3 (6.0) | 33.4 (5.9) | −2.6 (7.2)
Median (Min, Max) | 38.0 (23.0, 47.8) | 33.6 (23.7, 48.5) | −3.1 (−14.2, 14.0)
Platelet Count (10^3^/mm^3^)
N | 50 | 48 | 47 | 0.015
Mean (SD) | 262.2 (135.8) | 228.6 (97.5) | −39.5 (93.6)
Median (Min, Max) | 232.5 (93.0, 781.0) | 209.0 (64.0, 484.0) | −23.0 (−297, 155.0)

Note:

1 Non-parametric sign rank sum test is used to test the difference from baseline.

Table 14.3.3.1.2 Summary of Quantitative Clinical Laboratory Evaluations by Time (Baseline and Post-Baseline) Safety Population Chemistry Panel

Laboratory Test | Pre-Dose | Study Drug D/C | | P Value^1^
Laboratory Test | Result | Result | Change from Pre-Dose | P Value^1^
Sodium (mmol/L)
N | 51 | 50 | 50 | 0.002
Mean (SD) | 140.0 (5.6) | 138.0 (4.2) | −1.9 (5.4)
Median (Min, Max) | 140.0 (114.0, 149.0) | 138.0 (125.0, 147.0) | −2.0 (−15.0, 20.0)
Potassium (mmol/L)
N | 51 | 50 | 50 | 0.912
Mean (SD) | 3.9 (0.7) | 4.0 (0.9) | 0.1 (1.2)
Median (Min, Max) | 3.8 (2.6, 6.1) | 3.9 (2.9, 8.8) | 0.0 (−2.6, 5.5)
Chloride (mmol/L)
N | 51 | 50 | 50 | 0.081
Mean (SD) | 105.6 (6.5) | 104.0 (5.3) | −1.5 (5.8)
Median (Min, Max) | 106.0 (85.0, 121.0) | 105.0 (89.0, 117.0) | −1.0 (−17.0, 11.0)
Carbon Dioxide (mmol/L)
N | 51 | 50 | 50 | 0.838
Mean (SD) | 25.9 (3.9) | 25.8 (3.0) | −0.1 (3.3)
Median (Min, Max) | 26.0 (17.0, 41.0) | 25.5 (20.0, 35.0) | 0.0 (−10.0, 8.0)
BUN (Urea) (mg/dL)
N | 51 | 49 | 49 | 0.919
Mean (SD) | 10.9 (8.1) | 11.5 (9.5) | 0.3 (5.3)
Median (Min, Max) | 9.0 (1.0, 54.0) | 10.0 (1.0, 66.0) | 0.0 (−10.0, 12.0)
Creatinine (mg/dL)
N | 51 | 49 | 49 | 0.742
Mean (SD) | 0.5 (0.2) | 0.5 (0.2) | 0.0 (0.2)
Median (Min, Max) | 0.4 (0.1, 1.1) | 0.4 (0.2, 1.0) | 0.0 (−0.7, 0.3)

Note:

1 Non-parametric sign rank sum test is used to test the difference from baseline.

Table 14.3.3.1.3 Summary of Quantitative Clinical Laboratory Evaluations by Time (Baseline and Post-Baseline) Safety Population Liver Functions Tests Panel

Laboratory Test | Pre-Dose | Study Drug D/C | | P Value^1^
Laboratory Test | Result | Result | Change from Pre-Dose | P Value^1^
ALT (SGPT) (U/L)
N | 51 | 50 | 50 | 0.002
Mean (SD) | 50.6 (100.7) | 34.5 (56.2) | −16.9 (60.5)
Median (Min, Max) | 20.0 (9.0, 500.0) | 19.5 (9.0, 301.0) | −3.0 (−333, 63.0)
AST (SGOT) (U/L)
N | 51 | 49 | 49 | 0.289
Mean (SD) | 107.6 (289.9) | 72.6 (142.5) | −37.9 (161.3)
Median (Min, Max) | 40.0 (14.0, 2039) | 43.0 (18.0, 1023) | −3.0 (−1016, 79.0)

Note:

1 Non-parametric sign rank sum test is used to test the difference from baseline.

Table 14.3.3.1.4 Summary of Quantitative Clinical Laboratory Evaluations by Time (Baseline and Post-Baseline) Safety Population Lactate

Laboratory Test | Pre-Dose | 8 Hours Post-Start Drug | | | 16 Hours Post-Start Drug | | | Study Drug D/C
Laboratory Test | Result | Result | Change from Pre-Dose | P Value^1^ | Result | Change from Pre-Dose | P Value^1^ | Result | Change from Pre-Dose | P Value^1^
Lactate (mmol/L)
N | 51 | 46 | 46 | 0.209 | 15 | 15 | 0.858 | 48 | 48 | 0.449
Mean (SD) | 1.6 (1.1) | 1.3 (0.8) | −0.3 (1.1) | | 1.6 (1.1) | 0.1 (1.1) | | 1.6 (1.1) | 0.0 (1.2)
Median (Min, Max) | 1.2 (0.4, 5.8) | 1.1 (0.5, 3.7) | 0.0 (−4.2, 1.6) | | 1.1 (0.6, 4.7) | 0.1 (−1.9, 3.5) | | 1.3 (0.5, 5.5) | 0.1 (−4.0, 2.5)

Note:

1 Non-parametric sign rank sum test is used to test the difference from baseline.

Table 14.3.3.1.5 Summary of Quantitative Clinical Laboratory Evaluations by Time (Baseline and Post-Baseline) Safety Population ABG (Blood Gases)

Laboratory Test | Pre-Dose | 8 Hours Post-Start Drug | | | 16 Hours Post-Start Drug | | | Study Drug D/C
Laboratory Test | Result | Result | Change from Pre-Dose | P Value^1^ | Result | Change from Pre-Dose | P Value^1^ | Result | Change from Pre-Dose | P Value^1^
pH
N | 51 | 47 | 47 | 0.124 | 16 | 16 | 0.002 | 48 | 48 | 0.043
Mean (SD) | 7.4 (0.1) | 7.4 (0.1) | 0.0 (0.1) | | 7.4 (0.0) | 0.1 (0.1) | | 7.4 (0.0) | 0.0 (0.1)
Median (Min, Max) | 7.4 (7.2, 7.5) | 7.4 (7.3, 7.5) | 0.0 (−0.1, 0.3) | | 7.4 (7.4, 7.5) | 0.1 (−0.1, 0.2) | | 7.4 (7.3, 7.5) | 0.0 (−0.1, 0.3)
PCO_2_ (mmHg)
N | 51 | 47 | 47 | 0.832 | 16 | 16 | 0.048 | 48 | 48 | 0.440
Mean (SD) | 43.5 (9.1) | 42.6 (7.1) | −0.6 (8.4) | | 39.6 (4.7) | −3.6 (7.1) | | 42.4 (5.8) | −1.2 (8.8)
Median (Min, Max) | 43.0 (31.0, 74.0) | 42.0 (27.0, 63.0) | −1.0 (−31.0, 18.0) | | 40.0 (31.0, 47.0) | −2.5 (−24.0, 7.0) | | 42.0 (30.0, 61.0) | −1.0 (−28.0, 14.0)
PO_2_ (mmHg)
N | 51 | 47 | 47 | 0.003 | 16 | 16 | 0.021 | 48 | 48 | <.001
Mean (SD) | 160.8 (117.3) | 106.7 (45.2) | −58.7 (116.3) | | 93.8 (28.0) | −69.6 (127.2) | | 95.2 (35.8) | −61.4 (117.3)
Median (Min, Max) | 117.0 (37.0, 492.0) | 98.0 (40.0, 269.0) | −13.0 (−383, 92.0) | | 85.0 (64.0, 158.0) | −32.5 (−407, 52.0) | | 86.0 (39.0, 191.0) | −19.5 (−401, 124.0)
SO_2_ (%)
N | 51 | 44 | 44 | 0.114 | 16 | 16 | 0.134 | 48 | 48 | 0.438
Mean (SD) | 95.1 (6.5) | 93.9 (7.7) | −1.2 (5.2) | | 96.3 (1.8) | −0.9 (2.4) | | 94.6 (6.5) | −0.3 (5.0)
Median (Min, Max) | 97.0 (63.0, 100.0) | 96.5 (68.0, 100.0) | −0.5 (−23.0, 11.0) | | 96.0 (93.0, 99.0) | −1.0 (−6.0, 4.0) | | 96.5 (73.0, 100.0) | 0.0 (−22.0, 13.0)
HCO_3_ (mEq/L)
N | 51 | 47 | 47 | 0.125 | 16 | 16 | 0.014 | 48 | 48 | 0.014
Mean (SD) | 25.1 (3.5) | 25.8 (3.8) | 0.6 (2.4) | | 25.8 (2.8) | 1.5 (2.2) | | 26.3 (2.9) | 1.0 (2.7)
Median (Min, Max) | 24.0 (19.0, 39.0) | 25.0 (17.0, 37.0) | 1.0 (−4.0, 7.0) | | 25.5 (22.0, 30.0) | 1.5 (−4.0, 5.0) | | 26.0 (21.0, 35.0) | 1.0 (−5.0, 8.0)
Methemoglobin (%)
N | 48 | 43 | 40 | 0.494 | 15 | 14 | 0.746 | 47 | 45 | 0.958
Mean (SD) | 0.8 (0.5) | 0.9 (0.5) | 0.1 (0.6) | | 0.8 (0.6) | 0.1 (0.5) | | 1.0 (1.6) | 0.2 (1.6)
Median (Min, Max) | 0.9 (0.0, 2.4) | 1.0 (0.0, 2.3) | 0.0 (−1.2, 1.7) | | 0.7 (0.0, 1.7) | 0.1 (−0.5, 1.3) | | 0.8 (0.0, 11.3) | 0.0 (−1.2, 10.1)

Note:

1 Non-parametric sign rank sum test is used to test the difference from baseline.

Table 14.3.3.1.6 Summary of Quantitative Clinical Laboratory Evaluations by Time (Baseline and Post-Baseline) Safety Population VBG (Blood Gases)

Laboratory Test | Pre-Dose | 8 Hours Post-Start Drug | | | 16 Hours Post-Start Drug | | | Study Drug D/C
Laboratory Test | Result | Result | Change from Pre-Dose | P Value^1^ | Result | Change from Pre-Dose | P Value^1^ | Result | Change from Pre-Dose | P Value^1^
pH
N | 46 | 42 | 40 | 0.053 | 13 | 12 | 0.203 | 47 | 44 | 0.101
Mean (SD) | 7.3 (0.1) | 7.4 (0.0) | 0.0 (0.1) | | 7.4 (0.0) | 0.0 (0.1) | | 7.4 (0.1) | 0.0 (0.1)
Median (Min, Max) | 7.4 (7.1, 7.5) | 7.4 (7.3, 7.5) | 0.0 (−0.1, 0.3) | | 7.4 (7.3, 7.5) | 0.0 (−0.1, 0.2) | | 7.4 (7.2, 7.5) | 0.0 (−0.2, 0.2)
PCO_2_ (mmHg)
N | 46 | 42 | 40 | 0.400 | 13 | 12 | 0.096 | 47 | 44 | 0.205
Mean (SD) | 50.7 (10.1) | 49.0 (7.5) | −2.3 (9.6) | | 45.9 (7.2) | −2.5 (5.3) | | 48.3 (6.8) | −2.6 (9.7)
Median (Min, Max) | 49.5 (29.0, 78.0) | 49.0 (33.0, 69.0) | 0.0 (−31.0, 11.0) | | 47.0 (28.0, 56.0) | −3.5 (−11.0, 10.0) | | 48.0 (37.0, 69.0) | −0.5 (−29.0, 13.0)
PO_2_ (mmHg)
N | 46 | 42 | 40 | 0.270 | 13 | 12 | 0.106 | 47 | 44 | 0.074
Mean (SD) | 44.7 (14.0) | 42.8 (8.8) | −1.9 (12.3) | | 43.2 (8.2) | −4.7 (11.7) | | 40.5 (8.9) | −3.4 (12.9)
Median (Min, Max) | 44.0 (11.0, 101.0) | 41.0 (25.0, 73.0) | 0.0 (−28.0, 26.0) | | 40.0 (34.0, 62.0) | −7.5 (−17.0, 25.0) | | 40.0 (22.0, 62.0) | −3.0 (−46.0, 28.0)
SO_2_ (%)
N | 47 | 41 | 41 | 0.569 | 14 | 13 | 0.317 | 48 | 45 | 0.293
Mean (SD) | 74.7 (15.3) | 74.6 (11.3) | −0.4 (16.5) | | 79.9 (9.0) | −0.5 (15.1) | | 72.2 (12.4) | −1.1 (16.1)
Median (Min, Max) | 78.0 (13.0, 97.0) | 76.0 (36.0, 94.0) | 0.0 (−40.0, 45.0) | | 79.0 (66.0, 96.0) | −3.0 (−13.0, 44.0) | | 75.0 (42.0, 93.0) | −2.0 (−48.0, 61.0)
HCO_3_ (mEq/L)
N | 46 | 42 | 40 | 0.094 | 13 | 12 | 0.535 | 47 | 44 | 0.345
Mean (SD) | 25.3 (3.8) | 26.5 (3.5) | 0.9 (2.7) | | 25.8 (3.2) | 0.3 (3.1) | | 25.8 (3.4) | 0.4 (3.9)
Median (Min, Max) | 25.0 (16.0, 39.0) | 26.0 (21.0, 38.0) | 1.0 (−4.0, 8.0) | | 26.0 (18.0, 30.0) | 1.0 (−7.0, 3.0) | | 25.0 (17.0, 37.0) | 1.0 (−14.0, 12.0)
Methemoglobin (%)
N | 45 | 41 | 39 | 0.320 | 13 | 12 | 0.980 | 47 | 42 | 0.131
Mean (SD) | 0.7 (0.6) | 0.8 (0.6) | 0.1 (0.6) | | 0.7 (0.5) | 0.0 (0.5) | | 0.6 (0.6) | −0.1 (0.6)
Median (Min, Max) | 0.7 (0.0, 2.8) | 0.9 (0.0, 2.3) | 0.0 (−1.0, 1.6) | | 0.9 (0.0, 1.2) | 0.0 (−1.1, 0.8) | | 0.6 (0.0, 2.4) | −0.2 (−1.1, 1.5)

Note:

1 Non-parametric sign rank sum test is used to test the difference from baseline.

Table 14.3.3.1.7 Summary of Quantitative Clinical Laboratory Evaluations by Time (Baseline and Post-Baseline) Safety Population Central Laboratary Tests

Laboratory Test | Pre-dose | 8 Hours Post-Start Drug | | | 16 Hours Post-Start Drug | | | 24 Hours Post-Start Drug
Laboratory Test | Result | Result | Change from Pre-Dose | P Value^1^ | Result | Change from Pre-Dose | P Value^1^ | Result | Change from Pre-Dose | P Value^1^
Cyanide in whole blood (mcg/mL)
N | 48 | 46 | 42 | <.001 | 16 | 14 | 0.031 | 1 | 1 | NA
Mean (SD) | 0.0 (0.0) | 0.4 (0.9) | 0.5 (0.9) | | 1.2 (1.8) | 1.3 (1.9) | | 0.0 | 0.0
Median (Min, Max) | 0.0 (0.0, 0.0) | 0.0 (0.0, 3.3) | 0.0 (0.0, 3.3) | | 0.0 (0.0, 5.1) | 0.0 (0.0, 5.1) | | 0.0 | 0.0
Thiocyanate in plasma (mcg/mL)
N | 48 | 47 | 43 | <.001 | 16 | 15 | <.001 | 1 | 1 | 1.000
Mean (SD) | 0.4 (1.2) | 2.3 (1.7) | 2.0 (1.3) | | 5.1 (3.1) | 5.2 (3.2) | | 2.3 | 2.3
Median (Min, Max) | 0.0 (0.0, 6.9) | 2.1 (0.0, 9.1) | 1.9 (−0.3, 5.0) | | 4.5 (1.5, 13.0) | 4.1 (1.5, 13.0) | | 2.3 | 2.3
Thiocyanate in urine (mcg/mL)
N | 47 | 47 | 42 | 0.019 | 17 | 13 | 0.007 | 1 | 1 | 1.000
Mean (SD) | 0.2 (0.7) | 0.6 (1.2) | 0.4 (1.0) | | 2.4 (2.5) | 2.2 (2.9) | | 1.3 | 1.3
Median (Min, Max) | 0.0 (0.0, 2.9) | 0.0 (0.0, 4.9) | 0.0 (−1.8, 3.6) | | 1.7 (0.0, 10.0) | 1.7 (−1.2, 10.0) | | 1.3 | 1.3

Note:

1 Non-parametric sign rank sum test is used to test the difference from baseline.

Only scheduled measurements are included in the table.

Laboratory Test | Study Drug D/C | | | 8 hours post Blinded Study Drug | | | 12 hours post Blinded Study Drug
Laboratory Test | Result | Change from Pre-Dose | P Value^1^ | Result | Change from Pre-Dose | P Value^1^ | Result | Change from Pre-Dose | P Value^1^
Cyanide in whole blood (mcg/mL)
N | 43 | 41 | <.001 | ▬ | ▬ | ▬ | 37 | 36 | 0.016
Mean (SD) | 0.9 (1.6) | 1.0 (1.6) | | ▬ | ▬ | ▬ | 0.6 (1.5) | 0.6 (1.5)
Median (Min, Max) | 0.0 (0.0, 4.6) | 0.0 (0.0, 4.6) | | ▬ | ▬ | ▬ | 0.0 (0.0, 6.1) | 0.0 (0.0, 6.1)
Thiocyanate in plasma (mcg/mL)
N | 47 | 43 | <.001 | ▬ | ▬ | ▬ | 39 | 37 | <.001
Mean (SD) | 4.7 (3.4) | 4.3 (3.6) | | ▬ | ▬ | ▬ | 6.8 (4.2) | 6.8 (4.3)
Median (Min, Max) | 3.9 (0.0, 18.0) | 3.6 (−0.4, 18.0) | | ▬ | ▬ | ▬ | 6.3 (0.0, 18.0) | 6.3 (0.0, 18.0)
Thiocyanate in urine (mcg/mL)
N | 45 | 40 | <.001 | 35 | 31 | <.001 | ▬ | ▬ | ▬
Mean (SD) | 2.4 (2.1) | 2.1 (2.2) | | 3.7 (2.8) | 3.4 (2.6) | | ▬ | ▬ | ▬
Median (Min, Max) | 2.0 (0.0, 7.1) | 1.8 (−2.9, 7.1) | | 3.0 (0.0, 10.0) | 2.9 (0.0, 10.0) | | ▬ | ▬ | ▬

Note:

1 Non-parametric sign rank sum test is used to test the difference from baseline.

Only scheduled measurements are included in the table.

Laboratory Test | 16 hours post Blinded Study Drug | | | 24 hours post Blinded Study Drug | | | Worst Post-Dose Measurement^2^
Laboratory Test | Result | Change from Pre-Dose | P Value^1^ | Result | Change from Pre-Dose | P Value^1^ | Result | Change from Pre-Dose | P Value^1^
Cyanide in whole blood (mcg/mL)
N | ▬ | ▬ | ▬ | ▬ | ▬ | ▬ | 51 | 47 | <.001
Mean (SD) | ▬ | ▬ | ▬ | ▬ | ▬ | ▬ | 1.0 (1.9) | 1.1 (1.9)
Median (Min, Max) | ▬ | ▬ | ▬ | ▬ | ▬ | ▬ | 0.0 (0.0, 6.5) | 0.0 (0.0, 6.5)
Thiocyanate in plasma (mcg/mL)
N | ▬ | ▬ | ▬ | ▬ | ▬ | ▬ | 52 | 48 | <.001
Mean (SD) | ▬ | ▬ | ▬ | ▬ | ▬ | ▬ | 7.0 (4.6) | 6.7 (4.9)
Median (Min, Max) | ▬ | ▬ | ▬ | ▬ | ▬ | ▬ | 6.4 (0.0, 18.0) | 6.4 (−0.3, 18.0)
Thiocyanate in urine (mcg/mL)
N | 33 | 29 | <.001 | 33 | 30 | <.001 | 52 | 47 | <.001
Mean (SD) | 5.9 (7.4) | 4.7 (2.9) | | 6.4 (7.6) | 4.7 (3.3) | | 5.6 (6.7) | 4.3 (3.6)
Median (Min, Max) | 4.6 (0.0, 44.0) | 4.1 (0.0, 11.0) | | 4.9 (0.0, 41.0) | 4.0 (0.0, 11.0) | | 4.1 (0.0, 44.0) | 3.8 (−1.8, 11.0)

Note:

1 Non-parametric sign rank sum test is used to test the difference from baseline.

2 Only this column may contain unscheduled measurements.

Table 14.3.3.2.1 Summary of Quantitative Clinical Laboratory Evaluations by Treatment (Baseline and Post-Baseline) ITT Population Hematology Panel

Laboratory Test | SNP | | | | Placebo | | | | P Value^2^
Laboratory Test | Pre-Dose | Study Drug D/C | | P Value^1^ | Pre-Dose | Study Drug D/C | | P Value^1^ | P Value^2^
Laboratory Test | Result | Result | Change from Pre-Dose | P Value^1^ | Result | Result | Change from Pre-Dose | P Value^1^ | P Value^2^
WBC (10^3^/mm^3^)
N | 25 | 24 | 24 | 0.342 | 20 | 20 | 19 | 0.028 | 0.191
Mean (SD) | 11.3 (6.2) | 12.5 (6.3) | 0.9 (4.7) | | 10.3 (5.4) | 12.3 (4.5) | 3.0 (5.3)
Median (Min, Max) | 9.4 (4.3, 30.8) | 11.2 (4.0, 33.0) | 1.6 (−8.7, 7.7) | | 8.5 (5.1, 26.9) | 11.9 (5.6, 20.0) | 3.7 (−8.2, 13.0)
HGB (g/dL)
N | 25 | 24 | 24 | 0.006 | 20 | 20 | 19 | 0.522 | 0.310
Mean (SD) | 12.5 (2.0) | 11.2 (1.9) | −1.2 (2.2) | | 12.1 (1.9) | 11.8 (2.0) | −0.2 (2.7)
Median (Min, Max) | 13.1 (8.0, 15.2) | 10.8 (8.2, 16.8) | −1.4 (−4.9, 4.2) | | 12.5 (7.9, 16.2) | 11.4 (8.9, 16.5) | −1.0 (−4.5, 5.1)
HCT (%)
N | 25 | 24 | 24 | 0.003 | 20 | 20 | 19 | 0.447 | 0.178
Mean (SD) | 37.1 (6.3) | 32.7 (5.7) | −4.1 (6.6) | | 35.3 (5.5) | 34.3 (6.0) | −0.8 (7.9)
Median (Min, Max) | 38.7 (23.8, 47.8) | 31.4 (23.7, 48.5) | −5.0 (−14.0, 13.1) | | 36.5 (23.0, 47.0) | 34.0 (25.8, 48.0) | −2.3 (−14.2, 14.0)
Platelet Count (10^3^/mm^3^)
N | 25 | 24 | 24 | 0.149 | 20 | 20 | 19 | 0.011 | 0.139
Mean (SD) | 236.3 (95.0) | 208.0 (98.8) | −24.6 (73.4) | | 306.6 (172.1) | 249.0 (97.3) | −69.0 (111.8)
Median (Min, Max) | 215.0 (103.0, 396.0) | 197.0 (64.0, 414.0) | −19.0 (−257, 96.0) | | 252.5 (101.0, 781.0) | 220.5 (115.0, 484.0) | −44.0 (−297, 155.0)

Note:

1 Non-parametric sign rank sum test is used to test the difference from baseline.

2 Non-parametric Kruskal Wallis test is used to test the difference of change from pre-dose between treatment arms.

Table 14.3.3.2.2 Summary of Quantitative Clinical Laboratory Evaluations by Treatment (Baseline and Post-Baseline) ITT Population Chemistry Panel

Laboratory Test | SNP | | | | Placebo | | | | P Value^2^
Laboratory Test | Pre-Dose | Study Drug D/C | | P Value^1^ | Pre-Dose | Study Drug D/C | | P Value^1^ | P Value^2^
Laboratory Test | Result | Result | Change from Pre-Dose | P Value^1^ | Result | Result | Change from Pre-Dose | P Value^1^ | P Value^2^
Sodium (mmol/L)
N | 25 | 25 | 25 | 0.041 | 21 | 21 | 21 | 0.052 | 0.715
Mean (SD) | 140.3 (5.0) | 137.9 (4.9) | −2.4 (5.1) | | 139.1 (6.6) | 137.6 (3.5) | −1.5 (6.3)
Median (Min, Max) | 140.0 (130.0, 149.0) | 138.0 (125.0, 147.0) | −3.0 (−15.0, 7.0) | | 140.0 (114.0, 146.0) | 138.0 (129.0, 146.0) | −2.0 (−11.0, 20.0)
Potassium (mmol/L)
N | 25 | 25 | 25 | 0.888 | 21 | 21 | 21 | 0.906 | 0.938
Mean (SD) | 3.9 (0.7) | 4.0 (1.1) | 0.1 (1.4) | | 3.9 (0.8) | 4.0 (0.6) | 0.1 (0.9)
Median (Min, Max) | 3.8 (3.1, 6.1) | 3.8 (3.0, 8.8) | 0.0 (−2.6, 5.5) | | 3.9 (2.6, 5.8) | 4.0 (2.9, 5.3) | −0.1 (−1.5, 2.3)
Chloride (mmol/L)
N | 25 | 25 | 25 | 0.470 | 21 | 21 | 21 | 0.090 | 0.749
Mean (SD) | 105.0 (7.1) | 104.0 (6.0) | −1.0 (7.0) | | 105.2 (5.7) | 103.3 (4.6) | −1.9 (4.4)
Median (Min, Max) | 104.0 (90.0, 121.0) | 105.0 (89.0, 117.0) | −1.0 (−17.0, 11.0) | | 106.0 (85.0, 114.0) | 104.0 (91.0, 111.0) | −1.0 (−10.0, 6.0)
Carbon Dioxide (mmol/L)
N | 25 | 25 | 25 | 0.504 | 21 | 21 | 21 | 0.969 | 0.617
Mean (SD) | 26.0 (2.7) | 25.6 (2.8) | −0.4 (3.7) | | 26.4 (5.1) | 26.3 (3.2) | 0.0 (3.0)
Median (Min, Max) | 26.0 (21.0, 33.0) | 25.0 (20.0, 32.0) | −1.0 (−10.0, 8.0) | | 26.0 (17.0, 41.0) | 26.0 (22.0, 35.0) | 0.0 (−6.0, 5.0)
BUN (Urea) (mg/dL)
N | 25 | 24 | 24 | 0.264 | 21 | 21 | 21 | 0.350 | 0.174
Mean (SD) | 13.0 (10.2) | 12.5 (12.1) | −1.0 (5.1) | | 8.6 (4.5) | 10.1 (5.8) | 1.5 (5.4)
Median (Min, Max) | 10.0 (1.0, 54.0) | 10.0 (5.0, 66.0) | −1.0 (−10.0, 12.0) | | 8.0 (1.0, 19.0) | 9.0 (1.0, 20.0) | 0.0 (−7.0, 10.0)
Creatinine (mg/dL)
N | 25 | 24 | 24 | 0.066 | 21 | 21 | 21 | 0.128 | 0.020
Mean (SD) | 0.5 (0.2) | 0.4 (0.2) | −0.1 (0.2) | | 0.4 (0.2) | 0.4 (0.2) | 0.0 (0.1)
Median (Min, Max) | 0.5 (0.2, 1.1) | 0.4 (0.2, 0.8) | 0.0 (−0.7, 0.3) | | 0.4 (0.1, 0.7) | 0.4 (0.2, 1.0) | 0.0 (−0.2, 0.3)

Note:

1 Non-parametric sign rank sum test is used to test the difference from baseline.

2 Non-parametric Kruskal Wallis test is used to test the difference of change from pre-dose between treatment arms.

Table 14.3.3.2.3 Summary of Quantitative Clinical Laboratory Evaluations by Treatment (Baseline and Post-Baseline) ITT Population Liver Functions Tests Panel

Laboratory Test | SNP | | | | Placebo | | | | P Value^2^
Laboratory Test | Pre-Dose | Study Drug D/C | | P Value^1^ | Pre-Dose | Study Drug D/C | | P Value^1^ | P Value^2^
Laboratory Test | Result | Result | Change from Pre-Dose | P Value^1^ | Result | Result | Change from Pre-Dose | P Value^1^ | P Value^2^
ALT (SGPT) (U/L)
N | 25 | 25 | 25 | 0.003 | 21 | 21 | 21 | 0.298 | 0.265
Mean (SD) | 57.9 (113.2) | 31.0 (55.5) | −26.9 (76.3) | | 27.1 (15.1) | 27.4 (19.5) | 0.2 (18.1)
Median (Min, Max) | 23.0 (11.0, 500.0) | 19.0 (9.0, 291.0) | −4.0 (−333, 8.0) | | 20.0 (13.0, 69.0) | 20.0 (10.0, 83.0) | −3.0 (−25.0, 63.0)
AST (SGOT) (U/L)
N | 25 | 24 | 24 | 0.395 | 21 | 21 | 21 | 0.437 | 0.991
Mean (SD) | 144.7 (399.9) | 96.1 (201.0) | −53.6 (211.0) | | 54.6 (37.3) | 45.8 (24.0) | −8.8 (26.5)
Median (Min, Max) | 40.0 (19.0, 2039) | 45.0 (18.0, 1023) | −5.0 (−1016, 79.0) | | 40.0 (19.0, 148.0) | 38.0 (21.0, 124.0) | −4.0 (−90.0, 17.0)

Note:

1 Non-parametric sign rank sum test is used to test the difference from baseline.

2 Non-parametric Kruskal Wallis test is used to test the difference of change from pre-dose between treatment arms.

Table 14.3.3.2.4 Summary of Quantitative Clinical Laboratory Evaluations by Treatment (Baseline and Post-Baseline) ITT Population Lactate

Laboratory Test | SNP | | | | Placebo | | | | P Value^2^
Laboratory Test | Pre-Dose | Study Drug D/C | | P Value^1^ | Pre-Dose | Study Drug D/C | | P Value^1^ | P Value^2^
Laboratory Test | Result | Result | Change from Pre-Dose | P Value^1^ | Result | Result | Change from Pre-Dose | P Value^1^ | P Value^2^
Lactate (mmol/L)
N | 25 | 24 | 24 | 0.616 | 21 | 20 | 20 | 0.924 | 0.715
Mean (SD) | 1.6 (1.2) | 1.8 (1.3) | 0.1 (1.2) | | 1.6 (1.2) | 1.3 (0.6) | −0.2 (1.3)
Median (Min, Max) | 1.2 (0.4, 5.8) | 1.2 (0.6, 5.5) | 0.1 (−2.4, 2.5) | | 1.2 (0.5, 4.9) | 1.2 (0.5, 2.8) | 0.1 (−4.0, 1.4)

Note:

1 Non-parametric sign rank sum test is used to test the difference from baseline.

2 Non-parametric Kruskal Wallis test is used to test the difference of change from pre-dose between treatment arms.

Table 14.3.3.2.5 Summary of Quantitative Clinical Laboratory Evaluations by Treatment (Baseline and Post-Baseline) ITT Population ABG (Blood Gases)

Laboratory Test | SNP | | | | Placebo | | | | P Value^2^
Laboratory Test | Pre-Dose | Study Drug D/C | | P Value^1^ | Pre-Dose | Study Drug D/C | | P Value^1^ | P Value^2^
Laboratory Test | Result | Result | Change from Pre-Dose | P Value^1^ | Result | Result | Change from Pre-Dose | P Value^1^ | P Value^2^
pH
N | 25 | 23 | 23 | 0.024 | 21 | 21 | 21 | 0.316 | 0.452
Mean (SD) | 7.4 (0.1) | 7.4 (0.0) | 0.0 (0.1) | | 7.4 (0.1) | 7.4 (0.0) | 0.0 (0.1)
Median (Min, Max) | 7.4 (7.2, 7.5) | 7.4 (7.3, 7.5) | 0.0 (−0.1, 0.2) | | 7.4 (7.2, 7.5) | 7.4 (7.4, 7.5) | 0.0 (−0.1, 0.3)
PCO_2_ (mmHg)
N | 25 | 23 | 23 | 0.184 | 21 | 21 | 21 | 0.852 | 0.741
Mean (SD) | 42.9 (7.9) | 41.2 (5.1) | −1.9 (6.3) | | 43.6 (8.8) | 42.7 (6.3) | −0.9 (10.0)
Median (Min, Max) | 43.0 (32.0, 70.0) | 42.0 (30.0, 50.0) | −1.0 (−20.0, 12.0) | | 42.0 (31.0, 66.0) | 41.0 (33.0, 61.0) | −1.0 (−28.0, 14.0)
PO_2_ (mmHg)
N | 25 | 23 | 23 | 0.034 | 21 | 21 | 21 | 0.002 | 0.264
Mean (SD) | 148.5 (107.5) | 90.9 (35.7) | −44.8 (105.4) | | 171.5 (119.5) | 90.9 (27.5) | −80.6 (118.9)
Median (Min, Max) | 109.0 (37.0, 492.0) | 86.0 (39.0, 191.0) | −11.0 (−401, 124.0) | | 135.0 (49.0, 478.0) | 82.0 (44.0, 154.0) | −35.0 (−396, 69.0)
SO_2_ (%)
N | 25 | 23 | 23 | 0.992 | 21 | 21 | 21 | 0.070 | 0.148
Mean (SD) | 94.3 (8.1) | 93.3 (8.1) | −0.6 (5.7) | | 96.0 (4.7) | 95.3 (4.7) | −0.7 (3.9)
Median (Min, Max) | 97.0 (63.0, 100.0) | 96.0 (73.0, 99.0) | 0.0 (−22.0, 10.0) | | 97.0 (80.0, 100.0) | 96.0 (77.0, 100.0) | −1.0 (−7.0, 13.0)
HCO_3_ (mEq/L)
N | 25 | 23 | 23 | 0.067 | 21 | 21 | 21 | 0.213 | 0.670
Mean (SD) | 24.9 (3.0) | 26.3 (2.5) | 1.2 (3.0) | | 25.7 (4.3) | 26.5 (3.3) | 0.8 (2.6)
Median (Min, Max) | 24.0 (19.0, 31.0) | 26.0 (21.0, 32.0) | 1.0 (−5.0, 8.0) | | 24.0 (20.0, 39.0) | 26.0 (22.0, 35.0) | 1.0 (−4.0, 6.0)
Methemoglobin (%)
N | 23 | 22 | 21 | 0.960 | 20 | 21 | 20 | 0.890 | 0.794
Mean (SD) | 0.8 (0.3) | 0.9 (0.5) | 0.0 (0.6) | | 0.8 (0.7) | 0.8 (0.6) | 0.0 (0.5)
Median (Min, Max) | 0.9 (0.1, 1.4) | 0.8 (0.0, 1.6) | 0.1 (−1.2, 1.0) | | 0.8 (0.0, 2.4) | 0.7 (0.0, 1.9) | 0.0 (−0.9, 0.7)

Note:

1 Non-parametric sign rank sum test is used to test the difference from baseline.

2 Non-parametric Kruskal Wallis test is used to test the difference of change from pre-dose between treatment arms.

Table 14.3.3.2.6 Summary of Quantitative Clinical Laboratory Evaluations by Treatment (Baseline and Post-Baseline) ITT Population VBG (Blood Gases)

Laboratory Test | SNP | | | | Placebo | | | | P Value^2^
Laboratory Test | Pre-Dose | Study Drug D/C | | P Value^1^ | Pre-Dose | Study Drug D/C | | P Value^1^ | P Value^2^
Laboratory Test | Result | Result | Change from Pre-Dose | P Value^1^ | Result | Result | Change from Pre-Dose | P Value^1^ | P Value^2^
pH
N | 23 | 24 | 22 | 0.136 | 18 | 19 | 18 | 0.116 | 0.522
Mean (SD) | 7.3 (0.1) | 7.4 (0.1) | 0.0 (0.1) | | 7.3 (0.1) | 7.4 (0.0) | 0.0 (0.1)
Median (Min, Max) | 7.4 (7.1, 7.5) | 7.4 (7.2, 7.5) | 0.0 (−0.2, 0.2) | | 7.3 (7.2, 7.4) | 7.4 (7.3, 7.5) | 0.0 (−0.1, 0.2)
PCO_2_ (mmHg)
N | 23 | 24 | 22 | 0.236 | 18 | 19 | 18 | 0.078 | 0.614
Mean (SD) | 49.6 (12.0) | 46.3 (6.1) | −3.7 (10.3) | | 53.3 (7.8) | 49.6 (7.3) | −3.8 (8.7)
Median (Min, Max) | 48.0 (29.0, 78.0) | 46.5 (37.0, 58.0) | −0.5 (−29.0, 8.0) | | 52.5 (44.0, 72.0) | 47.0 (40.0, 69.0) | −4.0 (−29.0, 9.0)
PO_2_ (mmHg)
N | 23 | 24 | 22 | 0.134 | 18 | 19 | 18 | 0.177 | 0.913
Mean (SD) | 45.7 (16.8) | 40.0 (8.0) | −4.4 (14.2) | | 44.3 (10.0) | 40.9 (8.8) | −3.1 (10.3)
Median (Min, Max) | 44.0 (11.0, 101.0) | 40.5 (23.0, 57.0) | −3.5 (−46.0, 28.0) | | 44.5 (28.0, 71.0) | 40.0 (26.0, 62.0) | −3.0 (−25.0, 17.0)
SO_2_ (%)
N | 24 | 24 | 23 | 0.341 | 19 | 20 | 19 | 0.483 | 0.980
Mean (SD) | 74.5 (17.5) | 72.5 (12.2) | −0.3 (16.1) | | 74.9 (13.2) | 71.8 (13.1) | −2.2 (15.9)
Median (Min, Max) | 77.5 (13.0, 97.0) | 75.5 (42.0, 90.0) | −4.0 (−27.0, 61.0) | | 78.0 (47.0, 95.0) | 73.0 (42.0, 93.0) | −2.0 (−48.0, 31.0)
HCO_3_ (mEq/L)
N | 23 | 24 | 22 | 0.397 | 18 | 19 | 18 | 0.830 | 0.564
Mean (SD) | 24.7 (3.6) | 25.4 (3.6) | 0.6 (5.3) | | 26.4 (4.3) | 26.5 (3.5) | 0.1 (2.0)
Median (Min, Max) | 25.0 (16.0, 31.0) | 25.5 (17.0, 32.0) | 0.5 (−14.0, 12.0) | | 25.0 (21.0, 39.0) | 26.0 (23.0, 37.0) | 1.0 (−4.0, 3.0)
Methemoglobin (%)
N | 23 | 24 | 22 | 0.337 | 18 | 19 | 17 | 0.454 | 0.977
Mean (SD) | 0.7 (0.5) | 0.7 (0.6) | −0.1 (0.6) | | 0.7 (0.7) | 0.7 (0.6) | −0.1 (0.6)
Median (Min, Max) | 0.7 (0.0, 2.0) | 0.4 (0.0, 1.7) | −0.2 (−1.1, 1.5) | | 0.7 (0.0, 2.8) | 0.7 (0.0, 2.4) | −0.1 (−1.1, 0.9)

Note:

1 Non-parametric sign rank sum test is used to test the difference from baseline.

2 Non-parametric Kruskal Wallis test is used to test the difference of change from pre-dose between treatment arms.

Table 14.3.3.2.7 Summary of Quantitative Clinical Laboratory Evaluations by Treatment (Baseline and Post-Baseline) ITT Population Central Laboratary Tests

Laboratory Test | SNP; (N=25) | | | | Placebo; (N=21) | | | | P Value^2^
Laboratory Test | Pre-Dose | Study Drug D/C | | P Value^1^ | Pre-Dose | Study Drug D/C | | P Value^1^ | P Value^2^
Laboratory Test | Result | Result | Change from Pre-Dose | P Value^1^ | Result | Result | Change from Pre-Dose | P Value^1^ | P Value^2^
Cyanide in whole blood (mcg/mL)
N | 23 | 22 | 21 | 0.016 | 19 | 18 | 17 | 0.063 | 0.859
Mean (SD) | 0.0 (0.0) | 1.1 (1.6) | 1.1 (1.6) | | 0.0 (0.0) | 1.0 (1.7) | 1.0 (1.7)
Median (Min, Max) | 0.0 (0.0, 0.0) | 0.0 (0.0, 3.9) | 0.0 (0.0, 3.9) | | 0.0 (0.0, 0.0) | 0.0 (0.0, 4.6) | 0.0 (0.0, 4.6)
Thiocyanate in plasma (mcg/mL)
N | 24 | 23 | 22 | <.001 | 18 | 21 | 18 | <.001 | 0.430
Mean (SD) | 0.2 (0.7) | 4.1 (2.3) | 4.0 (2.5) | | 0.6 (1.7) | 5.8 (4.1) | 5.5 (4.4)
Median (Min, Max) | 0.0 (0.0, 3.4) | 3.5 (0.0, 9.0) | 3.7 (−0.4, 9.0) | | 0.0 (0.0, 6.9) | 5.3 (0.0, 18.0) | 4.9 (0.0, 18.0)
Thiocyanate in urine (mcg/mL)
N | 22 | 21 | 18 | 0.004 | 19 | 21 | 19 | <.001 | 0.532
Mean (SD) | 0.3 (0.8) | 2.1 (1.7) | 2.0 (2.1) | | 0.2 (0.7) | 3.0 (2.3) | 2.7 (2.2)
Median (Min, Max) | 0.0 (0.0, 2.9) | 1.9 (0.0, 5.7) | 1.9 (−2.9, 5.7) | | 0.0 (0.0, 2.9) | 2.3 (0.0, 7.1) | 2.1 (0.0, 7.1)

Note:

1 Non-parametric sign rank sum test is used to test the difference from baseline.

2 Non-parametric Kruskal Wallis test is used to test the difference of change from pre-dose between treatment arms.

Table 14.3.3.3.1 Summary of Categorical Clinical Laboratory Evaluations by Time (Baseline and Post-Baseline) Safety Population Hematology Panel

Laboratory Test | Pre-Dose; Normal | | Pre-Dose; Abnormal | | Total; N (%) | P Value^1^
Laboratory Test | Post-Baseline; Normal; N (%) | Post-Baseline; Abnormal^2^; N (%) | Post-Baseline; Normal; N (%) | Post-Baseline; Abnormal^2^; N (%) | Total; N (%) | P Value^1^
WBC (10^3^/mm^3^)
All subjects | 26 (55.3%) | 13 (27.7%) | 3 (6.4%) | 5 (10.6%) | 47 (100%) | 0.021
Placebo | 16 (66.7%) | 4 (16.7%) | 1 (4.2%) | 3 (12.5%) | 24 (100%) | 0.375
SNP | 8 (42.1%) | 8 (42.1%) | 2 (10.5%) | 1 (5.3%) | 19 (100%) | 0.109
HGB (g/dL)
All subjects | 14 (29.8%) | 17 (36.2%) | 5 (10.6%) | 11 (23.4%) | 47 (100%) | 0.017
Placebo | 6 (25.0%) | 9 (37.5%) | 2 (8.3%) | 7 (29.2%) | 24 (100%) | 0.065
SNP | 7 (36.8%) | 6 (31.6%) | 3 (15.8%) | 3 (15.8%) | 19 (100%) | 0.508
HCT (%)
All subjects | 9 (19.1%) | 16 (34.0%) | 4 (8.5%) | 18 (38.3%) | 47 (100%) | 0.012
Placebo | 6 (25.0%) | 8 (33.3%) | 1 (4.2%) | 9 (37.5%) | 24 (100%) | 0.039
SNP | 2 (10.5%) | 6 (31.6%) | 3 (15.8%) | 8 (42.1%) | 19 (100%) | 0.508
Platelet Count (10_3_/mm_3_)
All subjects | 31 (66.0%) | 4 (8.5%) | 3 (6.4%) | 9 (19.1%) | 47 (100%) | 1.000
Placebo | 17 (70.8%) | 3 (12.5%) | 0 | 4 (16.7%) | 24 (100%) | 0.250
SNP | 11 (57.9%) | 1 (5.3%) | 3 (15.8%) | 4 (21.1%) | 19 (100%) | 0.625

Note:

1 McNemar’s test is used to test whether the proportion of subjects with abnormal measurement at pre-dose is the same as the proportion at post-baseline.

2 Abnormal is defined with abnormally and clinically significant and abnormally but not clinically significant combined.

Table 14.3.3.3.2 Summary of Categorical Clinical Laboratory Evaluations by Time (Baseline and Post-Baseline) Safety Population Chemistry Panel

Laboratory Test | Pre-Dose; Normal | | Pre-Dose; Abnormal | | Total; N (%) | McNemar Test P Value
Laboratory Test | Post-Baseline; Normal; N (%) | Post-Baseline; Abnormal^2^; N (%) | Post-Baseline; Normal; N (%) | Post-Baseline; Abnormal^2^; N (%) | Total; N (%) | McNemar Test P Value
Sodium (mmol/L)
All subjects | 29 (58.0%) | 12 (24.0%) | 6 (12.0%) | 3 (6.0%) | 50 (100%) | 0.238
Placebo | 10 (40.0%) | 7 (28.0%) | 5 (20.0%) | 3 (12.0%) | 25 (100%) | 0.774
SNP | 15 (71.4%) | 5 (23.8%) | 1 (4.8%) | 0 | 21 (100%) | 0.219
Potassium (mmol/L)
All subjects | 25 (50.0%) | 6 (12.0%) | 12 (24.0%) | 7 (14.0%) | 50 (100%) | 0.238
Placebo | 11 (44.0%) | 3 (12.0%) | 7 (28.0%) | 4 (16.0%) | 25 (100%) | 0.344
SNP | 12 (57.1%) | 2 (9.5%) | 4 (19.0%) | 3 (14.3%) | 21 (100%) | 0.688
Chloride (mmol/L)
All subjects | 38 (76.0%) | 3 (6.0%) | 5 (10.0%) | 4 (8.0%) | 50 (100%) | 0.727
Placebo | 16 (64.0%) | 3 (12.0%) | 4 (16.0%) | 2 (8.0%) | 25 (100%) | 1.000
SNP | 19 (90.5%) | 0 | 1 (4.8%) | 1 (4.8%) | 21 (100%) | 1.000
Carbon Dioxide (mmol/L)
All subjects | 32 (64.0%) | 2 (4.0%) | 9 (18.0%) | 7 (14.0%) | 50 (100%) | 0.065
Placebo | 16 (64.0%) | 2 (8.0%) | 4 (16.0%) | 3 (12.0%) | 25 (100%) | 0.688
SNP | 13 (61.9%) | 0 | 5 (23.8%) | 3 (14.3%) | 21 (100%) | 0.063
BUN (Urea) (mg/dL)
All subjects | 38 (77.6%) | 5 (10.2%) | 3 (6.1%) | 3 (6.1%) | 49 (100%) | 0.727
Placebo | 17 (70.8%) | 3 (12.5%) | 2 (8.3%) | 2 (8.3%) | 24 (100%) | 1.000
SNP | 18 (85.7%) | 1 (4.8%) | 1 (4.8%) | 1 (4.8%) | 21 (100%) | 1.000
Creatinine (mg/dL)
All subjects | 30 (61.2%) | 6 (12.2%) | 2 (4.1%) | 11 (22.4%) | 49 (100%) | 0.289
Placebo | 14 (58.3%) | 5 (20.8%) | 1 (4.2%) | 4 (16.7%) | 24 (100%) | 0.219
SNP | 12 (57.1%) | 1 (4.8%) | 1 (4.8%) | 7 (33.3%) | 21 (100%) | 1.000

Note:

1 McNemar’s test is used to test whether the proportion of subjects with abnormal measurement at pre-dose is the same as the proportion at post-baseline.

2 Abnormal is defined with abnormally and clinically significant and abnormally but not clinically significant combined.

Table 14.3.3.3.3 Summary of Categorical Clinical Laboratory Evaluations by Time (Baseline and Post-Baseline) Safety Population Liver Functions Tests Panel

Laboratory Test | Pre-Dose; Normal | | Pre-Dose; Abnormal | | Total; N (%) | P Value^1^
Laboratory Test | Post-Baseline; Normal; N (%) | Post-Baseline; Abnormal^2^; N (%) | Post-Baseline; Normal; N (%) | Post-Baseline; Abnormal^2^; N (%) | Total; N (%) | P Value^1^
ALT (SGPT) (U/L)
All subjects | 40 (80.0%) | 1 (2.0%) | 3 (6.0%) | 6 (12.0%) | 50 (100%) | 0.625
Placebo | 20 (80.0%) | 0 | 3 (12.0%) | 2 (8.0%) | 25 (100%) | 0.250
SNP | 18 (85.7%) | 1 (4.8%) | 0 | 2 (9.5%) | 21 (100%) | 1.000
AST (SGOT) (U/L)
All subjects | 29 (59.2%) | 5 (10.2%) | 4 (8.2%) | 11 (22.4%) | 49 (100%) | 1.000
Placebo | 14 (58.3%) | 1 (4.2%) | 2 (8.3%) | 7 (29.2%) | 24 (100%) | 1.000
SNP | 14 (66.7%) | 2 (9.5%) | 2 (9.5%) | 3 (14.3%) | 21 (100%) | 1.000

Note:

1 McNemar’s test is used to test whether the proportion of subjects with abnormal measurement at pre-dose is the same as the proportion at post-baseline.

2 Abnormal is defined with abnormally and clinically significant and abnormally but not clinically significant combined.

Table 14.3.3.3.4 Summary of Categorical Clinical Laboratory Evaluations by Time (Baseline and Post-Baseline) Safety Population Lactate

Laboratory Test | Pre-Dose; Normal | | Pre-Dose; Abnormal | | Total; N (%) | P Value^1^
Laboratory Test | Post-Baseline; Normal; N (%) | Post-Baseline; Abnormal^2^; N (%) | Post-Baseline; Normal; N (%) | Post-Baseline; Abnormal^2^; N (%) | Total; N (%) | P Value^1^
Lactate (mmol/L)
All subjects | 29 (59.2%) | 9 (18.4%) | 4 (8.2%) | 7 (14.3%) | 49 (100%) | 0.267
Placebo | 14 (56.0%) | 5 (20.0%) | 3 (12.0%) | 3 (12.0%) | 25 (100%) | 0.727
SNP | 13 (65.0%) | 3 (15.0%) | 1 (5.0%) | 3 (15.0%) | 20 (100%) | 0.625

Note:

1 McNemar’s test is used to test whether the proportion of subjects with abnormal measurement at pre-dose is the same as the proportion at post-baseline.

2 Abnormal is defined with abnormally and clinically significant and abnormally but not clinically significant combined.

Table 14.3.3.3.5 Summary of Categorical Clinical Laboratory Evaluations by Time (Baseline and Post-Baseline) Safety Population ABG (Blood Gases)

Laboratory Test | Pre-Dose; Normal | | Pre-Dose; Abnormal | | Total; N (%) | P Value^1^
Laboratory Test | Post-Baseline; Normal; N (%) | Post-Baseline; Abnormal^2^; N (%) | Post-Baseline; Normal; N (%) | Post-Baseline; Abnormal^2^; N (%) | Total; N (%) | P Value^1^
pH
All subjects | 24 (48.0%) | 8 (16.0%) | 11 (22.0%) | 7 (14.0%) | 50 (100%) | 0.648
Placebo | 10 (40.0%) | 6 (24.0%) | 6 (24.0%) | 3 (12.0%) | 25 (100%) | 1.000
SNP | 12 (57.1%) | 1 (4.8%) | 4 (19.0%) | 4 (19.0%) | 21 (100%) | 0.375
PCO_2_ (mmHg)
All subjects | 9 (18.0%) | 12 (24.0%) | 4 (8.0%) | 25 (50.0%) | 50 (100%) | 0.077
Placebo | 4 (16.0%) | 5 (20.0%) | 1 (4.0%) | 15 (60.0%) | 25 (100%) | 0.219
SNP | 4 (19.0%) | 6 (28.6%) | 3 (14.3%) | 8 (38.1%) | 21 (100%) | 0.508
PO_2_ (mmHg)
All subjects | 3 (6.0%) | 6 (12.0%) | 6 (12.0%) | 35 (70.0%) | 50 (100%) | 1.000
Placebo | 2 (8.0%) | 5 (20.0%) | 2 (8.0%) | 16 (64.0%) | 25 (100%) | 0.453
SNP | 1 (4.8%) | 1 (4.8%) | 4 (19.0%) | 15 (71.4%) | 21 (100%) | 0.375
SO_2_ (%)
All subjects | 26 (52.0%) | 12 (24.0%) | 5 (10.0%) | 7 (14.0%) | 50 (100%) | 0.143
Placebo | 11 (44.0%) | 9 (36.0%) | 1 (4.0%) | 4 (16.0%) | 25 (100%) | 0.021
SNP | 12 (57.1%) | 2 (9.5%) | 4 (19.0%) | 3 (14.3%) | 21 (100%) | 0.688
HCO_3_ (mEq/L)
All subjects | 23 (46.0%) | 11 (22.0%) | 3 (6.0%) | 13 (26.0%) | 50 (100%) | 0.057
Placebo | 10 (40.0%) | 5 (20.0%) | 2 (8.0%) | 8 (32.0%) | 25 (100%) | 0.453
SNP | 11 (52.4%) | 4 (19.0%) | 1 (4.8%) | 5 (23.8%) | 21 (100%) | 0.375
Methemoglobin (%)
All subjects | 42 (89.4%) | 3 (6.4%) | 0 | 2 (4.3%) | 47 (100%) | 0.250
Placebo | 21 (91.3%) | 2 (8.7%) | 0 | 0 | 23 (100%) | 0.453
SNP | 18 (90.0%) | 0 | 0 | 2 (10.0%) | 20 (100%) | ·

Note:

1 McNemar’s test is used to test whether the proportion of subjects with abnormal measurement at pre-dose is the same as the proportion at post-baseline.

2 Abnormal is defined with abnormally and clinically significant and abnormally but not clinically significant combined.

Table 14.3.3.3.6 Summary of Categorical Clinical Laboratory Evaluations by Time (Baseline and Post-Baseline) Safety Population VBG (Blood Gases)

Laboratory Test | Pre-Dose; Normal | | Pre-Dose; Abnormal | | Total; N (%) | P Value^1^
Laboratory Test | Post-Baseline; Normal; N (%) | Post-Baseline; Abnormal^2^; N (%) | Post-Baseline; Normal; N (%) | Post-Baseline; Abnormal^2^; N (%) | Total; N (%) | P Value^1^
pH
All subjects | 16 (37.2%) | 8 (18.6%) | 10 (23.3%) | 9 (20.9%) | 43 (100%) | 0.815
Placebo | 5 (23.8%) | 4 (19.0%) | 8 (38.1%) | 4 (19.0%) | 21 (100%) | 0.388
SNP | 8 (44.4%) | 3 (16.7%) | 2 (11.1%) | 5 (27.8%) | 18 (100%) | 1.000
PCO_2_ (mmHg)
All subjects | 11 (25.6%) | 5 (11.6%) | 7 (16.3%) | 20 (46.5%) | 43 (100%) | 0.774
Placebo | 2 (9.5%) | 4 (19.0%) | 4 (19.0%) | 11 (52.4%) | 21 (100%) | 1.000
SNP | 7 (38.9%) | 1 (5.6%) | 3 (16.7%) | 7 (38.9%) | 18 (100%) | 0.625
PO_2_ (mmHg)
All subjects | 12 (27.9%) | 8 (18.6%) | 7 (16.3%) | 16 (37.2%) | 43 (100%) | 1.000
Placebo | 6 (28.6%) | 1 (4.8%) | 7 (33.3%) | 7 (33.3%) | 21 (100%) | 0.070
SNP | 5 (27.8%) | 6 (33.3%) | 0 | 7 (38.9%) | 18 (100%) | 0.031
SO_2_ (%)
All subjects | 7 (15.9%) | 3 (6.8%) | 3 (6.8%) | 31 (70.5%) | 44 (100%) | 1.000
Placebo | 2 (9.1%) | 1 (4.5%) | 1 (4.5%) | 18 (81.8%) | 22 (100%) | 1.000
SNP | 4 (21.1%) | 1 (5.3%) | 2 (10.5%) | 12 (63.2%) | 19 (100%) | 1.000
HCO_3_ (mEq/L)
All subjects | 14 (32.6%) | 9 (20.9%) | 4 (9.3%) | 16 (37.2%) | 43 (100%) | 0.267
Placebo | 5 (23.8%) | 6 (28.6%) | 1 (4.8%) | 9 (42.9%) | 21 (100%) | 0.125
SNP | 7 (38.9%) | 3 (16.7%) | 2 (11.1%) | 6 (33.3%) | 18 (100%) | 1.000
Methemoglobin (%)
All subjects | 41 (93.2%) | 0 | 1 (2.3%) | 2 (4.5%) | 44 (100%) | 1.000
Placebo | 22 (95.7%) | 0 | 0 | 1 (4.3%) | 23 (100%) | ·
SNP | 17 (94.4%) | 0 | 0 | 1 (5.6%) | 18 (100%) | ·

Note:

1 McNemar’s test is used to test whether the proportion of subjects with abnormal measurement at pre-dose is the same as the proportion at post-baseline.

2 Abnormal is defined with abnormally and clinically significant and abnormally but not clinically significant combined.

Table 14.3.3.4.1 Summary of Categorical Clinical Laboratory Evaluations by Treatment (Baseline and Post-Baseline) ITT Population Hematology Panel

Laboratory Test | SNP; (N=25) | Placebo; (N=21) | P Value^1^
WBC (10^3^/mm^3^)
Not declined^2^ | 20 (80.0%) | 11 (52.4%) | 0.091
Declined^3^ | 4 (16.0%) | 8 (38.1%)
HGB (g/dL)
Not declined^2^ | 15 (60.0%) | 13 (61.9%) | 0.755
Declined^3^ | 9 (36.0%) | 6 (28.6%)
HCT (%)
Not declined^2^ | 16 (64.0%) | 13 (61.9%) | 1.000
Declined^3^ | 8 (32.0%) | 6 (28.6%)
Platelet Count (10^3^/mm^3^)
Not declined^2^ | 21 (84.0%) | 18 (85.7%) | 0.618
Declined^3^ | 3 (12.0%) | 1 (4.8%)

Note:

1 Fisher’s exact test is used to test the equality of the proportion of subjects with declined measurement between treatment arms

2 A measurement is defined as Not declined if it is abnormal at pre-dose or normal at both pre-dose and post-baseline.

3 A measurement is defined as Declined if it is normal at pre-dose and abnormal at post-baseline.

Table 14.3.3.4.2 Summary of Categorical Clinical Laboratory Evaluations by Treatment (Baseline and Post-Baseline) Chemistry Panel ITT Population

Laboratory Test | SNP; (N=25) | Placebo; (N=21) | P Value^1^
Sodium (mmol/L)
Not declined^2^ | 18 (72.0%) | 16 (76.2%) | 1.000
Declined^3^ | 7 (28.0%) | 5 (23.8%)
Potassium (mmol/L)
Not declined^2^ | 22 (88.0%) | 19 (90.5%) | 1.000
Declined^3^ | 3 (12.0%) | 2 (9.5%)
Chloride (mmol/L)
Not declined^2^ | 22 (88.0%) | 21 (100.0%) | 0.239
Declined^3^ | 3 (12.0%) | 0
Carbon Dioxide (mmol/L)
Not declined^2^ | 23 (92.0%) | 21 (100.0%) | 0.493
Declined^3^ | 2 (8.0%) | 0
BUN (Urea) (mg/dL)
Not declined^2^ | 21 (84.0%) | 20 (95.2%) | 0.611
Declined^3^ | 3 (12.0%) | 1 (4.8%)
Creatinine (mg/dL)
Not declined^2^ | 19 (76.0%) | 20 (95.2%) | 0.193
Declined^3^ | 5 (20.0%) | 1 (4.8%)

Note:

1 Fisher’s exact test is used to test the equality of the proportion of subjects with declined measurement between treatment arms

2 A measurement is defined as Not declined if it is abnormal at pre-dose or normal at both pre-dose and post-baseline.

3 A measurement is defined as Declined if it is normal at pre-dose and abnormal at post-baseline.

Table 14.3.3.4.3 Summary of Categorical Clinical Laboratory Evaluations by Treatment (Baseline and Post-Baseline) Liver Functions Tests Panel ITT Population

Laboratory Test | SNP; (N=25) | Placebo; (N=21) | P Value^1^
ALT (SGPT) (U/L)
Not declined^2^ | 25 (100.0%) | 20 (95.2%) | 0.457
Declined^3^ | 0 | 1 (4.8%)
AST (SGOT) (U/L)
Not declined^2^ | 23 (92.0%) | 19 (90.5%) | 0.592
Declined^3^ | 1 (4.0%) | 2 (9.5%)

Note:

1 Fisher’s exact test is used to test the equality of the proportion of subjects with declined measurement between treatment arms

2 A measurement is defined as Not declined if it is abnormal at pre-dose or normal at both pre-dose and post-baseline.

3 A measurement is defined as Declined if it is normal at pre-dose and abnormal at post-baseline.

Table 14.3.3.4.4 Summary of Categorical Clinical Laboratory Evaluations by Treatment (Baseline and Post-Baseline) Lactate ITT Population

Laboratory Test | SNP; (N=25) | Placebo; (N=21) | P Value^1^
Lactate (mmol/L)
Not declined^2^ | 20 (80.0%) | 17 (81.0%) | 0.716
Declined^3^ | 5 (20.0%) | 3 (14.3%)

Note:

1 Fisher’s exact test is used to test the equality of the proportion of subjects with declined measurement between treatment arms

2 A measurement is defined as Not declined if it is abnormal at pre-dose or normal at both pre-dose and post-baseline.

3 A measurement is defined as Declined if it is normal at pre-dose and abnormal at post-baseline.

Table 14.3.3.4.5 Summary of Categorical Clinical Laboratory Evaluations by Treatment (Baseline and Post-Baseline) ABG (Blood Gases) ITT Population

Laboratory Test | SNP; (N=25) | Placebo; (N=21) | P Value^1^
pH
Not declined^2^ | 19 (76.0%) | 20 (95.2%) | 0.106
Declined^3^ | 6 (24.0%) | 1 (4.8%)
PCO_2_ (mmHg)
Not declined^2^ | 20 (80.0%) | 15 (71.4%) | 0.730
Declined^3^ | 5 (20.0%) | 6 (28.6%)
PO_2_ (mmHg)
Not declined^2^ | 20 (80.0%) | 20 (95.2%) | 0.198
Declined^3^ | 5 (20.0%) | 1 (4.8%)
SO_2_ (%)
Not declined^2^ | 16 (64.0%) | 19 (90.5%) | 0.045
Declined^3^ | 9 (36.0%) | 2 (9.5%)
HCO_3_ (mEq/L)
Not declined^2^ | 20 (80.0%) | 17 (81.0%) | 1.000
Declined^3^ | 5 (20.0%) | 4 (19.0%)
Methemoglobin (%)
Not declined^2^ | 21 (84.0%) | 20 (95.2%) | 0.491
Declined^3^ | 2 (8.0%) | 0

Note:

1 Fisher’s exact test is used to test the equality of the proportion of subjects with declined measurement between treatment arms

2 A measurement is defined as Not declined if it is abnormal at pre-dose or normal at both pre-dose and post-baseline.

3 A measurement is defined as Declined if it is normal at pre-dose and abnormal at post-baseline.

Table 14.3.3.4.6 Summary of Categorical Clinical Laboratory Evaluations by Treatment (Baseline and Post-Baseline) VBG (Blood Gases) ITT Population

Laboratory Test | SNP; (N=25) | Placebo; (N=21) | P Value^1^
pH
Not declined^2^ | 17 (68.0%) | 15 (71.4%) | 1.000
Declined^3^ | 4 (16.0%) | 3 (14.3%)
PCO_2_ (mmHg)
Not declined^2^ | 17 (68.0%) | 17 (81.0%) | 0.349
Declined^3^ | 4 (16.0%) | 1 (4.8%)
PO_2_ (mmHg)
Not declined^2^ | 20 (80.0%) | 12 (57.1%) | 0.035
Declined^3^ | 1 (4.0%) | 6 (28.6%)
SO_2_ (%)
Not declined^2^ | 21 (84.0%) | 18 (85.7%) | 1.000
Declined^3^ | 1 (4.0%) | 1 (4.8%)
HCO_3_ (mEq/L)
Not declined^2^ | 15 (60.0%) | 15 (71.4%) | 0.464
Declined^3^ | 6 (24.0%) | 3 (14.3%)
Methemoglobin (%)
Not declined^2^ | 23 (92.0%) | 18 (85.7%)

Note:

1 Fisher’s exact test is used to test the equality of the proportion of subjects with declined measurement between treatment arms

2 A measurement is defined as Not declined if it is abnormal at pre-dose or normal at both pre-dose and post-baseline.

3 A measurement is defined as Declined if it is normal at pre-dose and abnormal at post-baseline.

Table 14.3.4.1.1 Descriptive Statistics for Pulse (bpm) By Time and Age Group (Open-Label Phase) Safety Population

Assessments/Statistics | Age Strata | | | | | Total; (N=52)
Assessments/Statistics | 0 - < 30 days; (N=3) | 30 days - < 2 yrs; (N=21) | 2 yrs - < 6 yrs; (N=7) | 6 yrs - TS II^1^; (N=12) | TS III - 17 yrs; (N=9) | Total; (N=52)
B1
N | 3 | 21 | 7 | 12 | 9 | 52
Mean (SD) | 125.3 (11.0) | 138.5 (23.8) | 122.7 (31.4) | 103.1 (29.8) | 89.8 (14.9) | 119.0 (30.7)
Median (Min, Max) | 120.0 (118.0, 138.0) | 144.0 (84.0, 178.0) | 128.0 (70.0, 158.0) | 102.0 (52.0, 156.0) | 85.0 (71.0, 114.0) | 119.5 (52.0, 178.0)
0 or 1 min (first record in open-label phase)
N | 3 | 21 | 7 | 12 | 9 | 52
Mean (SD) | 126.3 (14.4) | 140.9 (22.5) | 121.9 (30.5) | 103.9 (31.0) | 94.3 (17.3) | 120.9 (30.5)
Median (Min, Max) | 118.0 (118.0, 143.0) | 140.0 (86.0, 182.0) | 129.0 (68.0, 150.0) | 105.0 (52.0, 162.0) | 104.0 (68.0, 114.0) | 125.0 (52.0, 182.0)
5 mins
N | 3 | 20 | 7 | 12 | 9 | 51
Mean (SD) | 126.0 (14.0) | 143.0 (23.4) | 127.1 (30.0) | 104.0 (28.5) | 94.3 (14.2) | 122.0 (30.5)
Median (Min, Max) | 120.0 (116.0, 142.0) | 143.0 (94.0, 184.0) | 128.0 (82.0, 168.0) | 106.0 (52.0, 144.0) | 96.0 (75.0, 114.0) | 126.0 (52.0, 184.0)
10 mins
N | 3 | 20 | 7 | 12 | 9 | 51
Mean (SD) | 124.7 (15.0) | 140.1 (21.1) | 122.7 (26.8) | 110.3 (24.5) | 96.4 (16.9) | 122.1 (26.9)
Median (Min, Max) | 116.0 (116.0, 142.0) | 141.5 (90.0, 184.0) | 130.0 (76.0, 149.0) | 111.0 (68.0, 159.0) | 94.0 (74.0, 120.0) | 126.0 (68.0, 184.0)
15 ± 2 mins
N | 3 | 20 | 7 | 12 | 9 | 51
Mean (SD) | 124.0 (15.6) | 139.1 (20.6) | 128.1 (19.7) | 112.5 (22.5) | 96.7 (14.6) | 123.0 (25.0)
Median (Min, Max) | 116.0 (114.0, 142.0) | 139.0 (86.0, 182.0) | 128.0 (92.0, 146.0) | 113.0 (76.0, 154.0) | 98.0 (75.0, 118.0) | 128.0 (75.0, 182.0)
30 ± 5 mins
N | 3 | 21 | 7 | 12 | 8 | 51
Mean (SD) | 124.3 (16.4) | 137.6 (20.8) | 123.6 (22.0) | 110.9 (27.8) | 98.6 (14.8) | 122.5 (25.7)
Median (Min, Max) | 118.0 (112.0, 143.0) | 140.0 (90.0, 182.0) | 126.0 (80.0, 147.0) | 112.0 (68.0, 168.0) | 103.0 (79.0, 114.0) | 126.0 (68.0, 182.0)
1 hour ± 20 mins
N | 3 | 20 | 7 | 12 | 8 | 50
Mean (SD) | 132.7 (11.7) | 137.5 (22.1) | 129.3 (17.1) | 110.8 (27.1) | 100.5 (11.6) | 123.7 (25.1)
Median (Min, Max) | 128.0 (124.0, 146.0) | 138.0 (90.0, 184.0) | 130.0 (96.0, 148.0) | 113.0 (62.0, 162.0) | 101.0 (82.0, 114.0) | 124.0 (62.0, 184.0)
2 hours ± 20 mins
N | 3 | 20 | 7 | 12 | 8 | 50
Mean (SD) | 137.0 (17.6) | 137.5 (22.5) | 131.1 (12.1) | 110.2 (25.2) | 103.9 (12.3) | 124.6 (24.4)
Median (Min, Max) | 130.0 (124.0, 157.0) | 134.0 (94.0, 184.0) | 130.0 (116.0, 152.0) | 112.0 (60.0, 144.0) | 102.0 (90.0, 122.0) | 125.0 (60.0, 184.0)
3 hours ± 20 mins
N | 2 | 20 | 7 | 11 | 8 | 48
Mean (SD) | 153.0 (26.9) | 137.9 (21.4) | 126.4 (17.4) | 109.4 (24.9) | 108.6 (8.8) | 125.4 (24.3)
Median (Min, Max) | 153.0 (134.0, 172.0) | 135.0 (106.0, 182.0) | 120.0 (102.0, 158.0) | 114.0 (60.0, 143.0) | 109.0 (96.0, 124.0) | 122.0 (60.0, 182.0)
4 hours ± 20 mins
N | 2 | 20 | 7 | 11 | 8 | 48
Mean (SD) | 158.0 (25.5) | 134.4 (19.2) | 130.0 (18.1) | 108.9 (24.6) | 109.1 (10.4) | 124.7 (23.2)
Median (Min, Max) | 158.0 (140.0, 176.0) | 128.5 (104.0, 182.0) | 132.0 (102.0, 158.0) | 114.0 (68.0, 147.0) | 113.0 (96.0, 124.0) | 123.0 (68.0, 182.0)
5 hours ± 20 mins
N | 2 | 20 | 7 | 10 | 8 | 47
Mean (SD) | 153.0 (21.2) | 136.5 (23.7) | 129.3 (21.5) | 109.1 (28.5) | 108.8 (10.9) | 125.6 (25.9)
Median (Min, Max) | 153.0 (138.0, 168.0) | 128.0 (109.0, 184.0) | 128.0 (100.0, 168.0) | 113.0 (68.0, 161.0) | 112.0 (92.0, 124.0) | 120.0 (68.0, 184.0)
6 hours ± 20 mins
N | 2 | 20 | 7 | 9 | 8 | 46
Mean (SD) | 156.0 (11.3) | 132.8 (26.7) | 126.0 (20.0) | 109.8 (21.8) | 110.5 (13.7) | 124.4 (25.0)
Median (Min, Max) | 156.0 (148.0, 164.0) | 127.5 (78.0, 184.0) | 124.0 (94.0, 156.0) | 108.0 (72.0, 140.0) | 112.0 (90.0, 132.0) | 120.0 (72.0, 184.0)
7 hours ± 20 mins
N | 2 | 20 | 7 | 9 | 7 | 45
Mean (SD) | 152.0 (8.5) | 133.2 (26.7) | 123.3 (23.9) | 111.0 (24.1) | 110.1 (15.3) | 124.4 (25.8)
Median (Min, Max) | 152.0 (146.0, 158.0) | 127.0 (75.0, 182.0) | 126.0 (86.0, 160.0) | 110.0 (72.0, 157.0) | 116.0 (90.0, 132.0) | 122.0 (72.0, 182.0)
8 hours ± 20 mins
N | 2 | 20 | 7 | 9 | 7 | 45
Mean (SD) | 151.0 (4.2) | 130.9 (28.4) | 122.6 (21.4) | 115.3 (19.7) | 114.3 (14.3) | 124.8 (24.4)
Median (Min, Max) | 151.0 (148.0, 154.0) | 124.0 (87.0, 190.0) | 120.0 (96.0, 162.0) | 120.0 (76.0, 144.0) | 110.0 (92.0, 132.0) | 120.0 (76.0, 190.0)
9 hours ± 20 mins
N | 2 | 20 | 7 | 8 | 7 | 44
Mean (SD) | 146.0 (0.0) | 131.9 (25.9) | 126.9 (31.3) | 109.3 (21.1) | 116.0 (14.4) | 125.1 (25.3)
Median (Min, Max) | 146.0 (146.0, 146.0) | 135.0 (81.0, 178.0) | 122.0 (82.0, 172.0) | 117.0 (72.0, 138.0) | 122.0 (92.0, 130.0) | 122.0 (72.0, 178.0)
10 hours ± 20 mins
N | 2 | 20 | 7 | 8 | 7 | 44
Mean (SD) | 149.5 (2.1) | 134.2 (28.0) | 122.7 (24.1) | 111.3 (20.2) | 114.0 (15.7) | 125.7 (25.5)
Median (Min, Max) | 149.5 (148.0, 151.0) | 129.0 (82.0, 184.0) | 122.0 (86.0, 160.0) | 113.0 (82.0, 146.0) | 111.0 (93.0, 134.0) | 121.0 (82.0, 184.0)
11 hours ± 20 mins
N | 2 | 20 | 7 | 8 | 7 | 44
Mean (SD) | 146.0 (11.3) | 132.0 (26.0) | 116.1 (24.1) | 111.1 (18.6) | 115.0 (16.6) | 123.6 (24.2)
Median (Min, Max) | 146.0 (138.0, 154.0) | 125.0 (80.0, 186.0) | 115.0 (78.0, 160.0) | 118.0 (84.0, 132.0) | 114.0 (90.0, 138.0) | 121.5 (78.0, 186.0)
12 hours ± 20 mins
N | 2 | 20 | 7 | 9 | 7 | 45
Mean (SD) | 146.0 (5.7) | 129.6 (25.2) | 113.7 (26.3) | 105.0 (14.4) | 117.3 (15.0) | 121.0 (23.7)
Median (Min, Max) | 146.0 (142.0, 150.0) | 125.0 (74.0, 182.0) | 116.0 (70.0, 160.0) | 102.0 (82.0, 124.0) | 120.0 (97.0, 144.0) | 120.0 (70.0, 182.0)
13 hours ± 20 mins
N | 2 | 14 | 4 | 7 | 5 | 32
Mean (SD) | 136.0 (19.8) | 135.6 (28.4) | 115.0 (37.6) | 107.4 (14.8) | 113.2 (12.5) | 123.4 (26.7)
Median (Min, Max) | 136.0 (122.0, 150.0) | 134.5 (81.0, 190.0) | 116.0 (68.0, 160.0) | 114.0 (86.0, 124.0) | 112.0 (100.0, 126.0) | 120.0 (68.0, 190.0)
14 hours ± 20 mins
N | 2 | 11 | 4 | 6 | 5 | 28
Mean (SD) | 143.0 (4.2) | 138.5 (30.0) | 110.0 (40.6) | 114.5 (11.3) | 112.8 (12.4) | 125.0 (27.4)
Median (Min, Max) | 143.0 (140.0, 146.0) | 142.0 (90.0, 176.0) | 105.0 (66.0, 164.0) | 116.5 (94.0, 126.0) | 108.0 (102.0, 134.0) | 116.5 (66.0, 176.0)
15 hours ± 20 mins
N | 2 | 9 | 3 | 5 | 4 | 23
Mean (SD) | 148.0 (0.0) | 133.1 (28.4) | 118.7 (28.0) | 111.6 (11.7) | 110.0 (11.0) | 123.8 (23.8)
Median (Min, Max) | 148.0 (148.0, 148.0) | 122.0 (85.0, 164.0) | 110.0 (96.0, 150.0) | 116.0 (92.0, 120.0) | 106.0 (102.0, 126.0) | 120.0 (85.0, 164.0)
16 hours ± 20 mins
N | 1 | 7 | 3 | 5 | 3 | 19
Mean (SD) | 136.0 | 119.0 (22.8) | 116.7 (30.6) | 111.6 (9.4) | 106.3 (7.1) | 115.6 (18.7)
Median (Min, Max) | 136.0 | 116.0 (84.0, 160.0) | 110.0 (90.0, 150.0) | 112.0 (96.0, 120.0) | 105.0 (100.0, 114.0) | 113.0 (84.0, 160.0)
17 hours ± 20 mins
N | 1 | 6 | 3 | 5 | 3 | 18
Mean (SD) | 140.0 | 127.7 (25.8) | 119.3 (21.9) | 117.2 (14.3) | 107.7 (5.7) | 120.7 (19.4)
Median (Min, Max) | 140.0 | 119.0 (104.0, 174.0) | 112.0 (102.0, 144.0) | 114.0 (102.0, 140.0) | 106.0 (103.0, 114.0) | 114.0 (102.0, 174.0)
18 hours ± 20 mins
N | 1 | 6 | 3 | 4 | 3 | 17
Mean (SD) | 140.0 | 118.0 (23.6) | 118.7 (26.1) | 113.5 (12.5) | 106.0 (3.5) | 116.2 (18.7)
Median (Min, Max) | 140.0 | 114.5 (87.0, 158.0) | 110.0 (98.0, 148.0) | 111.0 (102.0, 130.0) | 104.0 (104.0, 110.0) | 110.0 (87.0, 158.0)
19 hours ± 20 mins
N | 0 | 6 | 3 | 2 | 3 | 14
Mean (SD) | | 119.2 (22.9) | 126.7 (18.6) | 121.0 (12.7) | 109.0 (6.6) | 118.9 (17.6)
Median (Min, Max) | | 114.5 (92.0, 158.0) | 118.0 (114.0, 148.0) | 121.0 (112.0, 130.0) | 110.0 (102.0, 115.0) | 114.5 (92.0, 158.0)
20 hours ± 20 mins
N | 0 | 6 | 2 | 1 | 3 | 12
Mean (SD) | | 115.2 (31.1) | 129.0 (15.6) | 128.0 | 109.3 (7.2) | 117.1 (22.9)
Median (Min, Max) | | 111.5 (70.0, 164.0) | 129.0 (118.0, 140.0) | 128.0 | 113.0 (101.0, 114.0) | 114.5 (70.0, 164.0)
21 hours ± 20 mins
N | 0 | 3 | 2 | 1 | 3 | 9
Mean (SD) | | 123.3 (30.1) | 131.0 (18.4) | 120.0 | 105.7 (8.0) | 118.8 (19.9)
Median (Min, Max) | | 108.0 (104.0, 158.0) | 131.0 (118.0, 144.0) | 120.0 | 105.0 (98.0, 114.0) | 114.0 (98.0, 158.0)
22 hours ± 20 mins
N | 0 | 2 | 1 | 0 | 3 | 6
Mean (SD) | | 118.5 (10.6) | 142.0 | | 107.7 (7.5) | 117.0 (14.9)
Median (Min, Max) | | 118.5 (111.0, 126.0) | 142.0 | | 112.0 (99.0, 112.0) | 112.0 (99.0, 142.0)
23 hours ± 20 mins
N | 0 | 1 | 1 | 0 | 2 | 4
Mean (SD) | | 110.0 | 138.0 | | 106.0 (2.8) | 115.0 (15.5)
Median (Min, Max) | | 110.0 | 138.0 | | 106.0 (104.0, 108.0) | 109.0 (104.0, 138.0)
24 hours ± 20 mins
N | 0 | 1 | 0 | 0 | 1 | 2
Mean (SD) | | 106.0 | | | 101.0 | 103.5 (3.5)
Median (Min, Max) | | 106.0 | | | 101.0 | 103.5 (101.0, 106.0)
B2
N | 2 | 20 | 7 | 9 | 8 | 46
Mean (SD) | 145.0 (1.4) | 130.1 (23.0) | 114.7 (25.9) | 112.3 (13.8) | 121.4 (10.3) | 123.4 (21.0)
Median (Min, Max) | 145.0 (144.0, 146.0) | 124.0 (96.0, 176.0) | 118.0 (62.0, 140.0) | 115.0 (88.0, 130.0) | 122.0 (110.0, 136.0) | 121.0 (62.0, 176.0)

Note:

1 TS II: Tanner Stage II

Table 14.3.4.1.2 Descriptive Statistics for Blood Pressure (Systolic) (mmHg) By Time and Age Group (Open-Label Phase) Safety Population

Assessments/Statistics | Age Strata | | | | | Total; (N=52)
Assessments/Statistics | 0 - < 30 days; (N=3) | 30 days - < 2 yrs; (N=21) | 2 yrs - < 6 yrs; (N=7) | 6 yrs - TS II^1^; (N=12) | TS III - 17 yrs; (N=9) | Total; (N=52)
B1
N | 3 | 21 | 7 | 12 | 9 | 52
Mean (SD) | 88.0 (6.9) | 116.0 (17.4) | 130.6 (23.3) | 140.3 (15.6) | 147.9 (14.1) | 127.4 (23.0)
Median (Min, Max) | 84.0 (84.0, 96.0) | 113.0 (96.0, 154.0) | 134.0 (98.0, 166.0) | 137.0 (116.0, 178.0) | 152.0 (119.0, 164.0) | 131.0 (84.0, 178.0)
0 or 1 min (first record in open-label phase)
N | 3 | 21 | 7 | 12 | 8 | 51
Mean (SD) | 85.7 (10.6) | 111.3 (21.8) | 124.9 (16.9) | 143.8 (18.2) | 144.1 (20.1) | 124.5 (25.9)
Median (Min, Max) | 84.0 (76.0, 97.0) | 107.0 (66.0, 162.0) | 130.0 (105.0, 152.0) | 139.0 (118.0, 176.0) | 149.0 (110.0, 168.0) | 126.0 (66.0, 176.0)
5 mins
N | 3 | 20 | 7 | 12 | 8 | 50
Mean (SD) | 80.7 (15.3) | 101.6 (22.4) | 120.7 (20.4) | 141.3 (20.5) | 137.4 (17.0) | 118.2 (27.9)
Median (Min, Max) | 84.0 (64.0, 94.0) | 101.0 (38.0, 148.0) | 118.0 (91.0, 144.0) | 134.0 (118.0, 186.0) | 137.0 (113.0, 158.0) | 118.0 (38.0, 186.0)
10 mins
N | 3 | 20 | 7 | 12 | 8 | 50
Mean (SD) | 77.0 (18.5) | 103.4 (18.1) | 118.4 (30.0) | 125.2 (20.0) | 127.1 (22.3) | 112.9 (24.5)
Median (Min, Max) | 84.0 (56.0, 91.0) | 105.0 (60.0, 146.0) | 123.0 (74.0, 152.0) | 126.0 (96.0, 156.0) | 121.0 (101.0, 158.0) | 112.0 (56.0, 158.0)
15 ± 2 mins
N | 3 | 20 | 7 | 12 | 8 | 50
Mean (SD) | 77.7 (12.7) | 101.4 (17.8) | 110.3 (23.3) | 120.0 (17.0) | 120.5 (24.9) | 108.7 (22.0)
Median (Min, Max) | 80.0 (64.0, 89.0) | 103.0 (66.0, 146.0) | 113.0 (82.0, 144.0) | 122.0 (88.0, 148.0) | 115.0 (80.0, 154.0) | 108.0 (64.0, 154.0)
30 ± 5 mins
N | 3 | 21 | 7 | 12 | 7 | 50
Mean (SD) | 71.7 (6.0) | 95.0 (18.3) | 115.6 (17.9) | 116.4 (16.1) | 122.9 (18.9) | 105.5 (22.0)
Median (Min, Max) | 71.0 (66.0, 78.0) | 94.0 (64.0, 132.0) | 107.0 (98.0, 142.0) | 116.0 (82.0, 144.0) | 116.0 (106.0, 162.0) | 107.5 (64.0, 162.0)
1 hour ± 20 mins
N | 3 | 20 | 7 | 12 | 8 | 50
Mean (SD) | 72.0 (8.0) | 91.0 (17.4) | 110.6 (23.9) | 117.8 (17.5) | 125.5 (25.7) | 104.5 (24.8)
Median (Min, Max) | 72.0 (64.0, 80.0) | 92.0 (50.0, 122.0) | 98.0 (80.0, 136.0) | 121.5 (86.0, 136.0) | 117.0 (108.0, 188.0) | 104.5 (50.0, 188.0)
2 hours ± 20 mins
N | 3 | 20 | 7 | 12 | 8 | 50
Mean (SD) | 69.7 (17.0) | 98.1 (18.8) | 112.9 (25.7) | 114.5 (17.6) | 128.6 (20.3) | 107.3 (23.9)
Median (Min, Max) | 79.0 (50.0, 80.0) | 90.0 (68.0, 151.0) | 109.0 (88.0, 158.0) | 116.0 (82.0, 136.0) | 126.0 (102.0, 172.0) | 106.0 (50.0, 172.0)
3 hours ± 20 mins
N | 2 | 20 | 7 | 11 | 8 | 48
Mean (SD) | 78.5 (7.8) | 97.3 (18.8) | 105.4 (23.2) | 113.9 (22.8) | 130.1 (15.1) | 107.0 (23.1)
Median (Min, Max) | 78.5 (73.0, 84.0) | 89.5 (68.0, 128.0) | 106.0 (74.0, 142.0) | 120.0 (78.0, 151.0) | 130.0 (108.0, 153.0) | 106.5 (68.0, 153.0)
4 hours ± 20 mins
N | 2 | 20 | 7 | 11 | 8 | 48
Mean (SD) | 75.5 (6.4) | 93.8 (22.1) | 109.0 (21.1) | 116.5 (14.8) | 123.9 (22.1) | 105.5 (23.6)
Median (Min, Max) | 75.5 (71.0, 80.0) | 87.0 (66.0, 156.0) | 108.0 (80.0, 142.0) | 116.0 (93.0, 138.0) | 124.0 (92.0, 158.0) | 100.0 (66.0, 158.0)
5 hours ± 20 mins
N | 2 | 20 | 7 | 10 | 8 | 47
Mean (SD) | 74.0 (0.0) | 91.0 (15.2) | 110.7 (27.5) | 114.9 (14.2) | 131.5 (21.9) | 105.2 (24.1)
Median (Min, Max) | 74.0 (74.0, 74.0) | 90.0 (68.0, 125.0) | 100.0 (86.0, 160.0) | 114.0 (96.0, 140.0) | 123.0 (104.0, 164.0) | 101.0 (68.0, 164.0)
6 hours ± 20 mins
N | 2 | 20 | 7 | 9 | 8 | 46
Mean (SD) | 80.0 (0.0) | 96.8 (19.8) | 108.4 (21.3) | 112.4 (22.8) | 122.9 (20.9) | 105.4 (22.6)
Median (Min, Max) | 80.0 (80.0, 80.0) | 97.0 (66.0, 160.0) | 96.0 (86.0, 140.0) | 122.0 (80.0, 140.0) | 122.0 (100.0, 163.0) | 99.5 (66.0, 163.0)
7 hours ± 20 mins
N | 2 | 20 | 7 | 9 | 7 | 45
Mean (SD) | 71.0 (7.1) | 88.0 (19.4) | 109.0 (23.3) | 121.2 (24.1) | 127.4 (24.5) | 103.3 (27.3)
Median (Min, Max) | 71.0 (66.0, 76.0) | 88.0 (52.0, 148.0) | 99.0 (80.0, 140.0) | 130.0 (86.0, 152.0) | 118.0 (106.0, 171.0) | 94.0 (52.0, 171.0)
8 hours ± 20 mins
N | 2 | 20 | 7 | 9 | 7 | 45
Mean (SD) | 77.0 (7.1) | 91.0 (13.6) | 110.0 (20.3) | 114.6 (21.1) | 129.6 (29.1) | 104.0 (24.0)
Median (Min, Max) | 77.0 (72.0, 82.0) | 89.5 (66.0, 126.0) | 100.0 (88.0, 142.0) | 114.0 (90.0, 156.0) | 132.0 (100.0, 168.0) | 100.0 (66.0, 168.0)
9 hours ± 20 mins
N | 2 | 20 | 7 | 8 | 7 | 44
Mean (SD) | 72.0 (11.3) | 90.5 (19.7) | 107.4 (21.0) | 117.5 (18.4) | 125.4 (29.2) | 102.8 (25.5)
Median (Min, Max) | 72.0 (64.0, 80.0) | 88.0 (64.0, 152.0) | 98.0 (80.0, 142.0) | 119.0 (90.0, 148.0) | 108.0 (100.0, 170.0) | 98.0 (64.0, 170.0)
10 hours ± 20 mins
N | 2 | 20 | 7 | 8 | 7 | 44
Mean (SD) | 69.0 (9.9) | 89.8 (19.5) | 108.0 (19.0) | 122.4 (16.9) | 124.1 (23.5) | 103.1 (25.0)
Median (Min, Max) | 69.0 (62.0, 76.0) | 84.5 (64.0, 142.0) | 98.0 (90.0, 136.0) | 129.5 (92.0, 138.0) | 112.0 (100.0, 165.0) | 96.5 (62.0, 165.0)
11 hours ± 20 mins
N | 2 | 20 | 7 | 8 | 7 | 44
Mean (SD) | 77.0 (15.6) | 84.4 (12.6) | 109.7 (24.8) | 120.1 (24.2) | 135.6 (27.8) | 102.7 (28.1)
Median (Min, Max) | 77.0 (66.0, 88.0) | 83.0 (58.0, 110.0) | 112.0 (80.0, 152.0) | 116.0 (88.0, 162.0) | 130.0 (94.0, 173.0) | 96.0 (58.0, 173.0)
12 hours ± 20 mins
N | 2 | 20 | 7 | 9 | 7 | 45
Mean (SD) | 74.0 (11.3) | 86.7 (15.0) | 107.1 (22.2) | 114.0 (28.4) | 134.3 (21.4) | 102.2 (26.8)
Median (Min, Max) | 74.0 (66.0, 82.0) | 82.0 (64.0, 122.0) | 102.0 (80.0, 138.0) | 122.0 (65.0, 146.0) | 122.0 (115.0, 169.0) | 98.0 (64.0, 169.0)
13 hours ± 20 mins
N | 2 | 14 | 4 | 7 | 5 | 32
Mean (SD) | 75.0 (7.1) | 81.4 (11.9) | 105.5 (24.6) | 122.7 (19.1) | 125.6 (26.8) | 99.9 (26.6)
Median (Min, Max) | 75.0 (70.0, 80.0) | 81.5 (60.0, 100.0) | 106.0 (76.0, 134.0) | 116.0 (104.0, 144.0) | 124.0 (98.0, 167.0) | 97.5 (60.0, 167.0)
14 hours ± 20 mins
N | 2 | 11 | 4 | 6 | 5 | 28
Mean (SD) | 74.0 (0.0) | 83.3 (14.5) | 98.5 (21.6) | 121.8 (22.6) | 127.2 (27.5) | 100.9 (27.3)
Median (Min, Max) | 74.0 (74.0, 74.0) | 82.0 (64.0, 106.0) | 100.0 (76.0, 118.0) | 114.5 (96.0, 156.0) | 120.0 (94.0, 169.0) | 97.0 (64.0, 169.0)
15 hours ± 20 mins
N | 2 | 9 | 3 | 5 | 4 | 23
Mean (SD) | 77.0 (1.4) | 94.3 (20.9) | 107.3 (13.6) | 112.0 (18.6) | 146.0 (19.0) | 107.3 (26.8)
Median (Min, Max) | 77.0 (76.0, 78.0) | 90.0 (68.0, 141.0) | 112.0 (92.0, 118.0) | 112.0 (84.0, 134.0) | 141.0 (130.0, 172.0) | 108.0 (68.0, 172.0)
16 hours ± 20 mins
N | 1 | 7 | 3 | 5 | 3 | 19
Mean (SD) | 74.0 | 89.9 (14.7) | 110.7 (14.0) | 112.6 (19.2) | 135.3 (29.2) | 105.5 (24.2)
Median (Min, Max) | 74.0 | 88.0 (70.0, 118.0) | 112.0 (96.0, 124.0) | 108.0 (88.0, 134.0) | 120.0 (117.0, 169.0) | 103.0 (70.0, 169.0)
17 hours ± 20 mins
N | 1 | 6 | 3 | 5 | 3 | 18
Mean (SD) | 68.0 | 96.8 (11.6) | 108.7 (17.0) | 116.2 (22.5) | 139.0 (31.1) | 109.6 (25.1)
Median (Min, Max) | 68.0 | 97.5 (78.0, 114.0) | 108.0 (92.0, 126.0) | 118.0 (82.0, 138.0) | 132.0 (112.0, 173.0) | 108.5 (68.0, 173.0)
18 hours ± 20 mins
N | 1 | 6 | 3 | 4 | 3 | 17
Mean (SD) | 82.0 | 97.8 (13.4) | 108.7 (13.6) | 115.0 (34.8) | 144.3 (11.9) | 111.1 (25.6)
Median (Min, Max) | 82.0 | 100.0 (74.0, 113.0) | 104.0 (98.0, 124.0) | 113.0 (80.0, 154.0) | 139.0 (136.0, 158.0) | 104.0 (74.0, 158.0)
19 hours ± 20 mins
N | 0 | 6 | 3 | 2 | 3 | 14
Mean (SD) | | 95.2 (13.0) | 122.7 (22.3) | 126.0 (53.7) | 126.3 (11.6) | 112.1 (24.9)
Median (Min, Max) | | 99.0 (74.0, 108.0) | 114.0 (106.0, 148.0) | 126.0 (88.0, 164.0) | 132.0 (113.0, 134.0) | 107.0 (74.0, 164.0)
20 hours ± 20 mins
N | 0 | 6 | 2 | 1 | 3 | 12
Mean (SD) | | 100.8 (19.8) | 111.0 (24.0) | 132.0 | 139.3 (21.9) | 114.8 (24.9)
Median (Min, Max) | | 98.5 (80.0, 130.0) | 111.0 (94.0, 128.0) | 132.0 | 132.0 (122.0, 164.0) | 117.0 (80.0, 164.0)
21 hours ± 20 mins
N | 0 | 3 | 2 | 1 | 3 | 9
Mean (SD) | | 84.7 (14.2) | 107.0 (24.0) | 132.0 | 140.3 (12.7) | 113.4 (28.2)
Median (Min, Max) | | 82.0 (72.0, 100.0) | 107.0 (90.0, 124.0) | 132.0 | 138.0 (129.0, 154.0) | 124.0 (72.0, 154.0)
22 hours ± 20 mins
N | 0 | 2 | 1 | 0 | 3 | 6
Mean (SD) | | 101.5 (2.1) | 140.0 | | 125.0 (16.5) | 119.7 (18.5)
Median (Min, Max) | | 101.5 (100.0, 103.0) | 140.0 | | 126.0 (108.0, 141.0) | 117.0 (100.0, 141.0)
23 hours ± 20 mins
N | 0 | 1 | 1 | 0 | 2 | 4
Mean (SD) | | 90.0 | 134.0 | | 173.0 (26.9) | 142.5 (42.5)
Median (Min, Max) | | 90.0 | 134.0 | | 173.0 (154.0, 192.0) | 144.0 (90.0, 192.0)
24 hours ± 20 mins
N | 0 | 1 | 0 | 0 | 1 | 2
Mean (SD) | | 82.0 | | | 152.0 | 117.0 (49.5)
Median (Min, Max) | | 82.0 | | | 152.0 | 117.0 (82.0, 152.0)
B2
N | 2 | 20 | 7 | 9 | 8 | 46
Mean (SD) | 80.0 (8.5) | 86.5 (11.2) | 104.3 (16.9) | 119.3 (22.3) | 126.8 (18.2) | 102.3 (23.0)
Median (Min, Max) | 80.0 (74.0, 86.0) | 89.5 (68.0, 112.0) | 106.0 (86.0, 130.0) | 114.0 (90.0, 156.0) | 126.0 (100.0, 156.0) | 96.0 (68.0, 156.0)

Note:

1 TS II: Tanner Stage II

Table 14.3.4.1.3 Descriptive Statistics for Blood Pressure (Diastolic) (mmHg) By Time and Age Group (Open-Label Phase) Safety Population

Assessments/Statistics | Age Strata | | | | | Total; (N=52)
Assessments/Statistics | 0 - < 30 days; (N=3) | 30 days - < 2 yrs; (N=21) | 2 yrs - < 6 yrs; (N=7) | 6 yrs - TS II^1^; (N=12) | TS III - 17 yrs; (N=9) | Total; (N=52)
B1
N | 3 | 21 | 7 | 12 | 9 | 52
Mean (SD) | 57.3 (5.0) | 65.3 (14.1) | 80.4 (15.6) | 83.1 (11.2) | 76.9 (9.3) | 73.0 (14.9)
Median (Min, Max) | 58.0 (52.0, 62.0) | 64.0 (40.0, 90.0) | 78.0 (63.0, 110.0) | 84.5 (68.0, 108.0) | 76.0 (62.0, 90.0) | 72.0 (40.0, 110.0)
0 or 1 min (first record in open-label phase)
N | 3 | 21 | 7 | 12 | 8 | 51
Mean (SD) | 56.0 (5.3) | 62.5 (14.7) | 75.7 (12.6) | 85.3 (15.9) | 71.0 (11.5) | 70.6 (16.6)
Median (Min, Max) | 54.0 (52.0, 62.0) | 60.0 (40.0, 90.0) | 70.0 (64.0, 100.0) | 86.5 (66.0, 120.0) | 71.0 (52.0, 90.0) | 70.0 (40.0, 120.0)
5 mins
N | 3 | 20 | 7 | 12 | 8 | 50
Mean (SD) | 53.0 (8.9) | 55.8 (14.7) | 69.7 (18.9) | 81.1 (16.7) | 65.4 (9.1) | 65.2 (17.8)
Median (Min, Max) | 50.0 (46.0, 63.0) | 57.0 (26.0, 88.0) | 74.0 (48.0, 92.0) | 75.0 (60.0, 122.0) | 62.5 (52.0, 78.0) | 64.0 (26.0, 122.0)
10 mins
N | 3 | 20 | 7 | 12 | 8 | 50
Mean (SD) | 50.0 (10.0) | 56.1 (12.5) | 65.0 (24.0) | 69.3 (14.0) | 60.6 (9.2) | 60.9 (15.1)
Median (Min, Max) | 50.0 (40.0, 60.0) | 55.0 (36.0, 88.0) | 52.0 (36.0, 92.0) | 72.0 (48.0, 89.0) | 57.5 (52.0, 82.0) | 57.5 (36.0, 92.0)
15 ± 2 mins
N | 3 | 20 | 7 | 12 | 8 | 50
Mean (SD) | 50.0 (6.9) | 55.4 (12.0) | 58.9 (16.5) | 66.6 (11.2) | 57.8 (10.6) | 58.6 (12.6)
Median (Min, Max) | 46.0 (46.0, 58.0) | 55.5 (36.0, 88.0) | 60.0 (42.0, 92.0) | 68.0 (44.0, 84.0) | 57.0 (48.0, 82.0) | 58.0 (36.0, 92.0)
30 ± 5 mins
N | 3 | 21 | 7 | 12 | 7 | 50
Mean (SD) | 46.0 (2.0) | 51.7 (10.7) | 62.1 (13.1) | 63.8 (10.3) | 56.6 (4.0) | 56.4 (11.3)
Median (Min, Max) | 46.0 (44.0, 48.0) | 52.0 (32.0, 72.0) | 58.0 (49.0, 90.0) | 64.0 (46.0, 78.0) | 54.0 (54.0, 64.0) | 54.0 (32.0, 90.0)
1 hour ± 20 mins
N | 3 | 20 | 7 | 12 | 8 | 50
Mean (SD) | 47.0 (7.5) | 48.4 (9.8) | 59.7 (17.2) | 64.0 (12.8) | 57.1 (8.2) | 55.0 (13.0)
Median (Min, Max) | 46.0 (40.0, 55.0) | 48.0 (34.0, 72.0) | 58.0 (36.0, 86.0) | 66.0 (46.0, 84.0) | 56.0 (46.0, 75.0) | 54.0 (34.0, 86.0)
2 hours ± 20 mins
N | 3 | 20 | 7 | 12 | 8 | 50
Mean (SD) | 44.7 (8.1) | 51.8 (13.6) | 59.0 (17.6) | 62.0 (11.4) | 57.1 (6.4) | 55.7 (13.1)
Median (Min, Max) | 46.0 (36.0, 52.0) | 50.0 (34.0, 95.0) | 52.0 (44.0, 96.0) | 59.0 (44.0, 82.0) | 57.0 (50.0, 66.0) | 54.0 (34.0, 96.0)
3 hours ± 20 mins
N | 2 | 20 | 7 | 11 | 8 | 48
Mean (SD) | 50.0 (0.0) | 51.3 (12.2) | 54.1 (13.2) | 62.7 (14.5) | 55.1 (7.5) | 54.9 (12.5)
Median (Min, Max) | 50.0 (50.0, 50.0) | 50.5 (34.0, 78.0) | 52.0 (41.0, 80.0) | 58.0 (44.0, 96.0) | 55.0 (43.0, 64.0) | 52.0 (34.0, 96.0)
4 hours ± 20 mins
N | 2 | 20 | 7 | 11 | 8 | 48
Mean (SD) | 48.5 (0.7) | 49.2 (14.2) | 62.0 (18.4) | 62.5 (9.5) | 54.5 (8.4) | 55.0 (13.8)
Median (Min, Max) | 48.5 (48.0, 49.0) | 46.0 (34.0, 94.0) | 56.0 (46.0, 102.0) | 61.0 (54.0, 87.0) | 52.0 (44.0, 66.0) | 53.0 (34.0, 102.0)
5 hours ± 20 mins
N | 2 | 20 | 7 | 10 | 8 | 47
Mean (SD) | 48.0 (2.8) | 48.3 (9.8) | 58.3 (19.5) | 62.3 (7.0) | 56.0 (7.9) | 54.1 (11.9)
Median (Min, Max) | 48.0 (46.0, 50.0) | 48.5 (30.0, 72.0) | 56.0 (40.0, 100.0) | 63.5 (52.0, 76.0) | 54.5 (48.0, 66.0) | 50.0 (30.0, 100.0)
6 hours ± 20 mins
N | 2 | 20 | 7 | 9 | 8 | 46
Mean (SD) | 51.0 (4.2) | 52.1 (14.3) | 57.6 (14.1) | 59.7 (11.6) | 52.3 (4.7) | 54.4 (12.3)
Median (Min, Max) | 51.0 (48.0, 54.0) | 50.0 (32.0, 99.0) | 56.0 (41.0, 86.0) | 56.0 (48.0, 82.0) | 50.0 (46.0, 60.0) | 54.0 (32.0, 99.0)
7 hours ± 20 mins
N | 2 | 20 | 7 | 9 | 7 | 45
Mean (SD) | 44.5 (2.1) | 48.0 (11.0) | 56.3 (10.7) | 64.7 (16.5) | 56.1 (4.7) | 53.7 (12.9)
Median (Min, Max) | 44.5 (43.0, 46.0) | 47.0 (34.0, 85.0) | 56.0 (44.0, 76.0) | 56.0 (48.0, 90.0) | 58.0 (50.0, 62.0) | 52.0 (34.0, 90.0)
8 hours ± 20 mins
N | 2 | 20 | 7 | 9 | 7 | 45
Mean (SD) | 49.0 (1.4) | 49.3 (10.2) | 59.9 (12.4) | 60.1 (10.1) | 58.6 (8.8) | 54.5 (11.1)
Median (Min, Max) | 49.0 (48.0, 50.0) | 48.0 (32.0, 76.0) | 58.0 (47.0, 86.0) | 62.0 (46.0, 75.0) | 59.0 (48.0, 72.0) | 54.0 (32.0, 86.0)
9 hours ± 20 mins
N | 2 | 20 | 7 | 8 | 7 | 44
Mean (SD) | 44.0 (2.8) | 48.7 (13.5) | 59.1 (13.9) | 62.1 (14.7) | 58.4 (11.0) | 54.1 (14.1)
Median (Min, Max) | 44.0 (42.0, 46.0) | 46.0 (34.0, 92.0) | 54.0 (46.0, 82.0) | 56.0 (48.0, 92.0) | 54.0 (48.0, 76.0) | 52.0 (34.0, 92.0)
10 hours ± 20 mins
N | 2 | 20 | 7 | 8 | 7 | 44
Mean (SD) | 43.0 (1.4) | 49.5 (13.2) | 58.7 (10.2) | 61.5 (10.0) | 52.3 (4.4) | 53.3 (11.8)
Median (Min, Max) | 43.0 (42.0, 44.0) | 48.0 (34.0, 90.0) | 56.0 (45.0, 78.0) | 61.0 (52.0, 82.0) | 52.0 (46.0, 60.0) | 52.0 (34.0, 90.0)
11 hours ± 20 mins
N | 2 | 20 | 7 | 8 | 7 | 44
Mean (SD) | 51.0 (7.1) | 45.5 (9.4) | 55.9 (11.7) | 61.9 (10.7) | 57.4 (7.4) | 52.3 (11.5)
Median (Min, Max) | 51.0 (46.0, 56.0) | 45.5 (28.0, 64.0) | 54.0 (43.0, 80.0) | 59.5 (48.0, 82.0) | 58.0 (46.0, 68.0) | 52.0 (28.0, 82.0)
12 hours ± 20 mins
N | 2 | 20 | 7 | 9 | 7 | 45
Mean (SD) | 45.0 (4.2) | 47.7 (11.1) | 54.7 (11.7) | 56.3 (14.5) | 56.7 (5.3) | 51.8 (11.6)
Median (Min, Max) | 45.0 (42.0, 48.0) | 47.0 (32.0, 77.0) | 54.0 (44.0, 78.0) | 56.0 (34.0, 82.0) | 58.0 (50.0, 66.0) | 50.0 (32.0, 82.0)
13 hours ± 20 mins
N | 2 | 14 | 4 | 7 | 5 | 32
Mean (SD) | 45.0 (1.4) | 45.6 (7.6) | 58.5 (17.5) | 63.1 (8.9) | 51.8 (5.9) | 52.0 (11.3)
Median (Min, Max) | 45.0 (44.0, 46.0) | 47.0 (32.0, 55.0) | 56.0 (40.0, 82.0) | 58.0 (56.0, 78.0) | 49.0 (46.0, 60.0) | 50.5 (32.0, 82.0)
14 hours ± 20 mins
N | 2 | 11 | 4 | 6 | 5 | 28
Mean (SD) | 44.0 (2.8) | 46.2 (10.9) | 55.5 (13.2) | 60.3 (6.3) | 53.8 (8.7) | 51.8 (10.9)
Median (Min, Max) | 44.0 (42.0, 46.0) | 48.0 (26.0, 67.0) | 56.0 (40.0, 70.0) | 62.0 (52.0, 68.0) | 49.0 (46.0, 66.0) | 51.0 (26.0, 70.0)
15 hours ± 20 mins
N | 2 | 9 | 3 | 5 | 4 | 23
Mean (SD) | 47.0 (4.2) | 52.4 (18.3) | 60.0 (7.2) | 58.4 (9.1) | 56.8 (7.3) | 55.0 (12.8)
Median (Min, Max) | 47.0 (44.0, 50.0) | 55.0 (30.0, 91.0) | 58.0 (54.0, 68.0) | 60.0 (48.0, 68.0) | 56.5 (50.0, 64.0) | 55.0 (30.0, 91.0)
16 hours ± 20 mins
N | 1 | 7 | 3 | 5 | 3 | 19
Mean (SD) | 50.0 | 48.0 (12.1) | 63.3 (4.6) | 62.2 (15.2) | 54.3 (3.8) | 55.3 (12.3)
Median (Min, Max) | 50.0 | 46.0 (36.0, 73.0) | 66.0 (58.0, 66.0) | 55.0 (52.0, 88.0) | 56.0 (50.0, 57.0) | 52.0 (36.0, 88.0)
17 hours ± 20 mins
N | 1 | 6 | 3 | 5 | 3 | 18
Mean (SD) | 46.0 | 53.7 (8.0) | 59.3 (6.4) | 60.0 (8.6) | 56.3 (5.5) | 56.4 (7.7)
Median (Min, Max) | 46.0 | 54.0 (40.0, 64.0) | 62.0 (52.0, 64.0) | 64.0 (48.0, 68.0) | 56.0 (51.0, 62.0) | 56.0 (40.0, 68.0)
18 hours ± 20 mins
N | 1 | 6 | 3 | 4 | 3 | 17
Mean (SD) | 56.0 | 53.5 (11.5) | 62.0 (8.0) | 53.3 (7.4) | 61.3 (12.0) | 56.5 (9.7)
Median (Min, Max) | 56.0 | 54.0 (38.0, 70.0) | 62.0 (54.0, 70.0) | 53.5 (44.0, 62.0) | 62.0 (49.0, 73.0) | 56.0 (38.0, 73.0)
19 hours ± 20 mins
N | 0 | 6 | 3 | 2 | 3 | 14
Mean (SD) | | 52.7 (8.4) | 72.7 (7.0) | 54.0 (8.5) | 53.0 (7.5) | 57.2 (10.9)
Median (Min, Max) | | 53.5 (38.0, 64.0) | 72.0 (66.0, 80.0) | 54.0 (48.0, 60.0) | 54.0 (45.0, 60.0) | 54.5 (38.0, 80.0)
20 hours ± 20 mins
N | 0 | 6 | 2 | 1 | 3 | 12
Mean (SD) | | 55.3 (15.5) | 57.0 (1.4) | 54.0 | 56.3 (6.5) | 55.8 (10.8)
Median (Min, Max) | | 53.0 (42.0, 85.0) | 57.0 (56.0, 58.0) | 54.0 | 56.0 (50.0, 63.0) | 54.5 (42.0, 85.0)
21 hours ± 20 mins
N | 0 | 3 | 2 | 1 | 3 | 9
Mean (SD) | | 48.0 (11.1) | 59.0 (9.9) | 48.0 | 58.7 (8.4) | 54.0 (9.7)
Median (Min, Max) | | 50.0 (36.0, 58.0) | 59.0 (52.0, 66.0) | 48.0 | 63.0 (49.0, 64.0) | 52.0 (36.0, 66.0)
22 hours ± 20 mins
N | 0 | 2 | 1 | 0 | 3 | 6
Mean (SD) | | 63.0 (1.4) | 80.0 | | 49.3 (10.3) | 59.0 (13.9)
Median (Min, Max) | | 63.0 (62.0, 64.0) | 80.0 | | 52.0 (38.0, 58.0) | 60.0 (38.0, 80.0)
23 hours ± 20 mins
N | 0 | 1 | 1 | 0 | 2 | 4
Mean (SD) | | 54.0 | 86.0 | | 81.0 (8.5) | 75.5 (15.3)
Median (Min, Max) | | 54.0 | 86.0 | | 81.0 (75.0, 87.0) | 80.5 (54.0, 87.0)
24 hours ± 20 mins
N | 0 | 1 | 0 | 0 | 1 | 2
Mean (SD) | | 50.0 | | | 57.0 | 53.5 (4.9)
Median (Min, Max) | | 50.0 | | | 57.0 | 53.5 (50.0, 57.0)
B2
N | 2 | 20 | 7 | 9 | 8 | 46
Mean (SD) | 51.0 (1.4) | 46.1 (7.4) | 55.9 (12.7) | 59.8 (6.1) | 54.4 (6.5) | 51.9 (9.4)
Median (Min, Max) | 51.0 (50.0, 52.0) | 45.5 (34.0, 62.0) | 54.0 (44.0, 82.0) | 60.0 (51.0, 68.0) | 53.5 (46.0, 62.0) | 52.0 (34.0, 82.0)

Note:

1 TS II: Tanner Stage II

Table 14.3.4.2.1 Descriptive Statistics for Pulse (bpm) By Time and Treatment (Blinded Phase) ITT Population

Assessments/Statistics | Treatment | | Total; (N=46)
Assessments/Statistics | SNP; (N=25) | Placebo; (N=21) | Total; (N=46)
B2
N | 25 | 21 | 46
Mean (SD) | 124.0 (21.9) | 122.7 (20.4) | 123.4 (21.0)
Median (Min, Max) | 122.0 (62.0, 166.0) | 118.0 (88.0, 176.0) | 121.0 (62.0, 176.0)
1 min
N | 25 | 19 | 44
Mean (SD) | 123.4 (22.3) | 121.7 (20.6) | 122.7 (21.4)
Median (Min, Max) | 118.0 (64.0, 166.0) | 118.0 (87.0, 176.0) | 118.0 (64.0, 176.0)
2 mins
N | 25 | 19 | 44
Mean (SD) | 120.3 (21.9) | 120.9 (20.8) | 120.5 (21.2)
Median (Min, Max) | 116.0 (60.0, 160.0) | 118.0 (88.0, 174.0) | 117.0 (60.0, 174.0)
3 mins
N | 25 | 19 | 44
Mean (SD) | 119.8 (22.3) | 119.0 (23.0) | 119.4 (22.3)
Median (Min, Max) | 114.0 (58.0, 160.0) | 120.0 (80.0, 174.0) | 116.0 (58.0, 174.0)
4 mins
N | 25 | 19 | 44
Mean (SD) | 119.0 (21.5) | 117.5 (22.9) | 118.3 (21.9)
Median (Min, Max) | 114.0 (60.0, 160.0) | 120.0 (80.0, 174.0) | 116.0 (60.0, 174.0)
5 mins
N | 25 | 18 | 43
Mean (SD) | 118.6 (21.2) | 116.9 (22.7) | 117.9 (21.6)
Median (Min, Max) | 120.0 (56.0, 162.0) | 116.0 (86.0, 172.0) | 118.0 (56.0, 172.0)
6 mins
N | 25 | 17 | 42
Mean (SD) | 118.6 (21.0) | 116.8 (24.0) | 117.9 (22.0)
Median (Min, Max) | 118.0 (54.0, 158.0) | 116.0 (86.0, 172.0) | 117.5 (54.0, 172.0)
7 mins
N | 25 | 17 | 42
Mean (SD) | 119.4 (21.1) | 114.5 (25.7) | 117.4 (22.9)
Median (Min, Max) | 120.0 (52.0, 158.0) | 118.0 (72.0, 170.0) | 118.0 (52.0, 170.0)
8 mins
N | 25 | 15 | 40
Mean (SD) | 120.5 (22.2) | 114.8 (25.8) | 118.4 (23.4)
Median (Min, Max) | 120.0 (52.0, 162.0) | 114.0 (80.0, 172.0) | 117.5 (52.0, 172.0)
9 mins
N | 24 | 15 | 39
Mean (SD) | 120.6 (23.3) | 113.7 (26.1) | 117.9 (24.3)
Median (Min, Max) | 121.0 (52.0, 162.0) | 113.0 (76.0, 172.0) | 118.0 (52.0, 172.0)
10 mins
N | 23 | 14 | 37
Mean (SD) | 123.2 (18.2) | 112.0 (28.0) | 119.0 (22.7)
Median (Min, Max) | 118.0 (98.0, 156.0) | 111.0 (74.0, 172.0) | 117.0 (74.0, 172.0)
11 mins
N | 23 | 12 | 35
Mean (SD) | 123.0 (18.4) | 117.1 (25.4) | 121.0 (20.9)
Median (Min, Max) | 120.0 (99.0, 158.0) | 111.0 (76.0, 170.0) | 120.0 (76.0, 170.0)
12 mins
N | 23 | 11 | 34
Mean (SD) | 123.3 (19.7) | 120.2 (23.6) | 122.3 (20.7)
Median (Min, Max) | 120.0 (97.0, 166.0) | 114.0 (94.0, 172.0) | 118.0 (94.0, 172.0)
13 mins
N | 23 | 10 | 33
Mean (SD) | 123.5 (18.6) | 119.6 (25.0) | 122.3 (20.4)
Median (Min, Max) | 122.0 (94.0, 166.0) | 110.5 (94.0, 172.0) | 118.0 (94.0, 172.0)
14 mins
N | 22 | 9 | 31
Mean (SD) | 123.7 (18.8) | 118.4 (25.1) | 122.2 (20.5)
Median (Min, Max) | 121.0 (95.0, 166.0) | 109.0 (94.0, 166.0) | 118.0 (94.0, 166.0)
15 mins
N | 21 | 9 | 30
Mean (SD) | 124.1 (18.0) | 119.0 (26.9) | 122.6 (20.7)
Median (Min, Max) | 122.0 (96.0, 162.0) | 111.0 (92.0, 172.0) | 118.5 (92.0, 172.0)
16 mins
N | 21 | 9 | 30
Mean (SD) | 123.7 (18.4) | 119.2 (26.1) | 122.3 (20.6)
Median (Min, Max) | 120.0 (96.0, 156.0) | 110.0 (92.0, 170.0) | 117.5 (92.0, 170.0)
17 mins
N | 21 | 9 | 30
Mean (SD) | 123.6 (18.8) | 124.4 (26.9) | 123.8 (21.0)
Median (Min, Max) | 120.0 (96.0, 160.0) | 114.0 (90.0, 172.0) | 117.5 (90.0, 172.0)
18 mins
N | 21 | 8 | 29
Mean (SD) | 124.3 (19.3) | 121.1 (29.6) | 123.4 (22.0)
Median (Min, Max) | 118.0 (100.0, 164.0) | 112.5 (90.0, 176.0) | 118.0 (90.0, 176.0)
19 mins
N | 21 | 8 | 29
Mean (SD) | 124.2 (19.5) | 120.8 (28.4) | 123.3 (21.8)
Median (Min, Max) | 119.0 (99.0, 164.0) | 110.0 (90.0, 172.0) | 116.0 (90.0, 172.0)
20 mins
N | 21 | 8 | 29
Mean (SD) | 123.9 (19.2) | 120.3 (27.9) | 122.9 (21.4)
Median (Min, Max) | 119.0 (98.0, 162.0) | 109.5 (90.0, 170.0) | 116.0 (90.0, 170.0)
21 mins
N | 21 | 8 | 29
Mean (SD) | 122.9 (19.1) | 120.1 (28.4) | 122.1 (21.6)
Median (Min, Max) | 118.0 (97.0, 160.0) | 109.5 (92.0, 172.0) | 114.0 (92.0, 172.0)
22 mins
N | 21 | 8 | 29
Mean (SD) | 122.7 (18.7) | 119.9 (29.3) | 121.9 (21.6)
Median (Min, Max) | 118.0 (99.0, 162.0) | 109.0 (90.0, 172.0) | 117.0 (90.0, 172.0)
23 mins
N | 20 | 8 | 28
Mean (SD) | 124.4 (17.5) | 120.4 (28.9) | 123.2 (20.9)
Median (Min, Max) | 120.0 (98.0, 162.0) | 109.5 (90.0, 172.0) | 116.0 (90.0, 172.0)
24 mins
N | 21 | 8 | 29
Mean (SD) | 124.2 (18.2) | 120.3 (29.0) | 123.1 (21.2)
Median (Min, Max) | 120.0 (98.0, 164.0) | 110.0 (90.0, 172.0) | 116.0 (90.0, 172.0)
25 mins
N | 21 | 8 | 29
Mean (SD) | 124.0 (18.7) | 120.1 (29.1) | 122.9 (21.5)
Median (Min, Max) | 118.0 (98.0, 164.0) | 109.0 (90.0, 172.0) | 116.0 (90.0, 172.0)
26 mins
N | 21 | 8 | 29
Mean (SD) | 124.0 (19.0) | 120.8 (28.9) | 123.1 (21.7)
Median (Min, Max) | 118.0 (99.0, 164.0) | 111.5 (90.0, 172.0) | 118.0 (90.0, 172.0)
27 mins
N | 21 | 7 | 28
Mean (SD) | 124.7 (19.4) | 121.1 (30.8) | 123.8 (22.2)
Median (Min, Max) | 118.0 (98.0, 164.0) | 111.0 (90.0, 170.0) | 118.0 (90.0, 170.0)
28 mins
N | 21 | 7 | 28
Mean (SD) | 125.4 (21.0) | 121.1 (30.6) | 124.4 (23.2)
Median (Min, Max) | 120.0 (98.0, 170.0) | 109.0 (90.0, 168.0) | 118.5 (90.0, 170.0)
29 mins
N | 21 | 8 | 29
Mean (SD) | 125.5 (20.8) | 121.8 (28.2) | 124.5 (22.6)
Median (Min, Max) | 120.0 (98.0, 168.0) | 111.0 (90.0, 168.0) | 120.0 (90.0, 168.0)
30 mins
N | 21 | 8 | 29
Mean (SD) | 124.1 (20.4) | 122.0 (28.1) | 123.5 (22.3)
Median (Min, Max) | 120.0 (96.0, 164.0) | 112.5 (90.0, 168.0) | 118.0 (90.0, 168.0)

Table 14.3.4.2.2 Descriptive Statistics for Blood Pressure (Systolic) (mmHg) By Time and Treatment (Blinded Phase) ITT Population

Assessments/Statistics | Treatment | | Total; (N=46)
Assessments/Statistics | SNP; (N=25) | Placebo; (N=21) | Total; (N=46)
B2
N | 25 | 21 | 46
Mean (SD) | 104.4 (27.3) | 100.0 (17.0) | 102.3 (23.0)
Median (Min, Max) | 98.0 (70.0, 156.0) | 90.0 (68.0, 134.0) | 96.0 (68.0, 156.0)
1 min
N | 25 | 19 | 44
Mean (SD) | 103.0 (29.4) | 102.3 (19.7) | 102.7 (25.4)
Median (Min, Max) | 102.0 (46.0, 160.0) | 100.0 (70.0, 138.0) | 102.0 (46.0, 160.0)
2 mins
N | 25 | 19 | 44
Mean (SD) | 107.3 (33.7) | 104.7 (21.5) | 106.2 (28.8)
Median (Min, Max) | 104.0 (47.0, 176.0) | 102.0 (68.0, 154.0) | 103.0 (47.0, 176.0)
3 mins
N | 25 | 19 | 44
Mean (SD) | 110.1 (34.8) | 108.6 (23.4) | 109.5 (30.1)
Median (Min, Max) | 102.0 (66.0, 174.0) | 104.0 (68.0, 160.0) | 103.0 (66.0, 174.0)
4 mins
N | 25 | 19 | 44
Mean (SD) | 112.6 (33.8) | 110.8 (24.6) | 111.8 (29.8)
Median (Min, Max) | 104.0 (68.0, 180.0) | 110.0 (68.0, 168.0) | 107.0 (68.0, 180.0)
5 mins
N | 25 | 18 | 43
Mean (SD) | 112.1 (32.4) | 111.6 (23.7) | 111.9 (28.8)
Median (Min, Max) | 102.0 (70.0, 184.0) | 109.0 (70.0, 174.0) | 108.0 (70.0, 184.0)
6 mins
N | 25 | 17 | 42
Mean (SD) | 109.6 (30.5) | 109.5 (19.0) | 109.5 (26.2)
Median (Min, Max) | 102.0 (70.0, 185.0) | 110.0 (72.0, 140.0) | 106.0 (70.0, 185.0)
7 mins
N | 25 | 17 | 42
Mean (SD) | 108.1 (29.8) | 110.6 (19.5) | 109.1 (25.9)
Median (Min, Max) | 104.0 (72.0, 180.0) | 108.0 (68.0, 142.0) | 107.0 (68.0, 180.0)
8 mins
N | 25 | 15 | 40
Mean (SD) | 108.0 (28.3) | 113.1 (19.8) | 109.9 (25.3)
Median (Min, Max) | 102.0 (70.0, 170.0) | 113.0 (70.0, 142.0) | 106.0 (70.0, 170.0)
9 mins
N | 24 | 15 | 39
Mean (SD) | 108.4 (29.2) | 114.9 (21.2) | 110.9 (26.3)
Median (Min, Max) | 101.0 (68.0, 172.0) | 115.0 (70.0, 149.0) | 114.0 (68.0, 172.0)
10 mins
N | 23 | 14 | 37
Mean (SD) | 109.3 (30.2) | 112.8 (21.4) | 110.6 (26.9)
Median (Min, Max) | 102.0 (68.0, 166.0) | 115.0 (70.0, 155.0) | 112.0 (68.0, 166.0)
11 mins
N | 23 | 12 | 35
Mean (SD) | 110.9 (30.7) | 109.3 (18.5) | 110.3 (26.9)
Median (Min, Max) | 102.0 (70.0, 170.0) | 115.0 (70.0, 140.0) | 106.0 (70.0, 170.0)
12 mins
N | 23 | 11 | 34
Mean (SD) | 110.3 (31.2) | 109.5 (18.2) | 110.0 (27.4)
Median (Min, Max) | 102.0 (70.0, 176.0) | 114.0 (70.0, 134.0) | 105.5 (70.0, 176.0)
13 mins
N | 23 | 10 | 33
Mean (SD) | 110.6 (30.5) | 108.6 (17.4) | 110.0 (27.0)
Median (Min, Max) | 104.0 (70.0, 170.0) | 110.0 (72.0, 128.0) | 108.0 (70.0, 170.0)
14 mins
N | 22 | 9 | 31
Mean (SD) | 108.8 (29.6) | 108.8 (17.4) | 108.8 (26.4)
Median (Min, Max) | 102.5 (66.0, 168.0) | 114.0 (72.0, 126.0) | 108.0 (66.0, 168.0)
15 mins
N | 21 | 9 | 30
Mean (SD) | 105.7 (27.5) | 108.0 (19.0) | 106.4 (25.0)
Median (Min, Max) | 104.0 (64.0, 162.0) | 116.0 (70.0, 130.0) | 106.0 (64.0, 162.0)
16 mins
N | 21 | 9 | 30
Mean (SD) | 106.7 (28.5) | 105.4 (18.8) | 106.3 (25.7)
Median (Min, Max) | 103.0 (60.0, 162.0) | 112.0 (72.0, 130.0) | 105.5 (60.0, 162.0)
17 mins
N | 21 | 9 | 30
Mean (SD) | 104.3 (28.0) | 103.7 (21.3) | 104.1 (25.8)
Median (Min, Max) | 100.0 (60.0, 160.0) | 112.0 (72.0, 134.0) | 102.5 (60.0, 160.0)
18 mins
N | 21 | 8 | 29
Mean (SD) | 103.9 (28.0) | 105.8 (19.9) | 104.4 (25.7)
Median (Min, Max) | 106.0 (60.0, 154.0) | 110.5 (72.0, 130.0) | 106.0 (60.0, 154.0)
19 mins
N | 21 | 8 | 29
Mean (SD) | 105.5 (29.1) | 106.8 (19.4) | 105.9 (26.4)
Median (Min, Max) | 110.0 (58.0, 158.0) | 114.0 (74.0, 130.0) | 112.0 (58.0, 158.0)
20 mins
N | 21 | 8 | 29
Mean (SD) | 106.5 (29.3) | 106.5 (19.9) | 106.5 (26.7)
Median (Min, Max) | 108.0 (60.0, 158.0) | 111.0 (74.0, 134.0) | 108.0 (60.0, 158.0)
21 mins
N | 21 | 8 | 29
Mean (SD) | 107.5 (29.6) | 106.0 (19.4) | 107.1 (26.9)
Median (Min, Max) | 110.0 (66.0, 161.0) | 111.5 (72.0, 128.0) | 110.0 (66.0, 161.0)
22 mins
N | 21 | 8 | 29
Mean (SD) | 106.6 (28.6) | 105.9 (20.3) | 106.4 (26.2)
Median (Min, Max) | 107.0 (70.0, 162.0) | 109.5 (72.0, 134.0) | 107.0 (70.0, 162.0)
23 mins
N | 20 | 8 | 28
Mean (SD) | 106.3 (27.6) | 106.1 (19.7) | 106.3 (25.2)
Median (Min, Max) | 106.5 (70.0, 158.0) | 110.5 (72.0, 132.0) | 107.0 (70.0, 158.0)
24 mins
N | 21 | 8 | 29
Mean (SD) | 104.7 (26.8) | 107.6 (20.4) | 105.5 (24.8)
Median (Min, Max) | 103.0 (70.0, 156.0) | 110.5 (74.0, 134.0) | 103.0 (70.0, 156.0)
25 mins
N | 21 | 8 | 29
Mean (SD) | 104.2 (27.0) | 107.5 (19.5) | 105.1 (24.9)
Median (Min, Max) | 104.0 (68.0, 158.0) | 112.0 (74.0, 130.0) | 106.0 (68.0, 158.0)
26 mins
N | 21 | 8 | 29
Mean (SD) | 103.2 (27.0) | 106.3 (20.3) | 104.0 (25.0)
Median (Min, Max) | 102.0 (66.0, 154.0) | 109.5 (74.0, 130.0) | 102.0 (66.0, 154.0)
27 mins
N | 21 | 7 | 28
Mean (SD) | 105.0 (28.5) | 106.1 (20.5) | 105.3 (26.3)
Median (Min, Max) | 102.0 (64.0, 156.0) | 114.0 (72.0, 132.0) | 105.0 (64.0, 156.0)
28 mins
N | 21 | 7 | 28
Mean (SD) | 106.8 (28.5) | 108.7 (21.6) | 107.3 (26.6)
Median (Min, Max) | 102.0 (70.0, 170.0) | 115.0 (74.0, 132.0) | 105.0 (70.0, 170.0)
29 mins
N | 21 | 8 | 29
Mean (SD) | 105.7 (30.6) | 108.6 (18.7) | 106.5 (27.5)
Median (Min, Max) | 96.0 (70.0, 162.0) | 109.0 (76.0, 132.0) | 104.0 (70.0, 162.0)
30 mins
N | 21 | 8 | 29
Mean (SD) | 105.7 (28.2) | 108.5 (19.1) | 106.5 (25.7)
Median (Min, Max) | 98.0 (72.0, 160.0) | 109.5 (76.0, 134.0) | 102.0 (72.0, 160.0)

Table 14.3.4.2.3 Descriptive Statistics for Blood Pressure (Diastolic) (mmHg) By Time and Age Group (Blinded Phase) ITT Population

Assessments/Statistics | Treatment | | Total; (N=46)
Assessments/Statistics | SNP; (N=25) | Placebo; (N=21) | Total; (N=46)
B2
N | 25 | 21 | 46
Mean (SD) | 51.3 (10.1) | 52.6 (8.8) | 51.9 (9.4)
Median (Min, Max) | 51.0 (34.0, 82.0) | 55.0 (38.0, 68.0) | 52.0 (34.0, 82.0)
1 min
N | 25 | 19 | 44
Mean (SD) | 50.6 (12.3) | 54.7 (11.1) | 52.4 (11.8)
Median (Min, Max) | 50.0 (22.0, 84.0) | 53.0 (37.0, 76.0) | 52.0 (22.0, 84.0)
2 mins
N | 25 | 19 | 44
Mean (SD) | 52.8 (14.6) | 55.9 (11.5) | 54.1 (13.3)
Median (Min, Max) | 52.0 (25.0, 100.0) | 55.0 (38.0, 79.0) | 54.0 (25.0, 100.0)
3 mins
N | 25 | 19 | 44
Mean (SD) | 54.4 (15.1) | 58.8 (16.0) | 56.3 (15.5)
Median (Min, Max) | 54.0 (32.0, 100.0) | 57.0 (36.0, 100.0) | 54.0 (32.0, 100.0)
4 mins
N | 25 | 19 | 44
Mean (SD) | 55.8 (14.8) | 61.2 (16.2) | 58.2 (15.5)
Median (Min, Max) | 56.0 (34.0, 98.0) | 58.0 (36.0, 98.0) | 56.5 (34.0, 98.0)
5 mins
N | 25 | 18 | 43
Mean (SD) | 55.8 (14.4) | 60.9 (14.1) | 58.0 (14.4)
Median (Min, Max) | 54.0 (36.0, 94.0) | 58.0 (38.0, 86.0) | 56.0 (36.0, 94.0)
6 mins
N | 25 | 17 | 42
Mean (SD) | 54.0 (14.0) | 60.2 (13.5) | 56.5 (14.0)
Median (Min, Max) | 50.0 (34.0, 92.0) | 56.0 (38.0, 86.0) | 52.5 (34.0, 92.0)
7 mins
N | 25 | 17 | 42
Mean (SD) | 53.2 (12.4) | 61.1 (12.8) | 56.4 (13.0)
Median (Min, Max) | 52.0 (34.0, 84.0) | 60.0 (36.0, 84.0) | 54.0 (34.0, 84.0)
8 mins
N | 25 | 15 | 40
Mean (SD) | 53.4 (13.1) | 61.3 (13.9) | 56.4 (13.8)
Median (Min, Max) | 52.0 (38.0, 92.0) | 56.0 (36.0, 86.0) | 54.0 (36.0, 92.0)
9 mins
N | 24 | 15 | 39
Mean (SD) | 53.2 (13.2) | 62.2 (14.6) | 56.7 (14.3)
Median (Min, Max) | 50.0 (38.0, 94.0) | 60.0 (36.0, 92.0) | 54.0 (36.0, 94.0)
10 mins
N | 23 | 14 | 37
Mean (SD) | 53.3 (12.8) | 61.9 (15.1) | 56.6 (14.1)
Median (Min, Max) | 52.0 (36.0, 86.0) | 59.0 (36.0, 93.0) | 54.0 (36.0, 93.0)
11 mins
N | 23 | 12 | 35
Mean (SD) | 53.9 (13.1) | 58.5 (12.8) | 55.5 (13.0)
Median (Min, Max) | 52.0 (36.0, 90.0) | 58.5 (36.0, 84.0) | 54.0 (36.0, 90.0)
12 mins
N | 23 | 11 | 34
Mean (SD) | 53.6 (11.7) | 59.6 (12.7) | 55.6 (12.2)
Median (Min, Max) | 52.0 (40.0, 84.0) | 58.0 (38.0, 84.0) | 53.5 (38.0, 84.0)
13 mins
N | 23 | 10 | 33
Mean (SD) | 53.6 (12.1) | 58.2 (11.4) | 55.0 (11.9)
Median (Min, Max) | 50.0 (36.0, 82.0) | 58.0 (38.0, 83.0) | 53.0 (36.0, 83.0)
14 mins
N | 22 | 9 | 31
Mean (SD) | 53.3 (12.1) | 58.7 (11.2) | 54.9 (11.9)
Median (Min, Max) | 51.0 (34.0, 80.0) | 58.0 (40.0, 80.0) | 52.0 (34.0, 80.0)
15 mins
N | 21 | 9 | 30
Mean (SD) | 51.9 (11.1) | 57.6 (11.0) | 53.6 (11.2)
Median (Min, Max) | 48.0 (32.0, 84.0) | 57.0 (38.0, 79.0) | 54.0 (32.0, 84.0)
16 mins
N | 21 | 9 | 30
Mean (SD) | 51.7 (12.6) | 56.6 (12.3) | 53.2 (12.5)
Median (Min, Max) | 50.0 (30.0, 90.0) | 58.0 (38.0, 79.0) | 52.0 (30.0, 90.0)
17 mins
N | 21 | 9 | 30
Mean (SD) | 51.0 (12.0) | 56.1 (14.1) | 52.5 (12.6)
Median (Min, Max) | 50.0 (32.0, 84.0) | 57.0 (36.0, 78.0) | 51.0 (32.0, 84.0)
18 mins
N | 21 | 8 | 29
Mean (SD) | 50.7 (12.7) | 57.6 (13.1) | 52.6 (13.0)
Median (Min, Max) | 48.0 (28.0, 84.0) | 61.0 (38.0, 79.0) | 50.0 (28.0, 84.0)
19 mins
N | 21 | 8 | 29
Mean (SD) | 51.7 (13.1) | 58.5 (12.9) | 53.6 (13.2)
Median (Min, Max) | 52.0 (26.0, 82.0) | 60.5 (38.0, 79.0) | 52.0 (26.0, 82.0)
20 mins
N | 21 | 8 | 29
Mean (SD) | 52.5 (14.8) | 58.0 (12.5) | 54.0 (14.2)
Median (Min, Max) | 48.0 (28.0, 88.0) | 60.0 (38.0, 78.0) | 52.0 (28.0, 88.0)
21 mins
N | 21 | 8 | 29
Mean (SD) | 52.7 (14.1) | 58.4 (13.3) | 54.3 (13.9)
Median (Min, Max) | 48.0 (32.0, 86.0) | 61.0 (38.0, 78.0) | 52.0 (32.0, 86.0)
22 mins
N | 21 | 8 | 29
Mean (SD) | 52.1 (12.6) | 57.8 (13.2) | 53.7 (12.8)
Median (Min, Max) | 50.0 (34.0, 88.0) | 59.5 (36.0, 79.0) | 52.0 (34.0, 88.0)
23 mins
N | 20 | 8 | 28
Mean (SD) | 50.2 (12.3) | 57.9 (13.0) | 52.4 (12.7)
Median (Min, Max) | 48.0 (34.0, 88.0) | 60.5 (36.0, 78.0) | 48.5 (34.0, 88.0)
24 mins
N | 21 | 8 | 29
Mean (SD) | 50.2 (12.8) | 58.9 (13.2) | 52.6 (13.2)
Median (Min, Max) | 46.0 (34.0, 90.0) | 61.5 (38.0, 81.0) | 47.0 (34.0, 90.0)
25 mins
N | 21 | 8 | 29
Mean (SD) | 49.8 (11.7) | 58.8 (13.4) | 52.3 (12.7)
Median (Min, Max) | 46.0 (34.0, 86.0) | 60.5 (38.0, 80.0) | 48.0 (34.0, 86.0)
26 mins
N | 21 | 8 | 29
Mean (SD) | 49.7 (11.5) | 57.9 (13.1) | 51.9 (12.3)
Median (Min, Max) | 48.0 (34.0, 86.0) | 60.5 (38.0, 80.0) | 48.0 (34.0, 86.0)
27 mins
N | 21 | 7 | 28
Mean (SD) | 51.2 (13.7) | 58.0 (12.4) | 52.9 (13.5)
Median (Min, Max) | 48.0 (34.0, 94.0) | 58.0 (38.0, 78.0) | 51.0 (34.0, 94.0)
28 mins
N | 21 | 7 | 28
Mean (SD) | 52.5 (13.6) | 59.3 (12.7) | 54.2 (13.5)
Median (Min, Max) | 50.0 (36.0, 90.0) | 62.0 (38.0, 77.0) | 51.5 (36.0, 90.0)
29 mins
N | 21 | 8 | 29
Mean (SD) | 51.4 (13.5) | 59.3 (11.1) | 53.6 (13.1)
Median (Min, Max) | 48.0 (34.0, 88.0) | 61.0 (40.0, 75.0) | 52.0 (34.0, 88.0)
30 mins
N | 21 | 8 | 29
Mean (SD) | 51.4 (12.9) | 58.5 (10.9) | 53.4 (12.6)
Median (Min, Max) | 48.0 (36.0, 86.0) | 59.0 (40.0, 76.0) | 52.0 (36.0, 86.0)

Table 14.3.4.3.1 Descriptive Statistics for Pulse (bpm) By Time and Treatment (Follow-Up Phase) Safety Population

Assessments/Statistics | Non-ITT Population; (N=6) | Treatment | | Total; (N=52)
Assessments/Statistics | Non-ITT Population; (N=6) | SNP; (N=25) | Placebo; (N=21) | Total; (N=52)
Study Drug D/C
N | 4 | 24 | 21 | 49
Mean (SD) | 107.5 (28.1) | 121.9 (22.7) | 118.3 (20.9) | 119.2 (22.2)
Median (Min, Max) | 107.0 (80.0, 136.0) | 119.5 (60.0, 171.0) | 113.0 (84.0, 168.0) | 118.0 (60.0, 171.0)
8 Hours Post Blinded Study Drug
N | 4 | 24 | 21 | 49
Mean (SD) | 127.8 (31.1) | 121.8 (25.1) | 118.4 (27.3) | 120.9 (26.0)
Median (Min, Max) | 136.0 (85.0, 154.0) | 118.0 (84.0, 180.0) | 118.0 (69.0, 177.0) | 118.0 (69.0, 180.0)
24 Hours Post Blinded Study Drug
N | 4 | 24 | 21 | 49
Mean (SD) | 122.3 (28.3) | 114.4 (26.9) | 117.0 (25.5) | 116.1 (25.9)
Median (Min, Max) | 130.5 (82.0, 146.0) | 114.5 (60.0, 172.0) | 115.0 (60.0, 165.0) | 115.0 (60.0, 172.0)

Table 14.3.4.3.2 Descriptive Statistics for Blood Pressure (Systolic) (mmHg) By Time and Treatment (Follow-Up Phase) Safety Population

Assessments/Statistics | Non-ITT Population; (N=6) | Treatment | | Total; (N=52)
Assessments/Statistics | Non-ITT Population; (N=6) | SNP; (N=25) | Placebo; (N=21) | Total; (N=52)
Study Drug D/C
N | 4 | 24 | 21 | 49
Mean (SD) | 89.8 (19.4) | 107.8 (24.3) | 103.0 (17.6) | 104.2 (21.4)
Median (Min, Max) | 92.0 (64.0, 111.0) | 110.0 (68.0, 162.0) | 100.0 (76.0, 134.0) | 102.0 (64.0, 162.0)
8 Hours Post Blinded Study Drug
N | 4 | 24 | 21 | 49
Mean (SD) | 92.8 (18.2) | 109.8 (21.5) | 105.1 (17.0) | 106.4 (19.6)
Median (Min, Max) | 95.5 (69.0, 111.0) | 108.0 (86.0, 159.0) | 105.0 (75.0, 138.0) | 105.0 (69.0, 159.0)
24 Hours Post Blinded Study Drug
N | 4 | 24 | 21 | 49
Mean (SD) | 94.5 (10.7) | 103.8 (25.0) | 109.4 (19.6) | 105.4 (22.0)
Median (Min, Max) | 92.5 (85.0, 108.0) | 95.5 (73.0, 158.0) | 108.0 (72.0, 151.0) | 100.0 (72.0, 158.0)

Table 14.3.4.3.3 Descriptive Statistics for Blood Pressure (Diastolic) (mmHg) By Time and Treatment (Follow-Up Phase) Safety Population

Assessments/Statistics | Non-ITT Population; (N=6) | Treatment | | Total; (N=52)
Assessments/Statistics | Non-ITT Population; (N=6) | SNP; (N=25) | Placebo; (N=21) | Total; (N=52)
Study Drug D/C
N | 4 | 24 | 21 | 49
Mean (SD) | 50.3 (16.6) | 55.0 (13.7) | 54.1 (9.3) | 54.2 (12.0)
Median (Min, Max) | 48.5 (32.0, 72.0) | 53.0 (34.0, 94.0) | 54.0 (40.0, 76.0) | 53.0 (32.0, 94.0)
8 Hours Post Blinded Study Drug
N | 4 | 24 | 21 | 49
Mean (SD) | 53.8 (9.8) | 58.3 (12.1) | 56.8 (12.5) | 57.3 (11.9)
Median (Min, Max) | 56.0 (40.0, 63.0) | 57.0 (32.0, 83.0) | 56.0 (33.0, 80.0) | 56.0 (32.0, 83.0)
24 Hours Post Blinded Study Drug
N | 4 | 24 | 21 | 49
Mean (SD) | 56.3 (9.2) | 59.8 (19.8) | 59.2 (12.8) | 59.2 (16.2)
Median (Min, Max) | 57.5 (46.0, 64.0) | 55.5 (26.0, 118.0) | 56.0 (33.0, 87.0) | 56.0 (26.0, 118.0)

Table 14.3.4.3.4 Descriptive Statistics for MAP Score (mmHg) By Time and Treatment (Follow-Up Phase) Safety Population

Assessments/Statistics | Non-ITT Population; (N=6) | ITT Population; (N=46) | Total; (N=52)
Study Drug D/C
N | 4 | 45 | 49
Mean (SD) | 63.3 (16.5) | 72.8 (12.7) | 72.0 (13.1)
Median (Min, Max) | 62.5 (44.0, 84.0) | 71.0 (46.0, 104.0) | 71.0 (44.0, 104.0)
8 Hours Post Blinded Study Drug
N | 4 | 45 | 49
Mean (SD) | 67.8 (15.4) | 75.3 (12.0) | 74.7 (12.3)
Median (Min, Max) | 72.5 (46.0, 80.0) | 74.0 (51.0, 101.0) | 74.0 (46.0, 101.0)
24 Hours Post Blinded Study Drug
N | 4 | 45 | 49
Mean (SD) | 72.3 (9.0) | 76.7 (16.3) | 76.3 (15.8)
Median (Min, Max) | 69.5 (65.0, 85.0) | 74.0 (48.0, 121.0) | 72.0 (48.0, 121.0)

Figure 14.1.1 Kaplan-Meier Probability of Treatment Failure over Time in Blinded Phase By Treatment Log Rank Test P Value=0.028

Figure 14.1.2 Vital Signs Over Time by Subject (Open-Label and Blinded Phases) Safety Population

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-02 Blinded Treatment: SNP

Vital Signs over Time at Blinded Phase Subject: 12-2-02 Infusion Rate:4.05 (mcg/kg/min) Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-03 Blinded Treatment: SNP

Vital Signs over Time at Blinded Phase Subject: 12-2-03 Infusion Rate:1.5 (mcg/kg/min) Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-04 Blinded Treatment: Placebo

Vital Signs over Time at Blinded Phase Subject: 12-2-04 Infusion Rate:2.52 (mcg/kg/min) Blinded Treatment: Placebo

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-05 Blinded Treatment: Placebo

Vital Signs over Time at Blinded Phase Subject: 12-2-05 Infusion Rate:4.64 (mcg/kg/min) Blinded Treatment: Placebo

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-06 Blinded Treatment: Placebo

Vital Signs over Time at Blinded Phase Subject: 12-2-06 Infusion Rate:3 (mcg/kg/min) Blinded Treatment: Placebo

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-07 Blinded Treatment: SNP

Vital Signs over Time at Blinded Phase Subject: 12-2-07 Infusion Rate:1.31 (mcg/kg/min) Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-08 Blinded Treatment: SNP

Vital Signs over Time at Blinded Phase Subject: 12-2-08 Infusion Rate:7.49 (mcg/kg/min) Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-09 Blinded Treatment: SNP

Vital Signs over Time at Blinded Phase Subject: 12-2-09 Infusion Rate:4.95 (mcg/kg/min) Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-10 Blinded Treatment: SNP

Vital Signs over Time at Blinded Phase Subject: 12-2-10 Infusion Rate:4.58 (mcg/kg/min) Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-11 Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-12 Blinded Treatment: Placebo

Vital Signs over Time at Blinded Phase Subject: 12-2-12 Infusion Rate:7.04 (mcg/kg/min) Blinded Treatment: Placebo

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-13 Blinded Treatment: Placebo

Vital Signs over Time at Blinded Phase Subject: 12-2-13 Infusion Rate:5 (mcg/kg/min) Blinded Treatment: Placebo

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-14 Blinded Treatment: SNP

Vital Signs over Time at Blinded Phase Subject: 12-2-14 Infusion Rate:0.62 (mcg/kg/min) Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-15 Blinded Treatment: Placebo

Vital Signs over Time at Blinded Phase Subject: 12-2-15 Infusion Rate:2.5 (mcg/kg/min) Blinded Treatment: Placebo

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-16 Blinded Treatment: Placebo

Vital Signs over Time at Blinded Phase Subject: 12-2-16 Infusion Rate:1.99 (mcg/kg/min) Blinded Treatment: Placebo

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-17 Blinded Treatment: Placebo

Vital Signs over Time at Blinded Phase Subject: 12-2-17 Infusion Rate:7.02 (mcg/kg/min) Blinded Treatment: Placebo

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-18 Blinded Treatment: Placebo

Vital Signs over Time at Blinded Phase Subject: 12-2-18 Infusion Rate:1 (mcg/kg/min) Blinded Treatment: Placebo

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-19 Blinded Treatment: Placebo

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-21 Blinded Treatment: SNP

Vital Signs over Time at Blinded Phase Subject: 12-2-21 Infusion Rate:0.95 (mcg/kg/min) Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-22 Blinded Treatment: Placebo

Vital Signs over Time at Blinded Phase Subject: 12-2-22 Infusion Rate:2 (mcg/kg/min) Blinded Treatment: Placebo

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-23 Blinded Treatment: SNP

Vital Signs over Time at Blinded Phase Subject: 12-2-23 Infusion Rate:1 (mcg/kg/min) Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-24 Blinded Treatment: SNP

Vital Signs over Time at Blinded Phase Subject: 12-2-24 Infusion Rate:7 (mcg/kg/min) Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-25 Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-26 Blinded Treatment: Placebo

Vital Signs over Time at Blinded Phase Subject: 12-2-26 Infusion Rate:1.51 (mcg/kg/min) Blinded Treatment: Placebo

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-27 Blinded Treatment: Placebo

Vital Signs over Time at Blinded Phase Subject: 12-2-27 Infusion Rate:6.99 (mcg/kg/min) Blinded Treatment: Placebo

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-30 Blinded Treatment: SNP

Vital Signs over Time at Blinded Phase Subject: 12-2-30 Infusion Rate:3.2 (mcg/kg/min) Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-31 Blinded Treatment: SNP

Vital Signs over Time at Blinded Phase Subject: 12-2-31 Infusion Rate:2.5 (mcg/kg/min) Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-32 Blinded Treatment: SNP

Vital Signs over Time at Blinded Phase Subject: 12-2-32 Infusion Rate:0.9 (mcg/kg/min) Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-33 Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-34 Blinded Treatment: SNP

Vital Signs over Time at Blinded Phase Subject: 12-2-34 Infusion Rate:6.01 (mcg/kg/min) Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-38 Blinded Treatment: SNP

Vital Signs over Time at Blinded Phase Subject: 12-2-38 Infusion Rate:3.02 (mcg/kg/min) Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-39 Blinded Treatment: SNP

Vital Signs over Time at Blinded Phase Subject: 12-2-39 Infusion Rate:3.54 (mcg/kg/min) Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-41 Blinded Treatment: Placebo

Vital Signs over Time at Blinded Phase Subject: 12-2-41 Infusion Rate:5.49 (mcg/kg/min) Blinded Treatment: Placebo

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-42 Blinded Treatment: SNP

Vital Signs over Time at Blinded Phase Subject: 12-2-42 Infusion Rate:2.5 (mcg/kg/min) Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-43 Blinded Treatment: Placebo

Vital Signs over Time at Blinded Phase Subject: 12-2-43 Infusion Rate:1.2 (mcg/kg/min) Blinded Treatment: Placebo

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 12-2-44 Blinded Treatment: SNP

Vital Signs over Time at Blinded Phase Subject: 12-2-44 Infusion Rate:1.2 (mcg/kg/min) Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 20-2-02 Blinded Treatment: Placebo

Vital Signs over Time at Blinded Phase Subject: 20-2-02 Infusion Rate:1.9 (mcg/kg/min) Blinded Treatment: Placebo

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 20-2-04 Blinded Treatment: SNP

Vital Signs over Time at Blinded Phase Subject: 20-2-04 Infusion Rate:3.54 (mcg/kg/min) Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 20-2-07 Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 20-2-08 Blinded Treatment: SNP

Vital Signs over Time at Blinded Phase Subject: 20-2-08 Infusion Rate:0.56 (mcg/kg/min) Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 20-2-12 Blinded Treatment: Placebo

Vital Signs over Time at Blinded Phase Subject: 20-2-12 Infusion Rate:3.54 (mcg/kg/min) Blinded Treatment: Placebo

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 21-2-01 Blinded Treatment: Placebo

Vital Signs over Time at Blinded Phase Subject: 21-2-01 Infusion Rate:4.02 (mcg/kg/min) Blinded Treatment: Placebo

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 21-2-02 Blinded Treatment: Placebo

Vital Signs over Time at Blinded Phase Subject: 21-2-02 Infusion Rate:9.9 (mcg/kg/min) Blinded Treatment: Placebo

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 21-2-03 Blinded Treatment: SNP

Vital Signs over Time at Blinded Phase Subject: 21-2-03 Infusion Rate:7.5 (mcg/kg/min) Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 21-2-04 Blinded Treatment: Placebo

Vital Signs over Time at Blinded Phase Subject: 21-2-04 Infusion Rate:0.49 (mcg/kg/min) Blinded Treatment: Placebo

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 28-2-02 Blinded Treatment: SNP

Vital Signs over Time at Blinded Phase Subject: 28-2-02 Infusion Rate:0.4 (mcg/kg/min) Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 28-2-03 Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 28-2-05 Blinded Treatment: SNP

Vital Signs over Time at Blinded Phase Subject: 28-2-05 Infusion Rate:0.4 (mcg/kg/min) Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 29-2-01 Blinded Treatment: Placebo

Vital Signs over Time at Blinded Phase Subject: 29-2-01 Infusion Rate:2 (mcg/kg/min) Blinded Treatment: Placebo

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 29-2-02 Blinded Treatment: SNP

Vital Signs over Time at Blinded Phase Subject: 29-2-02 Infusion Rate:1.6 (mcg/kg/min) Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 29-2-03 Blinded Treatment: SNP

Vital Signs over Time at Blinded Phase Subject: 29-2-03 Infusion Rate:3.55 (mcg/kg/min) Blinded Treatment: SNP

Figure 14.1.2 Vital Signs over Time at Open Label Phase Subject: 29-2-04 Blinded Treatment: Placebo

Vital Signs over Time at Blinded Phase Subject: 29-2-04 Infusion Rate:0.15 (mcg/kg/min) Blinded Treatment: Placebo

Figure 14.1.3 Clinical Outcomes and Adverse Events Over Time by Subject Safety Population

1. T0: Start of Open-label Phase; T1: Blinded Phase.

2. Cyanide toxicity in whole blood >1.5 mcg/mL is defined as ‘severe’.

3. Pre-dose measurements might occur up to 72 hours prior to the open-label phase.

4. * Sample result is none, less than lower limit of quantitation (< LLOQ), test cancelled due to quantity not sufficient (TNP), or no sample.

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-02) Blinded Treatment: SNP

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-03) Blinded Treatment: SNP

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-04) Blinded Treatment: Placebo

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-05) Blinded Treatment: Placebo

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-06) Blinded Treatment: Placebo

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-07) Blinded Treatment: SNP

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-08) Blinded Treatment: SNP

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-09) Blinded Treatment: SNP

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-10) Blinded Treatment: SNP

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-11) Blinded Treatment: SNP

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-12) Blinded Treatment: Placebo

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-13) Blinded Treatment: Placebo

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-14) Blinded Treatment: SNP

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-15) Blinded Treatment: Placebo

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-16) Blinded Treatment: Placebo

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-17) Blinded Treatment: Placebo

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-18) Blinded Treatment: Placebo

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-19) Blinded Treatment

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-21) Blinded Treatment: SNP

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-22) Blinded Treatment: Placebo

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-23) Blinded Treatment: SNP

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-24) Blinded Treatment: SNP

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-25) Blinded Treatment

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-26) Blinded Treatment: Placebo

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-27) Blinded Treatment: Placebo

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-30) Blinded Treatment: SNP

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-31) Blinded Treatment: SNP

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-32) Blinded Treatment: SNP

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-33) Blinded Treatment

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-34) Blinded Treatment: SNP

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-38) Blinded Treatment: SNP

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-39) Blinded Treatment: SNP

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-41) Blinded Treatment: Placebo

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-42) Blinded Treatment: SNP

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-43) Blinded Treatment: Placebo

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-44) Blinded Treatment: SNP

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (12-2-46) Blinded Treatment

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (20-2-02) Blinded Treatment: Placebo

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (20-2-04) Blinded Treatment: SNP

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (20-2-07) Blinded Treatment: SNP

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (20-2-08) Blinded Treatment: SNP

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (20-2-12) Blinded Treatment: Placebo

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (21-2-01) Blinded Treatment: Placebo

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (21-2-02) Blinded Treatment: Placebo

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (21-2-03) Blinded Treatment: SNP

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (21-2-04) Blinded Treatment: Placebo

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (28-2-02) Blinded Treatment: SNP

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (28-2-03) Blinded Treatment

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (28-2-05) Blinded Treatment: SNP

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (29-2-01) Blinded Treatment: Placebo

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (29-2-02) Blinded Treatment: SNP

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (29-2-03) Blinded Treatment: SNP

Figure 14.1.3 Clinical Outcomes and Adverse Events over Time Subject ID (29-2-04) Blinded Treatment: Placebo

Figure 14.1.4.1.1 MAP Over Time Open-Label Phase

Figure 14.1.4.1.2 MAP Over Time by Treatment Blinded Phase

Figure 14.1.4.2.1 Blood Pressure (Systolic) Over Time Open-Label Phase

Figure 14.1.4.2.2 Blood Pressure (Systolic) Over Time by Treatment Blinded Phase

Figure 14.1.4.3.1 Blood Pressure (Diastolic) Over Time Open-Label Phase

Figure 14.1.4.3.2 Blood Pressure (Diastolic) Over Time by Treatment Blinded Phase

Figure 14.1.4.4.1 Pulse Over Time Open-Label Phase

Figure 14.1.4.4.2 Pulse Over Time by Treatment Blinded Phase

Figure 14.1.5 Selected Clinical Laboratory Outcomes over Time

Figure 14.1.6.1 8 Hour Dose Response Model of Lactate and the AUC for Administered SNP Model: Linear Regression on log(Lactate) Adjusted for Baseline Lactate

Parameter | Estimate | Std Error | P-Value | 95% Confidence Interval
Parameter | Estimate | Std Error | P-Value | Lower Bound | Upper Bound
Intercept | −0.0686 | 0.1429 | 0.6312 | −0.3486 | 0.2115
Ave 8 Hr AUC | 0.0949 | 0.0499 | 0.0569 | −0.0028 | 0.1927
Centered Baseline Lactate | 0.3423 | 0.0692 | <.0001 | 0.2067 | 0.4780

Figure 14.1.6.2 8 Hour Dose Response Model of HCO3 and the AUC for Administered SNP Model: Robust Linear Regression Adjusted for Baseline HCO3

Parameter | Estimate | Std Error | P-Value | 95% Confidence Interval
Parameter | Estimate | Std Error | P-Value | Lower Bound | Upper Bound
Intercept | 25.68916 | 0.71472 | <.0001 | 24.24779 | 27.13054
Ave 8 Hr AUC | 0.01904 | 0.24195 | 0.9376 | −0.46890 | 0.50698
Centered Baseline HCO3 | 0.82896 | 0.10073 | <.0001 | 0.62582 | 1.03211

Figure 14.1.6.3 8 Hour Dose Response Model of Cyanide and the AUC for Administered SNP Model for Cyanide=0: Logistic with Probability (1+exp(b0_p+b1_p*DOSE))^−1^ Model when Cyanide>0: Gamma with Mean exp(b0_g+b1_g*DOSE)

Parameter | Estimate | Std Error | P-Value | 95% Confidence Interval
Parameter | Estimate | Std Error | P-Value | Lower Bound | Upper Bound
b0_p | 8.9047 | 2.7971 | 0.0026 | 3.2710 | 14.5384
b1_p | −2.2709 | 0.7246 | 0.0030 | −3.7304 | −0.8115
b0_g | −1.2927 | 1.2736 | 0.3155 | −3.8577 | 1.2724
b1_g | 0.3912 | 0.2775 | 0.1654 | −0.1676 | 0.9501
log_theta | 0.7927 | 0.3984 | 0.0527 | −0.00971 | 1.5952