# 5 ETHICS

## 5.1 Institutional Review Board

Good Clinical Practice (GCP) requires that the clinical protocol, any protocol amendments, the Investigator Brochure (IB), the informed parental consent, assent and all other forms of subject information related to the study (e.g., advertisements used to recruit subjects) and any other necessary documents be reviewed by an Independent Ethics Committee (IEC) or Institutional Review Board (IRB). IEC/IRB approval of the protocol, informed consent form, assent, and subject information and/or advertising as relevant, were obtained prior to the authorization of drug shipment to a study site. Any amendments to the protocol required IEC/IRB approval prior to implementation of any changes made to the study design.

## 5.2 Ethical Conduct of the Study

This study was conducted in accordance with the protocol, GCP, FDA regulations governing clinical study conduct, ethical principles that have their origin in the Declaration of Helsinki, 2008 revision (see Section 16.1.1) and all applicable local regulations. The investigator assured that the study is conducted in accordance with the provisions as stated in the FDA regulations and complies with prevailing local laws and customs. Responsibilities of the Investigator were specified in the protocol (Section 16.1.1).

## 5.3 Patient Information, Consent, and Assent

The principles of informed consent in the current edition of the Declaration of Helsinki were implemented before protocol-specified procedures were carried out. Informed consent was obtained and documented in accordance with U.S. 21 CFR Part 50.25, §§ 116, 117 and 408 of 45 CFR Part 46 and all other applicable regulatory requirements.

Prior to any study procedures being performed, the investigator or his/her designee informed the subject’s legally authorized representative (e.g., parent, guardian) of all aspects pertaining to study participation.

Information was given in both oral and written form whenever possible and deemed appropriate by the IRB. The subject’s legally authorized representative (parent or guardian) was given ample opportunity to inquire about details of the study.

The description of the study procedures is included in the consent form as well as the purpose of the research and procedures, risks and benefits of the research, alternative procedures, confidentiality, legal rights, parental or guardian permission, the contact person and phone number if there were any questions, and the voluntary nature of participation. It was emphasized that participation is voluntary and subjects could withdraw from the study at any time without any effect on standard care. The investigator or his/her designee, and the subject’s legally authorized representative were required to both sign and date the informed consent form, which included all elements of informed consent as described in 21 CFR 50.25. An original signed informed consent form was retained in the site study records. The subject’s legally authorized representative received a copy of the signed and dated informed consent form and a copy of the signed assent (if applicable).

The parental/guardian informed consent form generated by the investigator with the assistance of BPCA DCC was approved (along with the protocol) by the IRB and was acceptable to the Steering Committee. Informed consent forms were in a language fully comprehensible to the subject’s legally authorized representative. Permission was documented by the use of a written consent form approved by the IRB and signed and dated by the subject’s legally authorized representative.

The written parental/legal guardian informed consent form embodied the elements of informed consent as described in the Declaration of Helsinki, the Code of Federal Regulations, and the ICH Guidelines and complied with local regulations. This form was read to the subject’s legally authorized representative and the investigator gave the representative adequate opportunity to read it before it was signed and dated.

Permission was documented by the dated signature of the subject’s legally authorized representative. The signature confirms that the permission is based on information that has been understood. Each signed consent form is kept on file by the investigators for possible inspection by BPCA DCC, Regulatory Authorities, and NICHD or its designees.