# Descriptive Supplementary Documents

- Study Protocol
- Data Collection Instruments
- Codebook/Variable Dictionary
- De-Identification Methodology