# 16 APPENDICES

16.1 Study Information
  16.1.1 Protocol and Protocol Amendments
  16.1.2 Sample Case Report Form
  16.1.3 Institutional Review Boards (IRBs) and Patient Consents and Information
    16.1.3.1 Names and Addresses of IRBs
    16.1.3.2 Sample Informed Consent Forms
  16.1.4 Description of Investigators
    16.1.4.1 Investigators and Locations
    16.1.4.2 CVs of Principal Investigators
  16.1.5 Signature Page
  16.1.6 Listing of Batch Numbers by Study Site
  16.1.7 Randomization Schedule
  16.1.8 Audit Certificates (if available)
  16.1.9 Statistical Analysis Plan
  16.1.10 Documentation of Inter-laboratory Standardization Methods and Quality Assurance Procedures, if Used
  16.1.11 Publications Based on the Study
  16.1.12 Important Publications Referenced in the Report
  16.1.13 FDA Written Request
16.2 Patient Data Listings (All Subjects)
  16.2.1 Study Population Status by Phase
  16.2.2 Final Study Disposition and Study Blind Status
  16.2.3 Inclusion/Exclusion Criteria
  16.2.4 Demographic Characteristics
  16.2.5 Physical Examination Abnormalities at Screening Visit
  16.2.6 Medical History (Abnormal History Only)
  16.2.7 Prior Medication
  - 16.2.8.1-2 Operative Information (Part 1-2)
  - 16.2.9.1 Study Medication Information
    16.2.9.2 Open-Label Infusion Rates
  16.2.10 MAP Scores
  - 16.2.11.1 Adverse Events
    16.2.11.2 Serious Adverse Events
    16.2.11.3 Serious Adverse Events Leading to Study Drug Discontinuation
  16.2.12 Concomitant Medications
  - 16.2.13.1 Clinical Laboratory Data
    16.2.13.2 Clinically Significant Laboratory Values
  - 16.2.14.1 Open-Label Phase Vital Signs
    16.2.14.2 Blinded Phase Vital Signs
    16.2.14.3 Follow-Up Phase Vital Signs
  - 16.2.15.1 Protocol Deviation Category
    16.2.15.2 Protocol Deviation Reporting
16.3 Case Report Forms for Participants of Special Interest
16.4 Datasets
  16.4.1 Datasets
    16.4.1.1 Raw Datasets
    16.4.1.2 Analysis Datasets
  16.4.2 ‘Define.pdf’ file
  16.4.3 SAS Programs

For documents listed but not available for download, please check the DASH repository at https://dash.nichd.nih.gov/study/14