# 4 LIST OF ABBREVIATIONS AND DEFINITION OF TERMS

Abbreviation: Definition
AE: Adverse Event
ALT: Alanine Transaminase
AST: Aspartate Transaminase
BMI: Body Mass Index
BPCA: Best Pharmaceuticals for Children Act
CL: Clearance
CFR: Code of Federal Regulations
CRF: Case Report Form
CSR: Clinical Study Report
DCC: Data Coordinating Center
DCRI: Duke Clinical Research Institute
DEV: Protocol Deviation
DOI: Drug of Interest
DSI: Data of Special Interest
ECMO: Extracorporeal Membrane Oxygenation
FDA: US Food and Drug Administration
FFM: Fat Free Mass
GA: Gestational Age
GCP: Good Clinical Practice
HIPAA: Health Insurance Portability and Accountability Act
ICF: Informed Consent Form
IEC: Institutional Ethics Committee
IND: Investigational New Drug application
IRB: Institutional Review Board
LBM: Lean Body Mass
NFM: Normal Fat Mass
NICHD: National Institute for Child Health and Development
NICHD-2011POP01: BPCA Protocol “Pharmacokinetics of Understudied Drugs Administered to Children Per Standard of Care”
NIH: National Institutes of Health
NONMEM: Nonlinear Mixed Effects Modeling
OFV: Objective Function Value
PHI: Protected Health Information
PI: Principal Investigator
PK: Pharmacokinetics
PMA: Postmenstrual Age
PNA: Postnatal Age
PTN: Pediatric Trials Network
RMSF: Rocky Mountain Spotted Fever
SAE: Serious Adverse Event
SOC: Standard of Care
V: Volume of Distribution
WT: Body Weight