# 2 SYNOPSIS

IND SPONSOR: Danny Benjamin, MD, MPH, PhD, Duke University, Duke Clinical Research Institute

FUNDING SPONSOR: Eunice Kennedy Shriver National Institute of Child Health and Human Development

NAME OF STUDY DRUG: Doxycycline

TITLE OF STUDY: Pharmacokinetics of Understudied Drugs Administered to Children per Standard of Care

PROTOCOL ID: NICHD-2011-POP01

PRINCIPAL INVESTIGATORS:

- Chiara Melloni, MD, MHS, Assistant Professor, Department of Medicine, Duke Clinical Research Institute (DCRI), Duke University
- Michael Cohen-Wolkowiez, MD, PhD, Associate Professor, Department of Pediatrics, DCRI, Duke University
- Danny Benjamin, MD, PhD, Kiser-Arena Distinguished Professor of Pediatrics, DCRI, Duke University

STUDY PERIOD: | Phase of Development: Phase 1
(date of first enrollment): March 12, 2012; (date of last completed): February 2, 2016

PRIMARY OBJECTIVE: Characterize the pharmacokinetics (PK) of doxycycline administered to children per standard of care as prescribed by their treating caregiver.

METHODOLOGY: The PK and safety analyses in this report include doxycycline data from NICHD-2011-POP01 (“Pharmacokinetics of Understudied Drugs Administered to Children per Standard of Care”), a multicenter, prospective opportunistic PK study of understudied drugs in children less than 21 years of age who receive drugs per standard of care, as prescribed by a treating caregiver. The NICHD-2011-POP01 study enrolls participants under multiple drugs of interest (DOI) including doxycycline. The date of the first doxycycline enrollment in the NICHD-2011-POP01 study was March 12, 2012. The last completion date for an NICHD-2011-POP01 participant included in the PK population for this report was February 2, 2016.

INCLUSION AND EXCLUSION CRITERIA:

Inclusion Criteria:

- Children less than 21 years of age who are receiving understudied drugs of interest per standard of care as prescribed by their treating caregiver.

Exclusion Criteria:

- Failure to obtain consent/assent, as indicated
- Known pregnancy as determined via interview or testing, if available.

TEST PRODUCT, DOSE AND MODE OF ADMINISTRATION, BATCH NUMBER:

In the NICHD-2011-POP01 study, participants received standard of care doxycycline, provided by the sites’ local pharmacies, according to their standard operating procedures. The study protocols did not specify the brand or batch numbers to be used.

CRITERIA FOR EVALUATION:

Efficacy: The efficacy of doxycycline was not evaluated in this study.

Pharmacokinetics:

The following primary PK parameters were assessed for doxycycline through a population PK analysis:

1. Clearance (CL)
2. Volume of distribution (V)
3. Population absorption rate constant (K_A_)

Safety:

Adverse events (AEs) and serious adverse events (SAEs) related to study procedures, and serious, unexpected, and suspected adverse reactions of doxycycline were collected.

STATISTICAL METHODS:

A population PK analysis using nonlinear mixed effects modeling approach and the software NONMEM (version 7.2, Icon Solutions, Ellicott City, MD) was performed to characterize doxycycline PK data in children. A covariate analysis was performed to determine the influence of demographic factors (e.g., sex, weight [WT]) and clinical factors (e.g., gestational age [GA], postnatal age [PNA], postmenstrual age [PMA], body mass index [BMI], and obese status) on PK parameters. In addition, inter-subject variability and residual variability were assessed. Individual empirical Bayesian post-hoc PK parameters were then estimated for each subject.

Models were evaluated based on successful minimization, goodness-of-fit plots, and precision of parameter estimates. In addition, the precision of the final population PK model estimates was evaluated using non-parametric bootstrapping. The final PK model was also evaluated by visual predictive check.

STUDY POPULATION:

A total of 47 subjects receiving doxycycline (21 IV, 19 oral, 7 IV and oral) contributed 74 plasma samples to the population PK analysis. Three participants were <2 years of age, 11 participants were 2 to ≤8 years of age, and 33 participants were >8 years of age.

RESULTS:

PK:

A one-compartment model offered the best fit to characterize doxycycline PK data based on model selection criteria.

The final population PK model included body weight for clearance (CL) and volume of distribution (V):

CL ( L / h ) = 3.32 * ( WT / 70 kg )^0.75^ ; V ( L ) = 96.8 * ( WT / 70 kg ) .

Allometrically-scaled doxycycline CL did not significantly differ between participants 2 to ≤8 years of age and those >8 years of age (median [range] 3.58 [2.27-10.82] and 3.27 [1.11-8.12] L/h/70 kg, P = 0.49). For participants weighing ≤45 kg, body weight normalized doxycycline CL did not differ significantly between children 2 to ≤8 years of age and those >8 years of age (median [range] 0.071 [0.041-0.202] and 0.081 [0.035-0.126] L/kg/h, P = 0.86). A comparison of weight normalized CL in children >45 kg could not be performed due to limitations in sample size (0.050 vs. 0.044 [0.014-0.121] L/kg/h); however, the limited data suggests that they were not clinically different.

Safety:

No AEs or SAEs related to study procedures were reported. No unexpected, suspected, adverse reactions to doxycycline were collected. Of the 6 participants ≤8 years of age with available tooth discoloration data, none reported tooth discoloration.

CONCLUSIONS:

PK:

A one-compartment model characterized the PK data for doxycycline in children. Allometrically-scaled doxycycline CL following oral and IV dosing in children 2 to ≤8 years of age did not differ significantly from those >8 years of age. For children weighing ≤45 kg, body weight normalized doxycycline CL in those 2 to ≤8 years of age did not differ significantly from those >8 years of age, and, in heavier children (>45 kg), no clinically significant differences were observed. This suggests that children 2 to ≤8 years of age may be given the same per kg dosing as that for children >8 years of age.

Safety:

There were no unexpected or suspected adverse reactions to doxycycline.

Overall:

Children 2 to ≤8 years of age should be given the same per kg dosing of oral and IV doxycycline as children >8 years of age.

Date of Report: January 11, 2017