# 13 DISCUSSION AND OVERALL CONCLUSIONS

## 13.1 Discussion

A one-compartment model appropriately characterized the PK of oral and IV doxycycline in children. Parameter estimates for clearance (3.32 L/h) and volume of distribution (96.8 L) in the population PK model scaled to a 70 kg adult were similar to those reported previously in adults (CL: 2.22-3.78 L/h; V/F: 50-80 L or 0.7-1.4 L/kg) [7, 8]. The bioavailability estimated in this study (89.6%) is consistent with that reported in adults (73-95%) [7]. Allometrically-scaled clearance of doxycycline in children ≥2 to ≤8 years of age was not significantly different from that in children >8 years of age. For children weighing ≤45 kg, body weight normalized doxycycline CL did not differ significantly between those ≥2 to ≤8 years of age and those >8 years of age. This may be explained by the maturation of elimination routes for doxycycline (biliary secretion and renal excretion). Both glomerular filtration rate and tubular secretion achieve adult level by 1 year of age [9, 10]. There have been few studies for ontogeny of biliary excretion in humans. Body weight based allometric scaling for biliary clearance was reported to be sufficient to predict drug clearance in children [11]. No clinically significant trends in CL differences between oral and IV were observed in the small cohort of patients who received the oral formulation alone.

Other than total body weight, there were no significant covariates identified for doxycycline PK. Fasting state may be a confounding factor in evaluation of relationships between PK parameters and body size/composition covariates (BMI, OBESE, LBM, FFM, NFM) in this study. In addition, a low sample size of obese children combined with sparse PK sampling could have affected the ability to separate these confounding effects on doxycycline drug disposition.

Tooth discoloration was not reported by a small cohort of children ≤8 years of age treated with doxycycline. This result was consistent with findings from a study in children <8 years of age (n = 58) treated with doxycycline for suspected Rocky Mountain spotted fever that reported no differences in tooth color, dental staining, or enamel hypoplasia between children who had received doxycycline and those who had never received doxycycline [12].

## 13.2 Overall Conclusions

The PK of doxycycline in children suggests that children 2 to ≤8 years of age may be given the same per kg dosing as children >8 years of age.