# 12 SAFETY EVALUATION

## 12.1 Extent of Exposure

Select administered SOC doses were recorded in the electronic data system to support the PK analysis. Dosing is summarized as needed in the PK Report (Appendix 16.4.1).

## 12.2 Adverse Events or Deaths

As of the date on this report, no AEs or SAEs related to study procedures have been reported among participants enrolled in the NICHD-2011-POP01 study. Study investigators reported no serious, unexpected, suspected adverse reactions to doxycycline. No deaths were reported.

## 12.3 Tooth Discoloration

Of the 6 participants ≤8 years of age with available tooth discoloration data, none reported tooth discoloration (Appendix 16.2.7).

## 12.4 Safety Conclusions

No safety events were reported. Of the 6 participants ≤8 years of age with available tooth discoloration data, none reported tooth discoloration.