# 11 EVALUATION OF PHARMACOKINETICS

## 11.1 Data Sets Analyzed

All doxycycline participants with plasma PK samples analyzed by the central laboratory who were not receiving ECMO were eligible to be included in the PK analysis.

## 11.2 Summary of PK Analysis

A population PK analysis was performed using plasma concentration-time data of doxycycline from 47 participants. A one-compartment model characterized the doxycycline PK data best. After incorporating body weight (WT) as a covariate (allometric scaling) on PK parameters, incorporation of effect of BMI on V resulted in the most significant drop in the objective function value (OFV). Scatter plots of BMI and V showed no relationship between BMI and V in participants who only had PK data after IV dose as well as participants who had PK data after oral dose under fed state. Given the small sample size and sparse sampling data in this study as well as presence of a confounding factor (fed state), body size covariates (LBM, FFM, and NFM), BMI, and OBESE were not selected for inclusion in the final model.

The final population PK model included body weight for clearance (CL) and volume of distribution (V): CL (L/h) = 3.32*(WT/70kg)^0.75^; V (L) = 96.8*(WT/70kg). Diagnostic plots, including visual predictive checks, for the final model are shown in the PK Report (Appendix 16.4.1).

Empirical Bayesian estimates (EBEs) obtained from the final model were stratified by age and body weight in Table 11-1. Allometrically-scaled doxycycline CL did not differ significantly between participants ≥2 to ≤8 years of age and those >8 years of age (median [range] 3.58 [2.27 - 10.82] and 3.27 [1.11-8.12] L/h/70 kg, P = 0.49). For participants weighing ≤45 kg, body weight normalized doxycycline CL did not differ significantly between children ≥2 to ≤8 years of age and those >8 years of age (median [range] 0.071 [0.041-0.202] and 0.081 [0.035-0.126] L/kg/h, P = 0.86). A comparison of weight normalized CL in children >45 kg could not be performed due to limitations in sample size (0.050 vs. 0.044 [0.014-0.121] L/kg/h), however, the limited data suggests that they were not clinically different.

Table 11-1 Individual Empirical Bayesian Post-hoc Parameter Estimates in Children

PNA (years) | N | CL (L/kg/h) | CL (L/h for 70kg) | V (L/kg) | Half-life (h)
<2 | 3 | 0.059; (0.050 – 0.077) | 1.99; (1.36 – 3.21) | 1.50; (1.41 – 1.91) | 17.7; (12.6 – 26.5)
≥2 to ≤8 | 11 | 0.068; (0.041 – 0.202) | 3.58; (2.27 – 10.82) | 1.43; (1.02 – 2.56) | 17.2; (5.8 – 24.0)
WT≤45 kg | 10 | 0.071; (0.041 – 0.202) | 3.60; (2.27 – 10.82) | 1.51; (1.02 – 2.56) | 16.9; (5.8 – 24.0)
WT>45 kg | 1 | 0.050 | 3.39 | 1.43 | 19.9
>8 | 33 | 0.047; (0.014 – 0.126) | 3.27; (1.11 – 8.12) | 1.25; (0.38 – 3.18) | 20.4; (4.8 – 41.3)
WT≤45 kg | 8 | 0.081; (0.035 – 0.126) | 4.58; (2.05 – 7.64) | 1.16; (0.87 – 3.18) | 15.2; (4.8 – 30.5)
WT>45 kg | 25 | 0.044; (0.014 – 0.121) | 3.22; (1.11 – 8.12) | 1.26; (0.38 – 2.93) | 20.4; (6.3 – 41.3)
Overall | 47 | 0.051; (0.014 – 0.202) | 3.37; (1.11 – 10.82) | 1.36; (0.38 – 3.18) | 18.8; (4.8 – 41.3)

Data are median (range); WT is body weight.

## 11.3 Conclusions

Allometrically-scaled doxycycline CL following oral and IV dosing in children 2 to ≤8 years of age did not differ significantly from those >8 years of age. For children weighing ≤45 kg, body weight normalized doxycycline CL in those 2 to 8 years of age did not differ significantly from those >8 years of age, and in heavier children (>45 kg) no clinically significant differences were observed. This suggests that children 2 to ≤8 years of age may be given the same per kg dosing as that for children >8 years of age.