# 10 DISPOSITION OF PARTICIPANTS

A total of 52 participants at 15 sites were enrolled under doxycycline prior to data freeze for this analysis. PK samples from a total of 47 participants at 14 sites were available for analysis and were included in the PK analysis (Appendix 16.4).

Specimens collected at different times from SOC medical laboratory collections from 3 participants enrolled at Children’s Mercy Hospital for whom consent was not provided were destroyed and were not included in the PK analysis.

One participant was excluded from the PK analysis since that participant was receiving extracorporeal membrane oxygenation (ECMO). One additional participant had no plasma samples collected.

## 10.1 Demographic Information

Key demographic information and indication for the first recorded doxycycline dose for the PK population is in Table 10-1.

Table 10-1 Demographic Characteristics

| Age at First Sample Collection
| ≤30 Days; (N=2) | >30 Days-<2 Years; (N=1) | 2-<13 Years; (N=24) | 13-<17 Years; (N=10) | 17-20 Years; (N=10) | Total; (N=47)
Gender
Female | 1 (50.0%) | 0 | 10 (41.7%) | 6 (60.0%) | 7 (70.0%) | 24 (51.1%)
Male | 1 (50.0%) | 1 (100.0%) | 14 (58.3%) | 4 (40.0%) | 3 (30.0%) | 23 (48.9%)
Race
Black or African American | 0 | 0 | 6 (25.0%) | 0 | 3 (30.0%) | 9 (19.1%)
White | 2 (100.0%) | 1 (100.0%) | 17 (70.8%) | 10 (100.0%) | 7 (70.0%) | 37 (78.7%)
Unknown or not reported | 0 | 0 | 1 (4.2%) | 0 | 0 | 1 (2.1%)
Ethnicity
Hispanic or Latino | 0 | 0 | 1 (4.2%) | 0 | 1 (10.0%) | 2 (4.3%)
Not Hispanic or Latino | 2 (100.0%) | 1 (100.0%) | 23 (95.8%) | 10 (100.0%) | 9 (90.0%) | 45 (95.7%)
Obese (BMI ≥ 95th Percentile)
Not Obese | 0 | 0 | 16 (66.7%) | 9 (90.0%) | 3 (30.0%) | 28 (59.6%)
Obese | 0 | 0 | 8 (33.3%) | 1 (10.0%) | 7 (70.0%) | 16 (34.0%)
Unknown or Unevaluable | 2 (100.0%) | 1 (100.0%) | 0 | 0 | 0 | 3 (6.4%)
Indication
Acne vulgaris | 0 | 0 | 0 | 0 | 3 (30.0%) | 3 (6.4%)
Central nervous system infections | 1 (50.0%) | 0 | 2 (8.3%) | 1 (10.0%) | 0 | 4 (8.5%)
Gram-negative infection | 0 | 0 | 3 (12.5%) | 1 (10.0%) | 0 | 4 (8.5%)
Infection, other type | 0 | 0 | 5 (20.8%) | 1 (10.0%) | 1 (10.0%) | 7 (14.9%)
Kawasaki disease | 0 | 0 | 1 (4.2%) | 0 | 0 | 1 (2.1%)
Mycoplasma | 0 | 0 | 0 | 1 (10.0%) | 0 | 1 (2.1%)
Other | 0 | 0 | 3 (12.5%) | 1 (10.0%) | 1 (10.0%) | 5 (10.6%)
Pneumonia | 0 | 0 | 2 (8.3%) | 2 (20.0%) | 0 | 4 (8.5%)
Prophylaxis | 0 | 0 | 1 (4.2%) | 0 | 0 | 1 (2.1%)
Q fever | 0 | 0 | 1 (4.2%) | 0 | 0 | 1 (2.1%)
Rickettsial disease | 0 | 1 (100.0%) | 2 (8.3%) | 0 | 0 | 3 (6.4%)
Rocky Mountain spotted fever | 1 (50.0%) | 0 | 2 (8.3%) | 2 (20.0%) | 0 | 5 (10.6%)
Skin and skin structure infections caused by staphylococcus aureus | 0 | 0 | 2 (8.3%) | 0 | 1 (10.0%) | 3 (6.4%)
Urogenital infection | 0 | 0 | 0 | 1 (10.0%) | 4 (40.0%) | 5 (10.6%)

## 10.2 Protocol Deviations and Waivers

Of the 47 participants enrolled under doxycycline that were included in the PK analysis, 4 (8.5%) had participant-specific deviations, with 3 participants (6.4%) having protocol procedure/assessment deviations and 1 participant (2.1%) having an informed consent deviation (Table 10-2). Participant-specific deviations reported for all 52 participants enrolled under doxycycline prior to data freeze are listed in Appendix 16.2.5. Site-specific deviations reported at sites during the time period of enrollment of doxycycline participants are listed in Appendix 16.2.6. There were no site-specific deviations related to the collection of plasma PK samples for doxycycline for participants included in the PK population.

Table 10-2 Participant-Specific Protocol Deviations (DEVs) by Deviation Type

| | Informed Consent/Assent | | Protocol Procedure/Assessment | | Other Classification | | Total
Site | Participants Enrolled | Participants with DEV N (%) | Total DEVs N | Participants with DEV N (%) | Total DEVs N | Participants with DEV N (%) | Total DEVs N | Participants with DEV N (%) | Total DEVs N
▬ | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
▬ | 3 | 1 (33.3%) | 1 | 0 | 0 | 0 | 0 | 1 (33.3%) | 1
▬ | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
▬ | 5 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
▬ | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
▬ | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
▬ | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
▬ | 7 | 0 | 0 | 3 (42.9%) | 3 | 0 | 0 | 3 (42.9%) | 3
▬ | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
▬ | 8 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
▬ | 5 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
▬ | 8 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
▬ | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
▬ | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Total | 47 | 1 (2.1%) | 1 | 3 (6.4%) | 3 | 0 | 0 | 4 (8.5%) | 4