# 9 INVESTIGATIONAL PLAN

## 9.1 Overall Design and Plan Description

NICHD-2011-POP01 is a multicenter, prospective PK study of understudied drugs in children less than 21 years of age who receive DOIs per standard of care, as prescribed by a treating caregiver. Doxycycline is one of the DOIs included in the NICHD-2011-POP01 study.

NICHD-2011-POP01 participants are enrolled in 90-day segments. Participants can provide data for multiple drugs of interest in the same 90-day segment. In addition, a previously-enrolled participant can re-consent to be enrolled in additional 90-day segments in order to contribute data for a different DOI.

### 9.1.1 Schedule of Assessments

The NICHD-2011-POP01 study provides a standardized plan for study assessments that apply across all DOIs. In addition to demographic data, assessment data collected under this protocol include dosing, PK sampling, clinical laboratory assessments, and adverse events (AEs) related to study procedures. The annotated case report forms (CRFs) for these assessments are included in Appendix 16.1.2.

Additional DOI-specific Data of Special Interest (DSI) are also collected for some DOIs. For doxycycline, DSI included the approximate total duration of all prior doxycycline treatments and whether there was discoloration of the teeth after doxycycline treatment, as observed by the clinical site team or documented in the medical record. The annotated CRF for the doxycycline DSI is included in Appendix 16.1.2.

### 9.1.2 Dosing Information

Under the NICHD-2011-POP01 protocol, dosing information for DOIs is collected for up to 8 doses prior to the sampling dose (last dose prior to biological sample collection).

### 9.1.3 Prior and Concomitant Therapy

Concomitant medications collected for doxycycline were bismuth subsalicylate, carbamazepine, phenobarbital, and phenytoin. Only medication administered within 24 hours before and after the last dose of the DOI prior to the time of biological sample collection were recorded.

### 9.1.4 PK Data

#### 9.1.4.1 PK Assessments

Under the NICHD-2011-POP01 protocol, PK samples are obtained via SOC draws as well as non-SOC draws. Samples collected via non-SOC draws are only to be collected from participants who provided consent for the collection of these samples. Suggested sampling windows are provided in the study Manual of Procedures (Table 9-1). The sampling windows were developed to guide PK sampling, and excursions from these windows are not considered protocol deviations under the protocol.

For doxycycline, only fresh plasma samples were included in the PK analysis. For inpatients, blood samples drawn at separate times from SOC draws were not to have exceeded 10 samples in a 90-day period, and blood draws done at separate times from SOC draws were not to have exceeded 3 samples within a 24-hour period. For outpatients, blood samples drawn at separate times from SOC draws were not to have exceeded 6 in a 90-day period, and blood draws at separate times from SOC draws were not to have exceeded 3 samples within a 24-hour period. Each blood sample was expected to be approximately 200 µL to 2 mL, depending on the age of the participant.

Table 9-1 Optimal Sample Collection Scheme

Intravenous Administration
| Dosing Interval (Hours) | | | | | | | | Dosing Interval (Days)
Sample Name | 2 | 4 | 6 | 8 | 12 | 24 | 48 | 72 | 7 | 21 | 28
Sample #1 | 0^a^ | 0^a^ | 0^a^ | 0^a^ | 0^a^ | 0^a^ | 0^a^ | 0^a^ | 0^a^ | 0^a^ | 0^a^
Sample #2 | 0.15^b^-0.5 | 0.5-2 | 1-4 | 2-5 | 2-8 | 3-12 | 3-24 | 3-48 | 2-4 | 7-14 | 14-21
Sample #3 | Pre^c^ | Pre^c^ | Pre^c^ | Pre^c^ | Pre^c^ | Pre^c^ | Pre^c^ | Pre^c^ | Pre^c^ | Pre^c^ | Pre^c^
Sample #4 (elimination) | 4-8 | 8-12 | 12-18 | 16-24 | 24-36 | 48-72 | 96-144 | 144-216 | 14-21 | 42-63 | 56-84

Other (oral, spray, nebulized, etc.) Routes of Administration
| Dosing Interval (Hours) | | | | | | | | Dosing Interval (Days)
Sample Name | 2 | 4 | 6 | 8 | 12 | 24 | 48 | 72 | 7 | 21 | 28
Sample #1 | 0.15^a^-.5 | 0.25^b^-1 | 0.5-2 | 0.5-2 | 0.5-2 | 0.5-2 | 0.5-2 | 0.5-2 | 0.5-2 | 0.5-2 | 0.5-2
Sample #2 | 0.5-1 | 0.5-2 | 1-4 | 2-5 | 2-8 | 3-12 | 3-24 | 3-48 | 2-4 | 7-14 | 14-21
Sample #3 | Pre^c^ | Pre^c^ | Pre^c^ | Pre^c^ | Pre^c^ | Pre^c^ | Pre^c^ | Pre^c^ | Pre^c^ | Pre^c^ | Pre^c^
Sample #4 (elimination) | 4-8 | 8-12 | 12-18 | 16-24 | 24-36 | 48-72 | 96-144 | 144-216 | 14-21 | 42-63 | 56-84

Administered via Continuous Infusion^*^ or Single Dose Administered Once via IV or Oral
Sample Name | Time points after start of continuous infusion or end of single dose administration (hours)
Sample #1 | 0-0.25
Sample #2 | 0.15-0.5
Sample #3 | 1-3
Sample #4 | 4-8

a Time 0 = end of infusion; collect sample after flush* ends

b 0.15 hours = 9 minutes

c Pre = within 1 hour prior to next administration of study drug

a 0.15 hours = 9 minutes

b 0.25 hours = 15 minutes

c Pre = within 1 hour prior to next administration of study drug

For participants undergoing bariatric surgery, optimally, sites were recommended to collect a set of pre- and post-surgery PK samples to study the influence of the changes in the anatomy of the gastrointestinal tract (for oral drugs) associated with bariatric surgery.

* Instructions apply to continuous infusions of <3 days. If continuous infusion is for 3 days (or longer), sites were recommended to collect samples following site SOC for sampling.

#### 9.1.4.2 PK Sample Analysis

Pharmacokinetic samples collected under NICHD-2011-POP01 are sent to the PTN central laboratory for drug concentration measurements. Samples are to be labeled only with a unique accession number, without protected health information (PHI) that could identify the study participant. Once samples are analyzed, data are sent to the BPCA DCC and entered into the study records.

Doxycycline concentrations in plasma were quantified by the PTN central laboratory (OpAns, LLC, Durham, NC, USA) using a validated HPLC/MS-MS assay as described in Document OPR-NIH-0072.02 (Appendix 16.4.5). Accuracy and precision assessed using four determinations at theoretical levels 50, 150, 1,500, and 8,000 ng/mL were within the Food and Drug Administration (FDA) bioanalytical assay validation criteria (e.g., ±15%). The lower limit of quantification for doxycycline was 50 ng/mL. The central laboratory’s bioanalytical study report (Document OPR-NIH-0081.02) is included in Appendix 16.4.6.

### 9.1.5 Clinical Laboratory Assessments

Per the NICHD-2011-POP01 protocol, for serum creatinine, plasma albumin, aspartate transaminase (AST), alanine transaminase (ALT), and bilirubin, the concentration value as well as the date of collection are to be collected only if drawn within 72 hours (before or after) of the sampling dose of the DOI. If more than 1 result is available within the 72-hour time frame, the result closest to the time of the sampling dose of drug of interest is to be recorded. If more than 1 biological sample is collected within a 72 hour period, one serum creatinine, plasma albumin, AST, ALT, and/or bilirubin value (closest to the time of the sampling dose of the drug of interest) is to be recorded.

### 9.1.6 Adverse Events

Under NICHD-2011-POP01, AEs, SAEs, and serious, unexpected, suspected adverse reactions are reported as defined in the study protocol (Appendix 16.1.1). The following types of events are collected:

1. AEs and SAEs caused by the study specimen collection are to be reported at each time point when study-specified biological sample collection occurs up until 1 hour after collection. AE information is to be gained from direct monitoring of the study participant, as well as from clinician observation and self-reporting by the study participant or his/her guardian(s). AEs related to study procedures are to be followed until resolution even if this extended beyond the study-reporting period. Resolution of an AE is defined as the return to pretreatment status or stabilization of the condition with the expectation that it will remain chronic.
2. Serious, unexpected, suspected adverse reactions of the understudied drug of interest were to be reported from the time of first biological sample collection until 3 days after the last biological sample was collected if participant was available.

### 9.1.7 Doxycycline Data of Special Interest

Data of special interest collected for doxycycline participants ≤8 years old included the approximate total duration of all prior doxycycline treatments and whether there was discoloration of the teeth after doxycycline treatment. Data regarding the approximate total duration of all prior doxycycline treatments and the source of this information was collected at the time of enrollment. Data regarding the interval of the current course of doxycycline and discoloration of the teeth was recorded after the participant finished the current course of doxycycline or up to 90 days after consent, if the participant was still receiving doxycycline at that time. Clinical sites were instructed to indicate if either discoloration of the teeth (yellow-gray-brown) was observed by the clinical site team and/or was documented in the medical record.

## 9.2 Discussion of Study Design

One of the primary challenges for standard of care PK studies is ensuring the accuracy of data collection for sampling times and other PK variables, particularly in multicenter studies. Careful consideration and planning of data collection for this study by experienced pediatric clinical pharmacology experts and a strong data management team minimized this potential limitation of the study. Regular investigator meetings and training sessions for site staff are held to maximize consistency in data collection across the PTN. Other limitations include challenges associated with PK modeling of limited samples, participant selection bias, and other unknown biases.

## 9.3 Study Population

### 9.3.1 Inclusion Criteria

For NICHD-2011-POP01 as a whole:

- Children <21 years of age who are receiving understudied drugs of interest per SOC as prescribed by their treating caregiver were eligible for the NICHD-2011-POP01 protocol.

### 9.3.2 Exclusion Criteria

- Failure to obtain consent/assent, as indicated.
- Known pregnancy as determined via interview or testing, if available.

### 9.3.3 Additional Doxycycline Enrollment Criteria

The following additional criteria were used in the enrollment of doxycycline participants. Protocol deviations were not given if sites enrolled participants that violated these enrollment criteria. Participants that violated these criteria were eligible for inclusion in the PK and safety analyses.

- Children who were <1 month postnatal age at enrollment were not to have been enrolled.
- Children who were <5 months postnatal age at enrollment who were born prematurely (≤37 weeks gestational age) were not to have been enrolled.
- Children and young adults who were 17 to 20 years of age at enrollment and were not obese nor receiving extracorporeal membrane oxygenation (ECMO) were not to have been enrolled.

### 9.3.4 Removal of Participants from Assessment

- Parents or legal guardians of participants who withdrew consent or participants ≥18 years of age who withdrew consent to participate in the study and requested no further follow-up were terminated from the study.
- If minor participants decided not to remain in the study, they were withdrawn even if the parent or guardian of the minor participants had not withdrawn consent.
- Females who became pregnant during the study were permitted to remain in the study; however, a replacement participant may have been enrolled.
- In cases of early or premature termination (defined as participant with no samples obtained or drawn for the study and/or participant was withdrawn from the study), a replacement participant may have been enrolled.

## 9.4 Treatments

Participants received doxycycline as per standard of care.

### 9.4.1 Identity of Investigational Products

Doxycycline was provided by the sites’ local pharmacies, according to their standard operating procedures (SOPs). The study protocol did not specify the brand or batch numbers to be used.

### 9.4.2 Method of Assigning Participants to Treatment Groups

Treatment assignment was performed through SOC by a treating caregiver.

### 9.4.3 Selection of Doses in the Study

Doxycycline was prescribed by a treating caregiver under SOC.

### 9.4.4 Selection and Timing of Dose for Each Participant

Dosing was prescribed by a treating caregiver under SOC.

### 9.4.5 Blinding

Not applicable.

### 9.4.6 Treatment Compliance

Participants were administered doxycycline through SOC; therefore, treatment compliance was not monitored.

## 9.5 Pharmacokinetic and Safety Variables

### 9.5.1 Pharmacokinetic Variables

PK variables are parameters estimated from the population PK analysis.

### 9.5.2 Safety Variables

For all DOIs under NICHD-2011-POP01, AEs or SAEs related to study procedures (collection of biological samples for research purposes) and serious, unexpected, suspected adverse reactions of understudied drug of interest are reportable.

## 9.6 Data Quality Assurance

The NICHD-2011-POP01 Principal Investigators (PIs) provide direct access to all trial-related sites, source data/documents, data collection forms, and reports for the purpose of monitoring and auditing by the sponsor, and inspection by local and regulatory authorities. The PIs ensure that all study personnel are appropriately trained and applicable documentations are maintained on site.

Emmes-designated clinical monitors verify that the study is conducted and data are generated, documented (recorded), and reported in compliance with the protocol, GCP, and the applicable regulatory requirements. Clinical monitoring reports are submitted to the PIs, PTN, and NIH/NICHD.

The DCC implements quality control procedures beginning with the data entry system and generates data quality control checks that are run on the database. Any missing data or data anomalies are communicated to the site(s) for prompt clarification and resolution.

## 9.7 Statistical Methods

As outlined in the Statistical Analysis Plan for NICHD-2011-POP01 (Appendix 16.1.9), statistical analyses include study disposition, demographic characteristics, and protocol deviations (Section 10). Deviations from the Statistical Analysis Plan for this DOI analysis are summarized in Section 9.8.5. All summaries except study disposition were limited to participants who were eligible for the PK analysis (PK population). All participants with available samples analyzed by the central laboratory were included in the PK population. Available samples are samples that have not been lost or destroyed by the site or central laboratories. Clinical laboratory evaluations were evaluated as covariates in the population PK analysis but were not used to assess drug safety. Clinical laboratory values were imputed in the PK dataset using the closest laboratory value collected within 72 hours of a sampling dose.

Reported demographic information included age at first sample collection, sex, race, and ethnicity. Obesity (body mass index ≥ 95th percentile) status was only assessed in children ≥ 2 years of age, and was calculated using the closest weight recorded at the time of the first sample collection. Deviations reported at sites with participants in the doxycycline PK population are included in the listing of site-specific protocol deviations (Appendix 16.2). Deviations are included in this listing if they were reported between the first date of enrollment in a 90-day study segment for participants in the doxycycline PK population at that site and the last date of PK plasma sample testing at the central laboratory.

### 9.7.1 Pharmacokinetic Analyses

A population PK analysis using nonlinear mixed effects modeling approach and the software NONMEM (version 7.2, Icon Solutions, Ellicott City, MD) was performed to characterize doxycycline PK data in children. A covariate analysis was performed to determine the influence of demographic factors (e.g., sex, weight) and clinical factors (e.g., GA, PNA, PMA, BMI, and obese status) on PK parameters. In addition, inter-subject variability and residual variability were assessed. Post-hoc Bayesian individual PK parameters were then estimated for each subject and compared between the ≥2 to ≤8 year age group and the >8 year age group. Participants who had their first PK sample collected on or after the day of their 2nd birthday and before or on the day of their 8th birthday were included in the ≥2 to ≤8 year age group. Participants who had their first PK sample collected on any day after the day of their 8th birthday were included in the >8 year age group.

Models were evaluated based on successful minimization, goodness-of-fit plots, and precision of parameter estimates. In addition, the precision of the final population PK model estimates was evaluated using non-parametric bootstrapping. The final PK model was also evaluated by visual predictive check.

A detailed description of PK analysis can be found in the PK analysis report.

## 9.8 Changes in the Conduct of the Study or the Planned Analyses

Version 1.0 through Version 5.0 are provided in Appendix 16.1.1. Major amendments to the protocol are summarized below.

### 9.8.1 NICHD-2011-POP01 Protocol Version 2.0 – Summary of Changes

PROTOCOL SECTION | SUMMARY OF CHANGES (Version 2.0)
Protocol Synopsis | - Study duration extended to November 2014; - Number of Sites increased to 50-100
Flowchart of Study Procedures | - Revised to indicate that clinical data are collected from Day 1 up to Day 90 or Termination Visit.
4.3 Withdrawal and/or Replacement | - Text added:; - [underlined: 2) If minor subjects decide not to remain in the study, they will be withdrawn even if the parent or guardian of the minor subject has not withdrawn consent.]; - [underlined: 4) In cases of early / premature termination (defined as participant has had no samples obtained / drawn for the study and / or participant is withdrawn from the study), a replacement subject may be enrolled.]
6.4 Study Procedures After Biological Sample Collection | - Revised text to clarify procedures for collecting biological sample and to include reference to the Manual of Operating Procedures.
8.1 Definition of Adverse Events | - Text revised to clarify that AEs and SAEs are defined by protocol as relating to collection of biological samples for research purposes.
8.2 Adverse Event Collection Period | - Text added:; - [underlined: Any event that requires expedited reporting based on federal regulations will be forwarded to the IND Sponsor via notification by site staff through data entry into the EDC System. The IND Sponsor or its representative will submit expedited safety reports (IND Safety Reports) to the FDA and other regulatory agencies as necessary, and will inform the Investigators of such regulatory reports. Site Investigators must submit IND safety reports as required by their IRB. Documentation of the submission and receipt by the IRB must be retained for each IND safety report.]
8.3 Risk Assessment | - Text deleted:; - [struck: The maximum total sample volume collected will vary by age and biological matrix (see appendix B)].; - Text added:; - [underlined: For inpatients, blood samples drawn solely for research purposes will not exceed 10 in a 90 day period, and blood draws done for research purposes will not exceed three within a 24-hour period.]; - [underlined: For outpatients, blood samples drawn solely for research purposes will not exceed 6 in a 90 day period, and blood draws done for research purposes will not exceed three within a 24-hour period.]; - [underlined: Each blood sample will be approximately 200 uL. No more than 2 milliliters/kilogram per blood sample will be collected at any one time. For additional information on age/weight based recommendations for maximum total sample volume collected for research purposes, see the Manual of Operating Procedures.]
9 STATISTICAL METHODS | - Section added:; - [underlined: 9.4 Population to be Analyzed]; - [underlined: Data and samples from patients enrolled in PK studies other than NICHD-POPS01 may be analyzed with this protocol’s data and biological samples. For example, Ketamine samples and data collected from a Ketamine PK study are being sent to and used by Duke and/or its authorized representatives, The Emmes Corporation (Data Collection Center) and OpAns (the POPS study central PK laboratory) and for analysis.]

### 9.8.2 NICHD-2011-POP01 Protocol Version 3.0 – Summary of Changes

PROTOCOL SECTION | SUMMARY OF CHANGES (Version 3.0)
Protocol Synopsis | - Approximate number of subjects increased to 1,000.; - Number of Sites revised to “Up to 100.”; - Study duration extended to November 2015
5.1 Sampling Information | - Text added:; - [underlined: 6) Dried Plasma Spot (DPS)]; - [underlined: 7) Dried Urine Spot (DUS)]
5.2 Understudied Drug Information | - Text added:; - [underlined: 6) Dried Plasma Spot (DPS)]; - [underlined: 7) Dried Urine Spot (DUS)]
8.3 Risk Assessment | - Text changed to clarify that for inpatients blood samples drawn solely for research purposes will not exceed 10 samples per drug in a 90 day period.
9.3 Sample Size | - Text revised to clarify that interim PK analyses on some DOIs may be performed prior to enrollment of 25 participants.

### 9.8.3 NICHD-2011-POP01 Protocol Version 4.0 – Summary of Changes

PROTOCOL SECTION | SUMMARY OF CHANGES (Version 4.0)
Protocol Synopsis | - Approximately number of subjects increased to 2,000.
1 Background and Rationale | - Text added to introductory paragraph:; - [underlined: The Best Pharmaceuticals for Children Act (BPCA) mandates the National Institutes of Health (NIH) to prioritize therapeutic areas in critical need for pediatric labeling, sponsor pediatric clinical trials, and submit these data to FDA for consideration for labeling changes. This study will be conducted in accordance with Section 409I of the Public Health Service Act; as such, the results from this research may be submitted to the FDA for review and use in negotiated labeling changes. This research study is contractually supported by the NICHD. The NICHD awarded a contract to the Duke Clinical Research Institute (DCRI) to establish a Pediatric Trials Network (PTN) in order to facilitate trial design for studies supported by NIH.]
4.3 Withdrawal and/or Replacement | - Text revised to clarify that participants can be enrolled in the study on more than 1 occasion as long as the maximum number of blood samples per participant have not been collected within 90 days of enrolment into the study.
5.2 Understudied Drug Information | - Strikeout text removed:; - Exact date and time of previous dose administration for other (i.e. oral, [struck: topical], inhaled) formulations.; - Strikeout text removed:; - Collect drug of interest information for up to 8 doses prior to the sampling dose (last dose prior to [struck: first] biological sample collection).
5.5 Clinical Information | - Strikeout text removed and underlined text added:; - For serum creatinine, plasma albumin, AST, ALT, and bilirubin the concentration value as well as the date of collection [struck: will] [underlined: should] be obtained. The laboratory data defined above will be [struck: collected] [underlined: recorded] only if drawn within [underlined: 72][struck: 24] hours (before or after) of the dose [struck: of] [underlined: for the] drug of interest [struck: closest to] [underlined: just before] the time of biological sample collection. If more than 1 result is available within the [underlined: 72][struck: 24]hour time frame, record the result closest to the time of the dose of drug of interest. If more than 1 biological sample is collected within a [underlined: 72][struck: 24]hour period, one serum creatinine, plasma albumin, AST, ALT, and/or bilirubin value ([struck: closest to] [underlined: just before] the time of the dose of drug of interest) will be obtained. [struck: If biological samples are collected in a span of more than 1 day, above laboratory data will be collected each day of biological sample collection and closest to the time of the dose of for the drug of interest closest to the time of biological sample collection]
6.1 Informed Consent | - Underlined text added:; - If several drugs of interest are prescribed to the same subject during the same hospital stay, only one informed consent/assent form will be required for [underlined: 90 day] participation in the study
8.3 Risk Assessment | - Strikeout text removed:; - For inpatients, blood samples drawn solely for research purposes will not exceed 10 samples [struck: per drug] in a 90 day period, and blood draws done for research purposes will not exceed three within a 24-hour period; - Underlined text inserted and strikeout text removed:; - Each blood sample will be approximately 200 uL [underlined: – 2 mL depending on the age of the participant.] [struck: No more than 2 milliliters/kilogram per blood sample will be collected at any one time]
10.3 Subject Information and Consent/Assent | - Strikeout text removed:; - Prior to any study related [struck: screening] procedures being performed on the subject, the informed consent/ assent (as indicated) statement will be reviewed, signed and dated by the subject/ subject’s parent or legal guardian, and by the person who administered the informed consent

### 9.8.4 NICHD-2011-POP01 Protocol Version 5.0 – Summary of Changes

PROTOCOL SECTION | SUMMARY OF CHANGES (Version 5.0)
Statement of Compliance | - Text revised to broaden language for non-US sites:; - This trial will be conducted in compliance with the protocol and in accordance with all applicable regulatory requirements, including US CFR 21 part 312 (where applicable) and all applicable rules, regulations, and federal, state, and local laws relating to the conduct of clinical studies and the protection of human patients. The trial will be conducted in accordance with “good clinical practice” (GCP) ICH guideline E6, all applicable subject privacy requirements, and the guiding principles of the Declaration of Helsinki. This includes, but is not limited to, the following:; - IRB / IEC review and favorable opinion / approval to conduct the study and of any subsequent relevant amended documents; - Written informed consent (and any amendments) to be obtained for each participant prior to participation in study procedures; - Investigator reporting requirements (e.g. reporting of AEs/SAEs/protocol deviations to IRB / IEC)
List of Abbreviations | - Added FDAASIA, IEC, IRB, and PREA.
Protocol Synopsis | - Study duration extended to November 2016
Flowchart of Study Procedures (footers) | - Footnotes added:; - [underlined: c. AEs and SAEs caused by the study specimen collections will be recorded at each time point when the study specified biological sample collection occurs up until 1 hour after collection. Serious, unexpected, suspected adverse reactions related to the understudied drug of interest will be recorded from the time of first biological sample collection until 3 days after the last biological sample is collected if subject is available.]; - [underlined: d. May include lab collection (which could also be pre-sample collection)]; - [underlined: e. If participant is accessible, collect 1 PK plasma sample at time of identification of serious, unexpected, suspected adverse reactions of the understudied drug of interest.]
1.4 Best Pharmaceuticals for Children Act | - Text revised to clarify BPCA prioritization:; - BPCA Priority List of Needs in Pediatric Therapeutics: NICHD, in consultation with the Food and Drug Administration and experts in pediatric research, develop and publish a priority list of needs in pediatric therapeutics. Part of fulfilling the NIH’s authority and responsibility outlined in the BPCA legislation is to establish a program for pediatric drug testing and development and to publish a list of drugs/needs in pediatric therapeutics. The BPCA Priority List consists of key therapeutic needs in the medical treatment of children and adolescents; it is organized by therapeutic area, which can be a group of conditions, a subgroup of the population, or a setting of care.
5.1 Sampling Information | - Text added:; - Samples may be collected on Day 1 through Day 90 post consent or until a Termination Visit, whichever occurs first. The following variables should be documented in the eCRF:; - Underlined text inserted in list of variables:; - 3) Sample [underlined: type] volume (estimated); - Underlined text inserted in list of biological matrix categories:; - 2) Whole blood [underlined: / cellular pellet]
5.5 Clinical Information | - Text added:; - Certain drugs of interest will also require the collection of data of special interest.
6.2 Study Procedures Before Biological Sample Collection | - Underlined text added:; - 1) Signed and dated informed consent/assent [underlined: (unless a waiver of written consent has been obtained from the local IRB or IEC)]
8.2 Adverse Event Collection Period | - Text revised to improve readability, and to broaden language so that it applies to both US and non-US sites.
8.3 Risk Assessment | - Text revised so that language applies to both US and non-US sites.
9 Statistical Methods | - Strikeout text removed and underlined text added:; - Descriptive statistics such as number of observations, mean, median, 95% confidence interval, standard deviation, standard error, minimum, and maximum will be presented for continuous variables (such as age, weight, etc). Other descriptive statistics such as counts, proportions, and/or percentages will be presented by drug and dosage group to summarize discrete variables (such as race, sex, etc.). The number of subjects completed [underlined: or][struck: , and] discontinued early from study, and the reasons for discontinuation, will be summarized by study drug. Demographic and safety characteristics will be summarized by study drug [struck: and dosage group].; - [underlined: Exploratory efficacy evaluations using data collected from standard of care procedures may be performed for select drugs of interest]. [struck: Efficacy evaluation of the drugs under study is beyond the scope of this investigation.]; - Analysis Population: All participants with at least 1 evaluable sample will be included in the analysis.; - Missing data: Due to the nature of the study, there is a potential for missing data. Multiple imputation methods will [underlined: be] employed to account for [underlined: some] missing data. Sensitivity analyses will be performed to evaluate the impact of multiple imputation of the missing data.
9.3 Sample Size | - Text deleted:; - [struck: For some drugs the sample size may be approximately 25 per cohort per drug].
10.3 Subject Information and Consent/Assent | - Underlined text added:; - Prior to any study related procedures being performed on the subject, the informed consent / assent (as indicated) statement will be reviewed, signed and dated by the subject / subject’s parent or legal guardian, and by the person who administered the informed consent [underlined: unless a waiver of written consent has been obtained from the local IRB or IEC. If a waiver of written consent has been obtained, the site will follow local site policy for documenting informed consent.]

### 9.8.5 Changes to Planned Analysis

Due to the low sample size, the absence of safety events, and the limited data of special interest collected for doxycycline, tables presented in the CSR are limited to key summaries of enrollment, demographics, and PK results. Section 14 tables specified in the SAP were not prepared for this drug of interest. Content planned in the SAP to be presented in Section 14 is presented as in-text tables, or discussed in the narrative of the CSR or the PK analysis report (Section 16.4.1). In-text tables are restricted to the PK analysis population. Data for all enrolled doxycycline participants are presented in the Section 16.2 data listings. Concomitant medication, clinical laboratory, and additional baseline data were collected for the PK analysis and are summarized in the PK analysis report as needed. Dosing and PK sample collection are also summarized in the PK analysis report as needed.

Tooth discoloration associated with doxycycline use was analyzed using frequency counts of the number of participants with recorded tooth discoloration. No additional changes to the planned analyses were made.