# 8 STUDY OBJECTIVES

## Primary Objective

Characterize the PK of doxycycline administered to children per standard of care as prescribed by their treating caregiver.