# 7 INTRODUCTION

## 7.1 BPCA

The Best Pharmaceuticals for Children Act (BPCA) mandates the National Institutes of Health (NIH) to prioritize therapeutic areas in critical need for pediatric labeling, sponsor pediatric clinical trials, and submit these data to the U.S. Food and Drug Administration (FDA) for consideration for labeling changes. This study was conducted in accordance with Section 409I of the Public Health Service Act; as such, the results from this research are being submitted to the FDA for review and may be used in negotiated labeling changes. This research study was contractually supported by the NICHD. The NICHD awarded a contract to Duke University, which established a Pediatric Trials Network (PTN) through its Duke Clinical Research Institute (DCRI) to facilitate trial design for studies supported by NIH. A separate contract was awarded to The Emmes Corporation to serve as the BPCA Data Coordinating Center (DCC).

## 7.2 NICHD-2011-POP01

Study NICHD-2011-POP01, entitled “Pharmacokinetics of Understudied Drugs Administered to Children per Standard of Care,” is a prospective multi-center trial conducted under the BPCA to characterize the PK of understudied drugs administered by their treating caregiver to children <21 years old per standard of care (SOC). This protocol (Appendix 16.1.1) enrolls participants through the PTN under multiple drugs of interest (DOIs), each of which is administered to children per SOC. Enrollment in NICHD-2011-POP01 is ongoing for multiple DOIs. Enrollments for doxycycline were closed on February 24, 2016.

The NICHD-2011-POP01 study utilizes an “opportunistic” study mechanism. The majority of drugs administered to children are used off label, and PK studies to define appropriate dosing are lacking across pediatric age groups. Challenges associated with clinical trials in children limit the ability to conduct PK and dosing trials in this population. Studies capitalizing on SOC procedures have proven successful in characterizing the PK of drugs used in children. The opportunistic study mechanism serves as a tool to better understand drug exposure in children receiving drugs per standard of care.

## 7.3 Pediatric Labeling for Doxycycline

Doxycycline was identified as a DOI for the NICHD-2011-POP01 study by the NICHD. Doxycycline is included on the BPCA Priority List of Needs in Pediatric Therapeutics for 2015, in the table of infectious disease priorities. Identified knowledge and labeling gaps include pharmacokinetic and safety data in children younger than 8 years old [1].

Doxycycline is a tetracycline-class antimicrobial indicated to treat infections caused by many microorganisms. It is labeled to treat rickettsiea; mycoplasma pneumonia; agents of psittacosis (ornithosis); lymphogranuloma venereum and granuloma inguinale; spirochetal agent of relapsing fever (Borelia recurrentis); the gram negative microorganism Haemophilus ducreyi (chancroid); Pasteurella pestis; Pasteurella tularensis; Bartonella bacilliformis; Bacteroides species; Vibrio comma and Vibrio fetus; Brucella species (in conjunction with streptomycin); and Bacillus anthracis in adults and in children >8 years of age. Doxycycline is indicated in children ≤8 years of age for treating severe life-threatening conditions (i.e., anthrax and inhalation anthrax [post-exposure]), and when alternative therapies are likely to be ineffective or are contraindicated.

The usual dose of oral doxycycline in adults is 200 mg on the first day of treatment (administered 100 mg every 12 hours) followed by a maintenance dose of 100 mg/day.

The recommended dose for patients >8 years of age weighing 100 pounds or less is 2 mg/lb of body weight divided into two doses on the first day of treatment, followed by 1 mg/lb of body weight given as a single daily dose or divided into two doses on subsequent days. For more severe infections, up to 2 mg/lb of body weight may be used. For children over 100 lb the usual adult dose should be used. The label indicates that doxycycline should not be used in children ≤8 years of age except for the treatment of anthrax, including inhalational anthrax, as this class of drug may lead to permanent tooth discoloration. Dosing for the treatment of anthrax in children weighing less than 100 lb is 1 mg/lb (2.2 mg/kg) of body weight by mouth twice daily for 60 days. Children weighing 100 pounds or more should receive the adult dose.

Currently, the great majority of the published labels for doxycycline still provide weight-based dosing either as per pound, or per pound with the per kg equivalent in parenthesis.

## 7.4 Scientific Rationale

While the majority of labels only support the use of doxycycline in children <8 years of age for treatment of anthrax, current literature recommends doxycycline as the drug of choice for life-threatening infections seen in this age group, such as tick-borne rickettsial infections [2]. Investigators have shown that early treatment with doxycycline decreases morbidity and mortality in some tick-borne illness, such as Rocky Mountain spotted fever (RMSF) [3]. Despite this clear evidence, only 35% of US healthcare providers report using the drug in patients <8 years of age with suspected RMSF [4]. Additional safety concerns include the lack of pediatric pharmacologic data in the current doxycycline label.

To support the safe use of doxycycline in children, the goal of this study was to improve the drug label to include pediatric pharmacokinetic data for children ≤8 and >8 years of age who may require the drug for anthrax or other, more common, severe childhood infections [5]. Further, the study aimed to change current dosing information in all doxycycline labels from pounds to kilograms to improve consistency between doxycycline labels and other medication labels. Current best practice guidelines recommend the exclusive use of metric units to decrease medication dosing errors [6].

## 7.5 Potential Risks

The NICHD-2011-POP01 protocol involves biological sample collection from children receiving drugs per SOC as prescribed by the treating caregiver. The prescribing of drugs to children is not a part of the NICHD-2011-POP01 protocol. This principle was expected to minimize risk, while providing an expanded enrollment net and maximizing study efficiency. There are small risks to blood sampling, which commonly include some pain/discomfort with the blood stick. Every effort is made to avoid additional sticks (beyond those occurring per SOC) by coordinating timed samples with clinical blood draws when possible and using existing intravenous (IV) lines when feasible. Blood samples are not to exceed 10 samples in a 90-day period, and no more than 3 blood draws performed for study purposes collected at different times from routine clinical blood draws are permitted to occur within 24 hours.

The NICHD has appointed a Data Monitoring Committee (DMC) for the BPCA to provide independent safety and data reviews. The DMC reviews protocols and protocol amendments, ICFs, Serious Adverse Events (SAEs), and data and safety reports for BPCA protocols, including NICHD-2011-POP01.

## 7.6 Data Sources

This CSR presents doxycycline data from NICHD-2011-POP01. For doxycycline enrollments and other anti-infective DOIs included in this opportunistic study, NICHD-2011-POP01 was conducted under IND 113,645. Results for doxycycline are being reported under a new IND to facilitate FDA consideration of potential label changes for this DOI.

The first doxycycline participant was enrolled in NICHD-2011-POP01 on March 12, 2012, and study completion for the last doxycycline participant that was included in the PK analysis was on February 2, 2016. Participants included in the PK analysis were enrolled under protocol versions 1.0, 2.0, 3.0, 4.0 and 5.0 (Appendix 16.1.1). Study methodology described in Section 9 reflects version 5.0 of the protocol. Data were frozen for this analysis on May 11, 2016.

## 7.7 Structure for this Clinical Study Report

Sections 8, 9 and 10 of this report cover the investigational plan and study population for NICHD-2011-POP01 and doxycycline enrollments within the study. The investigational plan is presented in Section 9. Participant disposition is presented under Section 10. Section 11 presents the PK analysis of data. Section 12 includes safety data and analysis.