# 6 INVESTIGATORS AND STUDY ADMINISTRATIVE STRUCTURE

This clinical study report (CSR) includes data from a study that was sponsored by the National Institute of Child Health and Human Development (NICHD) as part of the Best Pharmaceuticals for Children Act (BPCA).

## 6.1 Principal Investigators

The NICHD-2011-POP01 study enrolled participants receiving SOC treatment with doxycycline at 15 sites in the United States, and 14 sites enrolled participants that were included in the PK analysis population. A list of investigators is provided in Appendix 16.1.4.

## 6.2 Administrative Structure

The following is a list of organizations that were critical to the conduct of the NICHD-2011-POP01 study:

IND SPONSOR: | Danny Benjamin, MD, MPH, PhD; Kiser-Arena Distinguished Professor; Duke University, Dept. of Pediatrics; Duke Clinical Research Institute; 2400 Pratt Street; Durham, NC 27715; ▬
PRINCIPAL INVESTIGATORS: | Chiara Melloni, MD, MHS; Assistant Professor of Medicine; Duke Clinical Research Institute; 2400 Pratt Street; Durham, NC 27715; ▬; Michael Cohen-Wolkowiez, MD, PhD; Associate Professor, Department of Pediatrics; Director, Pharmacometrics Center; Duke Clinical Research Institute; 2400 Pratt Street; Durham, NC 27715; ▬
FUNDING SPONSOR | David Siegel, MD; National Institutes of Health (NIH); National Institute of Child Health & Human Development (NICHD); 6710B Rockledge Dr ▬; Bethesda, MD 20892; ▬
CONTRACT RESEARCH ORGANIZATION; Project Management, Data Management, Statistical Analysis, Programming, and Medical Writing | The Emmes Corporation; 401 N. Washington Street, ▬; Rockville, MD 20850; ▬; PI: ▬; Project Director: ▬
MEDICAL MONITOR | ▬; Chief Medical Office; The Emmes Corporation; 401 N. Washington Street, ▬; Rockville, MD 20850; ▬
BIOANALYTICAL LABORATORY; Pharmacokinetic Assays | Optimized Analytical Solutions (OpAns); 4134 S. Alston Avenue, ▬; Durham, NC 27713; ▬
PHARMACOKINETIC ANALYST | ▬; Duke Clinical Research Institute; 2400 Pratt Street Durham, NC 27715; ▬