# 15 REFERENCE LIST

1 US National Institutes of Health. Best Pharmaceuticals for Children Act (BPCA) priority list of needs in pediatric therapeutics [2015]. https://bpca.nichd.nih.gov/prioritization/status/Documents/Priority_List_073115.pdf. Accessed November 1, 2016.
2 Mukkada S, Buckingham SC. Recognition of and prompt treatment for tick-borne infections in children. Infect Dis Clin North Am. 2015;29(3):539–555.26188606
3 Regan JJ, Traeger MS, Humpherys D, . Risk factors for fatal outcome from Rocky Mountain spotted fever in a highly endemic area-Arizona, 2002-2011. Clin Infect Dis. 2015;60(11):1659–1666.25697742
4 Zientek J, Dahlgren FS, McQuiston JH, Regan J. Self-reported treatment practices by healthcare providers could lead to death from Rocky Mountain spotted fever. J Pediatr. 2014;164(2):416–418.24252781
5 Viergever RF, Rademaker CMA, Ghersi D. Pharmacokinetic research in children: an analysis of registered records of clinical trials. BMJ Open. 2011;1(1):e000221.
6 Institute for Safe Medication Practices. 2016-2017 Targeted Medication Safety Best Practices for Hospitals. http://www.ismp.org/tools/bestpractices/TMSBP-for-Hospitals.pdf. Accessed June 25, 2016.
7 Agwuh KN, MacGowan A. Pharmacokinetics and pharmacodynamics of the tetracyclines including glycylcyclines. J Antimicrob Chemother. 2006;58(2):256–265.16816396
8 Newton PN, Chaulet JF, Brockman A, . Pharmacokinetics of oral doxycycline during combination treatment of severe falciparum malaria. Antimicrob Agents Chemother. 2005;49(4):1622–1625.15793155
9 Chen N, Aleksa K, Woodland C, Rieder M, Koren G. Ontogeny of drug elimination by the human kidney. Pediatr Nephrol. 2006;21(2):160–168.16331517
10 Hayton WL. Maturation and growth of renal function: dosing renally cleared drugs in children. AAPS PharmSci. 2000;2(1):E3.11741219
11 Edginton AN, Schmitt W, Voith B, Willmann S. A mechanistic approach for the scaling of clearance in children. Clin Pharmacokinet. 2006;45(7):683–704.16802850
12 Todd SR, Dahlgren FS, Traeger MS, . No visible dental staining in children treated with doxycycline for suspected Rocky Mountain Spotted Fever. J Pediatr. 2015;166(5):1246–1251.25794784