# 14 TABLES, FIGURES, AND GRAPHS REFERRED TO BUT NOT INCLUDED IN THE TEXT

Additional tables, figures, and listings are provided with the PK Analysis (Appendix 16.4.1).