# 5 ETHICS

## 5.1 Institutional Review Board (IRB)

Institutional Review Board (IRB) approval of the protocol, informed consent, and participant information and/or advertising, as relevant, was obtained prior to the collection of any data from a study site. Amendments to the protocol received IRB approval prior to implementation of any changes made to the study design. Detailed IRB information is provided in Appendix 16.1.3.

## 5.2 Ethical Conduct of the Study

This study was conducted in accordance with the ethical principles originating from the Declaration of Helsinki and current Good Clinical Practice (GCP), and in compliance with federal, state and local regulatory requirements and 21 CFR Part 50; 21 CFR Part 56; and 21 CFR Part 312.

## 5.3 Participant Information, Consent, and Assent

All participants in this study were under 21 years of age at enrollment. The investigator or designated representative explained the nature of the study to the participant and/or the participant’s parents or legal guardian, as applicable, to the extent compatible with the participant’s understanding, and answered all questions regarding this study. Prior to any study-related procedures being performed on the participant, the informed consent (parental permission) statement was signed and dated by the participant or the participant’s parent or legal guardian, as applicable, and by the person who administered the informed consent. The participant gave assent when appropriate. A copy of the signed informed consent form (ICF) was given to the participant, or the participant’s parent or legal guardian, and the original was placed in the study record. An entry was also made in the participant’s source documents to confirm that informed consent was obtained prior to any study-related procedures and that the participant, or the participant’s parent or legal guardian, received a signed copy. In addition, the Health Insurance Portability and Accountability Act (HIPAA) statement was reviewed, signed, and dated by the participant’s parent or legal guardian as a part of the ICF or as a separate form. A sample ICF is provided in Appendix 16.1.3.