# 16 APPENDICES

16.1 Study Information
  16.1.1 Protocol and Protocol Amendments
  16.1.2 Sample Case Report Form
  16.1.3 Institutional Review Boards (IRBs) Information and Sample Consent Forms
  16.1.4 Description of Investigators
  16.1.5 Signature Pages
  16.1.6 Listing of Lot Numbers by Participant
  16.1.7 Randomization Scheme and Codes
  16.1.8 Audit Certificates
  16.1.9 Statistical Analysis Plan
  16.1.10 Inter-laboratory Standardization Methods and Quality Assurance Procedures
  16.1.11 Publications Based on the Study
  16.1.12 Important Publications Referenced in the Report
16.2 Participant Data Listings
  16.2.1 Disposition and Eligibility
  16.2.2 Informed Consent/Assent and HIPAA Authorization
  16.2.3 Demographic and Baseline Characteristics
  16.2.4 Deaths During Study Period
  16.2.5 Participant-Specific Protocol Deviations
  16.2.6 Site-Specific Protocol Deviations
  16.2.7 Tooth Discoloration after Doxycycline Treatment
16.3 Case Report Forms for SAEs and Withdrawals Due to Adverse Events
16.4 PK Analysis
  16.4.1 PK Report
  16.4.2 PK Datasets in XPT format
  16.4.3 PK-Define.pdf
  16.4.4 NONMEM Model Codes, Control Streams, and Output Listings
  16.4.5 Assay Validation Report
  16.4.6 Bioanalytical Study Report
16.5 NICHD-2011-POP01 Doxycycline Datasets and Define.pdf
  16.5.1 Datasets in XPT format
  16.5.2 Define.pdf

For documents listed but not available for download, please check the DASH repository at https://dash.nichd.nih.gov/study/19016