# 3 GLOSSARY OF ABBREVIATIONS AND TERMS

ALB: Albumin
AUC_0-τ_: Area Under the Concentration vs. Time Curve – Over a Dose Interval
AUC_0-∞_: Area Under the Concentration vs. Time Curve – From Time 0 to Infinity
BPCA: Best Pharmaceuticals for Children Act
BPCA-CC: BPCA Coordinating Center, Premier Research Group
BPCA DCC: BPCA Data Coordinating Center, The EMMES Corporation
BUN: Blood Urea Nitrogen
C: Drug Concentration
CBC: Complete Blood Count
C_L_: Clearance
C_max_: Maximum Concentration
CONS: Coagulase Negative Staphylococcus
CRA: Clinical Research Associate
CRF: Case Report Form
DCRI: Duke Clinical Research Institute
DSMB: Data and Safety Monitoring Board
DOL: Day of Life
ELBW: Extremely Low Birth Weight
ESBL: Extended Spectrum Beta-lactamases
FDA: Food and Drug Administration
g/dL: Grams per Deciliter
GA: Gestational Age
GCP: Good Clinical Practice
GNR: Gram Negative Rod
HIPAA: Health Insurance Portability and Accountability Act
ICF: Informed Consent Form
ICU: Intensive Care Unit
IEC: Independent Ethics Committee
IRB: Institutional Review Board
IVH: Intraventricular Hemorrhage
IVRS: Interactive Voice Responsive System
K_e_: Elimination Rate Constant
Kg: Kilogram
LFT: Liver Function Tests
Mcg: Microgram
Mg: Milligrams
MIC: Minimum Inhibitory Concentration
mL: Milliliter
MPODS: Meropenem Off-Patent Drug Studies
MRSA: Methicillin Resistant Staphylococcus aureus
NEC: Necrotizing Enterocolitis
NICHD: National Institute for Child Health and Human Development
PCA: Post-Conception Age
PD: Pharmacodynamic
PI: Principal Investigator
PK: Pharmacokinetic
PNA: Postnatal Age
PODS: Pediatric Off-Patent Drug Studies
SAE: Serious Adverse Event
SCR: Serum Creatinine
SNAP: Score for Neonatal Acute Physiology
TEAE: Treatment Emergent Adverse Event
T_1/2_: Half-life
Tmax: Time of Maximum Concentration
Vd: Volume of Distribution
WR: Written Request