# 12 SAFETY EVALUATION

## 12.1 Extent of Exposure

The extent of exposure to study medication is summarized along with PK results in Section 11.4.4.1. Listings of study drug administration for individual participants are provided in Section 16, Listing 16.2.9.2.

## 12.2 Adverse Events and Tolerability

AEs were recorded from the time of informed consent until 72 hours following the last dose of study drug for non SAEs and until 30 days after the last dose of study drug for SAEs. Any AE that occurred between the time informed consent was obtained and the initial dose of study drug and was considered related to a protocol specified procedure and was required to be reported. AEs that increased in severity were counted as new AEs.

### 12.2.1 Summary of Treatment Emergent Adverse Events

An overall summary of tolerability is shown in Table 12.1. Overall, there were 316 AEs reported in 99 of the 200 safety participants (49.5%) during the study. The participants in the GA <32 weeks and PNA <2 weeks had an AE rate of 66.7% (26 of 39 participants). AE rates in other groups were 45.6%, 41.9% and 48.1% for the GA <32 weeks/PNA ≥2 weeks, GA ≥32 weeks/PNA <2 weeks and GA ≥32 weeks/PNA ≥2 weeks groups, respectively.

The maximum severity of any TEAE was mild for 24 participants (12.0%); moderate for 44 participants (22.0%); and severe for 31 participants (15.5%). Twenty-one participants (10.5%) experienced a TEAE that was considered to be possibly related to study meropenem, while no participants experienced a TEAE that was considered to be probably or definitely related to study meropenem.

Table 12.1 Overall Summary of Tolerability

| GA <32 weeks | | GA ≥32 weeks | | Total
| PNA <2 weeks | PNA ≥2 weeks | PNA <2 weeks | PNA ≥2 weeks | Total
Safety population | 39 | 103 | 31 | 27 | 200
Number of Participants with at Least One TEAE | 26 (66.7%) | 47 (45.6%) | 13 (41.9%) | 13 (48.1%) | 99 (49.5%)
Participants with at Least One TEAE by Severity^1^
Mild | 5 (12.8%) | 10 (9.7%) | 6 (19.4%) | 3 (11.1%) | 24 (12.0%)
Moderate | 13 (33.3%) | 21 (20.4%) | 6 (19.4%) | 4 (14.8%) | 44 (22.0%)
Severe | 8 (20.5%) | 16 (15.5%) | 1 (3.2%) | 6 (22.2%) | 31 (15.5%)
Participants with at Least One TEAE by Causality^2^
Unrelated | 19 (48.7%) | 37 (35.9%) | 12 (38.7%) | 10 (37.0%) | 78 (39.0%)
Possibly | 7 (17.9%) | 10 (9.7%) | 1 (3.2%) | 3 (11.1%) | 21 (10.5%)

1 Participants are counted only once at the greatest severity. TEAE with missing severity will be considered as severe.

2 Participants are counted only once at the strongest relationship to study drug (causality). TEAE with missing causality will be considered as definitely related to study drug.

AEs of special interest included seizures and Level II laboratory AEs. These were experienced by a total of 17 participants (8.5%). Serious AEs were seen in 34 (17.0%) participants. A total of 6 participants (3.0%) had a TEAE that lead to study drug discontinuation. There were 11 (5.5%) deaths reported during the study (Table 12.2).

Table 12.2 Summary of Special Interest Adverse Events, Deaths and Drug Discontinuation Due to Adverse Events

| GA <32 weeks | | GA ≥32 weeks | | Total
| PNA <2 weeks | PNA ≥2 weeks | PNA <2 weeks | PNA ≥2 weeks | Total
Safety population | 39 | 103 | 31 | 27 | 200
Number of Participants with Special Interest AEs
Seizure | 4 (10.3%) | 3 (2.9%) | 1 (3.2%) | 2 (7.4%) | 10 (5.0%)
Level II AE | 2 (5.1%) | 7 (6.8%) | 0 | 0 | 9 (4.5%)
Number of Participants with SAE | 9 (23.1%) | 18 (17.5%) | 2 (6.5%) | 5 (18.5%) | 34 (17.0%)
Death | 3 (7.7%) | 8 (7.8%) | 0 | 0 | 11 (5.5%)
Participants with AE that Led to Study Drug Discontinuation | 1 (2.6%) | 3 (2.9%) | 0 | 2 (7.4%) | 6 (3.0%)

### 12.2.2 Display of Treatment Emergent Adverse Events and Critical or Near Critical Incidents

Treatment-emergent AEs and SAE data are presented in the following tables:

- Overall Summary of TEAEs by gestational and post-natal age group in Section 14, Table 14.3.1.1
- Summary of TEAEs by gestational and post-natal age group, MedDRA System Organ Class, and Preferred Term in Section 14, Table 14.3.1.2
- Summary of TEAEs by gestational and post-natal age group, MedDRA System Organ Class, Preferred Term, and the greatest severity in Section 14, Table 14.3.1.3
- Summary of TEAEs by gestational and post-natal age group, MedDRA System Organ Class, Preferred Term, and the strongest relationship to study drug in Section 14, Table 14.3.1.4
- Summary of Level 2 Laboratory Adverse Events by Gestational, Postnatal Age Stratum, MedDRA System Organ class and preferred term in Section 14, Table 14.3.1.5.
- Summary of adverse events of Special Interest by gestational and post-natal age group, MedDRA System Organ Class, and Preferred Term in Section 14, Table 14.3.2.1
- Summary of Adverse Events of Seizures by gestational and post-natal age group, MedDRA System Organ Class, and Preferred Term in Section 14, Table 14.3.2.2
- Summary of SAEs by gestational and post-natal age group, MedDRA System Organ Class, and Preferred Term in Section 14, Table 14.3.2.3
- Summary of TEAEs Leading to study drug discontinuation by gestational and post-natal age group, MedDRA System Organ Class, and Preferred Term in Section 14, Table 14.3.2.4
- Summary of TEAEs resulting death by gestational and post-natal age group, MedDRA System Organ Class, and Preferred Term in Section 14, Table 14.3.2.5
- Analysis of key safety endpoints in Section 14, Table 14.3.2.6
- Analysis of seizures in Section 14, Table 14.3.2.7

Individual patient data associated with TEAEs are listed in Section 16 as follows:

- All AEs (Listing 16.2.10.1)
- AEs of special interest (Listing 16.2.10.2)
- All SAEs (Listing 16.2.10.3)
- All AEs leading to study discontinuation (Listing 16.2.10.4)
- AEs resulting in death (Listing 16.2.10.5)
- Seizure Activity (Listing 16.2.10.6)

### 12.2.3 Analysis of Adverse Events

#### 12.2.3.1 Most Frequently Reported Treatment-Emergent Adverse Events

The most frequently reported AEs were sepsis (12 participants, 6%) and convulsion (10 participants, 5%) (see Table 12.3). All other TEAEs occurred in <5% of the total safety population.

In the GA <32 week/PNA <2 weeks group 12.8% of the participants developed sepsis, 12.8% had bilirubin conjugated increased and 10.3% developed convulsions. 12.9% of the participants in the GA ≥32 week/PNA <2 weeks group had vomiting and 11.1% of the participants in the GA ≥32 week/PNA ≥2 weeks group had atelectasis.

Table 12.3 Most Frequently Occurring (≥5 Participants) Treatment-Emergent Adverse Events

| GA <32 weeks | | GA ≥32 weeks | | Total
| PNA <2 weeks | PNA ≥2 weeks | PNA <2 weeks | PNA ≥2 weeks | Total
Safety population | 39 | 103 | 31 | 27 | 200
Number of Participants with at Least One TEAE | 26 (66.7%) | 47 (45.6%) | 13 (41.9%) | 13 (48.1%) | 99 (49.5%)
Congenital, familial and genetic disorders
Patent ductus arteriosus | 4 (10.3%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 6 (3.0%)
Eye disorders
Retinopathy of prematurity | 0 (0.0%) | 5 (4.9%) | 0 (0.0%) | 0 (0.0%) | 5 (2.5%)
Gastrointestinal disorders
Vomiting | 0 (0.0%) | 1 (1.0%) | 4 (12.9%) | 0 (0.0%) | 5 (2.5%)
Infections and infestations
Sepsis | 5 (12.8%) | 5 (4.9%) | 1 (3.2%) | 1 (3.7%) | 12 (6.0%)
Investigations
Aspartate aminotransferase increased | 0 (0.0%) | 3 (2.9%) | 0 (0.0%) | 2 (7.4%) | 5 (2.5%)
Bilirubin conjugated increased | 5 (12.8%) | 3 (2.9%) | 0 (0.0%) | 1 (3.7%) | 9 (4.5%)
Metabolism and nutrition disorders
Hyperglycemia | 2 (5.1%) | 2 (1.9%) | 1 (3.2%) | 0 (0.0%) | 5 (2.5%)
Hypoglycemia | 3 (7.7%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 5 (2.5%)
Hypokalemia | 2 (5.1%) | 6 (5.8%) | 0 (0.0%) | 1 (3.7%) | 9 (4.5%)
Nervous system disorders
Convulsion | 4 (10.3%) | 3 (2.9%) | 1 (3.2%) | 2 (7.4%) | 10 (5.0%)
Respiratory, thoracic and mediastinal disorders
Atelectasis | 2 (5.1%) | 0 (0.0%) | 0 (0.0%) | 3 (11.1%) | 5 (2.5%)
Vascular disorders
Hypotension | 1 (2.6%) | 5 (4.9%) | 0 (0.0%) | 0 (0.0%) | 6 (3.0%)

#### 12.2.3.2 Treatment-Emergent Adverse Events by Intensity

There were 36 SAEs in 34 participants. These SAEs include 4 participants with intestinal perforation, 4 with multi-organ failure, 3 with necrotizing colitis and 3 participants with sepsis. The GA ≥32 weeks, PNA <2 weeks group had only one severe AE reported.

There were 44 (22.0%) participants with moderate AEs and 24 (12.0%) participants that had AE with a maximum severity of mild.

#### 12.2.3.3 Treatment-Emergent Adverse Events by Relationship

No AEs were considered to be probably or definitely related to meropenem. There were 30 AEs in 21 participants that were considered “possibly” related to study drug. These include 7 seizures, 4 increased conjugated bilirubin and 2 each of hypotension and sepsis. These events occurred in 7 (17.9%) participants in the GA <32 week/PNA <2 weeks group, 10 (9.7%) in the GA <32 week/PNA ≥2 weeks group. The GA ≥32 weeks category had 1 (3.2%) with a “possibly” related AE in the PNA <2 weeks group and 3 (11.1%) in the PNA ≥2 weeks group.

### 12.2.4 Listing of Adverse Events by Participant

A complete listing of all AEs is provided in Section 16, Listing 16.2.10.1.

## 12.3 Deaths, Other Serious Adverse Events, and Adverse Events of Special Interest

### 12.3.1 Deaths

There were 11 deaths in this population, a complete listing is provided in Listing 16.2.10.5. All deaths have occurred in the GA <32 weeks group: 3 of 39 (7.7%) in the PNA <2 weeks group and 8 of 103 (7.8%) in the PNA ≥2 weeks group. Two of the PNA <2 weeks participants died of multi-organ failure and one died from subarachnoid hemorrhage. In the PNA ≥2 weeks group, of the 8 deaths, 2 had multi-organ failure, and 1 each died of pulmonary hemorrhage, intestinal perforation, congenital diaphragmatic hernia, respiratory failure, meningitis and bacterial sepsis. None of the deaths were considered related to study medication.

### 12.3.2 Serious Adverse Events

34/200 (17.0%) of the participants had at least 1 SAE (2 of these participants have had 2 SAEs). The GA <32 weeks/PNA <2 weeks group had 9/39 (23.1%) of the participants reporting an SAE. These SAEs included the deaths described above as well as 5 GI disorders, 1 bradycardia, 1 sepsis and 1 respiratory arrest. One event (GI disorder: ileal bowel perforation isolated) was possibly related to study drug. The GA <32 weeks/PNA ≥2 weeks group had 18/103 (17.5%) participants with an SAE which included the 8 deaths described above and 4 GI disorders, 4 infections, 1 wound dehiscence and 1 retinopathy of prematurity. One infection (fungal sepsis) was reported to be possibly related to study drug. The GA ≥32 weeks group had 7/58 participants with SAEs (2/31 in the PNA <2 weeks and 5/27 participants, (total of 6 SAEs in the ≥32 weeks group). These SAEs included 3 GI disorders, 3 respiratory, thoracic and mediastinal disorders, an abnormal chest x-ray and patent ductus arteriosus. None were related to study medication.

### 12.3.3 Adverse Events of Special Interest

AEs of special interest included level 2 laboratory AEs (refer to Table 12.3) not otherwise explained by the participant’s underlying illness and seizures judged not otherwise explained by the participant’s underlying illnesses (including IVH, meningitis, electrolyte abnormality, genetic/metabolic disorder, drug withdrawal, hypoxia-ischemia, cerebral anomalies).

Laboratory AEs of Special Interest

Laboratory Value | Level II
Direct bilirubin | >5 mg/dL
Indirect bilirubin | >15 if <36 weeks adjusted GA; >20 if >36 weeks adjusted GA
AST | Increase 10* (baseline)
ALT | Increase 10* (baseline)
Creatinine | >2.5 mg/dL

#### 12.3.3.1 Level II AEs

All level II AEs are listed in Table 14.3.1.5 and Listing 16.2.10.2. There were 9 (4.5%) participants with level II laboratory AEs. All of these AEs occurred in the GA <32 weeks groups. There were 5 increases in conjugated bilirubin, 3 increases in serum creatinine and 1 increase in AST.

#### 12.3.3.2 Seizures

Seizure or seizure-like activity was reported in 10 (5.0%) participants. Four of 39 (10.3%) participants had seizures in the GA <32 weeks/PNA <2 weeks group; 3 of 103 (2.9%) in the GA <32 weeks/PNA ≥2 weeks group; one of 31(3.2%) in the GA ≥32 weeks/PNA <2 weeks group and 2 of 27 (7.4%) in the GA ≥32 weeks/PNA ≥2 weeks group. Upon central review, one participant was not considered to have a seizure and one seizure was identified as occurring prior to enrollment, these seizures are not included in this analysis. All ten of these seizures have been locally diagnosed clinical seizures, two were also locally diagnosed and EEG confirmed seizure. Central review confirmed the 10 as clinical seizures and 2 as EEG confirmed seizure. Five participants had negative EEGs for seizure and 3 participants did not have EEGs completed. There were no statistical differences in rates among the GA/PNA groups.

### 12.3.4 Analysis of Key Safety Endpoints

The results of the key safety endpoints are summarized in Table 12.4. These results are shown by GA/PNA group in Section 14, Table 14.3.2.6.

#### Deaths

Eleven (5.5%) of the participants died, this is lower than expected rate of 20%. Note that all of the deaths occurred in the premature participants.

#### Seizures

Seizures are described above in Section 12.3.3.2. The observed seizure rate of 5.0% is higher than the expected seizure rate of 2.0%.

#### Strictures

There were no strictures reported in this population.

#### Perforations

The observed rate of 2.0% perforations is not significantly (statistically) different from the expected rate of 5.0%. All 4 of the perforations were reported in the premature participants.

#### Wound Dehiscence

There were 4 reported cases of wound dehiscence, one in each GA/PNA group. The observed rate of 2.0% is not different from the expected rate of 2.0%.

#### Short Gut

There were no reported cases of short gut in this study.

#### Development of ESBL Infection

The proportion of infants with ESBL infections was not reported in this study as only one participant developed an infection (blood culture) with an ESBL producing Serratia marcescens, and antibiotic sensitivities were not reported for this isolate.

#### Development of Candidiasis

A participant was considered to have developed candidiasis if an AE was reported specifying fungal encephalitis, fungal infection or fungal sepsis or if the participant reported a strain of Candida in a culture from sterile body fluids anytime from the start of study medication until 30 days after the last dose of study medication. Eight (4.0%) of the participants were positive for candidiasis, this is below the expected rate of 10%. All reported cases of candidiasis occurred in premature infants.

#### Antimicrobial Therapy Failure

Antimicrobial therapy failure is defined as a change in antibiotic therapy while on study drug, with the exception of the addition of Gram positive therapy to treat infections caused by Staphylococcus species. Gram positive therapy was defined as the addition of vancomycin, rifampin, or linezolid to treat a participant that has a concurrent positive Staphylococcus (any species) culture from sterile body fluids. Twenty three (11.5%) participants started new antibiotic therapy while on study meropenem, without a concurrent Staphylococcus infection. This rate is below the expected rate of 45%.

Table 12.4 Key Safety Endpoints

Safety Endpoint | Expected Proportion (%) | Observed Proportion N (%) | Observed Proportion 95% exact CI
Death | 20% | 11 (5.5%) | (2.8, 9.6)
Seizures | 2% | 10 (5.0%) | (2.4, 9.0)
Strictures | 2% | 0 (0%) | --
Perforation | 5% | 4 (2.0%) | (0.6 – 5.0)
Wound Dehiscence | 2% | 4 (2.0%) | (0.6 – 5.0)
Short Gut | 5% | 0 (0%) | --
Development of ESBL Infection | 2% | -- | --
Development of Candidiasis | 10% | 8 (4.0%) | (1.7 – 7.7)
Antimicrobial Therapy Failure | 45% | 23 (11.5%) | (7.4 – 16.8)

### 12.3.5 Narratives of Deaths, Other Serious Adverse Events, and Other Significant Adverse Events

Narratives of deaths, other SAEs and other significant AEs are provided in Section 14.3.3.

## 12.4 Clinical Laboratory Evaluations

Descriptive summaries (mean, standard deviation (SD), 95% confidence interval (CI) of mean, median, minimum, and maximum) of observed values and changes from baseline values are presented for chemistry and hematology clinical laboratory values by gestational and postnatal group. Tables 14.3.4.1 and 14.3.4.6 show for observed values while Tables 14.3.4.2 and 14.3.4.7 show changes from baseline. Baseline is defined as the assessment taken at pre-dose. Many clinical laboratory assessments were not performed in a large percent of participants as they were not obtained as part of the infants’ standard of care.

### Creatinine

Mean (± SE) creatinine level was 0.94 ± 0.06 mg/dL at baseline in the GA <32 week, PNA <2 week group. Creatinine decreased to 0.58 ± 0.07 (mean ± SE) at day 22-28 in this group. At baseline 183 participants had a creatinine assessment, 11 (6.0%) were abnormal, clinically significant. On day 22-28, 54 participants had creatinine assessment with none considered abnormal, clinically significant (see Figure 12.1).

Figure 12.1 Creatinine Levels

### AST

AST levels were available in 60 participants at baseline, 3 of these measurements (5.0%) were abnormal, clinically significant. One participant in the GA <32 weeks/PNA ≥2 week group had a value of 3358 which dropped to within normal limits by day 1-7. Mean (±SE) for all participants was 72.6 ± 12.8 U/L at baseline (excluding the 3358 measurement) and 56.2 ± 7.9, 54.9 ± 7.1, 83.7 ± 14.6 and 99.1 ± 26.4 at day 1-7, day 8-14, day 15-21 and day 22-28, respectively (see Figure 12.2). Infants with necrotizing enterocolitis or suspected necrotizing enterocolitis are frequently maintained on total parenteral nutrition while oral feedings are held. Total parenteral nutrition is associated with increased AST levels.^24^

Figure 12.2 AST Levels

### ALT

At baseline, the GA <32 weeks groups had ALT means ± SE of 17.8 ± 11.3 U/L (n=6) and 30.9 ± 5.5 (n=31) for the PNA <2 week and PNA ≥2 weeks groups. The GA ≥32 weeks groups had ALT of 184.9 ± 130.6 (n=7) and 100.4 ± 44.3 (n=16) for the PNA <2 week and PNA ≥2 weeks groups, respectively. At study day 22-28 mean ALT values were similar with a mean ± SE of 46.5 ± 8.3 (n=30). 6.7% (n=4) of the participants at baseline and 6.7% (n=2) of the participants at day 22-28 were abnormal, clinically significant (see Figure 12.3). Infants with necrotizing enterocolitis or suspected necrotizing enterocolitis are frequently maintained on total parenteral nutrition while oral feedings are held. Total parenteral nutrition is associated with increased ALT levels.^24^

Figure 12.3 ALT Levels

### Alkaline Phosphatase

Alkaline phosphatase measurements were available on 64 participants at baseline: 17.1% (11/64) were abnormal, clinically significant with a mean ± SE of 347.1 ± 33.7 U/L. At study day 22-28 there were 28 participants with an alkaline phosphatase measurement: 25.0% were abnormal, clinically significant with a mean of 500.3 ± 45.2 U/L (see Figure 12.4). In general, alkaline phosphatase levels increased for all age groups during the course of the study. Alkaline phosphatase levels have previously been shown to increase over the 1^st^ months of life in premature infants.^25^

Figure 12.4 Alkaline Phosphatase Levels

### Direct Bilirubin

Direct bilirubin measurements were available in 71 participants at baseline. Levels in the GA <32 weeks/PNA <2 week group increased over the course of the study from a mean of 1.03 ± 0.38 mg/dL in 17 participants at baseline to a mean of 3.46 ± 0.64 mg/dL in 5 patients at day 22-28. Abnormal, clinically significant values in all participants increased from 22.5% (16/71) at baseline to 57.1% (8/14) at day 22-28 (see Figure 12.5). Infants with necrotizing enterocolitis or suspected necrotizing enterocolitis are frequently maintained on total parenteral nutrition while oral feedings are held. Total parenteral nutrition is associated with increased direct bilirubin levels.^24,26^

Figure 12.5 Direct Bilirubin Levels

## 12.5 Vital Signs, Physical Examinations, and Other Observations Related to Safety

### Vital Signs

Heart rate, respiration rate, systolic blood pressure and diastolic blood pressure are presented in Table 14.3.4.12, and change from baseline to end-of-study values are shown in Table 14.3.4.13. Median heart rate was 154 bpm at baseline and increased a median of 2 bpm over the course of the study. Participants in the GA <32 weeks/PNA <2 weeks group increased by a median of 4 bpm, the participants GA <32 weeks/PNA ≥2 weeks group increased a median of 1 bpm, participants in the GA ≥32 weeks increased a median of 13 bpm in the PNA <2 weeks group and decreased a median of 4 bmp in the PNA ≥2 weeks group.

The median respiration rate for participants in the study was 45 rpm at baseline. Respiration is dependent on the type of ventilation. The table below describes the type of ventilation used in the participants at baseline and at the end-of-study. Forty-nine percent of the participants were ventilator-supported at baseline compared to 23% at the end-of-study visit. High frequency ventilation with extreme values (<4 or >120) were removed from the tables.

Ventilation Type
| Baseline Visit N (%) | End-of-Study Visit N (%)
Spontaneous | 60 (33.3%) | 111 (60.3%)
Ventilator-supported | 89 (49.4%) | 43 (23.4%)
NCPAP | 9 (5.0%) | 18 (9.8%)
High Frequency | 18 (10.0%) | 7 (3.8%)
Missing | 4 (2.2%) | 5 (2.7%)
Total with RR | 180 (100.0%) | 184 (100.0%)

Systolic blood pressure is lower in the GA <32 weeks groups, median of 55.5 mmHg in PNA <2 weeks and 65.0 mmHg in the PNA ≥2 weeks group than in the GA ≥32 weeks group with median SBP of 71.5 mmHG in the PNA <2 week group and 78.0 in the PNA ≥2 weeks group at baseline. Change in systolic blood pressure during the study was highest in the GA <32 weeks/PNA <2 weeks group with an increase of 13 mmHg. Diastolic blood pressure showed a similar distribution with a median of 35 and 38 mmHG in the GA <32 weeks groups (PNA <2 weeks and PNA ≥2 weeks, respectively) at baseline and a median of 42 and 43 mmHg in the GA ≥32 weeks groups (PNA <2 weeks and PNA ≥2 weeks, respectively). Diastolic blood pressure increased a median of 3 mmHg during the study.

### Growth Parameters

Growth parameters are presented in Tables 14.3.4.10 and 14.3.4.11. Participants gained a median of 417 g over the course of the study from a median of 1508 g at baseline to a median of 2150 g at the 22-28 day visit. The participants in the GA <32 weeks/PNA <2 weeks group gained a median of 335 g, the participants GA <32 weeks/PNA ≥2 weeks group gained a median of 494 g, participants in the GA ≥32 weeks gained a median of 265 g in the PNA <2 weeks group and a median of 417 g in the PNA ≥2 weeks group.

The infants grew a median of 3 cm during the study. The median length at baseline was 39.5 cm and the median length at the 22-28 day visit was 44 cm. The median changes were 3.5 cm, 3.6 cm, 2.0 cm and 3.0 cm for the GA <32 weeks/PNA <2 weeks, GA <32 weeks/PNA ≥2 weeks, GA ≥32 weeks/PNA <2 weeks and GA ≥32 weeks/PNA ≥2 weeks groups, respectively.

### Concomitant Medications

Concomitant medications were taken by 98% of the participants during the course of the study. The most commonly used medication was vancomycin (53%) followed by gentamicin (50.5%) (Table 12.5). Caffeine citrate was used in 36.5%, the majority of which were the premature infants. Also frequently used were morphine in 35.5%, fentanyl in 35.0% and midazolam in 30.0% of the participants.

Table 12.5 Most Frequently Used (≥10% of the Participants) Concomitant Medication

| GA <32 weeks | | GA ≥32 weeks | | Total
| PNA <2 weeks | PNA ≥2 weeks | PNA <2 weeks | PNA ≥2 weeks | Total
Safety population | 39 | 103 | 31 | 27 | 200
Number of Participants with Concomitant Medication | 39 (100.0%) | 103 (100.0%) | 28 (90.3%) | 26 (96.3%) | 196 (98.0%)
Medication
ACETAMINOPHEN | 1 (2.6%) | 9 (8.7%) | 5 (16.1%) | 8 (29.6%) | 23 (11.5%)
AMPICILLIN | 9 (23.1%) | 17 (16.5%) | 8 (25.8%) | 3 (11.1%) | 37 (18.5%)
CAFFEINE CITRATE | 19 (48.7%) | 52 (50.5%) | 2 (6.5%) | 0 (0.0%) | 73 (36.5%)
CLINDAMYCIN | 6 (15.4%) | 12 (11.7%) | 2 (6.5%) | 0 (0.0%) | 20 (10.0%)
DOPAMINE | 15 (38.5%) | 16 (15.5%) | 4 (12.9%) | 0 (0.0%) | 35 (17.5%)
FENTANYL | 16 (41.0%) | 34 (33.0%) | 11 (35.5%) | 9 (33.3%) | 70 (35.0%)
FLUCONAZOLE | 14 (35.9%) | 28 (27.2%) | 3 (9.7%) | 6 (22.2%) | 51 (25.5%)
FUROSEMIDE | 18 (46.2%) | 59 (57.3%) | 6 (19.4%) | 8 (29.6%) | 91 (45.5%)
GENTAMICIN | 24 (61.5%) | 52 (50.5%) | 13 (41.9%) | 12 (44.4%) | 101 (50.5%)
HEPARIN | 5 (12.8%) | 11 (10.7%) | 2 (6.5%) | 6 (22.2%) | 24 (12.0%)
HYDROCORTISONE | 16 (41.0%) | 25 (24.3%) | 2 (6.5%) | 2 (7.4%) | 45 (22.5%)
LORAZEPAM | 5 (12.8%) | 14 (13.6%) | 4 (12.9%) | 4 (14.8%) | 27 (13.5%)
MIDAZOLAM | 9 (23.1%) | 32 (31.1%) | 9 (29.0%) | 10 (37.0%) | 60 (30.0%)
MORPHINE | 18 (46.2%) | 39 (37.9%) | 7 (22.6%) | 7 (25.9%) | 71 (35.5%)
NYSTATIN | 4 (10.3%) | 10 (9.7%) | 5 (16.1%) | 4 (14.8%) | 23 (11.5%)
RANITIDINE | 4 (10.3%) | 8 (7.8%) | 4 (12.9%) | 4 (14.8%) | 20 (10.0%)
VANCOMYCIN | 22 (56.4%) | 64 (62.1%) | 7 (22.6%) | 13 (48.1%) | 106 (53.0%)

## 12.6 Safety Conclusions

Meropenem was well tolerated in this open-label study of 200 infants. This cohort represented a group of critically ill infants with the following conditions at baseline: 88.5% with respiratory illness, 89.5% with gastrointestinal disorders, 73.0% with cardiovascular conditions and 90.5% with blood/lymphatic system problems. The majority of these infants were premature with a median gestational age at birth of 27.8 weeks (22-40).

Overall, 99/200 (49.5%) infants suffered an AE during the study. The proportion of infants with AEs was highest, 26/39 (66.7%), among infants <32 weeks gestational age and <2 weeks postnatal age. Only 21/200 (10.5%) infants were determined to have an AE possibly related to meropenem, and this proportion was highest, 7/39 (17.9%), among infants <32 weeks gestational age and <2 weeks postnatal age. Of the 316 AEs reported, only 30 (9.5%) were determined by the investigators to be possibly related to meropenem. These 30 AEs included 7 seizures and 4 episodes of elevated bilirubin. No AEs were determined to be probably or definitely related to meropenem.

For this study, we defined an AE of special interest as either a seizure or a level II laboratory AE. Nine (4.2%) infants experienced a level II laboratory AE and all were <32 weeks gestational age. These 9 events included: 5 elevated conjugated bilirubin levels, 3 elevated serum creatinine levels, and 1 elevated aspartate aminotransferase concentration. Clinical seizures were reported in 10 (5.0%) infants; however, only 2 cases were confirmed by EEG. Seizures were most commonly reported among infants <32 weeks gestational age and <2 weeks postnatal age, 4/39 (10.3%).

A total of 36 SAEs were reported in 34 (17.0%) infants. SAEs were most commonly reported among infants <32 weeks gestational age and <2 weeks postnatal age, 9/39 (23.1%). Only 2 (5.6%) of the SAEs were determined to be possible related to study drug (isolated ileal perforation and an episode of fungal sepsis). There were 11 (5.5%) deaths in the study population. None of the deaths were determined to be related to study drug. All deaths occurred in infant <32 weeks gestational age.