# 11 EFFICACY EVALUATION

## 11.1 Data Sets Analyzed

The participant populations of safety and efficacy were described above in Section 10. All but five participants are included in both the safety population (n=200) and efficacy population (195 participants; 97.5%).

## 11.2 Demographic and Other Baseline Characteristics

Baseline demographics and disease characteristics are summarized for the Safety Population in Table 11.1 and Section 14, Tables 14.1.3 through 14.1.9.2. These tables include information on participant demographics, medical, surgical, radiographic, physical and medication history. Postnatal age is defined by the first dosing date of study meropenem minus the date of birth. The median postnatal age for the population is 21 days (ranging from 1 day to 92 days), stratified into <2 weeks and ≥2 weeks. The median gestational age for the population was 27.8 weeks (ranging from 22.5 weeks to 40.0 weeks), stratified into <32 weeks and ≥32 weeks. 59% of the participants were male and 65% were of Caucasian descent.

Table 11.1 Demographic Characteristics (Safety Population)

Participant Demographics | GA <32 weeks | | GA ≥32 weeks | | Total
Participant Demographics | PNA <2 weeks | PNA ≥2 weeks | PNA <2 weeks | PNA ≥2 weeks | Total
Safety population | 39 | 103 | 31 | 27 | 200
Gestational age (weeks)
Mean (SD) | 26.3 (2.7) | 26.6 (2.1) | 36.3 (2.4) | 35.5 (2.9) | 29.2 (4.9)
Median | 26.0 | 26.3 | 36.0 | 34.4 | 27.8
Min, Max | 22.5, 31.5 | 23.0, 31.5 | 32.1, 40.0 | 32.0, 40.0 | 22.5, 40.0
Postnatal age (days)
Mean (SD) | 8.5 (3.3) | 38.3 (19.3) | 6.5 (3.5) | 36.0 (22.0) | 27.3 (21.6)
Median | 9.0 | 32.0 | 6.0 | 26.0 | 21.0
Min, Max | 1.0, 13.0 | 14.0, 92.0 | 1.0, 14.0 | 14.0, 82.0 | 1.0, 92.0
Gender
Male | 24 (61.5%) | 56 (54.4%) | 22 (71.0%) | 16 (59.3%) | 118 (59.0%)
Female | 15 (38.5%) | 47 (45.6%) | 9 (29.0%) | 11 (40.7%) | 82 (41.0%)
Ethnicity
Hispanic or Latino | 5 (12.8%) | 16 (15.5%) | 4 (12.9%) | 3 (11.1%) | 28 (14.0%)
Not Hispanic or Latino | 32 (82.1%) | 81 (78.6%) | 27 (87.1%) | 24 (88.9%) | 164 (82.0%)
Not reported | 2 (5.1%) | 6 (5.8%) | 0 | 0 | 8 (4.0%)
Race
Asian | 0 | 1 (1.0%) | 0 | 1 (3.7%) | 2 (1.0%)
Black or African American | 12 (30.8%) | 33 (32.0%) | 8 (25.8%) | 6 (22.2%) | 59 (29.5%)
Native Hawaiian or Pacific Islander | 1 (2.6%) | 0 | 1 (3.2%) | 0 | 2 (1.0%)
White or Caucasian | 26 (66.7%) | 65 (63.1%) | 21 (67.7%) | 18 (66.7%) | 130 (65.0%)
Not reported | 0 | 2 (1.9%) | 1 (3.2%) | 1 (3.7%) | 4 (2.0%)
Other | 1 (2.6%) | 2 (1.9%) | 0 | 2 (7.4%) | 5 (2.5%)

Baseline medical history (Table 14.1.4) shows that 177 (88.5%) participants had respiratory problems; 95% and 98% in the GA <32 weeks, PNA <2weeks and PNA ≥2 weeks, respectively. In participants with GA ≥32 weeks, respiratory issues are present in 55% and 82% of the PNA <2 weeks and PNA ≥2 weeks groups, respectively. Gastrointestinal problems are present in 179 (89.5%), cardiovascular problems in 146 (73.0%) and blood/lymphatic system problems in 181 (90.5%). Of the 298 baseline cardiovascular problems, 42 (14%) were congenital heart defects; 76 (26%) were patent ductus arteriosus; 27 (9%) were patent foramen ovale; and 153 (51%) were acquired cardiovascular conditions. The results of the baseline physical examination (Table 14.1.7) indicate that 93.5% of the participants had an abnormal finding: 64.0% respiratory, 25.5% cardiovascular and 78.5% gastrointestinal.

Eighty-nine (44.5%) participants had prior abdominal surgery of which 44 had a laparotomy. Baseline radiographs were performed in 174 (87.0%) participants and were normal in 17 of these participants. See Section 14, Tables 14.1.5 and 14.1.6.

The most frequently reported indication for meropenem was that the participant was already receiving meropenem as standard of care (32.5%). NEC grade II or higher by Bell’s criteria was indicated by 30.5% of the participants. Prior cardioactive drugs were being used in 38 (19.0%) of the participants, dopamine being the most common. Prior medications were used in 189 (94.5%) of the participants. Table 11.2 lists medications used in >10% of the population.

Table 11.2 Prior Medications Used by >10% of Participants

Prior Medications used by >10% of Participants | Total (N=200)
Number of Participants with Prior Medication | 189 (94.5%)
AMPICILLIN | 62 (31.0%)
CAFFEINE CITRATE | 48 (24.0%)
CEFOTAXIME | 25 (12.5%)
CLINDAMYCIN | 26 (13.0%)
DOPAMINE | 26 (13.0%)
FENTANYL | 42 (21.0%)
FLUCONAZOLE | 35 (17.5%)
FUROSEMIDE | 22 (11.0%)
GENTAMICIN | 110 (55.0%)
HYDROCORTISONE | 26 (13.0%)
MEROPENEM | 75 (37.5%)
METRONIDAZOLE | 32 (16.0%)
MIDAZOLAM | 31 (15.5%)
MORPHINE | 42 (21.0%)
VANCOMYCIN | 93 (46.5%)

## 11.3 Measurement of Treatment Compliance

The protocol provided guidelines for study medication dosing. Treatment compliance was not analyzed for this study. However, there were 17 dose or dose/PK related protocol deviations. These are listed in Appendix 16.2.15.

## 11.4 Efficacy Results and Tabulations of Individual Participant Data

### 11.4.1 Analysis of Efficacy

#### 11.4.1.1 Definition of Efficacy

Success is defined as ALL of the following:

- Alive at efficacy visit.
- Last culture (if obtained) from sterile body fluid is negative for bacteria (except Staphylococcus species) from start of study meropenem until efficacy visit.
- Presumptive clinical cure score ≥7 at efficacy visit.

Failure was defined by ANY of the following:

- Change in antibiotic therapy while on study drug will be considered a treatment failure except the addition of Gram positive therapy to treat organisms that require it and have been isolated from a non-abdominal source (including CONS, MRSA).
- Death before efficacy visit.
- Presumptive clinical cure score <7.

##### Deaths

The meropenem study has reported 11 deaths, three took place >3 weeks after the last dose (all 3 had the final efficacy visit). These 3 will not be considered “efficacy failures” due to death. The remaining 8 participants will be included as efficacy failures (due to death).

##### Cultures

Last cultures from sterile body fluids collected from start of study meropenem until 7 days after the end of study meropenem were evaluated. If a culture was obtained, it was required to be negative for bacteria (excluding Staphylococcus spp.) for the participant to be an efficacy success. Cultures were not available on 94 (49.0%) of the participants.

##### Presumptive Clinical Cure Score

This is a 10 item score comparing baseline status to efficacy visit status. The 10 items include:

1) Mean blood pressure
2) Temperature
3) O_2_%
4) Serum pH
5) Presence or absence of seizures
6) Urine output
7) Cardiovascular inotrope support
8) C-reactive protein
9) Abdominal girth
10) Findings on abdominal radiograph

Points will be awarded as in the table below and the score is the sum of the ten items:

| Efficacy Visit
Baseline visit | No change | Worsening | Asymptomatic | Improved | Missing
Asymptomatic | 1 point | 0 points | 1 point | 1 point | missing
Symptomatic | 0 points | 0 points | 1 point | 1 point | missing
Missing | missing | 0 points | 1 point | 1 point | missing

Seven participants had a score <7 and one or more missing items. Four of these participants started new antibiotic therapy and are considered efficacy failures, the other 3 are unevaluable for efficacy. 179 participants had a score ≥7 and one participant had a score <7. The score was not calculated for the eight participants that died.

##### Change in Antibiotic Therapy

A participant was considered to have a change in antibiotic therapy while on study drug if one of the following medications was started during the period from the start of study drug +1 day and the end of study drug −1 day. The antibiotic was not a trigger for an efficacy failure if it was started on the same day study meropenem was started or if the antibiotic was started on the same day study meropenem was ended. If the start of linezolid, rifampin or vancomycin was associated with a sterile body fluid (non-abdominal) culture positive for a Staphylococcus infection, it was not included as a failure due to change in antibiotic therapy.

- Amikacin
- Amoxicillin
- Amoxicillin+Clavulanate
- Ampicillin
- Ampicillin+Sulbactam
- Azithromycin
- Aztreonam
- Cefaclor
- Cefazolin
- Cefepime
- Cefotaxime
- Cefotetan
- Cefoxitin
- Ceftazidime
- Ceftriaxone
- Cefuroxime
- Cephalexin
- Ciprofloxacin
- Clindamycin
- Erythromycin
- Gentamicin
- Imipenem+Cilastatin
- Linezolid
- Metronidazole
- Nafcillin
- Oxacillin
- Penicillin G
- Penicillin V
- Piperacillin
- Piperacillin+Tazobactum
- Rifampin
- Ticarcillin
- Ticarcillin+Clavulanate
- Tobramycin
- Vancomycin

#### 11.4.1.2 Efficacy Results

The overall success rate for efficacy in this population is 84.4% (162/192) with a 95% confidence interval from 78.5% to 89.2% (see Tables 11.3 and 11.4). The success rate for participants with GA <32 weeks was 74.4% (29/39) for those with PNA <2 weeks and 83.7% (82/98) for participants with PNA ≥2 weeks. The GA ≥32 weeks had a success rate of 92.9% (26/28) and 92.6% (25/27) for PNA <2 weeks and ≥2 weeks, respectively.

Table 11.3 Efficacy Results

| GA <32 weeks | | GA ≥32 weeks | | Total
| PNA <2 weeks | PNA ≥2 weeks | PNA <2 weeks | PNA ≥2 weeks | Total
Efficacy population | 39 | 101 | 28 | 27 | 195
Evaluable for efficacy | 39 (100.0%) | 98 (97.0%) | 28 (100.0%) | 27 (100.0%) | 192 (98.5%)
Success (n,%)^1^ | 29 (74.4%) | 82 (83.7%) | 26 (92.9%) | 25 (92.6%) | 162 (84.4%)
95% confidence interval^2^ | (57.9 – 87.0) | (74.8 – 90.4) | (76.5 – 99.1) | (75.7 – 99.1) | (78.5 – 89.2)

1 Success will be defined as alive, negative bacterial cultures (if obtained) from normally sterile body fluids, presumptive clinical cure score ≥7 at efficacy visit and no new antibiotic therapy during study meropenem.

2 Exact Binomial 95% confidence intervals.

In participants where the presumptive clinical score could be determined, all but 1 participant had a score ≥7. Score was not calculated for the 8 participant deaths and was missing in 4 participants known to have started antibiotic therapy while on meropenem.

Change in antibiotic therapy was the largest determinant of efficacy failure with 23 participants starting new antibiotic therapy while on meropenem. Vancomycin therapy was added for 6 of these participants, gentamicin in 6 participants and 2 additional patients received both vancomycin and gentamicin.

Cultures on sterile body fluids were completed on 98 (51.0%) participants from the start of study meropenem until 7 days after study meropenem ended. Only the last culture for each patient was evaluated. No participants had a positive last culture (this excluded cultures positive for Staphylococcus spp.).

Table 11.4 Efficacy Component Results

| GA <32 weeks | | GA ≥32 weeks | | Total
| PNA <2 weeks | PNA ≥2 weeks | PNA <2 weeks | PNA ≥2 weeks | Total
Enrolled population | 39 | 103 | 31 | 27 | 200
Efficacy population | 39 (100.0%) | 101 (98.1%) | 28 (90.3%) | 27 (100.0%) | 195 (97.5%)
Evaluable for efficacy | 39 (100.0%) | 98 (97.0%) | 28 (100.0%) | 27 (100.0%) | 192 (98.5%)
Efficacy Success^1^ | 29 (74.4%) | 82 (83.7%) | 26 (92.9%) | 25 (92.6%) | 162 (84.4%)
Deaths^2^ | 3 (7.7%) | 5 (5.1%) | 0 | 0 | 8 (4.2%)
Clinical Cure Score ≥7 | 35 (89.7%) | 90 (91.8%) | 27 (96.4%) | 27 (100.0%) | 179 (93.2%)
Clinical Cure Score <7 | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Clinical Cure Score missing | 4 (10.3%) | 7 (7.1%) | 1 (3.6%) | 0 | 12 (6.3%)
Change in antibiotic therapy | 7 (17.9%) | 12 (12.2%) | 2 (7.1%) | 2 (7.4%) | 23 (12.0%)
Cultures negative for bacteria | 27 (69.2%) | 49 (50.0%) | 9 (32.1%) | 13 (48.1%) | 98 (51.0%)
Cultures not done | 12 (30.8%) | 49 (50.0%) | 19 (67.9%) | 14 (51.9%) | 94 (49.0%)

1 Success will be defined as alive, negative last bacterial cultures (if obtained) from normally sterile body fluids (excluding Staphylococcus species), presumptive clinical cure score ≥7 at efficacy visit and no new antibiotic therapy during study meropenem (except related to Staphylococcus infections).

2 Deaths occurring ≤7 days from end of study meropenem.

### 11.4.2 Statistical and Analytical Issues

#### 11.4.2.1 Adjustments for Covariate

There were no adjustments for covariates in the analysis of data.

#### 11.4.2.2 Handling of Dropouts or Missing Data

There were 5 (2.5%) early termination participants without an efficacy visit. Parents/guardians of two participants withdrew consent, 2 participants terminated early due to investigator’s judgment and one participant was discharged prior to the efficacy visit. All other participants (except deaths) completed a baseline and efficacy visit.

Rules for handling missing presumptive clinical score items are described below.

Missing investigator interpretations were imputed for seizures and cardioactive drugs as follows:

- If no or not used at baseline, investigator’s decision was asymptomatic.
- If yes or used at baseline, investigator’s decision will be symptomatic.
- If no or not used at efficacy, investigator’s decision will be asymptomatic.
- If yes or used at efficacy, investigator’s decision will be no change for baseline symptomatic and worse for baseline asymptomatic.

Missing investigator’s interpretation was imputed for abdominal radiograph test done as follows:

- If not done at baseline, investigator’s decision will be asymptomatic.
- If not done at efficacy, investigator’s decision will be asymptomatic

#### 11.4.2.3 Interim Analysis and Data Monitoring

Interim PK analysis was done using data from 99 meropenem concentrations obtained from the first 22 infants enrolled in the study. Population and individual participant (Bayesian) PK parameters were estimated using NONMEM. Dosing was based on both gestational age and postnatal age: 3 infants received 20 mg/kg q12 hr, 12 received 20 mg/kg q8 hr, 5 received 30 mg/kg q8 hr, and 2 received 40 mg/kg q8 hr. All infants had the predicted meropenem concentrations of above an MIC (Minimum Inhibitory concentration) of 2 μg/mL for >75% of the dosing interval (Figure 11.1). Since none of the infants presented with an MIC of ≥2 μg/ml for >75% of the dose interval, no dose escalation was performed and the rest of the study was carried using the initial dosing plan.

Figure 11.1 75% Dosing Interval Meropenem Concentration

Additional results from the interim analysis are presented in Appendix 16.1.14.

#### 11.4.2.4 Multi-center Studies

The possible effects of study center were not investigated.

#### 11.4.2.5 Multiple Comparison/Multiplicity

This study was not powered to determine efficacy and no inferential statistical tests have been performed.

#### 11.4.2.6 Use of an “Efficacy Subset” of Participants

The efficacy analysis was conducted on all study participants with an efficacy visit or death (n=195). There were 3 additional participants for whom a presumptive clinical cure could not be determined due to missing score items. These participants did not die, receive additional antibiotic therapy while on meropenem or have a positive sterile culture. Therefore efficacy status was undeterminable.

#### 11.4.2.7 Active-Control Studies Intended to Show Equivalence

This section does not apply to this report.

#### 11.4.2.8 Examination of Subgroups

Analyses of the efficacy outcome and individual components of the efficacy tabulation were presented for subgroups of participants based on postnatal and gestational age.

### 11.4.3 Tabulation of Individual Response Data

Tabulations of individual response data can be found in Section 16, Appendix 16.2.

### 11.4.4 Drug Dose, Drug Concentration, and Relationship to Response

#### 11.4.4.1 Pharmacokinetic Analysis

The initial dosing paradigm used 3 different dose levels in 4 age strata based on gestational and post-natal age. A total of 780 scheduled plasma meropenem concentrations from 188 participants were available to construct the population PK model. A one-compartment model with proportional residual error was chosen to describe the PK of meropenem. Meropenem clearance was lowest in the most immature cohort (<32 weeks gestation and <2 weeks postnatal age), 0.089 L/h/kg and highest in the most mature cohort (≥32 weeks gestation and ≥2 weeks postnatal age, 0.202 L/h/kg. As neonates are relatively immuno-compromised, the overall PD targets for meropenem concentrations were >4 μg/mL for 50% of the dosing interval and >2 μg/mL for 75% of the dosing interval. These targets were achieved in 95.7% and 92.0% of participants, respectively. Therefore, the initial dosing strategy met the overall goals for exposure. The final population model is:

V (L/kg) = θ_(1)_* (ALB/2.3)^θ(5)^;

CL (L/h/kg) =θ_(2)_ * (0.5/SCR) ^θ(3)^ * (PCA/32.7)^θ(4)^

where θ_1_=0.460, θ_(2)_ =0.122, θ_(3)_. =0.267, θ_(4)_ =1.460, θ_(5)_. = −0.444.

The Monte Carlo simulation predicts >99% of virtual participants will achieve the desired target.

At the following doses, therapeutic meropenem concentrations will be obtained in almost all infants, ≤90 days of age:

- 20 mg/kg every 12 hours in infants <32 weeks GA and PNA <2 weeks
- 20 mg/kg every 8 hours in infants <32 weeks GA and PNA ≥2 weeks
- 20 mg/kg every 8 hours in infants ≥32 weeks GA and PNA <2 weeks
- 30 mg/kg every 8 hours in infants ≥32 weeks GA and PNA ≥2 weeks

### 11.4.5 Drug-Drug and Drug-Disease Interactions

Potential interactions were not investigated in this study.

### 11.4.6 By-Participant Displays

By-participant displays (i.e., “patient profiles”) were not produced for this study.

### 11.4.7 Efficacy Conclusions

Of the 200 infants enrolled in the trial, 195 were included in the efficacy population and 192 of 195 (98.5%) were evaluable for efficacy. Mortality prior to the efficacy assessment was 8/192 (4.2%). Mortality was highest among infants <32 weeks gestational age and <2 weeks postnatal age, 3/39 (7.7%). None of the 50 infants with ≥32 weeks gestational age died prior to the efficacy visit. Efficacy success, defined as being alive with negative cultures from normally sterile body fluids and a presumptive clinical cure score ≥7 at the efficacy assessment, was achieved in 162/192 (84.4%) of the infants. Efficacy success was lowest among infants <32 weeks gestational age and <2 weeks postnatal age, 29/39 (74.4%) and highest among infants ≥32 weeks gestational age 51/55 (92.7%).