# 10 STUDY PARTICIPANTS

## 10.1 Disposition of Participants

Participant accounting is summarized in Table 10.1 and in Section 14, Table 14.1.1. A total of 200 participants signed parental permission and were treated with study meropenem. Participants were classified by gestational age (GA) - GA <32 weeks (n=142, 71%) and GA ≥32 weeks (n=58, 29%) and by post-natal age (PNA) <2 weeks (n=70, 35%) and PNA ≥2 weeks (n=130, 65%). 51.5% of the participants were in the GA <32 weeks and PNA ≥2 weeks category.

All participants were included in the safety population. 83 participants were already receiving meropenem at the start of the study. 179 participants completed the study and 21 (10.5%) terminated the study early for reasons as follows: death (7), investigator decision (4), incomplete final assessments (4), withdrawal of parent/guardian consent (2), protocol non-compliance (2) and SAE (2).

Table 10.1 Participant Disposition

Participant Accounting | GA <32 weeks | | GA ≥32 weeks | | Total
Participant Accounting | PNA <2 weeks | PNA ≥2 weeks | PNA <2 weeks | PNA ≥2 weeks | Total
Enrolled population | 39 | 103 | 31 | 27 | 200
Safety population | 39 | 103 | 31 | 27 | 200
Efficacy population | 39 | 101 | 28 | 27 | 195
Completed | 35 (89.7%) | 94 (91.3%) | 26 (83.9%) | 24 (88.9%) | 179 (89.5%)
Early Termination | 4 (10.3%) | 9 (8.7%) | 5 (16.1%) | 3 (11.1%) | 21 (10.5%)
Reasons for ET
Parent/guardian withdrew consent | 0 | 0 | 2 (6.5%) | 0 | 2 (1.0%)
Investigator judgment | 1 (2.6%) | 3 (2.9%) | 0 | 0 | 4 (2.0%)
Protocol non-compliance (after enrollment) | 1 (2.6%) | 0 | 0 | 1 (3.7%) | 2 (1.0%)
Serious Adverse Event/Adverse Event | 0 | 1 (1.0%) | 0 | 1 (3.7%) | 2 (1.0%)
Participant death | 2 (5.1%) | 5 (4.9%) | 0 | 0 | 7 (3.5%)
Participant discharged - final assessments not completed | 0 | 0 | 3 (9.7%) | 1 (3.7%) | 4 (2.0%)

## 10.2 Protocol Deviations

There were 76 protocol deviations listed for this study (see Appendix 16.2.15 for a complete list). Nine of these deviations were related to inclusion/exclusion criteria of which six had history of seizure or seizure-like activity, one participant had serum creatinine of 1.9 while on previously initiated meropenem, one participant had 24 hours of imipenem and one participant had PNA of 92 days. Waivers were granted in all cases except one, where seizure was discovered after the participant completed the study. There were 57 PK and/or dose related protocol violations.