# 9 INVESTIGATIONAL PLAN

## 9.1 Overall Design and Plan Description

This was a multi-center, prospective, PK and safety study of meropenem in infants <91 days of age for the treatment of suspected or documented complicated intra-abdominal infections.

The dosing of meropenem, stratified by GA and PNA, was predicted to provide therapeutic exposure in the majority of infants. Infants were enrolled in four GA/PNA strata. Safety was assessed in real time by the Meropenem Off-Patent Drug Studies (MPODS) Clinical Events Safety Committee and by an independent Data Safety Monitoring Board (DSMB). First dose and steady state meropenem PK were studied in an interim analysis by GA/PNA group after 12 babies were enrolled in a GA/PNA stratum. During interim PK analysis, infants in the GA/PNA group under analysis were continued to be enrolled for ongoing safety evaluation and steady state PK. If the interim PK analysis had suggested that the initial dosing did not achieve concentrations more than the MIC of 2 μg/ml for >75% of the dose interval in at least 90% of infants, then the dose would have been escalated. However, an interim analysis showed that the initial dosing achieved the target MIC, so a higher dosage was not implemented. First dose and steady state meropenem PK were obtained along with ongoing safety evaluation. The final goal of 200 infants was reached when subsequent enrollment occurred in the safety group with steady state PK. The study scheme is illustrated in Figure 9.1. Table 9.1 illustrates the schematic representation of assessments. The following was the overall study design:

1) First dose and steady state meropenem PK was studied in infants <91 days of age using a population PK design.
2) There were four GA/PNA groups (see Section 9.3).
3) Two hundred (200) infants were enrolled.
  a. First dose and steady state PK - 12 infants were enrolled in 4 GA/PNA strata at initial dose (48 infants).
  b. Safety and steady state PK - 152 additional infants were enrolled for ongoing safety evaluation and further collection of steady state PK data. These safety/steady state infants received initial dose of meropenem.
4) Investigators were encouraged to provide infants with concomitant aminoglycoside therapy. Use of other antimicrobial agents was discouraged, but may have been given per local standard of care.

Figure 9.1 Study Scheme

Table 9.1 Schematic Representation of Assessments

| Study Day
PROCEDURE | 0 | 1-27 | 28 | 29 to end of study
Informed Consent | X^a^
Antibacterial Therapy | X^b^ | X^b^
Intestinal sample obtained | | X
Urine sample obtained | | X
Plasma sample obtained | | X
Peritoneal fluid sample obtained | | X
Pleural fluid sample obtained | | X
Plasma PK Evaluation | | X^c^

a Prior to enrollment and other study activities

b Treatment for minimum of 3 days

c Obtained per MPODS protocol

The duration of meropenem therapy for the 200 infants in this trial was at least 3 days and no more than 21 days. Infants were given therapy until the attending physician believed that the infant has had presumptive clinical cure.

## 9.2 Discussion of Study Design and Choice of Control Groups

The initial plan to conduct a PK and safety study using meropenem as monotherapy was altered due to concerns regarding the safety and ethics of using the treatment in this patient population. Although meropenem monotherapy may be considered appropriate for use in adult peritonitis, the flora of an infant is a changing target during the first 90 days of life, thereby leaving significant safety, efficacy, and potential dosing gaps in designing a study using monotherapy. Therefore the design of the study incorporated the use of other antimicrobials (e.g., aminoglycosides) in addition to meropenem. In order to better identify safety signals during the study, particularly hepatic and seizure AE, a separate safety committee was established to monitor these AEs in real time prior to DSMB meetings. Finally, the study was designed as an open-label, dose escalation study because sufficient data regarding the feasibility of a randomized, active controlled efficacy study was unavailable.

## 9.3 Selection of Study Population

Infants were to be enrolled in each of the following groups:

- Group 1: GA at birth below 32 weeks - PNA <2 weeks;
- Group 2: GA at birth below 32 weeks - PNA ≥2 weeks and <91 days;
- Group 3: GA at birth 32 weeks or older - PNA <2 weeks;
- Group 4: GA at birth 32 weeks or older - PNA ≥2 weeks and <91 days.

### 9.3.1 Inclusion Criteria

Participants were eligible for study inclusion if they met all of the following inclusion criteria:

1. Written permission from parent or legal guardian.
2. Age younger than 91 days.
3. Likely to survive beyond the first 48 hours after enrollment.
4. Sufficient intravascular access (either peripheral or central) to receive study drug.
  AND ONE OF THE FOLLOWING
5. a) Physical, radiological, and/or bacteriological findings of a complicated intra-abdominal infection. These included peritonitis, NEC Grade II or higher by Bell’s criteria, Hirschsprung’s disease with perforation, spontaneous perforation, meconium ileus with perforation, bowel obstruction with perforation as evidenced by free peritoneal air on abdominal radiograph, intestinal pneumatosis or portal venous gas on abdominal radiographic examination.
    OR
  b) Possible NEC.
    OR
  c) Otherwise receiving meropenem per local standard of care.

## 9.4 Exclusion Criteria

Participants were excluded from study participation if they met any of the following exclusion criteria:

1. Renal dysfunction as evidenced by urine output <0.5 ml/hr/kg over the prior 24 hours.
2. Serum creatinine >1.7 mg/dl.
3. History of clinical seizures or EEG confirmed seizures.
4. Concomitant treatment with another carbapenem (ertapenem or imipenem) at the time of informed consent.
5. Any condition which could make the participant or the caregiver, in the opinion of the investigator, unsuitable for the study.

### 9.4.1 Withdrawal from Study

Participation in this study could have been terminated by the participant parent or guardian or the investigator at any time during the study. If a participant was terminated, the reason(s) were stated in the appropriate section of the case report form (CRF) and all applicable study documents were completed. Reasons for infant withdrawal from the study included, but were not limited to -

- Infant’s parent or legal guardian chooses to withdraw the infant for any reason.
- AEs, conditions, or intercurrent illnesses that precluded compliance with the protocol, particularly if continuation would pose a risk to the infant’s safety.
- Clinical seizure occurred between informed consent and first administration of study drug.
- The investigator determined that it was in the infant’s best medical interest to be withdrawn. Withdrawn infants were to be followed for safety endpoints to the extent possible.

## 9.5 Treatments

### 9.5.1 Treatments Administered

Study medications were purchased and repackaged for the study by the BPCA DCC. Meropenem was administered concomitantly with compatible medications. Because an in-line filter is not appropriate due to drug binding, the 30 minute infusion was rate controlled by using appropriate infusion (syringe) pumps. Dosing and administration of other antimicrobial therapy (e.g., an aminoglycoside) was administered per local standard of care at the discretion of the infant’s neonatologist. If there was a delay in the study drug shipment, sites were to use open-label meropenem to protect the safety of the participant.

### 9.5.2 Identity of Investigational Products

MERREM I.V. (Meropenem for injection) was supplied as 500 mg/20ml single use vial (Batch Number – NM0156). The vials were packed as 50x packer vials (batch number – 22162.1/22162).

### 9.5.3 Method of Assigning Participants to Treatment Groups

This was an open label phase II study and there was no randomization involved.

### 9.5.4 Selection of Doses in the Study

Meropenem demonstrates time dependent pharmacodynamics. Clinical antimicrobial effects are observed when concentrations exceed the MIC for at least 30-40% of the dose interval in immunocompetent participants; and for neutropenic participants, levels should exceed the MIC for >75% of the dose interval. We consider neonates to be relatively immunocompromised. We determined the dose needed to provide exposure above MIC of 2 μg/ml for >75% of the dosing interval in most of the participants, and above MIC of 4 μg/ml (upper limit of MIC) for >50% of the interval for >90% of participants. We suspected that the inflammatory process and capillary leak associated with necrotizing enterocolitis and bowel perforation may increase the volume of distribution of the drug in the sickest infants. We aimed to avoid sub-therapeutic exposure in these infants. We developed the following initial meropenem dosing scheme using a population PK model for meropenem in neonates.

Initial Dosing:

- [underlined: Infants with gestational age <32 weeks]
  - <2 weeks PNA 20 mg/kg Q12 hours
  - ≥2 weeks PNA 20 mg/kg Q8 hours
- [underlined: Infants with gestational age ≥32 weeks]
  - <2 weeks PNA 20 mg/kg Q8 hours
  - ≥2 weeks PNA 30 mg/kg Q8 hours

### 9.5.5 Blinding

This was an open-label study and no study treatments were blinded or masked.

### 9.5.6 Prior and Concomitant Therapy

All antimicrobial agents and all medications received during the 72 hours prior to study administration and for 72 hours following last dose of study and concomitant medications were documented in the source documents and appropriate CRFs, along with information of manufacturer, dose in mg/kg or mg/kg/hour, and total dose to identify any other potential sources of excipients.

### 9.5.7 Treatment Compliance

Participants were administered study drug by clinical staff. Records were maintained at each clinical site for the receipt, administration, and disposition of study medication. All unused study medication was destroyed at the site per the site’s destruction policy. Investigators were to allow the FDA to inspect and copy records of drug distribution.

## 9.6 Efficacy, Safety and Pharmacokinetic Assessments

### 9.6.1 Efficacy Assessments

Limited efficacy data was obtained in this study. Efficacy data was based on comparing initial clinical status to clinical status at study Day 28 or at an efficacy visit after at least 7 days after treatment. Initial clinical status was based on the presenting signs and symptoms of each infant and was recorded by the local principal investigator (PI) or designee prior to administration of the first dose of study drug. The same physician also recorded the clinical signs and physical findings on study Day 0 (pre-study drug) and Day 28 in order to derive the efficacy assessments. Success was defined as all of the following:

1) Alive,
2) Negative bacterial cultures from sterile body fluid, and
3) Presumptive clinical cure (details of the presumptive clinical cure are provided below).

Failure was defined by any of the following:

1. Change in antibiotic therapy while on study drug was considered a treatment failure except the addition of Gram positive therapy to treat organisms that require it and have been isolated from a non-abdominal source (including CONS, MRSA);
2. Death; or
3. Lack of presumptive clinical cure.

The presumptive clinical cure score was derived by comparing clinical signs and symptoms prior to administration of the first dose of study drug and study Day 28. The clinical, laboratory and radiographic findings were based on the components of the Score for Neonatal Acute Physiology (SNAP) II and other items listed below. The SNAP II has not been validated as a clinical tool beyond the first hours of life, but there is no alternative clinical tool to predict mortality in serious abdominal infections. The original assessment, efficacy assessment and resulting efficacy interpretation is listed in Table 9.2.

Table 9.2 Original Assessment, Efficacy Assessment and Resulting Efficacy Interpretation

[underlined: Initial Assessment] | [underlined: Efficacy Assessment] | [underlined: Resulting Efficacy Interpretation Score]
Asymptomatic | Asymptomatic | 1
Asymptomatic | Worsening | 0
Symptomatic | Worsening | 0
Symptomatic | No change | 0
Symptomatic | Improved | 1
Symptomatic | Asymptomatic | 1

If 7 or more of 10 signs received a score of 1, then the infant was considered a presumptive clinical cure. The elements of the presumptive clinical score are:

1. Mean blood pressure
2. Temperature
3. PaO_2_ (mmHg)/FiO_2_
4. Lowest serum pH
5. Presence or absence of seizures*
6. Urine output
7. Cardiovascular inotrope support: Record number and amount of each cardioactive drug
8. C-reactive protein (CRP)^#^ (prior to study drug, day 3-5, and day 28)
9. Abdominal girth
10. Findings on abdominal radiograph^

* The presence or absence of seizures was adjudicated by the MPODS Clinical Events and Safety Committee.

^#^ For efficacy assessment, trends in CRP levels were evaluated on 3 occasions: baseline (72 hours) prior to study drug, between day 3-5, and between day 7-28. Inability to obtain a CRP level resulted in a protocol deviation that was reported to the study PI but did not disqualify the patient from the study.

^ The findings on abdominal radiograph were determined locally.

When there were multiple observations for one aspect of the clinical score recorded at baseline or study day 7-28 (e.g., more than one temperature is obtained on day 28), then the first reading obtained was used unless the reading was felt by the PI to be spurious and noted as such in the record. Non-CRP elements of clinical score, that were not otherwise available as part of standard clinical care, were omitted. If the infant is nearing discharge, the score was recorded prior to study day 28, provided that the infant had been off meropenem for at least 7 days.

### 9.6.2 Safety Assessments

The collection of safety data was a primary objective of this trial. The safety of meropenem was a primary focus for monitoring AEs. Safety assessments included death, seizure documentation (including correlation of serum meropenem level and seizures), strictures, perforation, wound dehiscence, short gut, development of extended beta lactamase infection, development of candidiasis, antimicrobial therapy failure, physical examination, clinical laboratory values (as available per standard local care including LFTs, renal function, blood counts and microbiology cultures of sterile body fluids to track nosocomial infections by pathogen) and concomitant medications. Vital signs, electrolytes, creatinine, BUN, liver-function tests (LFT) and complete blood counts were recorded weekly when available per local standard of care. SAE data was continued to be collected for 30 days following completion of study drug administration.

#### 9.6.2.1 Blood Samples

Blood samples were minimized using the following methods:

1. Hematology and chemistry laboratory measures were recorded from laboratories drawn as standard of care and were not drawn strictly for purpose of this study.
2. No more than 2 cc/kg was obtained for study purposes. First priority for blood acquisition was PK samples (up to 0.7 cc of blood). Second priority was CRP levels.
3. CRP levels were obtained from the participants on 3 occasions: baseline (72 hours) prior to study drug, between days 3-5 and between days 7-28 of the study. CRP levels were obtained from residual blood in clinical laboratory if less than 12 hours from time of sample collection. Inability to obtain CRP levels was considered a protocol deviation that was reported to the MPODS PI but did not disqualify the participant from the study.
4. A limited PK sampling scheme was employed such that no more than a total of 0.7 mL of blood (7 samples) was obtained from each participant for PK analysis.

#### 9.6.2.2 Seizures

Seizures were closely monitored throughout the trial. The presentation of a seizure could have been subtle such as ocular deviation, sucking and lip smacking movements, swimming or ‘rowing’ or ‘bicycling’ movements of limbs. They could be tonic/clonic, localized, multifocal, or generalized. They could have also been diagnosed by EEG. If seizures (or possible seizure like activities) are present, they were to be recorded on the CRF. Assessment of seizure activity prior to enrollment, at enrollment, while on study drug and up to 30 days post study drug administration, was recorded on the CRF.

If seizures occurred while on therapy, 100 μl of blood (if possible) was obtained to document meropenem level at time of seizure. When possible, up to 2 additional samples were obtained, each at least 24 hours apart, during additional infant seizure activity. Scavenged samples whenever possible were considered appropriate during infant seizure activity. Time of sample collection was recorded on CRF. These samples were then sent to the central lab with the other PK samples from the infant.

The CRF has a seizure documentation page for every infant thought to have a seizure or seizure-like activity by the local site PI not explained by the infant’s underlying illness. When clinical seizures or seizure-like activity occurred, the local PI (or their designee) recorded the findings on the CRF. EEG’s, if obtained per local standard of care, were evaluated. The local PI obtained a copy of the EEG, preferably in digital format, removed all participant identifiers except study ID, and submitted as source documentation for the seizure or seizure like activity. The local PI or a local neurologist made the final determination of whether or not the infant has had a seizure or seizure like activity. The decision was to be used to determine whether dosing level was to be advanced in an age group.

Infants with seizures or seizure-like activity were characterized in two components:

1) Locally Diagnosed Clinical Seizure (yes/no),
2) Locally Diagnosed EEG-confirmed Seizure (yes/no).

#### 9.6.2.3 Adverse Events and Critical and Near-Critical Incidents

##### 9.6.2.3.1 Definition of an Adverse Event

An AE is defined as any untoward medical occurrence such as a sign(s), symptom(s), and/or laboratory finding(s) concurrent with the use of a drug in humans. AEs include worsening of any baseline symptoms. The event may/may not necessarily have a causal relationship with the administration of the drug. AEs may have been reported by the participant, or detected by the investigator, or other competent observer. The investigator also evaluated any change in laboratory values. If the investigator determined a laboratory abnormality to be clinically significant, it was considered a laboratory AE; however, if the laboratory value abnormality was consistent with the then current diagnosis, it was documented accordingly.

##### 9.6.2.3.21 Reporting Period

AEs were recorded from the time of informed consent until 72 hours following the last dose of study drug for non-SAEs and until 30 days after the last dose of study drug for SAEs. Any AE that occurred between the time informed consent was obtained and the initial dose of study, that was considered related to a protocol specified procedure, were reported.

##### 9.6.2.3.3 Assessment and Recording of Adverse Events and Critical and Near-Critical Incidents

Throughout the duration of the study, the investigator closely monitored each participant for clinical evidence of drug intolerance and monitored all clinically obtained laboratory values for laboratory evidence of AEs. AEs not explained by the infant’s underlying illness, which occurred during the course of the study were reported in detail on the appropriate CRFs and followed until resolution or until it became stable. All SAEs were reported to BPCA DCC within 24 hours.

The description of the AE included description of event, start date, stop date, intensity, if it was serious, and relationship to the study drug. The investigator verified this information.

The Investigator was responsible for assessing relationship of AE to study medication using the following definitions:

- Not related: An AE that is due to a pre-existing illness or use of another drug, and is not related to the study drug.
- Possibly related: An AE that has little or no relationship to the study drug and there exists a more likely alternative cause.
- Probably related: An AE that is likely to be related to the administration of the study drug and an alternative cause less likely when compared to the study drug.
- Definitely Related: An AE that has a strong temporal relationship to the study drug will recur with continued or repeated use of the study drug and another cause is unlikely or less likely.

##### 9.6.2.3.4 Follow-up of AEs

AEs were followed until resolution or until stability was reached using good clinical practices.

##### 9.6.2.4 Serious Adverse Event

SAEs are defined (21 Code of Federal Regulations part 312.32) as those AEs, which meet any of the following serious outcome criteria:

- Is fatal
- Is life-threatening, meaning, the participant was, in the view of the investigator, at immediate risk of death from the reaction as it occurred, i.e., it does not include a reaction that, had it occurred in a more serious form, might have caused death
- Is a persistent or significant disability/incapacity, i.e., the event causes a substantial disruption of a person’s ability to conduct normal life functions
- Requires or prolongs in patient hospitalization
- Is a congenital anomaly/birth defect
- Is an important medical event, based on appropriate medical judgment, that may jeopardize the participant or participant may require medical or surgical intervention to prevent one of the other outcomes above.

### 9.6.3 Pharmacokinetic Measurements

A population PK approach was employed. This included sparse sampling with samples obtained at time intervals rather than at fixed times for assessment of drug concentration. Samples were no more than 100μL each. For the PK analysis, study nurses collected any remaining plasma from the clinical laboratories from infants receiving meropenem as part of this protocol. For the genomic studies, study nurses collected remaining whole blood samples, ideally EDTA tube blood. A maximum of 10 plasma samples and 5 whole blood samples were collected per participant. 50-200 μL of additional CSF were collected from infants when CSF was obtained as part of clinical care while an infant is receiving study drug (meropenem).

Prior to PK sampling (pre study drug assessment), creatinine, BUN, liver function tests (LFT), and urine output over previous 24 hours were recorded. All sample times were recorded on the appropriate CRF in 24 hour time format. All timing and length of drug infusions before PK sampling was obtained were also listed on the CRF. Daily weight and all meropenem doses were recorded on CRF. Infants in each PK cohort were continued to be enrolled ensuring that at least 12 infants with at least 3 PK samples around the 1^st^ dose and 2 samples at steady state were available for analysis.

#### 9.6.3.1 PK Sampling Times

Dose 1 PK-odd Group (infants with birthday on an odd date, e.g., 1^st^, 3^rd^, 5^th^, etc.)

1) Pre: anytime in the 24 hours prior to the first dose
2) Peak: 30 minutes to 1 hour after completion of first dose
3) 3-4 hours after completion of first dose
4) Trough: 7-8 hours after completion of first dose if Q8 hour dosing, or 10-12 hours after completion of first dose if Q12 hour dosing

Dose 1 PK-even Group (infants with birthday on an even date, e.g., 2^nd^, 4^th^, 6^th^, etc.)

1) Pre: anytime in the 24 hours prior to the first dose
2) Peak: 1-2 hours after completion of first dose
3) 4-6 hours after completion of first dose
4) Trough: 7-8 hours after completion of first dose if Q8 hour dosing, or 10-12 hours after completion of first dose if Q12 hour dosing

Dose 5 PK-steady state (around 5^th^ dose if possible, but may have been done around the 4^th^, 6^th^, 7^th^, 8^th^, 9^th^ or 10^th^ dose)

1) Pre: anytime in the 3 hours prior to the 5^th^ dose
2) Peak: 15 minutes-2.5 hours after completion of 5^th^ dose
3) 4-12 hours after completion of fifth dose

Safety Steady-state Group

1. No Dose 1 PK samples was drawn
2. Follow Dose 5 PK-steady state instructions above.

The following plasma PK parameters were estimated in this study.

1. Plasma clearance
2. Volume of distribution
3. Cmax
4. Tmax
5. AUC_0-Τ_, (at steady state)
6. Ke
7. t_1/2_
8. AUC_0-∞_(estimated from the 1^st^ dose)

From intestinal tissue samples, the following were evaluated:

1. Metabolism of meropenem (to ICI 213689) by DHP-1 in the intestine
2. Role of transporters in the intestinal clearance of meropenem

Enzyme activity is expressed as nmol product/mg protein/min (mean ± SD), and transporter activity is expressed as nmol flux/mg protein/min (mean ± SD). From the urine, plasma, pleural, and peritoneal fluid samples the following were evaluated:

1. Meropenem and metabolite distribution (drug concentration in body fluids)
2. Intestinal/plasma meropenem and metabolite concentration ratio
3. Peritoneal fluid/plasma meropenem and metabolite concentration ratio
4. Pleural fluid/plasma meropenem and metabolite concentration ratio
5. Urinary excretion of meropenem and metabolite

### 9.6.4 Appropriateness of Measurements

#### 9.6.4.1 Scavenge Sampling

The Meropenem Off-Patent Drug Studies (MPODS) allowed for determination of the PK of meropenem in preterm infants with GA <30 weeks and collection of specific data on the disposition of meropenem in infants <3 months with complicated intra-abdominal infections. Scavenge samples are samples obtained as part of the normal clinical care of the infants. These samples, once collected, were sent to the clinical laboratories for chemical and hematological assays. Blood sent to the laboratories is often in excess of what is needed for the laboratory assay. Handling of the blood is not standardized and it is often exposed to room temperature for periods of time.

Blood is routinely drawn from infants with complicated intra-abdominal infections (up to 4-6 times per day). As blood sampling for study purposes is limited at many institutions to 7 mL/kg over the period of the study, alternative methods of sampling were needed. The amount of blood allowed for study sampling was 3.5 mL (<1 teaspoon) for an infant with a weight of 500 g. These infants are exposed to prolonged courses of numerous antimicrobials while in the Neonatal Intensive Care Unit (NICU) and are at the highest risk of adverse drug events due to an almost complete lack of information regarding PK and safety of therapeutic agents.

#### 9.6.4.2 Rationale for Collecting Scavenged Blood for DNA Testing

Epidemiologic data has been gathered for the plausibility of a genetic contribution to risk of diseases in extremely preterm birth. Testing a cohort of mono- and di-zygotic twins, investigators recently identified possible familial contribution to risk of Necrotizing Enterocolitis (NEC) and other complications of preterm birth^13,14,15^. Only a handful of studies have been done to assess specific genetic variants for associations with risk of NEC in preterm infants. Searches for associations with NEC have also identified a few possible candidate genes, including immune related genes and most recently, a gene involved in arginine metabolism and carbamoyl-phosphate synthetase 1. However^15,16,17,18^, these studies have multiple limitations including small numbers; in one study only 17 cases and 34 controls were used^16^ and varied phenotype definitions (52 of 153 very low birth weight infants in Bokodi’s study were classified as NEC cases, with no modified Bell’s criteria specified for the cases, while 17 of 46 cases in Treszl’s study had stage I NEC.)

The scavenged deoxyribonucleic acid (DNA) samples could be used for comparisons of prevalence of genetic variants among those with different outcomes, and could also be shared with investigators interested in phenotypes of infants whose samples were included in the collection. Samples could also be used to assess the influence of pharmacogenomic variations in the drug metabolic pathways on pharmacokinetic results^19^. A tool such as the multiplex array simultaneously test for 1227 genetic variants in 169 genes involved in drug metabolism, excretion, and transport described by Daly et al, would allow efficient analysis of pharmacogenomic variations and associations with meropenem PK in the study population^20^.

#### 9.6.4.3 Rationale for Evaluating Cerebrospinal Fluid PK

The cumulative incidence of meningitis is highest in the first month of life and is higher in preterm infants than term infants^21^. For infants who develop meningitis, the neurodevelopmental consequences are often profound^22^. Empirical antibiotics are often given to sick infants in the NICU. However, blood culture sensitivity may be compromised by the relatively small amount of blood used for the blood culture, 0.5-1 mL in infants vs. >20 mL in adult participants. Unfortunately, many clinicians often delay lumbar puncture in infants for several reasons including: clinical instability of the infant and belief that meningitis is of low probability. However, 30-38% of cases of meningitis in infants are associated with negative blood cultures. In this setting, use of empirical therapy with poor CNS penetration (aminoglycosides) may not effectively treat undiagnosed CNS infections. Even agents that penetrate the CNS well (3^rd^ generation cephalosporins) may be ineffective in the setting of highly resistant organisms such as extended spectrum beta-lactamase producing organisms (e.g. Klebsiella spp)^23^.

## 9.7 Data Quality Assurance

### 9.7.1 Data Processing and Data Management

Clinical data processing and data management was employed based on the procedures developed by the BPCA DCC in conjunction with the NICHD. All of the data entered into the study data set (at the BPCA DCC) were checked for valid values and ranges, between item logical consistency, and within-participant variation.

### 9.7.2 Ensuring Confidentiality

A study number was assigned for each participant in the MPODS study which was retained for identification for this protocol. Data forms were identified by participant number and initials. The database did not contain any personal identifiers other than participant number and initials.

### 9.7.3 Record Retention

To enable evaluations and/or audits from Regulatory Authorities and NICHD or its designees, the investigators kept records, including the identification of all medical charts and associated source documents and copies of all CRFs. The investigators contacted NICHD before disposing of any such materials. Monitoring visits to the trial sites were made periodically during the study to ensure that all aspects of the protocol were followed. Source documents were reviewed for verification of primary efficacy and safety data collected on the CRFs. The participating sites and investigators provided access to source documents by BPCA DCC and the IRB. The PI and relevant site personnel were routinely available during the monitoring visits to support this process. The study sites were also participant to quality assurance audits by the NICHD or its designees and appropriate regulatory agencies. Audit certificates are not available for this study. Data was recorded on paper CRFs by the sites and the BPCA DCC transferred the information from paper to an electronic data capture system. The BPCA CC used a system provided by Lifetree Clinical Research and The BPCA DCC used its own proprietary system (AdvantageEDC^SM^). Data management was performed by the BPCA DCC. All of the data entered into the study database were checked for valid values and ranges, between-item logical consistency, and within-participant variation using a combination of programmed edit checks and manual review.

## 9.8 Statistical Methods and Determination of Sample Size

The Data Coordinating Center contractor finalized a complete Statistical Analysis Plan (SAP) prior to locking the database for the study, and can be found in Appendix 16.1.9.

### 9.8.1 Statistical and Analytical Plans

#### 9.8.1.1 Analysis Population

The following analysis populations were planned for this study:

- Enrolled Population (ENROLLED): The Enrolled Population included all participants in the database who provided informed consent regardless of the participant’s treatment status in the trial.
- Safety Population (SAFETY): The Safety Population included all participants who received any amount of meropenem.

#### 9.8.1.2 General Statistical Methodology

Descriptive summaries are provided where appropriate for each of the primary and secondary variables. In general, summaries are completed by gestational and post-natal age groups for the safety population. Continuous, quantitative variable summaries include the number of participants (N), mean, standard deviation, 95% confidence interval (CI) of mean, median, ranges (minimum and maximum). Categorical, qualitative variable summaries include the frequency and percentage of participants who are in the particular category. In general the denominator for the percentage calculation is based upon the total number of participants in the study population for GA and PNA groups, unless otherwise specified.

All analyses and data summaries were produced using SAS^®^ Software version 9.2.

#### 9.8.1.3 Participant Disposition and Withdrawal

All participants who provided informed consent are accounted for in this study. The frequency and percentage of participants in each study population and study withdrawals are presented for each gestational and post-natal age group (disposition, Table 14.1.1), unless otherwise specified. A breakdown of study population by study site are also provided (disposition, Table 14.1.2).

#### 9.8.1.4 Demographic and Baseline Characteristics

Descriptive summaries of the demographic parameters and baseline disease characteristics have been completed for safety participants in the study population gestational and post-natal age groups (demographics, Table 14.1.3) and included in the data listings, if appropriate, unless otherwise specified. Descriptive summaries of demographic and other baseline conditions include:

- Demographics (Age including gestational and postnatal age, gender, ethnicity, race, birth weight, baseline dosing weight, baseline head circumference and length, and study drug administration as dosing days).
- Baseline medical history.
- Baseline abdominal surgery history.
- Baseline radiography findings.
- Baseline physical examination
- Indication for study drug (multiple may apply).
- Prior medications including prior cardioactive drugs.

Baseline medical history, abdominal surgical history and baseline radiography findings are summarized by surgical procedures and radiography findings for the participants in the safety population by gestational and post-natal age groups (Table 14.1.4 for medical history, Table 14.1.5 for abdominal surgical history, and Table 14.1.6 for baseline radiography findings). Abnormal physical examination is summarized by Body System for the participants in the safety population gestational and post-natal age groups (Table 14.1.7). Indication for study drug is summarized by indication for the participants in the safety population gestational and post-natal age groups (Table 14.1.8). Prior Cardioactive Drugs are summarized by drug name for the participants in the safety population by gestational and post-natal age groups (Table 14.1.9). Prior medication is defined as the medications taken prior to the date of first study medication given. Dosing days was calculated as the date of last dose of study medication minus the date of first study medication plus one.

#### 9.8.1.5 Efficacy Analyses

Efficacy data will be based on comparing initial clinical status to clinical status at study Day 28. This study was not powered to determine efficacy. No inferential statistical tests have been performed. These data were used in assessing the feasibility of a potential efficacy study.

Success was defined by all of the following: Alive, negative bacterial cultures (if obtained) from normally sterile body fluids and presumptive clinical cure score ≥7.

Failure was defined by any of following: Change in antibiotic therapy while on study drug is considered a treatment failure except the addition of Gram positive therapy to treat organisms that require it, or death, or lack of presumptive clinical cure. The number and the percentages of participants who were considered as success/failure are presented by gestational and post-natal age groups (Table 14.2). The table also presents the number and the percentages of participants who were alive and summaries of the other components of the efficacy analysis (including negative bacterial cultures and presumptive clinical score). Descriptive summaries (mean, SD, 95% confidence interval (CI) of mean, median, minimum, and maximum) of presumptive clinical cure score have also been provided in the same table.

#### 9.8.1.6 Safety and Tolerability Analyses

The analysis of safety assessments in this study included summaries of the following categories of safety and tolerability data collected for each participant:

- Adverse Events
  – Overall Summary of AEs
  – Summary of TEAEs, TEAEs by Severity, and TEAEs by Relationship to study drug
  – AEs of special interest including Level 2 laboratory AEs, Seizures and SAEs
  – AEs leading to Study Drug Discontinuation
  – AEs resulting in death
  – Analysis of Key Safety Endpoint
  – Analysis of Seizures
- Clinical Laboratory Investigations (Chemistry and Hematology)
- Vital Signs (Blood Pressure, Pulse, Respiratory Rate, and growth parameters including weight, length, and head circumference)
- Summary of Concomitant Medications
- Other (EEG, Protocol Deviation, Significant Comments)

##### 9.8.1.6.1 Adverse Events

All AEs were coded using the Medical Dictionary for Regulatory Activities (MedDRA) central coding dictionary, version 13.0. Treatment Emergent Adverse Events (TEAE) is defined as any AEs that started on or after the first dose date of study medication. When onset date was missing for an AE, the event was defined as TEAE. An overall summary of TEAE include the number and percentage of participants with at least one TEAE, TEAEs by severity and relationship to study drug, special interest AEs (including seizures, level II laboratory AE, and SAE), categories of SAEs, and TEAEs leading to study drug discontinuation (Table 14.3.1). Summaries of incidence rates (frequencies and percentages), intensity, and relationship to study drug of individual TEAEs by MedDRA System Organ Class (SOC) and Preferred Term have been prepared (Table 14.3.1.1 for overall, Table 14.3.1.2 for incident rates, Table 14.3.1.3 by severity, and Table 14.3.1.4 by relationship to study drug). Each participant was counted only once within each SOC and preferred term if a participant experienced more than one TEAE within a SOC or preferred term for the same recording period. Only the TEAE with the strongest relationship or the greatest intensity, if appropriate, has been included in the summaries of relationship and intensity. TEAE with missing severity has been considered as severe and TEAE with missing causality has been considered as definitely related to study drug. A data listing of all AEs is also provided, displaying details of the event(s) captured on the CRF.

###### 9.8.1.6.1.1 Adverse Events of Special Interest

A summary of incidence rates (frequencies and percentages) of AEs of special interest by gestational and post-natal age groups, SOC, and Preferred Term were prepared for the Safety Population (Table 14.3.2.1) In addition, the summaries of incidence rates (frequencies and percentages) of Seizures, Level 2 AEs and SAE by gestational and post-natal age groups, SOC and Preferred Term were prepared separately for the Safety Population (Table 14.3.2.2 for seizures, Table 14.3.1.5 for level II Laboratory AEs, and Table 14.3.2.3 for SAEs). SAE reconciliation was performed by Data Management, Clinical Research, Drug Safety and Pharmacovigilance via data listings. A data listing of SAEs will also be provided in Listing 16.2.10.3., displaying details of the event(s) captured on the CRF. A part of the SAE narratives was provided in the CSR by the BPCA CC, and the other part was provided by the safety group at The BPCA DCC.

###### 9.8.1.6.1.2 Adverse Events Leading to Study Drug Discontinuation

A summary of incidence rates (frequencies and percentages) of TEAEs leading to discontinuation of study drug, by gestational and post-natal age groups, SOC, and Preferred Term, was prepared for the Safety Population (Table 14.3.2.4). A data listing of AEs leading to discontinuation of study drug is also provided, displaying details of the event(s) captured on the CRF.

###### 9.8.1.6.1.3 Adverse Events Resulting in Death

A summary of incidence rates (frequencies and percentages) of AEs resulting in Death by gestational and post-natal age groups, SOC, and Preferred Term was prepared for the Safety Population. No inferential statistical tests have been performed (Table 14.3.2.5). A data listing of AEs resulting in death is also provided, displaying details of the event(s) captured on the CRF.

###### 9.8.1.6.1.4 Analysis of Key Safety Endpoint

The key safety endpoints included: death, seizures, strictures, perforation, wound dehiscence, short gut, development of Extended Spectrum Beta Lactamase (ESBL) infection, development of candidiasis, and antimicrobial therapy failure. The medical monitor reviewed all AEs prior to database lock and grouped relevant AEs into each of the nine safety endpoint categories on the basis of clinical judgment. The grouping of relevant AEs had been submitted to PODS for review and approval prior to the final analysis. The number of and the proportion of participants affected, and the exact 95% binomial Confidence Interval (CI) of Proportion for each key safety endpoint was prepared for Safety Population, by gestational and post-natal age groups (Table 14.3.2.6). The key safety endpoints and the proportion expected to develop for each safety endpoint are presented in Table 9.3. The p-values to test the expected proportion for each safety endpoint will be provided by gestational and post-natal age groups for safety population.

Table 9.3 Key Safety Endpoint and Expected Proportion

Safety Endpoint | Expected Proportion
Death | 20%
Seizures | 2%
Strictures | 2%
Perforation | 5%
Wound Dehiscence | 2%
Short Gut | 5%
Development of ESBL Infection | 2%
Development of Candidiasis | 10%
Antimicrobial Therapy Failure | 45%

###### 9.8.1.6.1.5 Analysis of Seizure

The number of and the proportion of participants in each seizure category, and the exact 95% binomial CI of Proportion for each seizure category was prepared for Safety Population, by gestational and post-natal age groups. Additionally, the differences in overall seizure (or seizure-like activities) rate and the rate of each seizure category among the age groups was compared using Pearson’s Chi-square test or Fisher’s exact test when at least 25% of the cells had expected counts <5 (Table 14.3.2.7).

#### 9.8.1.7 Clinical Laboratory Evaluation

Descriptive summaries (mean, standard deviation (SD), 95% confidence interval (CI) of mean, median, minimum, and maximum) of observed values and changes from baseline values are presented for blood chemistry and hematology clinical laboratory values by gestational and post-natal age groups and scheduled visits for the Safety Population (Tables 14.3.4.1 and 14.3.4.6 for observed values and Tables 14.3.4.2 and 14.3.4.7 for changes from baseline). Baseline was defined as the assessment taken at pre-dose. The number of participants with chemistry and hematology clinical laboratory values within normal range, abnormal but not clinically significant, and abnormal clinically significant is presented for each clinical laboratory analyte for the Safety Population by scheduled visit and gestational and post-natal age groups (Tables 14.3.4.3 and 14.3.4.8). The shift from baseline to each scheduled visit for an interpretation of within normal range, abnormal but not clinically significant, or abnormal and clinically significant is presented by gestational and post-natal age groups for the Safety Population (Tables 14.3.4.4 and 14.3.4.9). The laboratory tests reflective of liver toxicity (AST, ALT and Direct bilirubin) are further summarized in terms of the most extreme (largest) values and the largest change from baseline observed from start of study drug to the-end-of-therapy by gestational and post-natal age groups(Table 14.3.4.5). All laboratory data is presented in the data listing. Any out-of-range values that were identified by the investigator as being clinically significant are presented in a separate data listing.

#### 9.8.1.8 Vital Signs

Descriptive summaries (mean, SD, 95% confidence interval (CI) of mean, median, minimum, and maximum) of observed values and changes from baseline were calculated for vital signs (heart rate, respiration rate and blood pressure) and growth parameters (weight, length, and head circumference). These summaries are presented by gestational and post-natal age groups and scheduled visits for the safety population (Table 14.3.4.10 for observed growth parameter values, Table 14.3.4.11 for changes from baseline in growth parameters, Table 14.3.4.12 for observed vital sign values, and Table 14.3.4.13 for changes from baseline in vital signs).

## 9.9 Changes in the Conduct of the Study or Planned Analyses

### 9.9.1 Protocol Amendments

No Amendments to the protocol were made for this study.

### 9.9.2 Changes to Planned Analyses

Based on the results of the interim analysis, the higher meropenem dosage groups were not implemented. Thus, all tables and analyses are organized and presented by just two criteria namely Gestational and Post-natal age groups and not by the originally proposed additional criteria of Dosage groups. In order to comply with the ICH and FDA guideline for structure, content and format of a Clinical Study Report, the Caption numbers for some tables in Section 14 were changed. Table 9.4 presents the changes made.

The baseline medical history is presented by reported body system (Table 14.1.4). The medical history was not MedDRA coded and is summarized by system organ class and preferred term. In addition, WHO drug classification of prior (Table 14.1.9.2) and concomitant medications (Table 14.3.5) was not performed and the medications are presented as reported by the site.

Tables 14.2.1 (Efficacy Response) and 14.2.2 (Summary of Efficacy Components) have been combined into Table 14.2. Due to missing values, the Presumptive Clinical score was classified as ≥7 and <7 only and the mean, standard deviation, median, minimum and maximum of the score have not been calculated.

Table 14.3.2.6 (Analysis of Key Safety Endpoints) – Five new categories, namely Strictures, Perforation, Wound Dehiscence, Development of Candidiasis and Antimicrobial Therapy Failure were added as specified in the protocol.

Table 14.3.2.7 (Analysis of Seizure) – One new category, namely Number of Participants with at least one Seizure, was added.

Table 14.3.4.12 (Summary of Vital Signs) and Table 14.3.4.13 (Summary of Change Vital Signs) have been added for heart rate, respiration rate, systolic blood pressure and diastolic blood pressure.

Table 14.3.4.5.3 (Summary of the Extreme Values of Liver Toxicity Direct Bilirubin (mg/dL) by Gestational and Postnatal Age Stratum) has been added for review of liver toxicities.

Some additional minor changes to the SAP include the following:

- Overall “Patients” changed to “Participants”
- Listing 16.2.6.1 - Deleted “Radiography Tests” column
- Listing 16.2.6.2 - Deleted “Radiography Tests” column
- Listing 16.2.7 - Deleted “Significant” column
- Listing 16.2.8.1 - Deleted “Efficacy Score” column
- Listing 16.2.9.2 - Deleted “Dosage per Kilogram” column
- Listing 16.2.10.1 - Deleted “AE Cat” column
- Listing 16.2.10.2 - Deleted “AE Cat” column
- Listing 16.2.10.3 - Deleted “AE Cat” column
- Listing 16.2.10.4 - Deleted “Special” column
- Listings 16.2.10.5 changed “AE Cat” to “SAE Cat”
- Listings 16.2.10.6 deleted “MPODS Neurologist Seizure Type” column
- Listing 16.2.13.1 title changed to Prior Cardioactive Drug and deleted “visit” column since it supported Table 14.1.9.1 (Prior Cardioactive Drug by Dosage and Age Group)
- Listing 16.2.16 (Significant Comments) – Removed

Table 9.4 Changes in Caption Numbering to Tables in Section 14

Old Number | New Number | Table Title
14.3.1 | 14.3.1.1 | Overall Summary of Treatment-Emergent Adverse Events by Gestational and Postnatal Age Stratum
14.3.2.1 | 14.3.1.2 | Summary of Treatment Emergent Adverse Events by Gestational, Postnatal Age Stratum, MedDRA System Organ Class and Preferred Term
14.3.2.2 | 14.3.1.3 | Summary of Treatment Emergent Adverse Events by Gestational, Postnatal Age Stratum, MedDRA System Organ Class, Preferred Term and by Severity
14.3.2.3 | 14.3.1.4 | Summary of Treatment Emergent Adverse Events by Gestational, Postnatal Age Stratum, MedDRA System Organ Class, Preferred Term and by Relationship
14.3.3.1 | 14.3.2.1 | Summary of Adverse Events of Special Interest by Gestational, Postnatal Age Stratum, MedDRA System Organ Class and Preferred Term
14.3.3.2 | 14.3.2.2 | Summary of Adverse Events of Seizures by Gestational, Postnatal Age Stratum, MedDRA System Organ Class and Preferred Term
14.3.3.3 | 14.3.1.5 | Summary of Level 2 Laboratory Adverse Events by Gestational, Postnatal Age Stratum, MedDRA System Organ Class and Preferred Term.
14.3.3.4 | 14.3.2.3 | Summary of Serious Adverse Events by Gestational, Postnatal Age Stratum, MedDRA System Organ Class and Preferred Term
14.3.4 | 14.3.2.4 | Summary of Treatment Emergent Adverse Events Leading to Study Drug Discontinuation by Gestational, Postnatal Age Stratum, MedDRA System Organ Class and Preferred Term
14.3.5 | 14.3.2.5 | Summary of Treatment Emergent Adverse Event Resulting in Death by Gestational, Postnatal Age Stratum, MedDRA System Organ Class and Preferred Term
14.3.6 | 14.3.2.6 | Analysis of Key Safety Endpoints
14.3.7 | 14.3.2.7 | Analysis of Seizures
14.3.8.1 | 14.3.4.1 | Summary of Blood Chemistry by Scheduled Visit, Gestational and Postnatal Age Stratum Tests
14.3.8.2 | 14.3.4.2 | Summary of Change of Blood Chemistry from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests
14.3.8.3 | 14.3.4.3 | Summary of Blood Chemistry Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests
14.3.8.4 | 14.3.4.4 | Summary of Shift of Blood Chemistry Interpretations from Baseline to each Scheduled visit by Gestational and Postnatal Age Stratum Tests.
14.3.8.5.1 | 14.3.4.5.1 | Summary of the Extreme Values of Liver Toxicity AST (U/L) by Gestational and Postnatal Age Stratum
14.3.8.5.2 | 14.3.4.5.2 | Summary of the Extreme Values of Liver Toxicity ALT (U/L) by Gestational and Postnatal Age Stratum
14.3.9.1 | 14.3.4.6 | Summary of Blood Hematology by Gestational and Postnatal Age Stratum Tests
14.3.9.2 | 14.3.4.7 | Summary of Change of Blood Hematology by Gestational and Postnatal Age Stratum Tests
14.3.9.3 | 14.3.4.8 | Summary of Blood Hematology Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests
14.3.9.4 | 14.3.4.9 | Summary of Shift of Blood Hematology Interpretations from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests
14.3.10.1.1 | 14.3.4.10.1 | Summary of Growth Parameters Weight (g) by Scheduled Visit, Gestational and Postnatal Age Stratum
14.3.10.1.2 | 14.3.4.10.2 | Summary of Growth Parameters length (cm) by Scheduled Visit, Gestational and Postnatal Age Stratum
14.3.10.1.3 | 14.3.4.10.3 | Summary of Growth Parameters Head circumference (cm) by Scheduled Visit, Gestational and Postnatal Age Stratum
14.3.10.2.1 | 14.3.4.11.1 | Summary of Change Growth Parameters Weight (g) from Baseline to each Scheduled Visit, Gestational and Postnatal Age Stratum
14.3.10.2.2 | 14.3.4.11.2 | Summary of Change Growth Parameters Length (cm) from Baseline to each Scheduled Visit, Gestational and Postnatal Age Stratum
14.3.10.2.3 | 14.3.4.11.3 | Summary of Change Growth Parameters Head Circumference (cm) from Baseline to each Scheduled Visit, Gestational and Postnatal Age Stratum
14.3.11 | 14.3.5 | Concomitant Medications by Gestational and Postnatal Age Stratum