# 8 STUDY OBJECTIVES

## 8.1 Primary Objective

The primary objectives were:

- To characterize meropenem single-dose and multiple-dose PK in participants (<91 days).
- To characterize the safety profile of meropenem in the treatment of participants (<91 days) with suspected and complicated intra-abdominal infections.
- To assess collected efficacy data for meropenem for the treatment of participants (<91 days) with suspected and complicated intra-abdominal infections.