# 7 INTRODUCTION

## 7.1 Introduction

The Best Pharmaceuticals for Children Act (BPCA) directs the Secretary of Department of Health and Human Services, acting through the Director of the National Institutes of Health and in consultation with the Commissioner of the FDA and experts in pediatric research, to develop and prioritize a list of off-patent drugs for which pediatric studies are most urgently needed. Meropenem is one of such off-patent drugs.

Meropenem, a carbapenem, belongs to an antibiotic class that possesses one of the broadest spectra of antimicrobial activity available, including most of the bacterial pathogens responsible for serious, life-threatening infections occurring in young (<91 days) infants. Meropenem is stable against hydrolysis by most extended spectrum beta-lactamases and AmpC chromosomal beta-lactamases underscoring the drug’s activity against many antibiotic resistant Gram positive (e.g., penicillin-resistant S. pneumoniae) and Gram negative (e.g., P. aeruginosa) bacteria. Important indications for meropenem involve infections due to multi-drug resistant pathogens and polymicrobial sepsis. Meropenem is FDA-labeled for pediatric patients from three months of age through adolescence as single agent antimicrobial therapy for bacterial meningitis and complicated intra-abdominal infections. There is substantial off-label use of meropenem in neonates and infants <3 months of age. This off-label use occurs despite the lack of adequate meropenem PK, dosing, tolerability and safety data for this vulnerable patient group. The present proposal aims to determine PK and safety of meropenem for the treatment of suspected and complicated intra-abdominal infections in infants <3 months of age.

## 7.2 Meropenem Background

The Best Pharmaceuticals for Children Act mandates the National Institutes of Health (NIH) to prioritize drugs (and in 2007 therapeutic areas) in critical need for pediatric labeling, sponsor pediatric clinical trials, and submit these data to FDA for consideration of labeling changes. This work was delegated to the Eunice Kennedy Shriver National Institute of Child Health and Human Development (NICHD). The NICHD prioritized meropenem as such a drug in its 2003 Federal Register notice (FR68: 156; August 13, 2003). The labeling gap was for infants <90 days of age with suspected or confirmed intra-abdominal infections. The question driving this Written Request (WR) was “does meropenem cause seizures, and if so, is it at the same rate as imipenem?” The NIH was involved in multiple meetings with US Food and Drug Administration (FDA) regarding elements of the WR for meropenem. There was considerable discussion regarding the elements of Study 2, a randomized trial of 600 infants (assuming a 1% seizure rate), 300 of who were to receive an antibiotic regimen without meropenem and 300 to receive the same antibiotic regimen with meropenem. NIH received the WR for meropenem in 2005. Two meetings were held between NIH and FDA, one with the review division without the clinical pharmacology reviewers on September 6, 2006, and a follow-up meeting with the clinical pharmacology reviewers on October 18, 2006, to discuss the NIH’s position that it was not possible to perform Study 2. Dr. Anne Zajicek of NIH and Dr. Lisa Mathis of FDA attended both meetings. The lack of feasibility was based on two factors: 1) input from academic neonatologists across the US, including members of the NICHD Neonatal Research Units Network which performs many RCTs in infants; and 2) the fact that since the trial was powered to detect a safety signal with an assumed 1% rate of seizures from imipenem, which may not have reflected the seizure rate from meropenem, even 600 infants may have been insufficient to answer the question. At the conclusion of these meetings, the WR remained in place and the NIH position was clear that Study 2 would not go forward.

The NIH Request for Proposal for meropenem was released in 2007. The Statement of Work contained the work described in Study 1 of the WR, and determination of the potential number of patients who would qualify for Study 2 at the study sites. The contract was awarded in 2007 to Duke University. Patient enrollment began in June 2008 and was completed in October 2009 with 200 infants.

The Written Request for Study 1 included both single dose and multiple dose pharmacokinetics. Due to ethical issues of giving sick neonates a single dose of a broad-spectrum antibiotic, which arose during both the RFP Special Emphasis Panel review and the Data Monitoring Committee review, it was determined that the single dose PK would be from the first dose of a clinically indicated course of meropenem treatment. A special review panel, including neonatologists and neurologists, was convened to review all adverse events of special interest including seizures and hepatotoxicity.

## 7.3 Metabolism in Adults

Meropenem mean peak plasma concentrations were approximately 23 μg/mL (range 14-26) for 500 mg single dose and 49 μg/mL (range 39-58) for a 1 g single dose in adult volunteers. Following intravenous doses of 500 mg in adults mean plasma concentrations of meropenem usually decline to approximately 1 μg/mL at 6 hours after administration. In patients with normal renal function, the elimination half-life of meropenem is approximately 1 hour. Approximately 70% of the intravenously administered dose is recovered as unchanged meropenem in the urine over 12 hours, after which little further urinary excretion is detectable. Urinary concentrations of meropenem in excess of 10 μg/mL are maintained for up to 5 hours after a 500 mg dose. No accumulation of meropenem in plasma or urine was observed with regimens using 500 mg administered every 8 hours or 1 g administered every 6 hours in volunteers with normal renal function. Plasma protein binding of meropenem is approximately 2%. There is one metabolite which is microbiologically inactive.

## 7.4 Previous Studies in Children

Two large-scale multi-center randomized studies have been published as of July 2011. The first of these compared meropenem to cefotaxime, with or without the addition of metronidazole or amikacin in 170 children, 3 months to 12 years^1^. Antibiotics were given empirically for presumed serious bacterial infection. Satisfactory clinical response was achieved in 98% of the meropenem-treated participants and in 93% receiving one of the cefotaxime regimens. Similar results were obtained in a study of 414 children between 1 month and 12 years given either meropenem or cefotaxime with or without clindamycin or tobramycin^3^. Children in the meropenem arm received 10 or 20 mg/kg; and illnesses included lower respiratory tract infection, urinary tract infection, septicemia, skin infections, and intra-abdominal infections. Meropenem was similar in efficacy to cefotaxime and ceftriaxone in infants and children with bacterial meningitis^4^.

## 7.5 Safety

The most commonly reported side effects considered related to meropenem in studies in children have been diarrhea (3.3 to 4.7%), diaper rash from yeast (3.1%), glossitis (tongue swelling) (1%), oral thrush (1.9%), nausea and vomiting (0.4 to 1%), rash (0.8%) and redness and swelling at the injection site (0.5%). In comparison trials, these reactions occurred in similar frequency in the comparison (cephalosporin) groups^1,5^. Similar results have also been observed in clinical trials of adult participants.

The potential for adverse CNS effects, particularly seizures, has been carefully studied with meropenem in older participants. All beta-lactam antibiotics have the potential to cause neurotoxicity. The mechanism for this adverse effect is believed to be competitive inhibition of gamma-aminobutyric acid (GABA). Imipenem has been linked to the development of seizures for several years. In adults, the incidence of this adverse effect has been as high as 3% in some reports. In children, neurotoxicity with imipenem has also been reported. Meropenem has less affinity for GABA receptors and has been found to cause less neurotoxicity than imipenem both in animal models and during clinical trials. In trials comparing meropenem to cephalosporin regimens, the incidence of seizures was not significantly different between groups. The only seizures reported in meropenem-treated pediatric patients to date have occurred during treatment for meningitis. No cases have been reported in children treated for non-CNS infections^5^.

## 7.6 Studies in Young Infants

Van Enk et al. reported the results from 7 preterm infants (gestational ages 27-32 weeks, chronological ages 5-44 days) who were treated for infections with meropenem at a dose of 15 mg/kg every 12 hours^6^. Meropenem PK parameter estimates were highly variable and significantly different from older infants, age 2-5 months^7,8,9^. Meropenem clearance in these 7 neonates was 40% less and V_d_ 50% greater than infants, resulting in an average half-life twice that of older infants.

Two studies in young infants have been completed. The first study evaluated single dose PK of meropenem (10, 20 or 40 mg/kg) in 37 newborn infants (23 preterm and 15 full term) who already were receiving empirical antibacterial treatment for presumed infection^10^. There were no drug-related AEs reported. Based on the data generated by this single-dose study, the investigators recommended that a regimen of 20 mg/kg meropenem every 8 hours should result in adequate meropenem systemic exposure; however, few of these infants were <30 weeks gestational age in the first week of life. The second completed study supports 20-30mg/kg as the initial doses for younger and more mature infants, respectively. This study included a population PK analysis of meropenem in preterm and term infants^11^. Of the 37 infants enrolled, 22 were preterm and the mean gestational age was 30 weeks. The preponderance of preterm infants in this study complements the van den Anker study. The population analysis demonstrated an effect of post-conception age where post-conception age is defined as PNA + GA at birth. Additionally, serum creatinine was correlated with meropenem clearance. The model predicted meropenem dosed in preterm infants at 20-30 mg/kg q 8-12hr would maintain serum concentrations above 4 μg/mL for >75% of the dose interval in about 75% of simulated infants.

## 7.7 Rationale for the Proposed Study

The last 30 years have seen a substantial rise in antibiotic resistance by common bacterial pathogens. This increasing microbial drug resistance requires the use of antibiotics with broad spectrum activity that can be relied upon when first line antimicrobials fail. Imipenem-cilastatin and meropenem are carbapenems with widespread pediatric use. Imipenem-cilastatin has been labeled for use in pediatric patients (including newborns) for many serious infections such as pneumonia, skin and skin structure infections, osteomyelitis and complicated intra-abdominal infections. Meropenem is labeled for pediatric patients from three months of age through adolescence as single agent antimicrobial therapy for meningitis and complicated intra-abdominal infections, and is a recommended option for monotherapy of high severity, complicated intra-abdominal infections in adults^12^.

There is significant off-label use of meropenem in newborn and infant patients <3 months of age. For example, in 2003, the Child Health Corporation of America Pediatric Health Information System dataset (inpatient data from 31 free-standing children’s hospitals) mentions 589 uses in this population for serious infections such as necrotizing enterocolitis and peritonitis. This off-label use occurs despite the lack of adequate PK, dosing, tolerability and safety data for this vulnerable age group. Collecting this data through the study of infants with complicated intra-abdominal infections will fill this knowledge gap. The FDA has made a formal Written Request (WR), pursuant to Section 505A of the Federal Food, Drug, and Cosmetic Act, to obtain needed pediatric information on meropenem. This written request is provided in Appendix 16.1.13.

The present study was designed to characterize single dose meropenem PK, safety and tolerability in preterm and term newborn and infant participants with complicated intra-abdominal infections. The following were requested in the WR:

- To characterize the safety profile of meropenem in the treatment of complicated intra-abdominal infections.
- To characterize meropenem multiple-dose PK in participants with complicated intra-abdominal infections.
- To assess collected efficacy data for meropenem for the treatment of complicated intra-abdominal infections.