# 6 INVESTIGATORS AND STUDY ADMINISTRATIVE STRUCTURE

## 6.1 Principal Investigators

This multi-center study was conducted at 24 study sites in the United States which were a part of the Pediatric Off-Patent Drug Studies (PODS) network. A list of principal investigators and their affiliations, roles in the study, and curriculum vitae are provided in Appendix 16.1.4. The signatures of the sponsor’s responsible medical officer, medical monitor, and coordinating investigator for this study appear in Appendix 16.1.5.

## 6.2 Administrative Structure

The following is a list of organizations that were critical to the conduct of the study:

Sponsor | Eunice Kennedy Shriver National Institute of Child Health and Human Development; National Institutes of Health; 6100 Executive Blvd, Suite 4A01, MSC 7510; Bethesda, MD 20892-7510
PODS Center | Daniel K. Benjamin, MD, PhD, MPH; Duke Clinical Research Institute; 2400 Pratt Street; Durham, NC 27715
BPCA-CC | Premier Research Group Limited; 1500 Market Street, Suite 3500; Philadelphia, PA 19102
BPCA DCC as of July 29, 2009 | The EMMES Corporation; 401 N. Washington Street, Suite 700; Rockville, MD 20850
Pharmacokinetic Sample Analyses | Pediatric Pharmacology Research Laboratory; University Hospitals of Cleveland; Rainbow Babies and Children’s Hospitals; 11100 Euclid Avenue, Room 4030; Cleveland, OH 44106
Pharmacokineticist | ▬▬▬▬▬; Pediatrics Division of Clinical Pharmacology and Developmental Therapeutics; Schools of Medicine and Pharmacy & Pharmaceutical Sciences; University of California; San Diego, CA 92093