# 5 ETHICS

## 5.1 Institutional Review Board

The protocol NICHD-2005-18, protocol amendments and parental permissions/informed consent forms (ICFs) were reviewed and approved by each site’s duly constituted Institutional Review Board (IRB) prior to the Sponsor releasing study drug to the investigators, as required by United States Food and Drug Administration (FDA) Regulations (21 Code of Federal Regulations [CFR] Parts 50 and 56) and International Conference on Harmonization (ICH) Guidelines for Good Clinical Practice (GCP), Topic E6. A letter documenting the IRB approval was provided to the Best Pharmaceuticals for Children Act Data Coordinating Center (BPCA DCC) prior to the initiation of the study. Amendments to the protocol were answerable to the same requirements as the original protocol. The BPCA DCC maintained copies of these approvals.

The investigators complied with all legal obligations to make certain that all aspects of the IRB review were conducted in accordance with current institutional, local, and national regulations. The investigators submitted all periodic reports and updates that the IRB might have required, including any final close-out reports. The investigators also informed the IRB of any serious or unexpected adverse events (AEs), whether requiring study withdrawal or not, that were likely to affect the safety of the participants or the conduct of the study.

The final protocol and all amendments for study NICHD-2005-18 are located in Appendix 16.1.1. A list of the IRBs can be found in Appendix 16.1.3.

## 5.2 Ethical Conduct of the Study

Study NICHD-2005-18 was performed in accordance with the ethical principles stated in the Declaration of Helsinki, the applicable FDA CFR (21 CFR Parts 50, 56, and 312), and ICH GCP (E6).

## 5.3 Participant Information and Consent

Parental permission/informed consent were obtained in accordance with 21 CFR Part 50.25 and all other applicable regulatory requirements. Prior to the initiation of any study procedures, the investigator (or designee) informed the participant’s legally authorized representative of all aspects pertaining to study participation.

Information was given in both oral and written form whenever possible and deemed appropriate by the IRB. The participant’s legally authorized representatives were allowed to ask and have answered questions concerning all portions of the conduct of the study. The investigator (or designee) and the participant’s legally authorized representative signed and dated the ICF. An original signed ICF were retained in the site study records. The participant’s legally authorized representative received a copy of the signed and dated ICF.

The ICF generated by the investigator with the assistance of BPCA DCC was approved (along with the protocol) by the IRB and was acceptable to the Steering Committee. Parental permission/informed consent were documented by the use of a written ICF approved by the IRB and signed and dated by the participant’s legally authorized representative. Each signed ICF was kept on file by the investigators for possible inspection by BPCA DCC, Regulatory Authorities, and the National Institute of Child Health and Human Development (NICHD) or its designees. Copies of the sample ICF form are provided in Appendix 16.1.3.