# 15 REFERENCE LIST

1 Schuler D, Meropenem Study Group: Safety and efficacy of meropenem in hospitalized children: Randomized comparison with cefotaxime, alone and combined with metronidazole or amikacin. J Antimicrob Chemother 1995; 36(Suppl A):99–108.8543503
2 Jin C, , Low convulsive activity of a new carbapenem antibiotic, DK-35C, as compared with existing congeners. Toxicology 1999; 138(2):59–67.10576583
3 Arrieta A. Use of meropenem in the treatment of serious infections in children: Review of the current literature. Clin Infect Dis 1997; 24(Suppl 2):S207–212.9126695
4 Odio CM, Puig J, Feris J. Prospective, randomized, investigator-blinded study of the efficacy and safety of meropenem vs. cefotaxime therapy in bacterial meningitis in children. Pediatr Infect Dis J 1999; 18(7): 581–590.10440432
5 Bradley JS, Faulkner KL, Klugman KP. Efficacy, safety and tolerability of meropenem as empiric antibiotic therapy in hospitalized pediatric participants. Pediatr Infect Dis J 1996; 15:749–757.8858694
6 Van Enk JG, Touw DJ, Lafeber HN. Pharmacokinetics of meropenem in preterm neonates. Ther Drug Monit 2001; 23:198–201.11360025
7 Blumer JL, Reed MD, Kearns GL, . Sequential, single-dose pharmacokinetic evaluation of meropenem in hospitalized infants and children. Antimicrob Agent Chemother 1995; 39:1721–1725.
8 Blumer JL. Pharmacokinetic determinants of carbapenem therapy in neonates and children. Pediatr Infect Dis J 1996; 15:733–737.8858691
9 Parker EM, Hutchison M, Blumer JL. The pharmacokinetics of meropenem in infants and children: A population analysis. J Antimicrob Chem 1995; 36(Suppl A):63–71.
10 Van den Anker JN, Pokorna P, Kinzig-Schippers M, Martinkova J, de Groot R, Drusano GL, . Meropenem pharmacokinetics in the newborn. Antimicrob Agents Chemother 2009 Sep; 53(9):3871–3879.19581463
11 Capparelli E, Cannavino C, Rasmussen M, Bradley JS. Meropenem population pharmacokinetics in infants - Developmental changes in elimination. Abstract, International Conference on Antimicrobial Agents and Chemotherapy, 2006.
12 Solomkin JS, Mazuski JE, Baron EJ, Sawyer RG, Nathens AB, DiPiro JT, Buchman T, Dellinger EP, Jernigan J, Gorbach S, Chow AW, Bartlett J. Guidelines for the selection of anti-infective agents for complicated intra-abdominal infections. Clin Infect Dis 2003; 37:997–1005.14523762
13 Bhandari V, Bizzarro MJ, . Familial and genetic susceptibility to major neonatal morbidities in preterm twins. Pediatrics 2006; 117(6):1901–1906.16740829
14 Bizzarro MJ, Hussain N, . Genetic susceptibility to retinopathy of prematurity. Pediatrics 2006; 118(5):1858–1863.17079555
15 Bokodi G, Derzbach L, . Association of interferon gamma T+874A and interleukin 12 p40 promoter CTCTAA/GC polymorphism with the need for respiratory support and perinatal complications in low birthweight neonates. Arch Dis Child Fetal Neonatal Ed 2007; 92(1):F25–29.16754651
16 Moonen RM, Paulussen AD, . Carbamoyl phosphate synthetase polymorphisms as a risk factor for necrotizing enterocolitis. Pediatr Res 2007; 62(2):188–190.17597649
17 Szebeni B, Szekeres R, . Genetic polymorphisms of CD14, toll-like receptor 4, and caspase-recruitment domain 15 are not associated with necrotizing enterocolitis in very low birth weight infants. J Pediatr Gastroenterol Nutr 2006; 42(1):27–31.16385250
18 Treszl A, Heninger E, . Lower prevalence of IL-4 receptor alpha-chain gene G variant in very-low-birth-weight infants with necrotizing enterocolitis. J Pediatr Surg 2003; 38(9):1374–1378.14523823
19 Evans WE, McLeod HL. Pharmacogenomics - Drug disposition, drug targets, and side effects. N Engl J Med 2003; 348(6):538–549.12571262
20 Daly TM, Dumaual CM, . Multiplex assay for comprehensive genotyping of genes involved in drug metabolism, excretion, and transport. Clin Chem 2007; 53(7):1222–1230.17510302
21 Overall JC Jr. Neonatal bacterial meningitis. Analysis of predisposing factors and outcome compared with matched control participants. J Pediatr 1970; 76(4):499–511.5420788
22 Stoll BJ, Hansen NI, . Neurodevelopmental and growth impairment among extremely low-birth-weight infants with neonatal infection. JAMA 2004; 292(19):2357–2365.15547163
23 Goitein K, Michel J, Sacks T. Penetration of parenterally administered gentamicin into the cerebrospinal fluid in experimental meningitis. Chemotherapy 1975; 21(3–4):181–188.1157573
24 Duro D, Mitchell PD, Kalish LA, . Risk factors for parenteral nutrition-associated liver disease following surgical therapy for necrotizing enterocolitis. J Pediatr Gastroenterol Nutr. 2011 May; 52(5):595–600.21464752
25 Lucas A, Brooke OG, Baker BA, Bishop N, Morley R. High alkaline phosphatase activity and growth in preterm neonates. Arch Dis Child 1989 Jul; 64(7 Spec No):902–909.2774631
26 Kubota A, Yonekura T, Hoki M, . Total parenteral nutrition-associated intrahepatic cholestasis in infants: 25 years’ experience. J Pediatr Surg 2000 Jul; 35(7):1049–1051.10917294
27 Bradley JS, Faulkner KL, Klaugman KP. Efficacy, safety and tolerability of meropenem as empiric antibiotic therapy in hospitalized pediatric patients. Pediatr Infect Dis J 1996 Aug; 15(8):749–757.8858694
28 Jin C, Jung I, Ku HJ, . Low convulsive activity of a new carbapenem antibiotic, DK-35C, as compared with existing congeners. Toxicology 1999 Nov 5; 138(2):59–67.10576583