# 14 TABLES, FIGURES, AND NARRATIVES

## 14.1 Demographic and Baseline Characteristics Summary Tables

14.1.1 Participant Accounting and Final Study Disposition by Gestational and Postnatal Age Stratum
14.1.2 Investigational Site Accounting Summary
  14.1.2.1 Investigational Site Accounting Summary for GA <32 Weeks, PNA <2 Weeks
  14.1.2.2 Investigational Site Accounting Summary for GA <32 Weeks, PNA ≥2 Weeks
  14.1.2.3 Investigational Site Accounting Summary for GA ≥32 Weeks, PNA <2 Weeks
  14.1.2.4 Investigational Site Accounting Summary for GA ≥32 Weeks, PNA ≥2 Weeks
14.1.3 Baseline Demographics Profile and Physical Characteristics by Gestational and Postnatal Age Stratum
14.1.4 Baseline Medical History by Gestational and Postnatal Age Stratum
14.1.5 Baseline Abdominal Surgical History by Gestational and Postnatal Age Stratum
14.1.6 Baseline Radiography Findings by Gestational and Postnatal Age Stratum
14.1.7 Baseline Abnormal Physical Examination Findings by Gestational and Postnatal Age Stratum
14.1.8 Indication for Meropenem by Gestational and Postnatal Age Stratum
14.1.9 Prior Medications
  14.1.9.1 Prior Cardioactive Drugs by Gestational and Postnatal Age Stratum
  14.1.9.2 Prior Medications by Gestational and Postnatal Age Stratum

## 14.2 Efficacy Data

14.2 Summary of Efficacy Components by Gestational and Postnatal Age Stratum

## 14.3 Safety Data

14.3.1 Displays of Adverse Events
  14.3.1.1 Overall Summary of Treatment-Emergent Adverse Events by Gestational and Postnatal Age Stratum
  14.3.1.2 Summary of Treatment-Emergent Adverse Events by Gestational, Postnatal Age Stratum, MedDRA System Organ Class, and Preferred Term
  14.3.1.3 Summary of Treatment-Emergent Adverse Events by Gestational, Postnatal Age Stratum, MedDRA System Organ Class, Preferred Term, and by Severity
  14.3.1.4 Summary of Treatment-Emergent Adverse Events by Gestational, Postnatal Age Stratum, MedDRA System Organ Class, Preferred Term, and by Relationship
  14.3.1.5 Summary of Level 2 Laboratory Adverse Events by Gestational, Postnatal Age Stratum, MedDRA System Organ Class, and Preferred Term
14.3.2 Listings of Deaths, Other Serious and Significant Adverse Events
  14.3.2.1 Summary of Adverse Events of Special Interest by Gestational, Postnatal Age Stratum, MedDRA System Organ Class, and Preferred Term
  14.3.2.2 Summary of Adverse Events of Seizures by Gestational, Postnatal Age Stratum, MedDRA System Organ Class, and Preferred Term
  14.3.2.3 Summary of Serious Adverse Events by Gestational, Postnatal Age Stratum, MedDRA System Organ Class, and Preferred Term
  14.3.2.4 Summary of Treatment-Emergent Adverse Events Leading to Study Drug Discontinuation by Gestational, Postnatal Age Stratum, MedDRA System Organ Class, and Preferred Term
  14.3.2.5 Summary of Treatment-Emergent Adverse Events Resulting in Death by Gestational, Postnatal Age Stratum, MedDRA System Organ Class, and Preferred Term
  14.3.2.6 Analysis of Key Safety Endpoints
  14.3.2.7 Analysis of Seizures
14.3.3 Narratives of Deaths, Other Serious and Certain Other Significant Adverse Events
14.3.4 Abnormal Laboratory Value Listings
  14.3.4.1 Summary of Blood Chemistry by Scheduled Visit, Gestational and Postnatal Age Stratum Tests
  14.3.4.2 Summary of Change of Blood Chemistry from Baseline to Each Scheduled Visit by Gestational and Postnatal Age Stratum Tests
  14.3.4.3 Summary of Blood Chemistry Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests
  14.3.4.4 Summary of Shift of Blood Chemistry Interpretations from Baseline to Each Scheduled visit by Gestational and Postnatal Age Stratum Tests
  14.3.4.5 Summary of the Extreme Values by Gestational and Postnatal Age Stratum
    14.3.4.5.1 Summary of the Extreme Values of Liver Toxicity AST (U/L) by Gestational and Postnatal Age Stratum
    14.3.4.5.2 Summary of the Extreme Values of Liver Toxicity ALT (U/L) by Gestational and Postnatal Age Stratum
    14.3.4.5.3 Summary of the Extreme Values of Liver Toxicity Direct Bilirubin (mg/dL) by Gestational and Postnatal Age Stratum
  14.3.4.6 Summary of Blood Hematology by Gestational and Postnatal Age Stratum Tests
  14.3.4.7 Summary of Change of Blood Hematology by Gestational and Postnatal Age Stratum Tests
  14.3.4.8 Summary of Blood Hematology Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests
  14.3.4.9 Summary of Shift of Blood Hematology Interpretations from Baseline to Each Scheduled Visit by Gestational and Postnatal Age Stratum Tests
  14.3.4.10 Summary of Growth Parameters by Scheduled Visit, Gestational and Postnatal Age Stratum
    14.3.4.10.1 Summary of Growth Parameters Weight (grams) by Scheduled Visit, Gestational and Postnatal Age Stratum
    14.3.4.10.2 Summary of Growth Parameters Length (cm) by Scheduled Visit, Gestational and Postnatal Age Stratum
    14.3.4.10.3 Summary of Growth Parameters Head Circumference (cm) by Scheduled Visit, Gestational and Postnatal Age Stratum
  14.3.4.11 Summary of Change Growth Parameters from Baseline to Each Scheduled Visit, Gestational and Postnatal Age Stratum
    14.3.4.11.1 Summary of Change Growth Parameters Weight (grams) from Baseline to Each Scheduled Visit, Gestational and Postnatal Age Stratum
    14.3.4.11.2 Summary of Change Growth Parameters Length (cm) from Baseline to Each Scheduled Visit, Gestational and Postnatal Age Stratum
    14.3.4.11.3 Summary of Change Growth Parameters Head Circumference (cm) from Baseline to Each Scheduled Visit, Gestational and Postnatal Age Stratum
  14.3.4.12 Summary of Vital Signs by Scheduled Visit, Gestational and Postnatal Age Stratum
    14.3.4.12.1 Summary of Vital Signs Heart Rate (bpm) by Scheduled Visit, Gestational and Postnatal Age Stratum
    14.3.4.12.2 Summary of Vital Signs Respiration Rate (rpm) by Scheduled Visit, Gestational and Postnatal Age Stratum
    14.3.4.12.3 Summary of Vital Signs Systolic Blood Pressure (mmHg) by Scheduled Visit, Gestational and Postnatal Age Stratum
    14.3.4.12.4 Summary of Vital Signs Diastolic Blood Pressure (mmHg) by Scheduled Visit, Gestational and Postnatal Age Stratum
  14.3.4.13 Summary of Change Vital Signs from Baseline to Each Scheduled Visit, Gestational and Postnatal Age Stratum
    14.3.4.13.1 Summary of Change Vital Signs Heart Rate (bpm) from Baseline to Each Scheduled Visit, Gestational and Postnatal Age Stratum
    14.3.4.13.2 Summary of Change Vital Signs Respiration Rate (rpm) from Baseline to Each Scheduled Visit, Gestational and Postnatal Age Stratum
    14.3.4.13.3 Summary of Change Vital Signs Systolic Blood Pressure (mmHg) from Baseline to Each Scheduled Visit, Gestational and Postnatal Age Stratum
    14.3.4.13.4 Summary of Change Vital Signs Diastolic Blood Pressure (mmHg) from Baseline to Each Scheduled Visit, Gestational and Postnatal Age Stratum
14.3.5 Concomitant Medications by Gestational and Postnatal Age Stratum

Table 14.1.1 Participant Accounting and Final Study Disposition by Gestational and Postnatal Age Stratum

Population: Enrolled Participants

Participant Accounting | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Participant Accounting | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants
Enrolled^1^ | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Safety^2^ | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Efficacy^3^ | 39 (100.0%) | 101 (98.1%) | 28 (90.3%) | 27 (100.0%) | 195 (97.5%)
Completed | 35 (89.7%) | 94 (91.3%) | 26 (83.9%) | 24 (88.9%) | 179 (89.5%)
Early Termination | 4 (10.3%) | 9 (8.7%) | 5 (16.1%) | 3 (11.1%) | 21 (10.5%)
Reasons for Early Termination
Parent/guardian withdrew consent | 0 | 0 | 2 (6.5%) | 0 | 2 (1.0%)
Investigator judgment | 1 (2.6%) | 3 (2.9%) | 0 | 0 | 4 (2.0%)
Protocol non-compliance (after enrollment) | 1 (2.6%) | 0 | 0 | 1 (3.7%) | 2 (1.0%)
Serious Adverse Event/Adverse Event | 0 | 1 (1.0%) | 0 | 1 (3.7%) | 2 (1.0%)
Subject death | 2 (5.1%) | 5 (4.9%) | 0 | 0 | 7 (3.5%)
Subject discharced prior to study day 28 and final assessments were not complete | 0 | 0 | 3 (9.7%) | 1 (3.7%) | 4 (2.0%)

For Safety^2^ and efficacy^3^ population, the percentages are based on the total number of enrolled Participants in each age group or total.

All other percentages are based on the total number of safety Participants in each age group or total.

1 The Enrolled Population includes all Participants in the data base who provide informed consent regardless of the Participant’s treatment status in the trial.

2 The Safety Population includes all Participants who receive any amount of study Meropenem.

3 The Efficacy Population includes all Participants who have efficacy assessment at Pre-Dose and Study Day 28.

Table 14.1.2.1 Investigational Site Accounting Summary for GA<32 Weeks, PNA<2 Weeks

Population: Enrolled Participants

Site | Enrolled^1^ | Safety^2^ | Efficacy^3^ | Completed | Early Termination
Total | 39 | 39 (100.0%) | 39 (100.0%) | 35 (89.7%) | 4 (10.3%)
4 | 2 | 2 (100.0%) | 2 (100.0%) | 2 (100.0%) | 0 (0.0%)
7 | 1 | 1 (100.0%) | 1 (100.0%) | 1 (100.0%) | 0 (0.0%)
9 | 4 | 4 (100.0%) | 4 (100.0%) | 4 (100.0%) | 0 (0.0%)
10 | 1 | 1 (100.0%) | 1 (100.0%) | 1 (100.0%) | 0 (0.0%)
11 | 3 | 3 (100.0%) | 3 (100.0%) | 2 (66.7%) | 1 (33.3%)
12 | 4 | 4 (100.0%) | 4 (100.0%) | 2 (50.0%) | 2 (50.0%)
13 | 1 | 1 (100.0%) | 1 (100.0%) | 1 (100.0%) | 0 (0.0%)
14 | 2 | 2 (100.0%) | 2 (100.0%) | 2 (100.0%) | 0 (0.0%)
15 | 1 | 1 (100.0%) | 1 (100.0%) | 1 (100.0%) | 0 (0.0%)
16 | 4 | 4 (100.0%) | 4 (100.0%) | 4 (100.0%) | 0 (0.0%)
17 | 3 | 3 (100.0%) | 3 (100.0%) | 2 (66.7%) | 1 (33.3%)
18 | 1 | 1 (100.0%) | 1 (100.0%) | 1 (100.0%) | 0 (0.0%)
19 | 3 | 3 (100.0%) | 3 (100.0%) | 3 (100.0%) | 0 (0.0%)
20 | 1 | 1 (100.0%) | 1 (100.0%) | 1 (100.0%) | 0 (0.0%)
21 | 3 | 3 (100.0%) | 3 (100.0%) | 3 (100.0%) | 0 (0.0%)
22 | 1 | 1 (100.0%) | 1 (100.0%) | 1 (100.0%) | 0 (0.0%)
24 | 2 | 2 (100.0%) | 2 (100.0%) | 2 (100.0%) | 0 (0.0%)
25 | 2 | 2 (100.0%) | 2 (100.0%) | 2 (100.0%) | 0 (0.0%)

For Safety^2^ and efficacy^3^ population, the percentages are based on the total number of enrolled Participants in each age group or total at each site.

All other percentages are based on the total number of safety Participants in each age group or total at each site.

1 The Enrolled Population includes all Participants in the data base who provide informed consent regardless of the Participant’s treatment status in the trial.

2 The Safety Population includes all Participants who receive any amount of study Meropenem.

3 The Efficacy Population includes all Participants who have efficacy assessment at Pre-Dose and Study Day 28.

Table 14.1.2.2 Investigational Site Accounting Summary for GA<32 Weeks, PNA>=2 Weeks

Population: Enrolled Participants

Site | Enrolled^1^ | Safety^2^ | Efficacy^3^ | Completed | Early Termination
Total | 103 | 103 (100.0%) | 101 (98.1%) | 94 (91.3%) | 9 (8.7%)
1 | 7 | 7 (100.0%) | 6 (85.7%) | 6 (85.7%) | 1 (14.3%)
2 | 1 | 1 (100.0%) | 1 (100.0%) | 1 (100.0%) | 0 (0.0%)
4 | 2 | 2 (100.0%) | 2 (100.0%) | 1 (50.0%) | 1 (50.0%)
5 | 1 | 1 (100.0%) | 1 (100.0%) | 1 (100.0%) | 0 (0.0%)
6 | 3 | 3 (100.0%) | 2 (66.7%) | 2 (66.7%) | 1 (33.3%)
7 | 7 | 7 (100.0%) | 7 (100.0%) | 7 (100.0%) | 0 (0.0%)
8 | 4 | 4 (100.0%) | 4 (100.0%) | 3 (75.0%) | 1 (25.0%)
9 | 6 | 6 (100.0%) | 6 (100.0%) | 4 (66.7%) | 2 (33.3%)
11 | 12 | 12 (100.0%) | 12 (100.0%) | 11 (91.7%) | 1 (8.3%)
12 | 10 | 10 (100.0%) | 10 (100.0%) | 10 (100.0%) | 0 (0.0%)
14 | 3 | 3 (100.0%) | 3 (100.0%) | 3 (100.0%) | 0 (0.0%)
15 | 6 | 6 (100.0%) | 6 (100.0%) | 6 (100.0%) | 0 (0.0%)
16 | 6 | 6 (100.0%) | 6 (100.0%) | 6 (100.0%) | 0 (0.0%)
17 | 6 | 6 (100.0%) | 6 (100.0%) | 6 (100.0%) | 0 (0.0%)
18 | 3 | 3 (100.0%) | 3 (100.0%) | 3 (100.0%) | 0 (0.0%)
19 | 4 | 4 (100.0%) | 4 (100.0%) | 4 (100.0%) | 0 (0.0%)
20 | 4 | 4 (100.0%) | 4 (100.0%) | 4 (100.0%) | 0 (0.0%)
21 | 6 | 6 (100.0%) | 6 (100.0%) | 4 (66.7%) | 2 (33.3%)
22 | 1 | 1 (100.0%) | 1 (100.0%) | 1 (100.0%) | 0 (0.0%)
23 | 5 | 5 (100.0%) | 5 (100.0%) | 5 (100.0%) | 0 (0.0%)
24 | 6 | 6 (100.0%) | 6 (100.0%) | 6 (100.0%) | 0 (0.0%)

For Safety^2^ and efficacy^3^ population, the percentages are based on the total number of enrolled Participants in each age group or total at each site.

All other percentages are based on the total number of safety Participants in each age group or total at each site.

1 The Enrolled Population includes all Participants in the data base who provide informed consent regardless of the Participant’s treatment status in the trial.

2 The Safety Population includes all Participants who receive any amount of study Meropenem.

3 The Efficacy Population includes all Participants who have efficacy assessment at Pre-Dose and Study Day 28.

Table 14.1.2.3 Investigational Site Accounting Summary for GA>=32 Weeks, PNA<2 Weeks

Population: Enrolled Participants

Site | Enrolled^1^ | Safety^2^ | Efficacy^3^ | Completed | Early Termination
Total | 31 | 31 (100.0%) | 28 (90.3%) | 26 (83.9%) | 5 (16.1%)
1 | 1 | 1 (100.0%) | 1 (100.0%) | 0 (0.0%) | 1 (100.0%)
4 | 3 | 3 (100.0%) | 3 (100.0%) | 3 (100.0%) | 0 (0.0%)
6 | 3 | 3 (100.0%) | 3 (100.0%) | 3 (100.0%) | 0 (0.0%)
7 | 1 | 1 (100.0%) | 1 (100.0%) | 1 (100.0%) | 0 (0.0%)
9 | 3 | 3 (100.0%) | 2 (66.7%) | 2 (66.7%) | 1 (33.3%)
10 | 1 | 1 (100.0%) | 1 (100.0%) | 1 (100.0%) | 0 (0.0%)
11 | 1 | 1 (100.0%) | 1 (100.0%) | 1 (100.0%) | 0 (0.0%)
12 | 11 | 11 (100.0%) | 10 (90.9%) | 9 (81.8%) | 2 (18.2%)
23 | 4 | 4 (100.0%) | 4 (100.0%) | 4 (100.0%) | 0 (0.0%)
24 | 3 | 3 (100.0%) | 2 (66.7%) | 2 (66.7%) | 1 (33.3%)

For Safety^2^ and efficacy^3^ population, the percentages are based on the total number of enrolled Participants in each age group or total at each site.

All other percentages are based on the total number of safety Participants in each age group or total at each site.

1 The Enrolled Population includes all Participants in the data base who provide informed consent regardless of the Participant’s treatment status in the trial.

2 The Safety Population includes all Participants who receive any amount of study Meropenem.

3 The Efficacy Population includes all Participants who have efficacy assessment at Pre-Dose and Study Day 28.

Table 14.1.2.4 Investigational Site Accounting Summary for GA>=32 Weeks, PNA>=2 Weeks

Population: Enrolled Participants

Site | Enrolled^1^ | Safety^2^ | Efficacy^3^ | Completed | Early Termination
Total | 27 | 27 (100.0%) | 27 (100.0%) | 24 (88.9%) | 3 (11.1%)
4 | 1 | 1 (100.0%) | 1 (100.0%) | 1 (100.0%) | 0 (0.0%)
6 | 3 | 3 (100.0%) | 3 (100.0%) | 3 (100.0%) | 0 (0.0%)
7 | 1 | 1 (100.0%) | 1 (100.0%) | 1 (100.0%) | 0 (0.0%)
9 | 2 | 2 (100.0%) | 2 (100.0%) | 2 (100.0%) | 0 (0.0%)
12 | 7 | 7 (100.0%) | 7 (100.0%) | 6 (85.7%) | 1 (14.3%)
17 | 2 | 2 (100.0%) | 2 (100.0%) | 1 (50.0%) | 1 (50.0%)
19 | 2 | 2 (100.0%) | 2 (100.0%) | 2 (100.0%) | 0 (0.0%)
20 | 1 | 1 (100.0%) | 1 (100.0%) | 1 (100.0%) | 0 (0.0%)
22 | 2 | 2 (100.0%) | 2 (100.0%) | 2 (100.0%) | 0 (0.0%)
23 | 2 | 2 (100.0%) | 2 (100.0%) | 2 (100.0%) | 0 (0.0%)
24 | 4 | 4 (100.0%) | 4 (100.0%) | 3 (75.0%) | 1 (25.0%)

For Safety^2^ and efficacy^3^ population, the percentages are based on the total number of enrolled Participants in each age group or total at each site.

All other percentages are based on the total number of safety Participants in each age group or total at each site.

1 The Enrolled Population includes all Participants in the data base who provide informed consent regardless of the Participant’s treatment status in the trial.

2 The Safety Population includes all Participants who receive any amount of study Meropenem.

3 The Efficacy Population includes all Participants who have efficacy assessment at Pre-Dose and Study Day 28.

Table 14.1.3 Baseline Demographic profile and Physical Characteristics by Gestational and Postnatal Age Stratum

Population: Safety Participants

Category/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Category/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Gestational Age (Wks)
N | 39 | 103 | 31 | 27 | 200
Mean (SD) | 26.3 (2.7) | 26.6 (2.1) | 36.3 (2.4) | 35.5 (2.9) | 29.2 (4.9)
95% CI | 25.4, 27.2 | 26.2, 27.0 | 35.4, 37.2 | 34.4, 36.6 | 28.5, 29.9
Median | 26.0 | 26.3 | 36.0 | 34.4 | 27.8
Min, Max | 22.5, 31.5 | 23.0, 31.5 | 32.1, 40.0 | 32.0, 40.0 | 22.5, 40.0
Postnatal Age (Days)
N | 39 | 103 | 31 | 27 | 200
Mean (SD) | 8.5 (3.3) | 38.3 (19.3) | 6.5 (3.5) | 36.0 (22.0) | 27.3 (21.6)
95% CI | 7.4, 9.5 | 34.6, 42.1 | 5.2, 7.8 | 27.3, 44.7 | 24.2, 30.3
Median | 9.0 | 32.0 | 6.0 | 26.0 | 21.0
Min, Max | 1.0, 13.0 | 14.0, 92.0 | 1.0, 14.0 | 14.0, 82.0 | 1.0, 92.0
Gender
Male | 24 (61.5%) | 56 (54.4%) | 22 (71.0%) | 16 (59.3%) | 118 (59.0%)
Female | 15 (38.5%) | 47 (45.6%) | 9 (29.0%) | 11 (40.7%) | 82 (41.0%)
Ethnicity
Hispanic or Latino | 5 (12.8%) | 16 (15.5%) | 4 (12.9%) | 3 (11.1%) | 28 (14.0%)
Not Hispanic or Latino | 32 (82.1%) | 81 (78.6%) | 27 (87.1%) | 24 (88.9%) | 164 (82.0%)
Not reported | 2 (5.1%) | 6 (5.8%) | 0 | 0 | 8 (4.0%)
Race^1^
Asian | 0 | 1 (1.0%) | 0 | 1 (3.7%) | 2 (1.0%)
Black or African American | 12 (30.8%) | 33 (32.0%) | 8 (25.8%) | 6 (22.2%) | 59 (29.5%)
Native Hawaiian or Pacific Islander | 1 (2.6%) | 0 | 1 (3.2%) | 0 | 2 (1.0%)
White or Caucasian | 26 (66.7%) | 65 (63.1%) | 21 (67.7%) | 18 (66.7%) | 130 (65.0%)
Not reported | 0 | 2 (1.9%) | 1 (3.2%) | 1 (3.7%) | 4 (2.0%)
Other | 1 (2.6%) | 2 (1.9%) | 0 | 2 (7.4%) | 5 (2.5%)
Birth Weight (grams)
N | 39 | 103 | 31 | 26 | 199
Mean (SD) | 927.2 (421.0) | 908.4 (325.9) | 2650.3 (777.1) | 2414.0 (852.9) | 1380.1 (906.2)
95% CI | 790.8, 1063.7 | 844.7, 972.1 | 2365.2, 2935.3 | 2069.5, 2758.5 | 1253.5, 1506.8
Median | 725.0 | 843.0 | 2430.0 | 2354.0 | 1080.0
Min, Max | 490.0, 2109.0 | 330.0, 2165.0 | 1470.0, 4768.0 | 1190.0, 4240.0 | 330.0, 4768.0
Baseline Dosing Weight (grams)
N | 37 | 102 | 30 | 27 | 196
Mean (SD) | 904.7 (403.4) | 1426.2 (675.9) | 2629.5 (805.2) | 3138.1 (1223.8) | 1747.8 (1067.3)
95% CI | 770.2, 1039.2 | 1293.5, 1559.0 | 2328.9, 2930.2 | 2654.0, 3622.3 | 1597.4, 1898.1
Median | 720.0 | 1275.0 | 2415.0 | 3000.0 | 1400.0
Min, Max | 480.0, 2040.0 | 425.0, 3700.0 | 1375.0, 4768.0 | 1600.0, 6500.0 | 425.0, 6500.0
Baseline Length (cm)
N | 32 | 87 | 28 | 22 | 169
Mean (SD) | 34.7 (5.3) | 38.0 (5.1) | 47.2 (4.1) | 48.7 (5.6) | 40.3 (7.1)
95% CI | 32.8, 36.6 | 36.9, 39.1 | 45.6, 48.8 | 46.2, 51.1 | 39.2, 41.4
Median | 33.5 | 37.5 | 47.5 | 48.8 | 39.5
Min, Max | 26.8, 44.0 | 25.5, 53.0 | 40.5, 55.0 | 39.0, 61.5 | 25.5, 61.5
Baseline Head Circumference (cm)
N | 34 | 94 | 28 | 21 | 177
Mean (SD) | 23.6 (3.0) | 26.8 (3.5) | 32.0 (2.2) | 33.1 (3.5) | 27.8 (4.5)
95% CI | 22.6, 24.7 | 26.1, 27.5 | 31.1, 32.8 | 31.5, 34.7 | 27.1, 28.4
Median | 23.0 | 26.7 | 31.5 | 32.5 | 27.5
Min, Max | 20.0, 29.5 | 17.0, 35.0 | 28.5, 35.2 | 27.5, 39.0 | 17.0, 39.0
Dosing Day^2^ (Days)
N | 39 | 103 | 31 | 27 | 200
Mean (SD) | 8.6 (5.3) | 8.3 (4.6) | 7.8 (5.4) | 8.9 (5.0) | 8.4 (4.9)
95% CI | 6.9, 10.4 | 7.4, 9.2 | 5.8, 9.7 | 6.9, 10.9 | 7.7, 9.1
Median | 8.0 | 7.0 | 6.0 | 8.0 | 8.0
Min, Max | 3.0, 25.0 | 2.0, 22.0 | 2.0, 21.0 | 2.0, 22.0 | 2.0, 25.0

The percentages are based on the total number of safety Participants in each age group or total.

1 More than one race category can be indicated for a Participant.

2 Dosing days will be calculated as exact days study drug was administered.

Table 14.1.4 Baseline Medical History by Gestational and Postnatal Age Stratum

Population: Safety Participants

Category/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Category/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
ENT (Ears, Nose, Throat) | 0 | 5 (4.9%) | 1 (3.2%) | 2 (7.4%) | 8 (4.0%)
Eyes | 2 (5.1%) | 21 (20.4%) | 0 | 2 (7.4%) | 25 (12.5%)
Respiratory system | 37 (94.9%) | 101 (98.1%) | 17 (54.8%) | 22 (81.5%) | 177 (88.5%)
Cardiovascular system | 30 (76.9%) | 80 (77.7%) | 17 (54.8%) | 19 (70.4%) | 146 (73.0%)
Gastrointestinal system | 35 (89.7%) | 95 (92.2%) | 24 (77.4%) | 25 (92.6%) | 179 (89.5%)
Urinary system | 11 (28.2%) | 35 (34.0%) | 4 (12.9%) | 9 (33.3%) | 59 (29.5%)
Reproductive system | 0 | 2 (1.9%) | 3 (9.7%) | 1 (3.7%) | 6 (3.0%)
Blood & Lymphatic system | 37 (94.9%) | 99 (96.1%) | 21 (67.7%) | 24 (88.9%) | 181 (90.5%)
Musculoskeletal system | 7 (17.9%) | 16 (15.5%) | 2 (6.5%) | 3 (11.1%) | 28 (14.0%)
Dermatologic system | 8 (20.5%) | 19 (18.4%) | 4 (12.9%) | 4 (14.8%) | 35 (17.5%)
Neurological system | 19 (48.7%) | 55 (53.4%) | 7 (22.6%) | 8 (29.6%) | 89 (44.5%)
Other | 33 (84.6%) | 81 (78.6%) | 19 (61.3%) | 18 (66.7%) | 151 (75.5%)

The percentages are based on the total number of safety Participants in each age group or total.

Participants are counted once at each body system level.

Table 14.1.5 Baseline Abdominal Surgical History by Gestational and Postnatal Age Stratum

Population: Safety Participants

Procedures | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Procedures | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Number of Participants with Abdominal Surgical History | 22 (56.4%) | 35 (34.0%) | 16 (51.6%) | 16 (59.3%) | 89 (44.5%)
Laparotomy | 11 (28.2%) | 22 (21.4%) | 2 (6.5%) | 9 (33.3%) | 44 (22.0%)
Bowel resection (end to end anastomosis) | 5 (12.8%) | 14 (13.6%) | 3 (9.7%) | 2 (7.4%) | 24 (12.0%)
Jejunostomy/ileostomy/colostomy | 6 (15.4%) | 17 (16.5%) | 5 (16.1%) | 4 (14.8%) | 32 (16.0%)
Ostomy takedown/reanastomosis | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Peritoneal drain (for NEC) | 9 (23.1%) | 11 (10.7%) | 0 | 0 | 20 (10.0%)
Gastrostomy | 0 | 0 | 1 (3.2%) | 0 | 1 (0.5%)
Appendectomy | 0 | 0 | 0 | 1 (3.7%) | 1 (0.5%)
Fundoplication | 0 | 0 | 1 (3.2%) | 0 | 1 (0.5%)
T-E fistula/esophageal atresia repair | 0 | 0 | 1 (3.2%) | 0 | 1 (0.5%)
Gastroschisis/omphalocele repair | 0 | 0 | 8 (25.8%) | 3 (11.1%) | 11 (5.5%)
Diaphragmatic hernia repair | 0 | 0 | 0 | 5 (18.5%) | 5 (2.5%)
Silo Application | 0 | 0 | 1 (3.2%) | 0 | 1 (0.5%)
Other | 5 (12.8%) | 8 (7.8%) | 8 (25.8%) | 6 (22.2%) | 27 (13.5%)
Unknown | 0 | 0 | 0 | 1 (3.7%) | 1 (0.5%)

The percentages are based on the total number of safety Participants in each age group or total.

Participants are counted once at each surgical procedure.

Table 14.1.6 Baseline Radiography Findings by Gestational and Postnatal Age Stratum

Population: Safety Participants

Category/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Category/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
X-ray Taken
Yes | 38 (97.4%) | 89 (86.4%) | 24 (77.4%) | 23 (85.2%) | 174 (87.0%)
No | 1 (2.6%) | 14 (13.6%) | 7 (22.6%) | 4 (14.8%) | 26 (13.0%)
Projection
Antero-Posterior (A-P) only | 17 (43.6%) | 41 (39.8%) | 17 (54.8%) | 14 (51.9%) | 89 (44.5%)
Lateral only | 3 (7.7%) | 4 (3.9%) | 0 | 0 | 7 (3.5%)
Both A-P and Lateral | 17 (43.6%) | 42 (40.8%) | 6 (19.4%) | 7 (25.9%) | 72 (36.0%)
Radiography Finding^1^
Normal | 3 (7.7%) | 10 (9.7%) | 1 (3.2%) | 3 (11.1%) | 17 (8.5%)
Asymmetric bowel pattern | 0 | 5 (4.9%) | 1 (3.2%) | 4 (14.8%) | 10 (5.0%)
Non-specific bowel dilatation | 1 (2.6%) | 3 (2.9%) | 1 (3.2%) | 1 (3.7%) | 6 (3.0%)
Mild dilatation | 1 (2.6%) | 4 (3.9%) | 0 | 0 | 5 (2.5%)
Moderate dilatation | 2 (5.1%) | 4 (3.9%) | 1 (3.2%) | 1 (3.7%) | 8 (4.0%)
Severe dilatation | 1 (2.6%) | 0 | 1 (3.2%) | 1 (3.7%) | 3 (1.5%)
Focal distension | 1 (2.6%) | 4 (3.9%) | 1 (3.2%) | 0 | 6 (3.0%)
Bowel wall thickening | 1 (2.6%) | 1 (1.0%) | 0 | 1 (3.7%) | 3 (1.5%)
Separation of bowel loops | 2 (5.1%) | 1 (1.0%) | 0 | 0 | 3 (1.5%)
Featureless loops | 2 (5.1%) | 2 (1.9%) | 0 | 1 (3.7%) | 5 (2.5%)
Bubbly lucencies | 1 (2.6%) | 11 (10.7%) | 0 | 0 | 12 (6.0%)
Possible pneumatosis | 0 | 10 (9.7%) | 2 (6.5%) | 1 (3.7%) | 13 (6.5%)
Persistent loop | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
Pneumatosis intestinalis | 4 (10.3%) | 12 (11.7%) | 4 (12.9%) | 6 (22.2%) | 26 (13.0%)
Portal venous gas | 1 (2.6%) | 6 (5.8%) | 1 (3.2%) | 0 | 8 (4.0%)
Free air | 15 (38.5%) | 6 (5.8%) | 1 (3.2%) | 2 (7.4%) | 24 (12.0%)
Dilated bowel loops | 3 (7.7%) | 22 (21.4%) | 4 (12.9%) | 2 (7.4%) | 31 (15.5%)
Other | 14 (35.9%) | 32 (31.1%) | 11 (35.5%) | 10 (37.0%) | 67 (33.5%)

The percentages are based on the total number of safety Participants in each age group or total.

1 More than one radiography findings can be indicated for a Participant.

Table 14.1.7 Baseline Abnormal Physical Examination Findings by Gestational and Postnatal Age Stratum

Population: Safety Participants

Indication | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Indication | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Patient with Abnormal Finding | 37 (94.9%) | 99 (96.1%) | 28 (90.3%) | 23 (85.2%) | 187 (93.5%)
ENT (Ears, Nose, Throat) | 4 (10.3%) | 15 (14.6%) | 5 (16.1%) | 5 (18.5%) | 29 (14.5%)
Eyes | 5 (12.8%) | 5 (4.9%) | 3 (9.7%) | 0 | 13 (6.5%)
Respiratory system | 26 (66.7%) | 74 (71.8%) | 13 (41.9%) | 15 (55.6%) | 128 (64.0%)
Cardiovascular system | 10 (25.6%) | 25 (24.3%) | 7 (22.6%) | 9 (33.3%) | 51 (25.5%)
Gastrointestinal system | 30 (76.9%) | 86 (83.5%) | 24 (77.4%) | 17 (63.0%) | 157 (78.5%)
Urinary system | 1 (2.6%) | 10 (9.7%) | 1 (3.2%) | 3 (11.1%) | 15 (7.5%)
Reproductive system | 3 (7.7%) | 9 (8.7%) | 3 (9.7%) | 2 (7.4%) | 17 (8.5%)
Blood & Lymphatic system | 9 (23.1%) | 23 (22.3%) | 0 | 3 (11.1%) | 35 (17.5%)
Musculoskeletal system | 2 (5.1%) | 11 (10.7%) | 5 (16.1%) | 3 (11.1%) | 21 (10.5%)
Dermatologic system | 12 (30.8%) | 20 (19.4%) | 7 (22.6%) | 3 (11.1%) | 42 (21.0%)
Neurological system | 7 (17.9%) | 25 (24.3%) | 8 (25.8%) | 7 (25.9%) | 47 (23.5%)
Other | 5 (12.8%) | 13 (12.6%) | 0 | 4 (14.8%) | 22 (11.0%)

The percentages are based on the total number of safety Participants in each age group or total.

Participants are counted only once for each body system.

Table 14.1.8 Indication for Meropenem by Gestational and Postnatal Age Stratum

Population: Safety Participants

Indication^1^ | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Indication^1^ | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
NEC Grade II or higher by Bell’s criteria | 12 (30.8%) | 35 (34.0%) | 6 (19.4%) | 8 (29.6%) | 61 (30.5%)
Spontaneous perforation | 15 (38.5%) | 5 (4.9%) | 1 (3.2%) | 0 | 21 (10.5%)
Meconium ileus with perforation | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Bowel obstruction with perforation | 1 (2.6%) | 0 | 0 | 2 (7.4%) | 3 (1.5%)
Infant with Stage I NEC and would receive broad spectrum antibiotics per local s | 5 (12.8%) | 26 (25.2%) | 2 (6.5%) | 0 | 33 (16.5%)
Infant who is otherwise receiving meropenem per local standard of care | 8 (20.5%) | 33 (32.0%) | 13 (41.9%) | 11 (40.7%) | 65 (32.5%)
Peritonitis | 1 (2.6%) | 6 (5.8%) | 4 (12.9%) | 4 (14.8%) | 15 (7.5%)
Other | 4 (10.3%) | 15 (14.6%) | 10 (32.3%) | 4 (14.8%) | 33 (16.5%)

The percentages are based on the total number of safety Participants in each age group or total.

1 More than one indication can be present for a Participant.

Table 14.1.9.1 Prior Cardioactive Drugs ^1^ by Gestational and Postnatal Age Stratum

Population: Safety Participants

Indication | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Indication | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Number of Participants with Prior Cardioactive Drugs | 12 (30.8%) | 17 (16.5%) | 5 (16.1%) | 4 (14.8%) | 38 (19.0%)
Dopamine | 11 (28.2%) | 15 (14.6%) | 4 (12.9%) | 2 (7.4%) | 32 (16.0%)
Epinephrine | 3 (7.7%) | 5 (4.9%) | 0 | 0 | 8 (4.0%)
Vasopressin | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Other | 4 (10.3%) | 5 (4.9%) | 1 (3.2%) | 2 (7.4%) | 12 (6.0%)

The percentages are based on the total number of safety Participants in each age group or total.

1 Prior Cardioactive Drugs are the cardioactive medications recorded at pre-dose.

Table 14.1.9.2 Prior Medications ^1^ by Gestational and Postnatal Age Stratum

Population: Safety Participants

Category/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Category/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Number of Participants with Prior Medication | 37 (94.9%) | 97 (94.2%) | 28 (90.3%) | 27 (100.0%) | 189 (94.5%)
Prior Medication Name
0.9% NACI LOCK FINISH | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
ACETAMINOPHEN | 0 (0.0%) | 2 (1.9%) | 3 (9.7%) | 4 (14.8%) | 9 (4.5%)
ACYCLOVIR | 0 (0.0%) | 1 (1.0%) | 1 (3.2%) | 1 (3.7%) | 3 (1.5%)
ALBUMIN | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 1 (3.7%) | 3 (1.5%)
ALBUTEROL | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
ALBUTEROL INH | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
ALPROSTADIL | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
AMIKACIN | 1 (2.6%) | 6 (5.8%) | 0 (0.0%) | 1 (3.7%) | 8 (4.0%)
AMINOPHYLLINE | 4 (10.3%) | 4 (3.9%) | 0 (0.0%) | 0 (0.0%) | 8 (4.0%)
AMOXICILLIN | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
AMPHOTERCIN B LIPOSOME | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
AMPHOTERICIN B | 1 (2.6%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
AMPHOTERICIN B LIPID COMPLEX | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
AMPICILLIN | 24 (61.5%) | 16 (15.5%) | 16 (51.6%) | 6 (22.2%) | 62 (31.0%)
AQUAMEPHYTON | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
ATROPINE | 2 (5.1%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
AZITHROMYCIN | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
BACITRACIN | 0 (0.0%) | 0 (0.0%) | 2 (6.5%) | 0 (0.0%) | 2 (1.0%)
BACITRACIN OINT | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
BACITRACIN OINTMENT | 2 (5.1%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
BACITRACIN TOPICAL | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
BACTROBAN OINT. | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
BACTROBAN TOPICAL | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
BONE PROTEIN | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
BUDESONIDE | 0 (0.0%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
CAFFEINE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
CAFFEINE CITRATE | 14 (35.9%) | 33 (32.0%) | 1 (3.2%) | 0 (0.0%) | 48 (24.0%)
CAFFINE CITRATE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
CALCITRIOL | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
CALCIUM GLUCONATE | 2 (5.1%) | 1 (1.0%) | 1 (3.2%) | 0 (0.0%) | 4 (2.0%)
CALCIUM GUCONATE | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
CASPOFUNGIN | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
CATHFLO ACTIVASE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
CEFAZOLIN | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 1 (3.7%) | 2 (1.0%)
CEFEPIME | 2 (5.1%) | 4 (3.9%) | 2 (6.5%) | 2 (7.4%) | 10 (5.0%)
CEFOTAXIME | 4 (10.3%) | 14 (13.6%) | 6 (19.4%) | 1 (3.7%) | 25 (12.5%)
CEFOXITIN | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
CEFTAZIDIME | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 1 (3.7%) | 3 (1.5%)
CEFTRIAXONE | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
CHLOROTHIAZIDE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
CISATRACURIUM | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
CLINDAMYCIN | 9 (23.1%) | 15 (14.6%) | 1 (3.2%) | 1 (3.7%) | 26 (13.0%)
CUROSURF | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
CYCLOMYDRILL | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
CYCLOPENTOLATE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
D10 NA ACETATE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
D10W IMB & HEPARIN | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
DEXAMETHASONE | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
DEXTROSE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
DIGOXIN | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
DOBUTAMINE | 3 (7.7%) | 2 (1.9%) | 1 (3.2%) | 0 (0.0%) | 6 (3.0%)
DOPAMINE | 11 (28.2%) | 10 (9.7%) | 4 (12.9%) | 1 (3.7%) | 26 (13.0%)
ELEMENTAL CALCIUM | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
EPINEPHRINE | 2 (5.1%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 5 (2.5%)
EPINEPHRINE DRIP | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
EPOIETIN ALPHA | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
ERYTHROMYCIN | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
ERYTHROMYCIN EYE OINTMENT | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
ESOMEPRAZOLE | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
EXOXAPRIN | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
FACTOR VIIA | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
FAMOTIDINE | 1 (2.6%) | 3 (2.9%) | 0 (0.0%) | 1 (3.7%) | 5 (2.5%)
FAT EMULSIONS 20% | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
FENTANYL | 5 (12.8%) | 20 (19.4%) | 8 (25.8%) | 9 (33.3%) | 42 (21.0%)
FERROUS SULFATE | 0 (0.0%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
FILIGASTIM | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
FLUCONAZOLE | 6 (15.4%) | 23 (22.3%) | 2 (6.5%) | 4 (14.8%) | 35 (17.5%)
FUROSEMIDE | 0 (0.0%) | 20 (19.4%) | 0 (0.0%) | 2 (7.4%) | 22 (11.0%)
GANCICLOVIR | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
GENTAMICIN | 25 (64.1%) | 55 (53.4%) | 16 (51.6%) | 14 (51.9%) | 110 (55.0%)
GLYCERIN SUPP. | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
GLYCERIN SUPPOSITORY | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
HAEMOPHILUS VACCINE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
HEPARIN | 2 (5.1%) | 8 (7.8%) | 1 (3.2%) | 2 (7.4%) | 13 (6.5%)
HEPARIN FLUSH | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
HEPARIN FLUSH 10 U/ML | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
HEPARIN FLUSH 10 UNIT/ML | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
HEPARIN LOCK FLUSH 10 UNIT/ML | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
HYDRALAZINE | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
HYDROCORTISONE | 7 (17.9%) | 16 (15.5%) | 2 (6.5%) | 1 (3.7%) | 26 (13.0%)
HYDROCORTISONE NA SUCCINATE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
HYDROCORTISONE NA-SUCCINATE INJECTION | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
IBUPROFEN | 2 (5.1%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
INDOMETHACIN | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
INSULIN | 2 (5.1%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
INTRALIPID | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
INTRALIPIDS | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
IPRATROPIUM | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
K PHOS | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
LACRILUBE EYE OINT OU. | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
LANSOPRAZOLE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
LEVALBUTEROL | 0 (0.0%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
LEVOTHYROXINE (T4) | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
LIDOCAINE | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
LINEZOLID | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
LORAZEPAM | 3 (7.7%) | 6 (5.8%) | 1 (3.2%) | 1 (3.7%) | 11 (5.5%)
MEROPENEM | 8 (20.5%) | 39 (37.9%) | 15 (48.4%) | 13 (48.1%) | 75 (37.5%)
METHADONE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
METOCLOPRAMIDE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
METOCLOPROMIDE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
METRONIDAZLOE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
METRONIDAZOLE | 6 (15.4%) | 15 (14.6%) | 5 (16.1%) | 6 (22.2%) | 32 (16.0%)
MICAFUNGIN | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 3 (1.5%)
MIDAZOLAM | 4 (10.3%) | 14 (13.6%) | 7 (22.6%) | 6 (22.2%) | 31 (15.5%)
MILRINONE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
MILRINONE - 0.5 MCG/KG/MIN | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
MILRINONE GTT | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
MORPHINE | 10 (25.6%) | 20 (19.4%) | 7 (22.6%) | 5 (18.5%) | 42 (21.0%)
MULTIVITAMIN | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
MULTIVITAMIN DROPS | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
MUPIROCEN | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
MVI | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
NA BICARB | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
NITRIC OXIDE | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
NYSTATIN | 4 (10.3%) | 5 (4.9%) | 3 (9.7%) | 3 (11.1%) | 15 (7.5%)
NYSTATIN OINTMENT | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
NYSTATIN ORAL SUSP. | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
NYSTATIN POWDER | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
OXACILLIN | 2 (5.1%) | 5 (4.9%) | 0 (0.0%) | 1 (3.7%) | 8 (4.0%)
PANCURONIUM | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
PANTOPRAZOLE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
PAPAVERINE | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 3 (1.5%)
PAPAVERINE HCL | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
PEDIARIX VACCINE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
PENICILLIN G | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
PENTOBARBITAL | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
PHENOBARBITAL | 1 (2.6%) | 5 (4.9%) | 0 (0.0%) | 2 (7.4%) | 8 (4.0%)
PHYTONADION | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
PIPERACILLIN | 0 (0.0%) | 3 (2.9%) | 1 (3.2%) | 0 (0.0%) | 4 (2.0%)
PIPERACILLIN & TAZOBACTUM | 0 (0.0%) | 3 (2.9%) | 1 (3.2%) | 0 (0.0%) | 4 (2.0%)
PIPERACILLIN + TAZOBACTAM | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
PIPERACILLIN + TAZOBACTUM | 4 (10.3%) | 3 (2.9%) | 0 (0.0%) | 2 (7.4%) | 9 (4.5%)
PIPERACILLIN+TAZOBACTUM | 1 (2.6%) | 0 (0.0%) | 1 (3.2%) | 3 (11.1%) | 5 (2.5%)
PLATELETS | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
PNEUMOCOCCAL VACCINE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
POLY-VI-SOL | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
POLY-VI-SOL & IRON | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
POLYMYXIN B SULFATE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
POLYVISOL | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
PORACTANT ALFA (CUROSURF) | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
POTASSIUM | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
POTASSIUM CHLORIDE | 0 (0.0%) | 2 (1.9%) | 1 (3.2%) | 1 (3.7%) | 4 (2.0%)
POTASSIUM CHLORIDE INJ | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
PRBC | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
PROPOFOL | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
RANITIDINE | 0 (0.0%) | 4 (3.9%) | 2 (6.5%) | 2 (7.4%) | 8 (4.0%)
RETINOIC ACID | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
RIFAMPIN | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
SILDENAFIL | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 2 (7.4%) | 3 (1.5%)
SILVER SULFADIAZINE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
SINCALIDE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
SODIUM ACETATE | 2 (5.1%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
SODIUM BICARB | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
SODIUM BICARBONATE | 2 (5.1%) | 3 (2.9%) | 1 (3.2%) | 0 (0.0%) | 6 (3.0%)
SODIUM BICARBONATE INJ | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
SODIUM CHLORIDE | 1 (2.6%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
SODIUM CHLORIDE INJ | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
SPIRONOLACTONE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
SUCROSE 24: PRN | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
THAM | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
TOBRAMYCIN | 3 (7.7%) | 4 (3.9%) | 0 (0.0%) | 1 (3.7%) | 8 (4.0%)
TPN | 0 (0.0%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
TROMETHAMINE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
URSODIOL (URSODEOXYCHOLIC ACID) | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
VANCOMYCIN | 19 (48.7%) | 50 (48.5%) | 11 (35.5%) | 13 (48.1%) | 93 (46.5%)
VANCOMYCIN FLUSH FOR PICC | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
VASOPRESSIN | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
VECURONIUM | 1 (2.6%) | 5 (4.9%) | 0 (0.0%) | 1 (3.7%) | 7 (3.5%)
VERSED | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
VIT A | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
VIT. A | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
VITAMIN A | 8 (20.5%) | 7 (6.8%) | 0 (0.0%) | 0 (0.0%) | 15 (7.5%)
VITAMIN K | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
XOPENEX | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)

The percentages are based on the total number of safety Participants in each age group or total.

Participants are counted once for each prior medication.

1 Prior medication will be defined as the medications taken prior to the date of first meropenem study dose.

Table 14.2 Summary of Efficacy Components by Gestational and Postnatal Age Stratum

Population: Efficacy Participants

Response | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Response | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Efficacy Participants | 39 (100.0%) | 101 (98.1%) | 28 (90.3%) | 27 (100.0%) | 195 (97.5%)
Efficacy Determination | 39 (100.0%) | 98 (97.0%) | 28 (100.0%) | 27 (100.0%) | 192 (98.5%)
Success ^1^ | 29 (74.4%) | 82 (83.7%) | 26 (92.9%) | 25 (92.6%) | 162 (84.4%)
Failure | 10 (25.6%) | 16 (16.3%) | 2 (7.1%) | 2 (7.4%) | 30 (15.6%)
Alive | 36 (92.3%) | 93 (94.9%) | 28 (100.0%) | 27 (100.0%) | 184 (95.8%)
Death | 3 (7.7%) | 5 (5.1%) | 0 | 0 | 8 (4.2%)
Bacterial Cultures
Negative | 27 (69.2%) | 49 (50.0%) | 9 (32.1%) | 13 (48.1%) | 98 (51.0%)
Not Done | 12 (30.8%) | 49 (50.0%) | 19 (67.9%) | 14 (51.9%) | 94 (49.0%)
Change in antibiotic therapy | 7 (17.9%) | 12 (12.2%) | 2 (7.1%) | 2 (7.4%) | 23 (12.0%)
Presumptive Clinical Cure Score
>=7 | 35 (89.7%) | 90 (91.8%) | 27 (96.4%) | 27 (100.0%) | 179 (93.2%)
<7 | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Missing | 4 (10.3%) | 7 (7.1%) | 1 (3.6%) | 0 | 12 (6.3%)

The percentages are based on the total number of efficacy Participants in each age group or total.

1 Success will be defined as alive, negative last bacterial cultures (if obtained) from normally sterile body fluids (excluding Staphylococcus species), presumptive clinical cure score >=7 at efficacy visit and no new antibiotic therapy during study meropenem (except related to Staphylococcus infections).

Table 14.3.1.1 Overall Summary of Treatment-Emergent Adverse Events by Gestational and Postnatal Age Stratum

Population: Safety Participants

Category/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Category/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Number of Participants with at Least One TEAE | 26 (66.7%) | 47 (45.6%) | 13 (41.9%) | 13 (48.1%) | 99 (49.5%)
Participants with at Least One TEAE by Severity^1^
Mild | 5 (12.8%) | 10 (9.7%) | 6 (19.4%) | 3 (11.1%) | 24 (12.0%)
Moderate | 13 (33.3%) | 21 (20.4%) | 6 (19.4%) | 4 (14.8%) | 44 (22.0%)
Severe | 8 (20.5%) | 16 (15.5%) | 1 (3.2%) | 6 (22.2%) | 31 (15.5%)
Participants with at Least One TEAE by Causality^2^
Unrelated | 19 (48.7%) | 37 (35.9%) | 12 (38.7%) | 10 (37.0%) | 78 (39.0%)
Possibly | 7 (17.9%) | 10 (9.7%) | 1 (3.2%) | 3 (11.1%) | 21 (10.5%)
Participants with Special Interest TEAE
Seizure | 4 (10.3%) | 3 (2.9%) | 1 (3.2%) | 2 (7.4%) | 10 (5.0%)
Level II AE | 2 (5.1%) | 7 (6.8%) | 0 | 0 | 9 (4.5%)
Number of Participants with at Least One SAE | 9 (23.1%) | 18 (17.5%) | 2 (6.5%) | 5 (18.5%) | 34 (17.0%)
Death | 3 (7.7%) | 8 (7.8%) | 0 | 0 | 11 (5.5%)
Life Threatening | 3 (7.7%) | 6 (5.8%) | 1 (3.2%) | 0 | 10 (5.0%)
Prolonged Hospitalization | 2 (5.1%) | 4 (3.9%) | 0 | 2 (7.4%) | 8 (4.0%)
Important Medical Event | 3 (7.7%) | 4 (3.9%) | 1 (3.2%) | 3 (11.1%) | 11 (5.5%)
Participants with AE that Led to Study Drug Discontinuation | 1 (2.6%) | 3 (2.9%) | 0 | 2 (7.4%) | 6 (3.0%)

The percentages are based on the total number of safety Participants in each age group or total.

1 Participants are counted only once at the greatest severity. TEAE with missing severity will be considered as severe.

2 Participants are counted only once at the strongest relationship to study drug (causality). TEAE with missing causality will be considered as definitely related to study drug.

Participant ▬ seizure occurred prior to enrollment. It is not included in this table.

Participant ▬ reported seizure but central and local review determined it was not a seizure. It is not included in this table.

Table 14.3.1.2 Summary of Treatment Emergent Adverse Events by Gestational, Postnatal Age Stratum, MedDRA System Organ Class, and Preferred Term

Population: Safety Participants

System Organ Class (SOC)/Preferred Term | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
System Organ Class (SOC)/Preferred Term | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Number of Participants with at Least One TEAE | 26 (66.7%) | 47 (45.6%) | 13 (41.9%) | 13 (48.1%) | 99 (49.5%)
Blood and lymphatic system disorders | 4 (10.3%) | 4 (3.9%) | 1 (3.2%) | 2 (7.4%) | 11 (5.5%)
Anaemia | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 2 (7.4%) | 3 (1.5%)
Anaemia neonatal | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Coagulopathy | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Disseminated intravascular coagulation | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Leukocytosis | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Polycythaemia | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Thrombocytopenia | 1 (2.6%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
Cardiac disorders | 4 (10.3%) | 1 (1.0%) | 0 (0.0%) | 2 (7.4%) | 7 (3.5%)
Bradycardia | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 2 (7.4%) | 4 (2.0%)
Supraventricular tachycardia | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Tachycardia | 2 (5.1%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Congenital, familial and genetic disorders | 4 (10.3%) | 2 (1.9%) | 1 (3.2%) | 1 (3.7%) | 8 (4.0%)
Atrial septal defect | 1 (2.6%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 2 (1.0%)
Congenital choroid plexus cyst | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Congenital diaphragmatic hernia | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Patent ductus arteriosus | 4 (10.3%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 6 (3.0%)
Endocrine disorders | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 3 (1.5%)
Adrenal insufficiency | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Hypothyroidism | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Eye disorders | 0 (0.0%) | 5 (4.9%) | 0 (0.0%) | 0 (0.0%) | 5 (2.5%)
Eye discharge | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Retinopathy of prematurity | 0 (0.0%) | 5 (4.9%) | 0 (0.0%) | 0 (0.0%) | 5 (2.5%)
Gastrointestinal disorders | 7 (17.9%) | 11 (10.7%) | 5 (16.1%) | 5 (18.5%) | 28 (14.0%)
Abdominal distension | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 1 (3.7%) | 3 (1.5%)
Ascites | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Colonic stenosis | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Constipation | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Enterocutaneous fistula | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Gastrointestinal haemorrhage | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Gastrooesophageal reflux disease | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Haematochezia | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Ileal perforation | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Ileus | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Inguinal hernia | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Intestinal dilatation | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Intestinal ischaemia | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Intestinal obstruction | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 3 (1.5%)
Intestinal perforation | 1 (2.6%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
Intestinal stenosis | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Necrotising colitis | 2 (5.1%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
Rectal haemorrhage | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Vomiting | 0 (0.0%) | 1 (1.0%) | 4 (12.9%) | 0 (0.0%) | 5 (2.5%)
General disorders and administration site conditions | 6 (15.4%) | 5 (4.9%) | 2 (6.5%) | 2 (7.4%) | 15 (7.5%)
Catheter related complication | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 3 (1.5%)
Catheter thrombosis | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Generalised oedema | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Hyperthermia | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Infusion site extravasation | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Multi-organ failure | 2 (5.1%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
Oedema | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Oedema peripheral | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Pain | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Hepatobiliary disorders | 1 (2.6%) | 0 (0.0%) | 1 (3.2%) | 1 (3.7%) | 3 (1.5%)
Cholelithiasis | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Cholestasis | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Infections and infestations | 9 (23.1%) | 13 (12.6%) | 3 (9.7%) | 3 (11.1%) | 28 (14.0%)
Abdominal abscess | 0 (0.0%) | 0 (0.0%) | 2 (6.5%) | 0 (0.0%) | 2 (1.0%)
Abdominal sepsis | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Bacterial sepsis | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Encephalitis fungal | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Fungal infection | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Fungal sepsis | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Fungal skin infection | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Hydrocele male infected | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Meningitis | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Purulent discharge | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Respiratory syncytial virus infection | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Sepsis | 5 (12.8%) | 5 (4.9%) | 1 (3.2%) | 1 (3.7%) | 12 (6.0%)
Sepsis neonatal | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Sepsis syndrome | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Staphylococcal infection | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Urinary tract infection fungal | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Wound infection | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Injury, poisoning and procedural complications | 3 (7.7%) | 2 (1.9%) | 2 (6.5%) | 3 (11.1%) | 10 (5.0%)
Abdominal wound dehiscence | 1 (2.6%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 2 (1.0%)
Brain herniation | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Caustic injury | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Collapse of lung | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Endotracheal intubation complication | 1 (2.6%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 2 (1.0%)
Excoriation | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Inflammation of wound | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Wound complication | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Wound dehiscence | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Investigations | 8 (20.5%) | 17 (16.5%) | 3 (9.7%) | 3 (11.1%) | 31 (15.5%)
Alanine aminotransferase increased | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 2 (7.4%) | 3 (1.5%)
Aspartate aminotransferase increased | 0 (0.0%) | 3 (2.9%) | 0 (0.0%) | 2 (7.4%) | 5 (2.5%)
Bilirubin conjugated increased | 5 (12.8%) | 3 (2.9%) | 0 (0.0%) | 1 (3.7%) | 9 (4.5%)
Blood alkaline phosphatase increased | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Blood caffeine increased | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Blood chloride decreased | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Blood chloride increased | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Blood cortisol decreased | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Blood creatinine increased | 0 (0.0%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
Blood glucose decreased | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Blood magnesium decreased | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Blood pH decreased | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Blood triglycerides increased | 1 (2.6%) | 1 (1.0%) | 1 (3.2%) | 0 (0.0%) | 3 (1.5%)
Calcium ionised decreased | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Chest X-ray abnormal | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Glomerular filtration rate decreased | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Haemoglobin decreased | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Platelet count decreased | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Thyroid function test abnormal | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Ultrasound kidney abnormal | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Urine output decreased | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Waist circumference increased | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
White blood cell count increased | 0 (0.0%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
Metabolism and nutrition disorders | 8 (20.5%) | 15 (14.6%) | 1 (3.2%) | 1 (3.7%) | 25 (12.5%)
Fluid overload | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Hypercalcaemia | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Hyperchloraemia | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Hyperglycaemia | 2 (5.1%) | 2 (1.9%) | 1 (3.2%) | 0 (0.0%) | 5 (2.5%)
Hyperkalaemia | 1 (2.6%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
Hyperlipidaemia | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Hypoalbuminaemia | 2 (5.1%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
Hypocalcaemia | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Hypochloraemia | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Hypoglycaemia | 3 (7.7%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 5 (2.5%)
Hypokalaemia | 2 (5.1%) | 6 (5.8%) | 0 (0.0%) | 1 (3.7%) | 9 (4.5%)
Hypomagnesaemia | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Hyponatraemia | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Hypophosphataemia | 1 (2.6%) | 2 (1.9%) | 0 (0.0%) | 1 (3.7%) | 4 (2.0%)
Hypoproteinaemia | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Metabolic alkalosis | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Musculoskeletal and connective tissue disorders | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Fistula | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Osteopenia | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Nervous system disorders | 8 (20.5%) | 4 (3.9%) | 3 (9.7%) | 2 (7.4%) | 17 (8.5%)
Cerebral ventricle dilatation | 1 (2.6%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 2 (1.0%)
Convulsion | 4 (10.3%) | 3 (2.9%) | 1 (3.2%) | 2 (7.4%) | 10 (5.0%)
Encephalomalacia | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Intracranial haematoma | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Intraventricular haemorrhage neonatal | 2 (5.1%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Periventricular leukomalacia | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Subarachnoid haemorrhage | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Vocal cord paralysis | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Vocal cord paresis | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Psychiatric disorders | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Agitation | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Renal and urinary disorders | 1 (2.6%) | 2 (1.9%) | 0 (0.0%) | 1 (3.7%) | 4 (2.0%)
Hydronephrosis | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Renal failure | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Renal failure acute | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Vesicoureteric reflux | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Respiratory, thoracic and mediastinal disorders | 8 (20.5%) | 10 (9.7%) | 4 (12.9%) | 5 (18.5%) | 27 (13.5%)
Acute respiratory failure | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Apnoea | 0 (0.0%) | 1 (1.0%) | 1 (3.2%) | 0 (0.0%) | 2 (1.0%)
Atelectasis | 2 (5.1%) | 0 (0.0%) | 0 (0.0%) | 3 (11.1%) | 5 (2.5%)
Bronchopulmonary dysplasia | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Hypercapnia | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Hypopnoea | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Infantile apnoeic attack | 2 (5.1%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Lung disorder | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Neonatal respiratory distress syndrome | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Pneumonia aspiration | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Pneumothorax | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Pulmonary haemorrhage | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Pulmonary hypertension | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Pulmonary interstitial emphysema syndrome | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Pulmonary oedema | 1 (2.6%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 2 (1.0%)
Pulmonary pneumatocele | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Pulmonary vascular disorder | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Respiratory arrest | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Respiratory distress | 0 (0.0%) | 3 (2.9%) | 0 (0.0%) | 1 (3.7%) | 4 (2.0%)
Respiratory failure | 1 (2.6%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
Stridor | 0 (0.0%) | 1 (1.0%) | 1 (3.2%) | 0 (0.0%) | 2 (1.0%)
Tachypnoea | 0 (0.0%) | 0 (0.0%) | 3 (9.7%) | 0 (0.0%) | 3 (1.5%)
Skin and subcutaneous tissue disorders | 0 (0.0%) | 3 (2.9%) | 1 (3.2%) | 0 (0.0%) | 4 (2.0%)
Dermatitis diaper | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Periorbital oedema | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Rash | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Skin disorder | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Surgical and medical procedures | 0 (0.0%) | 1 (1.0%) | 1 (3.2%) | 1 (3.7%) | 3 (1.5%)
Endotracheal intubation | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Ileostomy | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Mechanical ventilation | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Vascular disorders | 2 (5.1%) | 6 (5.8%) | 0 (0.0%) | 1 (3.7%) | 9 (4.5%)
Hypertension | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Hypotension | 1 (2.6%) | 5 (4.9%) | 0 (0.0%) | 0 (0.0%) | 6 (3.0%)
Hypovolaemic shock | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Poor peripheral circulation | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Poor venous access | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Not Coded | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Not Coded | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)

The percentages are based on the total number of safety Participants in each age group or total.

Participants are counted once at each SOC and preferred term levels.

Table 14.3.1.3 Summary of Treatment Emergent Adverse Events by Gestational, Postnatal Age Stratum, MedDRA System Organ Class, Preferred Term, and by Severity

Population: Safety Participants

System Organ Class (SOC)/Preferred Term | Severity | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
System Organ Class (SOC)/Preferred Term | Severity | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Number of Patients with TEAE | Mild | 5 (12.8%) | 10 (9.7%) | 6 (19.4%) | 3 (11.1%) | 24 (12.0%)
Number of Patients with TEAE | Moderate | 13 (33.3%) | 21 (20.4%) | 6 (19.4%) | 4 (14.8%) | 44 (22.0%)
Number of Patients with TEAE | Severe | 8 (20.5%) | 16 (15.5%) | 1 (3.2%) | 6 (22.2%) | 31 (15.5%)
Blood and lymphatic system disorders | Mild | 2 (5.1%) | 3 (2.9%) | 1 (3.2%) | 1 (3.7%) | 7 (3.5%)
Blood and lymphatic system disorders | Moderate | 2 (5.1%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 4 (2.0%)
Anaemia | Mild | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Anaemia | Moderate | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Anaemia neonatal | Mild | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Coagulopathy | Moderate | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Disseminated intravascular coagulation | Moderate | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Leukocytosis | Moderate | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Polycythaemia | Mild | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Thrombocytopenia | Mild | 1 (2.6%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
Thrombocytopenia | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Cardiac disorders | Mild | 3 (7.7%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 4 (2.0%)
Cardiac disorders | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Cardiac disorders | Severe | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Bradycardia | Mild | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Bradycardia | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Bradycardia | Severe | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Supraventricular tachycardia | Mild | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Tachycardia | Mild | 2 (5.1%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Congenital, familial and genetic disorders | Mild | 3 (7.7%) | 1 (1.0%) | 1 (3.2%) | 0 (0.0%) | 5 (2.5%)
Congenital, familial and genetic disorders | Moderate | 2 (5.1%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 3 (1.5%)
Congenital, familial and genetic disorders | Severe | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Atrial septal defect | Mild | 1 (2.6%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 2 (1.0%)
Congenital choroid plexus cyst | Mild | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Congenital diaphragmatic hernia | Severe | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Patent ductus arteriosus | Mild | 3 (7.7%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
Patent ductus arteriosus | Moderate | 2 (5.1%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 3 (1.5%)
Endocrine disorders | Moderate | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Endocrine disorders | Severe | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Adrenal insufficiency | Moderate | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Adrenal insufficiency | Severe | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Hypothyroidism | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Eye disorders | Mild | 0 (0.0%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
Eye disorders | Moderate | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Eye discharge | Mild | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Retinopathy of prematurity | Mild | 0 (0.0%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
Retinopathy of prematurity | Moderate | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Gastrointestinal disorders | Mild | 3 (7.7%) | 5 (4.9%) | 4 (12.9%) | 3 (11.1%) | 15 (7.5%)
Gastrointestinal disorders | Moderate | 1 (2.6%) | 2 (1.9%) | 2 (6.5%) | 1 (3.7%) | 6 (3.0%)
Gastrointestinal disorders | Severe | 4 (10.3%) | 6 (5.8%) | 0 (0.0%) | 2 (7.4%) | 12 (6.0%)
Abdominal distension | Mild | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Abdominal distension | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Ascites | Mild | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Ascites | Moderate | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Colonic stenosis | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Colonic stenosis | Severe | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Constipation | Mild | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Enterocutaneous fistula | Mild | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Gastrointestinal haemorrhage | Mild | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Gastrooesophageal reflux disease | Mild | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Haematochezia | Mild | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Ileal perforation | Severe | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Ileus | Mild | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Inguinal hernia | Mild | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Intestinal dilatation | Mild | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Intestinal ischaemia | Severe | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Intestinal obstruction | Moderate | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Intestinal obstruction | Severe | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Intestinal perforation | Severe | 1 (2.6%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
Intestinal stenosis | Severe | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Necrotising colitis | Severe | 2 (5.1%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
Rectal haemorrhage | Moderate | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Vomiting | Mild | 0 (0.0%) | 1 (1.0%) | 3 (9.7%) | 0 (0.0%) | 4 (2.0%)
Vomiting | Moderate | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
General disorders and administration site conditions | Mild | 2 (5.1%) | 2 (1.9%) | 2 (6.5%) | 1 (3.7%) | 7 (3.5%)
General disorders and administration site conditions | Moderate | 2 (5.1%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 4 (2.0%)
General disorders and administration site conditions | Severe | 2 (5.1%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
Catheter related complication | Mild | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 3 (1.5%)
Catheter thrombosis | Mild | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Generalised oedema | Moderate | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Hyperthermia | Mild | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Infusion site extravasation | Moderate | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Multi-organ failure | Severe | 2 (5.1%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
Oedema | Mild | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Oedema peripheral | Mild | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Pain | Moderate | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Hepatobiliary disorders | Mild | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Hepatobiliary disorders | Moderate | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Cholelithiasis | Mild | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Cholestasis | Moderate | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Infections and infestations | Mild | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Infections and infestations | Moderate | 9 (23.1%) | 8 (7.8%) | 3 (9.7%) | 1 (3.7%) | 21 (10.5%)
Infections and infestations | Severe | 0 (0.0%) | 5 (4.9%) | 0 (0.0%) | 1 (3.7%) | 6 (3.0%)
Abdominal abscess | Moderate | 0 (0.0%) | 0 (0.0%) | 2 (6.5%) | 0 (0.0%) | 2 (1.0%)
Abdominal sepsis | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Bacterial sepsis | Severe | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Encephalitis fungal | Severe | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Fungal infection | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Fungal sepsis | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Fungal skin infection | Moderate | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Hydrocele male infected | Mild | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Meningitis | Severe | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Purulent discharge | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Respiratory syncytial virus infection | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Sepsis | Mild | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Sepsis | Moderate | 5 (12.8%) | 2 (1.9%) | 1 (3.2%) | 0 (0.0%) | 8 (4.0%)
Sepsis | Severe | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 1 (3.7%) | 3 (1.5%)
Sepsis neonatal | Moderate | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Sepsis syndrome | Moderate | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Staphylococcal infection | Moderate | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Urinary tract infection fungal | Moderate | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Wound infection | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Injury, poisoning and procedural complications | Mild | 1 (2.6%) | 0 (0.0%) | 1 (3.2%) | 1 (3.7%) | 3 (1.5%)
Injury, poisoning and procedural complications | Moderate | 2 (5.1%) | 0 (0.0%) | 1 (3.2%) | 2 (7.4%) | 5 (2.5%)
Injury, poisoning and procedural complications | Severe | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 1 (3.7%) | 3 (1.5%)
Abdominal wound dehiscence | Mild | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Abdominal wound dehiscence | Moderate | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Brain herniation | Severe | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Caustic injury | Mild | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Collapse of lung | Moderate | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Endotracheal intubation complication | Moderate | 1 (2.6%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 2 (1.0%)
Excoriation | Mild | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Inflammation of wound | Moderate | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Wound complication | Moderate | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Wound dehiscence | Severe | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Investigations | Mild | 6 (15.4%) | 6 (5.8%) | 2 (6.5%) | 1 (3.7%) | 15 (7.5%)
Investigations | Moderate | 2 (5.1%) | 11 (10.7%) | 1 (3.2%) | 3 (11.1%) | 17 (8.5%)
Investigations | Severe | 0 (0.0%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
Alanine aminotransferase increased | Mild | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Alanine aminotransferase increased | Moderate | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Aspartate aminotransferase increased | Mild | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Aspartate aminotransferase increased | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 2 (7.4%) | 3 (1.5%)
Bilirubin conjugated increased | Mild | 3 (7.7%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
Bilirubin conjugated increased | Moderate | 2 (5.1%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 4 (2.0%)
Bilirubin conjugated increased | Severe | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Blood alkaline phosphatase increased | Moderate | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Blood caffeine increased | Mild | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Blood chloride decreased | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Blood chloride increased | Mild | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Blood cortisol decreased | Mild | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Blood creatinine increased | Mild | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Blood creatinine increased | Moderate | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Blood glucose decreased | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Blood magnesium decreased | Mild | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Blood pH decreased | Mild | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Blood triglycerides increased | Mild | 1 (2.6%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 2 (1.0%)
Blood triglycerides increased | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Calcium ionised decreased | Mild | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Chest X-ray abnormal | Moderate | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Glomerular filtration rate decreased | Moderate | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Haemoglobin decreased | Mild | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Platelet count decreased | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Thyroid function test abnormal | Mild | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Ultrasound kidney abnormal | Mild | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Urine output decreased | Mild | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Waist circumference increased | Severe | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
White blood cell count increased | Moderate | 0 (0.0%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
Metabolism and nutrition disorders | Mild | 6 (15.4%) | 9 (8.7%) | 1 (3.2%) | 1 (3.7%) | 17 (8.5%)
Metabolism and nutrition disorders | Moderate | 4 (10.3%) | 6 (5.8%) | 0 (0.0%) | 0 (0.0%) | 10 (5.0%)
Metabolism and nutrition disorders | Severe | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Fluid overload | Mild | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Hypercalcaemia | Mild | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Hyperchloraemia | Mild | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Hyperglycaemia | Mild | 1 (2.6%) | 1 (1.0%) | 1 (3.2%) | 0 (0.0%) | 3 (1.5%)
Hyperglycaemia | Moderate | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Hyperkalaemia | Mild | 1 (2.6%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
Hyperkalaemia | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Hyperlipidaemia | Mild | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Hyperlipidaemia | Severe | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Hypoalbuminaemia | Mild | 2 (5.1%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
Hypoalbuminaemia | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Hypocalcaemia | Mild | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Hypochloraemia | Moderate | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Hypoglycaemia | Mild | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Hypoglycaemia | Moderate | 2 (5.1%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
Hypokalaemia | Mild | 2 (5.1%) | 4 (3.9%) | 0 (0.0%) | 1 (3.7%) | 7 (3.5%)
Hypokalaemia | Moderate | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Hypomagnesaemia | Mild | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Hyponatraemia | Mild | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Hyponatraemia | Moderate | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Hypophosphataemia | Mild | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 3 (1.5%)
Hypophosphataemia | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Hypoproteinaemia | Mild | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Hypoproteinaemia | Moderate | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Metabolic alkalosis | Mild | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Musculoskeletal and connective tissue disorders | Mild | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Musculoskeletal and connective tissue disorders | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Fistula | Mild | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Osteopenia | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Nervous system disorders | Mild | 5 (12.8%) | 1 (1.0%) | 3 (9.7%) | 1 (3.7%) | 10 (5.0%)
Nervous system disorders | Moderate | 2 (5.1%) | 3 (2.9%) | 0 (0.0%) | 1 (3.7%) | 6 (3.0%)
Nervous system disorders | Severe | 2 (5.1%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
Cerebral ventricle dilatation | Mild | 1 (2.6%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 2 (1.0%)
Convulsion | Mild | 3 (7.7%) | 1 (1.0%) | 1 (3.2%) | 1 (3.7%) | 6 (3.0%)
Convulsion | Moderate | 1 (2.6%) | 2 (1.9%) | 0 (0.0%) | 1 (3.7%) | 4 (2.0%)
Encephalomalacia | Severe | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Intracranial haematoma | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Intraventricular haemorrhage neonatal | Mild | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Intraventricular haemorrhage neonatal | Moderate | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Periventricular leukomalacia | Severe | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Subarachnoid haemorrhage | Severe | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Vocal cord paralysis | Mild | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Vocal cord paresis | Mild | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Psychiatric disorders | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Agitation | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Renal and urinary disorders | Mild | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Renal and urinary disorders | Moderate | 1 (2.6%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
Hydronephrosis | Mild | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Renal failure | Moderate | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Renal failure acute | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Vesicoureteric reflux | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Respiratory, thoracic and mediastinal disorders | Mild | 2 (5.1%) | 2 (1.9%) | 2 (6.5%) | 2 (7.4%) | 8 (4.0%)
Respiratory, thoracic and mediastinal disorders | Moderate | 6 (15.4%) | 7 (6.8%) | 1 (3.2%) | 1 (3.7%) | 15 (7.5%)
Respiratory, thoracic and mediastinal disorders | Severe | 1 (2.6%) | 3 (2.9%) | 1 (3.2%) | 2 (7.4%) | 7 (3.5%)
Acute respiratory failure | Severe | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Apnoea | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Apnoea | Severe | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Atelectasis | Mild | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 2 (7.4%) | 3 (1.5%)
Atelectasis | Moderate | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Bronchopulmonary dysplasia | Severe | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Hypercapnia | Mild | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Hypopnoea | Mild | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Infantile apnoeic attack | Moderate | 2 (5.1%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Lung disorder | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Neonatal respiratory distress syndrome | Moderate | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Pneumonia aspiration | Severe | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Pneumothorax | Mild | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Pneumothorax | Moderate | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Pulmonary haemorrhage | Severe | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Pulmonary hypertension | Moderate | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Pulmonary interstitial emphysema syndrome | Moderate | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Pulmonary oedema | Mild | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Pulmonary oedema | Moderate | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Pulmonary pneumatocele | Mild | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Pulmonary vascular disorder | Mild | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Respiratory arrest | Severe | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Respiratory distress | Moderate | 0 (0.0%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
Respiratory distress | Severe | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Respiratory failure | Moderate | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Respiratory failure | Severe | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Stridor | Mild | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Stridor | Moderate | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Tachypnoea | Mild | 0 (0.0%) | 0 (0.0%) | 2 (6.5%) | 0 (0.0%) | 2 (1.0%)
Tachypnoea | Moderate | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Skin and subcutaneous tissue disorders | Mild | 0 (0.0%) | 3 (2.9%) | 1 (3.2%) | 0 (0.0%) | 4 (2.0%)
Dermatitis diaper | Mild | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Periorbital oedema | Mild | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Rash | Mild | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Skin disorder | Mild | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Surgical and medical procedures | Mild | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Surgical and medical procedures | Moderate | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 1 (3.7%) | 2 (1.0%)
Endotracheal intubation | Mild | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Ileostomy | Moderate | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Mechanical ventilation | Moderate | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Vascular disorders | Mild | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 3 (1.5%)
Vascular disorders | Moderate | 1 (2.6%) | 4 (3.9%) | 0 (0.0%) | 0 (0.0%) | 5 (2.5%)
Vascular disorders | Severe | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Hypertension | Mild | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Hypotension | Moderate | 1 (2.6%) | 4 (3.9%) | 0 (0.0%) | 0 (0.0%) | 5 (2.5%)
Hypotension | Severe | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Hypovolaemic shock | Moderate | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Poor peripheral circulation | Mild | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Poor venous access | Mild | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Not Coded | Mild | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Not Coded | Mild | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)

The percentages are based on the total number of safety Participants in each age group or total.

Participants are counted once at the greatest severity at each SOC and preferred term levels. TEAE with missing severity will be considered as severe.

Table 14.3.1.4 Summary of Treatment Emergent Adverse Events by Gestational, Postnatal Age Stratum, MedDRA System Organ Class, Preferred Term, and by Relationship

Population: Safety Participants

System Organ Class (SOC)/Preferred Term | Relationship | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
System Organ Class (SOC)/Preferred Term | Relationship | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Number of Patients with TEAE | Unrelated | 19 (48.7%) | 37 (35.9%) | 12 (38.7%) | 10 (37.0%) | 78 (39.0%)
Number of Patients with TEAE | Possibly | 7 (17.9%) | 10 (9.7%) | 1 (3.2%) | 3 (11.1%) | 21 (10.5%)
Blood and lymphatic system disorders | Unrelated | 3 (7.7%) | 4 (3.9%) | 1 (3.2%) | 2 (7.4%) | 10 (5.0%)
Blood and lymphatic system disorders | Possibly | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Anaemia | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 2 (7.4%) | 3 (1.5%)
Anaemia neonatal | Unrelated | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Coagulopathy | Possibly | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Disseminated intravascular coagulation | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Leukocytosis | Unrelated | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Polycythaemia | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Thrombocytopenia | Unrelated | 1 (2.6%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
Cardiac disorders | Unrelated | 4 (10.3%) | 1 (1.0%) | 0 (0.0%) | 2 (7.4%) | 7 (3.5%)
Bradycardia | Unrelated | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 2 (7.4%) | 4 (2.0%)
Supraventricular tachycardia | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Tachycardia | Unrelated | 2 (5.1%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Congenital, familial and genetic disorders | Unrelated | 4 (10.3%) | 2 (1.9%) | 1 (3.2%) | 1 (3.7%) | 8 (4.0%)
Atrial septal defect | Unrelated | 1 (2.6%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 2 (1.0%)
Congenital choroid plexus cyst | Unrelated | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Congenital diaphragmatic hernia | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Patent ductus arteriosus | Unrelated | 4 (10.3%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 6 (3.0%)
Endocrine disorders | Unrelated | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 3 (1.5%)
Adrenal insufficiency | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Hypothyroidism | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Eye disorders | Unrelated | 0 (0.0%) | 5 (4.9%) | 0 (0.0%) | 0 (0.0%) | 5 (2.5%)
Eye discharge | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Retinopathy of prematurity | Unrelated | 0 (0.0%) | 5 (4.9%) | 0 (0.0%) | 0 (0.0%) | 5 (2.5%)
Gastrointestinal disorders | Unrelated | 6 (15.4%) | 11 (10.7%) | 5 (16.1%) | 5 (18.5%) | 27 (13.5%)
Gastrointestinal disorders | Possibly | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Abdominal distension | Unrelated | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 1 (3.7%) | 3 (1.5%)
Ascites | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Colonic stenosis | Unrelated | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Constipation | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Enterocutaneous fistula | Unrelated | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Gastrointestinal haemorrhage | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Gastrooesophageal reflux disease | Unrelated | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Haematochezia | Unrelated | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Ileal perforation | Possibly | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Ileus | Unrelated | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Inguinal hernia | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Intestinal dilatation | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Intestinal ischaemia | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Intestinal obstruction | Unrelated | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 3 (1.5%)
Intestinal perforation | Unrelated | 1 (2.6%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
Intestinal stenosis | Unrelated | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Necrotising colitis | Unrelated | 2 (5.1%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
Rectal haemorrhage | Unrelated | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Vomiting | Unrelated | 0 (0.0%) | 1 (1.0%) | 4 (12.9%) | 0 (0.0%) | 5 (2.5%)
General disorders and administration site conditions | Unrelated | 5 (12.8%) | 5 (4.9%) | 2 (6.5%) | 2 (7.4%) | 14 (7.0%)
General disorders and administration site conditions | Possibly | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Catheter related complication | Unrelated | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 3 (1.5%)
Catheter thrombosis | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Generalised oedema | Unrelated | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Hyperthermia | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Infusion site extravasation | Possibly | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Multi-organ failure | Unrelated | 2 (5.1%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
Oedema | Unrelated | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Oedema peripheral | Unrelated | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Pain | Unrelated | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Hepatobiliary disorders | Unrelated | 1 (2.6%) | 0 (0.0%) | 1 (3.2%) | 1 (3.7%) | 3 (1.5%)
Cholelithiasis | Unrelated | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Cholestasis | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Infections and infestations | Unrelated | 7 (17.9%) | 11 (10.7%) | 3 (9.7%) | 3 (11.1%) | 24 (12.0%)
Infections and infestations | Possibly | 2 (5.1%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
Abdominal abscess | Unrelated | 0 (0.0%) | 0 (0.0%) | 2 (6.5%) | 0 (0.0%) | 2 (1.0%)
Abdominal sepsis | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Bacterial sepsis | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Encephalitis fungal | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Fungal infection | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Fungal sepsis | Possibly | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Fungal skin infection | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Fungal skin infection | Possibly | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Hydrocele male infected | Unrelated | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Meningitis | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Purulent discharge | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Respiratory syncytial virus infection | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Sepsis | Unrelated | 3 (7.7%) | 5 (4.9%) | 1 (3.2%) | 1 (3.7%) | 10 (5.0%)
Sepsis | Possibly | 2 (5.1%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Sepsis neonatal | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Sepsis syndrome | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Staphylococcal infection | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Urinary tract infection fungal | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Wound infection | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Injury, poisoning and procedural complications | Unrelated | 3 (7.7%) | 2 (1.9%) | 2 (6.5%) | 3 (11.1%) | 10 (5.0%)
Abdominal wound dehiscence | Unrelated | 1 (2.6%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 2 (1.0%)
Brain herniation | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Caustic injury | Unrelated | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Collapse of lung | Unrelated | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Endotracheal intubation complication | Unrelated | 1 (2.6%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 2 (1.0%)
Excoriation | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Inflammation of wound | Unrelated | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Wound complication | Unrelated | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Wound dehiscence | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Investigations | Unrelated | 5 (12.8%) | 14 (13.6%) | 3 (9.7%) | 3 (11.1%) | 25 (12.5%)
Investigations | Possibly | 3 (7.7%) | 3 (2.9%) | 0 (0.0%) | 1 (3.7%) | 7 (3.5%)
Alanine aminotransferase increased | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 2 (7.4%) | 3 (1.5%)
Aspartate aminotransferase increased | Unrelated | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 2 (7.4%) | 4 (2.0%)
Aspartate aminotransferase increased | Possibly | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Bilirubin conjugated increased | Unrelated | 3 (7.7%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 5 (2.5%)
Bilirubin conjugated increased | Possibly | 2 (5.1%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 4 (2.0%)
Blood alkaline phosphatase increased | Unrelated | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Blood caffeine increased | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Blood chloride decreased | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Blood chloride increased | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Blood cortisol decreased | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Blood creatinine increased | Unrelated | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Blood creatinine increased | Possibly | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Blood glucose decreased | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Blood magnesium decreased | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Blood pH decreased | Unrelated | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Blood triglycerides increased | Unrelated | 0 (0.0%) | 1 (1.0%) | 1 (3.2%) | 0 (0.0%) | 2 (1.0%)
Blood triglycerides increased | Possibly | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Calcium ionised decreased | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Chest X-ray abnormal | Unrelated | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Glomerular filtration rate decreased | Unrelated | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Haemoglobin decreased | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Platelet count decreased | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Thyroid function test abnormal | Unrelated | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Ultrasound kidney abnormal | Unrelated | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Urine output decreased | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Waist circumference increased | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
White blood cell count increased | Unrelated | 0 (0.0%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
Metabolism and nutrition disorders | Unrelated | 7 (17.9%) | 15 (14.6%) | 1 (3.2%) | 1 (3.7%) | 24 (12.0%)
Metabolism and nutrition disorders | Possibly | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Fluid overload | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Hypercalcaemia | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Hyperchloraemia | Unrelated | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Hyperglycaemia | Unrelated | 2 (5.1%) | 2 (1.9%) | 1 (3.2%) | 0 (0.0%) | 5 (2.5%)
Hyperkalaemia | Unrelated | 1 (2.6%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
Hyperlipidaemia | Unrelated | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Hypoalbuminaemia | Unrelated | 2 (5.1%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
Hypocalcaemia | Unrelated | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Hypochloraemia | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Hypoglycaemia | Unrelated | 2 (5.1%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
Hypoglycaemia | Possibly | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Hypokalaemia | Unrelated | 2 (5.1%) | 6 (5.8%) | 0 (0.0%) | 1 (3.7%) | 9 (4.5%)
Hypomagnesaemia | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Hyponatraemia | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Hypophosphataemia | Unrelated | 1 (2.6%) | 2 (1.9%) | 0 (0.0%) | 1 (3.7%) | 4 (2.0%)
Hypoproteinaemia | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Metabolic alkalosis | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Musculoskeletal and connective tissue disorders | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Musculoskeletal and connective tissue disorders | Possibly | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Fistula | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Osteopenia | Possibly | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Nervous system disorders | Unrelated | 6 (15.4%) | 3 (2.9%) | 2 (6.5%) | 0 (0.0%) | 11 (5.5%)
Nervous system disorders | Possibly | 2 (5.1%) | 2 (1.9%) | 1 (3.2%) | 2 (7.4%) | 7 (3.5%)
Cerebral ventricle dilatation | Unrelated | 1 (2.6%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 2 (1.0%)
Convulsion | Unrelated | 2 (5.1%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
Convulsion | Possibly | 2 (5.1%) | 2 (1.9%) | 1 (3.2%) | 2 (7.4%) | 7 (3.5%)
Encephalomalacia | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Intracranial haematoma | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Intraventricular haemorrhage neonatal | Unrelated | 2 (5.1%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Periventricular leukomalacia | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Subarachnoid haemorrhage | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Vocal cord paralysis | Unrelated | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Vocal cord paresis | Unrelated | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Psychiatric disorders | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Agitation | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Renal and urinary disorders | Unrelated | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 3 (1.5%)
Renal and urinary disorders | Possibly | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Hydronephrosis | Unrelated | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Renal failure | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Renal failure acute | Possibly | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Vesicoureteric reflux | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Respiratory, thoracic and mediastinal disorders | Unrelated | 8 (20.5%) | 9 (8.7%) | 4 (12.9%) | 5 (18.5%) | 26 (13.0%)
Respiratory, thoracic and mediastinal disorders | Possibly | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Acute respiratory failure | Possibly | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Apnoea | Unrelated | 0 (0.0%) | 1 (1.0%) | 1 (3.2%) | 0 (0.0%) | 2 (1.0%)
Atelectasis | Unrelated | 2 (5.1%) | 0 (0.0%) | 0 (0.0%) | 3 (11.1%) | 5 (2.5%)
Bronchopulmonary dysplasia | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Hypercapnia | Unrelated | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Hypopnoea | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Infantile apnoeic attack | Unrelated | 2 (5.1%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Lung disorder | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Neonatal respiratory distress syndrome | Unrelated | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Pneumonia aspiration | Unrelated | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Pneumothorax | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Pneumothorax | Possibly | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Pulmonary haemorrhage | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Pulmonary hypertension | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Pulmonary interstitial emphysema syndrome | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Pulmonary oedema | Unrelated | 1 (2.6%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 2 (1.0%)
Pulmonary pneumatocele | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Pulmonary vascular disorder | Unrelated | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Respiratory arrest | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Respiratory distress | Unrelated | 0 (0.0%) | 3 (2.9%) | 0 (0.0%) | 1 (3.7%) | 4 (2.0%)
Respiratory failure | Unrelated | 1 (2.6%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
Stridor | Unrelated | 0 (0.0%) | 1 (1.0%) | 1 (3.2%) | 0 (0.0%) | 2 (1.0%)
Tachypnoea | Unrelated | 0 (0.0%) | 0 (0.0%) | 3 (9.7%) | 0 (0.0%) | 3 (1.5%)
Skin and subcutaneous tissue disorders | Unrelated | 0 (0.0%) | 1 (1.0%) | 1 (3.2%) | 0 (0.0%) | 2 (1.0%)
Skin and subcutaneous tissue disorders | Possibly | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Dermatitis diaper | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Periorbital oedema | Unrelated | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Rash | Possibly | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Skin disorder | Possibly | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Surgical and medical procedures | Unrelated | 0 (0.0%) | 1 (1.0%) | 1 (3.2%) | 1 (3.7%) | 3 (1.5%)
Endotracheal intubation | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Ileostomy | Unrelated | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Mechanical ventilation | Unrelated | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Vascular disorders | Unrelated | 2 (5.1%) | 4 (3.9%) | 0 (0.0%) | 1 (3.7%) | 7 (3.5%)
Vascular disorders | Possibly | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Hypertension | Unrelated | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Hypotension | Unrelated | 1 (2.6%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
Hypotension | Possibly | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Hypovolaemic shock | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Poor peripheral circulation | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Poor venous access | Unrelated | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Not Coded | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Not Coded | Unrelated | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)

The percentages are based on the total number of safety Participants in each age group or total.

Participants are counted once at the greatest relationship at each SOC and preferred term levels. TEAE with missing causality will be considered as definitely related to study drug.

Table 14.3.1.5 Summary of Level 2 Laboratory Adverse Events by Gestational, Postnatal Age Stratum, MedDRA System Organ Class, and Preferred Term

Population: Safety Participants

System Organ Class (SOC)/Preferred Term | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
System Organ Class (SOC)/Preferred Term | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Level II AE | 2 (5.1%) | 7 (6.8%) | 0 | 0 | 9 (4.5%)
Investigations | 2 (5.1%) | 7 (6.8%) | 0 (0.0%) | 0 (0.0%) | 9 (4.5%)
Aspartate aminotransferase increased | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Bilirubin conjugated increased | 2 (5.1%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 5 (2.5%)
Blood creatinine increased | 0 (0.0%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)

The percentages are based on the total number of safety Participants in each age group or total.

Participants are counted once at the SOC and preferred term levels.

Table 14.3.2.1 Summary of Adverse Events of Special Interest by Gestational, Postnatal Age Stratum, MedDRA System Organ Class, and Preferred Term

Population: Safety Participants

System Organ Class (SOC)/Preferred Term | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
System Organ Class (SOC)/Preferred Term | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Number of Participants with Special Interest AEs | 6 (15.4%) | 8 (7.8%) | 1 (3.2%) | 2 (7.4%) | 17 (8.5%)
Investigations | 2 (5.1%) | 7 (6.8%) | 0 (0.0%) | 0 (0.0%) | 9 (4.5%)
Aspartate aminotransferase increased | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Bilirubin conjugated increased | 2 (5.1%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 5 (2.5%)
Blood creatinine increased | 0 (0.0%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
Nervous system disorders | 4 (10.3%) | 3 (2.9%) | 1 (3.2%) | 2 (7.4%) | 10 (5.0%)
Convulsion | 4 (10.3%) | 3 (2.9%) | 1 (3.2%) | 2 (7.4%) | 10 (5.0%)

The percentages are based on the total number of safety Participants in each age group or total.

Participants are counted once at the SOC and preferred term levels.

Table 14.3.2.2 Summary of Adverse Events of Seizures by Gestational, Postnatal Age Stratum, MedDRA System Organ Class, and Preferred Term

Population: Safety Participants

System Organ Class (SOC)/Preferred Term | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
System Organ Class (SOC)/Preferred Term | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Seizure | 4 (10.3%) | 3 (2.9%) | 1 (3.2%) | 2 (7.4%) | 10 (5.0%)
Nervous system disorders | 4 (10.3%) | 3 (2.9%) | 1 (3.2%) | 2 (7.4%) | 10 (5.0%)
Convulsion | 4 (10.3%) | 3 (2.9%) | 1 (3.2%) | 2 (7.4%) | 10 (5.0%)

The percentages are based on the total number of safety Participants in each age group or total.

Participants are counted once at the SOC and preferred term levels.

Participant ▬ seizure occurred prior to enrollment. It is not included in this table.

Participant ▬ reported seizure but central and local review determined it was not a seizure. It is not included in this table.

Table 14.3.2.3 Summary of Serious Adverse Events by Gestational, Postnatal Age Stratum, MedDRA System Organ Class, and Preferred Term

Population: Safety Participants

System Organ Class (SOC)/Preferred Term | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
System Organ Class (SOC)/Preferred Term | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Number of Participants with at Least One SAE | 9 (23.1%) | 18 (17.5%) | 2 (6.5%) | 5 (18.5%) | 34 (17.0%)
Cardiac disorders | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Bradycardia | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Congenital, familial and genetic disorders | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Congenital diaphragmatic hernia | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Patent ductus arteriosus | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Eye disorders | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Retinopathy of prematurity | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Gastrointestinal disorders | 5 (12.8%) | 5 (4.9%) | 1 (3.2%) | 2 (7.4%) | 13 (6.5%)
Colonic stenosis | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Ileal perforation | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Intestinal ischaemia | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Intestinal obstruction | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Intestinal perforation | 2 (5.1%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
Intestinal stenosis | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Necrotising colitis | 2 (5.1%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
Rectal haemorrhage | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
General disorders and administration site conditions | 2 (5.1%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
Multi-organ failure | 2 (5.1%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
Infections and infestations | 1 (2.6%) | 6 (5.8%) | 0 (0.0%) | 0 (0.0%) | 7 (3.5%)
Abdominal sepsis | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Bacterial sepsis | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Fungal sepsis | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Meningitis | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Respiratory syncytial virus infection | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Sepsis | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Injury, poisoning and procedural complications | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Wound dehiscence | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Investigations | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Chest X-ray abnormal | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Nervous system disorders | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Subarachnoid haemorrhage | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Respiratory, thoracic and mediastinal disorders | 1 (2.6%) | 2 (1.9%) | 1 (3.2%) | 2 (7.4%) | 6 (3.0%)
Apnoea | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
Pneumonia aspiration | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Pulmonary haemorrhage | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Respiratory arrest | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Respiratory distress | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Respiratory failure | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)

The percentages are based on the total number of safety Participants in each age group or total.

Participants are counted once at the SOC and preferred term levels.

Participant ▬ had one Serious Adverse Event before first study dose.

Table 14.3.2.4 Summary of Treatment Emergent Adverse Events Leading to Study Drug Discontinuation by Gestational, Postnatal Age Stratum, MedDRA System Organ Class, and Preferred Term

Population: Safety Participants

System Organ Class (SOC)/Preferred Term | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
System Organ Class (SOC)/Preferred Term | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Participants with AE that Led to Study Drug Discontinuation | 1 (2.6%) | 3 (2.9%) | 0 | 2 (7.4%) | 6 (3.0%)
Investigations | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Bilirubin conjugated increased | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Nervous system disorders | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Convulsion | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
Renal and urinary disorders | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Renal failure | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Renal failure acute | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Vascular disorders | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
Hypertension | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)

The percentages are based on the total number of safety Participants in each age group or total.

Participants are counted once at the SOC and preferred term levels.

Table 14.3.2.5 Summary of Treatment Emergent Adverse Events Resulting In Death by Gestational, Postnatal Age Stratum, MedDRA System Organ Class, and Preferred Term

Population: Safety Participants

System Organ Class (SOC)/Preferred Term | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
System Organ Class (SOC)/Preferred Term | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Death | 3 (7.7%) | 8 (7.8%) | 0 | 0 | 11 (5.5%)
Congenital, familial and genetic disorders | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Congenital diaphragmatic hernia | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Gastrointestinal disorders | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Intestinal perforation | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
General disorders and administration site conditions | 2 (5.1%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
Multi-organ failure | 2 (5.1%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
Infections and infestations | 0 (0.0%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
Bacterial sepsis | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Meningitis | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Sepsis | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Investigations | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Bilirubin conjugated increased | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Blood triglycerides increased | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Metabolism and nutrition disorders | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Hyperlipidaemia | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Nervous system disorders | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Intracranial haematoma | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Subarachnoid haemorrhage | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Respiratory, thoracic and mediastinal disorders | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
Pulmonary haemorrhage | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Respiratory failure | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Vascular disorders | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
Hypotension | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)

The percentages are based on the total number of safety Participants in each age group or total.

Participants are counted once at the SOC and preferred term levels.

Table 14.3.2.6 Analysis of Key Safety Endpoints

Population: Safety Participants

Category/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Category/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Death
N(%) | 3 (7.7%) | 8 (7.8%) | 0 (0.0%) | 0 (0.0%) | 11 (5.5%)
95% CI for Proportion^1^ | (1.6%, 20.9%) | (3.4%, 14.7%) | | | (2.8%, 9.6%)
P-value^2^ (Proportion=20%) | 0.066 | 0.001 | | | 0.000
Seizures
N(%) | 4 (10.3%) | 3 (2.9%) | 1 (3.2%) | 2 (7.4%) | 10 (5.0%)
95% CI for Proportion^1^ | (2.9%, 24.2%) | (0.6%, 8.3%) | (0.1%, 16.7%) | (0.9%, 24.3%) | (2.4%, 9.0%)
P-value^2^ (Proportion=2%) | 0.015 | 0.679 | 0.931 | 0.202 | 0.015
Strictures
N(%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%)
95% CI for Proportion^1^
P-value^2^ (Proportion=2%)
Perforation
N(%) | 2 (5.1%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
95% CI for Proportion^1^ | (0.6%, 17.3%) | (0.2%, 6.8%) | | | (0.6%, 5.0%)
P-value^2^ (Proportion=5%) | 1.000 | 0.213 | | | 0.053
Wound Dehiscence
N(%) | 1 (2.6%) | 1 (1.0%) | 1 (3.2%) | 1 (3.7%) | 4 (2.0%)
95% CI for Proportion^1^ | (0.1%, 13.5%) | (0.0%, 5.3%) | (0.1%, 16.7%) | (0.1%, 19.0%) | (0.6%, 5.0%)
P-value^2^ (Proportion=2%) | 1.000 | 0.774 | 0.931 | 0.841 | 1.000
Development of Candidiasis
N(%) | 5 (12.8%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 8 (4.0%)
95% CI for Proportion^1^ | (4.3%, 27.4%) | (0.6%, 8.3%) | | | (1.7%, 7.7%)
P-value^2^ (Proportion=10%) | 0.701 | 0.012 | | | 0.003
Antimicrobial Therapy Failure
N(%) | 7 (17.9%) | 12 (11.7%) | 2 (6.5%) | 2 (7.4%) | 23 (11.5%)
95% CI for Proportion^1^ | (7.5%, 33.5%) | (6.2%, 19.5%) | (0.8%, 21.4%) | (0.9%, 24.3%) | (7.4%, 16.8%)
P-value^2^ (Proportion=45%) | 0.001 | 0.000 | 0.000 | 0.000 | 0.000

The percentages are based on the total number of safety Participants in each age group or total.

1 The exact binomial Confidence Interval will be used for 95% CI of Proportion.

2 P-value is used to test the expected proportion listed in the parenthesis for each safety endpoint.

Participant ▬ seizure occurred prior to enrollment. It is not included in this table.

Participant ▬ reported seizure but central and local review determined it was not a seizure. It is not included in this table.

Table 14.3.2.7 Analysis of Seizures

Population: Safety Participants

Category/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200) | P_value^1^
Category/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200) | P_value^1^
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Number of Participants with at least one Seizure
N(%) | 4 (10.3%) | 3 (2.9%) | 1 (3.2%) | 2 (7.4%) | 10 (5.0%) | 0.2111
95% CI for Proportion^2^ | (2.9%, 24.2%) | (0.6%, 8.3%) | (0.1%, 16.7%) | (0.9%, 24.3%) | (2.4%, 9.0%)
Number of Seizures or Seizure-Like Activity | 6 | 3 | 1 | 3 | 13
Locally Diagnosed Clinical Seizures
N(%) | 4 (10.3%) | 3 (2.9%) | 1 (3.2%) | 2 (7.4%) | 10 (5.0%) | 0.2111
95% CI for Proportion | (2.9%, 24.2%) | (0.6%, 8.3%) | (0.1%, 16.7%) | (0.9%, 24.3%) | (2.4%, 9.0%)
Locally Diagnosed EEG-confirmed Seizures
N(%) | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%) | 0.7360
95% CI for Proportion | (0.1%, 13.5%) | (0.0%, 5.3%) | | | (0.1%, 3.6%)
Centrally Diagnosed Clinical Seizures
N(%) | 4 (10.3%) | 3 (2.9%) | 1 (3.2%) | 2 (7.4%) | 10 (5.0%) | 0.2111
95% CI for Proportion | (2.9%, 24.2%) | (0.6%, 8.3%) | (0.1%, 16.7%) | (0.9%, 24.3%) | (2.4%, 9.0%)
Centrally Diagnosed EEG-confirmed Seizures
N(%) | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%) | 0.7360
95% CI for Proportion | (0.1%, 13.5%) | (0.0%, 5.3%) | | | (0.1%, 3.6%)

The percentages are based on the total number of safety Participants in each age group or total.

1 Fisher’s exact P-value is used to test the seizure rate among the age groups.

2 The exact binomial Confidence Interval will be used for 95% CI of Proportion.

Participant ▬ seizure occurred prior to enrollment. It is not included in this table.

Participant ▬ reported seizure but central and local review determined it was not a seizure. It is not included in this table.

Section 14.3.3 Narratives of Deaths, Other Serious and Certain Other Significant Adverse Events -- Note: For the purposes of de-identification of Protected Health Information, the narratives were redacted from the redacted version of the CSR.

Table 14.3.4.1

Summary of Blood Chemistry by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Glucose (mg/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 35 | 99 | 29 | 21 | 184
Mean (SD) | 115.8 (50.0) | 99.7 (36.5) | 84.3 (29.8) | 90.4 (27.4) | 99.3 (38.6)
95% CI | 98.7, 133.0 | 92.4, 107.0 | 73.0, 95.7 | 78.0, 102.9 | 93.7, 104.9
Median | 109.0 | 90.0 | 78.0 | 84.0 | 87.0
Min, Max | 48.0, 225.0 | 38.0, 248.0 | 45.0, 167.0 | 66.0, 186.0 | 38.0, 248.0
Days1_7
N | 34 | 90 | 26 | 19 | 169
Mean (SD) | 122.0 (69.2) | 93.2 (23.6) | 76.7 (15.9) | 90.2 (25.7) | 96.1 (39.3)
95% CI | 97.8, 146.1 | 88.2, 98.1 | 70.2, 83.1 | 77.8, 102.5 | 90.1, 102.1
Median | 101.5 | 89.5 | 73.5 | 86.0 | 88.0
Min, Max | 50.0, 436.0 | 50.0, 175.0 | 51.0, 126.0 | 51.0, 175.0 | 50.0, 436.0
Days8_14
N | 29 | 66 | 17 | 15 | 127
Mean (SD) | 106.5 (39.1) | 88.9 (26.9) | 74.6 (12.5) | 77.9 (7.3) | 89.7 (29.2)
95% CI | 91.7, 121.4 | 82.3, 95.5 | 68.2, 81.0 | 73.9, 82.0 | 84.6, 94.8
Median | 93.0 | 85.0 | 75.0 | 77.0 | 84.0
Min, Max | 63.0, 254.0 | 52.0, 239.0 | 53.0, 101.0 | 67.0, 89.0 | 52.0, 254.0
Days15_21
N | 22 | 43 | 10 | 9 | 84
Mean (SD) | 110.6 (22.8) | 85.8 (18.4) | 79.3 (11.0) | 82.6 (19.0) | 91.2 (22.2)
95% CI | 100.5, 120.7 | 80.2, 91.5 | 71.4, 87.2 | 67.9, 97.2 | 86.4, 96.0
Median | 113.5 | 81.0 | 76.5 | 84.0 | 87.0
Min, Max | 72.0, 154.0 | 55.0, 165.0 | 67.0, 102.0 | 55.0, 119.0 | 55.0, 165.0
Days22_28
N | 14 | 28 | 4 | 5 | 51
Mean (SD) | 112.3 (47.6) | 83.8 (11.7) | 89.5 (8.3) | 87.6 (33.3) | 92.4 (30.2)
95% CI | 84.8, 139.8 | 79.2, 88.3 | 76.2, 102.8 | 46.3, 128.9 | 83.9, 100.9
Median | 99.5 | 83.0 | 89.0 | 83.0 | 88.0
Min, Max | 73.0, 265.0 | 59.0, 112.0 | 80.0, 100.0 | 61.0, 144.0 | 59.0, 265.0

Summary of Blood Chemistry by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Creatinine (mg/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 35 | 95 | 29 | 22 | 181
Mean (SD) | 0.9 (0.4) | 0.5 (0.3) | 0.6 (0.3) | 0.4 (0.3) | 0.6 (0.4)
95% CI | 0.8, 1.1 | 0.5, 0.6 | 0.5, 0.7 | 0.3, 0.5 | 0.5, 0.7
Median | 1.0 | 0.4 | 0.6 | 0.3 | 0.5
Min, Max | 0.2, 1.9 | 0.1, 1.9 | 0.3, 1.3 | 0.1, 1.5 | 0.1, 1.9
Days1_7
N | 36 | 90 | 25 | 22 | 173
Mean (SD) | 0.8 (0.3) | 0.5 (0.4) | 0.4 (0.2) | 0.3 (0.2) | 0.5 (0.4)
95% CI | 0.7, 0.9 | 0.4, 0.6 | 0.4, 0.5 | 0.2, 0.4 | 0.5, 0.6
Median | 0.7 | 0.4 | 0.4 | 0.3 | 0.4
Min, Max | 0.3, 1.7 | 0.0, 3.1 | 0.2, 1.0 | 0.1, 1.1 | 0.0, 3.1
Days8_14
N | 30 | 65 | 16 | 16 | 127
Mean (SD) | 0.8 (0.4) | 0.4 (0.5) | 0.4 (0.2) | 0.3 (0.1) | 0.5 (0.4)
95% CI | 0.6, 0.9 | 0.3, 0.6 | 0.3, 0.5 | 0.2, 0.3 | 0.4, 0.6
Median | 0.6 | 0.3 | 0.3 | 0.3 | 0.4
Min, Max | 0.3, 1.9 | 0.0, 2.7 | 0.1, 0.9 | 0.1, 0.5 | 0.0, 2.7
Days15_21
N | 22 | 44 | 10 | 9 | 85
Mean (SD) | 0.7 (0.4) | 0.4 (0.4) | 0.3 (0.1) | 0.3 (0.2) | 0.4 (0.4)
95% CI | 0.5, 0.8 | 0.3, 0.5 | 0.2, 0.3 | 0.2, 0.4 | 0.3, 0.5
Median | 0.5 | 0.3 | 0.3 | 0.3 | 0.3
Min, Max | 0.3, 1.9 | 0.0, 2.9 | 0.1, 0.4 | 0.1, 0.6 | 0.0, 2.9
Days22_28
N | 16 | 29 | 4 | 4 | 53
Mean (SD) | 0.6 (0.3) | 0.4 (0.5) | 0.2 (0.1) | 0.2 (0.1) | 0.5 (0.4)
95% CI | 0.4, 0.7 | 0.3, 0.6 | 0.1, 0.3 | 0.1, 0.4 | 0.3, 0.6
Median | 0.5 | 0.3 | 0.2 | 0.3 | 0.3
Min, Max | 0.2, 1.2 | 0.0, 2.0 | 0.2, 0.3 | 0.1, 0.3 | 0.0, 2.0

Summary of Blood Chemistry by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: BUN (mg/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 36 | 97 | 28 | 22 | 183
Mean (SD) | 29.4 (15.2) | 16.2 (15.4) | 15.2 (10.6) | 15.5 (12.4) | 18.6 (15.3)
95% CI | 24.2, 34.5 | 13.1, 19.3 | 11.1, 19.3 | 10.0, 20.9 | 16.3, 20.8
Median | 25.5 | 12.0 | 13.5 | 12.0 | 14.0
Min, Max | 8.0, 68.0 | 1.0, 83.0 | 2.0, 41.0 | 3.0, 53.0 | 1.0, 83.0
Days1_7
N | 35 | 90 | 24 | 21 | 170
Mean (SD) | 21.0 (12.6) | 16.2 (14.7) | 15.4 (10.9) | 14.0 (7.7) | 16.8 (13.2)
95% CI | 16.7, 25.3 | 13.1, 19.3 | 10.8, 20.0 | 10.5, 17.5 | 14.8, 18.8
Median | 18.0 | 11.0 | 14.0 | 15.0 | 13.0
Min, Max | 4.0, 53.0 | 3.0, 82.0 | 3.0, 59.0 | 4.0, 37.0 | 3.0, 82.0
Days8_14
N | 30 | 65 | 16 | 17 | 128
Mean (SD) | 24.7 (17.1) | 14.7 (15.3) | 12.1 (5.3) | 11.9 (4.2) | 16.4 (14.6)
95% CI | 18.3, 31.1 | 11.0, 18.5 | 9.2, 14.9 | 9.7, 14.0 | 13.8, 18.9
Median | 19.5 | 11.0 | 11.0 | 11.0 | 12.0
Min, Max | 5.0, 76.0 | 2.0, 88.0 | 2.0, 21.0 | 5.0, 21.0 | 2.0, 88.0
Days15_21
N | 22 | 45 | 10 | 10 | 87
Mean (SD) | 22.2 (16.3) | 13.0 (16.8) | 14.2 (6.7) | 14.2 (5.6) | 15.6 (15.3)
95% CI | 15.0, 29.4 | 7.9, 18.0 | 9.4, 19.0 | 10.2, 18.2 | 12.3, 18.8
Median | 17.5 | 10.0 | 12.5 | 14.5 | 12.0
Min, Max | 5.0, 70.0 | 1.0, 114.0 | 4.0, 25.0 | 7.0, 25.0 | 1.0, 114.0
Days22_28
N | 16 | 29 | 4 | 6 | 55
Mean (SD) | 18.9 (11.2) | 15.1 (22.6) | 15.3 (8.6) | 15.7 (10.1) | 16.3 (17.7)
95% CI | 13.0, 24.9 | 6.5, 23.7 | 1.5, 29.0 | 5.1, 26.2 | 11.5, 21.1
Median | 14.5 | 10.0 | 15.0 | 13.0 | 12.0
Min, Max | 4.0, 39.0 | 2.0, 127.0 | 5.0, 26.0 | 2.0, 29.0 | 2.0, 127.0

Summary of Blood Chemistry by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: AST (U/L)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 6 | 31 | 7 | 16 | 60
Mean (SD) | 56.8 (68.3) | 52.9 (51.9) | 539.6 (1243.4) | 117.8 (163.4) | 127.4 (435.2)
95% CI | −14.8, 128.5 | 33.9, 71.9 | −610.4, 1689.6 | 30.7, 204.9 | 15.0, 239.8
Median | 26.5 | 31.0 | 73.0 | 52.5 | 36.5
Min, Max | 19.0, 194.0 | 12.0, 203.0 | 26.0, 3358.0 | 18.0, 621.0 | 12.0, 3358.0
Days1_7
N | 14 | 41 | 10 | 13 | 78
Mean (SD) | 28.6 (11.5) | 58.8 (73.5) | 34.9 (12.4) | 94.3 (100.0) | 56.2 (69.7)
95% CI | 21.9, 35.2 | 35.6, 82.0 | 26.0, 43.8 | 33.9, 154.8 | 40.5, 71.9
Median | 26.0 | 33.0 | 35.5 | 50.0 | 33.0
Min, Max | 9.0, 50.0 | 13.0, 419.0 | 19.0, 60.0 | 22.0, 381.0 | 9.0, 419.0
Days8_14
N | 14 | 36 | 10 | 8 | 68
Mean (SD) | 28.3 (7.5) | 60.8 (59.4) | 34.3 (17.2) | 100.9 (100.4) | 54.9 (58.6)
95% CI | 23.9, 32.6 | 40.7, 80.9 | 22.0, 46.6 | 17.0, 184.8 | 40.8, 69.1
Median | 26.5 | 35.0 | 32.5 | 66.5 | 32.5
Min, Max | 19.0, 46.0 | 15.0, 282.0 | 11.0, 67.0 | 19.0, 308.0 | 11.0, 308.0
Days15_21
N | 16 | 26 | 5 | 8 | 55
Mean (SD) | 32.8 (11.1) | 83.2 (79.2) | 37.6 (13.2) | 215.9 (198.9) | 83.7 (107.9)
95% CI | 26.9, 38.7 | 51.2, 115.2 | 21.2, 54.0 | 49.6, 382.2 | 54.5, 112.9
Median | 32.0 | 53.0 | 41.0 | 127.0 | 40.0
Min, Max | 16.0, 62.0 | 15.0, 295.0 | 19.0, 54.0 | 33.0, 567.0 | 15.0, 567.0
Days22_28
N | 11 | 15 | 3 | 3 | 32
Mean (SD) | 46.2 (22.9) | 98.6 (109.2) | 56.0 (11.8) | 338.3 (394.6) | 99.1 (149.4)
95% CI | 30.8, 61.6 | 38.2, 159.0 | 26.7, 85.3 | −641.8, 1318.5 | 45.2, 152.9
Median | 38.0 | 65.0 | 59.0 | 177.0 | 50.0
Min, Max | 25.0, 98.0 | 19.0, 410.0 | 43.0, 66.0 | 50.0, 788.0 | 19.0, 788.0

Summary of Blood Chemistry by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: ALT (U/L)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 6 | 31 | 7 | 16 | 60
Mean (SD) | 17.8 (27.6) | 30.9 (30.6) | 184.9 (345.6) | 100.4 (177.1) | 66.1 (153.4)
95% CI | −11.1, 46.8 | 19.7, 42.2 | −134.7, 504.4 | 6.0, 194.7 | 26.5, 105.7
Median | 7.5 | 18.0 | 14.0 | 41.0 | 24.5
Min, Max | 4.0, 74.0 | 4.0, 120.0 | 11.0, 956.0 | 12.0, 746.0 | 4.0, 956.0
Days1_7
N | 15 | 41 | 10 | 14 | 80
Mean (SD) | 13.3 (11.4) | 28.7 (33.1) | 35.5 (45.4) | 59.0 (36.1) | 32.0 (35.1)
95% CI | 7.0, 19.6 | 18.3, 39.1 | 3.0, 68.0 | 38.2, 79.8 | 24.2, 39.8
Median | 9.0 | 18.0 | 16.0 | 58.5 | 18.0
Min, Max | 5.0, 44.0 | 5.0, 140.0 | 6.0, 123.0 | 17.0, 126.0 | 5.0, 140.0
Days8_14
N | 14 | 37 | 10 | 8 | 69
Mean (SD) | 12.0 (4.9) | 33.5 (35.5) | 22.5 (14.8) | 61.3 (45.8) | 30.8 (33.4)
95% CI | 9.2, 14.8 | 21.7, 45.4 | 11.9, 33.1 | 23.0, 99.5 | 22.8, 38.8
Median | 12.0 | 17.0 | 16.5 | 53.0 | 16.0
Min, Max | 4.0, 21.0 | 6.0, 131.0 | 11.0, 59.0 | 14.0, 130.0 | 4.0, 131.0
Days15_21
N | 16 | 26 | 5 | 8 | 55
Mean (SD) | 16.3 (7.9) | 42.5 (44.0) | 20.6 (8.0) | 168.5 (196.9) | 51.2 (92.0)
95% CI | 12.1, 20.4 | 24.7, 60.2 | 10.7, 30.5 | 3.9, 333.1 | 26.3, 76.1
Median | 14.0 | 20.5 | 20.0 | 110.0 | 20.0
Min, Max | 5.0, 39.0 | 6.0, 149.0 | 11.0, 33.0 | 20.0, 605.0 | 5.0, 605.0
Days22_28
N | 10 | 15 | 3 | 2 | 30
Mean (SD) | 24.0 (11.5) | 55.1 (52.1) | 47.0 (23.6) | 93.0 (97.6) | 46.5 (45.6)
95% CI | 15.8, 32.2 | 26.3, 84.0 | −11.7, 105.7 | −783.7, 969.7 | 29.4, 63.5
Median | 22.5 | 36.0 | 37.0 | 93.0 | 27.0
Min, Max | 11.0, 48.0 | 8.0, 168.0 | 30.0, 74.0 | 24.0, 162.0 | 8.0, 168.0

Summary of Blood Chemistry by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Alkaline Phosphatase (U/L)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 6 | 38 | 7 | 13 | 64
Mean (SD) | 517.0 (452.7) | 401.8 (255.8) | 107.4 (29.5) | 237.6 (151.1) | 347.1 (269.3)
95% CI | 42.0, 992.0 | 317.7, 485.9 | 80.1, 134.7 | 146.3, 328.9 | 279.8, 414.3
Median | 374.0 | 355.5 | 97.0 | 191.0 | 255.0
Min, Max | 113.0, 1368.0 | 79.0, 1051.0 | 72.0, 145.0 | 98.0, 641.0 | 72.0, 1368.0
Days1_7
N | 16 | 51 | 7 | 12 | 86
Mean (SD) | 202.8 (97.1) | 376.4 (232.5) | 176.7 (50.9) | 225.0 (116.8) | 306.7 (206.6)
95% CI | 151.0, 254.5 | 311.0, 441.8 | 129.6, 223.8 | 150.8, 299.2 | 262.4, 351.0
Median | 180.0 | 295.0 | 180.0 | 190.0 | 244.0
Min, Max | 62.0, 408.0 | 35.0, 967.0 | 93.0, 247.0 | 90.0, 438.0 | 35.0, 967.0
Days8_14
N | 14 | 36 | 8 | 7 | 65
Mean (SD) | 312.0 (127.6) | 453.7 (220.3) | 223.5 (63.0) | 290.4 (155.7) | 377.3 (201.4)
95% CI | 238.3, 385.7 | 379.1, 528.2 | 170.8, 276.2 | 146.4, 434.4 | 327.4, 427.2
Median | 326.0 | 383.0 | 216.0 | 244.0 | 321.0
Min, Max | 147.0, 547.0 | 178.0, 1103.0 | 130.0, 313.0 | 104.0, 555.0 | 104.0, 1103.0
Days15_21
N | 15 | 26 | 4 | 7 | 52
Mean (SD) | 361.1 (229.2) | 529.9 (281.3) | 242.0 (132.7) | 528.7 (195.7) | 458.9 (261.7)
95% CI | 234.1, 488.0 | 416.3, 643.5 | 30.9, 453.1 | 347.7, 709.7 | 386.0, 531.8
Median | 304.0 | 490.5 | 184.5 | 404.0 | 411.5
Min, Max | 107.0, 921.0 | 101.0, 1600.0 | 159.0, 440.0 | 366.0, 838.0 | 101.0, 1600.0
Days22_28
N | 8 | 15 | 3 | 2 | 28
Mean (SD) | 427.8 (244.1) | 568.8 (238.6) | 345.0 (248.1) | 509.5 (153.4) | 500.3 (239.3)
95% CI | 223.7, 631.8 | 436.7, 700.9 | −271.3, 961.3 | −869.1, 1888.1 | 407.5, 593.1
Median | 399.5 | 579.0 | 216.0 | 509.5 | 508.0
Min, Max | 123.0, 917.0 | 176.0, 1145.0 | 188.0, 631.0 | 401.0, 618.0 | 123.0, 1145.0

Summary of Blood Chemistry by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Total Bilirubin (mg/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 25 | 43 | 21 | 17 | 106
Mean (SD) | 4.6 (2.6) | 3.7 (3.3) | 6.5 (4.9) | 4.4 (5.0) | 4.6 (3.9)
95% CI | 3.6, 5.7 | 2.7, 4.7 | 4.3, 8.7 | 1.8, 7.0 | 3.8, 5.3
Median | 4.1 | 2.9 | 6.5 | 3.4 | 3.7
Min, Max | 0.8, 12.4 | 0.4, 13.0 | 0.1, 19.2 | 0.4, 20.8 | 0.1, 20.8
Days1_7
N | 28 | 49 | 15 | 16 | 108
Mean (SD) | 4.1 (3.4) | 3.3 (2.9) | 5.8 (4.5) | 2.9 (2.6) | 3.8 (3.4)
95% CI | 2.8, 5.5 | 2.5, 4.2 | 3.3, 8.3 | 1.5, 4.3 | 3.2, 4.5
Median | 3.7 | 2.5 | 5.4 | 1.8 | 2.9
Min, Max | 0.4, 18.7 | 0.2, 14.2 | 0.7, 14.9 | 0.4, 7.3 | 0.2, 18.7
Days8_14
N | 17 | 42 | 11 | 9 | 79
Mean (SD) | 3.4 (2.4) | 3.5 (3.1) | 3.4 (4.0) | 2.6 (2.3) | 3.3 (3.0)
95% CI | 2.2, 4.7 | 2.5, 4.4 | 0.7, 6.0 | 0.8, 4.4 | 2.7, 4.0
Median | 2.9 | 2.5 | 2.2 | 1.5 | 2.5
Min, Max | 0.6, 9.5 | 0.5, 13.5 | 0.5, 14.2 | 0.4, 6.3 | 0.4, 14.2
Days15_21
N | 16 | 27 | 6 | 8 | 57
Mean (SD) | 3.0 (1.9) | 3.3 (3.2) | 1.5 (1.2) | 6.3 (4.8) | 3.5 (3.2)
95% CI | 2.0, 4.1 | 2.1, 4.6 | 0.2, 2.8 | 2.3, 10.3 | 2.6, 4.3
Median | 3.0 | 2.1 | 1.3 | 5.6 | 2.6
Min, Max | 0.3, 6.6 | 0.4, 11.4 | 0.3, 3.7 | 0.7, 16.6 | 0.3, 16.6
Days22_28
N | 10 | 16 | 3 | 3 | 32
Mean (SD) | 3.5 (2.0) | 4.4 (3.9) | 4.4 (4.1) | 9.7 (8.0) | 4.6 (4.1)
95% CI | 2.1, 5.0 | 2.4, 6.5 | −5.8, 14.5 | −10.2, 29.6 | 3.2, 6.1
Median | 3.4 | 4.1 | 3.8 | 7.5 | 3.7
Min, Max | 0.7, 6.3 | 0.3, 15.2 | 0.6, 8.7 | 3.0, 18.6 | 0.3, 18.6

Summary of Blood Chemistry by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Direct Bilirubin (mg/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 17 | 32 | 13 | 8 | 70
Mean (SD) | 1.0 (1.6) | 2.3 (2.7) | 0.5 (0.6) | 1.5 (1.6) | 1.6 (2.2)
95% CI | 0.2, 1.8 | 1.3, 3.3 | 0.1, 0.9 | 0.1, 2.8 | 1.0, 2.1
Median | 0.6 | 1.6 | 0.3 | 1.1 | 0.6
Min, Max | 0.0, 6.5 | 0.0, 10.8 | 0.0, 2.0 | 0.0, 4.0 | 0.0, 10.8
Days1_7
N | 19 | 36 | 7 | 9 | 71
Mean (SD) | 1.9 (2.4) | 2.2 (2.4) | 0.8 (1.0) | 1.0 (1.3) | 1.8 (2.2)
95% CI | 0.8, 3.0 | 1.4, 3.0 | −0.1, 1.8 | 0.0, 2.0 | 1.3, 2.3
Median | 0.9 | 0.9 | 0.5 | 0.5 | 0.8
Min, Max | 0.0, 9.6 | 0.0, 10.3 | 0.0, 3.1 | 0.1, 3.7 | 0.0, 10.3
Days8_14
N | 11 | 30 | 5 | 6 | 52
Mean (SD) | 1.5 (1.5) | 2.5 (2.4) | 0.6 (0.6) | 1.8 (1.5) | 2.0 (2.1)
95% CI | 0.5, 2.5 | 1.6, 3.4 | 0.0, 1.3 | 0.2, 3.3 | 1.5, 2.6
Median | 1.1 | 1.9 | 0.6 | 1.5 | 1.5
Min, Max | 0.0, 4.2 | 0.2, 10.7 | 0.0, 1.5 | 0.0, 4.0 | 0.0, 10.7
Days15_21
N | 10 | 16 | 3 | 5 | 34
Mean (SD) | 2.5 (1.9) | 2.1 (2.2) | 0.3 (0.3) | 2.3 (1.6) | 2.1 (2.0)
95% CI | 1.1, 3.8 | 0.9, 3.3 | −0.3, 1.0 | 0.3, 4.3 | 1.4, 2.7
Median | 2.3 | 1.3 | 0.3 | 2.2 | 1.7
Min, Max | 0.1, 5.6 | 0.3, 8.5 | 0.1, 0.6 | 0.1, 4.5 | 0.1, 8.5
Days22_28
N | 5 | 7 | 1 | 1 | 14
Mean (SD) | 3.5 (1.4) | 3.6 (1.6) | 0.2 | 1.8 | 3.2 (1.7)
95% CI | 1.7, 5.2 | 2.0, 5.1 | | | 2.2, 4.1
Median | 3.8 | 3.9 | 0.2 | 1.8 | 3.7
Min, Max | 1.1, 4.7 | 0.8, 6.0 | 0.2, 0.2 | 1.8, 1.8 | 0.2, 6.0

Summary of Blood Chemistry by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Sodium (mmol/L)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 39 | 102 | 29 | 27 | 197
Mean (SD) | 139.0 (7.4) | 135.4 (4.4) | 138.4 (4.8) | 137.4 (2.6) | 136.8 (5.2)
95% CI | 136.6, 141.4 | 134.5, 136.3 | 136.6, 140.2 | 136.4, 138.4 | 136.1, 137.6
Median | 138.0 | 135.5 | 140.0 | 137.0 | 137.0
Min, Max | 124.0, 157.0 | 121.0, 145.0 | 126.0, 147.0 | 133.0, 143.0 | 121.0, 157.0
Days1_7
N | 38 | 94 | 27 | 23 | 182
Mean (SD) | 135.5 (6.3) | 137.0 (4.2) | 139.0 (3.3) | 137.8 (2.5) | 137.1 (4.6)
95% CI | 133.4, 137.5 | 136.1, 137.8 | 137.7, 140.3 | 136.7, 138.9 | 136.4, 137.7
Median | 135.0 | 137.0 | 140.0 | 138.0 | 137.0
Min, Max | 123.0, 152.0 | 123.0, 154.0 | 131.0, 144.0 | 132.0, 142.0 | 123.0, 154.0
Days8_14
N | 31 | 71 | 18 | 19 | 139
Mean (SD) | 137.4 (6.2) | 137.5 (4.3) | 138.4 (3.0) | 137.3 (2.0) | 137.6 (4.4)
95% CI | 135.1, 139.7 | 136.5, 138.5 | 137.0, 139.9 | 136.4, 138.3 | 136.9, 138.3
Median | 137.0 | 138.0 | 139.0 | 138.0 | 138.0
Min, Max | 127.0, 154.0 | 121.0, 146.0 | 132.0, 143.0 | 134.0, 140.0 | 121.0, 154.0
Days15_21
N | 24 | 48 | 9 | 10 | 91
Mean (SD) | 136.1 (4.3) | 137.8 (3.3) | 138.8 (3.9) | 136.5 (2.4) | 137.3 (3.6)
95% CI | 134.3, 137.9 | 136.8, 138.7 | 135.8, 141.7 | 134.8, 138.2 | 136.5, 138.0
Median | 136.5 | 137.5 | 140.0 | 135.5 | 137.0
Min, Max | 127.0, 148.0 | 132.0, 145.0 | 131.0, 143.0 | 133.0, 141.0 | 127.0, 148.0
Days22_28
N | 17 | 31 | 4 | 5 | 57
Mean (SD) | 134.9 (5.1) | 138.2 (3.0) | 133.5 (4.8) | 137.8 (0.4) | 136.8 (4.0)
95% CI | 132.3, 137.5 | 137.1, 139.2 | 125.9, 141.1 | 137.2, 138.4 | 135.8, 137.9
Median | 135.0 | 138.0 | 134.0 | 138.0 | 137.0
Min, Max | 126.0, 146.0 | 133.0, 146.0 | 128.0, 138.0 | 137.0, 138.0 | 126.0, 146.0

Summary of Blood Chemistry by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Potassium (mmol/L)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 39 | 103 | 29 | 27 | 198
Mean (SD) | 4.1 (0.8) | 4.3 (0.8) | 4.5 (0.8) | 4.4 (0.8) | 4.3 (0.8)
95% CI | 3.9, 4.4 | 4.1, 4.4 | 4.1, 4.8 | 4.0, 4.7 | 4.2, 4.4
Median | 4.1 | 4.4 | 4.4 | 4.2 | 4.3
Min, Max | 2.8, 6.5 | 2.6, 6.3 | 3.0, 5.8 | 2.2, 5.8 | 2.2, 6.5
Days1_7
N | 38 | 95 | 27 | 23 | 183
Mean (SD) | 4.6 (0.8) | 4.5 (0.8) | 4.5 (0.8) | 4.7 (1.0) | 4.5 (0.8)
95% CI | 4.4, 4.9 | 4.3, 4.6 | 4.2, 4.8 | 4.3, 5.1 | 4.4, 4.7
Median | 4.6 | 4.6 | 4.5 | 4.7 | 4.6
Min, Max | 3.3, 6.7 | 2.9, 7.4 | 3.1, 6.1 | 3.2, 6.7 | 2.9, 7.4
Days8_14
N | 31 | 70 | 18 | 19 | 138
Mean (SD) | 4.9 (1.2) | 4.6 (0.8) | 4.8 (0.5) | 4.8 (0.9) | 4.7 (0.9)
95% CI | 4.5, 5.4 | 4.4, 4.8 | 4.5, 5.0 | 4.4, 5.2 | 4.6, 4.9
Median | 4.7 | 4.6 | 4.8 | 4.5 | 4.6
Min, Max | 3.0, 7.6 | 3.1, 7.6 | 4.0, 5.8 | 3.5, 7.0 | 3.0, 7.6
Days15_21
N | 24 | 48 | 9 | 10 | 91
Mean (SD) | 4.4 (0.8) | 4.5 (0.9) | 4.9 (0.4) | 4.8 (1.2) | 4.6 (0.9)
95% CI | 4.1, 4.8 | 4.3, 4.8 | 4.5, 5.2 | 4.0, 5.7 | 4.4, 4.8
Median | 4.4 | 4.7 | 4.9 | 4.5 | 4.7
Min, Max | 2.0, 6.1 | 2.8, 7.4 | 4.2, 5.5 | 3.3, 6.9 | 2.0, 7.4
Days22_28
N | 16 | 30 | 4 | 6 | 56
Mean (SD) | 4.6 (0.9) | 4.7 (1.0) | 4.8 (0.8) | 4.6 (1.2) | 4.6 (1.0)
95% CI | 4.1, 5.1 | 4.3, 5.1 | 3.6, 5.9 | 3.3, 5.8 | 4.4, 4.9
Median | 4.9 | 4.6 | 4.9 | 4.3 | 4.5
Min, Max | 2.9, 6.3 | 2.8, 6.9 | 3.8, 5.4 | 3.6, 6.9 | 2.8, 6.9

Summary of Blood Chemistry by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Chloride (mmol/L)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 36 | 98 | 29 | 27 | 190
Mean (SD) | 105.3 (8.0) | 102.3 (5.4) | 108.1 (4.2) | 102.9 (5.2) | 103.8 (6.1)
95% CI | 102.6, 108.0 | 101.2, 103.4 | 106.6, 109.7 | 100.8, 104.9 | 103.0, 104.7
Median | 105.5 | 103.0 | 108.0 | 104.0 | 104.5
Min, Max | 90.0, 123.0 | 88.0, 113.0 | 101.0, 118.0 | 93.0, 113.0 | 88.0, 123.0
Days1_7
N | 36 | 92 | 27 | 23 | 178
Mean (SD) | 100.9 (7.4) | 103.1 (5.3) | 107.1 (4.4) | 103.5 (4.9) | 103.3 (5.9)
95% CI | 98.4, 103.4 | 102.0, 104.2 | 105.4, 108.9 | 101.4, 105.6 | 102.5, 104.2
Median | 102.0 | 104.0 | 107.0 | 104.0 | 104.0
Min, Max | 84.0, 113.0 | 89.0, 117.0 | 96.0, 116.0 | 92.0, 113.0 | 84.0, 117.0
Days8_14
N | 30 | 71 | 18 | 19 | 138
Mean (SD) | 103.4 (6.3) | 104.2 (5.7) | 105.3 (4.3) | 103.9 (5.7) | 104.1 (5.7)
95% CI | 101.1, 105.8 | 102.9, 105.6 | 103.1, 107.4 | 101.2, 106.7 | 103.2, 105.1
Median | 103.0 | 104.0 | 105.0 | 105.0 | 104.0
Min, Max | 92.0, 116.0 | 88.0, 117.0 | 95.0, 112.0 | 91.0, 112.0 | 88.0, 117.0
Days15_21
N | 23 | 48 | 9 | 10 | 90
Mean (SD) | 102.7 (5.4) | 103.8 (6.0) | 108.2 (3.7) | 101.6 (6.2) | 103.7 (5.8)
95% CI | 100.4, 105.0 | 102.1, 105.6 | 105.4, 111.1 | 97.2, 106.0 | 102.5, 104.9
Median | 102.0 | 103.0 | 109.0 | 102.5 | 103.5
Min, Max | 94.0, 117.0 | 88.0, 115.0 | 102.0, 113.0 | 90.0, 109.0 | 88.0, 117.0
Days22_28
N | 16 | 30 | 4 | 6 | 56
Mean (SD) | 101.8 (4.5) | 104.1 (5.2) | 101.3 (4.8) | 102.8 (3.2) | 103.1 (4.8)
95% CI | 99.4, 104.2 | 102.2, 106.1 | 93.6, 108.9 | 99.5, 106.2 | 101.8, 104.4
Median | 102.0 | 103.5 | 102.5 | 102.5 | 103.0
Min, Max | 94.0, 111.0 | 95.0, 116.0 | 95.0, 105.0 | 99.0, 107.0 | 94.0, 116.0

Summary of Blood Chemistry by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Calcium (mg/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 34 | 98 | 28 | 25 | 185
Mean (SD) | 8.8 (1.0) | 9.1 (1.1) | 9.0 (1.1) | 9.5 (0.7) | 9.1 (1.1)
95% CI | 8.4, 9.2 | 8.9, 9.3 | 8.6, 9.4 | 9.3, 9.8 | 8.9, 9.2
Median | 8.9 | 9.3 | 9.1 | 9.5 | 9.2
Min, Max | 6.6, 10.6 | 1.3, 10.7 | 6.7, 10.9 | 8.4, 11.1 | 1.3, 11.1
Days1_7
N | 35 | 88 | 25 | 22 | 170
Mean (SD) | 9.2 (0.8) | 9.3 (0.7) | 9.6 (0.9) | 9.6 (0.7) | 9.4 (0.8)
95% CI | 9.0, 9.5 | 9.1, 9.4 | 9.3, 10.0 | 9.3, 9.9 | 9.2, 9.5
Median | 9.4 | 9.4 | 9.5 | 9.7 | 9.5
Min, Max | 7.4, 10.5 | 6.7, 10.5 | 7.9, 11.7 | 8.4, 10.9 | 6.7, 11.7
Days8_14
N | 28 | 64 | 15 | 18 | 125
Mean (SD) | 9.5 (0.8) | 9.0 (1.6) | 9.7 (0.5) | 9.7 (0.5) | 9.3 (1.2)
95% CI | 9.2, 9.8 | 8.6, 9.4 | 9.5, 10.0 | 9.4, 9.9 | 9.1, 9.5
Median | 9.7 | 9.2 | 9.8 | 9.6 | 9.5
Min, Max | 8.0, 10.8 | 1.3, 11.5 | 9.0, 10.6 | 9.1, 10.7 | 1.3, 11.5
Days15_21
N | 20 | 45 | 9 | 9 | 83
Mean (SD) | 9.6 (0.6) | 9.5 (0.6) | 9.6 (0.6) | 9.8 (0.4) | 9.6 (0.6)
95% CI | 9.3, 9.9 | 9.4, 9.7 | 9.1, 10.1 | 9.5, 10.1 | 9.5, 9.7
Median | 9.6 | 9.6 | 9.7 | 9.7 | 9.6
Min, Max | 8.6, 10.4 | 8.1, 10.9 | 8.1, 10.3 | 9.2, 10.4 | 8.1, 10.9
Days22_28
N | 14 | 28 | 4 | 5 | 51
Mean (SD) | 9.8 (0.5) | 9.5 (0.7) | 10.1 (0.2) | 9.8 (0.4) | 9.7 (0.6)
95% CI | 9.5, 10.1 | 9.3, 9.8 | 9.7, 10.5 | 9.2, 10.3 | 9.5, 9.8
Median | 9.8 | 9.6 | 10.0 | 9.7 | 9.7
Min, Max | 9.0, 11.2 | 8.2, 10.7 | 9.9, 10.4 | 9.2, 10.4 | 8.2, 11.2

Summary of Blood Chemistry by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Magnesium (mg/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 19 | 43 | 13 | 11 | 86
Mean (SD) | 2.1 (0.4) | 2.0 (0.4) | 2.1 (0.3) | 2.0 (0.2) | 2.0 (0.4)
95% CI | 1.9, 2.3 | 1.9, 2.2 | 1.9, 2.3 | 1.9, 2.1 | 2.0, 2.1
Median | 2.0 | 2.0 | 2.0 | 2.0 | 2.0
Min, Max | 1.3, 2.9 | 1.2, 3.2 | 1.8, 3.0 | 1.8, 2.2 | 1.2, 3.2
Days1_7
N | 26 | 50 | 12 | 15 | 103
Mean (SD) | 1.9 (0.4) | 2.0 (0.3) | 2.0 (0.3) | 1.9 (0.2) | 2.0 (0.3)
95% CI | 1.8, 2.1 | 2.0, 2.1 | 1.8, 2.1 | 1.8, 2.1 | 1.9, 2.0
Median | 1.9 | 2.1 | 2.1 | 1.9 | 2.0
Min, Max | 1.1, 2.8 | 1.5, 2.5 | 1.4, 2.4 | 1.6, 2.4 | 1.1, 2.8
Days8_14
N | 19 | 45 | 7 | 13 | 84
Mean (SD) | 2.2 (0.3) | 2.0 (0.3) | 2.0 (0.2) | 2.0 (0.2) | 2.1 (0.3)
95% CI | 2.1, 2.4 | 1.9, 2.1 | 1.7, 2.2 | 1.9, 2.1 | 2.0, 2.1
Median | 2.2 | 2.1 | 1.9 | 2.0 | 2.1
Min, Max | 1.6, 2.7 | 1.4, 2.7 | 1.6, 2.4 | 1.7, 2.3 | 1.4, 2.7
Days15_21
N | 16 | 31 | 4 | 5 | 56
Mean (SD) | 2.2 (0.2) | 2.1 (0.3) | 2.2 (0.1) | 1.9 (0.2) | 2.1 (0.3)
95% CI | 2.1, 2.3 | 2.0, 2.2 | 2.0, 2.4 | 1.6, 2.2 | 2.0, 2.2
Median | 2.2 | 2.1 | 2.2 | 1.9 | 2.1
Min, Max | 1.8, 2.5 | 1.4, 2.8 | 2.1, 2.4 | 1.5, 2.1 | 1.4, 2.8
Days22_28
N | 10 | 19 | 4 | 2 | 35
Mean (SD) | 2.1 (0.2) | 2.1 (0.3) | 2.0 (0.3) | 2.1 (0.1) | 2.1 (0.3)
95% CI | 1.9, 2.2 | 1.9, 2.2 | 1.5, 2.5 | 1.4, 2.7 | 2.0, 2.1
Median | 2.1 | 2.1 | 2.2 | 2.1 | 2.1
Min, Max | 1.8, 2.4 | 1.5, 2.7 | 1.5, 2.2 | 2.0, 2.1 | 1.5, 2.7

Summary of Blood Chemistry by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Total Protein (g/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 3 | 26 | 8 | 14 | 51
Mean (SD) | 4.7 (0.9) | 4.2 (0.8) | 4.2 (1.0) | 4.7 (0.6) | 4.4 (0.8)
95% CI | 2.4, 7.0 | 3.9, 4.5 | 3.4, 5.0 | 4.3, 5.0 | 4.2, 4.6
Median | 4.3 | 4.1 | 3.9 | 4.7 | 4.2
Min, Max | 4.1, 5.8 | 3.0, 6.5 | 3.1, 6.0 | 3.3, 5.7 | 3.0, 6.5
Days1_7
N | 10 | 33 | 9 | 12 | 64
Mean (SD) | 3.9 (0.4) | 4.3 (1.0) | 4.4 (0.8) | 4.7 (0.9) | 4.3 (0.9)
95% CI | 3.5, 4.2 | 4.0, 4.7 | 3.8, 5.0 | 4.1, 5.2 | 4.1, 4.5
Median | 3.9 | 4.2 | 4.5 | 4.8 | 4.2
Min, Max | 3.0, 4.5 | 2.8, 7.2 | 3.0, 5.5 | 3.3, 6.1 | 2.8, 7.2
Days8_14
N | 10 | 31 | 9 | 8 | 58
Mean (SD) | 3.9 (0.3) | 4.4 (1.1) | 4.6 (0.7) | 4.7 (0.9) | 4.4 (0.9)
95% CI | 3.7, 4.1 | 4.0, 4.8 | 4.1, 5.1 | 3.9, 5.5 | 4.2, 4.6
Median | 3.8 | 4.3 | 4.4 | 4.5 | 4.3
Min, Max | 3.6, 4.5 | 3.1, 7.8 | 3.8, 5.7 | 3.8, 6.5 | 3.1, 7.8
Days15_21
N | 10 | 22 | 5 | 7 | 44
Mean (SD) | 4.1 (0.4) | 4.4 (1.1) | 4.5 (0.6) | 5.0 (0.8) | 4.5 (0.9)
95% CI | 3.8, 4.4 | 4.0, 4.9 | 3.7, 5.3 | 4.3, 5.7 | 4.2, 4.7
Median | 4.0 | 4.3 | 4.7 | 4.9 | 4.4
Min, Max | 3.7, 4.7 | 2.8, 7.9 | 3.4, 5.0 | 4.1, 5.9 | 2.8, 7.9
Days22_28
N | 7 | 14 | 1 | 2 | 24
Mean (SD) | 4.2 (0.4) | 5.1 (1.3) | 5.0 | 4.9 (1.7) | 4.8 (1.1)
95% CI | 3.8, 4.6 | 4.3, 5.8 | | −10.3, 20.1 | 4.3, 5.3
Median | 4.1 | 4.7 | 5.0 | 4.9 | 4.5
Min, Max | 3.7, 5.0 | 3.4, 8.0 | 5.0, 5.0 | 3.7, 6.1 | 3.4, 8.0

Summary of Blood Chemistry by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Albumin (g/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 9 | 43 | 11 | 17 | 80
Mean (SD) | 2.4 (0.6) | 2.4 (0.7) | 2.0 (0.6) | 2.5 (0.6) | 2.4 (0.6)
95% CI | 2.0, 2.9 | 2.2, 2.6 | 1.6, 2.4 | 2.2, 2.8 | 2.2, 2.5
Median | 2.4 | 2.4 | 1.9 | 2.3 | 2.3
Min, Max | 1.4, 3.5 | 1.4, 3.8 | 1.0, 2.9 | 1.5, 3.8 | 1.0, 3.8
Days1_7
N | 16 | 47 | 10 | 14 | 87
Mean (SD) | 2.1 (0.5) | 2.4 (0.7) | 2.2 (0.5) | 2.7 (0.8) | 2.3 (0.7)
95% CI | 1.9, 2.4 | 2.2, 2.6 | 1.8, 2.5 | 2.2, 3.2 | 2.2, 2.5
Median | 2.2 | 2.3 | 2.2 | 2.6 | 2.3
Min, Max | 1.3, 2.9 | 1.2, 3.8 | 1.4, 3.0 | 1.3, 4.5 | 1.2, 4.5
Days8_14
N | 10 | 37 | 10 | 8 | 65
Mean (SD) | 2.3 (0.5) | 2.4 (0.5) | 2.4 (0.4) | 2.8 (0.7) | 2.4 (0.5)
95% CI | 1.9, 2.6 | 2.2, 2.5 | 2.1, 2.6 | 2.2, 3.3 | 2.3, 2.5
Median | 2.4 | 2.3 | 2.3 | 2.5 | 2.3
Min, Max | 1.6, 2.9 | 1.4, 3.4 | 1.8, 3.0 | 1.9, 3.7 | 1.4, 3.7
Days15_21
N | 12 | 29 | 5 | 7 | 53
Mean (SD) | 2.5 (0.5) | 2.5 (0.6) | 2.4 (0.3) | 3.2 (1.0) | 2.6 (0.6)
95% CI | 2.2, 2.8 | 2.3, 2.8 | 2.0, 2.8 | 2.3, 4.1 | 2.4, 2.8
Median | 2.7 | 2.5 | 2.5 | 2.8 | 2.5
Min, Max | 1.6, 3.5 | 1.7, 3.9 | 2.0, 2.7 | 2.0, 4.9 | 1.6, 4.9
Days22_28
N | 9 | 15 | 1 | 2 | 27
Mean (SD) | 2.7 (0.4) | 2.8 (0.6) | 3.1 | 2.5 (0.8) | 2.8 (0.5)
95% CI | 2.4, 3.0 | 2.5, 3.2 | | −4.5, 9.4 | 2.6, 3.0
Median | 2.7 | 2.8 | 3.1 | 2.5 | 2.8
Min, Max | 2.2, 3.3 | 2.0, 3.9 | 3.1, 3.1 | 1.9, 3.0 | 1.9, 3.9

Table 14.3.4.2

Summary of Change of Blood Chemistry from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Glucose (mg/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 32 | 89 | 24 | 17 | 162
Mean (SD) | 9.3 (68.0) | −6.0 (39.0) | −11.2 (33.1) | 0.3 (38.8) | −3.1 (45.5)
95% CI | −15.2, 33.8 | −14.2, 2.2 | −25.2, 2.7 | −19.7, 20.3 | −10.1, 4.0
Median | 0.5 | 1.0 | 0.5 | 3.0 | 1.0
Min, Max | −116.0, 234.0 | −113.0, 82.0 | −93.0, 36.0 | −103.0, 88.0 | −116.0, 234.0
Days8_14
N | 29 | 66 | 15 | 14 | 124
Mean (SD) | −9.0 (44.4) | −10.7 (42.3) | −21.4 (33.4) | −9.7 (19.1) | −11.5 (39.6)
95% CI | −25.8, 7.9 | −21.1, −0.3 | −39.9, −2.9 | −20.7, 1.3 | −18.5, −4.4
Median | −16.0 | −9.0 | −9.0 | −3.0 | −9.0
Min, Max | −78.0, 94.0 | −131.0, 158.0 | −84.0, 14.0 | −58.0, 8.0 | −131.0, 158.0
Days15_21
N | 22 | 42 | 9 | 7 | 80
Mean (SD) | −13.2 (50.7) | −13.0 (45.3) | −18.2 (35.8) | 0.1 (25.0) | −12.5 (44.1)
95% CI | −35.7, 9.2 | −27.1, 1.1 | −45.8, 9.3 | −23.0, 23.2 | −22.3, −2.7
Median | −9.5 | −10.0 | −11.0 | −2.0 | −9.5
Min, Max | −113.0, 82.0 | −167.0, 64.0 | −88.0, 17.0 | −37.0, 38.0 | −167.0, 82.0
Days22_28
N | 14 | 28 | 4 | 4 | 50
Mean (SD) | −24.9 (51.0) | −14.7 (36.6) | −8.3 (23.0) | −12.3 (12.5) | −16.8 (38.7)
95% CI | −54.4, 4.5 | −28.9, −0.5 | −44.8, 28.3 | −32.1, 7.6 | −27.8, −5.8
Median | −18.5 | −9.5 | −1.0 | −8.0 | −9.5
Min, Max | −133.0, 52.0 | −111.0, 38.0 | −41.0, 10.0 | −30.0, −3.0 | −133.0, 52.0

Change from baseline is the follow-up value minus the baseline value.

Summary of Change of Blood Chemistry from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Creatinine (mg/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 33 | 87 | 23 | 19 | 162
Mean (SD) | −0.1 (0.2) | 0.0 (0.3) | −0.2 (0.2) | −0.1 (0.1) | −0.1 (0.3)
95% CI | −0.2, 0.0 | −0.1, 0.0 | −0.3, −0.1 | −0.1, 0.0 | −0.1, 0.0
Median | −0.1 | 0.0 | −0.1 | 0.0 | −0.1
Min, Max | −0.7, 0.4 | −1.3, 1.3 | −0.8, 0.1 | −0.4, 0.1 | −1.3, 1.3
Days8_14
N | 28 | 63 | 14 | 15 | 120
Mean (SD) | −0.2 (0.3) | −0.1 (0.3) | −0.2 (0.1) | 0.0 (0.1) | −0.1 (0.3)
95% CI | −0.3, 0.0 | −0.2, 0.0 | −0.3, −0.2 | −0.1, 0.0 | −0.2, −0.1
Median | −0.2 | −0.1 | −0.2 | 0.0 | −0.1
Min, Max | −0.7, 0.7 | −1.1, 1.7 | −0.5, −0.1 | −0.2, 0.1 | −1.1, 1.7
Days15_21
N | 20 | 41 | 9 | 8 | 78
Mean (SD) | −0.2 (0.4) | −0.1 (0.4) | −0.2 (0.2) | −0.1 (0.1) | −0.2 (0.4)
95% CI | −0.4, −0.1 | −0.3, 0.0 | −0.4, −0.1 | −0.2, 0.0 | −0.2, −0.1
Median | −0.3 | −0.1 | −0.2 | 0.0 | −0.2
Min, Max | −0.6, 0.8 | −1.3, 2.0 | −0.5, 0.1 | −0.4, 0.0 | −1.3, 2.0
Days22_28
N | 14 | 28 | 4 | 4 | 50
Mean (SD) | −0.3 (0.3) | −0.1 (0.5) | −0.2 (0.1) | −0.2 (0.2) | −0.2 (0.4)
95% CI | −0.5, −0.1 | −0.3, 0.1 | −0.4, 0.0 | −0.6, 0.2 | −0.3, −0.1
Median | −0.3 | −0.2 | −0.2 | −0.1 | −0.2
Min, Max | −0.7, 0.1 | −1.5, 1.1 | −0.4, −0.1 | −0.5, 0.0 | −1.5, 1.1

Change from baseline is the follow-up value minus the baseline value.

Summary of Change of Blood Chemistry from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: BUN (mg/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 33 | 88 | 22 | 19 | 162
Mean (SD) | −9.0 (12.4) | −0.2 (14.2) | 0.0 (8.3) | −2.3 (10.2) | −2.2 (13.1)
95% CI | −13.4, −4.6 | −3.2, 2.8 | −3.7, 3.7 | −7.2, 2.6 | −4.3, −0.2
Median | −7.0 | 0.5 | 1.0 | −2.0 | −1.0
Min, Max | −42.0, 28.0 | −74.0, 45.0 | −28.0, 18.0 | −33.0, 13.0 | −74.0, 45.0
Days8_14
N | 28 | 63 | 13 | 16 | 120
Mean (SD) | −6.3 (19.7) | −2.9 (17.1) | −3.4 (11.0) | −2.4 (13.2) | −3.7 (16.6)
95% CI | −13.9, 1.4 | −7.2, 1.4 | −10.1, 3.3 | −9.5, 4.6 | −6.7, −0.7
Median | −8.5 | −1.0 | 2.0 | 1.0 | −1.0
Min, Max | −43.0, 51.0 | −78.0, 49.0 | −31.0, 9.0 | −48.0, 7.0 | −78.0, 51.0
Days15_21
N | 20 | 42 | 9 | 9 | 80
Mean (SD) | −7.5 (21.3) | −3.1 (19.3) | −1.2 (13.3) | −1.4 (6.9) | −3.8 (18.2)
95% CI | −17.5, 2.5 | −9.1, 2.9 | −11.5, 9.0 | −6.8, 3.9 | −7.8, 0.3
Median | −8.0 | −1.0 | 4.0 | 0.0 | −1.0
Min, Max | −50.0, 34.0 | −78.0, 62.0 | −22.0, 15.0 | −13.0, 6.0 | −78.0, 62.0
Days22_28
N | 14 | 28 | 4 | 5 | 51
Mean (SD) | −11.1 (17.2) | −2.5 (21.0) | 2.0 (11.0) | 0.4 (8.3) | −4.2 (18.7)
95% CI | −21.1, −1.2 | −10.6, 5.7 | −15.5, 19.5 | −9.9, 10.7 | −9.5, 1.0
Median | −13.5 | −3.0 | −1.5 | 1.0 | −4.0
Min, Max | −52.0, 22.0 | −69.0, 75.0 | −7.0, 18.0 | −9.0, 12.0 | −69.0, 75.0

Change from baseline is the follow-up value minus the baseline value.

Summary of Change of Blood Chemistry from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: AST (U/L)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 1 | 21 | 4 | 10 | 36
Mean (SD) | 2.0 | 20.4 (74.0) | −871.3 (1631.2) | −6.2 (47.1) | −86.6 (557.7)
95% CI | | −13.3, 54.0 | −3467, 1724.4 | −39.9, 27.5 | −275.3, 102.1
Median | 2.0 | 4.0 | −85.0 | 5.5 | 3.0
Min, Max | 2.0, 2.0 | −82.0, 318.0 | −3317, 2.0 | −92.0, 45.0 | −3317, 318.0
Days8_14
N | 1 | 18 | 3 | 7 | 29
Mean (SD) | −1.0 | 12.8 (50.9) | −44.0 (72.9) | 1.6 (69.9) | 3.7 (57.4)
95% CI | | −12.6, 38.1 | −225.0, 137.0 | −63.0, 66.2 | −18.1, 25.6
Median | −1.0 | 7.0 | −6.0 | 3.0 | 2.0
Min, Max | −1.0, −1.0 | −79.0, 145.0 | −128.0, 2.0 | −97.0, 88.0 | −128.0, 145.0
Days15_21
N | 1 | 12 | 1 | 5 | 19
Mean (SD) | 10.0 | 30.3 (33.7) | −114.0 | 86.4 (201.6) | 36.4 (108.3)
95% CI | | 8.9, 51.8 | | −163.9, 336.7 | −15.8, 88.6
Median | 10.0 | 21.5 | −114.0 | 19.0 | 19.0
Min, Max | 10.0, 10.0 | −21.0, 80.0 | −114.0, −114.0 | −69.0, 434.0 | −114.0, 434.0
Days22_28
N | 2 | 6 | 1 | 2 | 11
Mean (SD) | 5.5 (12.0) | 70.8 (129.6) | −102.0 | 300.0 (502.0) | 84.9 (218.5)
95% CI | −102.5, 113.5 | −65.2, 206.8 | | −4211, 4810.7 | −61.9, 231.7
Median | 5.5 | 19.5 | −102.0 | 300.0 | 9.0
Min, Max | −3.0, 14.0 | −65.0, 255.0 | −102.0, −102.0 | −55.0, 655.0 | −102.0, 655.0

Change from baseline is the follow-up value minus the baseline value.

Summary of Change of Blood Chemistry from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: ALT (U/L)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 1 | 21 | 4 | 11 | 37
Mean (SD) | 5.0 | 5.2 (25.3) | −210.0 (418.1) | 6.5 (26.4) | −17.6 (140.4)
95% CI | | −6.3, 16.7 | −875.3, 455.3 | −11.2, 24.3 | −64.5, 29.2
Median | 5.0 | 0.0 | −6.0 | 3.0 | 0.0
Min, Max | 5.0, 5.0 | −26.0, 95.0 | −837.0, 9.0 | −35.0, 49.0 | −837.0, 95.0
Days8_14
N | 1 | 18 | 3 | 7 | 29
Mean (SD) | 7.0 | 10.1 (33.6) | −29.3 (72.6) | 7.9 (31.1) | 5.3 (37.6)
95% CI | | −6.7, 26.8 | −209.7, 151.0 | −20.9, 36.6 | −9.0, 19.7
Median | 7.0 | 2.0 | 0.0 | −2.0 | 1.0
Min, Max | 7.0, 7.0 | −20.0, 118.0 | −112.0, 24.0 | −33.0, 56.0 | −112.0, 118.0
Days15_21
N | 1 | 12 | 1 | 5 | 19
Mean (SD) | 18.0 | 2.8 (9.4) | −114.0 | 110.0 (208.1) | 25.6 (114.4)
95% CI | | −3.2, 8.7 | | −148.4, 368.4 | −29.5, 80.8
Median | 18.0 | 1.5 | −114.0 | 31.0 | 3.0
Min, Max | 18.0, 18.0 | −11.0, 20.0 | −114.0, −114.0 | −26.0, 472.0 | −114.0, 472.0
Days22_28
N | 2 | 6 | 1 | 1 | 10
Mean (SD) | 11.5 (10.6) | 26.8 (42.5) | −105.0 | −23.0 | 5.6 (52.7)
95% CI | −83.8, 106.8 | −17.8, 71.5 | | | −32.1, 43.3
Median | 11.5 | 6.5 | −105.0 | −23.0 | 3.5
Min, Max | 4.0, 19.0 | −5.0, 101.0 | −105.0, −105.0 | −23.0, −23.0 | −105.0, 101.0

Change from baseline is the follow-up value minus the baseline value.

Summary of Change of Blood Chemistry from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Alkaline Phosphatase (U/L)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 2 | 27 | 4 | 9 | 42
Mean (SD) | −515.0 (642.1) | 11.3 (188.7) | 49.3 (30.4) | −1.4 (126.3) | −12.9 (221.2)
95% CI | −6284, 5253.6 | −63.3, 86.0 | 0.9, 97.6 | −98.5, 95.6 | −81.8, 56.1
Median | −515.0 | 0.0 | 56.0 | 0.0 | 2.0
Min, Max | −969.0, −61.0 | −546.0, 470.0 | 7.0, 78.0 | −192.0, 243.0 | −969.0, 470.0
Days8_14
N | 1 | 18 | 3 | 5 | 27
Mean (SD) | −76.0 | 70.6 (200.2) | 89.3 (63.6) | 86.8 (192.8) | 70.2 (182.0)
95% CI | | −29.0, 170.1 | −68.6, 247.3 | −152.5, 326.1 | −1.8, 142.2
Median | −76.0 | 76.5 | 62.0 | 6.0 | 62.0
Min, Max | −76.0, −76.0 | −491.0, 423.0 | 44.0, 162.0 | −79.0, 411.0 | −491.0, 423.0
Days15_21
N | 2 | 12 | 1 | 4 | 19
Mean (SD) | −597.5 (727.6) | 316.3 (423.1) | 73.0 | 343.5 (173.3) | 213.1 (478.3)
95% CI | −7135, 5939.8 | 47.5, 585.2 | | 67.7, 619.3 | −17.5, 443.6
Median | −597.5 | 186.5 | 73.0 | 338.5 | 171.0
Min, Max | −1112, −83.0 | −204.0, 1385.0 | 73.0, 73.0 | 151.0, 546.0 | −1112, 1385.0
Days22_28
N | 2 | 7 | 1 | 1 | 11
Mean (SD) | −22.5 (16.3) | 324.9 (353.3) | 102.0 | 296.0 | 238.8 (309.8)
95% CI | −168.6, 123.6 | −1.9, 651.6 | | | 30.7, 446.9
Median | −22.5 | 191.0 | 102.0 | 296.0 | 190.0
Min, Max | −34.0, −11.0 | −45.0, 1066.0 | 102.0, 102.0 | 296.0, 296.0 | −45.0, 1066.0

Change from baseline is the follow-up value minus the baseline value.

Summary of Change of Blood Chemistry from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Total Bilirubin (mg/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 21 | 28 | 12 | 12 | 73
Mean (SD) | −0.1 (2.1) | −0.1 (1.8) | −2.0 (2.8) | −0.3 (1.2) | −0.5 (2.1)
95% CI | −1.1, 0.8 | −0.8, 0.6 | −3.8, −0.2 | −1.1, 0.4 | −0.9, 0.0
Median | −0.4 | 0.1 | −1.6 | 0.0 | 0.0
Min, Max | −3.3, 6.3 | −4.4, 5.5 | −6.8, 3.0 | −3.2, 1.2 | −6.8, 6.3
Days8_14
N | 9 | 24 | 8 | 8 | 49
Mean (SD) | −1.5 (2.4) | −0.4 (2.9) | −4.8 (3.8) | −0.8 (2.5) | −1.4 (3.2)
95% CI | −3.3, 0.4 | −1.6, 0.8 | −8.0, −1.5 | −2.8, 1.3 | −2.3, −0.4
Median | −1.5 | −0.1 | −3.8 | −0.2 | −0.5
Min, Max | −5.2, 3.4 | −10.6, 4.4 | −11.5, −0.8 | −6.5, 1.5 | −11.5, 4.4
Days15_21
N | 10 | 12 | 4 | 6 | 32
Mean (SD) | −1.3 (2.3) | 0.0 (1.4) | −4.1 (2.3) | −1.9 (3.3) | −1.3 (2.5)
95% CI | −2.9, 0.4 | −0.9, 0.9 | −7.8, −0.4 | −5.3, 1.5 | −2.2, −0.4
Median | −1.2 | 0.3 | −4.2 | −1.9 | −1.2
Min, Max | −4.7, 1.6 | −2.4, 2.2 | −6.5, −1.5 | −6.6, 2.5 | −6.6, 2.5
Days22_28
N | 6 | 9 | 3 | 2 | 20
Mean (SD) | −1.3 (2.8) | 0.0 (3.7) | −0.6 (2.5) | −4.5 (3.3) | −0.9 (3.3)
95% CI | −4.3, 1.7 | −2.8, 2.8 | −6.7, 5.5 | −33.7, 24.7 | −2.4, 0.6
Median | −1.3 | 0.4 | −1.4 | −4.5 | −1.2
Min, Max | −5.5, 2.7 | −7.8, 4.2 | −2.5, 2.2 | −6.8, −2.2 | −7.8, 4.2

Change from baseline is the follow-up value minus the baseline value.

Summary of Change of Blood Chemistry from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Direct Bilirubin (mg/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 11 | 17 | 4 | 6 | 38
Mean (SD) | 0.7 (1.4) | −0.2 (1.0) | 0.5 (0.5) | −0.3 (1.2) | 0.1 (1.2)
95% CI | −0.3, 1.7 | −0.8, 0.3 | −0.3, 1.2 | −1.6, 1.0 | −0.3, 0.5
Median | 0.1 | 0.0 | 0.4 | 0.1 | 0.1
Min, Max | −1.1, 3.7 | −2.9, 1.4 | 0.0, 1.1 | −2.2, 1.0 | −2.9, 3.7
Days8_14
N | 4 | 15 | 2 | 3 | 24
Mean (SD) | 0.1 (0.9) | −0.3 (2.3) | 0.7 (0.9) | 0.2 (0.2) | −0.1 (1.9)
95% CI | −1.3, 1.5 | −1.6, 1.0 | −7.6, 8.9 | −0.3, 0.8 | −0.9, 0.7
Median | 0.3 | −0.1 | 0.7 | 0.3 | 0.2
Min, Max | −1.1, 0.9 | −6.7, 3.3 | 0.0, 1.3 | 0.0, 0.4 | −6.7, 3.3
Days15_21
N | 6 | 6 | 0 | 3 | 15
Mean (SD) | 1.1 (1.2) | 0.2 (0.7) | | 0.9 (1.9) | 0.7 (1.2)
95% CI | −0.1, 2.3 | −0.6, 1.0 | | −3.7, 5.5 | 0.1, 1.3
Median | 1.6 | 0.2 | | 1.8 | 0.8
Min, Max | −1.1, 2.1 | −0.7, 1.5 | | −1.2, 2.2 | −1.2, 2.2
Days22_28
N | 3 | 3 | 0 | 0 | 6
Mean (SD) | 1.6 (1.4) | −0.1 (3.6) | | | 0.8 (2.6)
95% CI | −1.9, 5.1 | −9.0, 8.9 | | | −2.0, 3.5
Median | 1.1 | 1.5 | | | 1.3
Min, Max | 0.5, 3.2 | −4.2, 2.5 | | | −4.2, 3.2

Change from baseline is the follow-up value minus the baseline value.

Summary of Change of Blood Chemistry from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Sodium (mmol/L)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 38 | 93 | 25 | 23 | 179
Mean (SD) | −3.8 (7.5) | 1.5 (5.5) | 0.8 (4.6) | 0.5 (2.7) | 0.2 (6.0)
95% CI | −6.3, −1.3 | 0.4, 2.7 | −1.1, 2.7 | −0.7, 1.7 | −0.7, 1.1
Median | −3.0 | 1.0 | 0.0 | 1.0 | 0.0
Min, Max | −22.0, 10.0 | −13.0, 24.0 | −6.0, 13.0 | −4.0, 5.0 | −22.0, 24.0
Days8_14
N | 31 | 70 | 16 | 19 | 136
Mean (SD) | −1.4 (8.4) | 2.2 (6.6) | 0.6 (4.1) | 0.2 (3.3) | 0.9 (6.6)
95% CI | −4.4, 1.7 | 0.6, 3.7 | −1.6, 2.8 | −1.4, 1.7 | −0.2, 2.0
Median | 0.0 | 2.0 | −0.5 | 0.0 | 1.0
Min, Max | −19.0, 16.0 | −15.0, 21.0 | −7.0, 9.0 | −6.0, 5.0 | −19.0, 21.0
Days15_21
N | 24 | 47 | 8 | 10 | 89
Mean (SD) | −2.8 (9.3) | 2.4 (4.9) | 1.1 (3.9) | −0.4 (3.2) | 0.6 (6.5)
95% CI | −6.7, 1.1 | 1.0, 3.8 | −2.1, 4.4 | −2.7, 1.9 | −0.8, 1.9
Median | −1.5 | 3.0 | 0.5 | 0.0 | 1.0
Min, Max | −21.0, 19.0 | −8.0, 17.0 | −3.0, 7.0 | −5.0, 5.0 | −21.0, 19.0
Days22_28
N | 17 | 30 | 4 | 5 | 56
Mean (SD) | −3.1 (8.1) | 3.2 (5.8) | −4.3 (4.0) | 0.8 (2.3) | 0.5 (6.9)
95% CI | −7.2, 1.1 | 1.0, 5.3 | −10.7, 2.2 | −2.0, 3.6 | −1.3, 2.4
Median | −2.0 | 3.0 | −4.0 | 0.0 | 1.5
Min, Max | −17.0, 11.0 | −8.0, 17.0 | −9.0, 0.0 | −2.0, 4.0 | −17.0, 17.0

Change from baseline is the follow-up value minus the baseline value.

Summary of Change of Blood Chemistry from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Potassium (mmol/L)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 38 | 95 | 25 | 23 | 181
Mean (SD) | 0.5 (1.2) | 0.2 (1.1) | 0.2 (1.0) | 0.4 (0.8) | 0.3 (1.1)
95% CI | 0.1, 0.9 | 0.0, 0.4 | −0.2, 0.6 | 0.0, 0.8 | 0.1, 0.4
Median | 0.3 | 0.1 | 0.0 | 0.4 | 0.3
Min, Max | −2.6, 2.6 | −2.5, 3.2 | −2.0, 2.6 | −0.9, 2.2 | −2.6, 3.2
Days8_14
N | 31 | 70 | 16 | 19 | 136
Mean (SD) | 0.8 (1.6) | 0.4 (1.2) | 0.5 (0.9) | 0.6 (1.0) | 0.5 (1.2)
95% CI | 0.2, 1.4 | 0.1, 0.7 | 0.0, 1.0 | 0.1, 1.1 | 0.3, 0.8
Median | 0.8 | 0.3 | 0.6 | 0.6 | 0.5
Min, Max | −2.1, 4.1 | −2.2, 3.2 | −0.9, 2.4 | −1.2, 2.5 | −2.2, 4.1
Days15_21
N | 24 | 48 | 8 | 10 | 90
Mean (SD) | 0.2 (1.2) | 0.3 (1.2) | 0.7 (0.4) | 0.7 (1.2) | 0.3 (1.2)
95% CI | −0.4, 0.7 | −0.1, 0.6 | 0.4, 1.1 | −0.1, 1.5 | 0.1, 0.6
Median | 0.3 | 0.4 | 0.8 | 0.8 | 0.5
Min, Max | −2.6, 2.3 | −2.4, 4.0 | 0.1, 1.2 | −1.9, 2.2 | −2.6, 4.0
Days22_28
N | 16 | 30 | 4 | 6 | 56
Mean (SD) | 0.2 (1.4) | 0.5 (1.3) | 0.8 (0.7) | 0.7 (1.0) | 0.4 (1.2)
95% CI | −0.5, 0.9 | 0.0, 1.0 | −0.4, 1.9 | −0.3, 1.7 | 0.1, 0.8
Median | 0.5 | 0.2 | 1.0 | 0.5 | 0.4
Min, Max | −2.6, 2.4 | −2.4, 2.8 | −0.3, 1.3 | −0.5, 2.3 | −2.6, 2.8

Change from baseline is the follow-up value minus the baseline value.

Summary of Change of Blood Chemistry from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Chloride (mmol/L)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 35 | 88 | 25 | 23 | 171
Mean (SD) | −4.7 (8.9) | 0.8 (6.2) | −0.8 (3.5) | 0.8 (4.7) | −0.6 (6.7)
95% CI | −7.8, −1.7 | −0.5, 2.1 | −2.3, 0.6 | −1.2, 2.8 | −1.6, 0.4
Median | −5.0 | 1.0 | −1.0 | 0.0 | 0.0
Min, Max | −21.0, 18.0 | −14.0, 18.0 | −8.0, 5.0 | −6.0, 8.0 | −21.0, 18.0
Days8_14
N | 29 | 67 | 16 | 19 | 131
Mean (SD) | −1.8 (8.5) | 2.0 (7.1) | −2.1 (3.7) | 1.6 (5.8) | 0.6 (7.1)
95% CI | −5.1, 1.4 | 0.3, 3.7 | −4.0, −0.1 | −1.2, 4.4 | −0.6, 1.8
Median | 0.0 | 2.0 | −2.0 | 3.0 | 2.0
Min, Max | −21.0, 9.0 | −23.0, 17.0 | −9.0, 4.0 | −15.0, 13.0 | −23.0, 17.0
Days15_21
N | 22 | 45 | 8 | 10 | 85
Mean (SD) | −3.6 (10.3) | 1.1 (6.3) | 1.8 (4.2) | 0.3 (4.0) | −0.2 (7.4)
95% CI | −8.2, 0.9 | −0.8, 3.0 | −1.8, 5.3 | −2.5, 3.1 | −1.8, 1.4
Median | −2.0 | 0.0 | 1.5 | 1.0 | 0.0
Min, Max | −24.0, 16.0 | −14.0, 21.0 | −3.0, 9.0 | −6.0, 7.0 | −24.0, 21.0
Days22_28
N | 15 | 29 | 4 | 6 | 54
Mean (SD) | −3.1 (8.7) | 2.1 (8.3) | −4.3 (5.9) | 1.8 (3.5) | 0.2 (8.1)
95% CI | −7.9, 1.7 | −1.1, 5.3 | −13.6, 5.1 | −1.9, 5.6 | −2.1, 2.4
Median | −2.0 | 1.0 | −4.0 | 1.5 | 1.0
Min, Max | −18.0, 11.0 | −14.0, 21.0 | −11.0, 2.0 | −4.0, 6.0 | −18.0, 21.0

Change from baseline is the follow-up value minus the baseline value.

Summary of Change of Blood Chemistry from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Calcium (mg/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 31 | 85 | 23 | 22 | 161
Mean (SD) | 0.6 (1.2) | 0.1 (0.8) | 0.7 (1.0) | 0.1 (0.8) | 0.3 (0.9)
95% CI | 0.2, 1.0 | −0.1, 0.3 | 0.3, 1.1 | −0.2, 0.5 | 0.1, 0.4
Median | 0.5 | 0.0 | 0.6 | 0.1 | 0.2
Min, Max | −1.4, 3.1 | −1.7, 2.5 | −1.0, 2.8 | −2.1, 1.9 | −2.1, 3.1
Days8_14
N | 27 | 62 | 12 | 18 | 119
Mean (SD) | 0.8 (1.0) | 0.0 (1.3) | 1.0 (0.9) | 0.2 (0.6) | 0.3 (1.2)
95% CI | 0.4, 1.2 | −0.4, 0.3 | 0.5, 1.5 | −0.1, 0.5 | 0.1, 0.5
Median | 0.8 | 0.0 | 0.7 | 0.3 | 0.3
Min, Max | −1.3, 2.9 | −8.3, 2.9 | 0.2, 2.8 | −0.7, 1.5 | −8.3, 2.9
Days15_21
N | 19 | 43 | 8 | 9 | 79
Mean (SD) | 1.2 (1.3) | 0.3 (0.9) | 1.1 (1.5) | 0.5 (0.5) | 0.6 (1.1)
95% CI | 0.5, 1.8 | 0.1, 0.6 | −0.1, 2.4 | 0.1, 0.9 | 0.4, 0.9
Median | 0.9 | 0.3 | 1.4 | 0.4 | 0.4
Min, Max | −1.1, 3.3 | −2.3, 3.4 | −1.6, 3.1 | −0.2, 1.3 | −2.3, 3.4
Days22_28
N | 13 | 27 | 4 | 5 | 49
Mean (SD) | 1.2 (1.4) | 0.4 (1.0) | 1.6 (1.1) | 0.7 (0.4) | 0.8 (1.1)
95% CI | 0.4, 2.1 | 0.0, 0.8 | −0.1, 3.3 | 0.2, 1.2 | 0.4, 1.1
Median | 1.1 | 0.5 | 1.8 | 0.6 | 0.6
Min, Max | −0.7, 4.3 | −1.6, 3.2 | 0.2, 2.8 | 0.4, 1.3 | −1.6, 4.3

Change from baseline is the follow-up value minus the baseline value.

Summary of Change of Blood Chemistry from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Magnesium (mg/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 18 | 36 | 8 | 8 | 70
Mean (SD) | −0.1 (0.5) | 0.0 (0.4) | −0.2 (0.4) | −0.1 (0.2) | −0.1 (0.4)
95% CI | −0.3, 0.1 | −0.2, 0.1 | −0.5, 0.1 | −0.3, 0.1 | −0.2, 0.0
Median | −0.3 | 0.0 | −0.2 | −0.1 | −0.1
Min, Max | −0.8, 1.1 | −1.1, 0.8 | −0.8, 0.3 | −0.4, 0.3 | −1.1, 1.1
Days8_14
N | 13 | 29 | 5 | 7 | 54
Mean (SD) | 0.1 (0.5) | 0.0 (0.4) | −0.1 (0.3) | 0.0 (0.1) | 0.0 (0.4)
95% CI | −0.2, 0.5 | −0.2, 0.1 | −0.5, 0.3 | −0.1, 0.1 | −0.1, 0.1
Median | 0.2 | 0.1 | −0.2 | 0.0 | 0.0
Min, Max | −0.8, 1.1 | −1.0, 1.1 | −0.4, 0.3 | −0.2, 0.2 | −1.0, 1.1
Days15_21
N | 11 | 22 | 3 | 4 | 40
Mean (SD) | 0.1 (0.5) | 0.1 (0.4) | −0.1 (0.5) | −0.1 (0.2) | 0.0 (0.4)
95% CI | −0.2, 0.4 | −0.1, 0.3 | −1.3, 1.0 | −0.4, 0.2 | −0.1, 0.2
Median | 0.2 | 0.2 | −0.1 | −0.1 | 0.1
Min, Max | −0.8, 1.0 | −1.1, 0.7 | −0.6, 0.3 | −0.3, 0.1 | −1.1, 1.0
Days22_28
N | 7 | 13 | 3 | 2 | 25
Mean (SD) | 0.0 (0.6) | 0.1 (0.2) | 0.0 (0.7) | 0.2 (0.2) | 0.0 (0.4)
95% CI | −0.5, 0.6 | −0.1, 0.2 | −1.7, 1.6 | −1.8, 2.1 | −0.1, 0.2
Median | 0.2 | 0.1 | 0.3 | 0.2 | 0.1
Min, Max | −0.7, 0.7 | −0.5, 0.4 | −0.8, 0.4 | 0.0, 0.3 | −0.8, 0.7

Change from baseline is the follow-up value minus the baseline value.

Summary of Change of Blood Chemistry from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Total Protein (g/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 0 | 17 | 4 | 10 | 31
Mean (SD) | | 0.0 (0.8) | 0.6 (0.6) | 0.1 (0.7) | 0.1 (0.7)
95% CI | | −0.4, 0.4 | −0.3, 1.5 | −0.4, 0.6 | −0.2, 0.4
Median | | −0.1 | 0.7 | 0.1 | 0.0
Min, Max | | −1.6, 1.3 | −0.1, 1.3 | −1.4, 1.1 | −1.6, 1.3
Days8_14
N | 0 | 16 | 4 | 7 | 27
Mean (SD) | | 0.2 (0.8) | 0.7 (0.5) | 0.3 (1.1) | 0.3 (0.8)
95% CI | | −0.2, 0.7 | −0.2, 1.6 | −0.7, 1.2 | 0.0, 0.6
Median | | 0.5 | 0.8 | 0.0 | 0.3
Min, Max | | −1.5, 1.4 | 0.0, 1.3 | −0.8, 2.3 | −1.5, 2.3
Days15_21
N | 0 | 9 | 1 | 5 | 15
Mean (SD) | | 0.7 (0.6) | 1.1 | 0.8 (0.7) | 0.7 (0.6)
95% CI | | 0.2, 1.2 | | −0.1, 1.6 | 0.4, 1.1
Median | | 0.6 | 1.1 | 0.8 | 0.8
Min, Max | | −0.5, 1.4 | 1.1, 1.1 | 0.1, 1.7 | −0.5, 1.7
Days22_28
N | 1 | 6 | 1 | 2 | 10
Mean (SD) | −0.8 | 0.7 (1.1) | 1.6 | 0.9 (0.6) | 0.7 (1.0)
95% CI | | −0.4, 1.9 | | −4.9, 6.6 | 0.0, 1.4
Median | −0.8 | 0.5 | 1.6 | 0.9 | 0.5
Min, Max | −0.8, −0.8 | −0.5, 2.5 | 1.6, 1.6 | 0.4, 1.3 | −0.8, 2.5

Change from baseline is the follow-up value minus the baseline value.

Summary of Change of Blood Chemistry from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Albumin (g/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 6 | 32 | 5 | 11 | 54
Mean (SD) | 0.0 (0.3) | 0.0 (0.5) | 0.3 (0.2) | 0.1 (0.5) | 0.1 (0.4)
95% CI | −0.3, 0.3 | −0.1, 0.2 | 0.1, 0.6 | −0.2, 0.4 | 0.0, 0.2
Median | −0.1 | 0.0 | 0.3 | 0.1 | 0.0
Min, Max | −0.3, 0.4 | −0.9, 1.1 | 0.1, 0.6 | −0.6, 0.8 | −0.9, 1.1
Days8_14
N | 3 | 24 | 4 | 7 | 38
Mean (SD) | 0.0 (0.7) | 0.3 (0.6) | 0.4 (0.4) | 0.2 (0.8) | 0.2 (0.6)
95% CI | −1.8, 1.8 | 0.0, 0.5 | −0.2, 0.9 | −0.6, 0.9 | 0.1, 0.4
Median | −0.2 | 0.3 | 0.4 | −0.2 | 0.3
Min, Max | −0.6, 0.8 | −1.0, 1.3 | −0.1, 0.8 | −0.5, 1.8 | −1.0, 1.8
Days15_21
N | 3 | 17 | 1 | 6 | 27
Mean (SD) | 0.5 (0.8) | 0.5 (0.6) | 0.7 | 1.0 (1.1) | 0.6 (0.7)
95% CI | −1.4, 2.5 | 0.2, 0.8 | | −0.1, 2.1 | 0.3, 0.9
Median | 0.3 | 0.6 | 0.7 | 0.5 | 0.5
Min, Max | −0.1, 1.4 | −0.6, 1.4 | 0.7, 0.7 | 0.1, 2.9 | −0.6, 2.9
Days22_28
N | 4 | 10 | 1 | 2 | 17
Mean (SD) | 0.2 (0.3) | 0.7 (0.9) | 1.3 | 0.6 (0.2) | 0.6 (0.7)
95% CI | −0.3, 0.6 | 0.0, 1.3 | | −1.4, 2.5 | 0.2, 0.9
Median | 0.2 | 0.8 | 1.3 | 0.6 | 0.4
Min, Max | −0.2, 0.4 | −0.4, 2.4 | 1.3, 1.3 | 0.4, 0.7 | −0.4, 2.4

Change from baseline is the follow-up value minus the baseline value.

Table 14.3.4.3

Summary of Blood Chemistry Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Glucose (mg/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participan | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
WNL | 13 (33.3%) | 66 (64.1%) | 25 (80.6%) | 19 (70.4%) | 123 (61.5%)
ABN-NCS | 20 (51.3%) | 26 (25.2%) | 4 (12.9%) | 2 (7.4%) | 52 (26.0%)
ABN-CS | 2 (5.1%) | 7 (6.8%) | 0 | 0 | 9 (4.5%)
Days1_7
WNL | 20 (51.3%) | 75 (72.8%) | 26 (83.9%) | 16 (59.3%) | 137 (68.5%)
ABN-NCS | 11 (28.2%) | 14 (13.6%) | 0 | 3 (11.1%) | 28 (14.0%)
ABN-CS | 3 (7.7%) | 1 (1.0%) | 0 | 0 | 4 (2.0%)
Days8_14
WNL | 19 (48.7%) | 54 (52.4%) | 14 (45.2%) | 15 (55.6%) | 102 (51.0%)
ABN-NCS | 9 (23.1%) | 11 (10.7%) | 3 (9.7%) | 0 | 23 (11.5%)
ABN-CS | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
Days15_21
WNL | 12 (30.8%) | 37 (35.9%) | 10 (32.3%) | 7 (25.9%) | 66 (33.0%)
ABN-NCS | 10 (25.6%) | 6 (5.8%) | 0 | 2 (7.4%) | 18 (9.0%)
Days22_28
WNL | 10 (25.6%) | 26 (25.2%) | 4 (12.9%) | 4 (14.8%) | 44 (22.0%)
ABN-NCS | 2 (5.1%) | 2 (1.9%) | 0 | 1 (3.7%) | 5 (2.5%)
ABN-CS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Blood Chemistry Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Creatinine (mg/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participan | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
WNL | 15 (38.5%) | 68 (66.0%) | 24 (77.4%) | 21 (77.8%) | 128 (64.0%)
ABN-NCS | 13 (33.3%) | 26 (25.2%) | 4 (12.9%) | 1 (3.7%) | 44 (22.0%)
ABN-CS | 7 (17.9%) | 2 (1.9%) | 1 (3.2%) | 1 (3.7%) | 11 (5.5%)
Days1_7
WNL | 21 (53.8%) | 72 (69.9%) | 22 (71.0%) | 18 (66.7%) | 133 (66.5%)
ABN-NCS | 14 (35.9%) | 16 (15.5%) | 3 (9.7%) | 2 (7.4%) | 35 (17.5%)
ABN-CS | 1 (2.6%) | 3 (2.9%) | 0 | 1 (3.7%) | 5 (2.5%)
Days8_14
WNL | 18 (46.2%) | 50 (48.5%) | 13 (41.9%) | 14 (51.9%) | 95 (47.5%)
ABN-NCS | 10 (25.6%) | 14 (13.6%) | 3 (9.7%) | 3 (11.1%) | 30 (15.0%)
ABN-CS | 2 (5.1%) | 1 (1.0%) | 0 | 0 | 3 (1.5%)
Days15_21
WNL | 15 (38.5%) | 40 (38.8%) | 9 (29.0%) | 9 (33.3%) | 73 (36.5%)
ABN-NCS | 7 (17.9%) | 5 (4.9%) | 1 (3.2%) | 1 (3.7%) | 14 (7.0%)
Days22_28
WNL | 11 (28.2%) | 22 (21.4%) | 3 (9.7%) | 4 (14.8%) | 40 (20.0%)
ABN-NCS | 5 (12.8%) | 7 (6.8%) | 1 (3.2%) | 1 (3.7%) | 14 (7.0%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Blood Chemistry Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: BUN (mg/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participan | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
WNL | 12 (30.8%) | 67 (65.0%) | 24 (77.4%) | 17 (63.0%) | 120 (60.0%)
ABN-NCS | 20 (51.3%) | 28 (27.2%) | 4 (12.9%) | 4 (14.8%) | 56 (28.0%)
ABN-CS | 3 (7.7%) | 2 (1.9%) | 0 | 2 (7.4%) | 7 (3.5%)
Days1_7
WNL | 18 (46.2%) | 64 (62.1%) | 20 (64.5%) | 18 (66.7%) | 120 (60.0%)
ABN-NCS | 16 (41.0%) | 23 (22.3%) | 4 (12.9%) | 2 (7.4%) | 45 (22.5%)
ABN-CS | 0 | 3 (2.9%) | 0 | 1 (3.7%) | 4 (2.0%)
Days8_14
WNL | 18 (46.2%) | 45 (43.7%) | 13 (41.9%) | 16 (59.3%) | 92 (46.0%)
ABN-NCS | 10 (25.6%) | 19 (18.4%) | 2 (6.5%) | 1 (3.7%) | 32 (16.0%)
ABN-CS | 2 (5.1%) | 1 (1.0%) | 0 | 0 | 3 (1.5%)
Days15_21
WNL | 15 (38.5%) | 35 (34.0%) | 8 (25.8%) | 8 (29.6%) | 66 (33.0%)
ABN-NCS | 7 (17.9%) | 9 (8.7%) | 2 (6.5%) | 2 (7.4%) | 20 (10.0%)
ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Days22_28
WNL | 9 (23.1%) | 22 (21.4%) | 3 (9.7%) | 4 (14.8%) | 38 (19.0%)
ABN-NCS | 7 (17.9%) | 7 (6.8%) | 1 (3.2%) | 2 (7.4%) | 17 (8.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Blood Chemistry Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: AST (U/L)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participan | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
WNL | 4 (10.3%) | 21 (20.4%) | 5 (16.1%) | 8 (29.6%) | 38 (19.0%)
ABN-NCS | 2 (5.1%) | 9 (8.7%) | 1 (3.2%) | 7 (25.9%) | 19 (9.5%)
ABN-CS | 0 | 1 (1.0%) | 1 (3.2%) | 1 (3.7%) | 3 (1.5%)
Days1_7
WNL | 11 (28.2%) | 21 (20.4%) | 8 (25.8%) | 7 (25.9%) | 47 (23.5%)
ABN-NCS | 3 (7.7%) | 17 (16.5%) | 2 (6.5%) | 5 (18.5%) | 27 (13.5%)
ABN-CS | 0 | 3 (2.9%) | 0 | 1 (3.7%) | 4 (2.0%)
Days8_14
WNL | 10 (25.6%) | 22 (21.4%) | 9 (29.0%) | 4 (14.8%) | 45 (22.5%)
ABN-NCS | 4 (10.3%) | 10 (9.7%) | 1 (3.2%) | 4 (14.8%) | 19 (9.5%)
ABN-CS | 0 | 4 (3.9%) | 0 | 1 (3.7%) | 5 (2.5%)
Days15_21
WNL | 13 (33.3%) | 13 (12.6%) | 5 (16.1%) | 2 (7.4%) | 33 (16.5%)
ABN-NCS | 3 (7.7%) | 11 (10.7%) | 0 | 4 (14.8%) | 18 (9.0%)
ABN-CS | 0 | 2 (1.9%) | 0 | 2 (7.4%) | 4 (2.0%)
Days22_28
WNL | 8 (20.5%) | 7 (6.8%) | 3 (9.7%) | 1 (3.7%) | 19 (9.5%)
ABN-NCS | 3 (7.7%) | 6 (5.8%) | 0 | 1 (3.7%) | 10 (5.0%)
ABN-CS | 0 | 2 (1.9%) | 0 | 1 (3.7%) | 3 (1.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Blood Chemistry Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: ALT (U/L)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participan | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
WNL | 4 (10.3%) | 23 (22.3%) | 4 (12.9%) | 9 (33.3%) | 40 (20.0%)
ABN-NCS | 2 (5.1%) | 7 (6.8%) | 1 (3.2%) | 6 (22.2%) | 16 (8.0%)
ABN-CS | 0 | 1 (1.0%) | 2 (6.5%) | 1 (3.7%) | 4 (2.0%)
Days1_7
WNL | 13 (33.3%) | 33 (32.0%) | 8 (25.8%) | 7 (25.9%) | 61 (30.5%)
ABN-NCS | 2 (5.1%) | 7 (6.8%) | 2 (6.5%) | 6 (22.2%) | 17 (8.5%)
ABN-CS | 0 | 1 (1.0%) | 0 | 1 (3.7%) | 2 (1.0%)
Days8_14
WNL | 13 (33.3%) | 28 (27.2%) | 10 (32.3%) | 5 (18.5%) | 56 (28.0%)
ABN-NCS | 1 (2.6%) | 6 (5.8%) | 0 | 3 (11.1%) | 10 (5.0%)
ABN-CS | 0 | 3 (2.9%) | 0 | 1 (3.7%) | 4 (2.0%)
Days15_21
WNL | 15 (38.5%) | 16 (15.5%) | 5 (16.1%) | 3 (11.1%) | 39 (19.5%)
ABN-NCS | 1 (2.6%) | 7 (6.8%) | 0 | 3 (11.1%) | 11 (5.5%)
ABN-CS | 0 | 1 (1.0%) | 0 | 2 (7.4%) | 3 (1.5%)
Days22_28
WNL | 9 (23.1%) | 10 (9.7%) | 2 (6.5%) | 1 (3.7%) | 22 (11.0%)
ABN-NCS | 1 (2.6%) | 3 (2.9%) | 1 (3.2%) | 1 (3.7%) | 6 (3.0%)
ABN-CS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Blood Chemistry Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Alkaline Phosphatase (U/L)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participan | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
WNL | 2 (5.1%) | 23 (22.3%) | 4 (12.9%) | 10 (37.0%) | 39 (19.5%)
ABN-NCS | 2 (5.1%) | 7 (6.8%) | 3 (9.7%) | 2 (7.4%) | 14 (7.0%)
ABN-CS | 2 (5.1%) | 8 (7.8%) | 0 | 1 (3.7%) | 11 (5.5%)
Days1_7
WNL | 14 (35.9%) | 31 (30.1%) | 6 (19.4%) | 10 (37.0%) | 61 (30.5%)
ABN-NCS | 1 (2.6%) | 12 (11.7%) | 1 (3.2%) | 2 (7.4%) | 16 (8.0%)
ABN-CS | 1 (2.6%) | 8 (7.8%) | 0 | 0 | 9 (4.5%)
Days8_14
WNL | 8 (20.5%) | 12 (11.7%) | 8 (25.8%) | 7 (25.9%) | 35 (17.5%)
ABN-NCS | 3 (7.7%) | 18 (17.5%) | 0 | 1 (3.7%) | 22 (11.0%)
ABN-CS | 2 (5.1%) | 7 (6.8%) | 0 | 0 | 9 (4.5%)
Days15_21
WNL | 8 (20.5%) | 3 (2.9%) | 3 (9.7%) | 1 (3.7%) | 15 (7.5%)
ABN-NCS | 5 (12.8%) | 18 (17.5%) | 1 (3.2%) | 5 (18.5%) | 29 (14.5%)
ABN-CS | 2 (5.1%) | 5 (4.9%) | 0 | 1 (3.7%) | 8 (4.0%)
Days22_28
WNL | 4 (10.3%) | 3 (2.9%) | 2 (6.5%) | 0 | 9 (4.5%)
ABN-NCS | 2 (5.1%) | 7 (6.8%) | 1 (3.2%) | 2 (7.4%) | 12 (6.0%)
ABN-CS | 2 (5.1%) | 5 (4.9%) | 0 | 0 | 7 (3.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Blood Chemistry Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Total Bilirubin (mg/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participan | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
WNL | 14 (35.9%) | 21 (20.4%) | 12 (38.7%) | 13 (48.1%) | 60 (30.0%)
ABN-NCS | 9 (23.1%) | 14 (13.6%) | 7 (22.6%) | 4 (14.8%) | 34 (17.0%)
ABN-CS | 2 (5.1%) | 8 (7.8%) | 2 (6.5%) | 0 | 12 (6.0%)
Days1_7
WNL | 12 (30.8%) | 25 (24.3%) | 10 (32.3%) | 9 (33.3%) | 56 (28.0%)
ABN-NCS | 13 (33.3%) | 20 (19.4%) | 5 (16.1%) | 4 (14.8%) | 42 (21.0%)
ABN-CS | 3 (7.7%) | 4 (3.9%) | 0 | 3 (11.1%) | 10 (5.0%)
Days8_14
WNL | 8 (20.5%) | 17 (16.5%) | 8 (25.8%) | 8 (29.6%) | 41 (20.5%)
ABN-NCS | 8 (20.5%) | 18 (17.5%) | 3 (9.7%) | 2 (7.4%) | 31 (15.5%)
ABN-CS | 1 (2.6%) | 7 (6.8%) | 0 | 0 | 8 (4.0%)
Days15_21
WNL | 6 (15.4%) | 16 (15.5%) | 3 (9.7%) | 2 (7.4%) | 27 (13.5%)
ABN-NCS | 10 (25.6%) | 8 (7.8%) | 3 (9.7%) | 5 (18.5%) | 26 (13.0%)
ABN-CS | 0 | 3 (2.9%) | 0 | 1 (3.7%) | 4 (2.0%)
Days22_28
WNL | 5 (12.8%) | 6 (5.8%) | 1 (3.2%) | 0 | 12 (6.0%)
ABN-NCS | 4 (10.3%) | 7 (6.8%) | 1 (3.2%) | 2 (7.4%) | 14 (7.0%)
ABN-CS | 1 (2.6%) | 3 (2.9%) | 1 (3.2%) | 1 (3.7%) | 6 (3.0%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Blood Chemistry Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Direct Bilirubin (mg/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participan | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
WNL | 8 (20.5%) | 12 (11.7%) | 9 (29.0%) | 6 (22.2%) | 35 (17.5%)
ABN-NCS | 8 (20.5%) | 8 (7.8%) | 4 (12.9%) | 0 | 20 (10.0%)
ABN-CS | 1 (2.6%) | 12 (11.7%) | 0 | 3 (11.1%) | 16 (8.0%)
Days1_7
WNL | 9 (23.1%) | 9 (8.7%) | 4 (12.9%) | 5 (18.5%) | 27 (13.5%)
ABN-NCS | 9 (23.1%) | 17 (16.5%) | 3 (9.7%) | 0 | 29 (14.5%)
ABN-CS | 2 (5.1%) | 10 (9.7%) | 0 | 4 (14.8%) | 16 (8.0%)
Days8_14
WNL | 3 (7.7%) | 4 (3.9%) | 2 (6.5%) | 2 (7.4%) | 11 (5.5%)
ABN-NCS | 6 (15.4%) | 10 (9.7%) | 3 (9.7%) | 3 (11.1%) | 22 (11.0%)
ABN-CS | 2 (5.1%) | 14 (13.6%) | 0 | 2 (7.4%) | 18 (9.0%)
Days15_21
WNL | 2 (5.1%) | 2 (1.9%) | 3 (9.7%) | 1 (3.7%) | 8 (4.0%)
ABN-NCS | 6 (15.4%) | 8 (7.8%) | 0 | 2 (7.4%) | 16 (8.0%)
ABN-CS | 2 (5.1%) | 6 (5.8%) | 0 | 2 (7.4%) | 10 (5.0%)
Days22_28
WNL | 0 | 0 | 1 (3.2%) | 0 | 1 (0.5%)
ABN-NCS | 2 (5.1%) | 2 (1.9%) | 0 | 1 (3.7%) | 5 (2.5%)
ABN-CS | 3 (7.7%) | 5 (4.9%) | 0 | 0 | 8 (4.0%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Blood Chemistry Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Sodium (mmol/L)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participan | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
WNL | 24 (61.5%) | 77 (74.8%) | 22 (71.0%) | 25 (92.6%) | 148 (74.0%)
ABN-NCS | 10 (25.6%) | 15 (14.6%) | 7 (22.6%) | 1 (3.7%) | 33 (16.5%)
ABN-CS | 5 (12.8%) | 10 (9.7%) | 0 | 0 | 15 (7.5%)
Days1_7
WNL | 24 (61.5%) | 78 (75.7%) | 25 (80.6%) | 20 (74.1%) | 147 (73.5%)
ABN-NCS | 10 (25.6%) | 10 (9.7%) | 2 (6.5%) | 1 (3.7%) | 23 (11.5%)
ABN-CS | 3 (7.7%) | 6 (5.8%) | 0 | 0 | 9 (4.5%)
Days8_14
WNL | 20 (51.3%) | 61 (59.2%) | 17 (54.8%) | 19 (70.4%) | 117 (58.5%)
ABN-NCS | 10 (25.6%) | 7 (6.8%) | 1 (3.2%) | 0 | 18 (9.0%)
ABN-CS | 1 (2.6%) | 3 (2.9%) | 0 | 0 | 4 (2.0%)
Days15_21
WNL | 15 (38.5%) | 43 (41.7%) | 8 (25.8%) | 7 (25.9%) | 73 (36.5%)
ABN-NCS | 8 (20.5%) | 5 (4.9%) | 0 | 2 (7.4%) | 15 (7.5%)
ABN-CS | 1 (2.6%) | 0 | 1 (3.2%) | 0 | 2 (1.0%)
Days22_28
WNL | 8 (20.5%) | 31 (30.1%) | 3 (9.7%) | 4 (14.8%) | 46 (23.0%)
ABN-NCS | 8 (20.5%) | 0 | 1 (3.2%) | 0 | 9 (4.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Blood Chemistry Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Potassium (mmol/L)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participan | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
WNL | 30 (76.9%) | 78 (75.7%) | 21 (67.7%) | 22 (81.5%) | 151 (75.5%)
ABN-NCS | 7 (17.9%) | 20 (19.4%) | 6 (19.4%) | 3 (11.1%) | 36 (18.0%)
ABN-CS | 2 (5.1%) | 5 (4.9%) | 1 (3.2%) | 2 (7.4%) | 10 (5.0%)
Days1_7
WNL | 29 (74.4%) | 72 (69.9%) | 20 (64.5%) | 15 (55.6%) | 136 (68.0%)
ABN-NCS | 7 (17.9%) | 20 (19.4%) | 7 (22.6%) | 6 (22.2%) | 40 (20.0%)
ABN-CS | 1 (2.6%) | 3 (2.9%) | 0 | 0 | 4 (2.0%)
Days8_14
WNL | 21 (53.8%) | 60 (58.3%) | 18 (58.1%) | 15 (55.6%) | 114 (57.0%)
ABN-NCS | 8 (20.5%) | 9 (8.7%) | 0 | 4 (14.8%) | 21 (10.5%)
ABN-CS | 2 (5.1%) | 1 (1.0%) | 0 | 0 | 3 (1.5%)
Days15_21
WNL | 22 (56.4%) | 40 (38.8%) | 9 (29.0%) | 7 (25.9%) | 78 (39.0%)
ABN-NCS | 2 (5.1%) | 7 (6.8%) | 0 | 2 (7.4%) | 11 (5.5%)
ABN-CS | 0 | 1 (1.0%) | 0 | 1 (3.7%) | 2 (1.0%)
Days22_28
WNL | 9 (23.1%) | 21 (20.4%) | 3 (9.7%) | 4 (14.8%) | 37 (18.5%)
ABN-NCS | 7 (17.9%) | 8 (7.8%) | 1 (3.2%) | 1 (3.7%) | 17 (8.5%)
ABN-CS | 0 | 1 (1.0%) | 0 | 1 (3.7%) | 2 (1.0%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Blood Chemistry Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Chloride (mmol/L)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participan | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
WNL | 22 (56.4%) | 75 (72.8%) | 22 (71.0%) | 20 (74.1%) | 139 (69.5%)
ABN-NCS | 10 (25.6%) | 21 (20.4%) | 6 (19.4%) | 5 (18.5%) | 42 (21.0%)
ABN-CS | 4 (10.3%) | 2 (1.9%) | 0 | 1 (3.7%) | 7 (3.5%)
Days1_7
WNL | 21 (53.8%) | 69 (67.0%) | 21 (67.7%) | 18 (66.7%) | 129 (64.5%)
ABN-NCS | 13 (33.3%) | 20 (19.4%) | 5 (16.1%) | 4 (14.8%) | 42 (21.0%)
ABN-CS | 2 (5.1%) | 3 (2.9%) | 1 (3.2%) | 0 | 6 (3.0%)
Days8_14
WNL | 22 (56.4%) | 51 (49.5%) | 15 (48.4%) | 15 (55.6%) | 103 (51.5%)
ABN-NCS | 7 (17.9%) | 19 (18.4%) | 3 (9.7%) | 4 (14.8%) | 33 (16.5%)
ABN-CS | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
Days15_21
WNL | 16 (41.0%) | 34 (33.0%) | 6 (19.4%) | 8 (29.6%) | 64 (32.0%)
ABN-NCS | 6 (15.4%) | 14 (13.6%) | 3 (9.7%) | 2 (7.4%) | 25 (12.5%)
ABN-CS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
Days22_28
WNL | 13 (33.3%) | 23 (22.3%) | 4 (12.9%) | 6 (22.2%) | 46 (23.0%)
ABN-NCS | 3 (7.7%) | 7 (6.8%) | 0 | 0 | 10 (5.0%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Blood Chemistry Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Calcium (mg/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participan | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
WNL | 28 (71.8%) | 82 (79.6%) | 25 (80.6%) | 22 (81.5%) | 157 (78.5%)
ABN-NCS | 6 (15.4%) | 14 (13.6%) | 3 (9.7%) | 2 (7.4%) | 25 (12.5%)
ABN-CS | 0 | 2 (1.9%) | 0 | 1 (3.7%) | 3 (1.5%)
Days1_7
WNL | 30 (76.9%) | 77 (74.8%) | 22 (71.0%) | 18 (66.7%) | 147 (73.5%)
ABN-NCS | 4 (10.3%) | 11 (10.7%) | 2 (6.5%) | 2 (7.4%) | 19 (9.5%)
ABN-CS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
Days8_14
WNL | 24 (61.5%) | 56 (54.4%) | 14 (45.2%) | 18 (66.7%) | 112 (56.0%)
ABN-NCS | 4 (10.3%) | 9 (8.7%) | 1 (3.2%) | 0 | 14 (7.0%)
Days15_21
WNL | 19 (48.7%) | 41 (39.8%) | 9 (29.0%) | 9 (33.3%) | 78 (39.0%)
ABN-NCS | 1 (2.6%) | 4 (3.9%) | 0 | 0 | 5 (2.5%)
Days22_28
WNL | 13 (33.3%) | 25 (24.3%) | 4 (12.9%) | 5 (18.5%) | 47 (23.5%)
ABN-NCS | 1 (2.6%) | 3 (2.9%) | 0 | 0 | 4 (2.0%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Blood Chemistry Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Magnesium (mg/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participan | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
WNL | 13 (33.3%) | 35 (34.0%) | 11 (35.5%) | 11 (40.7%) | 70 (35.0%)
ABN-NCS | 6 (15.4%) | 6 (5.8%) | 2 (6.5%) | 0 | 14 (7.0%)
ABN-CS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
Days1_7
WNL | 21 (53.8%) | 44 (42.7%) | 11 (35.5%) | 13 (48.1%) | 89 (44.5%)
ABN-NCS | 5 (12.8%) | 6 (5.8%) | 1 (3.2%) | 1 (3.7%) | 13 (6.5%)
Days8_14
WNL | 16 (41.0%) | 40 (38.8%) | 7 (22.6%) | 13 (48.1%) | 76 (38.0%)
ABN-NCS | 3 (7.7%) | 4 (3.9%) | 0 | 0 | 7 (3.5%)
ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Days15_21
WNL | 15 (38.5%) | 28 (27.2%) | 4 (12.9%) | 5 (18.5%) | 52 (26.0%)
ABN-NCS | 1 (2.6%) | 3 (2.9%) | 0 | 0 | 4 (2.0%)
Days22_28
WNL | 8 (20.5%) | 15 (14.6%) | 4 (12.9%) | 2 (7.4%) | 29 (14.5%)
ABN-NCS | 2 (5.1%) | 4 (3.9%) | 0 | 0 | 6 (3.0%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Blood Chemistry Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Total Protein (g/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participan | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
WNL | 0 | 10 (9.7%) | 3 (9.7%) | 6 (22.2%) | 19 (9.5%)
ABN-NCS | 3 (7.7%) | 9 (8.7%) | 5 (16.1%) | 6 (22.2%) | 23 (11.5%)
ABN-CS | 0 | 7 (6.8%) | 0 | 2 (7.4%) | 9 (4.5%)
Days1_7
WNL | 1 (2.6%) | 10 (9.7%) | 4 (12.9%) | 6 (22.2%) | 21 (10.5%)
ABN-NCS | 9 (23.1%) | 17 (16.5%) | 4 (12.9%) | 5 (18.5%) | 35 (17.5%)
ABN-CS | 0 | 6 (5.8%) | 0 | 1 (3.7%) | 7 (3.5%)
Days8_14
WNL | 2 (5.1%) | 8 (7.8%) | 5 (16.1%) | 5 (18.5%) | 20 (10.0%)
ABN-NCS | 7 (17.9%) | 14 (13.6%) | 4 (12.9%) | 4 (14.8%) | 29 (14.5%)
ABN-CS | 1 (2.6%) | 7 (6.8%) | 0 | 0 | 8 (4.0%)
Days15_21
WNL | 3 (7.7%) | 8 (7.8%) | 3 (9.7%) | 4 (14.8%) | 18 (9.0%)
ABN-NCS | 6 (15.4%) | 10 (9.7%) | 2 (6.5%) | 3 (11.1%) | 21 (10.5%)
ABN-CS | 1 (2.6%) | 4 (3.9%) | 0 | 0 | 5 (2.5%)
Days22_28
WNL | 2 (5.1%) | 7 (6.8%) | 1 (3.2%) | 1 (3.7%) | 11 (5.5%)
ABN-NCS | 4 (10.3%) | 6 (5.8%) | 0 | 1 (3.7%) | 11 (5.5%)
ABN-CS | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Blood Chemistry Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Albumin (g/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participan | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
WNL | 2 (5.1%) | 15 (14.6%) | 4 (12.9%) | 7 (25.9%) | 28 (14.0%)
ABN-NCS | 6 (15.4%) | 17 (16.5%) | 4 (12.9%) | 7 (25.9%) | 34 (17.0%)
ABN-CS | 1 (2.6%) | 11 (10.7%) | 3 (9.7%) | 3 (11.1%) | 18 (9.0%)
Days1_7
WNL | 2 (5.1%) | 17 (16.5%) | 7 (22.6%) | 8 (29.6%) | 34 (17.0%)
ABN-NCS | 12 (30.8%) | 18 (17.5%) | 2 (6.5%) | 6 (22.2%) | 38 (19.0%)
ABN-CS | 2 (5.1%) | 12 (11.7%) | 0 | 0 | 14 (7.0%)
Days8_14
WNL | 1 (2.6%) | 9 (8.7%) | 7 (22.6%) | 6 (22.2%) | 23 (11.5%)
ABN-NCS | 9 (23.1%) | 18 (17.5%) | 3 (9.7%) | 3 (11.1%) | 33 (16.5%)
ABN-CS | 0 | 9 (8.7%) | 0 | 0 | 9 (4.5%)
Days15_21
WNL | 4 (10.3%) | 9 (8.7%) | 2 (6.5%) | 4 (14.8%) | 19 (9.5%)
ABN-NCS | 8 (20.5%) | 14 (13.6%) | 3 (9.7%) | 3 (11.1%) | 28 (14.0%)
ABN-CS | 0 | 6 (5.8%) | 0 | 0 | 6 (3.0%)
Days22_28
WNL | 3 (7.7%) | 6 (5.8%) | 1 (3.2%) | 1 (3.7%) | 11 (5.5%)
ABN-NCS | 5 (12.8%) | 8 (7.8%) | 0 | 1 (3.7%) | 14 (7.0%)
ABN-CS | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Table 14.3.4.4

Summary of Shift of Blood Chemistry Interpretations from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Glucose (mg/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
No Change | 18 (46.2%) | 61 (59.2%) | 20 (64.5%) | 13 (48.1%) | 112 (56.0%)
WNL to WNL | 9 (23.1%) | 54 (52.4%) | 20 (64.5%) | 13 (48.1%) | 96 (48.0%)
ABN-NCS to ABN-NCS | 8 (20.5%) | 7 (6.8%) | 0 | 0 | 15 (7.5%)
ABN-CS to ABN-CS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
Worsening | 5 (12.8%) | 6 (5.8%) | 0 | 3 (11.1%) | 14 (7.0%)
WNL to ABN-NCS | 3 (7.7%) | 5 (4.9%) | 0 | 3 (11.1%) | 11 (5.5%)
WNL to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
ABN-NCS to ABN-CS | 2 (5.1%) | 0 | 0 | 0 | 2 (1.0%)
Improvement | 9 (23.1%) | 22 (21.4%) | 4 (12.9%) | 1 (3.7%) | 36 (18.0%)
ABN-NCS to WNL | 8 (20.5%) | 17 (16.5%) | 4 (12.9%) | 1 (3.7%) | 30 (15.0%)
ABN-CS to ABN-NCS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
ABN-CS to WNL | 1 (2.6%) | 4 (3.9%) | 0 | 0 | 5 (2.5%)
Days8_14
No Change | 16 (41.0%) | 38 (36.9%) | 10 (32.3%) | 13 (48.1%) | 77 (38.5%)
WNL to WNL | 8 (20.5%) | 34 (33.0%) | 10 (32.3%) | 13 (48.1%) | 65 (32.5%)
ABN-NCS to ABN-NCS | 7 (17.9%) | 4 (3.9%) | 0 | 0 | 11 (5.5%)
ABN-CS to ABN-CS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
Worsening | 2 (5.1%) | 8 (7.8%) | 2 (6.5%) | 0 | 12 (6.0%)
WNL to ABN-NCS | 2 (5.1%) | 7 (6.8%) | 2 (6.5%) | 0 | 11 (5.5%)
WNL to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Improvement | 11 (28.2%) | 20 (19.4%) | 3 (9.7%) | 1 (3.7%) | 35 (17.5%)
ABN-NCS to WNL | 10 (25.6%) | 16 (15.5%) | 3 (9.7%) | 1 (3.7%) | 30 (15.0%)
ABN-CS to WNL | 1 (2.6%) | 4 (3.9%) | 0 | 0 | 5 (2.5%)
Days15_21
No Change | 9 (23.1%) | 19 (18.4%) | 8 (25.8%) | 5 (18.5%) | 41 (20.5%)
WNL to WNL | 2 (5.1%) | 18 (17.5%) | 8 (25.8%) | 5 (18.5%) | 33 (16.5%)
ABN-NCS to ABN-NCS | 7 (17.9%) | 1 (1.0%) | 0 | 0 | 8 (4.0%)
Worsening | 2 (5.1%) | 4 (3.9%) | 0 | 2 (7.4%) | 8 (4.0%)
WNL to ABN-NCS | 2 (5.1%) | 4 (3.9%) | 0 | 2 (7.4%) | 8 (4.0%)
Improvement | 11 (28.2%) | 19 (18.4%) | 1 (3.2%) | 0 | 31 (15.5%)
ABN-NCS to WNL | 9 (23.1%) | 17 (16.5%) | 1 (3.2%) | 0 | 27 (13.5%)
ABN-CS to ABN-NCS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
ABN-CS to WNL | 1 (2.6%) | 2 (1.9%) | 0 | 0 | 3 (1.5%)
Days22_28
No Change | 6 (15.4%) | 16 (15.5%) | 4 (12.9%) | 3 (11.1%) | 29 (14.5%)
WNL to WNL | 3 (7.7%) | 15 (14.6%) | 4 (12.9%) | 3 (11.1%) | 25 (12.5%)
ABN-NCS to ABN-NCS | 2 (5.1%) | 1 (1.0%) | 0 | 0 | 3 (1.5%)
ABN-CS to ABN-CS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
Worsening | 0 | 1 (1.0%) | 0 | 1 (3.7%) | 2 (1.0%)
WNL to ABN-NCS | 0 | 1 (1.0%) | 0 | 1 (3.7%) | 2 (1.0%)
Improvement | 7 (17.9%) | 11 (10.7%) | 0 | 0 | 18 (9.0%)
ABN-NCS to WNL | 6 (15.4%) | 8 (7.8%) | 0 | 0 | 14 (7.0%)
ABN-CS to WNL | 1 (2.6%) | 3 (2.9%) | 0 | 0 | 4 (2.0%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Shift of Blood Chemistry Interpretations from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Creatinine (mg/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
No Change | 25 (64.1%) | 67 (65.0%) | 20 (64.5%) | 18 (66.7%) | 130 (65.0%)
WNL to WNL | 14 (35.9%) | 55 (53.4%) | 19 (61.3%) | 16 (59.3%) | 104 (52.0%)
ABN-NCS to ABN-NCS | 10 (25.6%) | 11 (10.7%) | 1 (3.2%) | 1 (3.7%) | 23 (11.5%)
ABN-CS to ABN-CS | 1 (2.6%) | 1 (1.0%) | 0 | 1 (3.7%) | 3 (1.5%)
Worsening | 0 | 7 (6.8%) | 1 (3.2%) | 1 (3.7%) | 9 (4.5%)
WNL to ABN-NCS | 0 | 5 (4.9%) | 1 (3.2%) | 1 (3.7%) | 7 (3.5%)
WNL to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
ABN-NCS to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Improvement | 8 (20.5%) | 14 (13.6%) | 2 (6.5%) | 0 | 24 (12.0%)
ABN-NCS to WNL | 3 (7.7%) | 13 (12.6%) | 1 (3.2%) | 0 | 17 (8.5%)
ABN-CS to ABN-NCS | 4 (10.3%) | 0 | 1 (3.2%) | 0 | 5 (2.5%)
ABN-CS to WNL | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
Days8_14
No Change | 15 (38.5%) | 47 (45.6%) | 12 (38.7%) | 14 (51.9%) | 88 (44.0%)
WNL to WNL | 9 (23.1%) | 37 (35.9%) | 11 (35.5%) | 13 (48.1%) | 70 (35.0%)
ABN-NCS to ABN-NCS | 5 (12.8%) | 9 (8.7%) | 1 (3.2%) | 1 (3.7%) | 16 (8.0%)
ABN-CS to ABN-CS | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
Worsening | 3 (7.7%) | 5 (4.9%) | 1 (3.2%) | 2 (7.4%) | 11 (5.5%)
WNL to ABN-NCS | 2 (5.1%) | 5 (4.9%) | 1 (3.2%) | 2 (7.4%) | 10 (5.0%)
ABN-NCS to ABN-CS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
Improvement | 10 (25.6%) | 11 (10.7%) | 1 (3.2%) | 0 | 22 (11.0%)
ABN-NCS to WNL | 5 (12.8%) | 10 (9.7%) | 0 | 0 | 15 (7.5%)
ABN-CS to ABN-NCS | 3 (7.7%) | 0 | 1 (3.2%) | 0 | 4 (2.0%)
ABN-CS to WNL | 2 (5.1%) | 1 (1.0%) | 0 | 0 | 3 (1.5%)
Days15_21
No Change | 11 (28.2%) | 32 (31.1%) | 8 (25.8%) | 8 (29.6%) | 59 (29.5%)
WNL to WNL | 8 (20.5%) | 27 (26.2%) | 8 (25.8%) | 8 (29.6%) | 51 (25.5%)
ABN-NCS to ABN-NCS | 3 (7.7%) | 5 (4.9%) | 0 | 0 | 8 (4.0%)
Worsening | 2 (5.1%) | 0 | 1 (3.2%) | 1 (3.7%) | 4 (2.0%)
WNL to ABN-NCS | 2 (5.1%) | 0 | 1 (3.2%) | 1 (3.7%) | 4 (2.0%)
Improvement | 7 (17.9%) | 10 (9.7%) | 0 | 0 | 17 (8.5%)
ABN-NCS to WNL | 5 (12.8%) | 9 (8.7%) | 0 | 0 | 14 (7.0%)
ABN-CS to ABN-NCS | 2 (5.1%) | 0 | 0 | 0 | 2 (1.0%)
ABN-CS to WNL | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Days22_28
No Change | 10 (25.6%) | 20 (19.4%) | 3 (9.7%) | 4 (14.8%) | 37 (18.5%)
WNL to WNL | 7 (17.9%) | 15 (14.6%) | 3 (9.7%) | 4 (14.8%) | 29 (14.5%)
ABN-NCS to ABN-NCS | 3 (7.7%) | 5 (4.9%) | 0 | 0 | 8 (4.0%)
Worsening | 1 (2.6%) | 1 (1.0%) | 1 (3.2%) | 1 (3.7%) | 4 (2.0%)
WNL to ABN-NCS | 1 (2.6%) | 1 (1.0%) | 1 (3.2%) | 1 (3.7%) | 4 (2.0%)
Improvement | 3 (7.7%) | 7 (6.8%) | 0 | 0 | 10 (5.0%)
ABN-NCS to WNL | 2 (5.1%) | 7 (6.8%) | 0 | 0 | 9 (4.5%)
ABN-CS to ABN-NCS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Shift of Blood Chemistry Interpretations from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: BUN (mg/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
No Change | 20 (51.3%) | 71 (68.9%) | 20 (64.5%) | 16 (59.3%) | 127 (63.5%)
WNL to WNL | 9 (23.1%) | 54 (52.4%) | 18 (58.1%) | 14 (51.9%) | 95 (47.5%)
ABN-NCS to ABN-NCS | 11 (28.2%) | 16 (15.5%) | 2 (6.5%) | 1 (3.7%) | 30 (15.0%)
ABN-CS to ABN-CS | 0 | 1 (1.0%) | 0 | 1 (3.7%) | 2 (1.0%)
Worsening | 2 (5.1%) | 8 (7.8%) | 2 (6.5%) | 1 (3.7%) | 13 (6.5%)
WNL to ABN-NCS | 2 (5.1%) | 6 (5.8%) | 2 (6.5%) | 1 (3.7%) | 11 (5.5%)
WNL to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
ABN-NCS to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Improvement | 9 (23.1%) | 9 (8.7%) | 0 | 3 (11.1%) | 21 (10.5%)
ABN-NCS to WNL | 7 (17.9%) | 8 (7.8%) | 0 | 2 (7.4%) | 17 (8.5%)
ABN-CS to ABN-NCS | 2 (5.1%) | 0 | 0 | 0 | 2 (1.0%)
ABN-CS to WNL | 0 | 1 (1.0%) | 0 | 1 (3.7%) | 2 (1.0%)
Days8_14
No Change | 14 (35.9%) | 44 (42.7%) | 12 (38.7%) | 14 (51.9%) | 84 (42.0%)
WNL to WNL | 8 (20.5%) | 32 (31.1%) | 11 (35.5%) | 13 (48.1%) | 64 (32.0%)
ABN-NCS to ABN-NCS | 6 (15.4%) | 11 (10.7%) | 1 (3.2%) | 1 (3.7%) | 19 (9.5%)
ABN-CS to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Worsening | 3 (7.7%) | 7 (6.8%) | 1 (3.2%) | 0 | 11 (5.5%)
WNL to ABN-NCS | 1 (2.6%) | 7 (6.8%) | 1 (3.2%) | 0 | 9 (4.5%)
ABN-NCS to ABN-CS | 2 (5.1%) | 0 | 0 | 0 | 2 (1.0%)
Improvement | 11 (28.2%) | 12 (11.7%) | 0 | 2 (7.4%) | 25 (12.5%)
ABN-NCS to WNL | 9 (23.1%) | 11 (10.7%) | 0 | 1 (3.7%) | 21 (10.5%)
ABN-CS to ABN-NCS | 2 (5.1%) | 0 | 0 | 0 | 2 (1.0%)
ABN-CS to WNL | 0 | 1 (1.0%) | 0 | 1 (3.7%) | 2 (1.0%)
Days15_21
No Change | 13 (33.3%) | 28 (27.2%) | 7 (22.6%) | 8 (29.6%) | 56 (28.0%)
WNL to WNL | 7 (17.9%) | 24 (23.3%) | 7 (22.6%) | 7 (25.9%) | 45 (22.5%)
ABN-NCS to ABN-NCS | 6 (15.4%) | 4 (3.9%) | 0 | 1 (3.7%) | 11 (5.5%)
Worsening | 1 (2.6%) | 6 (5.8%) | 2 (6.5%) | 1 (3.7%) | 10 (5.0%)
WNL to ABN-NCS | 1 (2.6%) | 5 (4.9%) | 2 (6.5%) | 1 (3.7%) | 9 (4.5%)
WNL to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Improvement | 6 (15.4%) | 8 (7.8%) | 0 | 0 | 14 (7.0%)
ABN-NCS to WNL | 5 (12.8%) | 7 (6.8%) | 0 | 0 | 12 (6.0%)
ABN-CS to WNL | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
Days22_28
No Change | 6 (15.4%) | 20 (19.4%) | 3 (9.7%) | 4 (14.8%) | 33 (16.5%)
WNL to WNL | 2 (5.1%) | 18 (17.5%) | 3 (9.7%) | 3 (11.1%) | 26 (13.0%)
ABN-NCS to ABN-NCS | 4 (10.3%) | 2 (1.9%) | 0 | 1 (3.7%) | 7 (3.5%)
Worsening | 2 (5.1%) | 5 (4.9%) | 1 (3.2%) | 1 (3.7%) | 9 (4.5%)
WNL to ABN-NCS | 2 (5.1%) | 5 (4.9%) | 1 (3.2%) | 1 (3.7%) | 9 (4.5%)
Improvement | 6 (15.4%) | 3 (2.9%) | 0 | 0 | 9 (4.5%)
ABN-NCS to WNL | 6 (15.4%) | 3 (2.9%) | 0 | 0 | 9 (4.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Shift of Blood Chemistry Interpretations from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: AST (U/L)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
No Change | 1 (2.6%) | 14 (13.6%) | 1 (3.2%) | 6 (22.2%) | 22 (11.0%)
WNL to WNL | 0 | 9 (8.7%) | 1 (3.2%) | 3 (11.1%) | 13 (6.5%)
ABN-NCS to ABN-NCS | 1 (2.6%) | 5 (4.9%) | 0 | 3 (11.1%) | 9 (4.5%)
Worsening | 0 | 5 (4.9%) | 1 (3.2%) | 1 (3.7%) | 7 (3.5%)
WNL to ABN-NCS | 0 | 4 (3.9%) | 1 (3.2%) | 1 (3.7%) | 6 (3.0%)
ABN-NCS to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Improvement | 0 | 2 (1.9%) | 2 (6.5%) | 3 (11.1%) | 7 (3.5%)
ABN-NCS to WNL | 0 | 2 (1.9%) | 1 (3.2%) | 3 (11.1%) | 6 (3.0%)
ABN-CS to WNL | 0 | 0 | 1 (3.2%) | 0 | 1 (0.5%)
Days8_14
No Change | 1 (2.6%) | 9 (8.7%) | 2 (6.5%) | 4 (14.8%) | 16 (8.0%)
WNL to WNL | 0 | 6 (5.8%) | 2 (6.5%) | 1 (3.7%) | 9 (4.5%)
ABN-NCS to ABN-NCS | 1 (2.6%) | 2 (1.9%) | 0 | 3 (11.1%) | 6 (3.0%)
ABN-CS to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Worsening | 0 | 7 (6.8%) | 0 | 2 (7.4%) | 9 (4.5%)
WNL to ABN-NCS | 0 | 5 (4.9%) | 0 | 1 (3.7%) | 6 (3.0%)
WNL to ABN-CS | 0 | 0 | 0 | 1 (3.7%) | 1 (0.5%)
ABN-NCS to ABN-CS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
Improvement | 0 | 2 (1.9%) | 1 (3.2%) | 1 (3.7%) | 4 (2.0%)
ABN-NCS to WNL | 0 | 2 (1.9%) | 0 | 1 (3.7%) | 3 (1.5%)
ABN-CS to ABN-NCS | 0 | 0 | 1 (3.2%) | 0 | 1 (0.5%)
Days15_21
No Change | 0 | 7 (6.8%) | 0 | 2 (7.4%) | 9 (4.5%)
WNL to WNL | 0 | 5 (4.9%) | 0 | 0 | 5 (2.5%)
ABN-NCS to ABN-NCS | 0 | 2 (1.9%) | 0 | 2 (7.4%) | 4 (2.0%)
Worsening | 0 | 4 (3.9%) | 0 | 2 (7.4%) | 6 (3.0%)
WNL to ABN-NCS | 0 | 3 (2.9%) | 0 | 0 | 3 (1.5%)
ABN-NCS to ABN-CS | 0 | 1 (1.0%) | 0 | 2 (7.4%) | 3 (1.5%)
Improvement | 1 (2.6%) | 1 (1.0%) | 1 (3.2%) | 1 (3.7%) | 4 (2.0%)
ABN-NCS to WNL | 1 (2.6%) | 1 (1.0%) | 0 | 1 (3.7%) | 3 (1.5%)
ABN-CS to WNL | 0 | 0 | 1 (3.2%) | 0 | 1 (0.5%)
Days22_28
No Change | 1 (2.6%) | 4 (3.9%) | 0 | 0 | 5 (2.5%)
WNL to WNL | 1 (2.6%) | 2 (1.9%) | 0 | 0 | 3 (1.5%)
ABN-NCS to ABN-NCS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
Worsening | 0 | 2 (1.9%) | 0 | 1 (3.7%) | 3 (1.5%)
WNL to ABN-NCS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
WNL to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
ABN-NCS to ABN-CS | 0 | 0 | 0 | 1 (3.7%) | 1 (0.5%)
Improvement | 1 (2.6%) | 0 | 1 (3.2%) | 1 (3.7%) | 3 (1.5%)
ABN-NCS to WNL | 1 (2.6%) | 0 | 0 | 1 (3.7%) | 2 (1.0%)
ABN-CS to WNL | 0 | 0 | 1 (3.2%) | 0 | 1 (0.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Shift of Blood Chemistry Interpretations from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: ALT (U/L)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
No Change | 1 (2.6%) | 18 (17.5%) | 3 (9.7%) | 6 (22.2%) | 28 (14.0%)
WNL to WNL | 1 (2.6%) | 14 (13.6%) | 2 (6.5%) | 4 (14.8%) | 21 (10.5%)
ABN-NCS to ABN-NCS | 0 | 4 (3.9%) | 1 (3.2%) | 2 (7.4%) | 7 (3.5%)
Worsening | 0 | 3 (2.9%) | 0 | 3 (11.1%) | 6 (3.0%)
WNL to ABN-NCS | 0 | 2 (1.9%) | 0 | 3 (11.1%) | 5 (2.5%)
ABN-NCS to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Improvement | 0 | 0 | 1 (3.2%) | 2 (7.4%) | 3 (1.5%)
ABN-NCS to WNL | 0 | 0 | 0 | 2 (7.4%) | 2 (1.0%)
ABN-CS to ABN-NCS | 0 | 0 | 1 (3.2%) | 0 | 1 (0.5%)
Days8_14
No Change | 1 (2.6%) | 12 (11.7%) | 2 (6.5%) | 4 (14.8%) | 19 (9.5%)
WNL to WNL | 1 (2.6%) | 10 (9.7%) | 2 (6.5%) | 2 (7.4%) | 15 (7.5%)
ABN-NCS to ABN-NCS | 0 | 1 (1.0%) | 0 | 2 (7.4%) | 3 (1.5%)
ABN-CS to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Worsening | 0 | 5 (4.9%) | 0 | 2 (7.4%) | 7 (3.5%)
WNL to ABN-NCS | 0 | 3 (2.9%) | 0 | 1 (3.7%) | 4 (2.0%)
WNL to ABN-CS | 0 | 0 | 0 | 1 (3.7%) | 1 (0.5%)
ABN-NCS to ABN-CS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
Improvement | 0 | 1 (1.0%) | 1 (3.2%) | 1 (3.7%) | 3 (1.5%)
ABN-NCS to WNL | 0 | 1 (1.0%) | 0 | 1 (3.7%) | 2 (1.0%)
ABN-CS to WNL | 0 | 0 | 1 (3.2%) | 0 | 1 (0.5%)
Days15_21
No Change | 1 (2.6%) | 7 (6.8%) | 0 | 2 (7.4%) | 10 (5.0%)
WNL to WNL | 1 (2.6%) | 6 (5.8%) | 0 | 0 | 7 (3.5%)
ABN-NCS to ABN-NCS | 0 | 1 (1.0%) | 0 | 2 (7.4%) | 3 (1.5%)
Worsening | 0 | 2 (1.9%) | 0 | 2 (7.4%) | 4 (2.0%)
WNL to ABN-NCS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
WNL to ABN-CS | 0 | 0 | 0 | 1 (3.7%) | 1 (0.5%)
ABN-NCS to ABN-CS | 0 | 0 | 0 | 1 (3.7%) | 1 (0.5%)
Improvement | 0 | 2 (1.9%) | 1 (3.2%) | 1 (3.7%) | 4 (2.0%)
ABN-NCS to WNL | 0 | 2 (1.9%) | 0 | 1 (3.7%) | 3 (1.5%)
ABN-CS to WNL | 0 | 0 | 1 (3.2%) | 0 | 1 (0.5%)
Days22_28
No Change | 2 (5.1%) | 5 (4.9%) | 0 | 0 | 7 (3.5%)
WNL to WNL | 2 (5.1%) | 3 (2.9%) | 0 | 0 | 5 (2.5%)
ABN-NCS to ABN-NCS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
Worsening | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
WNL to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Improvement | 0 | 0 | 1 (3.2%) | 1 (3.7%) | 2 (1.0%)
ABN-NCS to WNL | 0 | 0 | 0 | 1 (3.7%) | 1 (0.5%)
ABN-CS to WNL | 0 | 0 | 1 (3.2%) | 0 | 1 (0.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Shift of Blood Chemistry Interpretations from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Alkaline Phosphatase (U/L)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
No Change | 1 (2.6%) | 21 (20.4%) | 4 (12.9%) | 8 (29.6%) | 34 (17.0%)
WNL to WNL | 1 (2.6%) | 14 (13.6%) | 3 (9.7%) | 7 (25.9%) | 25 (12.5%)
ABN-NCS to ABN-NCS | 0 | 2 (1.9%) | 1 (3.2%) | 1 (3.7%) | 4 (2.0%)
ABN-CS to ABN-CS | 0 | 5 (4.9%) | 0 | 0 | 5 (2.5%)
Worsening | 0 | 2 (1.9%) | 0 | 1 (3.7%) | 3 (1.5%)
WNL to ABN-NCS | 0 | 2 (1.9%) | 0 | 1 (3.7%) | 3 (1.5%)
Improvement | 1 (2.6%) | 4 (3.9%) | 0 | 0 | 5 (2.5%)
ABN-NCS to WNL | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
ABN-CS to WNL | 1 (2.6%) | 2 (1.9%) | 0 | 0 | 3 (1.5%)
Days8_14
No Change | 1 (2.6%) | 11 (10.7%) | 2 (6.5%) | 5 (18.5%) | 19 (9.5%)
WNL to WNL | 1 (2.6%) | 4 (3.9%) | 2 (6.5%) | 4 (14.8%) | 11 (5.5%)
ABN-NCS to ABN-NCS | 0 | 3 (2.9%) | 0 | 1 (3.7%) | 4 (2.0%)
ABN-CS to ABN-CS | 0 | 4 (3.9%) | 0 | 0 | 4 (2.0%)
Worsening | 0 | 5 (4.9%) | 0 | 0 | 5 (2.5%)
WNL to ABN-NCS | 0 | 5 (4.9%) | 0 | 0 | 5 (2.5%)
Improvement | 0 | 2 (1.9%) | 1 (3.2%) | 0 | 3 (1.5%)
ABN-NCS to WNL | 0 | 1 (1.0%) | 1 (3.2%) | 0 | 2 (1.0%)
ABN-CS to WNL | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Days15_21
No Change | 1 (2.6%) | 3 (2.9%) | 0 | 0 | 4 (2.0%)
WNL to WNL | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
ABN-NCS to ABN-NCS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
ABN-CS to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Worsening | 0 | 8 (7.8%) | 0 | 4 (14.8%) | 12 (6.0%)
WNL to ABN-NCS | 0 | 7 (6.8%) | 0 | 3 (11.1%) | 10 (5.0%)
WNL to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
ABN-NCS to ABN-CS | 0 | 0 | 0 | 1 (3.7%) | 1 (0.5%)
Improvement | 1 (2.6%) | 1 (1.0%) | 1 (3.2%) | 0 | 3 (1.5%)
ABN-NCS to WNL | 0 | 0 | 1 (3.2%) | 0 | 1 (0.5%)
ABN-CS to ABN-NCS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
ABN-CS to WNL | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
Days22_28
No Change | 2 (5.1%) | 4 (3.9%) | 0 | 0 | 6 (3.0%)
WNL to WNL | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
ABN-NCS to ABN-NCS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
ABN-CS to ABN-CS | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
Worsening | 0 | 3 (2.9%) | 0 | 1 (3.7%) | 4 (2.0%)
WNL to ABN-NCS | 0 | 3 (2.9%) | 0 | 1 (3.7%) | 4 (2.0%)
Improvement | 0 | 0 | 1 (3.2%) | 0 | 1 (0.5%)
ABN-NCS to WNL | 0 | 0 | 1 (3.2%) | 0 | 1 (0.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Shift of Blood Chemistry Interpretations from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Total Bilirubin (mg/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
No Change | 16 (41.0%) | 22 (21.4%) | 8 (25.8%) | 8 (29.6%) | 54 (27.0%)
WNL to WNL | 8 (20.5%) | 11 (10.7%) | 6 (19.4%) | 6 (22.2%) | 31 (15.5%)
ABN-NCS to ABN-NCS | 7 (17.9%) | 8 (7.8%) | 2 (6.5%) | 2 (7.4%) | 19 (9.5%)
ABN-CS to ABN-CS | 1 (2.6%) | 3 (2.9%) | 0 | 0 | 4 (2.0%)
Worsening | 4 (10.3%) | 0 | 1 (3.2%) | 3 (11.1%) | 8 (4.0%)
WNL to ABN-NCS | 2 (5.1%) | 0 | 1 (3.2%) | 1 (3.7%) | 4 (2.0%)
WNL to ABN-CS | 0 | 0 | 0 | 2 (7.4%) | 2 (1.0%)
ABN-NCS to ABN-CS | 2 (5.1%) | 0 | 0 | 0 | 2 (1.0%)
Improvement | 1 (2.6%) | 6 (5.8%) | 3 (9.7%) | 1 (3.7%) | 11 (5.5%)
ABN-NCS to WNL | 0 | 3 (2.9%) | 1 (3.2%) | 1 (3.7%) | 5 (2.5%)
ABN-CS to ABN-NCS | 0 | 3 (2.9%) | 2 (6.5%) | 0 | 5 (2.5%)
ABN-CS to WNL | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
Days8_14
No Change | 7 (17.9%) | 12 (11.7%) | 6 (19.4%) | 7 (25.9%) | 32 (16.0%)
WNL to WNL | 4 (10.3%) | 4 (3.9%) | 5 (16.1%) | 6 (22.2%) | 19 (9.5%)
ABN-NCS to ABN-NCS | 3 (7.7%) | 4 (3.9%) | 1 (3.2%) | 1 (3.7%) | 9 (4.5%)
ABN-CS to ABN-CS | 0 | 4 (3.9%) | 0 | 0 | 4 (2.0%)
Worsening | 1 (2.6%) | 6 (5.8%) | 0 | 1 (3.7%) | 8 (4.0%)
WNL to ABN-NCS | 0 | 4 (3.9%) | 0 | 1 (3.7%) | 5 (2.5%)
WNL to ABN-CS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
ABN-NCS to ABN-CS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
Improvement | 1 (2.6%) | 6 (5.8%) | 2 (6.5%) | 1 (3.7%) | 10 (5.0%)
ABN-NCS to WNL | 0 | 3 (2.9%) | 0 | 1 (3.7%) | 4 (2.0%)
ABN-CS to ABN-NCS | 1 (2.6%) | 2 (1.9%) | 1 (3.2%) | 0 | 4 (2.0%)
ABN-CS to WNL | 0 | 1 (1.0%) | 1 (3.2%) | 0 | 2 (1.0%)
Days15_21
No Change | 8 (20.5%) | 4 (3.9%) | 3 (9.7%) | 3 (11.1%) | 18 (9.0%)
WNL to WNL | 3 (7.7%) | 2 (1.9%) | 2 (6.5%) | 1 (3.7%) | 8 (4.0%)
ABN-NCS to ABN-NCS | 5 (12.8%) | 1 (1.0%) | 1 (3.2%) | 2 (7.4%) | 9 (4.5%)
ABN-CS to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Worsening | 1 (2.6%) | 3 (2.9%) | 0 | 3 (11.1%) | 7 (3.5%)
WNL to ABN-NCS | 1 (2.6%) | 3 (2.9%) | 0 | 2 (7.4%) | 6 (3.0%)
ABN-NCS to ABN-CS | 0 | 0 | 0 | 1 (3.7%) | 1 (0.5%)
Improvement | 1 (2.6%) | 5 (4.9%) | 1 (3.2%) | 0 | 7 (3.5%)
ABN-NCS to WNL | 0 | 4 (3.9%) | 1 (3.2%) | 0 | 5 (2.5%)
ABN-CS to ABN-NCS | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
Days22_28
No Change | 4 (10.3%) | 5 (4.9%) | 1 (3.2%) | 0 | 10 (5.0%)
WNL to WNL | 2 (5.1%) | 1 (1.0%) | 1 (3.2%) | 0 | 4 (2.0%)
ABN-NCS to ABN-NCS | 2 (5.1%) | 3 (2.9%) | 0 | 0 | 5 (2.5%)
ABN-CS to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Worsening | 1 (2.6%) | 3 (2.9%) | 2 (6.5%) | 2 (7.4%) | 8 (4.0%)
WNL to ABN-NCS | 0 | 2 (1.9%) | 1 (3.2%) | 1 (3.7%) | 4 (2.0%)
WNL to ABN-CS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
ABN-NCS to ABN-CS | 0 | 1 (1.0%) | 1 (3.2%) | 1 (3.7%) | 3 (1.5%)
Improvement | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
ABN-NCS to WNL | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
ABN-CS to WNL | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Shift of Blood Chemistry Interpretations from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Direct Bilirubin (mg/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
No Change | 7 (17.9%) | 10 (9.7%) | 3 (9.7%) | 5 (18.5%) | 25 (12.5%)
WNL to WNL | 4 (10.3%) | 4 (3.9%) | 2 (6.5%) | 3 (11.1%) | 13 (6.5%)
ABN-NCS to ABN-NCS | 3 (7.7%) | 2 (1.9%) | 1 (3.2%) | 0 | 6 (3.0%)
ABN-CS to ABN-CS | 0 | 4 (3.9%) | 0 | 2 (7.4%) | 6 (3.0%)
Worsening | 3 (7.7%) | 3 (2.9%) | 1 (3.2%) | 1 (3.7%) | 8 (4.0%)
WNL to ABN-NCS | 1 (2.6%) | 2 (1.9%) | 1 (3.2%) | 0 | 4 (2.0%)
WNL to ABN-CS | 0 | 0 | 0 | 1 (3.7%) | 1 (0.5%)
ABN-NCS to ABN-CS | 2 (5.1%) | 1 (1.0%) | 0 | 0 | 3 (1.5%)
Improvement | 2 (5.1%) | 4 (3.9%) | 0 | 0 | 6 (3.0%)
ABN-NCS to WNL | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
ABN-CS to ABN-NCS | 0 | 3 (2.9%) | 0 | 0 | 3 (1.5%)
ABN-CS to WNL | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
Days8_14
No Change | 1 (2.6%) | 6 (5.8%) | 2 (6.5%) | 2 (7.4%) | 11 (5.5%)
WNL to WNL | 1 (2.6%) | 0 | 1 (3.2%) | 1 (3.7%) | 3 (1.5%)
ABN-NCS to ABN-NCS | 0 | 1 (1.0%) | 1 (3.2%) | 0 | 2 (1.0%)
ABN-CS to ABN-CS | 0 | 5 (4.9%) | 0 | 1 (3.7%) | 6 (3.0%)
Worsening | 2 (5.1%) | 5 (4.9%) | 0 | 2 (7.4%) | 9 (4.5%)
WNL to ABN-NCS | 2 (5.1%) | 3 (2.9%) | 0 | 1 (3.7%) | 6 (3.0%)
WNL to ABN-CS | 0 | 1 (1.0%) | 0 | 1 (3.7%) | 2 (1.0%)
ABN-NCS to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Improvement | 1 (2.6%) | 4 (3.9%) | 0 | 0 | 5 (2.5%)
ABN-NCS to WNL | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
ABN-CS to ABN-NCS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
ABN-CS to WNL | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
Days15_21
No Change | 3 (7.7%) | 4 (3.9%) | 0 | 1 (3.7%) | 8 (4.0%)
ABN-NCS to ABN-NCS | 3 (7.7%) | 1 (1.0%) | 0 | 0 | 4 (2.0%)
ABN-CS to ABN-CS | 0 | 3 (2.9%) | 0 | 1 (3.7%) | 4 (2.0%)
Worsening | 2 (5.1%) | 0 | 0 | 2 (7.4%) | 4 (2.0%)
WNL to ABN-NCS | 2 (5.1%) | 0 | 0 | 1 (3.7%) | 3 (1.5%)
WNL to ABN-CS | 0 | 0 | 0 | 1 (3.7%) | 1 (0.5%)
Improvement | 1 (2.6%) | 2 (1.9%) | 0 | 0 | 3 (1.5%)
ABN-NCS to WNL | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
ABN-CS to ABN-NCS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
Days22_28
No Change | 1 (2.6%) | 2 (1.9%) | 0 | 0 | 3 (1.5%)
ABN-NCS to ABN-NCS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
ABN-CS to ABN-CS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
Worsening | 2 (5.1%) | 1 (1.0%) | 0 | 0 | 3 (1.5%)
WNL to ABN-NCS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
WNL to ABN-CS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
ABN-NCS to ABN-CS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Shift of Blood Chemistry Interpretations from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Sodium (mmol/L)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
No Change | 20 (51.3%) | 67 (65.0%) | 18 (58.1%) | 19 (70.4%) | 124 (62.0%)
WNL to WNL | 15 (38.5%) | 61 (59.2%) | 17 (54.8%) | 19 (70.4%) | 112 (56.0%)
ABN-NCS to ABN-NCS | 4 (10.3%) | 3 (2.9%) | 1 (3.2%) | 0 | 8 (4.0%)
ABN-CS to ABN-CS | 1 (2.6%) | 3 (2.9%) | 0 | 0 | 4 (2.0%)
Worsening | 8 (20.5%) | 10 (9.7%) | 1 (3.2%) | 1 (3.7%) | 20 (10.0%)
WNL to ABN-NCS | 6 (15.4%) | 7 (6.8%) | 1 (3.2%) | 1 (3.7%) | 15 (7.5%)
WNL to ABN-CS | 2 (5.1%) | 3 (2.9%) | 0 | 0 | 5 (2.5%)
Improvement | 9 (23.1%) | 16 (15.5%) | 6 (19.4%) | 1 (3.7%) | 32 (16.0%)
ABN-NCS to WNL | 6 (15.4%) | 9 (8.7%) | 6 (19.4%) | 1 (3.7%) | 22 (11.0%)
ABN-CS to WNL | 3 (7.7%) | 7 (6.8%) | 0 | 0 | 10 (5.0%)
Days8_14
No Change | 12 (30.8%) | 46 (44.7%) | 13 (41.9%) | 18 (66.7%) | 89 (44.5%)
WNL to WNL | 10 (25.6%) | 46 (44.7%) | 12 (38.7%) | 18 (66.7%) | 86 (43.0%)
ABN-NCS to ABN-NCS | 1 (2.6%) | 0 | 1 (3.2%) | 0 | 2 (1.0%)
ABN-CS to ABN-CS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
Worsening | 9 (23.1%) | 8 (7.8%) | 0 | 0 | 17 (8.5%)
WNL to ABN-NCS | 9 (23.1%) | 5 (4.9%) | 0 | 0 | 14 (7.0%)
WNL to ABN-CS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
ABN-NCS to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Improvement | 10 (25.6%) | 16 (15.5%) | 3 (9.7%) | 0 | 29 (14.5%)
ABN-NCS to WNL | 8 (20.5%) | 8 (7.8%) | 3 (9.7%) | 0 | 19 (9.5%)
ABN-CS to ABN-NCS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
ABN-CS to WNL | 2 (5.1%) | 6 (5.8%) | 0 | 0 | 8 (4.0%)
Days15_21
No Change | 13 (33.3%) | 32 (31.1%) | 7 (22.6%) | 7 (25.9%) | 59 (29.5%)
WNL to WNL | 10 (25.6%) | 31 (30.1%) | 7 (22.6%) | 7 (25.9%) | 55 (27.5%)
ABN-NCS to ABN-NCS | 3 (7.7%) | 1 (1.0%) | 0 | 0 | 4 (2.0%)
Worsening | 6 (15.4%) | 2 (1.9%) | 1 (3.2%) | 2 (7.4%) | 11 (5.5%)
WNL to ABN-NCS | 5 (12.8%) | 2 (1.9%) | 0 | 2 (7.4%) | 9 (4.5%)
WNL to ABN-CS | 0 | 0 | 1 (3.2%) | 0 | 1 (0.5%)
ABN-NCS to ABN-CS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
Improvement | 5 (12.8%) | 13 (12.6%) | 0 | 0 | 18 (9.0%)
ABN-NCS to WNL | 4 (10.3%) | 9 (8.7%) | 0 | 0 | 13 (6.5%)
ABN-CS to ABN-NCS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
ABN-CS to WNL | 1 (2.6%) | 2 (1.9%) | 0 | 0 | 3 (1.5%)
Days22_28
No Change | 8 (20.5%) | 22 (21.4%) | 3 (9.7%) | 4 (14.8%) | 37 (18.5%)
WNL to WNL | 5 (12.8%) | 22 (21.4%) | 3 (9.7%) | 4 (14.8%) | 34 (17.0%)
ABN-NCS to ABN-NCS | 3 (7.7%) | 0 | 0 | 0 | 3 (1.5%)
Worsening | 4 (10.3%) | 0 | 1 (3.2%) | 0 | 5 (2.5%)
WNL to ABN-NCS | 4 (10.3%) | 0 | 1 (3.2%) | 0 | 5 (2.5%)
Improvement | 4 (10.3%) | 8 (7.8%) | 0 | 0 | 12 (6.0%)
ABN-NCS to WNL | 3 (7.7%) | 5 (4.9%) | 0 | 0 | 8 (4.0%)
ABN-CS to ABN-NCS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
ABN-CS to WNL | 0 | 3 (2.9%) | 0 | 0 | 3 (1.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Shift of Blood Chemistry Interpretations from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Potassium (mmol/L)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
No Change | 23 (59.0%) | 62 (60.2%) | 16 (51.6%) | 16 (59.3%) | 117 (58.5%)
WNL to WNL | 22 (56.4%) | 56 (54.4%) | 14 (45.2%) | 14 (51.9%) | 106 (53.0%)
ABN-NCS to ABN-NCS | 1 (2.6%) | 6 (5.8%) | 2 (6.5%) | 2 (7.4%) | 11 (5.5%)
Worsening | 6 (15.4%) | 16 (15.5%) | 3 (9.7%) | 3 (11.1%) | 28 (14.0%)
WNL to ABN-NCS | 5 (12.8%) | 13 (12.6%) | 3 (9.7%) | 3 (11.1%) | 24 (12.0%)
WNL to ABN-CS | 1 (2.6%) | 2 (1.9%) | 0 | 0 | 3 (1.5%)
ABN-NCS to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Improvement | 8 (20.5%) | 17 (16.5%) | 5 (16.1%) | 2 (7.4%) | 32 (16.0%)
ABN-NCS to WNL | 6 (15.4%) | 12 (11.7%) | 4 (12.9%) | 1 (3.7%) | 23 (11.5%)
ABN-CS to ABN-NCS | 1 (2.6%) | 1 (1.0%) | 0 | 1 (3.7%) | 3 (1.5%)
ABN-CS to WNL | 1 (2.6%) | 4 (3.9%) | 1 (3.2%) | 0 | 6 (3.0%)
Days8_14
No Change | 14 (35.9%) | 52 (50.5%) | 12 (38.7%) | 14 (51.9%) | 92 (46.0%)
WNL to WNL | 14 (35.9%) | 47 (45.6%) | 12 (38.7%) | 13 (48.1%) | 86 (43.0%)
ABN-NCS to ABN-NCS | 0 | 5 (4.9%) | 0 | 1 (3.7%) | 6 (3.0%)
Worsening | 9 (23.1%) | 3 (2.9%) | 0 | 3 (11.1%) | 15 (7.5%)
WNL to ABN-NCS | 7 (17.9%) | 2 (1.9%) | 0 | 3 (11.1%) | 12 (6.0%)
WNL to ABN-CS | 2 (5.1%) | 1 (1.0%) | 0 | 0 | 3 (1.5%)
Improvement | 8 (20.5%) | 15 (14.6%) | 4 (12.9%) | 2 (7.4%) | 29 (14.5%)
ABN-NCS to WNL | 7 (17.9%) | 10 (9.7%) | 4 (12.9%) | 1 (3.7%) | 22 (11.0%)
ABN-CS to ABN-NCS | 1 (2.6%) | 2 (1.9%) | 0 | 0 | 3 (1.5%)
ABN-CS to WNL | 0 | 3 (2.9%) | 0 | 1 (3.7%) | 4 (2.0%)
Days15_21
No Change | 15 (38.5%) | 31 (30.1%) | 7 (22.6%) | 6 (22.2%) | 59 (29.5%)
WNL to WNL | 15 (38.5%) | 28 (27.2%) | 7 (22.6%) | 5 (18.5%) | 55 (27.5%)
ABN-NCS to ABN-NCS | 0 | 3 (2.9%) | 0 | 1 (3.7%) | 4 (2.0%)
Worsening | 2 (5.1%) | 4 (3.9%) | 0 | 2 (7.4%) | 8 (4.0%)
WNL to ABN-NCS | 2 (5.1%) | 3 (2.9%) | 0 | 1 (3.7%) | 6 (3.0%)
WNL to ABN-CS | 0 | 1 (1.0%) | 0 | 1 (3.7%) | 2 (1.0%)
Improvement | 7 (17.9%) | 13 (12.6%) | 1 (3.2%) | 2 (7.4%) | 23 (11.5%)
ABN-NCS to WNL | 7 (17.9%) | 8 (7.8%) | 1 (3.2%) | 1 (3.7%) | 17 (8.5%)
ABN-CS to ABN-NCS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
ABN-CS to WNL | 0 | 4 (3.9%) | 0 | 1 (3.7%) | 5 (2.5%)
Days22_28
No Change | 7 (17.9%) | 13 (12.6%) | 2 (6.5%) | 4 (14.8%) | 26 (13.0%)
WNL to WNL | 6 (15.4%) | 13 (12.6%) | 2 (6.5%) | 3 (11.1%) | 24 (12.0%)
ABN-NCS to ABN-NCS | 1 (2.6%) | 0 | 0 | 1 (3.7%) | 2 (1.0%)
Worsening | 6 (15.4%) | 9 (8.7%) | 1 (3.2%) | 1 (3.7%) | 17 (8.5%)
WNL to ABN-NCS | 6 (15.4%) | 8 (7.8%) | 1 (3.2%) | 0 | 15 (7.5%)
WNL to ABN-CS | 0 | 1 (1.0%) | 0 | 1 (3.7%) | 2 (1.0%)
Improvement | 3 (7.7%) | 8 (7.8%) | 1 (3.2%) | 1 (3.7%) | 13 (6.5%)
ABN-NCS to WNL | 3 (7.7%) | 6 (5.8%) | 1 (3.2%) | 0 | 10 (5.0%)
ABN-CS to WNL | 0 | 2 (1.9%) | 0 | 1 (3.7%) | 3 (1.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Shift of Blood Chemistry Interpretations from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Chloride (mmol/L)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
No Change | 17 (43.6%) | 60 (58.3%) | 21 (67.7%) | 16 (59.3%) | 114 (57.0%)
WNL to WNL | 12 (30.8%) | 52 (50.5%) | 18 (58.1%) | 14 (51.9%) | 96 (48.0%)
ABN-NCS to ABN-NCS | 4 (10.3%) | 7 (6.8%) | 3 (9.7%) | 2 (7.4%) | 16 (8.0%)
ABN-CS to ABN-CS | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
Worsening | 9 (23.1%) | 14 (13.6%) | 2 (6.5%) | 2 (7.4%) | 27 (13.5%)
WNL to ABN-NCS | 8 (20.5%) | 12 (11.7%) | 1 (3.2%) | 2 (7.4%) | 23 (11.5%)
WNL to ABN-CS | 1 (2.6%) | 2 (1.9%) | 1 (3.2%) | 0 | 4 (2.0%)
Improvement | 9 (23.1%) | 14 (13.6%) | 1 (3.2%) | 3 (11.1%) | 27 (13.5%)
ABN-NCS to WNL | 6 (15.4%) | 13 (12.6%) | 1 (3.2%) | 2 (7.4%) | 22 (11.0%)
ABN-CS to ABN-NCS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
ABN-CS to WNL | 2 (5.1%) | 1 (1.0%) | 0 | 1 (3.7%) | 4 (2.0%)
Days8_14
No Change | 13 (33.3%) | 39 (37.9%) | 12 (38.7%) | 11 (40.7%) | 75 (37.5%)
WNL to WNL | 11 (28.2%) | 34 (33.0%) | 12 (38.7%) | 10 (37.0%) | 67 (33.5%)
ABN-NCS to ABN-NCS | 1 (2.6%) | 5 (4.9%) | 0 | 1 (3.7%) | 7 (3.5%)
ABN-CS to ABN-CS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
Worsening | 6 (15.4%) | 14 (13.6%) | 2 (6.5%) | 3 (11.1%) | 25 (12.5%)
WNL to ABN-NCS | 6 (15.4%) | 13 (12.6%) | 2 (6.5%) | 3 (11.1%) | 24 (12.0%)
WNL to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Improvement | 10 (25.6%) | 14 (13.6%) | 2 (6.5%) | 4 (14.8%) | 30 (15.0%)
ABN-NCS to WNL | 8 (20.5%) | 12 (11.7%) | 2 (6.5%) | 3 (11.1%) | 25 (12.5%)
ABN-CS to WNL | 2 (5.1%) | 2 (1.9%) | 0 | 1 (3.7%) | 5 (2.5%)
Days15_21
No Change | 11 (28.2%) | 30 (29.1%) | 6 (19.4%) | 7 (25.9%) | 54 (27.0%)
WNL to WNL | 9 (23.1%) | 25 (24.3%) | 5 (16.1%) | 5 (18.5%) | 44 (22.0%)
ABN-NCS to ABN-NCS | 2 (5.1%) | 5 (4.9%) | 1 (3.2%) | 2 (7.4%) | 10 (5.0%)
Worsening | 4 (10.3%) | 7 (6.8%) | 2 (6.5%) | 0 | 13 (6.5%)
WNL to ABN-NCS | 3 (7.7%) | 7 (6.8%) | 2 (6.5%) | 0 | 12 (6.0%)
ABN-NCS to ABN-CS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
Improvement | 7 (17.9%) | 8 (7.8%) | 0 | 2 (7.4%) | 17 (8.5%)
ABN-NCS to WNL | 6 (15.4%) | 8 (7.8%) | 0 | 2 (7.4%) | 16 (8.0%)
ABN-CS to ABN-NCS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
Days22_28
No Change | 5 (12.8%) | 17 (16.5%) | 3 (9.7%) | 3 (11.1%) | 28 (14.0%)
WNL to WNL | 5 (12.8%) | 16 (15.5%) | 3 (9.7%) | 3 (11.1%) | 27 (13.5%)
ABN-NCS to ABN-NCS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Worsening | 3 (7.7%) | 6 (5.8%) | 0 | 0 | 9 (4.5%)
WNL to ABN-NCS | 3 (7.7%) | 6 (5.8%) | 0 | 0 | 9 (4.5%)
Improvement | 7 (17.9%) | 6 (5.8%) | 1 (3.2%) | 2 (7.4%) | 16 (8.0%)
ABN-NCS to WNL | 6 (15.4%) | 6 (5.8%) | 1 (3.2%) | 2 (7.4%) | 15 (7.5%)
ABN-CS to WNL | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Shift of Blood Chemistry Interpretations from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Calcium (mg/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
No Change | 25 (64.1%) | 68 (66.0%) | 17 (54.8%) | 17 (63.0%) | 127 (63.5%)
WNL to WNL | 23 (59.0%) | 63 (61.2%) | 17 (54.8%) | 16 (59.3%) | 119 (59.5%)
ABN-NCS to ABN-NCS | 2 (5.1%) | 5 (4.9%) | 0 | 1 (3.7%) | 8 (4.0%)
Worsening | 2 (5.1%) | 6 (5.8%) | 2 (6.5%) | 1 (3.7%) | 11 (5.5%)
WNL to ABN-NCS | 2 (5.1%) | 6 (5.8%) | 2 (6.5%) | 1 (3.7%) | 11 (5.5%)
Improvement | 4 (10.3%) | 11 (10.7%) | 3 (9.7%) | 2 (7.4%) | 20 (10.0%)
ABN-NCS to WNL | 4 (10.3%) | 9 (8.7%) | 3 (9.7%) | 1 (3.7%) | 17 (8.5%)
ABN-CS to WNL | 0 | 2 (1.9%) | 0 | 1 (3.7%) | 3 (1.5%)
Days8_14
No Change | 24 (61.5%) | 48 (46.6%) | 9 (29.0%) | 16 (59.3%) | 97 (48.5%)
WNL to WNL | 21 (53.8%) | 45 (43.7%) | 9 (29.0%) | 16 (59.3%) | 91 (45.5%)
ABN-NCS to ABN-NCS | 3 (7.7%) | 3 (2.9%) | 0 | 0 | 6 (3.0%)
Worsening | 0 | 6 (5.8%) | 1 (3.2%) | 0 | 7 (3.5%)
WNL to ABN-NCS | 0 | 6 (5.8%) | 1 (3.2%) | 0 | 7 (3.5%)
Improvement | 3 (7.7%) | 9 (8.7%) | 2 (6.5%) | 2 (7.4%) | 16 (8.0%)
ABN-NCS to WNL | 3 (7.7%) | 9 (8.7%) | 2 (6.5%) | 2 (7.4%) | 16 (8.0%)
Days15_21
No Change | 15 (38.5%) | 33 (32.0%) | 6 (19.4%) | 7 (25.9%) | 61 (30.5%)
WNL to WNL | 14 (35.9%) | 31 (30.1%) | 6 (19.4%) | 7 (25.9%) | 58 (29.0%)
ABN-NCS to ABN-NCS | 1 (2.6%) | 2 (1.9%) | 0 | 0 | 3 (1.5%)
Worsening | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
WNL to ABN-NCS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
Improvement | 4 (10.3%) | 8 (7.8%) | 2 (6.5%) | 2 (7.4%) | 16 (8.0%)
ABN-NCS to WNL | 4 (10.3%) | 8 (7.8%) | 2 (6.5%) | 2 (7.4%) | 16 (8.0%)
Days22_28
No Change | 11 (28.2%) | 18 (17.5%) | 3 (9.7%) | 4 (14.8%) | 36 (18.0%)
WNL to WNL | 10 (25.6%) | 18 (17.5%) | 3 (9.7%) | 4 (14.8%) | 35 (17.5%)
ABN-NCS to ABN-NCS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
Worsening | 0 | 3 (2.9%) | 0 | 0 | 3 (1.5%)
WNL to ABN-NCS | 0 | 3 (2.9%) | 0 | 0 | 3 (1.5%)
Improvement | 2 (5.1%) | 6 (5.8%) | 1 (3.2%) | 1 (3.7%) | 10 (5.0%)
ABN-NCS to WNL | 2 (5.1%) | 6 (5.8%) | 1 (3.2%) | 1 (3.7%) | 10 (5.0%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Shift of Blood Chemistry Interpretations from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Magnesium (mg/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
No Change | 11 (28.2%) | 25 (24.3%) | 6 (19.4%) | 6 (22.2%) | 48 (24.0%)
WNL to WNL | 11 (28.2%) | 24 (23.3%) | 6 (19.4%) | 6 (22.2%) | 47 (23.5%)
ABN-NCS to ABN-NCS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Worsening | 1 (2.6%) | 4 (3.9%) | 1 (3.2%) | 1 (3.7%) | 7 (3.5%)
WNL to ABN-NCS | 1 (2.6%) | 4 (3.9%) | 1 (3.2%) | 1 (3.7%) | 7 (3.5%)
Improvement | 6 (15.4%) | 7 (6.8%) | 1 (3.2%) | 0 | 14 (7.0%)
ABN-NCS to WNL | 6 (15.4%) | 5 (4.9%) | 1 (3.2%) | 0 | 12 (6.0%)
ABN-CS to WNL | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
Days8_14
No Change | 7 (17.9%) | 22 (21.4%) | 4 (12.9%) | 7 (25.9%) | 40 (20.0%)
WNL to WNL | 7 (17.9%) | 22 (21.4%) | 4 (12.9%) | 7 (25.9%) | 40 (20.0%)
Worsening | 2 (5.1%) | 2 (1.9%) | 0 | 0 | 4 (2.0%)
WNL to ABN-NCS | 2 (5.1%) | 2 (1.9%) | 0 | 0 | 4 (2.0%)
Improvement | 4 (10.3%) | 5 (4.9%) | 1 (3.2%) | 0 | 10 (5.0%)
ABN-NCS to WNL | 4 (10.3%) | 3 (2.9%) | 1 (3.2%) | 0 | 8 (4.0%)
ABN-CS to ABN-NCS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
Days15_21
No Change | 7 (17.9%) | 17 (16.5%) | 2 (6.5%) | 4 (14.8%) | 30 (15.0%)
WNL to WNL | 7 (17.9%) | 17 (16.5%) | 2 (6.5%) | 4 (14.8%) | 30 (15.0%)
Worsening | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
WNL to ABN-NCS | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
Improvement | 3 (7.7%) | 4 (3.9%) | 1 (3.2%) | 0 | 8 (4.0%)
ABN-NCS to WNL | 3 (7.7%) | 3 (2.9%) | 1 (3.2%) | 0 | 7 (3.5%)
ABN-CS to WNL | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Days22_28
No Change | 3 (7.7%) | 12 (11.7%) | 1 (3.2%) | 2 (7.4%) | 18 (9.0%)
WNL to WNL | 3 (7.7%) | 12 (11.7%) | 1 (3.2%) | 2 (7.4%) | 18 (9.0%)
Worsening | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
WNL to ABN-NCS | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
Improvement | 3 (7.7%) | 0 | 2 (6.5%) | 0 | 5 (2.5%)
ABN-NCS to WNL | 3 (7.7%) | 0 | 2 (6.5%) | 0 | 5 (2.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Shift of Blood Chemistry Interpretations from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Total Protein (g/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
No Change | 0 | 9 (8.7%) | 3 (9.7%) | 6 (22.2%) | 18 (9.0%)
WNL to WNL | 0 | 4 (3.9%) | 1 (3.2%) | 4 (14.8%) | 9 (4.5%)
ABN-NCS to ABN-NCS | 0 | 2 (1.9%) | 2 (6.5%) | 2 (7.4%) | 6 (3.0%)
ABN-CS to ABN-CS | 0 | 3 (2.9%) | 0 | 0 | 3 (1.5%)
Worsening | 0 | 3 (2.9%) | 0 | 1 (3.7%) | 4 (2.0%)
WNL to ABN-NCS | 0 | 3 (2.9%) | 0 | 1 (3.7%) | 4 (2.0%)
Improvement | 0 | 5 (4.9%) | 1 (3.2%) | 3 (11.1%) | 9 (4.5%)
ABN-NCS to WNL | 0 | 2 (1.9%) | 1 (3.2%) | 2 (7.4%) | 5 (2.5%)
ABN-CS to ABN-NCS | 0 | 2 (1.9%) | 0 | 1 (3.7%) | 3 (1.5%)
ABN-CS to WNL | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Days8_14
No Change | 0 | 9 (8.7%) | 3 (9.7%) | 5 (18.5%) | 17 (8.5%)
WNL to WNL | 0 | 2 (1.9%) | 1 (3.2%) | 2 (7.4%) | 5 (2.5%)
ABN-NCS to ABN-NCS | 0 | 3 (2.9%) | 2 (6.5%) | 3 (11.1%) | 8 (4.0%)
ABN-CS to ABN-CS | 0 | 4 (3.9%) | 0 | 0 | 4 (2.0%)
Worsening | 0 | 4 (3.9%) | 0 | 1 (3.7%) | 5 (2.5%)
WNL to ABN-NCS | 0 | 2 (1.9%) | 0 | 1 (3.7%) | 3 (1.5%)
ABN-NCS to ABN-CS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
Improvement | 0 | 3 (2.9%) | 1 (3.2%) | 1 (3.7%) | 5 (2.5%)
ABN-NCS to WNL | 0 | 1 (1.0%) | 1 (3.2%) | 0 | 2 (1.0%)
ABN-CS to ABN-NCS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
ABN-CS to WNL | 0 | 0 | 0 | 1 (3.7%) | 1 (0.5%)
Days15_21
No Change | 0 | 4 (3.9%) | 0 | 3 (11.1%) | 7 (3.5%)
WNL to WNL | 0 | 1 (1.0%) | 0 | 1 (3.7%) | 2 (1.0%)
ABN-NCS to ABN-NCS | 0 | 1 (1.0%) | 0 | 2 (7.4%) | 3 (1.5%)
ABN-CS to ABN-CS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
Worsening | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
WNL to ABN-NCS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
ABN-NCS to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Improvement | 0 | 3 (2.9%) | 1 (3.2%) | 2 (7.4%) | 6 (3.0%)
ABN-NCS to WNL | 0 | 0 | 1 (3.2%) | 1 (3.7%) | 2 (1.0%)
ABN-CS to ABN-NCS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
ABN-CS to WNL | 0 | 1 (1.0%) | 0 | 1 (3.7%) | 2 (1.0%)
Days22_28
No Change | 1 (2.6%) | 3 (2.9%) | 0 | 1 (3.7%) | 5 (2.5%)
WNL to WNL | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
ABN-NCS to ABN-NCS | 1 (2.6%) | 0 | 0 | 1 (3.7%) | 2 (1.0%)
ABN-CS to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Worsening | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
WNL to ABN-NCS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Improvement | 0 | 2 (1.9%) | 1 (3.2%) | 1 (3.7%) | 4 (2.0%)
ABN-NCS to WNL | 0 | 0 | 1 (3.2%) | 1 (3.7%) | 2 (1.0%)
ABN-CS to ABN-NCS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
ABN-CS to WNL | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Shift of Blood Chemistry Interpretations from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Albumin (g/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
No Change | 5 (12.8%) | 27 (26.2%) | 2 (6.5%) | 7 (25.9%) | 41 (20.5%)
WNL to WNL | 0 | 11 (10.7%) | 1 (3.2%) | 4 (14.8%) | 16 (8.0%)
ABN-NCS to ABN-NCS | 4 (10.3%) | 10 (9.7%) | 1 (3.2%) | 3 (11.1%) | 18 (9.0%)
ABN-CS to ABN-CS | 1 (2.6%) | 6 (5.8%) | 0 | 0 | 7 (3.5%)
Worsening | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
ABN-NCS to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Improvement | 1 (2.6%) | 4 (3.9%) | 3 (9.7%) | 4 (14.8%) | 12 (6.0%)
ABN-NCS to WNL | 1 (2.6%) | 2 (1.9%) | 1 (3.2%) | 2 (7.4%) | 6 (3.0%)
ABN-CS to ABN-NCS | 0 | 2 (1.9%) | 1 (3.2%) | 2 (7.4%) | 5 (2.5%)
ABN-CS to WNL | 0 | 0 | 1 (3.2%) | 0 | 1 (0.5%)
Days8_14
No Change | 3 (7.7%) | 14 (13.6%) | 3 (9.7%) | 6 (22.2%) | 26 (13.0%)
WNL to WNL | 0 | 5 (4.9%) | 2 (6.5%) | 4 (14.8%) | 11 (5.5%)
ABN-NCS to ABN-NCS | 3 (7.7%) | 5 (4.9%) | 1 (3.2%) | 2 (7.4%) | 11 (5.5%)
ABN-CS to ABN-CS | 0 | 4 (3.9%) | 0 | 0 | 4 (2.0%)
Worsening | 0 | 3 (2.9%) | 0 | 0 | 3 (1.5%)
WNL to ABN-NCS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
ABN-NCS to ABN-CS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
Improvement | 0 | 6 (5.8%) | 1 (3.2%) | 2 (7.4%) | 9 (4.5%)
ABN-NCS to WNL | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
ABN-CS to ABN-NCS | 0 | 4 (3.9%) | 1 (3.2%) | 1 (3.7%) | 6 (3.0%)
ABN-CS to WNL | 0 | 1 (1.0%) | 0 | 1 (3.7%) | 2 (1.0%)
Days15_21
No Change | 2 (5.1%) | 10 (9.7%) | 0 | 4 (14.8%) | 16 (8.0%)
WNL to WNL | 0 | 4 (3.9%) | 0 | 2 (7.4%) | 6 (3.0%)
ABN-NCS to ABN-NCS | 2 (5.1%) | 3 (2.9%) | 0 | 2 (7.4%) | 7 (3.5%)
ABN-CS to ABN-CS | 0 | 3 (2.9%) | 0 | 0 | 3 (1.5%)
Worsening | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
WNL to ABN-NCS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Improvement | 1 (2.6%) | 6 (5.8%) | 1 (3.2%) | 2 (7.4%) | 10 (5.0%)
ABN-NCS to WNL | 1 (2.6%) | 2 (1.9%) | 0 | 0 | 3 (1.5%)
ABN-CS to ABN-NCS | 0 | 4 (3.9%) | 1 (3.2%) | 1 (3.7%) | 6 (3.0%)
ABN-CS to WNL | 0 | 0 | 0 | 1 (3.7%) | 1 (0.5%)
Days22_28
No Change | 3 (7.7%) | 3 (2.9%) | 0 | 0 | 6 (3.0%)
WNL to WNL | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
ABN-NCS to ABN-NCS | 3 (7.7%) | 1 (1.0%) | 0 | 0 | 4 (2.0%)
ABN-CS to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Worsening | 1 (2.6%) | 2 (1.9%) | 0 | 0 | 3 (1.5%)
WNL to ABN-NCS | 1 (2.6%) | 2 (1.9%) | 0 | 0 | 3 (1.5%)
Improvement | 0 | 5 (4.9%) | 1 (3.2%) | 2 (7.4%) | 8 (4.0%)
ABN-NCS to WNL | 0 | 3 (2.9%) | 0 | 1 (3.7%) | 4 (2.0%)
ABN-CS to ABN-NCS | 0 | 1 (1.0%) | 0 | 1 (3.7%) | 2 (1.0%)
ABN-CS to WNL | 0 | 1 (1.0%) | 1 (3.2%) | 0 | 2 (1.0%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Table 14.3.4.5.1 Summary of the Extreme Values of Liver Toxicity AST (U/L) by Gestational and Postnatal Age Stratum

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
The Largest Value
N | 26 | 64 | 20 | 21 | 131
Mean (SD) | 46.6 (35.2) | 78.5 (85.4) | 216.9 (739.9) | 166.7 (207.9) | 107.5 (306.6)
95% CI | 32.4, 60.8 | 57.2, 99.9 | −129.4, 563.2 | 72.1, 261.4 | 54.5, 160.4
Median | 38.0 | 45.0 | 44.0 | 105.0 | 45.0
Min, Max | 19.0, 194.0 | 13.0, 419.0 | 11.0, 3358.0 | 22.0, 788.0 | 11.0, 3358.0
The Largest Change from Baseline
N | 2 | 25 | 4 | 12 | 43
Mean (SD) | 5.5 (12.0) | 48.4 (90.4) | −855.8 (1641.5) | 66.4 (192.4) | −32.7 (527.4)
95% CI | −102.5, 113.5 | 11.0, 85.7 | −3468, 1756.3 | −55.8, 188.7 | −195.0, 129.6
Median | 5.5 | 24.0 | −54.0 | 24.5 | 14.0
Min, Max | −3.0, 14.0 | −79.0, 318.0 | −3317, 2.0 | −92.0, 655.0 | −3317, 655.0

Baseline is defined as the assessment taken at pre-dose.

The Largest Value is the maximum from baseline, Days1_7, Days8_14, Days15_21 and Days22_28.

The largest change from from baseline is the maximum value of Days1_7, Days8_14, Days15_21 and Days22_28 minus the baseline value.

Table 14.3.4.5.2 Summary of the Extreme Values of Liver Toxicity ALT (U/L) by Gestational and Postnatal Age Stratum

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
The Largest Value
N | 27 | 65 | 20 | 21 | 133
Mean (SD) | 20.4 (16.5) | 41.0 (41.6) | 82.3 (209.6) | 132.7 (191.8) | 57.5 (119.2)
95% CI | 13.9, 26.9 | 30.7, 51.3 | −15.8, 180.4 | 45.3, 220.0 | 37.1, 77.9
Median | 14.0 | 26.0 | 18.0 | 66.0 | 24.0
Min, Max | 4.0, 74.0 | 4.0, 168.0 | 6.0, 956.0 | 17.0, 746.0 | 4.0, 956.0
The Largest Change from Baseline
N | 2 | 25 | 4 | 13 | 44
Mean (SD) | 11.5 (10.6) | 20.2 (35.7) | −206.3 (420.8) | 51.7 (130.5) | 8.5 (150.8)
95% CI | −83.8, 106.8 | 5.5, 35.0 | −875.8, 463.3 | −27.2, 130.6 | −37.3, 54.4
Median | 11.5 | 7.0 | −6.0 | 10.0 | 8.0
Min, Max | 4.0, 19.0 | −18.0, 118.0 | −837.0, 24.0 | −35.0, 472.0 | −837.0, 472.0

Baseline is defined as the assessment taken at pre-dose.

The Largest Value is the maximum from baseline, Days1_7, Days8_14, Days15_21 and Days22_28.

The largest change from from baseline is the maximum value of Days1_7, Days8_14, Days15_21 and Days22_28 minus the baseline value.

Table 14.3.4.5.3 Summary of the Extreme Values of Liver Toxicity Direct Bilirubin (mg/dL) by Gestational and Postnatal Age Stratum

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
The Largest Value
N | 29 | 61 | 21 | 13 | 124
Mean (SD) | 2.2 (2.2) | 2.6 (2.6) | 0.6 (0.7) | 1.6 (1.4) | 2.0 (2.3)
95% CI | 1.3, 3.0 | 1.9, 3.2 | 0.3, 0.9 | 0.8, 2.5 | 1.6, 2.5
Median | 1.2 | 1.9 | 0.3 | 1.5 | 1.1
Min, Max | 0.0, 9.6 | 0.0, 10.8 | 0.0, 3.1 | 0.1, 4.5 | 0.0, 10.8
The Largest Change from Baseline
N | 12 | 23 | 5 | 6 | 46
Mean (SD) | 1.3 (1.5) | 0.3 (1.6) | 0.6 (0.6) | 0.5 (1.6) | 0.6 (1.5)
95% CI | 0.4, 2.3 | −0.4, 0.9 | −0.2, 1.3 | −1.2, 2.1 | 0.2, 1.0
Median | 1.2 | 0.2 | 0.4 | 0.5 | 0.4
Min, Max | −1.1, 3.7 | −4.2, 3.3 | 0.0, 1.3 | −2.2, 2.2 | −4.2, 3.7

Baseline is defined as the assessment taken at pre-dose.

The Largest Value is the maximum from baseline, Days1_7, Days8_14, Days15_21 and Days22_28.

The largest change from from baseline is the maximum value of Days1_7, Days8_14, Days15_21 and Days22_28 minus the baseline value.

Table 14.3.4.6

Summary of Blood Hematology by Gestational and Postnatal Age Stratum Tests: WBC (x10^9^ /mm^3^)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 39 | 96 | 30 | 24 | 189
Mean (SD) | 19.0 (12.4) | 14.2 (11.4) | 11.2 (6.5) | 14.0 (7.5) | 14.7 (10.8)
95% CI | 15.0, 23.1 | 11.9, 16.5 | 8.8, 13.6 | 10.8, 17.1 | 13.1, 16.2
Median | 16.8 | 11.1 | 10.2 | 11.5 | 11.6
Min, Max | 2.2, 48.3 | 1.3, 73.4 | 2.8, 34.2 | 1.6, 29.4 | 1.3, 73.4
Days1_7
N | 33 | 81 | 21 | 21 | 156
Mean (SD) | 22.4 (10.9) | 16.5 (10.9) | 16.4 (10.3) | 15.3 (5.9) | 17.5 (10.5)
95% CI | 18.5, 26.2 | 14.1, 18.9 | 11.7, 21.1 | 12.6, 18.0 | 15.9, 19.2
Median | 23.7 | 14.2 | 13.5 | 14.0 | 14.6
Min, Max | 2.4, 41.6 | 2.4, 63.1 | 5.9, 55.3 | 6.7, 27.6 | 2.4, 63.1
Days8_14
N | 22 | 55 | 12 | 9 | 98
Mean (SD) | 20.9 (8.8) | 14.3 (7.8) | 16.6 (3.8) | 11.3 (4.6) | 15.8 (8.0)
95% CI | 17.0, 24.8 | 12.2, 16.4 | 14.2, 19.0 | 7.8, 14.8 | 14.2, 17.4
Median | 19.5 | 12.9 | 16.3 | 10.3 | 13.9
Min, Max | 10.2, 40.6 | 5.5, 46.3 | 11.8, 26.0 | 6.1, 21.8 | 5.5, 46.3
Days15_21
N | 20 | 31 | 8 | 5 | 64
Mean (SD) | 19.6 (9.8) | 11.2 (4.7) | 15.0 (6.3) | 9.3 (2.5) | 14.1 (7.7)
95% CI | 15.0, 24.1 | 9.5, 12.9 | 9.7, 20.3 | 6.2, 12.4 | 12.2, 16.1
Median | 15.2 | 9.9 | 15.0 | 8.2 | 11.9
Min, Max | 6.7, 41.4 | 5.6, 28.3 | 8.4, 27.8 | 7.1, 12.9 | 5.6, 41.4
Days22_28
N | 12 | 25 | 3 | 2 | 42
Mean (SD) | 16.1 (10.6) | 12.0 (4.8) | 17.0 (4.4) | 6.9 (0.8) | 13.3 (7.1)
95% CI | 9.3, 22.8 | 10.0, 14.0 | 6.0, 28.0 | −0.7, 14.5 | 11.0, 15.5
Median | 13.4 | 10.6 | 18.2 | 6.9 | 11.0
Min, Max | 8.2, 40.6 | 5.4, 24.9 | 12.1, 20.7 | 6.3, 7.5 | 5.4, 40.6

Summary of Blood Hematology by Gestational and Postnatal Age Stratum Tests: RBC (x10^12^/mm^3^)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 37 | 96 | 30 | 24 | 187
Mean (SD) | 3.9 (0.9) | 3.9 (0.7) | 4.1 (0.7) | 3.7 (0.6) | 3.9 (0.7)
95% CI | 3.7, 4.2 | 3.8, 4.0 | 3.8, 4.3 | 3.4, 4.0 | 3.8, 4.0
Median | 3.9 | 3.9 | 4.0 | 3.5 | 3.9
Min, Max | 2.0, 7.1 | 2.4, 5.7 | 2.9, 5.3 | 2.6, 4.9 | 2.0, 7.1
Days1_7
N | 30 | 81 | 21 | 21 | 153
Mean (SD) | 4.3 (0.7) | 4.1 (0.6) | 3.9 (1.0) | 3.8 (0.8) | 4.0 (0.7)
95% CI | 4.0, 4.5 | 3.9, 4.2 | 3.4, 4.3 | 3.5, 4.2 | 3.9, 4.1
Median | 4.2 | 4.0 | 3.8 | 3.9 | 4.0
Min, Max | 2.9, 5.5 | 2.6, 5.4 | 2.5, 6.2 | 2.3, 5.2 | 2.3, 6.2
Days8_14
N | 20 | 55 | 12 | 9 | 96
Mean (SD) | 3.9 (0.7) | 3.9 (0.7) | 3.9 (0.7) | 3.5 (0.5) | 3.8 (0.7)
95% CI | 3.5, 4.2 | 3.7, 4.0 | 3.4, 4.3 | 3.1, 3.9 | 3.7, 4.0
Median | 3.8 | 3.8 | 3.7 | 3.6 | 3.8
Min, Max | 2.8, 5.8 | 2.6, 5.0 | 3.0, 5.5 | 3.0, 4.4 | 2.6, 5.8
Days15_21
N | 18 | 31 | 8 | 5 | 62
Mean (SD) | 3.9 (0.5) | 3.6 (0.5) | 3.4 (0.7) | 3.5 (0.6) | 3.7 (0.6)
95% CI | 3.6, 4.2 | 3.4, 3.8 | 2.9, 4.0 | 2.8, 4.2 | 3.5, 3.8
Median | 3.9 | 3.5 | 3.3 | 3.8 | 3.7
Min, Max | 2.8, 4.9 | 2.6, 4.8 | 2.5, 4.7 | 2.7, 4.1 | 2.5, 4.9
Days22_28
N | 11 | 25 | 3 | 2 | 41
Mean (SD) | 3.7 (0.4) | 3.8 (0.6) | 3.5 (0.9) | 2.9 (0.1) | 3.7 (0.6)
95% CI | 3.4, 4.0 | 3.5, 4.0 | 1.4, 5.7 | 1.9, 3.9 | 3.5, 3.9
Median | 3.6 | 4.0 | 3.2 | 2.9 | 3.7
Min, Max | 3.1, 4.2 | 2.6, 4.6 | 2.9, 4.5 | 2.8, 3.0 | 2.6, 4.6

Summary of Blood Hematology by Gestational and Postnatal Age Stratum Tests: HGB (g/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 38 | 97 | 30 | 24 | 189
Mean (SD) | 12.4 (2.1) | 11.9 (1.9) | 14.2 (2.6) | 11.2 (2.0) | 12.3 (2.2)
95% CI | 11.7, 13.1 | 11.5, 12.3 | 13.3, 15.2 | 10.4, 12.1 | 12.0, 12.6
Median | 12.6 | 11.9 | 14.5 | 10.9 | 12.1
Min, Max | 5.7, 15.8 | 7.9, 17.4 | 10.5, 18.9 | 7.9, 15.3 | 5.7, 18.9
Days1_7
N | 33 | 83 | 21 | 21 | 158
Mean (SD) | 13.5 (1.8) | 12.2 (1.7) | 13.0 (2.8) | 11.7 (2.2) | 12.5 (2.1)
95% CI | 12.9, 14.2 | 11.8, 12.5 | 11.7, 14.3 | 10.7, 12.7 | 12.2, 12.8
Median | 13.6 | 12.1 | 13.1 | 11.4 | 12.3
Min, Max | 9.8, 16.9 | 8.8, 16.5 | 8.2, 19.3 | 7.7, 15.9 | 7.7, 19.3
Days8_14
N | 26 | 57 | 12 | 11 | 106
Mean (SD) | 11.9 (2.0) | 11.6 (1.8) | 12.4 (2.0) | 13.1 (7.7) | 11.9 (3.0)
95% CI | 11.0, 12.7 | 11.1, 12.1 | 11.1, 13.7 | 7.9, 18.3 | 11.3, 12.5
Median | 11.9 | 11.5 | 12.0 | 11.2 | 11.5
Min, Max | 8.8, 17.7 | 8.0, 15.7 | 9.6, 16.7 | 8.3, 36.0 | 8.0, 36.0
Days15_21
N | 21 | 32 | 9 | 6 | 68
Mean (SD) | 11.7 (2.1) | 10.7 (1.7) | 10.6 (1.8) | 10.8 (1.9) | 11.0 (1.9)
95% CI | 10.8, 12.7 | 10.1, 11.4 | 9.2, 12.0 | 8.9, 12.8 | 10.6, 11.5
Median | 11.8 | 10.6 | 10.2 | 10.6 | 11.0
Min, Max | 7.1, 16.2 | 7.8, 14.2 | 8.2, 14.3 | 8.4, 13.1 | 7.1, 16.2
Days22_28
N | 12 | 26 | 3 | 2 | 43
Mean (SD) | 10.7 (1.2) | 11.7 (4.0) | 10.5 (2.0) | 8.6 (0.4) | 11.2 (3.2)
95% CI | 9.9, 11.4 | 10.1, 13.3 | 5.5, 15.4 | 4.8, 12.4 | 10.2, 12.2
Median | 10.7 | 11.6 | 9.8 | 8.6 | 10.8
Min, Max | 8.6, 12.3 | 7.4, 29.0 | 8.9, 12.7 | 8.3, 8.9 | 7.4, 29.0

Summary of Blood Hematology by Gestational and Postnatal Age Stratum Tests: HCT (%)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 39 | 99 | 30 | 24 | 192
Mean (SD) | 36.0 (5.7) | 34.7 (5.2) | 41.1 (6.9) | 33.2 (5.6) | 35.8 (6.1)
95% CI | 34.1, 37.8 | 33.6, 35.7 | 38.6, 43.7 | 30.9, 35.6 | 34.9, 36.6
Median | 36.3 | 34.7 | 41.9 | 32.1 | 35.2
Min, Max | 17.1, 46.6 | 23.1, 50.0 | 31.0, 55.3 | 22.4, 45.4 | 17.1, 55.3
Days1_7
N | 34 | 88 | 22 | 23 | 167
Mean (SD) | 38.5 (5.1) | 35.5 (4.9) | 37.5 (7.7) | 34.5 (6.2) | 36.2 (5.7)
95% CI | 36.8, 40.3 | 34.4, 36.5 | 34.1, 40.9 | 31.8, 37.1 | 35.3, 37.1
Median | 39.1 | 35.2 | 37.1 | 35.2 | 35.9
Min, Max | 28.6, 48.3 | 26.0, 48.0 | 24.2, 53.5 | 22.0, 46.0 | 22.0, 53.5
Days8_14
N | 28 | 66 | 14 | 16 | 124
Mean (SD) | 35.1 (6.2) | 34.0 (5.2) | 34.8 (6.4) | 30.6 (5.6) | 33.9 (5.7)
95% CI | 32.6, 37.5 | 32.7, 35.3 | 31.0, 38.5 | 27.6, 33.6 | 32.8, 34.9
Median | 34.6 | 33.3 | 34.1 | 32.7 | 33.5
Min, Max | 25.3, 50.6 | 23.5, 46.8 | 25.0, 48.1 | 21.3, 38.6 | 21.3, 50.6
Days15_21
N | 21 | 41 | 10 | 12 | 84
Mean (SD) | 34.4 (5.9) | 31.7 (5.0) | 32.0 (5.5) | 31.2 (4.1) | 32.4 (5.2)
95% CI | 31.7, 37.1 | 30.2, 33.3 | 28.1, 35.9 | 28.7, 33.8 | 31.2, 33.5
Median | 35.5 | 30.9 | 30.5 | 31.2 | 32.0
Min, Max | 21.0, 46.0 | 22.8, 43.0 | 24.5, 41.2 | 26.2, 38.0 | 21.0, 46.0
Days22_28
N | 15 | 30 | 4 | 6 | 55
Mean (SD) | 32.6 (4.8) | 31.9 (4.9) | 30.8 (5.0) | 31.7 (5.8) | 32.0 (4.8)
95% CI | 30.0, 35.3 | 30.1, 33.7 | 22.8, 38.7 | 25.7, 37.7 | 30.7, 33.3
Median | 32.0 | 33.4 | 29.0 | 31.5 | 32.0
Min, Max | 26.0, 44.0 | 22.7, 40.0 | 27.0, 38.0 | 25.7, 39.7 | 22.7, 44.0

Summary of Blood Hematology by Gestational and Postnatal Age Stratum Tests: Platelet Count (x10^3^/mm^3^)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 38 | 97 | 30 | 24 | 189
Mean (SD) | 182.6 (106.0) | 216.7 (150.2) | 216.6 (139.3) | 271.9 (143.5) | 216.8 (140.9)
95% CI | 147.8, 217.5 | 186.4, 247.0 | 164.6, 268.6 | 211.3, 332.5 | 196.6, 237.1
Median | 164.5 | 176.0 | 191.5 | 293.0 | 181.0
Min, Max | 31.0, 490.0 | 33.0, 710.0 | 31.0, 661.0 | 36.0, 594.0 | 31.0, 710.0
Days1_7
N | 32 | 83 | 23 | 20 | 158
Mean (SD) | 163.5 (86.0) | 230.1 (483.9) | 225.3 (146.3) | 301.9 (162.6) | 225.0 (362.6)
95% CI | 132.5, 194.5 | 124.4, 335.7 | 162.0, 288.5 | 225.8, 377.9 | 168.0, 282.0
Median | 151.5 | 141.0 | 152.0 | 362.5 | 151.5
Min, Max | 24.0, 348.0 | 15.0, 4400.0 | 50.0, 575.0 | 48.0, 533.0 | 15.0, 4400.0
Days8_14
N | 23 | 57 | 12 | 10 | 102
Mean (SD) | 198.7 (132.1) | 166.3 (120.2) | 360.4 (215.6) | 229.0 (160.0) | 202.6 (151.5)
95% CI | 141.6, 255.9 | 134.4, 198.2 | 223.4, 497.4 | 114.5, 343.5 | 172.8, 232.3
Median | 174.0 | 130.0 | 339.5 | 199.5 | 159.5
Min, Max | 13.0, 482.0 | 25.0, 653.0 | 50.0, 740.0 | 6.0, 469.0 | 6.0, 740.0
Days15_21
N | 18 | 31 | 8 | 5 | 62
Mean (SD) | 214.7 (122.1) | 197.6 (142.5) | 257.1 (104.2) | 769.2 (1387.5) | 256.4 (406.8)
95% CI | 154.0, 275.4 | 145.3, 249.9 | 170.0, 344.2 | −953.6, 2492.0 | 153.1, 359.7
Median | 183.5 | 156.0 | 237.0 | 152.0 | 176.0
Min, Max | 81.0, 509.0 | 28.0, 607.0 | 174.0, 499.0 | 108.0, 3250.0 | 28.0, 3250.0
Days22_28
N | 11 | 24 | 3 | 3 | 41
Mean (SD) | 248.3 (150.2) | 208.4 (136.5) | 261.7 (31.0) | 279.3 (176.1) | 228.2 (136.3)
95% CI | 147.4, 349.2 | 150.8, 266.0 | 184.6, 338.7 | −158.1, 716.7 | 185.2, 271.2
Median | 187.0 | 199.0 | 249.0 | 192.0 | 225.0
Min, Max | 92.0, 504.0 | 29.0, 562.0 | 239.0, 297.0 | 164.0, 482.0 | 29.0, 562.0

Summary of Blood Hematology by Gestational and Postnatal Age Stratum Tests: Neutrophils (%)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 35 | 90 | 29 | 21 | 175
Mean (SD) | 46.6 (18.4) | 36.2 (20.9) | 37.3 (19.3) | 38.0 (20.1) | 38.7 (20.3)
95% CI | 40.3, 53.0 | 31.9, 40.6 | 29.9, 44.6 | 28.8, 47.1 | 35.7, 41.7
Median | 51.0 | 36.0 | 37.0 | 42.0 | 40.0
Min, Max | 6.0, 74.0 | 3.0, 80.0 | 1.0, 74.7 | 3.0, 69.0 | 1.0, 80.0
Days1_7
N | 26 | 77 | 20 | 20 | 143
Mean (SD) | 50.9 (19.0) | 38.2 (19.4) | 44.1 (14.9) | 42.0 (21.0) | 41.9 (19.4)
95% CI | 43.2, 58.5 | 33.8, 42.6 | 37.1, 51.0 | 32.2, 51.9 | 38.6, 45.1
Median | 55.5 | 35.0 | 46.0 | 42.0 | 42.0
Min, Max | 11.0, 75.0 | 2.9, 88.0 | 1.0, 64.0 | 8.0, 82.4 | 1.0, 88.0
Days8_14
N | 20 | 50 | 12 | 7 | 89
Mean (SD) | 51.1 (13.3) | 41.7 (19.7) | 40.6 (19.2) | 29.3 (9.0) | 42.7 (18.4)
95% CI | 44.8, 57.3 | 36.1, 47.3 | 28.3, 52.8 | 20.9, 37.6 | 38.8, 46.5
Median | 52.8 | 37.0 | 39.5 | 29.0 | 41.0
Min, Max | 16.0, 73.0 | 4.0, 80.0 | 4.0, 72.0 | 18.0, 44.0 | 4.0, 80.0
Days15_21
N | 15 | 28 | 8 | 4 | 55
Mean (SD) | 52.3 (19.1) | 36.7 (18.6) | 36.7 (14.6) | 36.0 (10.1) | 40.9 (18.7)
95% CI | 41.7, 62.8 | 29.5, 43.9 | 24.5, 48.9 | 19.9, 52.1 | 35.8, 45.9
Median | 51.0 | 32.0 | 36.5 | 32.0 | 35.0
Min, Max | 7.0, 87.0 | 1.0, 81.0 | 18.0, 61.6 | 29.0, 51.0 | 1.0, 87.0
Days22_28
N | 9 | 21 | 3 | 2 | 35
Mean (SD) | 42.6 (22.3) | 39.8 (20.6) | 31.7 (20.0) | 33.0 (15.6) | 39.5 (20.2)
95% CI | 25.5, 59.8 | 30.4, 49.2 | −18.1, 81.4 | −106.8, 172.8 | 32.5, 46.4
Median | 42.0 | 39.0 | 33.0 | 33.0 | 39.0
Min, Max | 9.0, 78.0 | 5.8, 83.0 | 11.0, 51.0 | 22.0, 44.0 | 5.8, 83.0

Summary of Blood Hematology by Gestational and Postnatal Age Stratum Tests: Lymphocytes (%)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 35 | 90 | 29 | 21 | 175
Mean (SD) | 27.0 (20.4) | 32.1 (17.2) | 31.6 (14.1) | 38.6 (14.9) | 31.8 (17.3)
95% CI | 20.0, 34.0 | 28.4, 35.7 | 26.2, 36.9 | 31.8, 45.3 | 29.2, 34.3
Median | 18.0 | 30.5 | 29.0 | 38.0 | 29.0
Min, Max | 8.0, 79.4 | 5.0, 77.0 | 11.0, 65.0 | 17.0, 64.0 | 5.0, 79.4
Days1_7
N | 28 | 77 | 20 | 20 | 145
Mean (SD) | 22.0 (15.9) | 33.5 (16.2) | 32.7 (14.4) | 33.8 (16.4) | 31.2 (16.4)
95% CI | 15.8, 28.2 | 29.8, 37.2 | 25.9, 39.4 | 26.1, 41.5 | 28.5, 33.9
Median | 18.5 | 33.0 | 30.5 | 31.5 | 29.0
Min, Max | 3.0, 73.0 | 2.0, 77.0 | 15.0, 68.0 | 9.0, 65.1 | 2.0, 77.0
Days8_14
N | 20 | 51 | 12 | 7 | 90
Mean (SD) | 25.9 (13.0) | 34.4 (17.8) | 38.8 (15.8) | 44.7 (14.2) | 33.9 (16.9)
95% CI | 19.8, 32.0 | 29.3, 39.4 | 28.7, 48.8 | 31.6, 57.8 | 30.3, 37.4
Median | 21.0 | 34.0 | 42.5 | 42.0 | 33.0
Min, Max | 8.0, 56.0 | 4.0, 77.0 | 16.0, 69.0 | 29.0, 68.0 | 4.0, 77.0
Days15_21
N | 16 | 29 | 8 | 4 | 57
Mean (SD) | 22.1 (12.3) | 34.3 (16.5) | 42.3 (10.3) | 33.3 (6.6) | 31.9 (15.4)
95% CI | 15.5, 28.6 | 28.0, 40.5 | 33.7, 50.9 | 22.8, 43.7 | 27.8, 36.0
Median | 23.0 | 32.0 | 43.0 | 34.5 | 29.0
Min, Max | 3.0, 47.0 | 6.0, 66.0 | 27.3, 57.0 | 25.0, 39.0 | 3.0, 66.0
Days22_28
N | 10 | 21 | 3 | 2 | 36
Mean (SD) | 25.9 (19.1) | 34.4 (18.5) | 30.3 (8.1) | 46.5 (7.8) | 32.4 (17.9)
95% CI | 12.3, 39.6 | 26.0, 42.8 | 10.1, 50.6 | −23.4, 116.4 | 26.3, 38.5
Median | 23.0 | 36.0 | 34.0 | 46.5 | 33.0
Min, Max | 2.0, 65.0 | 1.0, 70.0 | 21.0, 36.0 | 41.0, 52.0 | 1.0, 70.0

Summary of Blood Hematology by Gestational and Postnatal Age Stratum Tests: Monocytes (%)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 35 | 90 | 29 | 20 | 174
Mean (SD) | 14.4 (9.1) | 13.2 (6.1) | 14.9 (9.7) | 11.7 (5.3) | 13.6 (7.4)
95% CI | 11.3, 17.6 | 11.9, 14.5 | 11.2, 18.6 | 9.3, 14.2 | 12.5, 14.7
Median | 14.0 | 12.0 | 14.0 | 12.0 | 12.5
Min, Max | 1.1, 37.0 | 2.0, 34.0 | 2.0, 36.0 | 1.0, 23.0 | 1.0, 37.0
Days1_7
N | 28 | 77 | 20 | 19 | 144
Mean (SD) | 14.7 (6.9) | 12.6 (6.5) | 10.7 (5.7) | 10.3 (4.6) | 12.4 (6.4)
95% CI | 12.1, 17.4 | 11.1, 14.0 | 8.0, 13.4 | 8.1, 12.6 | 11.4, 13.5
Median | 14.0 | 12.0 | 10.3 | 10.0 | 12.0
Min, Max | 3.0, 33.0 | 1.0, 33.0 | 3.0, 26.0 | 2.0, 19.0 | 1.0, 33.0
Days8_14
N | 20 | 51 | 12 | 7 | 90
Mean (SD) | 15.7 (9.6) | 12.1 (5.9) | 13.5 (5.1) | 15.0 (6.6) | 13.3 (6.9)
95% CI | 11.2, 20.2 | 10.4, 13.8 | 10.3, 16.8 | 8.9, 21.1 | 11.9, 14.8
Median | 12.0 | 12.0 | 13.5 | 16.0 | 12.0
Min, Max | 1.0, 42.0 | 0.6, 28.0 | 7.0, 26.0 | 5.0, 25.0 | 0.6, 42.0
Days15_21
N | 16 | 29 | 8 | 4 | 57
Mean (SD) | 17.0 (9.7) | 15.2 (7.9) | 12.4 (4.2) | 12.5 (7.9) | 15.1 (8.0)
95% CI | 11.8, 22.2 | 12.2, 18.2 | 8.9, 15.9 | −0.1, 25.1 | 13.0, 17.3
Median | 16.0 | 13.0 | 10.5 | 10.0 | 13.0
Min, Max | 4.0, 48.0 | 1.0, 39.0 | 8.0, 19.0 | 6.0, 24.0 | 1.0, 48.0
Days22_28
N | 10 | 21 | 3 | 2 | 36
Mean (SD) | 15.8 (10.8) | 14.7 (7.2) | 19.7 (5.9) | 7.0 (2.8) | 15.0 (8.2)
95% CI | 8.1, 23.5 | 11.4, 17.9 | 5.1, 34.2 | −18.4, 32.4 | 12.2, 17.8
Median | 17.2 | 14.0 | 22.0 | 7.0 | 13.5
Min, Max | 2.0, 28.0 | 5.0, 33.0 | 13.0, 24.0 | 5.0, 9.0 | 2.0, 33.0

Summary of Blood Hematology by Gestational and Postnatal Age Stratum Tests: Eosinophils (%)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 33 | 86 | 28 | 20 | 167
Mean (SD) | 2.5 (2.1) | 6.4 (7.0) | 3.1 (3.7) | 3.4 (2.7) | 4.7 (5.7)
95% CI | 1.8, 3.2 | 4.8, 7.9 | 1.7, 4.6 | 2.2, 4.7 | 3.8, 5.6
Median | 2.0 | 4.0 | 2.6 | 3.0 | 3.0
Min, Max | 0.0, 7.0 | 0.0, 27.0 | 0.0, 15.0 | 0.0, 9.3 | 0.0, 27.0
Days1_7
N | 26 | 73 | 19 | 19 | 137
Mean (SD) | 4.6 (6.0) | 6.9 (10.4) | 4.4 (5.1) | 4.2 (3.9) | 5.8 (8.4)
95% CI | 2.2, 7.0 | 4.5, 9.4 | 2.0, 6.9 | 2.3, 6.0 | 4.3, 7.2
Median | 2.5 | 4.0 | 2.0 | 3.0 | 4.0
Min, Max | 0.0, 26.0 | 0.0, 69.0 | 0.0, 21.0 | 0.0, 16.0 | 0.0, 69.0
Days8_14
N | 19 | 49 | 12 | 7 | 87
Mean (SD) | 2.3 (2.8) | 4.6 (4.9) | 4.0 (5.9) | 5.3 (3.0) | 4.0 (4.6)
95% CI | 1.0, 3.6 | 3.2, 6.0 | 0.2, 7.7 | 2.5, 8.0 | 3.1, 5.0
Median | 1.0 | 3.0 | 2.1 | 5.0 | 2.0
Min, Max | 0.0, 9.9 | 0.0, 23.0 | 0.0, 22.0 | 2.0, 10.0 | 0.0, 23.0
Days15_21
N | 16 | 29 | 7 | 4 | 56
Mean (SD) | 5.3 (5.2) | 5.5 (5.6) | 2.4 (1.4) | 6.5 (3.3) | 5.2 (5.0)
95% CI | 2.6, 8.1 | 3.4, 7.6 | 1.1, 3.7 | 1.2, 11.8 | 3.8, 6.5
Median | 4.0 | 4.0 | 2.0 | 6.0 | 4.0
Min, Max | 0.0, 17.0 | 0.0, 19.0 | 1.0, 5.0 | 3.0, 11.0 | 0.0, 19.0
Days22_28
N | 9 | 19 | 3 | 2 | 33
Mean (SD) | 4.5 (4.2) | 5.2 (4.4) | 5.7 (3.1) | 3.5 (4.9) | 5.0 (4.1)
95% CI | 1.3, 7.8 | 3.1, 7.3 | −1.9, 13.3 | −41.0, 48.0 | 3.5, 6.4
Median | 3.0 | 5.0 | 5.0 | 3.5 | 4.0
Min, Max | 0.0, 10.7 | 0.0, 17.0 | 3.0, 9.0 | 0.0, 7.0 | 0.0, 17.0

Summary of Blood Hematology by Gestational and Postnatal Age Stratum Tests: Basophils (%)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 28 | 70 | 27 | 14 | 139
Mean (SD) | 0.3 (0.5) | 0.3 (0.7) | 0.3 (0.6) | 0.2 (0.4) | 0.3 (0.6)
95% CI | 0.1, 0.5 | 0.2, 0.5 | 0.1, 0.6 | 0.0, 0.4 | 0.2, 0.4
Median | 0.0 | 0.0 | 0.0 | 0.0 | 0.0
Min, Max | 0.0, 2.0 | 0.0, 4.0 | 0.0, 2.0 | 0.0, 1.0 | 0.0, 4.0
Days1_7
N | 20 | 58 | 15 | 16 | 109
Mean (SD) | 0.2 (0.4) | 0.3 (0.8) | 0.1 (0.3) | 0.1 (0.2) | 0.2 (0.6)
95% CI | 0.0, 0.4 | 0.1, 0.5 | −0.1, 0.2 | −0.1, 0.2 | 0.1, 0.3
Median | 0.0 | 0.0 | 0.0 | 0.0 | 0.0
Min, Max | 0.0, 1.0 | 0.0, 5.0 | 0.0, 1.0 | 0.0, 1.0 | 0.0, 5.0
Days8_14
N | 15 | 40 | 10 | 5 | 70
Mean (SD) | 0.7 (0.7) | 0.1 (0.3) | 0.2 (0.3) | 1.2 (1.3) | 0.3 (0.6)
95% CI | 0.3, 1.1 | 0.0, 0.3 | 0.0, 0.4 | −0.4, 2.8 | 0.2, 0.5
Median | 0.9 | 0.0 | 0.0 | 1.0 | 0.0
Min, Max | 0.0, 2.0 | 0.0, 1.0 | 0.0, 1.0 | 0.0, 3.0 | 0.0, 3.0
Days15_21
N | 11 | 23 | 6 | 4 | 44
Mean (SD) | 0.1 (0.3) | 0.4 (0.6) | 0.4 (0.5) | 0.5 (0.6) | 0.3 (0.6)
95% CI | −0.1, 0.3 | 0.1, 0.7 | −0.2, 0.9 | −0.4, 1.4 | 0.2, 0.5
Median | 0.0 | 0.0 | 0.1 | 0.5 | 0.0
Min, Max | 0.0, 1.0 | 0.0, 2.0 | 0.0, 1.0 | 0.0, 1.0 | 0.0, 2.0
Days22_28
N | 8 | 18 | 2 | 2 | 30
Mean (SD) | 0.3 (0.7) | 0.0 (0.1) | 0.0 (0.0) | 0.5 (0.7) | 0.1 (0.4)
95% CI | −0.3, 0.8 | 0.0, 0.1 | ., . | −5.9, 6.9 | 0.0, 0.3
Median | 0.0 | 0.0 | 0.0 | 0.5 | 0.0
Min, Max | 0.0, 2.0 | 0.0, 0.5 | 0.0, 0.0 | 0.0, 1.0 | 0.0, 2.0

Summary of Blood Hematology by Gestational and Postnatal Age Stratum Tests: Bands (%)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 32 | 77 | 25 | 16 | 150
Mean (SD) | 7.0 (7.4) | 9.0 (9.7) | 11.8 (12.3) | 7.1 (7.6) | 8.8 (9.6)
95% CI | 4.3, 9.6 | 6.8, 11.2 | 6.8, 16.9 | 3.0, 11.1 | 7.3, 10.4
Median | 5.0 | 7.0 | 4.0 | 4.5 | 5.5
Min, Max | 0.0, 31.0 | 0.0, 47.0 | 0.0, 40.0 | 0.0, 29.0 | 0.0, 47.0
Days1_7
N | 26 | 68 | 18 | 17 | 129
Mean (SD) | 6.2 (6.2) | 6.3 (7.7) | 7.5 (6.6) | 6.9 (9.0) | 6.5 (7.4)
95% CI | 3.7, 8.7 | 4.5, 8.2 | 4.2, 10.8 | 2.3, 11.6 | 5.3, 7.8
Median | 4.0 | 4.0 | 5.5 | 4.0 | 4.0
Min, Max | 0.0, 22.0 | 0.0, 34.0 | 0.0, 19.0 | 0.0, 32.0 | 0.0, 34.0
Days8_14
N | 17 | 40 | 8 | 7 | 72
Mean (SD) | 3.2 (2.8) | 5.9 (6.6) | 3.3 (3.6) | 3.4 (3.0) | 4.7 (5.4)
95% CI | 1.7, 4.6 | 3.8, 8.0 | 0.3, 6.2 | 0.7, 6.2 | 3.4, 6.0
Median | 4.0 | 4.5 | 2.5 | 3.0 | 4.0
Min, Max | 0.0, 9.0 | 0.0, 32.0 | 0.0, 9.0 | 0.0, 9.0 | 0.0, 32.0
Days15_21
N | 12 | 23 | 6 | 4 | 45
Mean (SD) | 5.8 (5.4) | 5.0 (6.9) | 5.0 (4.1) | 4.8 (6.9) | 5.2 (6.0)
95% CI | 2.4, 9.2 | 2.0, 8.0 | 0.7, 9.3 | −6.2, 15.7 | 3.4, 7.0
Median | 5.0 | 3.0 | 3.0 | 2.0 | 3.0
Min, Max | 0.0, 15.0 | 0.0, 33.0 | 2.0, 12.0 | 0.0, 15.0 | 0.0, 33.0
Days22_28
N | 9 | 18 | 3 | 2 | 32
Mean (SD) | 7.7 (6.3) | 3.1 (2.9) | 9.7 (11.6) | 3.0 (1.4) | 5.0 (5.5)
95% CI | 2.8, 12.5 | 1.7, 4.5 | −19.1, 38.5 | −9.7, 15.7 | 3.0, 7.0
Median | 6.0 | 2.5 | 4.0 | 3.0 | 3.0
Min, Max | 1.0, 17.0 | 0.0, 10.0 | 2.0, 23.0 | 2.0, 4.0 | 0.0, 23.0

Table 14.3.4.7

Summary of Change of Blood Hematology by Gestational and Postnatal Age Stratum Tests: WBC (x10^9^ /mm^3^)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 33 | 77 | 21 | 18 | 149
Mean (SD) | 2.5 (10.8) | 1.3 (9.2) | 4.4 (11.9) | 0.8 (6.3) | 1.9 (9.7)
95% CI | −1.4, 6.3 | −0.8, 3.4 | −1.0, 9.9 | −2.3, 4.0 | 0.4, 3.5
Median | 2.6 | 0.2 | 1.4 | 0.6 | 0.7
Min, Max | −22.5, 22.7 | −34.6, 29.4 | −13.3, 46.9 | −13.0, 10.5 | −34.6, 46.9
Days8_14
N | 22 | 53 | 12 | 8 | 95
Mean (SD) | −0.4 (13.0) | −0.9 (11.5) | 3.7 (9.2) | −0.6 (9.8) | −0.2 (11.4)
95% CI | −6.2, 5.4 | −4.1, 2.2 | −2.2, 9.5 | −8.8, 7.5 | −2.5, 2.1
Median | −2.1 | −0.4 | 3.7 | 1.2 | 0.7
Min, Max | −24.3, 25.9 | −41.8, 36.5 | −22.1, 13.9 | −21.6, 11.0 | −41.8, 36.5
Days15_21
N | 20 | 31 | 8 | 4 | 63
Mean (SD) | −2.9 (13.6) | −2.7 (8.9) | 6.7 (7.8) | 3.1 (1.9) | −1.2 (10.6)
95% CI | −9.3, 3.4 | −6.0, 0.6 | 0.2, 13.2 | 0.1, 6.1 | −3.9, 1.5
Median | −2.5 | −2.6 | 4.4 | 2.3 | −0.8
Min, Max | −34.9, 17.0 | −29.6, 21.1 | −4.4, 22.1 | 1.9, 5.9 | −34.9, 22.1
Days22_28
N | 12 | 23 | 3 | 1 | 39
Mean (SD) | −11.2 (18.7) | −3.2 (9.8) | 6.1 (11.2) | 4.7 | −4.8 (13.8)
95% CI | −23.1, 0.7 | −7.4, 1.0 | −21.6, 33.9 | | −9.2, −0.3
Median | −7.8 | −3.6 | 9.8 | 4.7 | −4.1
Min, Max | −37.9, 13.9 | −30.2, 11.3 | −6.4, 15.0 | 4.7, 4.7 | −37.9, 15.0

Change from baseline is the follow-up value minus the baseline value.

Summary of Change of Blood Hematology by Gestational and Postnatal Age Stratum Tests: RBC (x10^12^/mm^3^)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 30 | 77 | 21 | 18 | 146
Mean (SD) | 0.4 (1.0) | 0.1 (0.7) | −0.2 (0.8) | 0.2 (0.6) | 0.1 (0.8)
95% CI | 0.1, 0.8 | −0.1, 0.3 | −0.5, 0.2 | −0.1, 0.5 | 0.0, 0.3
Median | 0.2 | 0.1 | 0.0 | 0.2 | 0.1
Min, Max | −0.7, 3.6 | −1.6, 2.2 | −1.5, 1.2 | −0.9, 1.2 | −1.6, 3.6
Days8_14
N | 20 | 53 | 12 | 8 | 93
Mean (SD) | −0.2 (0.9) | 0.0 (0.8) | −0.2 (0.6) | −0.3 (0.6) | −0.1 (0.8)
95% CI | −0.6, 0.3 | −0.3, 0.2 | −0.6, 0.2 | −0.8, 0.3 | −0.3, 0.1
Median | −0.2 | −0.1 | 0.1 | −0.4 | −0.2
Min, Max | −1.7, 1.8 | −1.6, 1.6 | −1.3, 0.4 | −1.1, 0.7 | −1.7, 1.8
Days15_21
N | 18 | 31 | 8 | 4 | 61
Mean (SD) | 0.0 (0.8) | −0.3 (0.8) | −0.4 (0.7) | 0.2 (0.5) | −0.2 (0.8)
95% CI | −0.4, 0.4 | −0.5, 0.0 | −1.0, 0.2 | −0.7, 1.0 | −0.4, 0.0
Median | −0.2 | −0.2 | −0.6 | 0.1 | −0.2
Min, Max | −1.8, 1.4 | −1.5, 1.2 | −1.2, 0.7 | −0.4, 0.9 | −1.8, 1.4
Days22_28
N | 11 | 23 | 3 | 1 | 38
Mean (SD) | −0.2 (0.5) | −0.3 (0.8) | −0.6 (1.6) | −0.2 | −0.3 (0.8)
95% CI | −0.6, 0.1 | −0.6, 0.1 | −4.4, 3.3 | | −0.5, 0.0
Median | −0.2 | −0.2 | −0.9 | −0.2 | −0.2
Min, Max | −1.4, 0.8 | −1.8, 1.0 | −1.9, 1.1 | −0.2, −0.2 | −1.9, 1.1

Change from baseline is the follow-up value minus the baseline value.

Summary of Change of Blood Hematology by Gestational and Postnatal Age Stratum Tests: HGB (g/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 32 | 80 | 21 | 18 | 151
Mean (SD) | 1.3 (2.7) | 0.3 (2.1) | −0.9 (2.9) | 0.5 (1.8) | 0.3 (2.4)
95% CI | 0.3, 2.3 | −0.2, 0.7 | −2.2, 0.4 | −0.5, 1.4 | −0.1, 0.7
Median | 0.9 | 0.1 | −0.1 | 0.4 | 0.2
Min, Max | −1.8, 10.2 | −4.9, 6.2 | −6.3, 3.5 | −3.0, 3.5 | −6.3, 10.2
Days8_14
N | 25 | 56 | 12 | 10 | 103
Mean (SD) | −0.7 (2.7) | −0.2 (2.3) | −1.4 (2.2) | 1.6 (8.5) | −0.3 (3.5)
95% CI | −1.8, 0.4 | −0.9, 0.4 | −2.8, 0.0 | −4.5, 7.7 | −1.0, 0.4
Median | −0.6 | −0.5 | −0.8 | −1.1 | −0.6
Min, Max | −4.7, 5.1 | −5.5, 5.2 | −5.7, 0.9 | −3.9, 25.5 | −5.7, 25.5
Days15_21
N | 20 | 32 | 9 | 5 | 66
Mean (SD) | −0.7 (2.4) | −1.0 (2.2) | −2.3 (2.2) | −0.6 (1.7) | −1.0 (2.3)
95% CI | −1.8, 0.4 | −1.8, −0.2 | −4.0, −0.6 | −2.7, 1.5 | −1.6, −0.5
Median | −1.1 | −1.1 | −1.5 | −1.4 | −1.3
Min, Max | −6.8, 2.8 | −4.8, 2.6 | −5.7, 0.5 | −2.3, 2.0 | −6.8, 2.8
Days22_28
N | 12 | 24 | 3 | 1 | 40
Mean (SD) | −1.7 (1.2) | −0.3 (4.5) | −3.0 (5.2) | −2.6 | −1.0 (3.8)
95% CI | −2.5, −0.9 | −2.2, 1.6 | −15.9, 10.0 | | −2.2, 0.2
Median | −1.5 | −0.6 | −2.9 | −2.6 | −1.3
Min, Max | −4.7, 0.6 | −5.4, 17.6 | −8.2, 2.2 | −2.6, −2.6 | −8.2, 17.6

Change from baseline is the follow-up value minus the baseline value.

Summary of Change of Blood Hematology by Gestational and Postnatal Age Stratum Tests: HCT (%)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 34 | 85 | 22 | 20 | 161
Mean (SD) | 3.1 (7.6) | 0.9 (5.7) | −2.9 (7.8) | 1.2 (5.4) | 0.9 (6.6)
95% CI | 0.5, 5.8 | −0.3, 2.1 | −6.3, 0.6 | −1.3, 3.8 | −0.1, 1.9
Median | 1.5 | 0.5 | −0.4 | 2.3 | 0.5
Min, Max | −7.3, 30.0 | −10.0, 16.6 | −16.7, 10.0 | −8.9, 9.7 | −16.7, 30.0
Days8_14
N | 28 | 65 | 14 | 14 | 121
Mean (SD) | −1.3 (8.2) | −0.1 (6.5) | −5.4 (7.7) | −3.1 (6.5) | −1.3 (7.2)
95% CI | −4.5, 1.8 | −1.7, 1.5 | −9.9, −1.0 | −6.8, 0.6 | −2.6, −0.1
Median | −0.6 | −0.6 | −3.9 | −4.0 | −1.1
Min, Max | −14.8, 14.3 | −12.7, 16.8 | −22.0, 3.5 | −15.0, 7.0 | −22.0, 16.8
Days15_21
N | 21 | 40 | 10 | 10 | 81
Mean (SD) | −2.0 (7.3) | −2.6 (6.6) | −7.1 (6.5) | −1.2 (4.2) | −2.8 (6.7)
95% CI | −5.3, 1.4 | −4.7, −0.5 | −11.7, −2.5 | −4.2, 1.8 | −4.3, −1.3
Median | −3.0 | −2.7 | −7.0 | −3.0 | −3.0
Min, Max | −18.5, 11.0 | −14.0, 9.3 | −16.0, 2.8 | −6.1, 5.4 | −18.5, 11.0
Days22_28
N | 15 | 29 | 4 | 5 | 53
Mean (SD) | −2.9 (5.0) | −3.5 (6.6) | −10.7 (12.2) | −0.3 (3.3) | −3.6 (6.7)
95% CI | −5.6, −0.1 | −6.0, −1.0 | −30.1, 8.7 | −4.4, 3.9 | −5.4, −1.7
Median | −4.0 | −3.1 | −13.5 | 0.0 | −3.5
Min, Max | −13.7, 9.0 | −16.0, 8.4 | −22.0, 6.0 | −5.7, 3.4 | −22.0, 9.0

Change from baseline is the follow-up value minus the baseline value.

Summary of Change of Blood Hematology by Gestational and Postnatal Age Stratum Tests: Platelet Count (x10^3^/mm^3^)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 31 | 80 | 23 | 17 | 151
Mean (SD) | −10.5 (82.1) | −23.8 (83.1) | 16.2 (75.8) | 79.5 (139.9) | −3.4 (94.8)
95% CI | −40.6, 19.6 | −42.3, −5.3 | −16.6, 49.0 | 7.6, 151.5 | −18.6, 11.9
Median | 7.0 | −8.0 | 9.0 | 69.0 | 0.0
Min, Max | −239.0, 116.0 | −262.0, 177.0 | −137.0, 254.0 | −117.0, 370.0 | −262.0, 370.0
Days8_14
N | 22 | 55 | 12 | 9 | 98
Mean (SD) | 49.7 (119.8) | −11.4 (106.9) | 138.0 (118.4) | 26.9 (170.9) | 24.1 (126.2)
95% CI | −3.5, 102.8 | −40.3, 17.5 | 62.8, 213.2 | −104.4, 158.2 | −1.2, 49.4
Median | 47.5 | −12.0 | 122.0 | 63.0 | 17.0
Min, Max | −285.0, 242.0 | −281.0, 317.0 | −45.0, 341.0 | −354.0, 267.0 | −354.0, 341.0
Days15_21
N | 17 | 31 | 8 | 4 | 60
Mean (SD) | 48.1 (146.9) | 20.8 (136.3) | 133.9 (130.0) | 718.3 (1528.0) | 90.1 (407.5)
95% CI | −27.5, 123.6 | −29.2, 70.8 | 25.2, 242.6 | −1713, 3149.7 | −15.2, 195.4
Median | 42.0 | 19.0 | 116.5 | 4.5 | 32.0
Min, Max | −229.0, 393.0 | −289.0, 303.0 | −13.0, 381.0 | −142.0, 3006.0 | −289.0, 3006.0
Days22_28
N | 10 | 23 | 3 | 2 | 38
Mean (SD) | 60.2 (165.1) | 24.1 (130.4) | 126.3 (84.3) | 125.0 (4.2) | 47.0 (135.4)
95% CI | −57.9, 178.3 | −32.3, 80.5 | −83.1, 335.8 | 86.9, 163.1 | 2.5, 91.5
Median | 60.5 | 18.0 | 149.0 | 125.0 | 32.0
Min, Max | −236.0, 384.0 | −247.0, 366.0 | 33.0, 197.0 | 122.0, 128.0 | −247.0, 384.0

Change from baseline is the follow-up value minus the baseline value.

Summary of Change of Blood Hematology by Gestational and Postnatal Age Stratum Tests: Neutrophils (%)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 26 | 70 | 19 | 15 | 130
Mean (SD) | 5.4 (15.4) | −0.6 (18.7) | 10.2 (17.7) | 2.6 (19.9) | 2.6 (18.3)
95% CI | −0.8, 11.6 | −5.0, 3.9 | 1.7, 18.8 | −8.5, 13.6 | −0.6, 5.8
Median | 4.5 | −0.5 | 6.0 | 1.0 | 2.0
Min, Max | −29.0, 38.0 | −49.0, 56.0 | −10.0, 48.0 | −20.0, 63.8 | −49.0, 63.8
Days8_14
N | 18 | 44 | 12 | 6 | 80
Mean (SD) | 0.2 (14.0) | 4.6 (21.0) | 4.1 (24.0) | −3.3 (18.3) | 3.0 (19.8)
95% CI | −6.7, 7.2 | −1.8, 11.0 | −11.2, 19.3 | −22.5, 15.9 | −1.4, 7.4
Median | −1.6 | 3.0 | 3.0 | −8.0 | 1.0
Min, Max | −34.0, 29.5 | −38.0, 72.4 | −41.4, 48.4 | −19.0, 27.0 | −41.4, 72.4
Days15_21
N | 14 | 26 | 8 | 3 | 51
Mean (SD) | 4.0 (14.6) | −8.0 (24.0) | 9.2 (12.4) | 2.7 (28.2) | −1.4 (21.1)
95% CI | −4.4, 12.4 | −17.7, 1.7 | −1.1, 19.5 | −67.3, 72.7 | −7.3, 4.6
Median | 3.5 | −13.5 | 4.0 | 12.0 | 0.0
Min, Max | −19.0, 29.0 | −42.0, 47.0 | −5.0, 28.0 | −29.0, 25.0 | −42.0, 47.0
Days22_28
N | 8 | 19 | 3 | 1 | 31
Mean (SD) | −2.7 (15.3) | −8.2 (21.6) | 2.7 (34.8) | 18.0 | −4.9 (21.1)
95% CI | −15.5, 10.1 | −18.6, 2.2 | −83.9, 89.2 | | −12.6, 2.9
Median | −2.5 | −12.0 | −3.0 | 18.0 | −8.0
Min, Max | −22.0, 23.0 | −59.2, 31.0 | −29.0, 40.0 | 18.0, 18.0 | −59.2, 40.0

Change from baseline is the follow-up value minus the baseline value.

Summary of Change of Blood Hematology by Gestational and Postnatal Age Stratum Tests: Lymphocytes (%)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 27 | 70 | 19 | 15 | 131
Mean (SD) | −4.8 (12.8) | 3.3 (14.7) | 0.0 (14.1) | −2.9 (16.8) | 0.4 (14.7)
95% CI | −9.9, 0.2 | −0.2, 6.8 | −6.8, 6.8 | −12.2, 6.4 | −2.1, 3.0
Median | −4.0 | 3.5 | 2.0 | −2.0 | 1.0
Min, Max | −37.0, 18.0 | −29.0, 39.0 | −27.0, 19.0 | −47.3, 21.0 | −47.3, 39.0
Days8_14
N | 18 | 45 | 12 | 6 | 81
Mean (SD) | 1.9 (15.6) | 4.8 (15.4) | 10.5 (12.7) | 7.8 (19.2) | 5.2 (15.3)
95% CI | −5.9, 9.7 | 0.1, 9.4 | 2.4, 18.5 | −12.3, 28.0 | 1.8, 8.6
Median | 6.0 | 2.0 | 11.1 | 12.5 | 5.0
Min, Max | −45.2, 22.0 | −21.0, 48.0 | −11.0, 32.8 | −28.0, 27.0 | −45.2, 48.0
Days15_21
N | 15 | 27 | 8 | 3 | 53
Mean (SD) | −3.3 (16.2) | 8.5 (19.3) | 5.5 (17.4) | −10.3 (24.6) | 3.6 (18.9)
95% CI | −12.3, 5.7 | 0.8, 16.1 | −9.0, 20.0 | −71.4, 50.7 | −1.6, 8.8
Median | −5.0 | 9.0 | 1.5 | −23.0 | 3.0
Min, Max | −38.9, 26.0 | −27.0, 53.0 | −12.7, 32.0 | −26.0, 18.0 | −38.9, 53.0
Days22_28
N | 8 | 19 | 3 | 1 | 31
Mean (SD) | 1.7 (22.6) | 10.7 (18.4) | 3.3 (14.8) | −5.0 | 7.2 (18.9)
95% CI | −17.2, 20.6 | 1.8, 19.6 | −33.5, 40.2 | | 0.2, 14.1
Median | 4.5 | 12.0 | 7.0 | −5.0 | 10.0
Min, Max | −39.2, 37.0 | −21.0, 42.0 | −13.0, 16.0 | −5.0, −5.0 | −39.2, 42.0

Change from baseline is the follow-up value minus the baseline value.

Summary of Change of Blood Hematology by Gestational and Postnatal Age Stratum Tests: Monocytes (%)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 27 | 70 | 19 | 14 | 130
Mean (SD) | 0.1 (8.9) | −0.4 (8.2) | −3.4 (9.2) | −0.7 (5.6) | −0.8 (8.3)
95% CI | −3.4, 3.6 | −2.4, 1.6 | −7.9, 1.0 | −3.9, 2.5 | −2.2, 0.7
Median | 1.0 | −1.0 | −2.0 | 1.0 | −1.0
Min, Max | −19.0, 16.0 | −18.0, 22.0 | −26.0, 11.0 | −12.0, 7.0 | −26.0, 22.0
Days8_14
N | 18 | 45 | 12 | 6 | 81
Mean (SD) | 1.6 (10.8) | −2.1 (8.9) | −0.4 (9.5) | −0.2 (10.5) | −0.9 (9.5)
95% CI | −3.8, 6.9 | −4.8, 0.5 | −6.5, 5.6 | −11.1, 10.8 | −3.0, 1.2
Median | 0.5 | −2.0 | −1.5 | 2.5 | −1.0
Min, Max | −18.0, 28.0 | −28.0, 17.5 | −22.0, 15.0 | −18.0, 13.0 | −28.0, 28.0
Days15_21
N | 15 | 27 | 8 | 3 | 53
Mean (SD) | −0.3 (10.5) | 2.6 (11.1) | 1.6 (9.5) | 2.0 (8.9) | 1.6 (10.4)
95% CI | −6.1, 5.5 | −1.8, 7.0 | −6.3, 9.6 | −20.1, 24.1 | −1.3, 4.5
Median | 3.0 | 0.0 | 3.0 | −1.0 | 1.0
Min, Max | −20.0, 16.1 | −17.0, 30.0 | −11.9, 15.0 | −5.0, 12.0 | −20.0, 30.0
Days22_28
N | 8 | 19 | 3 | 1 | 31
Mean (SD) | −3.2 (16.4) | 3.0 (8.0) | 5.3 (6.0) | −3.0 | 1.4 (10.6)
95% CI | −16.9, 10.5 | −0.8, 6.9 | −9.6, 20.3 | | −2.4, 5.3
Median | −7.0 | 4.0 | 6.0 | −3.0 | 3.0
Min, Max | −27.0, 21.2 | −11.0, 18.7 | −1.0, 11.0 | −3.0, −3.0 | −27.0, 21.2

Change from baseline is the follow-up value minus the baseline value.

Summary of Change of Blood Hematology by Gestational and Postnatal Age Stratum Tests: Eosinophils (%)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 23 | 66 | 17 | 14 | 120
Mean (SD) | 2.2 (6.9) | 1.2 (10.3) | 0.6 (5.9) | 1.0 (5.0) | 1.3 (8.7)
95% CI | −0.8, 5.2 | −1.4, 3.7 | −2.4, 3.6 | −1.9, 3.8 | −0.3, 2.8
Median | 0.0 | 0.0 | 0.0 | 0.0 | 0.0
Min, Max | −7.0, 26.0 | −21.1, 64.0 | −8.0, 17.0 | −8.3, 11.0 | −21.1, 64.0
Days8_14
N | 15 | 43 | 11 | 6 | 75
Mean (SD) | 0.2 (3.8) | −1.5 (7.1) | −0.1 (8.7) | 1.7 (1.8) | −0.7 (6.6)
95% CI | −2.0, 2.3 | −3.7, 0.7 | −6.0, 5.8 | −0.2, 3.5 | −2.2, 0.8
Median | 0.0 | 0.0 | −0.2 | 1.0 | 0.0
Min, Max | −7.0, 8.3 | −26.5, 7.0 | −15.0, 21.5 | 0.0, 5.0 | −26.5, 21.5
Days15_21
N | 14 | 25 | 7 | 3 | 49
Mean (SD) | 3.1 (4.7) | 1.0 (5.2) | −2.2 (6.0) | 1.3 (4.0) | 1.2 (5.2)
95% CI | 0.4, 5.8 | −1.1, 3.2 | −7.8, 3.4 | −8.7, 11.4 | −0.3, 2.7
Median | 1.0 | 0.0 | 1.0 | 2.0 | 0.0
Min, Max | −1.0, 11.8 | −9.0, 13.0 | −14.0, 2.0 | −3.0, 5.0 | −14.0, 13.0
Days22_28
N | 8 | 17 | 3 | 1 | 29
Mean (SD) | 2.5 (3.2) | 0.8 (6.5) | 2.3 (6.4) | −2.0 | 1.3 (5.6)
95% CI | −0.2, 5.2 | −2.6, 4.1 | −13.6, 18.3 | | −0.8, 3.4
Median | 1.5 | 2.0 | 5.0 | −2.0 | 2.0
Min, Max | 0.0, 9.1 | −17.0, 13.0 | −5.0, 7.0 | −2.0, −2.0 | −17.0, 13.0

Change from baseline is the follow-up value minus the baseline value.

Summary of Change of Blood Hematology by Gestational and Postnatal Age Stratum Tests: Basophils (%)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 19 | 48 | 14 | 9 | 90
Mean (SD) | −0.1 (0.4) | 0.0 (1.0) | −0.1 (0.4) | −0.1 (0.3) | −0.1 (0.8)
95% CI | −0.3, 0.1 | −0.3, 0.3 | −0.3, 0.1 | −0.4, 0.1 | −0.2, 0.1
Median | 0.0 | 0.0 | 0.0 | 0.0 | 0.0
Min, Max | −1.0, 1.0 | −4.0, 5.0 | −1.0, 0.3 | −1.0, 0.0 | −4.0, 5.0
Days8_14
N | 12 | 30 | 9 | 2 | 53
Mean (SD) | 0.5 (0.7) | −0.1 (0.5) | −0.1 (0.4) | 1.0 (1.4) | 0.1 (0.6)
95% CI | 0.1, 0.9 | −0.3, 0.1 | −0.4, 0.2 | −11.7, 13.7 | −0.1, 0.3
Median | 0.0 | 0.0 | 0.0 | 1.0 | 0.0
Min, Max | 0.0, 2.0 | −2.0, 1.0 | −1.0, 0.3 | 0.0, 2.0 | −2.0, 2.0
Days15_21
N | 11 | 17 | 6 | 1 | 35
Mean (SD) | −0.1 (0.5) | 0.1 (0.8) | 0.1 (0.5) | 0.0 | 0.0 (0.6)
95% CI | −0.5, 0.2 | −0.3, 0.5 | −0.5, 0.6 | | −0.2, 0.3
Median | 0.0 | 0.0 | 0.0 | 0.0 | 0.0
Min, Max | −1.0, 1.0 | −1.0, 2.0 | −0.6, 1.0 | 0.0, 0.0 | −1.0, 2.0
Days22_28
N | 7 | 14 | 2 | 0 | 23
Mean (SD) | 0.1 (0.4) | −0.1 (0.4) | 0.0 (0.0) | | 0.0 (0.4)
95% CI | −0.2, 0.5 | −0.4, 0.1 | ., . | | −0.2, 0.1
Median | 0.0 | 0.0 | 0.0 | | 0.0
Min, Max | 0.0, 1.0 | −1.0, 0.0 | 0.0, 0.0 | | −1.0, 1.0

Change from baseline is the follow-up value minus the baseline value.

Summary of Change of Blood Hematology by Gestational and Postnatal Age Stratum Tests: Bands (%)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 25 | 59 | 16 | 13 | 113
Mean (SD) | −2.3 (7.9) | −3.5 (9.4) | −7.3 (9.6) | −0.6 (8.2) | −3.4 (9.1)
95% CI | −5.5, 1.0 | −6.0, −1.0 | −12.4, −2.1 | −5.6, 4.3 | −5.1, −1.7
Median | −1.0 | −2.0 | −3.5 | 0.0 | −2.0
Min, Max | −25.0, 13.0 | −43.0, 16.0 | −30.0, 1.0 | −14.0, 21.0 | −43.0, 21.0
Days8_14
N | 16 | 35 | 8 | 6 | 65
Mean (SD) | −3.4 (7.6) | −5.2 (11.4) | −9.1 (13.8) | −4.2 (6.0) | −5.2 (10.4)
95% CI | −7.5, 0.6 | −9.1, −1.3 | −20.7, 2.4 | −10.4, 2.1 | −7.7, −2.6
Median | −1.5 | −5.0 | −4.0 | −5.0 | −4.0
Min, Max | −25.0, 4.0 | −40.0, 21.0 | −32.0, 2.0 | −12.0, 5.0 | −40.0, 21.0
Days15_21
N | 11 | 21 | 5 | 3 | 40
Mean (SD) | 1.5 (5.6) | −5.7 (13.1) | −17.6 (10.4) | −3.3 (4.2) | −5.0 (11.9)
95% CI | −2.3, 5.2 | −11.6, 0.3 | −30.5, −4.7 | −13.7, 7.0 | −8.8, −1.2
Median | 2.0 | −3.0 | −17.0 | −2.0 | −2.0
Min, Max | −10.0, 10.0 | −46.0, 18.0 | −30.0, −6.0 | −8.0, 0.0 | −46.0, 18.0
Days22_28
N | 7 | 15 | 3 | 1 | 26
Mean (SD) | 1.1 (8.8) | −8.1 (13.0) | −7.7 (20.3) | 0.0 | −5.2 (12.8)
95% CI | −7.0, 9.3 | −15.3, −0.9 | −58.1, 42.8 | | −10.4, −0.1
Median | 1.0 | −5.0 | 2.0 | 0.0 | −0.5
Min, Max | −15.0, 14.0 | −42.0, 7.0 | −31.0, 6.0 | 0.0, 0.0 | −42.0, 14.0

Change from baseline is the follow-up value minus the baseline value.

Table 14.3.4.8

Summary of Blood Hematology Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: WBC (x10^9^ /mm^3^)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participan | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
WNL | 26 (66.7%) | 68 (66.0%) | 22 (71.0%) | 16 (59.3%) | 132 (66.0%)
ABN-NCS | 6 (15.4%) | 8 (7.8%) | 4 (12.9%) | 5 (18.5%) | 23 (11.5%)
ABN-CS | 7 (17.9%) | 20 (19.4%) | 4 (12.9%) | 3 (11.1%) | 34 (17.0%)
Days1_7
WNL | 16 (41.0%) | 57 (55.3%) | 16 (51.6%) | 17 (63.0%) | 106 (53.0%)
ABN-NCS | 11 (28.2%) | 13 (12.6%) | 3 (9.7%) | 1 (3.7%) | 28 (14.0%)
ABN-CS | 6 (15.4%) | 10 (9.7%) | 2 (6.5%) | 3 (11.1%) | 21 (10.5%)
Days8_14
WNL | 12 (30.8%) | 44 (42.7%) | 10 (32.3%) | 7 (25.9%) | 73 (36.5%)
ABN-NCS | 8 (20.5%) | 9 (8.7%) | 1 (3.2%) | 2 (7.4%) | 20 (10.0%)
ABN-CS | 2 (5.1%) | 2 (1.9%) | 1 (3.2%) | 0 | 5 (2.5%)
Days15_21
WNL | 14 (35.9%) | 27 (26.2%) | 7 (22.6%) | 5 (18.5%) | 53 (26.5%)
ABN-NCS | 6 (15.4%) | 4 (3.9%) | 0 | 0 | 10 (5.0%)
ABN-CS | 0 | 0 | 1 (3.2%) | 0 | 1 (0.5%)
Days22_28
WNL | 9 (23.1%) | 21 (20.4%) | 1 (3.2%) | 2 (7.4%) | 33 (16.5%)
ABN-NCS | 3 (7.7%) | 4 (3.9%) | 1 (3.2%) | 0 | 8 (4.0%)
ABN-CS | 0 | 0 | 1 (3.2%) | 0 | 1 (0.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Blood Hematology Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: RBC (x10^12^/mm^3^)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participan | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
WNL | 20 (51.3%) | 66 (64.1%) | 20 (64.5%) | 14 (51.9%) | 120 (60.0%)
ABN-NCS | 10 (25.6%) | 23 (22.3%) | 9 (29.0%) | 9 (33.3%) | 51 (25.5%)
ABN-CS | 7 (17.9%) | 7 (6.8%) | 1 (3.2%) | 1 (3.7%) | 16 (8.0%)
Days1_7
WNL | 21 (53.8%) | 64 (62.1%) | 13 (41.9%) | 16 (59.3%) | 114 (57.0%)
ABN-NCS | 8 (20.5%) | 15 (14.6%) | 8 (25.8%) | 2 (7.4%) | 33 (16.5%)
ABN-CS | 1 (2.6%) | 2 (1.9%) | 0 | 2 (7.4%) | 5 (2.5%)
Days8_14
WNL | 9 (23.1%) | 42 (40.8%) | 7 (22.6%) | 8 (29.6%) | 66 (33.0%)
ABN-NCS | 8 (20.5%) | 13 (12.6%) | 5 (16.1%) | 1 (3.7%) | 27 (13.5%)
ABN-CS | 2 (5.1%) | 0 | 0 | 0 | 2 (1.0%)
Days15_21
WNL | 10 (25.6%) | 21 (20.4%) | 4 (12.9%) | 3 (11.1%) | 38 (19.0%)
ABN-NCS | 8 (20.5%) | 10 (9.7%) | 3 (9.7%) | 1 (3.7%) | 22 (11.0%)
ABN-CS | 0 | 0 | 1 (3.2%) | 0 | 1 (0.5%)
Days22_28
WNL | 6 (15.4%) | 15 (14.6%) | 1 (3.2%) | 0 | 22 (11.0%)
ABN-NCS | 4 (10.3%) | 9 (8.7%) | 2 (6.5%) | 1 (3.7%) | 16 (8.0%)
ABN-CS | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Blood Hematology Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: HGB (g/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participan | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
WNL | 15 (38.5%) | 61 (59.2%) | 18 (58.1%) | 12 (44.4%) | 106 (53.0%)
ABN-NCS | 14 (35.9%) | 27 (26.2%) | 10 (32.3%) | 9 (33.3%) | 60 (30.0%)
ABN-CS | 9 (23.1%) | 9 (8.7%) | 2 (6.5%) | 3 (11.1%) | 23 (11.5%)
Days1_7
WNL | 16 (41.0%) | 59 (57.3%) | 11 (35.5%) | 11 (40.7%) | 97 (48.5%)
ABN-NCS | 15 (38.5%) | 19 (18.4%) | 10 (32.3%) | 7 (25.9%) | 51 (25.5%)
ABN-CS | 2 (5.1%) | 5 (4.9%) | 0 | 2 (7.4%) | 9 (4.5%)
Days8_14
WNL | 8 (20.5%) | 38 (36.9%) | 4 (12.9%) | 7 (25.9%) | 57 (28.5%)
ABN-NCS | 11 (28.2%) | 14 (13.6%) | 7 (22.6%) | 3 (11.1%) | 35 (17.5%)
ABN-CS | 6 (15.4%) | 5 (4.9%) | 1 (3.2%) | 1 (3.7%) | 13 (6.5%)
Days15_21
WNL | 8 (20.5%) | 20 (19.4%) | 3 (9.7%) | 3 (11.1%) | 34 (17.0%)
ABN-NCS | 11 (28.2%) | 9 (8.7%) | 5 (16.1%) | 2 (7.4%) | 27 (13.5%)
ABN-CS | 2 (5.1%) | 3 (2.9%) | 1 (3.2%) | 0 | 6 (3.0%)
Days22_28
WNL | 5 (12.8%) | 15 (14.6%) | 1 (3.2%) | 0 | 21 (10.5%)
ABN-NCS | 6 (15.4%) | 9 (8.7%) | 2 (6.5%) | 1 (3.7%) | 18 (9.0%)
ABN-CS | 1 (2.6%) | 2 (1.9%) | 0 | 0 | 3 (1.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Blood Hematology Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: HCT (%)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participan | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
WNL | 13 (33.3%) | 55 (53.4%) | 17 (54.8%) | 13 (48.1%) | 98 (49.0%)
ABN-NCS | 19 (48.7%) | 34 (33.0%) | 10 (32.3%) | 8 (29.6%) | 71 (35.5%)
ABN-CS | 7 (17.9%) | 10 (9.7%) | 2 (6.5%) | 3 (11.1%) | 22 (11.0%)
Days1_7
WNL | 15 (38.5%) | 60 (58.3%) | 10 (32.3%) | 12 (44.4%) | 97 (48.5%)
ABN-NCS | 17 (43.6%) | 25 (24.3%) | 11 (35.5%) | 8 (29.6%) | 61 (30.5%)
ABN-CS | 2 (5.1%) | 3 (2.9%) | 1 (3.2%) | 2 (7.4%) | 8 (4.0%)
Days8_14
WNL | 9 (23.1%) | 39 (37.9%) | 5 (16.1%) | 6 (22.2%) | 59 (29.5%)
ABN-NCS | 13 (33.3%) | 22 (21.4%) | 7 (22.6%) | 7 (25.9%) | 49 (24.5%)
ABN-CS | 5 (12.8%) | 5 (4.9%) | 2 (6.5%) | 3 (11.1%) | 15 (7.5%)
Days15_21
WNL | 7 (17.9%) | 20 (19.4%) | 4 (12.9%) | 4 (14.8%) | 35 (17.5%)
ABN-NCS | 13 (33.3%) | 20 (19.4%) | 5 (16.1%) | 6 (22.2%) | 44 (22.0%)
ABN-CS | 1 (2.6%) | 1 (1.0%) | 1 (3.2%) | 1 (3.7%) | 4 (2.0%)
Days22_28
WNL | 7 (17.9%) | 16 (15.5%) | 0 | 2 (7.4%) | 25 (12.5%)
ABN-NCS | 7 (17.9%) | 10 (9.7%) | 4 (12.9%) | 3 (11.1%) | 24 (12.0%)
ABN-CS | 1 (2.6%) | 4 (3.9%) | 0 | 0 | 5 (2.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Blood Hematology Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Platelet Count (x10^3^/mm^3^)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participan | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
WNL | 20 (51.3%) | 47 (45.6%) | 16 (51.6%) | 17 (63.0%) | 100 (50.0%)
ABN-NCS | 9 (23.1%) | 29 (28.2%) | 8 (25.8%) | 4 (14.8%) | 50 (25.0%)
ABN-CS | 9 (23.1%) | 21 (20.4%) | 6 (19.4%) | 3 (11.1%) | 39 (19.5%)
Days1_7
WNL | 16 (41.0%) | 29 (28.2%) | 11 (35.5%) | 10 (37.0%) | 66 (33.0%)
ABN-NCS | 11 (28.2%) | 30 (29.1%) | 8 (25.8%) | 7 (25.9%) | 56 (28.0%)
ABN-CS | 6 (15.4%) | 24 (23.3%) | 3 (9.7%) | 2 (7.4%) | 35 (17.5%)
Days8_14
WNL | 11 (28.2%) | 23 (22.3%) | 5 (16.1%) | 4 (14.8%) | 43 (21.5%)
ABN-NCS | 9 (23.1%) | 22 (21.4%) | 6 (19.4%) | 6 (22.2%) | 43 (21.5%)
ABN-CS | 3 (7.7%) | 12 (11.7%) | 1 (3.2%) | 0 | 16 (8.0%)
Days15_21
WNL | 9 (23.1%) | 14 (13.6%) | 7 (22.6%) | 3 (11.1%) | 33 (16.5%)
ABN-NCS | 7 (17.9%) | 11 (10.7%) | 1 (3.2%) | 1 (3.7%) | 20 (10.0%)
ABN-CS | 2 (5.1%) | 6 (5.8%) | 0 | 0 | 8 (4.0%)
Days22_28
WNL | 4 (10.3%) | 9 (8.7%) | 3 (9.7%) | 2 (7.4%) | 18 (9.0%)
ABN-NCS | 6 (15.4%) | 8 (7.8%) | 0 | 1 (3.7%) | 15 (7.5%)
ABN-CS | 1 (2.6%) | 6 (5.8%) | 0 | 0 | 7 (3.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Blood Hematology Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Neutrophils (%)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participan | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
WNL | 23 (59.0%) | 51 (49.5%) | 23 (74.2%) | 17 (63.0%) | 114 (57.0%)
ABN-NCS | 9 (23.1%) | 24 (23.3%) | 3 (9.7%) | 3 (11.1%) | 39 (19.5%)
ABN-CS | 3 (7.7%) | 14 (13.6%) | 3 (9.7%) | 1 (3.7%) | 21 (10.5%)
Days1_7
WNL | 15 (38.5%) | 48 (46.6%) | 18 (58.1%) | 12 (44.4%) | 93 (46.5%)
ABN-NCS | 8 (20.5%) | 25 (24.3%) | 2 (6.5%) | 6 (22.2%) | 41 (20.5%)
ABN-CS | 3 (7.7%) | 4 (3.9%) | 0 | 1 (3.7%) | 8 (4.0%)
Days8_14
WNL | 12 (30.8%) | 35 (34.0%) | 9 (29.0%) | 6 (22.2%) | 62 (31.0%)
ABN-NCS | 7 (17.9%) | 14 (13.6%) | 3 (9.7%) | 0 | 24 (12.0%)
ABN-CS | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
Days15_21
WNL | 6 (15.4%) | 15 (14.6%) | 7 (22.6%) | 4 (14.8%) | 32 (16.0%)
ABN-NCS | 8 (20.5%) | 12 (11.7%) | 1 (3.2%) | 0 | 21 (10.5%)
ABN-CS | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
Days22_28
WNL | 3 (7.7%) | 14 (13.6%) | 2 (6.5%) | 2 (7.4%) | 21 (10.5%)
ABN-NCS | 6 (15.4%) | 6 (5.8%) | 1 (3.2%) | 0 | 13 (6.5%)
ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Blood Hematology Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Lymphocytes (%)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participan | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
WNL | 15 (38.5%) | 51 (49.5%) | 25 (80.6%) | 17 (63.0%) | 108 (54.0%)
ABN-NCS | 18 (46.2%) | 30 (29.1%) | 4 (12.9%) | 3 (11.1%) | 55 (27.5%)
ABN-CS | 2 (5.1%) | 8 (7.8%) | 0 | 1 (3.7%) | 11 (5.5%)
Days1_7
WNL | 9 (23.1%) | 43 (41.7%) | 17 (54.8%) | 13 (48.1%) | 82 (41.0%)
ABN-NCS | 17 (43.6%) | 29 (28.2%) | 3 (9.7%) | 5 (18.5%) | 54 (27.0%)
ABN-CS | 2 (5.1%) | 5 (4.9%) | 0 | 1 (3.7%) | 8 (4.0%)
Days8_14
WNL | 10 (25.6%) | 34 (33.0%) | 8 (25.8%) | 6 (22.2%) | 58 (29.0%)
ABN-NCS | 9 (23.1%) | 16 (15.5%) | 4 (12.9%) | 1 (3.7%) | 30 (15.0%)
ABN-CS | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
Days15_21
WNL | 8 (20.5%) | 15 (14.6%) | 8 (25.8%) | 3 (11.1%) | 34 (17.0%)
ABN-NCS | 7 (17.9%) | 13 (12.6%) | 0 | 1 (3.7%) | 21 (10.5%)
ABN-CS | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
Days22_28
WNL | 4 (10.3%) | 13 (12.6%) | 1 (3.2%) | 2 (7.4%) | 20 (10.0%)
ABN-NCS | 6 (15.4%) | 8 (7.8%) | 2 (6.5%) | 0 | 16 (8.0%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Blood Hematology Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Monocytes (%)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participan | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
WNL | 20 (51.3%) | 58 (56.3%) | 20 (64.5%) | 17 (63.0%) | 115 (57.5%)
ABN-NCS | 12 (30.8%) | 29 (28.2%) | 8 (25.8%) | 3 (11.1%) | 52 (26.0%)
ABN-CS | 3 (7.7%) | 3 (2.9%) | 1 (3.2%) | 0 | 7 (3.5%)
Days1_7
WNL | 18 (46.2%) | 53 (51.5%) | 18 (58.1%) | 17 (63.0%) | 106 (53.0%)
ABN-NCS | 9 (23.1%) | 23 (22.3%) | 2 (6.5%) | 1 (3.7%) | 35 (17.5%)
ABN-CS | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
Days8_14
WNL | 10 (25.6%) | 37 (35.9%) | 9 (29.0%) | 4 (14.8%) | 60 (30.0%)
ABN-NCS | 9 (23.1%) | 14 (13.6%) | 3 (9.7%) | 2 (7.4%) | 28 (14.0%)
ABN-CS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
Days15_21
WNL | 9 (23.1%) | 19 (18.4%) | 7 (22.6%) | 3 (11.1%) | 38 (19.0%)
ABN-NCS | 7 (17.9%) | 10 (9.7%) | 1 (3.2%) | 1 (3.7%) | 19 (9.5%)
Days22_28
WNL | 6 (15.4%) | 9 (8.7%) | 1 (3.2%) | 2 (7.4%) | 18 (9.0%)
ABN-NCS | 4 (10.3%) | 12 (11.7%) | 2 (6.5%) | 0 | 18 (9.0%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Blood Hematology Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Eosinophils (%)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participan | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
WNL | 28 (71.8%) | 54 (52.4%) | 26 (83.9%) | 16 (59.3%) | 124 (62.0%)
ABN-NCS | 4 (10.3%) | 27 (26.2%) | 2 (6.5%) | 3 (11.1%) | 36 (18.0%)
ABN-CS | 1 (2.6%) | 5 (4.9%) | 0 | 1 (3.7%) | 7 (3.5%)
Days1_7
WNL | 21 (53.8%) | 46 (44.7%) | 16 (51.6%) | 14 (51.9%) | 97 (48.5%)
ABN-NCS | 4 (10.3%) | 26 (25.2%) | 4 (12.9%) | 3 (11.1%) | 37 (18.5%)
ABN-CS | 1 (2.6%) | 1 (1.0%) | 0 | 1 (3.7%) | 3 (1.5%)
Days8_14
WNL | 17 (43.6%) | 34 (33.0%) | 10 (32.3%) | 5 (18.5%) | 66 (33.0%)
ABN-NCS | 2 (5.1%) | 15 (14.6%) | 2 (6.5%) | 2 (7.4%) | 21 (10.5%)
Days15_21
WNL | 11 (28.2%) | 19 (18.4%) | 7 (22.6%) | 2 (7.4%) | 39 (19.5%)
ABN-NCS | 5 (12.8%) | 10 (9.7%) | 0 | 2 (7.4%) | 17 (8.5%)
Days22_28
WNL | 7 (17.9%) | 11 (10.7%) | 2 (6.5%) | 2 (7.4%) | 22 (11.0%)
ABN-NCS | 2 (5.1%) | 8 (7.8%) | 1 (3.2%) | 0 | 11 (5.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Blood Hematology Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Basophils (%)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participan | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
WNL | 27 (69.2%) | 67 (65.0%) | 27 (87.1%) | 14 (51.9%) | 135 (67.5%)
ABN-NCS | 1 (2.6%) | 4 (3.9%) | 0 | 0 | 5 (2.5%)
Days1_7
WNL | 20 (51.3%) | 57 (55.3%) | 15 (48.4%) | 15 (55.6%) | 107 (53.5%)
ABN-NCS | 1 (2.6%) | 3 (2.9%) | 0 | 0 | 4 (2.0%)
Days8_14
WNL | 16 (41.0%) | 38 (36.9%) | 10 (32.3%) | 4 (14.8%) | 68 (34.0%)
ABN-NCS | 0 | 2 (1.9%) | 0 | 1 (3.7%) | 3 (1.5%)
Days15_21
WNL | 10 (25.6%) | 21 (20.4%) | 6 (19.4%) | 4 (14.8%) | 41 (20.5%)
ABN-NCS | 1 (2.6%) | 2 (1.9%) | 0 | 0 | 3 (1.5%)
Days22_28
WNL | 8 (20.5%) | 18 (17.5%) | 2 (6.5%) | 2 (7.4%) | 30 (15.0%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Blood Hematology Interpretations by Scheduled Visit, Gestational and Postnatal Age Stratum Tests: Bands (%)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participan | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
WNL | 22 (56.4%) | 47 (45.6%) | 16 (51.6%) | 14 (51.9%) | 99 (49.5%)
ABN-NCS | 4 (10.3%) | 12 (11.7%) | 3 (9.7%) | 2 (7.4%) | 21 (10.5%)
ABN-CS | 6 (15.4%) | 18 (17.5%) | 6 (19.4%) | 0 | 30 (15.0%)
Days1_7
WNL | 20 (51.3%) | 53 (51.5%) | 15 (48.4%) | 12 (44.4%) | 100 (50.0%)
ABN-NCS | 3 (7.7%) | 10 (9.7%) | 1 (3.2%) | 3 (11.1%) | 17 (8.5%)
ABN-CS | 3 (7.7%) | 5 (4.9%) | 2 (6.5%) | 1 (3.7%) | 11 (5.5%)
Days8_14
WNL | 13 (33.3%) | 28 (27.2%) | 7 (22.6%) | 6 (22.2%) | 54 (27.0%)
ABN-NCS | 4 (10.3%) | 11 (10.7%) | 1 (3.2%) | 1 (3.7%) | 17 (8.5%)
ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Days15_21
WNL | 7 (17.9%) | 16 (15.5%) | 5 (16.1%) | 3 (11.1%) | 31 (15.5%)
ABN-NCS | 5 (12.8%) | 6 (5.8%) | 1 (3.2%) | 0 | 12 (6.0%)
ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Days22_28
WNL | 7 (17.9%) | 15 (14.6%) | 2 (6.5%) | 2 (7.4%) | 26 (13.0%)
ABN-NCS | 2 (5.1%) | 2 (1.9%) | 1 (3.2%) | 0 | 5 (2.5%)
ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Table 14.3.4.9

Summary of Shift of Blood Hematology Interpretations from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: WBC (x10^9^ /mm^3^)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
No Change | 17 (43.6%) | 55 (53.4%) | 11 (35.5%) | 10 (37.0%) | 93 (46.5%)
WNL to WNL | 12 (30.8%) | 47 (45.6%) | 11 (35.5%) | 10 (37.0%) | 80 (40.0%)
ABN-NCS to ABN-NCS | 3 (7.7%) | 4 (3.9%) | 0 | 0 | 7 (3.5%)
ABN-CS to ABN-CS | 2 (5.1%) | 4 (3.9%) | 0 | 0 | 6 (3.0%)
Worsening | 9 (23.1%) | 7 (6.8%) | 4 (12.9%) | 3 (11.1%) | 23 (11.5%)
WNL to ABN-NCS | 5 (12.8%) | 2 (1.9%) | 2 (6.5%) | 0 | 9 (4.5%)
WNL to ABN-CS | 3 (7.7%) | 3 (2.9%) | 1 (3.2%) | 1 (3.7%) | 8 (4.0%)
ABN-NCS to ABN-CS | 1 (2.6%) | 2 (1.9%) | 1 (3.2%) | 2 (7.4%) | 6 (3.0%)
Improvement | 7 (17.9%) | 14 (13.6%) | 6 (19.4%) | 5 (18.5%) | 32 (16.0%)
ABN-NCS to WNL | 2 (5.1%) | 1 (1.0%) | 2 (6.5%) | 2 (7.4%) | 7 (3.5%)
ABN-CS to ABN-NCS | 3 (7.7%) | 6 (5.8%) | 1 (3.2%) | 1 (3.7%) | 11 (5.5%)
ABN-CS to WNL | 2 (5.1%) | 7 (6.8%) | 3 (9.7%) | 2 (7.4%) | 14 (7.0%)
Days8_14
No Change | 12 (30.8%) | 30 (29.1%) | 6 (19.4%) | 5 (18.5%) | 53 (26.5%)
WNL to WNL | 8 (20.5%) | 29 (28.2%) | 6 (19.4%) | 5 (18.5%) | 48 (24.0%)
ABN-NCS to ABN-NCS | 3 (7.7%) | 0 | 0 | 0 | 3 (1.5%)
ABN-CS to ABN-CS | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
Worsening | 4 (10.3%) | 7 (6.8%) | 2 (6.5%) | 1 (3.7%) | 14 (7.0%)
WNL to ABN-NCS | 3 (7.7%) | 6 (5.8%) | 1 (3.2%) | 1 (3.7%) | 11 (5.5%)
WNL to ABN-CS | 1 (2.6%) | 1 (1.0%) | 1 (3.2%) | 0 | 3 (1.5%)
Improvement | 6 (15.4%) | 16 (15.5%) | 4 (12.9%) | 2 (7.4%) | 28 (14.0%)
ABN-NCS to WNL | 1 (2.6%) | 6 (5.8%) | 2 (6.5%) | 0 | 9 (4.5%)
ABN-CS to ABN-NCS | 2 (5.1%) | 2 (1.9%) | 0 | 1 (3.7%) | 5 (2.5%)
ABN-CS to WNL | 3 (7.7%) | 8 (7.8%) | 2 (6.5%) | 1 (3.7%) | 14 (7.0%)
Days15_21
No Change | 10 (25.6%) | 21 (20.4%) | 6 (19.4%) | 3 (11.1%) | 40 (20.0%)
WNL to WNL | 8 (20.5%) | 21 (20.4%) | 5 (16.1%) | 3 (11.1%) | 37 (18.5%)
ABN-NCS to ABN-NCS | 2 (5.1%) | 0 | 0 | 0 | 2 (1.0%)
ABN-CS to ABN-CS | 0 | 0 | 1 (3.2%) | 0 | 1 (0.5%)
Worsening | 1 (2.6%) | 2 (1.9%) | 0 | 0 | 3 (1.5%)
WNL to ABN-NCS | 1 (2.6%) | 2 (1.9%) | 0 | 0 | 3 (1.5%)
Improvement | 9 (23.1%) | 8 (7.8%) | 2 (6.5%) | 1 (3.7%) | 20 (10.0%)
ABN-NCS to WNL | 3 (7.7%) | 1 (1.0%) | 1 (3.2%) | 0 | 5 (2.5%)
ABN-CS to ABN-NCS | 3 (7.7%) | 2 (1.9%) | 0 | 0 | 5 (2.5%)
ABN-CS to WNL | 3 (7.7%) | 5 (4.9%) | 1 (3.2%) | 1 (3.7%) | 10 (5.0%)
Days22_28
No Change | 4 (10.3%) | 12 (11.7%) | 1 (3.2%) | 0 | 17 (8.5%)
WNL to WNL | 3 (7.7%) | 12 (11.7%) | 1 (3.2%) | 0 | 16 (8.0%)
ABN-NCS to ABN-NCS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
Worsening | 0 | 2 (1.9%) | 1 (3.2%) | 0 | 3 (1.5%)
WNL to ABN-NCS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
ABN-NCS to ABN-CS | 0 | 0 | 1 (3.2%) | 0 | 1 (0.5%)
Improvement | 8 (20.5%) | 9 (8.7%) | 1 (3.2%) | 1 (3.7%) | 19 (9.5%)
ABN-NCS to WNL | 2 (5.1%) | 2 (1.9%) | 0 | 0 | 4 (2.0%)
ABN-CS to ABN-NCS | 2 (5.1%) | 2 (1.9%) | 1 (3.2%) | 0 | 5 (2.5%)
ABN-CS to WNL | 4 (10.3%) | 5 (4.9%) | 0 | 1 (3.7%) | 10 (5.0%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Shift of Blood Hematology Interpretations from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: RBC (x10^12^/mm^3^)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
No Change | 16 (41.0%) | 56 (54.4%) | 14 (45.2%) | 13 (48.1%) | 99 (49.5%)
WNL to WNL | 13 (33.3%) | 46 (44.7%) | 10 (32.3%) | 11 (40.7%) | 80 (40.0%)
ABN-NCS to ABN-NCS | 3 (7.7%) | 8 (7.8%) | 4 (12.9%) | 2 (7.4%) | 17 (8.5%)
ABN-CS to ABN-CS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
Worsening | 3 (7.7%) | 6 (5.8%) | 4 (12.9%) | 1 (3.7%) | 14 (7.0%)
WNL to ABN-NCS | 2 (5.1%) | 6 (5.8%) | 4 (12.9%) | 0 | 12 (6.0%)
WNL to ABN-CS | 0 | 0 | 0 | 1 (3.7%) | 1 (0.5%)
ABN-NCS to ABN-CS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
Improvement | 11 (28.2%) | 15 (14.6%) | 3 (9.7%) | 4 (14.8%) | 33 (16.5%)
ABN-NCS to WNL | 4 (10.3%) | 10 (9.7%) | 2 (6.5%) | 3 (11.1%) | 19 (9.5%)
ABN-CS to ABN-NCS | 3 (7.7%) | 0 | 0 | 0 | 3 (1.5%)
ABN-CS to WNL | 4 (10.3%) | 5 (4.9%) | 1 (3.2%) | 1 (3.7%) | 11 (5.5%)
Days8_14
No Change | 9 (23.1%) | 40 (38.8%) | 5 (16.1%) | 6 (22.2%) | 60 (30.0%)
WNL to WNL | 6 (15.4%) | 33 (32.0%) | 4 (12.9%) | 6 (22.2%) | 49 (24.5%)
ABN-NCS to ABN-NCS | 1 (2.6%) | 7 (6.8%) | 1 (3.2%) | 0 | 9 (4.5%)
ABN-CS to ABN-CS | 2 (5.1%) | 0 | 0 | 0 | 2 (1.0%)
Worsening | 5 (12.8%) | 5 (4.9%) | 3 (9.7%) | 0 | 13 (6.5%)
WNL to ABN-NCS | 5 (12.8%) | 5 (4.9%) | 3 (9.7%) | 0 | 13 (6.5%)
Improvement | 5 (12.8%) | 8 (7.8%) | 4 (12.9%) | 2 (7.4%) | 19 (9.5%)
ABN-NCS to WNL | 3 (7.7%) | 7 (6.8%) | 3 (9.7%) | 1 (3.7%) | 14 (7.0%)
ABN-CS to ABN-NCS | 2 (5.1%) | 0 | 1 (3.2%) | 0 | 3 (1.5%)
ABN-CS to WNL | 0 | 1 (1.0%) | 0 | 1 (3.7%) | 2 (1.0%)
Days15_21
No Change | 9 (23.1%) | 23 (22.3%) | 6 (19.4%) | 2 (7.4%) | 40 (20.0%)
WNL to WNL | 6 (15.4%) | 18 (17.5%) | 3 (9.7%) | 2 (7.4%) | 29 (14.5%)
ABN-NCS to ABN-NCS | 3 (7.7%) | 5 (4.9%) | 2 (6.5%) | 0 | 10 (5.0%)
ABN-CS to ABN-CS | 0 | 0 | 1 (3.2%) | 0 | 1 (0.5%)
Worsening | 4 (10.3%) | 4 (3.9%) | 1 (3.2%) | 0 | 9 (4.5%)
WNL to ABN-NCS | 4 (10.3%) | 4 (3.9%) | 1 (3.2%) | 0 | 9 (4.5%)
Improvement | 5 (12.8%) | 4 (3.9%) | 1 (3.2%) | 2 (7.4%) | 12 (6.0%)
ABN-NCS to WNL | 3 (7.7%) | 3 (2.9%) | 1 (3.2%) | 1 (3.7%) | 8 (4.0%)
ABN-CS to ABN-NCS | 1 (2.6%) | 1 (1.0%) | 0 | 1 (3.7%) | 3 (1.5%)
ABN-CS to WNL | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
Days22_28
No Change | 10 (25.6%) | 11 (10.7%) | 0 | 0 | 21 (10.5%)
WNL to WNL | 5 (12.8%) | 9 (8.7%) | 0 | 0 | 14 (7.0%)
ABN-NCS to ABN-NCS | 4 (10.3%) | 2 (1.9%) | 0 | 0 | 6 (3.0%)
ABN-CS to ABN-CS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
Worsening | 0 | 7 (6.8%) | 2 (6.5%) | 0 | 9 (4.5%)
WNL to ABN-NCS | 0 | 7 (6.8%) | 2 (6.5%) | 0 | 9 (4.5%)
Improvement | 1 (2.6%) | 5 (4.9%) | 1 (3.2%) | 1 (3.7%) | 8 (4.0%)
ABN-NCS to WNL | 0 | 4 (3.9%) | 0 | 0 | 4 (2.0%)
ABN-CS to ABN-NCS | 0 | 0 | 0 | 1 (3.7%) | 1 (0.5%)
ABN-CS to WNL | 1 (2.6%) | 1 (1.0%) | 1 (3.2%) | 0 | 3 (1.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Shift of Blood Hematology Interpretations from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: HGB (g/dL)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
No Change | 14 (35.9%) | 58 (56.3%) | 13 (41.9%) | 13 (48.1%) | 98 (49.0%)
WNL to WNL | 8 (20.5%) | 43 (41.7%) | 8 (25.8%) | 8 (29.6%) | 67 (33.5%)
ABN-NCS to ABN-NCS | 6 (15.4%) | 12 (11.7%) | 5 (16.1%) | 5 (18.5%) | 28 (14.0%)
ABN-CS to ABN-CS | 0 | 3 (2.9%) | 0 | 0 | 3 (1.5%)
Worsening | 4 (10.3%) | 7 (6.8%) | 4 (12.9%) | 2 (7.4%) | 17 (8.5%)
WNL to ABN-NCS | 3 (7.7%) | 5 (4.9%) | 4 (12.9%) | 1 (3.7%) | 13 (6.5%)
WNL to ABN-CS | 0 | 2 (1.9%) | 0 | 1 (3.7%) | 3 (1.5%)
ABN-NCS to ABN-CS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
Improvement | 14 (35.9%) | 15 (14.6%) | 4 (12.9%) | 3 (11.1%) | 36 (18.0%)
ABN-NCS to WNL | 5 (12.8%) | 10 (9.7%) | 2 (6.5%) | 1 (3.7%) | 18 (9.0%)
ABN-CS to ABN-NCS | 6 (15.4%) | 1 (1.0%) | 1 (3.2%) | 1 (3.7%) | 9 (4.5%)
ABN-CS to WNL | 3 (7.7%) | 4 (3.9%) | 1 (3.2%) | 1 (3.7%) | 9 (4.5%)
Days8_14
No Change | 13 (33.3%) | 39 (37.9%) | 9 (29.0%) | 5 (18.5%) | 66 (33.0%)
WNL to WNL | 4 (10.3%) | 29 (28.2%) | 3 (9.7%) | 5 (18.5%) | 41 (20.5%)
ABN-NCS to ABN-NCS | 7 (17.9%) | 9 (8.7%) | 5 (16.1%) | 0 | 21 (10.5%)
ABN-CS to ABN-CS | 2 (5.1%) | 1 (1.0%) | 1 (3.2%) | 0 | 4 (2.0%)
Worsening | 5 (12.8%) | 8 (7.8%) | 2 (6.5%) | 2 (7.4%) | 17 (8.5%)
WNL to ABN-NCS | 2 (5.1%) | 4 (3.9%) | 2 (6.5%) | 1 (3.7%) | 9 (4.5%)
WNL to ABN-CS | 2 (5.1%) | 3 (2.9%) | 0 | 1 (3.7%) | 6 (3.0%)
ABN-NCS to ABN-CS | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
Improvement | 6 (15.4%) | 9 (8.7%) | 1 (3.2%) | 3 (11.1%) | 19 (9.5%)
ABN-NCS to WNL | 4 (10.3%) | 8 (7.8%) | 0 | 1 (3.7%) | 13 (6.5%)
ABN-CS to ABN-NCS | 2 (5.1%) | 0 | 0 | 1 (3.7%) | 3 (1.5%)
ABN-CS to WNL | 0 | 1 (1.0%) | 1 (3.2%) | 1 (3.7%) | 3 (1.5%)
Days15_21
No Change | 15 (38.5%) | 16 (15.5%) | 5 (16.1%) | 3 (11.1%) | 39 (19.5%)
WNL to WNL | 6 (15.4%) | 12 (11.7%) | 1 (3.2%) | 2 (7.4%) | 21 (10.5%)
ABN-NCS to ABN-NCS | 8 (20.5%) | 4 (3.9%) | 3 (9.7%) | 1 (3.7%) | 16 (8.0%)
ABN-CS to ABN-CS | 1 (2.6%) | 0 | 1 (3.2%) | 0 | 2 (1.0%)
Worsening | 2 (5.1%) | 8 (7.8%) | 2 (6.5%) | 0 | 12 (6.0%)
WNL to ABN-NCS | 1 (2.6%) | 5 (4.9%) | 2 (6.5%) | 0 | 8 (4.0%)
WNL to ABN-CS | 0 | 3 (2.9%) | 0 | 0 | 3 (1.5%)
ABN-NCS to ABN-CS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
Improvement | 3 (7.7%) | 8 (7.8%) | 2 (6.5%) | 2 (7.4%) | 15 (7.5%)
ABN-NCS to WNL | 1 (2.6%) | 6 (5.8%) | 1 (3.2%) | 0 | 8 (4.0%)
ABN-CS to ABN-NCS | 1 (2.6%) | 0 | 0 | 1 (3.7%) | 2 (1.0%)
ABN-CS to WNL | 1 (2.6%) | 2 (1.9%) | 1 (3.2%) | 1 (3.7%) | 5 (2.5%)
Days22_28
No Change | 9 (23.1%) | 14 (13.6%) | 1 (3.2%) | 0 | 24 (12.0%)
WNL to WNL | 3 (7.7%) | 9 (8.7%) | 0 | 0 | 12 (6.0%)
ABN-NCS to ABN-NCS | 5 (12.8%) | 4 (3.9%) | 1 (3.2%) | 0 | 10 (5.0%)
ABN-CS to ABN-CS | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
Worsening | 1 (2.6%) | 5 (4.9%) | 1 (3.2%) | 0 | 7 (3.5%)
WNL to ABN-NCS | 1 (2.6%) | 5 (4.9%) | 1 (3.2%) | 0 | 7 (3.5%)
Improvement | 2 (5.1%) | 5 (4.9%) | 1 (3.2%) | 1 (3.7%) | 9 (4.5%)
ABN-NCS to WNL | 1 (2.6%) | 4 (3.9%) | 0 | 0 | 5 (2.5%)
ABN-CS to ABN-NCS | 0 | 0 | 0 | 1 (3.7%) | 1 (0.5%)
ABN-CS to WNL | 1 (2.6%) | 1 (1.0%) | 1 (3.2%) | 0 | 3 (1.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Shift of Blood Hematology Interpretations from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: HCT (%)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
No Change | 21 (53.8%) | 62 (60.2%) | 12 (38.7%) | 12 (44.4%) | 107 (53.5%)
WNL to WNL | 10 (25.6%) | 42 (40.8%) | 7 (22.6%) | 8 (29.6%) | 67 (33.5%)
ABN-NCS to ABN-NCS | 11 (28.2%) | 18 (17.5%) | 5 (16.1%) | 4 (14.8%) | 38 (19.0%)
ABN-CS to ABN-CS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
Worsening | 3 (7.7%) | 5 (4.9%) | 5 (16.1%) | 3 (11.1%) | 16 (8.0%)
WNL to ABN-NCS | 1 (2.6%) | 4 (3.9%) | 4 (12.9%) | 2 (7.4%) | 11 (5.5%)
WNL to ABN-CS | 0 | 0 | 1 (3.2%) | 1 (3.7%) | 2 (1.0%)
ABN-NCS to ABN-CS | 2 (5.1%) | 1 (1.0%) | 0 | 0 | 3 (1.5%)
Improvement | 10 (25.6%) | 18 (17.5%) | 4 (12.9%) | 5 (18.5%) | 37 (18.5%)
ABN-NCS to WNL | 3 (7.7%) | 12 (11.7%) | 2 (6.5%) | 3 (11.1%) | 20 (10.0%)
ABN-CS to ABN-NCS | 5 (12.8%) | 1 (1.0%) | 2 (6.5%) | 2 (7.4%) | 10 (5.0%)
ABN-CS to WNL | 2 (5.1%) | 5 (4.9%) | 0 | 0 | 7 (3.5%)
Days8_14
No Change | 16 (41.0%) | 42 (40.8%) | 9 (29.0%) | 6 (22.2%) | 73 (36.5%)
WNL to WNL | 5 (12.8%) | 28 (27.2%) | 3 (9.7%) | 4 (14.8%) | 40 (20.0%)
ABN-NCS to ABN-NCS | 10 (25.6%) | 14 (13.6%) | 5 (16.1%) | 2 (7.4%) | 31 (15.5%)
ABN-CS to ABN-CS | 1 (2.6%) | 0 | 1 (3.2%) | 0 | 2 (1.0%)
Worsening | 5 (12.8%) | 11 (10.7%) | 3 (9.7%) | 5 (18.5%) | 24 (12.0%)
WNL to ABN-NCS | 1 (2.6%) | 6 (5.8%) | 2 (6.5%) | 2 (7.4%) | 11 (5.5%)
WNL to ABN-CS | 2 (5.1%) | 2 (1.9%) | 1 (3.2%) | 2 (7.4%) | 7 (3.5%)
ABN-NCS to ABN-CS | 2 (5.1%) | 3 (2.9%) | 0 | 1 (3.7%) | 6 (3.0%)
Improvement | 6 (15.4%) | 12 (11.7%) | 2 (6.5%) | 3 (11.1%) | 23 (11.5%)
ABN-NCS to WNL | 4 (10.3%) | 9 (8.7%) | 1 (3.2%) | 2 (7.4%) | 16 (8.0%)
ABN-CS to ABN-NCS | 2 (5.1%) | 1 (1.0%) | 0 | 1 (3.7%) | 4 (2.0%)
ABN-CS to WNL | 0 | 2 (1.9%) | 1 (3.2%) | 0 | 3 (1.5%)
Days15_21
No Change | 16 (41.0%) | 18 (17.5%) | 6 (19.4%) | 6 (22.2%) | 46 (23.0%)
WNL to WNL | 5 (12.8%) | 11 (10.7%) | 2 (6.5%) | 3 (11.1%) | 21 (10.5%)
ABN-NCS to ABN-NCS | 11 (28.2%) | 7 (6.8%) | 3 (9.7%) | 3 (11.1%) | 24 (12.0%)
ABN-CS to ABN-CS | 0 | 0 | 1 (3.2%) | 0 | 1 (0.5%)
Worsening | 2 (5.1%) | 12 (11.7%) | 2 (6.5%) | 2 (7.4%) | 18 (9.0%)
WNL to ABN-NCS | 1 (2.6%) | 11 (10.7%) | 2 (6.5%) | 1 (3.7%) | 15 (7.5%)
WNL to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
ABN-NCS to ABN-CS | 1 (2.6%) | 0 | 0 | 1 (3.7%) | 2 (1.0%)
Improvement | 3 (7.7%) | 10 (9.7%) | 2 (6.5%) | 2 (7.4%) | 17 (8.5%)
ABN-NCS to WNL | 1 (2.6%) | 8 (7.8%) | 1 (3.2%) | 1 (3.7%) | 11 (5.5%)
ABN-CS to ABN-NCS | 1 (2.6%) | 1 (1.0%) | 0 | 1 (3.7%) | 3 (1.5%)
ABN-CS to WNL | 1 (2.6%) | 1 (1.0%) | 1 (3.2%) | 0 | 3 (1.5%)
Days22_28
No Change | 10 (25.6%) | 15 (14.6%) | 1 (3.2%) | 4 (14.8%) | 30 (15.0%)
WNL to WNL | 4 (10.3%) | 9 (8.7%) | 0 | 2 (7.4%) | 15 (7.5%)
ABN-NCS to ABN-NCS | 5 (12.8%) | 5 (4.9%) | 1 (3.2%) | 2 (7.4%) | 13 (6.5%)
ABN-CS to ABN-CS | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
Worsening | 2 (5.1%) | 7 (6.8%) | 2 (6.5%) | 0 | 11 (5.5%)
WNL to ABN-NCS | 2 (5.1%) | 5 (4.9%) | 2 (6.5%) | 0 | 9 (4.5%)
WNL to ABN-CS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
Improvement | 3 (7.7%) | 7 (6.8%) | 1 (3.2%) | 1 (3.7%) | 12 (6.0%)
ABN-NCS to WNL | 2 (5.1%) | 6 (5.8%) | 0 | 0 | 8 (4.0%)
ABN-CS to ABN-NCS | 0 | 0 | 1 (3.2%) | 1 (3.7%) | 2 (1.0%)
ABN-CS to WNL | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Shift of Blood Hematology Interpretations from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Platelet Count (x10^3^/mm^3^)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
No Change | 18 (46.2%) | 52 (50.5%) | 12 (38.7%) | 9 (33.3%) | 91 (45.5%)
WNL to WNL | 12 (30.8%) | 23 (22.3%) | 5 (16.1%) | 7 (25.9%) | 47 (23.5%)
ABN-NCS to ABN-NCS | 3 (7.7%) | 14 (13.6%) | 4 (12.9%) | 1 (3.7%) | 22 (11.0%)
ABN-CS to ABN-CS | 3 (7.7%) | 15 (14.6%) | 3 (9.7%) | 1 (3.7%) | 22 (11.0%)
Worsening | 6 (15.4%) | 18 (17.5%) | 4 (12.9%) | 4 (14.8%) | 32 (16.0%)
WNL to ABN-NCS | 3 (7.7%) | 9 (8.7%) | 4 (12.9%) | 3 (11.1%) | 19 (9.5%)
WNL to ABN-CS | 2 (5.1%) | 6 (5.8%) | 0 | 0 | 8 (4.0%)
ABN-NCS to ABN-CS | 1 (2.6%) | 3 (2.9%) | 0 | 1 (3.7%) | 5 (2.5%)
Improvement | 8 (20.5%) | 10 (9.7%) | 6 (19.4%) | 4 (14.8%) | 28 (14.0%)
ABN-NCS to WNL | 3 (7.7%) | 5 (4.9%) | 3 (9.7%) | 2 (7.4%) | 13 (6.5%)
ABN-CS to ABN-NCS | 4 (10.3%) | 4 (3.9%) | 0 | 1 (3.7%) | 9 (4.5%)
ABN-CS to WNL | 1 (2.6%) | 1 (1.0%) | 3 (9.7%) | 1 (3.7%) | 6 (3.0%)
Days8_14
No Change | 7 (17.9%) | 31 (30.1%) | 7 (22.6%) | 4 (14.8%) | 49 (24.5%)
WNL to WNL | 4 (10.3%) | 15 (14.6%) | 3 (9.7%) | 2 (7.4%) | 24 (12.0%)
ABN-NCS to ABN-NCS | 2 (5.1%) | 9 (8.7%) | 3 (9.7%) | 2 (7.4%) | 16 (8.0%)
ABN-CS to ABN-CS | 1 (2.6%) | 7 (6.8%) | 1 (3.2%) | 0 | 9 (4.5%)
Worsening | 6 (15.4%) | 12 (11.7%) | 3 (9.7%) | 2 (7.4%) | 23 (11.5%)
WNL to ABN-NCS | 4 (10.3%) | 7 (6.8%) | 3 (9.7%) | 2 (7.4%) | 16 (8.0%)
WNL to ABN-CS | 1 (2.6%) | 3 (2.9%) | 0 | 0 | 4 (2.0%)
ABN-NCS to ABN-CS | 1 (2.6%) | 2 (1.9%) | 0 | 0 | 3 (1.5%)
Improvement | 9 (23.1%) | 12 (11.7%) | 2 (6.5%) | 3 (11.1%) | 26 (13.0%)
ABN-NCS to WNL | 2 (5.1%) | 3 (2.9%) | 0 | 1 (3.7%) | 6 (3.0%)
ABN-CS to ABN-NCS | 2 (5.1%) | 4 (3.9%) | 0 | 1 (3.7%) | 7 (3.5%)
ABN-CS to WNL | 5 (12.8%) | 5 (4.9%) | 2 (6.5%) | 1 (3.7%) | 13 (6.5%)
Days15_21
No Change | 8 (20.5%) | 14 (13.6%) | 3 (9.7%) | 2 (7.4%) | 27 (13.5%)
WNL to WNL | 5 (12.8%) | 7 (6.8%) | 2 (6.5%) | 2 (7.4%) | 16 (8.0%)
ABN-NCS to ABN-NCS | 2 (5.1%) | 4 (3.9%) | 1 (3.2%) | 0 | 7 (3.5%)
ABN-CS to ABN-CS | 1 (2.6%) | 3 (2.9%) | 0 | 0 | 4 (2.0%)
Worsening | 3 (7.7%) | 6 (5.8%) | 0 | 0 | 9 (4.5%)
WNL to ABN-NCS | 2 (5.1%) | 3 (2.9%) | 0 | 0 | 5 (2.5%)
WNL to ABN-CS | 1 (2.6%) | 2 (1.9%) | 0 | 0 | 3 (1.5%)
ABN-NCS to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Improvement | 6 (15.4%) | 11 (10.7%) | 5 (16.1%) | 2 (7.4%) | 24 (12.0%)
ABN-NCS to WNL | 1 (2.6%) | 4 (3.9%) | 1 (3.2%) | 1 (3.7%) | 7 (3.5%)
ABN-CS to ABN-NCS | 2 (5.1%) | 4 (3.9%) | 0 | 1 (3.7%) | 7 (3.5%)
ABN-CS to WNL | 3 (7.7%) | 3 (2.9%) | 4 (12.9%) | 0 | 10 (5.0%)
Days22_28
No Change | 2 (5.1%) | 11 (10.7%) | 1 (3.2%) | 0 | 14 (7.0%)
WNL to WNL | 2 (5.1%) | 5 (4.9%) | 1 (3.2%) | 0 | 8 (4.0%)
ABN-NCS to ABN-NCS | 0 | 4 (3.9%) | 0 | 0 | 4 (2.0%)
ABN-CS to ABN-CS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
Worsening | 4 (10.3%) | 3 (2.9%) | 0 | 1 (3.7%) | 8 (4.0%)
WNL to ABN-NCS | 3 (7.7%) | 0 | 0 | 1 (3.7%) | 4 (2.0%)
WNL to ABN-CS | 1 (2.6%) | 3 (2.9%) | 0 | 0 | 4 (2.0%)
Improvement | 4 (10.3%) | 8 (7.8%) | 2 (6.5%) | 1 (3.7%) | 15 (7.5%)
ABN-NCS to WNL | 0 | 3 (2.9%) | 0 | 0 | 3 (1.5%)
ABN-CS to ABN-NCS | 3 (7.7%) | 4 (3.9%) | 0 | 0 | 7 (3.5%)
ABN-CS to WNL | 1 (2.6%) | 1 (1.0%) | 2 (6.5%) | 1 (3.7%) | 5 (2.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Shift of Blood Hematology Interpretations from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Neutrophils (%)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
No Change | 19 (48.7%) | 48 (46.6%) | 16 (51.6%) | 11 (40.7%) | 94 (47.0%)
WNL to WNL | 14 (35.9%) | 34 (33.0%) | 15 (48.4%) | 9 (33.3%) | 72 (36.0%)
ABN-NCS to ABN-NCS | 3 (7.7%) | 11 (10.7%) | 1 (3.2%) | 2 (7.4%) | 17 (8.5%)
ABN-CS to ABN-CS | 2 (5.1%) | 3 (2.9%) | 0 | 0 | 5 (2.5%)
Worsening | 5 (12.8%) | 7 (6.8%) | 0 | 3 (11.1%) | 15 (7.5%)
WNL to ABN-NCS | 4 (10.3%) | 7 (6.8%) | 0 | 2 (7.4%) | 13 (6.5%)
WNL to ABN-CS | 0 | 0 | 0 | 1 (3.7%) | 1 (0.5%)
ABN-NCS to ABN-CS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
Improvement | 2 (5.1%) | 14 (13.6%) | 3 (9.7%) | 1 (3.7%) | 20 (10.0%)
ABN-NCS to WNL | 1 (2.6%) | 7 (6.8%) | 1 (3.2%) | 0 | 9 (4.5%)
ABN-CS to ABN-NCS | 1 (2.6%) | 2 (1.9%) | 1 (3.2%) | 1 (3.7%) | 5 (2.5%)
ABN-CS to WNL | 0 | 5 (4.9%) | 1 (3.2%) | 0 | 6 (3.0%)
Days8_14
No Change | 13 (33.3%) | 27 (26.2%) | 7 (22.6%) | 4 (14.8%) | 51 (25.5%)
WNL to WNL | 10 (25.6%) | 23 (22.3%) | 7 (22.6%) | 4 (14.8%) | 44 (22.0%)
ABN-NCS to ABN-NCS | 3 (7.7%) | 4 (3.9%) | 0 | 0 | 7 (3.5%)
Worsening | 3 (7.7%) | 4 (3.9%) | 1 (3.2%) | 0 | 8 (4.0%)
WNL to ABN-NCS | 2 (5.1%) | 4 (3.9%) | 1 (3.2%) | 0 | 7 (3.5%)
ABN-NCS to ABN-CS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
Improvement | 2 (5.1%) | 12 (11.7%) | 4 (12.9%) | 2 (7.4%) | 20 (10.0%)
ABN-NCS to WNL | 0 | 7 (6.8%) | 2 (6.5%) | 1 (3.7%) | 10 (5.0%)
ABN-CS to ABN-NCS | 1 (2.6%) | 2 (1.9%) | 2 (6.5%) | 0 | 5 (2.5%)
ABN-CS to WNL | 1 (2.6%) | 3 (2.9%) | 0 | 1 (3.7%) | 5 (2.5%)
Days15_21
No Change | 6 (15.4%) | 15 (14.6%) | 6 (19.4%) | 1 (3.7%) | 28 (14.0%)
WNL to WNL | 3 (7.7%) | 11 (10.7%) | 6 (19.4%) | 1 (3.7%) | 21 (10.5%)
ABN-NCS to ABN-NCS | 3 (7.7%) | 3 (2.9%) | 0 | 0 | 6 (3.0%)
ABN-CS to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Worsening | 5 (12.8%) | 5 (4.9%) | 0 | 0 | 10 (5.0%)
WNL to ABN-NCS | 4 (10.3%) | 5 (4.9%) | 0 | 0 | 9 (4.5%)
ABN-NCS to ABN-CS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
Improvement | 3 (7.7%) | 6 (5.8%) | 2 (6.5%) | 2 (7.4%) | 13 (6.5%)
ABN-NCS to WNL | 1 (2.6%) | 3 (2.9%) | 1 (3.2%) | 1 (3.7%) | 6 (3.0%)
ABN-CS to ABN-NCS | 1 (2.6%) | 3 (2.9%) | 1 (3.2%) | 0 | 5 (2.5%)
ABN-CS to WNL | 1 (2.6%) | 0 | 0 | 1 (3.7%) | 2 (1.0%)
Days22_28
No Change | 3 (7.7%) | 13 (12.6%) | 1 (3.2%) | 0 | 17 (8.5%)
WNL to WNL | 1 (2.6%) | 11 (10.7%) | 1 (3.2%) | 0 | 13 (6.5%)
ABN-NCS to ABN-NCS | 2 (5.1%) | 1 (1.0%) | 0 | 0 | 3 (1.5%)
ABN-CS to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Worsening | 3 (7.7%) | 1 (1.0%) | 0 | 0 | 4 (2.0%)
WNL to ABN-NCS | 3 (7.7%) | 1 (1.0%) | 0 | 0 | 4 (2.0%)
Improvement | 2 (5.1%) | 5 (4.9%) | 2 (6.5%) | 1 (3.7%) | 10 (5.0%)
ABN-NCS to WNL | 0 | 2 (1.9%) | 1 (3.2%) | 0 | 3 (1.5%)
ABN-CS to ABN-NCS | 1 (2.6%) | 3 (2.9%) | 1 (3.2%) | 0 | 5 (2.5%)
ABN-CS to WNL | 1 (2.6%) | 0 | 0 | 1 (3.7%) | 2 (1.0%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Shift of Blood Hematology Interpretations from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Lymphocytes (%)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
No Change | 24 (61.5%) | 54 (52.4%) | 15 (48.4%) | 11 (40.7%) | 104 (52.0%)
WNL to WNL | 9 (23.1%) | 36 (35.0%) | 14 (45.2%) | 9 (33.3%) | 68 (34.0%)
ABN-NCS to ABN-NCS | 14 (35.9%) | 16 (15.5%) | 1 (3.2%) | 2 (7.4%) | 33 (16.5%)
ABN-CS to ABN-CS | 1 (2.6%) | 2 (1.9%) | 0 | 0 | 3 (1.5%)
Worsening | 2 (5.1%) | 7 (6.8%) | 2 (6.5%) | 3 (11.1%) | 14 (7.0%)
WNL to ABN-NCS | 1 (2.6%) | 5 (4.9%) | 2 (6.5%) | 2 (7.4%) | 10 (5.0%)
WNL to ABN-CS | 0 | 1 (1.0%) | 0 | 1 (3.7%) | 2 (1.0%)
ABN-NCS to ABN-CS | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
Improvement | 1 (2.6%) | 8 (7.8%) | 2 (6.5%) | 1 (3.7%) | 12 (6.0%)
ABN-NCS to WNL | 0 | 5 (4.9%) | 2 (6.5%) | 0 | 7 (3.5%)
ABN-CS to ABN-NCS | 1 (2.6%) | 2 (1.9%) | 0 | 0 | 3 (1.5%)
ABN-CS to WNL | 0 | 1 (1.0%) | 0 | 1 (3.7%) | 2 (1.0%)
Days8_14
No Change | 12 (30.8%) | 32 (31.1%) | 9 (29.0%) | 5 (18.5%) | 58 (29.0%)
WNL to WNL | 6 (15.4%) | 23 (22.3%) | 7 (22.6%) | 4 (14.8%) | 40 (20.0%)
ABN-NCS to ABN-NCS | 6 (15.4%) | 9 (8.7%) | 2 (6.5%) | 1 (3.7%) | 18 (9.0%)
Worsening | 2 (5.1%) | 3 (2.9%) | 2 (6.5%) | 0 | 7 (3.5%)
WNL to ABN-NCS | 1 (2.6%) | 3 (2.9%) | 2 (6.5%) | 0 | 6 (3.0%)
ABN-NCS to ABN-CS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
Improvement | 4 (10.3%) | 9 (8.7%) | 1 (3.2%) | 1 (3.7%) | 15 (7.5%)
ABN-NCS to WNL | 2 (5.1%) | 7 (6.8%) | 1 (3.2%) | 0 | 10 (5.0%)
ABN-CS to ABN-NCS | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
ABN-CS to WNL | 1 (2.6%) | 1 (1.0%) | 0 | 1 (3.7%) | 3 (1.5%)
Days15_21
No Change | 10 (25.6%) | 18 (17.5%) | 8 (25.8%) | 2 (7.4%) | 38 (19.0%)
WNL to WNL | 3 (7.7%) | 10 (9.7%) | 8 (25.8%) | 1 (3.7%) | 22 (11.0%)
ABN-NCS to ABN-NCS | 7 (17.9%) | 7 (6.8%) | 0 | 1 (3.7%) | 15 (7.5%)
ABN-CS to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Worsening | 1 (2.6%) | 4 (3.9%) | 0 | 0 | 5 (2.5%)
WNL to ABN-NCS | 0 | 4 (3.9%) | 0 | 0 | 4 (2.0%)
ABN-NCS to ABN-CS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
Improvement | 4 (10.3%) | 5 (4.9%) | 0 | 1 (3.7%) | 10 (5.0%)
ABN-NCS to WNL | 2 (5.1%) | 4 (3.9%) | 0 | 0 | 6 (3.0%)
ABN-CS to ABN-NCS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
ABN-CS to WNL | 2 (5.1%) | 0 | 0 | 1 (3.7%) | 3 (1.5%)
Days22_28
No Change | 5 (12.8%) | 9 (8.7%) | 1 (3.2%) | 0 | 15 (7.5%)
WNL to WNL | 1 (2.6%) | 7 (6.8%) | 1 (3.2%) | 0 | 9 (4.5%)
ABN-NCS to ABN-NCS | 4 (10.3%) | 2 (1.9%) | 0 | 0 | 6 (3.0%)
Worsening | 0 | 3 (2.9%) | 2 (6.5%) | 0 | 5 (2.5%)
WNL to ABN-NCS | 0 | 3 (2.9%) | 2 (6.5%) | 0 | 5 (2.5%)
Improvement | 3 (7.7%) | 7 (6.8%) | 0 | 1 (3.7%) | 11 (5.5%)
ABN-NCS to WNL | 1 (2.6%) | 5 (4.9%) | 0 | 0 | 6 (3.0%)
ABN-CS to ABN-NCS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
ABN-CS to WNL | 2 (5.1%) | 0 | 0 | 1 (3.7%) | 3 (1.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Shift of Blood Hematology Interpretations from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Monocytes (%)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
No Change | 18 (46.2%) | 50 (48.5%) | 16 (51.6%) | 11 (40.7%) | 95 (47.5%)
WNL to WNL | 13 (33.3%) | 37 (35.9%) | 14 (45.2%) | 11 (40.7%) | 75 (37.5%)
ABN-NCS to ABN-NCS | 4 (10.3%) | 12 (11.7%) | 2 (6.5%) | 0 | 18 (9.0%)
ABN-CS to ABN-CS | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
Worsening | 3 (7.7%) | 10 (9.7%) | 0 | 1 (3.7%) | 14 (7.0%)
WNL to ABN-NCS | 3 (7.7%) | 10 (9.7%) | 0 | 1 (3.7%) | 14 (7.0%)
Improvement | 6 (15.4%) | 10 (9.7%) | 3 (9.7%) | 2 (7.4%) | 21 (10.5%)
ABN-NCS to WNL | 4 (10.3%) | 9 (8.7%) | 3 (9.7%) | 2 (7.4%) | 18 (9.0%)
ABN-CS to ABN-NCS | 2 (5.1%) | 0 | 0 | 0 | 2 (1.0%)
ABN-CS to WNL | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Days8_14
No Change | 11 (28.2%) | 31 (30.1%) | 6 (19.4%) | 4 (14.8%) | 52 (26.0%)
WNL to WNL | 8 (20.5%) | 24 (23.3%) | 5 (16.1%) | 4 (14.8%) | 41 (20.5%)
ABN-NCS to ABN-NCS | 3 (7.7%) | 7 (6.8%) | 1 (3.2%) | 0 | 11 (5.5%)
Worsening | 4 (10.3%) | 6 (5.8%) | 2 (6.5%) | 2 (7.4%) | 14 (7.0%)
WNL to ABN-NCS | 3 (7.7%) | 6 (5.8%) | 2 (6.5%) | 2 (7.4%) | 13 (6.5%)
WNL to ABN-CS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
Improvement | 3 (7.7%) | 8 (7.8%) | 4 (12.9%) | 0 | 15 (7.5%)
ABN-NCS to WNL | 1 (2.6%) | 7 (6.8%) | 4 (12.9%) | 0 | 12 (6.0%)
ABN-CS to ABN-NCS | 2 (5.1%) | 0 | 0 | 0 | 2 (1.0%)
ABN-CS to WNL | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Days15_21
No Change | 10 (25.6%) | 15 (14.6%) | 6 (19.4%) | 1 (3.7%) | 32 (16.0%)
WNL to WNL | 6 (15.4%) | 11 (10.7%) | 6 (19.4%) | 1 (3.7%) | 24 (12.0%)
ABN-NCS to ABN-NCS | 4 (10.3%) | 4 (3.9%) | 0 | 0 | 8 (4.0%)
Worsening | 1 (2.6%) | 5 (4.9%) | 1 (3.2%) | 1 (3.7%) | 8 (4.0%)
WNL to ABN-NCS | 1 (2.6%) | 5 (4.9%) | 1 (3.2%) | 1 (3.7%) | 8 (4.0%)
Improvement | 4 (10.3%) | 7 (6.8%) | 1 (3.2%) | 1 (3.7%) | 13 (6.5%)
ABN-NCS to WNL | 2 (5.1%) | 6 (5.8%) | 1 (3.2%) | 1 (3.7%) | 10 (5.0%)
ABN-CS to ABN-NCS | 2 (5.1%) | 0 | 0 | 0 | 2 (1.0%)
ABN-CS to WNL | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Days22_28
No Change | 4 (10.3%) | 8 (7.8%) | 2 (6.5%) | 1 (3.7%) | 15 (7.5%)
WNL to WNL | 3 (7.7%) | 5 (4.9%) | 1 (3.2%) | 1 (3.7%) | 10 (5.0%)
ABN-NCS to ABN-NCS | 1 (2.6%) | 3 (2.9%) | 1 (3.2%) | 0 | 5 (2.5%)
Worsening | 0 | 7 (6.8%) | 1 (3.2%) | 0 | 8 (4.0%)
WNL to ABN-NCS | 0 | 7 (6.8%) | 1 (3.2%) | 0 | 8 (4.0%)
Improvement | 4 (10.3%) | 4 (3.9%) | 0 | 0 | 8 (4.0%)
ABN-NCS to WNL | 2 (5.1%) | 3 (2.9%) | 0 | 0 | 5 (2.5%)
ABN-CS to ABN-NCS | 2 (5.1%) | 1 (1.0%) | 0 | 0 | 3 (1.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Shift of Blood Hematology Interpretations from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Eosinophils (%)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
No Change | 18 (46.2%) | 47 (45.6%) | 16 (51.6%) | 11 (40.7%) | 92 (46.0%)
WNL to WNL | 16 (41.0%) | 34 (33.0%) | 15 (48.4%) | 9 (33.3%) | 74 (37.0%)
ABN-NCS to ABN-NCS | 2 (5.1%) | 12 (11.7%) | 1 (3.2%) | 2 (7.4%) | 17 (8.5%)
ABN-CS to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Worsening | 3 (7.7%) | 10 (9.7%) | 2 (6.5%) | 1 (3.7%) | 16 (8.0%)
WNL to ABN-NCS | 2 (5.1%) | 10 (9.7%) | 2 (6.5%) | 0 | 14 (7.0%)
WNL to ABN-CS | 1 (2.6%) | 0 | 0 | 1 (3.7%) | 2 (1.0%)
Improvement | 2 (5.1%) | 9 (8.7%) | 0 | 2 (7.4%) | 13 (6.5%)
ABN-NCS to WNL | 1 (2.6%) | 5 (4.9%) | 0 | 1 (3.7%) | 7 (3.5%)
ABN-CS to ABN-NCS | 0 | 3 (2.9%) | 0 | 0 | 3 (1.5%)
ABN-CS to WNL | 1 (2.6%) | 1 (1.0%) | 0 | 1 (3.7%) | 3 (1.5%)
Days8_14
No Change | 12 (30.8%) | 29 (28.2%) | 9 (29.0%) | 5 (18.5%) | 55 (27.5%)
WNL to WNL | 11 (28.2%) | 23 (22.3%) | 9 (29.0%) | 4 (14.8%) | 47 (23.5%)
ABN-NCS to ABN-NCS | 1 (2.6%) | 6 (5.8%) | 0 | 1 (3.7%) | 8 (4.0%)
Worsening | 1 (2.6%) | 6 (5.8%) | 1 (3.2%) | 0 | 8 (4.0%)
WNL to ABN-NCS | 1 (2.6%) | 6 (5.8%) | 1 (3.2%) | 0 | 8 (4.0%)
Improvement | 2 (5.1%) | 8 (7.8%) | 1 (3.2%) | 1 (3.7%) | 12 (6.0%)
ABN-NCS to WNL | 1 (2.6%) | 4 (3.9%) | 1 (3.2%) | 0 | 6 (3.0%)
ABN-CS to ABN-NCS | 0 | 3 (2.9%) | 0 | 1 (3.7%) | 4 (2.0%)
ABN-CS to WNL | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
Days15_21
No Change | 11 (28.2%) | 15 (14.6%) | 7 (22.6%) | 2 (7.4%) | 35 (17.5%)
WNL to WNL | 9 (23.1%) | 11 (10.7%) | 7 (22.6%) | 0 | 27 (13.5%)
ABN-NCS to ABN-NCS | 2 (5.1%) | 4 (3.9%) | 0 | 2 (7.4%) | 8 (4.0%)
Worsening | 2 (5.1%) | 4 (3.9%) | 0 | 0 | 6 (3.0%)
WNL to ABN-NCS | 2 (5.1%) | 4 (3.9%) | 0 | 0 | 6 (3.0%)
Improvement | 1 (2.6%) | 6 (5.8%) | 0 | 1 (3.7%) | 8 (4.0%)
ABN-NCS to WNL | 0 | 3 (2.9%) | 0 | 0 | 3 (1.5%)
ABN-CS to ABN-NCS | 1 (2.6%) | 2 (1.9%) | 0 | 0 | 3 (1.5%)
ABN-CS to WNL | 0 | 1 (1.0%) | 0 | 1 (3.7%) | 2 (1.0%)
Days22_28
No Change | 7 (17.9%) | 7 (6.8%) | 2 (6.5%) | 0 | 16 (8.0%)
WNL to WNL | 7 (17.9%) | 5 (4.9%) | 2 (6.5%) | 0 | 14 (7.0%)
ABN-NCS to ABN-NCS | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
Worsening | 0 | 5 (4.9%) | 1 (3.2%) | 0 | 6 (3.0%)
WNL to ABN-NCS | 0 | 5 (4.9%) | 1 (3.2%) | 0 | 6 (3.0%)
Improvement | 1 (2.6%) | 5 (4.9%) | 0 | 1 (3.7%) | 7 (3.5%)
ABN-NCS to WNL | 0 | 2 (1.9%) | 0 | 0 | 2 (1.0%)
ABN-CS to ABN-NCS | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
ABN-CS to WNL | 0 | 2 (1.9%) | 0 | 1 (3.7%) | 3 (1.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Shift of Blood Hematology Interpretations from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Basophils (%)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
No Change | 18 (46.2%) | 45 (43.7%) | 14 (45.2%) | 9 (33.3%) | 86 (43.0%)
WNL to WNL | 18 (46.2%) | 44 (42.7%) | 14 (45.2%) | 9 (33.3%) | 85 (42.5%)
ABN-NCS to ABN-NCS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Worsening | 1 (2.6%) | 2 (1.9%) | 0 | 0 | 3 (1.5%)
WNL to ABN-NCS | 1 (2.6%) | 2 (1.9%) | 0 | 0 | 3 (1.5%)
Improvement | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
ABN-NCS to WNL | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Days8_14
No Change | 12 (30.8%) | 28 (27.2%) | 9 (29.0%) | 2 (7.4%) | 51 (25.5%)
WNL to WNL | 12 (30.8%) | 27 (26.2%) | 9 (29.0%) | 2 (7.4%) | 50 (25.0%)
ABN-NCS to ABN-NCS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Worsening | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
WNL to ABN-NCS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Improvement | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
ABN-NCS to WNL | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Days15_21
No Change | 9 (23.1%) | 14 (13.6%) | 6 (19.4%) | 1 (3.7%) | 30 (15.0%)
WNL to WNL | 9 (23.1%) | 14 (13.6%) | 6 (19.4%) | 1 (3.7%) | 30 (15.0%)
Worsening | 1 (2.6%) | 2 (1.9%) | 0 | 0 | 3 (1.5%)
WNL to ABN-NCS | 1 (2.6%) | 2 (1.9%) | 0 | 0 | 3 (1.5%)
Improvement | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
ABN-NCS to WNL | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
Days22_28
No Change | 7 (17.9%) | 13 (12.6%) | 2 (6.5%) | 0 | 22 (11.0%)
WNL to WNL | 7 (17.9%) | 13 (12.6%) | 2 (6.5%) | 0 | 22 (11.0%)
Improvement | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
ABN-NCS to WNL | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Summary of Shift of Blood Hematology Interpretations from Baseline to each Scheduled Visit by Gestational and Postnatal Age Stratum Tests: Bands (%)

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
No Change | 16 (41.0%) | 39 (37.9%) | 13 (41.9%) | 10 (37.0%) | 78 (39.0%)
WNL to WNL | 14 (35.9%) | 33 (32.0%) | 11 (35.5%) | 9 (33.3%) | 67 (33.5%)
ABN-NCS to ABN-NCS | 1 (2.6%) | 3 (2.9%) | 0 | 1 (3.7%) | 5 (2.5%)
ABN-CS to ABN-CS | 1 (2.6%) | 3 (2.9%) | 2 (6.5%) | 0 | 6 (3.0%)
Worsening | 3 (7.7%) | 3 (2.9%) | 0 | 2 (7.4%) | 8 (4.0%)
WNL to ABN-NCS | 1 (2.6%) | 1 (1.0%) | 0 | 1 (3.7%) | 3 (1.5%)
WNL to ABN-CS | 2 (5.1%) | 1 (1.0%) | 0 | 1 (3.7%) | 4 (2.0%)
ABN-NCS to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Improvement | 6 (15.4%) | 16 (15.5%) | 3 (9.7%) | 1 (3.7%) | 26 (13.0%)
ABN-NCS to WNL | 1 (2.6%) | 4 (3.9%) | 1 (3.2%) | 1 (3.7%) | 7 (3.5%)
ABN-CS to ABN-NCS | 1 (2.6%) | 4 (3.9%) | 1 (3.2%) | 0 | 6 (3.0%)
ABN-CS to WNL | 4 (10.3%) | 8 (7.8%) | 1 (3.2%) | 0 | 13 (6.5%)
Days8_14
No Change | 10 (25.6%) | 25 (24.3%) | 6 (19.4%) | 5 (18.5%) | 46 (23.0%)
WNL to WNL | 9 (23.1%) | 21 (20.4%) | 6 (19.4%) | 4 (14.8%) | 40 (20.0%)
ABN-NCS to ABN-NCS | 1 (2.6%) | 3 (2.9%) | 0 | 1 (3.7%) | 5 (2.5%)
ABN-CS to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Worsening | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
WNL to ABN-NCS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Improvement | 6 (15.4%) | 8 (7.8%) | 2 (6.5%) | 1 (3.7%) | 17 (8.5%)
ABN-NCS to WNL | 2 (5.1%) | 2 (1.9%) | 1 (3.2%) | 1 (3.7%) | 6 (3.0%)
ABN-CS to ABN-NCS | 2 (5.1%) | 3 (2.9%) | 1 (3.2%) | 0 | 6 (3.0%)
ABN-CS to WNL | 2 (5.1%) | 3 (2.9%) | 0 | 0 | 5 (2.5%)
Days15_21
No Change | 6 (15.4%) | 12 (11.7%) | 2 (6.5%) | 3 (11.1%) | 23 (11.5%)
WNL to WNL | 4 (10.3%) | 9 (8.7%) | 2 (6.5%) | 3 (11.1%) | 18 (9.0%)
ABN-NCS to ABN-NCS | 2 (5.1%) | 2 (1.9%) | 0 | 0 | 4 (2.0%)
ABN-CS to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Worsening | 2 (5.1%) | 0 | 0 | 0 | 2 (1.0%)
WNL to ABN-NCS | 2 (5.1%) | 0 | 0 | 0 | 2 (1.0%)
Improvement | 3 (7.7%) | 9 (8.7%) | 3 (9.7%) | 0 | 15 (7.5%)
ABN-NCS to WNL | 1 (2.6%) | 1 (1.0%) | 0 | 0 | 2 (1.0%)
ABN-CS to ABN-NCS | 1 (2.6%) | 4 (3.9%) | 1 (3.2%) | 0 | 6 (3.0%)
ABN-CS to WNL | 1 (2.6%) | 4 (3.9%) | 2 (6.5%) | 0 | 7 (3.5%)
Days22_28
No Change | 5 (12.8%) | 6 (5.8%) | 1 (3.2%) | 1 (3.7%) | 13 (6.5%)
WNL to WNL | 4 (10.3%) | 6 (5.8%) | 1 (3.2%) | 1 (3.7%) | 12 (6.0%)
ABN-NCS to ABN-NCS | 1 (2.6%) | 0 | 0 | 0 | 1 (0.5%)
Worsening | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
WNL to ABN-CS | 0 | 1 (1.0%) | 0 | 0 | 1 (0.5%)
Improvement | 2 (5.1%) | 8 (7.8%) | 2 (6.5%) | 0 | 12 (6.0%)
ABN-NCS to WNL | 0 | 3 (2.9%) | 0 | 0 | 3 (1.5%)
ABN-CS to ABN-NCS | 0 | 1 (1.0%) | 1 (3.2%) | 0 | 2 (1.0%)
ABN-CS to WNL | 2 (5.1%) | 4 (3.9%) | 1 (3.2%) | 0 | 7 (3.5%)

ABN-CS: abnormal, clinically significant; ABN-NCS: abnormal, not clinically significant; WNL: within normal limits

The percentages are based on the total number of safety patients in each age group or total.

Table 14.3.4.10.1 Summary of Growth Parameters Weight (grams) by Scheduled Visit, Gestational and Postnatal Age Stratum

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 38 | 102 | 31 | 27 | 198
Mean (SD) | 940.3 (416.3) | 1475.7 (663.8) | 2668.3 (773.8) | 3183.9 (1219.5) | 1792.6 (1060.2)
95% CI | 803.5, 1077.1 | 1345.3, 1606.1 | 2384.5, 2952.1 | 2701.4, 3666.3 | 1644.0, 1941.2
Median | 749.0 | 1290.5 | 2470.0 | 3120.0 | 1498.0
Min, Max | 480.0, 2040.0 | 425.0, 3500.0 | 1375.0, 4630.0 | 1765.0, 6500.0 | 425.0, 6500.0
Days1_7
N | 36 | 97 | 27 | 27 | 187
Mean (SD) | 1018.6 (456.2) | 1652.9 (709.2) | 2729.4 (795.3) | 3278.0 (1159.3) | 1920.9 (1064.1)
95% CI | 864.2, 1172.9 | 1509.9, 1795.8 | 2414.8, 3044.0 | 2819.4, 3736.6 | 1767.3, 2074.4
Median | 837.5 | 1460.0 | 2640.0 | 3401.0 | 1760.0
Min, Max | 481.0, 2082.0 | 389.0, 3815.0 | 1575.0, 4930.0 | 1815.0, 6500.0 | 389.0, 6500.0
Days8_14
N | 30 | 81 | 20 | 20 | 151
Mean (SD) | 1064.8 (526.4) | 1770.6 (749.5) | 2874.8 (838.2) | 3108.2 (1044.6) | 1953.8 (1023.4)
95% CI | 868.2, 1261.3 | 1604.9, 1936.4 | 2482.5, 3267.1 | 2619.3, 3597.1 | 1789.2, 2118.4
Median | 887.5 | 1600.0 | 2667.5 | 3062.0 | 1720.0
Min, Max | 507.0, 2585.0 | 469.0, 3860.0 | 1710.0, 4930.0 | 1815.0, 5290.0 | 469.0, 5290.0
Days15_21
N | 23 | 53 | 11 | 11 | 98
Mean (SD) | 1187.7 (627.7) | 1785.8 (672.3) | 3071.5 (920.2) | 3413.4 (1217.9) | 1972.4 (1053.3)
95% CI | 916.3, 1459.1 | 1600.5, 1971.1 | 2453.3, 3689.7 | 2595.1, 4231.6 | 1761.2, 2183.6
Median | 961.0 | 1651.0 | 2750.0 | 2775.0 | 1810.0
Min, Max | 500.0, 2759.0 | 659.0, 4060.0 | 1972.0, 5065.0 | 2028.0, 5610.0 | 500.0, 5610.0
Days22_28
N | 36 | 97 | 28 | 26 | 187
Mean (SD) | 1362.8 (633.5) | 2009.3 (756.0) | 3035.1 (696.2) | 3585.1 (1085.5) | 2257.5 (1060.0)
95% CI | 1148.4, 1577.1 | 1856.9, 2161.7 | 2765.2, 3305.1 | 3146.7, 4023.6 | 2104.6, 2410.5
Median | 1151.5 | 1940.0 | 2807.5 | 3422.0 | 2150.0
Min, Max | 590.0, 2869.0 | 469.0, 4166.0 | 1985.0, 4722.0 | 2028.0, 6220.0 | 469.0, 6220.0

Table 14.3.4.10.2 Summary of Growth Parameters Length (cm) by Scheduled Visit, Gestational and Postnatal Age Stratum

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 32 | 87 | 28 | 22 | 169
Mean (SD) | 34.7 (5.3) | 38.0 (5.1) | 47.2 (4.1) | 48.7 (5.6) | 40.3 (7.1)
95% CI | 32.8, 36.6 | 36.9, 39.1 | 45.6, 48.8 | 46.2, 51.1 | 39.2, 41.4
Median | 33.5 | 37.5 | 47.5 | 48.8 | 39.5
Min, Max | 26.8, 44.0 | 25.5, 53.0 | 40.5, 55.0 | 39.0, 61.5 | 25.5, 61.5
Days1_7
N | 24 | 76 | 23 | 20 | 143
Mean (SD) | 35.0 (4.7) | 38.7 (5.2) | 46.7 (4.1) | 49.7 (5.9) | 40.9 (7.1)
95% CI | 33.0, 37.0 | 37.5, 39.9 | 45.0, 48.5 | 47.0, 52.5 | 39.7, 42.1
Median | 33.8 | 38.5 | 45.0 | 50.3 | 40.5
Min, Max | 29.0, 45.0 | 26.0, 52.0 | 41.0, 55.0 | 41.5, 63.8 | 26.0, 63.8
Days8_14
N | 25 | 61 | 15 | 16 | 117
Mean (SD) | 35.8 (5.9) | 39.9 (5.4) | 48.0 (4.6) | 48.8 (6.3) | 41.3 (7.2)
95% CI | 33.3, 38.2 | 38.5, 41.3 | 45.5, 50.6 | 45.5, 52.2 | 40.0, 42.6
Median | 34.0 | 39.5 | 46.5 | 47.5 | 41.0
Min, Max | 21.7, 47.0 | 26.6, 53.0 | 42.0, 55.0 | 41.0, 64.0 | 21.7, 64.0
Days15_21
N | 15 | 40 | 7 | 7 | 69
Mean (SD) | 37.1 (5.2) | 39.8 (4.0) | 49.7 (4.6) | 52.4 (8.2) | 41.5 (6.9)
95% CI | 34.2, 40.0 | 38.5, 41.1 | 45.5, 53.9 | 44.9, 60.0 | 39.8, 43.2
Median | 36.0 | 40.5 | 50.0 | 48.0 | 41.0
Min, Max | 30.5, 47.0 | 32.0, 47.0 | 44.5, 57.0 | 44.0, 65.5 | 30.5, 65.5
Days22_28
N | 26 | 73 | 24 | 20 | 143
Mean (SD) | 38.8 (5.5) | 41.9 (4.5) | 49.1 (3.6) | 52.0 (5.6) | 43.9 (6.5)
95% CI | 36.6, 41.0 | 40.8, 42.9 | 47.6, 50.6 | 49.4, 54.6 | 42.9, 45.0
Median | 37.5 | 42.0 | 49.4 | 51.5 | 44.0
Min, Max | 30.0, 47.5 | 33.0, 53.5 | 42.0, 57.0 | 44.0, 66.5 | 30.0, 66.5

Table 14.3.4.10.3 Summary of Growth Parameters Head Circumference (cm) by Scheduled Visit, Gestational and Postnatal Age Stratum

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 34 | 94 | 28 | 21 | 177
Mean (SD) | 23.6 (3.0) | 26.8 (3.5) | 32.0 (2.2) | 33.1 (3.5) | 27.8 (4.5)
95% CI | 22.6, 24.7 | 26.1, 27.5 | 31.1, 32.8 | 31.5, 34.7 | 27.1, 28.4
Median | 23.0 | 26.7 | 31.5 | 32.5 | 27.5
Min, Max | 20.0, 29.5 | 17.0, 35.0 | 28.5, 35.2 | 27.5, 39.0 | 17.0, 39.0
Days1_7
N | 29 | 79 | 24 | 20 | 152
Mean (SD) | 23.9 (3.1) | 27.7 (3.6) | 32.6 (2.5) | 34.6 (3.1) | 28.7 (4.7)
95% CI | 22.8, 25.1 | 26.9, 28.5 | 31.5, 33.7 | 33.2, 36.0 | 27.9, 29.4
Median | 23.0 | 27.5 | 32.0 | 35.0 | 28.5
Min, Max | 20.0, 30.0 | 19.5, 37.5 | 29.0, 37.0 | 28.5, 39.0 | 19.5, 39.0
Days8_14
N | 26 | 63 | 15 | 17 | 121
Mean (SD) | 24.6 (2.8) | 28.3 (3.4) | 33.0 (1.8) | 33.8 (3.1) | 28.9 (4.4)
95% CI | 23.5, 25.8 | 27.4, 29.1 | 32.0, 34.0 | 32.2, 35.4 | 28.1, 29.6
Median | 23.9 | 28.0 | 33.0 | 34.0 | 28.5
Min, Max | 21.0, 30.0 | 18.6, 37.0 | 30.5, 36.0 | 27.5, 39.5 | 18.6, 39.5
Days15_21
N | 15 | 44 | 8 | 9 | 76
Mean (SD) | 26.0 (3.0) | 28.8 (3.0) | 33.5 (1.7) | 34.9 (3.0) | 29.5 (4.0)
95% CI | 24.4, 27.7 | 27.9, 29.7 | 32.1, 34.9 | 32.7, 37.2 | 28.6, 30.4
Median | 25.5 | 29.0 | 33.3 | 35.0 | 29.5
Min, Max | 22.5, 31.0 | 21.8, 37.5 | 31.0, 36.0 | 31.0, 40.0 | 21.8, 40.0
Days22_28
N | 27 | 77 | 23 | 21 | 148
Mean (SD) | 26.9 (3.1) | 30.0 (3.0) | 33.8 (1.8) | 35.4 (2.2) | 30.8 (3.9)
95% CI | 25.7, 28.1 | 29.3, 30.7 | 33.0, 34.6 | 34.4, 36.4 | 30.2, 31.4
Median | 26.5 | 30.0 | 34.0 | 35.0 | 31.0
Min, Max | 21.5, 32.5 | 22.8, 37.5 | 30.0, 38.0 | 31.0, 40.0 | 21.5, 40.0

Table 14.3.4.11.1 Summary of Change Growth Parameters Weight (grams) from Baseline to each Scheduled Visit, Gestational and Postnatal Age Stratum

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 36 | 96 | 27 | 27 | 186
Mean (SD) | 78.7 (102.5) | 163.4 (249.2) | 46.6 (264.1) | 94.2 (272.5) | 120.0 (237.3)
95% CI | 44.0, 113.3 | 112.9, 213.9 | −57.9, 151.1 | −13.6, 202.0 | 85.7, 154.3
Median | 75.5 | 123.5 | 90.0 | 50.0 | 90.5
Min, Max | −90.0, 320.0 | −280.0, 1590.0 | −1060, 385.0 | −700.0, 660.0 | −1060, 1590.0
Days8_14
N | 30 | 80 | 20 | 20 | 150
Mean (SD) | 142.0 (155.1) | 293.3 (273.7) | 156.7 (210.2) | 176.8 (224.1) | 229.3 (247.5)
95% CI | 84.1, 199.9 | 232.4, 354.2 | 58.3, 255.0 | 71.9, 281.6 | 189.4, 269.2
Median | 128.5 | 230.0 | 176.0 | 128.5 | 200.0
Min, Max | −180.0, 545.0 | −120.0, 1870.0 | −245.0, 645.0 | −140.0, 590.0 | −245.0, 1870.0
Days15_21
N | 23 | 53 | 11 | 11 | 98
Mean (SD) | 250.9 (222.4) | 440.3 (318.8) | 361.0 (244.1) | 418.4 (201.1) | 384.5 (286.6)
95% CI | 154.7, 347.1 | 352.4, 528.1 | 197.0, 525.0 | 283.2, 553.5 | 327.0, 441.9
Median | 240.0 | 390.0 | 355.0 | 370.0 | 370.0
Min, Max | −148.0, 719.0 | −40.0, 1970.0 | 0.0, 695.0 | 131.0, 820.0 | −148.0, 1970.0
Days22_28
N | 36 | 96 | 28 | 26 | 186
Mean (SD) | 415.5 (315.3) | 532.4 (338.7) | 321.5 (298.7) | 355.7 (399.4) | 453.3 (346.1)
95% CI | 308.9, 522.2 | 463.7, 601.0 | 205.6, 437.3 | 194.4, 517.0 | 403.2, 503.4
Median | 355.0 | 494.0 | 265.0 | 417.0 | 417.0
Min, Max | −20.0, 1600.0 | −30.0, 2090.0 | −155.0, 1030.0 | −800.0, 890.0 | −800.0, 2090.0

Baseline is defined as the assessments taken at Pre-Dose.

Change from baseline is the follow-up value minus the baseline value.

Table 14.3.4.11.2 Summary of Change Growth Parameters Length (cm) from Baseline to each Scheduled Visit, Gestational and Postnatal Age Stratum

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 23 | 67 | 23 | 19 | 132
Mean (SD) | 1.2 (1.6) | 0.4 (1.3) | −0.1 (2.9) | 0.6 (2.1) | 0.5 (1.9)
95% CI | 0.5, 1.9 | 0.1, 0.7 | −1.3, 1.2 | −0.4, 1.6 | 0.2, 0.8
Median | 1.0 | 0.0 | 0.5 | 0.5 | 0.5
Min, Max | 0.0, 7.2 | −3.0, 5.0 | −6.5, 4.0 | −5.0, 4.1 | −6.5, 7.2
Days8_14
N | 22 | 55 | 15 | 15 | 107
Mean (SD) | 1.9 (4.4) | 1.5 (2.0) | 0.8 (3.3) | 1.2 (2.3) | 1.4 (2.9)
95% CI | 0.0, 3.9 | 0.9, 2.0 | −1.0, 2.6 | −0.1, 2.5 | 0.9, 2.0
Median | 1.3 | 1.0 | 0.0 | 1.5 | 1.0
Min, Max | −9.8, 16.2 | −2.0, 7.5 | −5.5, 9.0 | −3.5, 5.0 | −9.8, 16.2
Days15_21
N | 12 | 36 | 7 | 6 | 61
Mean (SD) | 3.3 (2.2) | 2.8 (2.7) | 0.8 (3.1) | 2.7 (1.8) | 2.7 (2.6)
95% CI | 1.9, 4.7 | 1.9, 3.8 | −2.0, 3.7 | 0.7, 4.6 | 2.0, 3.4
Median | 3.3 | 2.5 | 1.5 | 2.3 | 2.5
Min, Max | 0.5, 8.2 | −4.0, 11.0 | −4.6, 5.5 | 1.0, 5.5 | −4.6, 11.0
Days22_28
N | 22 | 69 | 23 | 19 | 133
Mean (SD) | 3.9 (3.3) | 3.2 (2.1) | 2.4 (2.9) | 2.6 (2.4) | 3.1 (2.5)
95% CI | 2.4, 5.4 | 2.7, 3.7 | 1.2, 3.6 | 1.5, 3.7 | 2.7, 3.5
Median | 3.5 | 3.6 | 2.0 | 3.0 | 3.0
Min, Max | 0.0, 15.5 | −1.5, 7.0 | −3.6, 9.0 | −3.5, 6.5 | −3.6, 15.5

Baseline is defined as the assessments taken at Pre-Dose.

Change from baseline is the follow-up value minus the baseline value.

Table 14.3.4.11.3 Summary of Change Growth Parameters Head Circumference (cm) from Baseline to each Scheduled Visit, Gestational and Postnatal Age Stratum

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days1_7
N | 27 | 75 | 23 | 18 | 143
Mean (SD) | 0.5 (0.7) | 1.0 (1.7) | 0.6 (1.4) | 0.6 (0.9) | 0.8 (1.4)
95% CI | 0.2, 0.8 | 0.6, 1.4 | 0.0, 1.2 | 0.2, 1.1 | 0.5, 1.0
Median | 0.5 | 0.5 | 0.0 | 0.3 | 0.5
Min, Max | −1.5, 2.0 | −2.0, 12.0 | −1.0, 6.0 | −0.7, 2.5 | −2.0, 12.0
Days8_14
N | 23 | 59 | 15 | 16 | 113
Mean (SD) | 1.1 (1.0) | 1.6 (1.2) | 1.2 (1.1) | 1.0 (1.3) | 1.3 (1.2)
95% CI | 0.6, 1.5 | 1.3, 1.9 | 0.6, 1.8 | 0.3, 1.7 | 1.1, 1.6
Median | 1.0 | 1.5 | 1.0 | 0.9 | 1.5
Min, Max | −1.5, 3.5 | −1.3, 5.8 | −1.1, 3.0 | −0.7, 4.0 | −1.5, 5.8
Days15_21
N | 12 | 42 | 8 | 8 | 70
Mean (SD) | 2.5 (1.5) | 2.4 (1.0) | 1.8 (1.4) | 1.8 (1.2) | 2.3 (1.2)
95% CI | 1.6, 3.5 | 2.1, 2.7 | 0.6, 3.0 | 0.8, 2.7 | 2.0, 2.6
Median | 2.4 | 2.5 | 2.3 | 1.6 | 2.3
Min, Max | 1.0, 6.5 | 0.0, 4.5 | −0.5, 4.0 | 0.0, 4.0 | −0.5, 6.5
Days22_28
N | 23 | 77 | 21 | 18 | 139
Mean (SD) | 3.1 (1.8) | 2.9 (1.4) | 1.6 (1.7) | 1.6 (1.6) | 2.6 (1.6)
95% CI | 2.3, 3.8 | 2.6, 3.2 | 0.8, 2.4 | 0.8, 2.4 | 2.3, 2.8
Median | 3.0 | 3.0 | 1.0 | 1.5 | 2.5
Min, Max | 0.5, 10.0 | 0.0, 7.5 | −1.1, 6.0 | −0.7, 5.0 | −1.1, 10.0

Baseline is defined as the assessments taken at Pre-Dose.

Change from baseline is the follow-up value minus the baseline value.

Table 14.3.4.12.1 Summary of Vital Signs Heart Rate (bpm) by Scheduled Visit, Gestational and Postnatal Age Stratum

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 39 | 103 | 31 | 27 | 200
Mean (SD) | 155.8 (16.4) | 156.5 (15.9) | 145.8 (19.6) | 151.7 (18.9) | 154.1 (17.3)
95% CI | 150.5, 161.1 | 153.4, 159.6 | 138.7, 153.0 | 144.2, 159.2 | 151.6, 156.5
Median | 154.0 | 156.0 | 149.0 | 156.0 | 154.0
Min, Max | 121.0, 189.0 | 122.0, 198.0 | 100.0, 174.0 | 110.0, 177.0 | 100.0, 198.0
Days22_28
N | 36 | 97 | 28 | 26 | 187
Mean (SD) | 158.8 (10.8) | 155.4 (14.2) | 156.9 (15.7) | 147.8 (16.2) | 155.2 (14.4)
95% CI | 155.1, 162.5 | 152.5, 158.2 | 150.8, 162.9 | 141.3, 154.4 | 153.1, 157.3
Median | 156.0 | 155.0 | 160.0 | 151.0 | 155.0
Min, Max | 143.0, 183.0 | 120.0, 192.0 | 124.0, 180.0 | 110.0, 184.0 | 110.0, 192.0

Table 14.3.4.12.2 Summary of Vital Signs Respiration Rate (rpm) by Scheduled Visit, Gestational and Postnatal Age Stratum

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 31 | 87 | 28 | 23 | 169
Mean (SD) | 46.2 (15.1) | 48.0 (15.7) | 45.4 (18.2) | 51.6 (12.0) | 47.7 (15.6)
95% CI | 40.6, 51.7 | 44.7, 51.4 | 38.3, 52.5 | 46.4, 56.7 | 45.4, 50.1
Median | 45.0 | 46.0 | 41.5 | 48.0 | 45.0
Min, Max | 15.0, 88.0 | 14.0, 90.0 | 14.0, 120.0 | 32.0, 76.0 | 14.0, 120.0
Days22_28
N | 36 | 91 | 28 | 26 | 181
Mean (SD) | 52.1 (9.0) | 52.1 (16.0) | 49.5 (10.3) | 51.3 (11.6) | 51.6 (13.4)
95% CI | 49.0, 55.1 | 48.8, 55.4 | 45.5, 53.5 | 46.6, 55.9 | 49.6, 53.5
Median | 53.0 | 52.0 | 52.0 | 49.0 | 52.0
Min, Max | 38.0, 72.0 | 15.0, 96.0 | 30.0, 68.0 | 33.0, 76.0 | 15.0, 96.0

Respiration rates above 120 rpm (n=12) and below 4 rpm (n=2) were excluded from this analysis. These extreme values were all High Frequency respiration type.

Table 14.3.4.12.3 Summary of Vital Signs Systolic Blood Pressure (mmHg) by Scheduled Visit, Gestational and Postnatal Age Stratum

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 38 | 103 | 30 | 27 | 198
Mean (SD) | 56.7 (14.1) | 65.2 (15.4) | 72.2 (13.7) | 78.6 (14.3) | 66.5 (16.1)
95% CI | 52.1, 61.4 | 62.2, 68.2 | 67.1, 77.3 | 72.9, 84.2 | 64.2, 68.7
Median | 55.5 | 65.0 | 71.5 | 78.0 | 66.0
Min, Max | 32.0, 83.0 | 30.0, 100.0 | 49.0, 103.0 | 54.0, 116.0 | 30.0, 116.0
Days22_28
N | 36 | 97 | 26 | 24 | 183
Mean (SD) | 66.6 (12.8) | 71.2 (13.0) | 80.6 (12.3) | 89.3 (12.0) | 74.0 (14.5)
95% CI | 62.3, 71.0 | 68.6, 73.9 | 75.6, 85.6 | 84.3, 94.4 | 71.9, 76.2
Median | 69.5 | 71.0 | 81.5 | 90.5 | 74.0
Min, Max | 38.0, 94.0 | 40.0, 97.0 | 57.0, 115.0 | 56.0, 109.0 | 38.0, 115.0

Table 14.3.4.12.4 Summary of Vital Signs Diastolic Blood Pressure (mmHg) by Scheduled Visit, Gestational and Postnatal Age Stratum

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Pre_Dose (Baseline)
N | 38 | 103 | 30 | 27 | 198
Mean (SD) | 35.3 (10.6) | 37.1 (10.6) | 44.2 (11.1) | 42.7 (8.5) | 38.6 (10.9)
95% CI | 31.8, 38.8 | 35.0, 39.2 | 40.0, 48.4 | 39.4, 46.1 | 37.1, 40.1
Median | 35.0 | 38.0 | 42.0 | 43.0 | 39.0
Min, Max | 17.0, 58.0 | 16.0, 63.0 | 27.0, 74.0 | 26.0, 59.0 | 16.0, 74.0
Days22_28
N | 36 | 97 | 26 | 24 | 183
Mean (SD) | 36.4 (9.3) | 40.6 (10.2) | 42.2 (6.0) | 48.6 (14.9) | 41.0 (10.8)
95% CI | 33.2, 39.5 | 38.5, 42.6 | 39.8, 44.6 | 42.3, 54.9 | 39.5, 42.6
Median | 39.5 | 41.0 | 42.5 | 47.5 | 41.0
Min, Max | 11.0, 49.0 | 16.0, 69.0 | 32.0, 55.0 | 27.0, 93.0 | 11.0, 93.0

Table 14.3.4.13.1 Summary of Change Vital Signs Heart Rate (bpm) from Baseline to each Scheduled Visit, Gestational and Postnatal Age Stratum

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days22_28 Change From Baseline
N | 36 | 97 | 28 | 26 | 187
Mean (SD) | 3.8 (21.0) | −0.2 (18.0) | 12.0 (23.7) | −3.5 (22.1) | 1.9 (20.5)
95% CI | −3.3, 11.0 | −3.8, 3.4 | 2.8, 21.2 | −12.4, 5.5 | −1.0, 4.9
Median | 4.0 | 1.0 | 13.0 | −4.0 | 2.0
Min, Max | −42.0, 46.0 | −50.0, 42.0 | −32.0, 48.0 | −46.0, 46.0 | −50.0, 48.0

Baseline is defined as the assessments taken at Pre-Dose.

Change from baseline is the follow-up value minus the baseline value.

Table 14.3.4.13.2 Summary of Change Vital Signs Respiration Rate (rpm) from Baseline to each Scheduled Visit, Gestational and Postnatal Age Stratum

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days22_28 Change From Baseline
N | 30 | 82 | 25 | 23 | 160
Mean (SD) | 5.5 (14.7) | 3.8 (21.5) | 6.8 (17.2) | −0.3 (16.1) | 4.0 (19.0)
95% CI | 0.1, 11.0 | −1.0, 8.5 | −0.3, 13.9 | −7.3, 6.6 | 1.0, 7.0
Median | 4.5 | 2.0 | 12.0 | −1.0 | 3.0
Min, Max | −18.0, 40.0 | −63.0, 56.0 | −30.0, 41.0 | −43.0, 28.0 | −63.0, 56.0

Baseline is defined as the assessments taken at Pre-Dose.

Change from baseline is the follow-up value minus the baseline value.

Respiration rates above 120 rpm (n=12) and below 4 rpm (n=2) were excluded from this analysis. These extreme values were all High Frequency respiration type.

Table 14.3.4.13.3 Summary of Change Vital Signs Systolic Blood Pressure (mmHg) from Baseline to each Scheduled Visit, Gestational and Postnatal Age Stratum

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days22_28 Change From Baseline
N | 35 | 97 | 26 | 24 | 182
Mean (SD) | 9.6 (14.1) | 5.7 (12.8) | 8.2 (17.5) | 9.7 (16.5) | 7.3 (14.3)
95% CI | 4.7, 14.4 | 3.1, 8.3 | 1.1, 15.2 | 2.7, 16.7 | 5.2, 9.4
Median | 13.0 | 5.0 | 7.0 | 7.5 | 7.5
Min, Max | −21.0, 34.0 | −26.0, 39.0 | −40.0, 46.0 | −26.0, 46.0 | −40.0, 46.0

Baseline is defined as the assessments taken at Pre-Dose.

Change from baseline is the follow-up value minus the baseline value.

Table 14.3.4.13.4 Summary of Change Vital Signs Diastolic Blood Pressure (mmHg) from Baseline to each Scheduled Visit, Gestational and Postnatal Age Stratum

Population: Safety Patients

Assessments/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Assessments/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Days22_28 Change From Baseline
N | 35 | 97 | 26 | 24 | 182
Mean (SD) | 1.8 (12.4) | 3.4 (10.5) | −2.3 (11.5) | 5.3 (14.8) | 2.5 (11.8)
95% CI | −2.5, 6.1 | 1.2, 5.5 | −6.9, 2.4 | −1.0, 11.5 | 0.8, 4.2
Median | 5.0 | 3.0 | 0.5 | 3.5 | 3.0
Min, Max | −28.0, 27.0 | −17.0, 34.0 | −24.0, 16.0 | −18.0, 41.0 | −28.0, 41.0

Baseline is defined as the assessments taken at Pre-Dose.

Change from baseline is the follow-up value minus the baseline value.

Table 14.3.5 Concomitant Medications ^1^ by Gestational and Postnatal Age Stratum

Population: Safety Participants

Category/Statistics | GA <32 Weeks | | GA ≥32 Weeks | | Total (N=200)
Category/Statistics | PNA <2 Weeks (N=39) | PNA ≥2 Weeks (N=103) | PNA <2 Weeks (N=31) | PNA ≥2 Weeks (N=27) | Total (N=200)
Number of Participants | 39 (100.0%) | 103 (100.0%) | 31 (100.0%) | 27 (100.0%) | 200 (100.0%)
Number of Participants with Concomitant Medication | 39 (100.0%) | 103 (100.0%) | 28 (90.3%) | 26 (96.3%) | 196 (98.0%)
Prior Medication Name
0.9% NACI LOCK FINISH | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
25% ALBUMIN | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
ACETAMINOPHEN | 1 (2.6%) | 9 (8.7%) | 5 (16.1%) | 8 (29.6%) | 23 (11.5%)
ACETAZOLAMIDE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
ACETYLCYSTEINE | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
ACYCLOVIR | 0 (0.0%) | 1 (1.0%) | 1 (3.2%) | 2 (7.4%) | 4 (2.0%)
ALBUMIN | 2 (5.1%) | 4 (3.9%) | 1 (3.2%) | 1 (3.7%) | 8 (4.0%)
ALBUMIN HUMAN | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
ALBUTEROL | 0 (0.0%) | 4 (3.9%) | 1 (3.2%) | 0 (0.0%) | 5 (2.5%)
ALBUTEROL INH | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
ALBUTEROL INHALANT | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
ALBUTEROL SULFATE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
ALPROSTADIL | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
ALTEPLASE | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
AMIKACIN | 4 (10.3%) | 11 (10.7%) | 1 (3.2%) | 1 (3.7%) | 17 (8.5%)
AMINOPHYLLINE | 5 (12.8%) | 6 (5.8%) | 0 (0.0%) | 0 (0.0%) | 11 (5.5%)
AMOXICILLIN | 0 (0.0%) | 3 (2.9%) | 0 (0.0%) | 1 (3.7%) | 4 (2.0%)
AMOXICILLIN + CLAVULANATE | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
AMPHOTERCIN B LIPOSOME | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
AMPHOTERICIN B | 2 (5.1%) | 4 (3.9%) | 0 (0.0%) | 0 (0.0%) | 6 (3.0%)
AMPHOTERICIN B LIPID COMPLEX | 1 (2.6%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
AMPHOTERICIN B LIPOSOME | 2 (5.1%) | 4 (3.9%) | 0 (0.0%) | 0 (0.0%) | 6 (3.0%)
AMPICILLIN | 9 (23.1%) | 17 (16.5%) | 8 (25.8%) | 3 (11.1%) | 37 (18.5%)
AMPICILLIN + SULBACTAM | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
ANESTHESIA INHALED GAS | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
AQUAPHOR TOP OINT. | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
ARGININE HC | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
ARGININE HCL | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
ATROPINE | 1 (2.6%) | 4 (3.9%) | 0 (0.0%) | 0 (0.0%) | 5 (2.5%)
ATROPINE EYE DROP | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
AZITHROMYCIN | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
BACITRACIN | 1 (2.6%) | 2 (1.9%) | 1 (3.2%) | 1 (3.7%) | 5 (2.5%)
BACITRACIN OINT | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
BACITRACIN OINTMENT | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
BACITRACIN TOP. | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
BACITRACIN TOPICAL | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
BACITRACIN TOPICAL OINTMENT | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
BACITRACIN-POLYMYCIN B OINT | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
BACTRACIAN | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
BACTROBAN OINT. | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
BONE PROTEIN | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
BUDESONIDE | 0 (0.0%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
BUMETANIDE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
CAFFEINE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
CAFFEINE CITRATE | 19 (48.7%) | 52 (50.5%) | 2 (6.5%) | 0 (0.0%) | 73 (36.5%)
CAFFINE CITRATE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
CALCITREL | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
CALCITRIOL | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
CALCITROL | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
CALCIUM CHLORIDE | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
CALCIUM GLUCONATE | 5 (12.8%) | 4 (3.9%) | 1 (3.2%) | 0 (0.0%) | 10 (5.0%)
CASPOFUNGIN | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
CEFAZOLIN | 0 (0.0%) | 2 (1.9%) | 1 (3.2%) | 0 (0.0%) | 3 (1.5%)
CEFAZOLIN XT | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
CEFEPIME | 1 (2.6%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
CEFOTAXIME | 2 (5.1%) | 5 (4.9%) | 2 (6.5%) | 0 (0.0%) | 9 (4.5%)
CEFOXITIN | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
CEFTAZIDIME | 1 (2.6%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
CHLORAL HYDRATE | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 2 (7.4%) | 2 (1.0%)
CHLOROTHIAZIDE | 1 (2.6%) | 8 (7.8%) | 0 (0.0%) | 1 (3.7%) | 10 (5.0%)
CIPROFLOXACIN | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
CISATRACURIUM | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
CISTATRACURONIUM | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
CLINDAMYCIN | 6 (15.4%) | 12 (11.7%) | 2 (6.5%) | 0 (0.0%) | 20 (10.0%)
COLLAGENASE | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
CYCLOMYDRIL | 0 (0.0%) | 10 (9.7%) | 0 (0.0%) | 1 (3.7%) | 11 (5.5%)
CYCLOMYDRIL EYE GTTS SOC | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
CYCLOMYDRIL OPHTH. SOLUTION | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
CYCLOMYDRIL OPTH GTTS | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
CYCLOMYDRIL OPTHALMIC GTTS | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
CYCLOMYDRIL OPTHALMIC GTTS SOC | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
CYCLOMYDRILL | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
CYCLOPENTOLATE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
CYCLOPENTOLATE PHENYLEPHRINE | 0 (0.0%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
CYCLOPENTOLATE-PHENYLEPHRINE OPHTHALMIC SOLUTION | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
D10W IMB & HEPARIN | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
DEXAMETHASONE | 0 (0.0%) | 8 (7.8%) | 0 (0.0%) | 1 (3.7%) | 9 (4.5%)
DEXTROSE BOLUS (D10) | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
DIGOXIN | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
DIPHENHYDRAMINE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
DOBUTAMINE | 5 (12.8%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 8 (4.0%)
DOPAMINE | 15 (38.5%) | 16 (15.5%) | 4 (12.9%) | 0 (0.0%) | 35 (17.5%)
DORNASE ALFA | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
DTP HEPATITIS B, IPV | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
ELEMENTAL CALCIUM | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
EPINCPHRINE | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
EPINEPHERINE | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
EPINEPHRINE | 2 (5.1%) | 8 (7.8%) | 0 (0.0%) | 0 (0.0%) | 10 (5.0%)
EPINEPHRINE DRIP | 2 (5.1%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
EPINEPHRINE RACEMIC INHALED | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
EPOIETIN ALPHA | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
ERYTHROMYCIN | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
ERYTHROMYCIN EYE OINT | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
ESOMEPRAZOLE | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
EXOXAPRIN | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
FAMOTIDINE | 1 (2.6%) | 4 (3.9%) | 0 (0.0%) | 1 (3.7%) | 6 (3.0%)
FAT EMULSION | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
FAT EMULSIONS 20% | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
FENTANYL | 16 (41.0%) | 34 (33.0%) | 11 (35.5%) | 9 (33.3%) | 70 (35.0%)
FERROUS SULFATE | 0 (0.0%) | 4 (3.9%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
FLUCONAZOLE | 14 (35.9%) | 28 (27.2%) | 3 (9.7%) | 6 (22.2%) | 51 (25.5%)
FRESH FROZEN PLASMA | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
FUROSEMIDE | 18 (46.2%) | 59 (57.3%) | 6 (19.4%) | 8 (29.6%) | 91 (45.5%)
FUROSEMIDE XT DOSE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
GAMUNEX, IVIG | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
GENTAMICIN | 24 (61.5%) | 52 (50.5%) | 13 (41.9%) | 12 (44.4%) | 101 (50.5%)
GENTAMICIN OPTH. OINTMENT | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
GLYCERIN | 0 (0.0%) | 4 (3.9%) | 2 (6.5%) | 0 (0.0%) | 6 (3.0%)
GLYCERIN CHIP | 2 (5.1%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
GLYCERIN CHIP SUPP | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
GLYCERIN ENEMA | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
GLYCERIN PRN | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
GLYCERIN SUPP. | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
GLYCERIN SUPPOS | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
GLYCERIN SUPPOSITORIES | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
GLYCERIN SUPPOSITORY | 2 (5.1%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 5 (2.5%)
HEPARIN | 5 (12.8%) | 11 (10.7%) | 2 (6.5%) | 6 (22.2%) | 24 (12.0%)
HEPARIN FLUSH | 0 (0.0%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
HEPARIN FLUSH 10 U/ML | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
HEPARIN FLUSH 10 UNIT/ML | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
HEPARIN FLUSH 5 UNIT | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
HEPARIN LOCK FLUSH | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
HEPARIN LOCK FLUSH 10 UNIT/ML | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
HEPATITIS B VACCINE | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
HYALURONIDASE | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
HYALURONIDOSE | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
HYDRALAZINE | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
HYDROCHLOROTHIAZIDE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
HYDROCORTISONE | 16 (41.0%) | 25 (24.3%) | 2 (6.5%) | 2 (7.4%) | 45 (22.5%)
HYDROCORTISONE NA SUCCINATE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
HYDROCORTISONE NA-SUCCINATE INJECTION | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
IBUPROFEN | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
IMMUNE GLOBULIN IGG | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
INDOMETHACIN | 2 (5.1%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
INSULIN | 5 (12.8%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 6 (3.0%)
INTRALIPID | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
INTRALIPIDS | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
IPRATROPIUM | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
IPRATROPRIUM | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
ISOVUE | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
IVIG | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
K GTT PRN SLIDING SCALE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
K PHOS | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
K PHOS RIDER | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
K+ RIDER | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
KCL | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
KCL GTT | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
KCL RIDER | 0 (0.0%) | 2 (1.9%) | 1 (3.2%) | 0 (0.0%) | 3 (1.5%)
LABETALOL | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
LACRILUBE EYE OINT OU. | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
LACTACTED RINGERS SOLUTION | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
LACTATED RINGERS INJ | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
LANSOPRAZOLE | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 1 (3.7%) | 3 (1.5%)
LASIX | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
LEVA/BUTEROL INHALANT | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
LEVALBUTEROL | 0 (0.0%) | 4 (3.9%) | 0 (0.0%) | 1 (3.7%) | 5 (2.5%)
LEVOTHYROXINE (T4) | 0 (0.0%) | 3 (2.9%) | 0 (0.0%) | 1 (3.7%) | 4 (2.0%)
LIDOCAINE | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
LIDOCAINE SUB-CUTANEOUS | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
LINEZOLID | 1 (2.6%) | 2 (1.9%) | 1 (3.2%) | 0 (0.0%) | 4 (2.0%)
LORAZEPAM | 5 (12.8%) | 14 (13.6%) | 4 (12.9%) | 4 (14.8%) | 27 (13.5%)
LOVENOX | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
MAGNESIUM SULFATE | 1 (2.6%) | 1 (1.0%) | 1 (3.2%) | 0 (0.0%) | 3 (1.5%)
MEROPENEM | 4 (10.3%) | 9 (8.7%) | 1 (3.2%) | 4 (14.8%) | 18 (9.0%)
METHADONE | 0 (0.0%) | 5 (4.9%) | 0 (0.0%) | 5 (18.5%) | 10 (5.0%)
METOCLOPROMIDE | 0 (0.0%) | 3 (2.9%) | 0 (0.0%) | 1 (3.7%) | 4 (2.0%)
METRONIDAZOLE | 1 (2.6%) | 7 (6.8%) | 0 (0.0%) | 2 (7.4%) | 10 (5.0%)
MICAFUNGIN | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 3 (1.5%)
MIDAZOLAM | 9 (23.1%) | 32 (31.1%) | 9 (29.0%) | 10 (37.0%) | 60 (30.0%)
MIDAZOLAM XT | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
MILRINONE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
MILRINONE - 0.5 MCG/KG/MIN | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
MORPHINE | 18 (46.2%) | 39 (37.9%) | 7 (22.6%) | 7 (25.9%) | 71 (35.5%)
MULTIVITAMIN | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
MULTIVITAMIN DROPS | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
MULTIVITAMIN DROPS & FE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
MULTIVITAMIN WITH FE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
MUPIROCEN | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
MUPIROCIN | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
MUPIROCIN 290 | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
MVI | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
MVI WITH FE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
MYDRIACYL | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
NA BICARB | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
NA PHOS | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
NACI - SALINE LOCK FLUSH | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
NACI BOLUS | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
NACI SUPPLEMENT | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
NACL BOLUS | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
NAFCILLIN | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
NALBUPHINE | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
NEUTRA PHOS | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
NIPRIDE | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
NITRIC OXIDE | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
NITROGLYCERIN OINTMENT | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
NITROPASTE | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
NORMAL SALINE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
NORMAL SALINE BOLUS | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
NOVOSEVEN | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
NYSTATIN | 4 (10.3%) | 10 (9.7%) | 5 (16.1%) | 4 (14.8%) | 23 (11.5%)
NYSTATIN OINTMENT | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
NYSTATIN ORAL SUSP. | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
NYSTATIN POWDER | 1 (2.6%) | 4 (3.9%) | 0 (0.0%) | 0 (0.0%) | 5 (2.5%)
OPTIRAY CT CONTRAST | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
OSETLAMIVIR | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
OXACILLIN | 2 (5.1%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
PALIVIZUMAB | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
PALIVIZUMAB - SYNAGIS | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
PANCURONIUM | 4 (10.3%) | 2 (1.9%) | 2 (6.5%) | 0 (0.0%) | 8 (4.0%)
PANTOPRAZOLE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
PAPAVERINE | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 2 (7.4%) | 4 (2.0%)
PAPAVERINE HCL | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
PBBC S | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
PBBC S PRN | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
PEPSID | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
PHENOBARBITAL | 6 (15.4%) | 8 (7.8%) | 0 (0.0%) | 3 (11.1%) | 17 (8.5%)
PHENYLEPHRINE | 0 (0.0%) | 13 (12.6%) | 0 (0.0%) | 0 (0.0%) | 13 (6.5%)
PHENYLEPHRINE 2.5% OPTH SOLUTION | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
PHENYLEPHRINE OPHTHALMIC SOLUTION | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
PHYLEPHRINE GTTS | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
PHYTONADINE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
PHYTONADION | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
PHYTONADIONE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
PIPERACILLIN | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
PIPERACILLIN & TAZOBACTUM | 1 (2.6%) | 1 (1.0%) | 1 (3.2%) | 0 (0.0%) | 3 (1.5%)
PIPERACILLIN + TAZOBACTUM | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
PIPERACILLIN+TAZOBACTUM | 3 (7.7%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
PLAIN YOGURT | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
PLATELETS | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
POLY-VI-SOL & IRON | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
POLYMYXIN B SULFATE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
POLYVISOL | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
POTASSIUM | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
POTASSIUM CHLORIDE | 5 (12.8%) | 7 (6.8%) | 1 (3.2%) | 1 (3.7%) | 14 (7.0%)
POTASSIUM CHLORIDE BOLUS | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
POTASSIUM PHOSPHATE | 1 (2.6%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
POTASSIUM PHOSPHATE BOLUS | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
PRBC | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
PREDNISOLONE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
PREDNISONE | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
PROPARACAINE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
PROPARACINE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
PULMICORT | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
PULMOZYME | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
RACEMIC EPI | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
RANITIDINE | 4 (10.3%) | 8 (7.8%) | 4 (12.9%) | 4 (14.8%) | 20 (10.0%)
RECOMBIVAX | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
RED BLOOD CELLS | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 1 (3.7%) | 2 (1.0%)
REGITINE | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
RETINOIC ACID | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
RIFAMPIN | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
ROCURONIUM | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
SEPTRA | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
SILDENAFIL | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 2 (7.4%) | 3 (1.5%)
SILVER SULFADIAZINE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
SILVER-HYDROCOLLOID | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
SILVER-SULFADIAZINE | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
SINCALIDE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
SODIUM BICARB | 2 (5.1%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
SODIUM BICARB KCL | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
SODIUM BICARB. | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
SODIUM BICARBONATE | 5 (12.8%) | 2 (1.9%) | 0 (0.0%) | 1 (3.7%) | 8 (4.0%)
SODIUM CHLORIDE | 2 (5.1%) | 5 (4.9%) | 0 (0.0%) | 1 (3.7%) | 8 (4.0%)
SODIUM CHLORIDE 0.9% | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
SODIUM PHOSPHATE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
SOLUMEDROL | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
SPIRONOLACTONE | 0 (0.0%) | 4 (3.9%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
STUDY FUROSEMIDE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
SUCROSE | 0 (0.0%) | 0 (0.0%) | 1 (3.2%) | 0 (0.0%) | 1 (0.5%)
SUCROSE 24: PRN | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
SULAMYD EYE GTTS | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
SYNAGIS | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (3.7%) | 1 (0.5%)
TERBUTALINE | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
THAM | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
TOBRAMYCIN | 3 (7.7%) | 5 (4.9%) | 0 (0.0%) | 1 (3.7%) | 9 (4.5%)
TPN | 1 (2.6%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 4 (2.0%)
TPN NEONATAL | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
TROPICAMIDE | 0 (0.0%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
TROPICAMIDE 1% OPTH SOLUTION | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
TROPICAMIDE 1% OPTHALMIC SOLUTION | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
TROPICAMIDE GTTS | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
TROPICAMIDE OPHTHALMIC SOLUTION | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
TROPICAMIDE OPTHALMIC SOLUTION | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
URSODIOL (URSODEOXYCHOLIC ACID) | 0 (0.0%) | 2 (1.9%) | 0 (0.0%) | 2 (7.4%) | 4 (2.0%)
VANCOMYCIN | 22 (56.4%) | 64 (62.1%) | 7 (22.6%) | 13 (48.1%) | 106 (53.0%)
VANCOMYCIN FLUSH FOR PICC | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
VASOPRESSIN | 0 (0.0%) | 3 (2.9%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)
VECURONIUM | 1 (2.6%) | 9 (8.7%) | 0 (0.0%) | 2 (7.4%) | 12 (6.0%)
VERSED | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
VIT A | 1 (2.6%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 2 (1.0%)
VIT E | 0 (0.0%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
VIT. A | 1 (2.6%) | 0 (0.0%) | 0 (0.0%) | 0 (0.0%) | 1 (0.5%)
VITAMIN A | 9 (23.1%) | 7 (6.8%) | 0 (0.0%) | 0 (0.0%) | 16 (8.0%)
VITAMIN K | 2 (5.1%) | 1 (1.0%) | 0 (0.0%) | 0 (0.0%) | 3 (1.5%)

The percentages are based on the total number of safety Participants in each age group or total.

Participants are counted once for each prior medication.

1 Concomitant medication is defined as the medications taken on or after the first study drug administration.