# 13 DISCUSSION AND OVERALL CONCLUSIONS

## 13.1 Primary Objective

### Pharmacokinetics

The final population model is:

V (L/kg) = θ_(1)_ * (ALB/2.3)^θ(5)^;

C_L_ (L/h/kg) =θ_(2)_ * (0.5/SCR)^θ(3)^ * (PCA/32.7)^θ(4)^

where θ_(1)_=0.460, θ_(2)_=0.122, θ_(3)_=0.267, θ_(4)_=1.460, θ_(5)_ = −0.444.

At the following doses, therapeutic meropenem concentrations will be obtained in almost all infants ≤ 90 days of age:

- 20 mg/kg every 12 hours in infants <32 weeks GA and PNA <2 weeks
- 20 mg/kg every 8 hours in infants <32 weeks GA and PNA ≥2 weeks
- 20 mg/kg every 8 hours in infants ≥32 weeks GA and PNA <2 weeks
- 30 mg/kg every 8 hours in infants ≥32 weeks GA and PNA ≥2 weeks

### Safety

Overall, meropenem was well tolerated in this population. Because of the association of imipenem-cilastatin with seizures, the potential for adverse CNS effects, particularly seizures, has been carefully studied with meropenem in older participants. Meropenem has less affinity for GABA receptors and has been found to cause less neurotoxicity than imipenem both in animal models and during clinical trials^27,^ ^28^. In trials comparing meropenem to cephalosporin regimens, the incidence of seizures was not significantly different between groups^1^. The only seizures reported in meropenem-treated pediatric participants in clinical studies published prior to January 2011 have occurred during treatment for meningitis^27^. In the present trial, clinical seizures were reported in 10 (5.0%) of 200 infants; however, only two were confirmed by EEG and none were considered to be probably or definitely related to meropenem. Because a comparator arm was not included in this trial, it is difficult to assess if the rate of seizures associated with meropenem is above the background seizure rate for this population. The majority of infants enrolled in this study were <32 weeks GA and critically ill at baseline; 177 (88.5%) had respiratory problems, 179 (89.5%) had gastrointestinal problems, and 146 (73.0%) had cardiovascular problems.

## 13.2 Secondary Objectives

### Efficacy

Treatment success was defined as 1) alive at efficacy visit; 2) culture negative; and 3) clinical cure score ≥7 at efficacy visit. Treatment failure was defined as 1) death prior to efficacy visit; 2) change in antibiotic therapy (except addition of Gram positive therapy in the presence of a positive culture); or 3) clinical cure score <7. Overall, in 162 (84.4%) participants treatment was successful. Success was lowest in infants <32 weeks gestation and <2 weeks postnatal age, 29/39 (74.4%). Failure occurred most frequently as a result of change in antibiotic therapy, 23/30 (76.7%). No participants were culture positive after meropenem therapy for non-Staphylococcus spp.