# 4 SYNOPSIS

NAME OF SPONSOR/COMPANY: NICHD
NAME OF FINISHED PRODUCT: Meropenem
NAME OF ACTIVE INGREDIENT: Meropenem

Title of Study: Multiple Dose Pharmacokinetic Study of Meropenem in Young Infants (<91 days) with Suspected or Complicated Intra-abdominal Infections

Principal Investigator: Danny Benjamin, MD, PhD, MPH, Duke Clinical Research Institute, 2400 Pratt Street, Durham, NC 27715

Study Period:; (date of first enrollment): June 19, 2008; (date of last completed): October 6, 2009 | Phase of Development: II

Study Objectives: This study evaluated the safety, tolerability and PK-PD of meropenem in infants <91 days of age with suspected and complicated intra-abdominal infections.

1. To characterize meropenem single-dose and multiple-dose PK in participants with suspected and complicated intra-abdominal infections.
2. To characterize the safety profile of meropenem in the treatment of suspected and complicated intra-abdominal infections.
3. To assess collected efficacy data for meropenem for the treatment of suspected and complicated intra-abdominal infections.

Methodology:

The dosing of meropenem, stratified by gestational age (GA) and postnatal age (PNA), was predicted to provide therapeutic exposure in the majority of infants. Infants were enrolled in four GA/PNA strata. Safety was assessed in real time by the Meropenem Off-Patent Drug Studies (MPODS) Clinical Events Safety Committee and by an independent Data Monitoring Committee (DMC). First dose and steady state meropenem PK were studied in an interim analysis by GA/PNA group after 12 babies were enrolled in a GA/PNA stratum. If the interim PK analysis suggested that the initial dosing did not achieve concentrations >MIC of 2 μg/ml for more than 75% of the dose interval in at least 90% of infants, then the dose would have been escalated. However, the interim analysis discovered that the initial dosing comfortably achieved the target MIC, so a higher dosage was not implemented. First dose and steady state meropenem PK were obtained along with ongoing safety evaluation. The final goal of 200 infants was reached when subsequent enrollment occurred in the safety group with steady state PK. The study scheme is illustrated in Figure 9.1. Table 9.1 illustrates the schematic representation of assessments. The following was the overall study design -

1) First dose and steady state meropenem PK was studied in infants <91 days of age using a population PK design.
2) There were four GA/PNA groups.
3) Two hundred (200) infants were enrolled.
  a. First dose and steady state PK - 12 infants were enrolled in 4 GA/PNA strata at initial dose (48 infants).
  b. Safety and steady state PK - 152 additional infants were enrolled for ongoing safety evaluation and further collection of steady state PK data.
4) Investigators were encouraged to provide infants with concomitant aminoglycoside therapy. Use of other antimicrobial agents was discouraged but may have been given per local standard of care.

The 200 infants in this trial received at least 3 days and no more than 21 days of therapy with meropenem. Infants were given therapy until the attending physician believed that the infant has had presumptive clinical cure.

Number of Participants (Planned and Analyzed):

Planned: A total of 200 infants at 24 study sites in the US were to be analyzed. These participants were subdivided into the following four groups:

- Group 1: GA at birth below 32 weeks - PNA <2 weeks;
- Group 2: GA at birth below 32 weeks - PNA ≥2 weeks and <91 days;
- Group 3: GA at birth 32 weeks or older - PNA <2 weeks;
- Group 4: GA at birth 32 weeks or older - PNA ≥2 weeks and <91 days.

Analyzed: A total of 200 participants at 24 study sites were enrolled.

Diagnosis and Main Criteria for Inclusion:

Inclusion Criteria:

1. Written permission from parent or legal guardian
2. Age <91 days
3. Likely to survive beyond the first 48 hours after enrollment
4. Sufficient intravascular access (either peripheral or central) to receive study drug
5. AND ONE OF THE FOLLOWING:
  a) Physical, radiological, and/or bacteriological findings of a complicated intra-abdominal infection. These include peritonitis, NEC Grade II or higher by Bell’s criteria, Hirschsprung’s disease with perforation, spontaneous perforation, meconium ileus with perforation, bowel obstruction with perforation, as evidenced by free peritoneal air on abdominal radiograph, intestinal pneumatosis or portal venous gas on abdominal radiographic examination.
  b) Possible NEC
  c) Otherwise receiving meropenem per local standard of care

Exclusion Criteria:

1. Renal dysfunction evidenced by urine output <0.5 mL/hr/kg over the prior 24 hours.
2. Serum creatinine >1.7 mg/dL
3. History of clinical seizures or EEG confirmed seizures
4. Concomitant treatment with another carbapenem (ertapenem or imipenem) at the time of informed consent
5. Any condition which would make the participant or the caregiver, in the opinion of the investigator, unsuitable for the study

Test Product, Dose and Mode of Administration, Batch Number:

MERREM I.V. (Meropenem for injection) was supplied as 500mg/20ml single use vial (Batch Number – NM0156). The vials for packed as 50x packer vials (Batch Number – 22162.1/22162).

Duration of Treatment: At least 3 days and no more than 21 days

Reference Therapy, Dose and Mode of Administration, Batch Number:

Not Applicable

Criteria for Evaluation:

Pharmacokinetics: The following PK parameters were estimated:

- Plasma clearance
- Volume of distribution
- Cmax, Tmax, AUC _0-T_, (at steady state), K_e_ and T_1/2_
- AUC_0-∞_ (estimated from the 1^st^ dose)

The PK parameters and MIC were used to estimate pharmacodynamic parameters of exposure (time above MIC).

Efficacy: Efficacy was assessed 28 days after first dose of study drug.

[underlined: Success was defined by all of the following:]

- Alive and negative bacterial cultures (if obtained) from normally sterile body fluids, and presumptive clinical score ≥7

[underlined: Failure was defined by any of the following]

- Change in antibiotic therapy while on study drug except the addition of Gram positive therapy to treat organisms that require it
- Death
- Lack of presumptive clinical cure

Safety:

- Death
- Seizures
- Strictures
- Antimicrobial therapy failure
- Perforation once enrolled
- Wound Dehiscence
- Short bowel syndrome
- Development of ESBL infection
- Development of candidiasis
- Laboratory
- Growth parameters (weight, length and head circumference)

STATISTICAL METHODS:

This phase II study was carried out to assess the safety, tolerability and pharmacokinetics (PK)-pharmacodynamics (PD) of meropenem in infants <91 days of age with suspected or complicated intra-abdominal infections. The sample size of 200 was designed to assess single- and multiple-dose PK of meropenem in young infants.

Descriptive summaries are provided where appropriate for each of the primary and secondary variables. In general, summaries were computed for GA and PNA groups and overall. No inferential statistical tests were performed, unless otherwise specified.

Safety

The Safety Population includes all patients who receive any amount of study meropenem. An overall summary of treatment emergent AEs includes the number and percentage of patients with at least one TEAE, TEAEs by severity and relationship to study drug, special interest AEs (including seizures, level II Laboratory AE, and SAE), categories of SAEs, and TEAEs leading to study drug discontinuation are presented overall and by GA and PNA groups.

The key safety endpoints include: death, seizures, strictures, perforation, wound dehiscence, short gut, development of Extended Spectrum Beta Lactamase (ESBL) infection, development of candidiasis, and antimicrobial therapy failure. The number of and the proportion of patients affected, and the exact 95% binomial Confidence Interval (CI) of Proportion for each key safety endpoint were prepared for the Safety Population, by GA and PNA group. The p-values to test the expected proportion to the observed proportion for each safety endpoint are provided by GA and PNA group.

Efficacy

The Efficacy Population includes all patients who have efficacy assessment (Clinical Signs) at Pre-Dose and Study Day 28 (or the day that the Day 28 assessments were taken) or who have died during this period.

Success was defined by all of the following: alive, negative bacterial cultures (if obtained) from normally sterile body fluids and presumptive clinical cure score ≥7. Failure was defined by any of following: change in antibiotic therapy while on study drug (except the addition of Gram positive therapy to treat organisms that require it), death, or lack of presumptive clinical cure. The number and the percentages of patients who were considered as success/failure are presented by GA and PNA group.

This study was not powered to determine efficacy. No inferential statistical tests were performed. The data from this study will be used in assessing the feasibility of a potential efficacy study.

RESULTS:

Pharmacokinetic Analysis:

The initial dosing paradigm used 3 different dose levels in 4 age strata based on GA and PNA. A total of 780 scheduled plasma meropenem concentrations from 188 participants were available to construct the population PK model. A one-compartment model with proportional residual error was chosen to describe the PK of meropenem. Meropenem clearance was lowest in the most immature cohort (<32 weeks GA and <2 weeks PNA), 0.089 L/h/kg, and highest in the most mature cohort (≥32 weeks GA and ≥2 weeks PNA, 0.202 L/h/kg. As infants are relatively immune-compromised, the overall PD targets for meropenem concentrations were >4 μg/mL for 50% of the dosing interval and >2 μg/mL for 75% of the dosing interval. These targets were achieved in 95.7% and 92.0% of participants, respectively. Therefore, the initial dosing strategy met the overall goals for exposure. The final population model is:

V (L/kg) = θ_(1)_ * (ALB/2.3)^θ(5)^; C_L_ (L/h/kg) =θ_(2)_ * (0.5/SCR)^θ(3)^ * (PCA/32.7)^θ(4)^ where θ_(1)_=0.460, θ_(2)_=0.122, θ_(3)_=0.267, θ_(4)_=1.460, θ_(5)_ = −0.444.

The Monte Carlo simulation predicts that >99% of virtual participants will achieve the desired target.

At the following doses, therapeutic meropenem concentrations were obtained in almost all infants ≤90 days of age:

- 20 mg/kg every 12 hours in infants <32 weeks GA and PNA <2 weeks (n=32)
- 20 mg/kg every 8 hours in infants <32 weeks GA and PNA ≥2 weeks (n=103)
- 20 mg/kg every 8 hours in infants ≥32 weeks GA and PNA <2 weeks (n=31)
- 30 mg/kg every 8 hours in infants ≥32 weeks GA and PNA ≥2 weeks (n=27)

RESULTS:

Safety:

Meropenem was well tolerated in this open-label study of 200 infants. This cohort represented a group of critically ill infants with the following conditions at baseline: 88.5% with respiratory illness, 89.5% with gastrointestinal disorders, 73.0% with cardiovascular conditions, and 90.5% with blood/lymphatic system problems. The majority of these infants were premature with a median GA at birth of 27.8 weeks (22-40).

Overall, 99/200 (49.5%) infants suffered an AE during the study. The proportion of infants with AEs was highest, 26/39 (66.7%), among infants <32 weeks GA and <2 weeks PNA. Only 21/200 (10.5%) infants were determined to have an AE possibly related to meropenem, and this proportion was highest, 7/39 (17.9%), among infants <32 weeks GA and <2 weeks PNA. Of the 316 AEs reported, only 30 (9.5%) were determined by the investigators to be possibly related to meropenem. These 30 AEs included 7 seizures and 4 episodes of elevated bilirubin. No AE was determined to be probably or definitely related to meropenem.

For this study we defined an AE of special interest as either a seizure or a level II laboratory AE. Nine (4.2%) infants experienced a level II laboratory AE and all were <32 weeks GA. These 9 events included: 5 elevated conjugated bilirubin levels, 3 elevated serum creatinine levels, and 1 elevated aspartate aminotransferase concentration. Clinical seizures were reported in 10 (5.0%) infants; however, only 2 cases were confirmed by EEG. Five of the EEGs were negative for seizure and 3 participants with seizure did not have an EEG completed. Seizures were most commonly reported among infants <32 weeks GA and <2 weeks PNA 4/39 (10.3%).

A total of 36 SAEs were reported in 34 (17.0%) infants. SAEs were most commonly reported among infants <32 weeks GA and <2 weeks PNA, 9/39 (23.1%). Only 2 (5.6%) of the SAEs were determined to be possibly related to study drug (isolated ileal perforation and an episode of fungal sepsis). There were 11 (5.5%) deaths in the study population. None of the deaths were determined to be related to study drug. All deaths occurred in infants <32 weeks gestational age.

RESULTS:

Efficacy:

Of the 200 infants enrolled in the trial, 195 were included in the efficacy population and 192 of 195 (98.5%) were evaluable for efficacy. Mortality prior to the efficacy assessment was 8/192 (4.2%). Mortality was highest among infants <32 weeks gestational age and <2 weeks postnatal age, 3/39 (7.7%). None of the 50 infants with ≥32 weeks gestational age died prior to the efficacy visit. Efficacy success, defined as being alive with negative cultures from normally sterile body fluids and a presumptive clinical cure score ≥7 at the efficacy assessment, was achieved in 162/192 (84.4%) of the infants. Efficacy success was lowest among infants <32 weeks gestational age and <2 weeks postnatal age, 29/39 (74.4%) and highest among infants ≥32 weeks gestational age, 51/55 (92.7%).

CONCLUSIONS:

Overall, meropenem was well tolerated in this population. Because of the association of imipenem-cilastatin with seizures, the potential for adverse CNS effects, particularly seizures, has been carefully studied with meropenem in older participants. Meropenem has less affinity for GABA receptors and has been found to cause less neurotoxicity than imipenem both in animal models and during clinical trials^27,28^. In trials comparing meropenem to cephalosporin regimens, the incidence of seizures was not significantly different between groups^27^. The only seizures reported in meropenem-treated pediatric participants to date have occurred during treatment for meningitis^27^. In the present trial, clinical seizures were reported in 10 (5.0%) of 200 infants; however, only 2 cases were confirmed by EEG and none were felt to be probably or definitely related to meropenem. Because a comparator arm was not included in this trial, it is difficult to assess if the rate of seizures associated with meropenem is above the background seizure rate for this population. The majority of infants enrolled in this study were <32 weeks GA and critically ill at baseline; 177 (88.5%) had respiratory problems, 179 (89.5%) had gastrointestinal problems, and 146 (73.0%) had cardiovascular problems.

The final population model is:

V (L/kg) = θ_(1)_ * (ALB/2.3)^θ(5)^; C_L_ (L/h/kg) =θ_(2)_ * (0.5/SCR)^θ(3)^ * (PCA/32.7)^θ(4)^

Where θ_(1)_=0.460, θ_(2)_=0.122, θ_(3)_=0.267, θ_(4)_=1.460, θ_(5)_= −0.444.

At the following doses, therapeutic meropenem concentrations will be obtained in almost all infants ≤ 90 days of age:

- 20 mg/kg every 12 hours in infants <32 weeks GA and PNA <2 weeks
- 20 mg/kg every 8 hours in infants <32 weeks GA and PNA ≥2 weeks
- 20 mg/kg every 8 hours in infants ≥32 weeks GA and PNA <2 weeks
- 30 mg/kg every 8 hours in infants ≥32 weeks GA and PNA ≥ weeks

Treatment success was defined as 1) alive at efficacy visit; 2) culture negative; and 3) clinical cure score ≥7 at efficacy visit. Treatment failure was defined as 1) death prior to efficacy visit; 2) change in antibiotic therapy (except addition of Gram positive therapy in the presence of a positive culture); or 3) clinical cure score <7. Overall, 192 patients were evaluable for efficacy and in 162 (84.4%) participants, treatment was successful. Success was lowest in infants <32 weeks gestation and <2 weeks postnatal age, 29/39 (74.4%). Failure occurred most frequently as a result of change in antibiotic therapy, 23/30 (76.7%). No participants were culture positive for non-Staphylococcus spp after meropenem therapy.

Date of the Report: July 15, 2011