# 16 APPENDICES

16.1 Study Information
  16.1.1 Protocol and Protocol Amendments
  16.1.2 Sample Case Report Forms
  16.1.3 Information for Institutional Review Boards (IRBs) and Sample Parental Permission Forms and Participant Consents
  16.1.4 Investigator Information
  16.1.5 Signature Page
  16.1.6 Listing of Batch Numbers by Participant
  16.1.7 Randomization Scheme and Codes
  16.1.8 Audit Certificates
  16.1.9 Statistical Analysis Plan
  16.1.10 Documentation of Inter-laboratory Standardization Methods and Quality Assurance Procedures, if Used
  16.1.11 Publications Based on the Study
  16.1.12 Important Publications Referenced in the Report
  16.1.13 FDA Written Request
  16.1.14 Interim Analysis Documentation
16.2 Participant Data Listings
  16.2.1 Participant Disposition
  16.2.2 Fulfillment of Inclusion/Exclusion Criteria
  16.2.3 Demographic Characteristics
  16.2.4 Medical History
  16.2.5 Surgical History and Surgical Procedures
  16.2.6 Radiography Log
  16.2.7 Baseline Physical Examination
  16.2.8 Efficacy Evaluations
  16.2.9 Study Drug Indication and Administration
  16.2.10 Adverse Events
  16.2.11 Laboratory Measurements
  16.2.12 Vital Signs
  16.2.13 Prior Medications
  16.2.14 EEG Results
  16.2.15 Protocol Deviations
16.3 Case Report Forms for Participants of Special Interest
16.4 Additional Data
  16.4.1 Pharmacokinetics Report

For documents listed but not available for download, please check the DASH repository at https://dash.nichd.nih.gov/study/2091