# 4 GLOSSARY OF ABBREVIATIONS AND TERMS

ADHD: Attention Deficit Hyperactivity Disorder
AdvantageEDC^SM^: Emmes’ Electronic Data Capture System
AE: Adverse event
AIMS: Abnormal Involuntary Movement Scale
ALT: Alanine aminotransferase
ANCOVA: Analysis of Covariance
ANOVA: Analysis of Variance
ARI: Aripiprazole
ARS-IV: ADHD Rating Scale
ASQ: Autism Screening Questionnaire
AST (SGOT): Aspartate transaminase (serum glutamic-oxaloacetic transaminase)
ATM: Atomoxetine
AUC: Area Under the Curve
BARS: Barnes Akathisia Rating Scale
BD: Bipolar Disorder
BID: Twice a day
BPCA: Best Pharmaceuticals for Children Act
BPCA DCC: BPCA Data Coordinating Center (The Emmes Corporation)
BPRS-C: Brief Psychiatric Rating Scale for Children
BUN: Blood Urea Nitrogen
▬: ▬
CBC: Complete Blood Count
CBT: Cognitive-Behavioral Therapy
CDRS-R: Children’s Depression Rating Scale-Revised
CFF-CBT: Child- and Family- Focused Cognitive-Behavioral Therapy
CFR: Code of Federal Regulations
CGAS: Children’s Global Assessment Scale
CGI-I: Clinical Global Impressions Improvement Scale
CGI-S: Clinical Global Impressions Severity Scale
CL: Clearance
CL/F: Apparent Total Clearance
Cmax: Maximum Serum Concentration
Cmin: Minimum Serum Concentration
CMRS-P: Child Mania Rating Scale for Children
COLT1: Collaborative Lithium Trial 1 (NICHD-2005-07-1)
COLT2: Collaborative Lithium Trial 2 (NICHD-2005-07-2)
CPM: Citalopram
CPT: Continuous Performance Test
CRC: Clinical Research Center
CrCl: Creatinine Clearance
CRF: Case Report Form
C-SSRS: Columbia-Suicide Severity Rating Scale
DCC: Data Coordinating Center
DHHS: Department of Health and Human Services
D-KEFS: Delis-Kaplan Executive Function System
DMC: Data Monitoring Committee
DSMB: Data Safety Monitoring Board
DSM-IV: Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition
DSMP: Data Safety Monitoring Plan
DVP: Divalproex
ECG: Electrocardiogram
eCRF: Electronic Case Report Form
ED: Emergency department
EDC: Electronic Data Capture
EEG: Electroencephalogram
EOW: End of Week
ER: Emergency room
ET: Early Termination
FDA: Food and Drug Administration
FFT: Family-Focused Treatment
GCP: Good Clinical Practice
GFR: Glomerular Filtration Rate
HIPAA: Health Insurance Portability and Accountability Act
Hr: Hour
ICF: Informed consent form
ICH: International Conference on Harmonization
IND: Investigational New Drug
IPSRT: Interpersonal and Social Rhythm Therapy (IPSRT)
IRB: Institutional Review Board
ITT: Intent to Treat
IV: Intravenous
Kg: Kilogram
KSADS-PL: Kiddie Schedule for Affective Disorders and Schizophrenia - Present and Lifetime
L: Liter
LFT: Liver function test
Li+: Lithium
LOCF: Last Observation Carried Forward
LS: Least squares
LTE: Long-Term Effectiveness phase
LTG: Lamotrigine
MAS: Mixed Amphetamine Salts
MDD: Major Depressive Disorder
MedDRA: Medical Dictionary for Regulatory Activities
MEq/L: Milliequivalents per Liter
Mg: Milligram
Min: Minute
ML: Milliliter
MOF: Minimum objective function
MPH: Methylphenidate
MSE: Mental Status Exam
N: Number
NA: Not Applicable
NC: Noncompartmental
NELi: Neurological Examination for Lithium
Ng: Nanogram
NICHD: Eunice Kennedy Shriver National Institute of Child Health and Human Development
NIH: National Institutes of Health
NONMEM: Nonlinear mixed effect modeling
NRS: Neurological Rating Scale
OFC: Olanzapine/Fluoxetine Combination
OTC: Over the Counter
PARS: Pediatric Anxiety Rating Scale
PC: Phone Call
PCB: Placebo
PCS: Potentially Clinically Significant
PGBI-10M: Parent General Behavior Inventory-10 Item Mania Scale
PHI: Personal Health Information
PK: Pharmacokinetic
PODS: Pediatric Off-Patent Drug Study
PODS-PI: Pediatric Off-Patent Drug Study- Principal Investigator
PT: Preferred Term
PT/PTT: Prothrombin Time/ Partial Thromboplastin Time
QUE: Quetiapine
RBC: Red Blood Cell
RIS: Risperidone
RUPP: Research Units in Pediatric Psychopharmacology
SAE: Serious Adverse Event
SAP: Statistical analysis plan
SAS: Statistical analysis software
SD: Standard Deviation
SE: Standard Error of Mean
SEM: Standard Error of Mean
SGAs: Second Generation Antipsychotics
SOC: System Organ Class
SSRI: Selective Serotonin Reuptake Inhibitor
T1/2: Half-life
TEAE: Treatment Emergent Adverse Event
TID: Three times a day
Tmax: Time to Reach Maximum Serum Concentration
TSH: Thyroid Stimulating Hormone
UA: Urinalysis
ULN: Upper limit of normal
US: United States
USP: United States Pharmacopeia
V/F: Elimination Phase
VPA: Valproate, divalproex sodium
WASI: Wechsler Abbreviated Scales of Intelligence
WBC: White Blood Cell
WHO: World Health Organization
WR: Written Request
WRAML-2: Wide Range Assessment of Memory and Learning-2
YMRS: Young Mania Rating Scale