# 2 SYNOPSIS

NAME OF SPONSOR/COMPANY: Eunice Kennedy Shriver National Institute of Child Health and Human Development (NICHD)

NAME OF FINISHED PRODUCT: Lithium

NAME OF ACTIVE INGREDIENT: Lithium carbonate

TITLE OF STUDY: A Randomized, Double-Blind, Placebo Controlled Study of the Efficacy of Lithium for the Treatment of Pediatric Mania followed by an Open Label Long-Term Safety Period, Double-Blind, Placebo-Controlled Discontinuation Phase, and Open Label Restabilization Period

PRINCIPAL INVESTIGATOR: Robert Findling, MD, MBA

PUBLICATION: None

STUDY PERIOD: | PHASE OF DEVELOPMENT: 3
(date of first enrollment): May 04, 2010; (date of last completed): March 19, 2013

PRIMARY OBJECTIVES:

1. To determine if lithium is more efficacious in reducing symptoms of mania in the pediatric population than placebo.
2. To describe the short-term safety of lithium in the pediatric population relative to placebo treatment.
3. To examine the effectiveness and efficacy of lithium as a maintenance treatment for children and adolescents with bipolar I disorder.
4. To examine the long-term and short-term safety and tolerability of lithium in pediatric bipolar disorder.

SECONDARY OBJECTIVES:

1. To examine the effects of lithium treatment over time in the pediatric population on specific aspects of cognitive functioning that have been reported to be adversely affected by lithium in the adult population.
2. To examine the relationship between the systemic exposure to lithium and effectiveness and toxicity in the pediatric population.
3. To examine the long-term safety and tolerability of combination therapy (lithium plus other psychotropic agents) in pediatric bipolar disorder.
4. To critically assess the efficacy of lithium for prophylaxis against recurrence of mood symptoms in children and adolescents.
5. In those participants who discontinue treatment with lithium and experience a mood relapse, to determine the duration of lithium treatment necessary before re-stabilization is achieved.
6. To evaluate the influence of intrinsic factors [e.g., age, gender, race, renal function, height, and weight] on lithium exposure in the pediatric population.

METHODOLOGY:

This study was the second of two multiphase, multicenter trials that comprehensively examined lithium in the treatment of pediatric participants with bipolar I disorder. The Clinical Study Report for the first study (COLT1 pharmacokinetic and safety study) was initially submitted to the agency on February 16, 2010 (IND 73,844 / A0017). The revised CSR was submitted on November 12, 2015 (IND 73,844 / A0033). The COLT2 study included four phases of treatment as described below.

In the first phase, the Efficacy Phase, participants were randomized to either lithium or placebo for 8 weeks to determine the efficacy of lithium in the treatment of children and adolescents with bipolar I disorder. Once participants completed the Efficacy Phase, eligible participants continued in the Long-Term Effectiveness Phase for a maximum of 24 weeks of lithium treatment. Subsequently, participants meeting response criteria during the Long-Term Effectiveness Phase were eligible to continue in the Discontinuation Phase. During the Discontinuation Phase, participants were randomized to either placebo or lithium treatment for up to 28 weeks. Finally, those participants who experienced a mood relapse during the Discontinuation Phase were enrolled in an Open Label Restabilization Phase and treated with lithium for up to 8 weeks.

[underlined: Efficacy Phase]

The Efficacy Phase was a randomized, 8-week, double-blind, parallel group, placebo-controlled acute phase in this trial. Participants were randomized at a 2:1 ratio between lithium and placebo.

The starting dose of lithium was 600 mg/day for children weighing <30 kg and 900 mg/day for all others. Based on the participant’s response and tolerability, the dose was increased by 300 mg/day three days after the baseline visit and at scheduled in-office weekly visits and phone calls until the maximum tolerated dose.

At 8 weeks participants were evaluated; lithium-treated participants who were responders/partial responders and placebo-treated participants who were partial/nonresponders, based on the a priori criteria described below, were eligible to begin treatment in the Long-Term Effectiveness Phase.

- [underlined: Response]: Young Mania Rating Scale (YMRS) reduction ≥ 50% from baseline [underlined: and] Clinical Global Impressions Improvement Scale (CGI-I) 1 or 2 (with baseline as a reference point).
- [underlined: Partial response]: YMRS reduction 25-49% [underlined: and] CGI-I ≤ 3 or
  YMRS reduction ≥ 50% AND CGI-I = 3
- [underlined: Non-response]: YMRS reduction <25% [underlined: or] CGI-I ≥ 4.

[underlined: Long-term Effectiveness Phase]

In the Long-term Effectiveness Phase, participants were treated for 24 weeks with open label lithium. If the participant completed 6 of the last 8 weeks of the Long-Term Effectiveness Phase with complete remission of psychotic features and a remission of mood symptoms (YMRS <10 and CDRS-R <35), the participant was eligible to continue into the Discontinuation Phase.

[underlined: Discontinuation Phase]

During this 28-week-long, double-blind phase, participants were randomized to either lithium or placebo. Using a blinded random assignment and blinded placebo-controlled discontinuation design, half of the responders remained on maintenance lithium treatment. The other half underwent a gradual taper of their lithium dose by the substitution of identically appearing placebo capsules for active lithium capsules.

Participants who experienced significant deterioration in clinical status during the Discontinuation Phase were offered 8 weeks of treatment with open label lithium in a Restabilization Phase. The decision to withdraw a participant from the Discontinuation Phase was made by the treating investigator based on the clinical status of the participant.

[underlined: Restabilization Phase]

If the participant withdrew from the Discontinuation Phase and continued in the Restabilization Phase, the participant received 8 weeks of open label lithium. Participants who received placebo during the double blind Discontinuation Phase were treated with the dose of lithium at which earlier stabilization occurred.

NUMBER OF PARTICIPANTS (PLANNED AND ANALYZED):

Planned: 225

Analyzed/Randomized: 81

DIAGNOSIS AND MAIN CRITERIA FOR INCLUSION AND EXCLUSION:

Inclusion Criteria:

1 Participants aged 7 years to 17 years 11 months at time of first dose.
2 Participants must meet Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition (DSM-IV) diagnostic criteria, as assessed by a semi-structured assessment (Kiddie Schedule for Affective Disorders and Schizophrenia - Present and Lifetime (KSADS-PL)) and a separate clinical interview with a child/adolescent psychiatrist for manic or mixed episodes in bipolar I disorder.
3 Score of ≥ 20 on the YMRS at screening and baseline.
4 The participant and legal guardian must understand the nature of the study and be able to comply with protocol requirements. The legal guardian must give written informed consent and the youth, written assent.
5 Participants with comorbid conditions [attention deficit hyperactivity disorder (ADHD), conduct disorder], except those listed in Exclusion Criterion 2, may participate.
6 If female: is premenarchal, or is incapable of pregnancy because of a hysterectomy, tubal ligation, or spousal/partner sterility. If sexually active and capable of pregnancy, has been using an acceptable method of contraception (hormonal contraceptives, intrauterine device, spermicide and barrier) for at least one month prior to study entry and agrees to continue to use one of these for the duration of the study. If sexually abstinent and capable of pregnancy, agrees to continued abstinence or to use of an acceptable method of birth control should sexual activity commence.
7 Has a negative quantitative serum ß-human chorionic gonadotrophin hormone pregnancy test at screening and a negative qualitative urine pregnancy test at baseline, if female.
  8 Participants with a history of substance abuse may participate if they agree to continue to abstain from drugs during the trial and have a negative drug screen at screening or prior to baseline. Those with an initial positive drug screen during initial screening may have another screen done 1-3 weeks later while in screening, and a negative result will allow the participant to participate.
  9 The participant is willing and clinically able to wash out of exclusion medications during the screening period unless previously approved by the Pediatric Off-Patent Drug Study (PODS) PI or a BPCA DCC Medical Monitor. Prior to the Day 0 visit, participants will have not used any of the following medications within the specified time frames:
    - Preceding 3 days: stimulants or melatonin
    - Preceding 1 week: all other psychotropic medications such as mood stabilizers, anticonvulsants, alpha-2 agonists, antipsychotics (other than aripiprazole) and/or antidepressants
    - Preceding 2 weeks: monoamine oxidase inhibitors, aripiprazole, fluoxetine or depot antipsychotics
    No stable participants will be asked to discontinue medications.
  10 Electrocardiogram (ECG) and blood work including Complete Blood Count (CBC), electrolytes, etc showing no clinically significant abnormalities.

Exclusion Criteria:

1. Participant who is clinically stable on current medication regimen for bipolar disorder.
2. A current or lifetime diagnosis of Schizophrenia or Schizoaffective Disorder, a Pervasive Developmental Disorder (Autism Screening Questionnaire score > 15), Anorexia Nervosa, Bulimia Nervosa, or Obsessive-Compulsive Disorder.
3. Current DSM-IV diagnosis of Substance Dependence.
4. Positive drug screen at initial screening and on retest 1-3 weeks later.
5. Participants with symptoms of mania that may be attributable to a general medical condition, or secondary to use of medications (e.g., corticosteroids).
6. Evidence of any serious, unstable neurological illness for which treatment under the auspices of this study would be contraindicated.
7. Any serious, unstable medical illness or clinically significant abnormal laboratory assessments that would adversely impact the scientific interpretability or unduly increase the risks of the protocol.
8. Current general medical condition including neurological disease, diabetes mellitus, thyroid dysfunction, or renal dysfunction that might be affected adversely by lithium, could influence the efficacy or safety of lithium, or would complicate interpretation of study results.
9. Evidence of current serious homicidal/suicidal ideation such that in the treating physician’s opinion it would not be appropriately safe for the participant to participate in this study.
10. Evidence of current active hallucinations and delusions such that in the treating physician’s opinion it would not be appropriately safe for the participant to participate in this study.
11. Concomitant prescription of over-the-counter medication or nutritional supplements (e.g., ibuprofen, naproxen, St John’s wort) that would interact with lithium or affect the participant’s physical or mental status.
12. Concomitant psychotherapy treatments provided outside the study initiated within 4 weeks prior to screening.
13. Previous adequate trial with Li^+^ (at least 4 weeks with Li^+^ serum levels between 8-1.2 mEq/L)
14. History of allergy to lithium or lithium intolerance
15. Psychiatric hospitalization within 1 month of screening for psychosis or serious homicidal/serious suicidal ideation
16. Clinician’s judgment that participant is not likely to be able to complete the study as an outpatient due to psychiatric reasons
17. Females who are currently pregnant or lactating
18. Sexually active females who, in the investigators’ opinion, are not using an adequate form of birth control.
19. Participants who are unable to swallow the study medication
20. Participants for whom a baseline YMRS score of < 20 is anticipated
21. Participants with an IQ less than 70 (determined using the Wechsler Abbreviated Scales of Intelligence [WASI] Vocabulary and Matrix Reasoning Subscales)

TEST PRODUCT, DOSE AND MODE OF ADMINISTRATION, BATCH NUMBER:

Product: Lithium carbonate, manufactured by West-Ward Pharmaceuticals

Mode of Administration: oral

Batch numbers: 64226A (expiration 5/31/2012) and 68949A (expiration 8/31/2015)

Dose: Participants weighing ≥ 30 kg will begin treatment with 300 mg TID; participants weighing < 30 kg will begin treatment with 300 mg BID. Doses may increase at approximately day 3, at the end of week, and then weekly thereafter.

Duration of Treatment: Participants were enrolled for a maximum of 68 weeks after the participant initially received medication.

REFERENCE THERAPY, DOSE AND MODE OF ADMINISTRATION, BATCH NUMBER:

Product: Placebo, manufactured by West-Ward Pharmaceuticals

Mode of Administration: oral

Batch number: 10B0127 (expiration 4/30/2013)

Dose: Participants weighing ≥ 30 kg will begin treatment with 300 mg TID; participants weighing < 30 kg will begin treatment with 300 mg BID. Doses may increase at approximately day 3, at the end of week, and then weekly thereafter

CRITERIA FOR EVALUATION:

Efficacy: The participants who were evaluated for efficacy for a given phase included all participants who had at least one post-baseline efficacy assessment in that phase. All participants were analyzed according to the treatment to which they were randomized, regardless of treatment actually received.

The efficacy participants who had no major protocol infractions were included in the per protocol (PP) efficacy population for the Efficacy Phase and the Discontinuation Phase. A revised definition of major protocol deviations created a second Revised-PP efficacy population.

Safety: The safety population for a given study phase consisted of all consented participants who received at least one dose of study medication during that phase. Participants were analyzed according to treatment actually received.

STATISTICAL METHODS:

Descriptive summaries of demographic, efficacy and safety variables were presented. For quantitative variables, summary statistics included N, mean, SD, median, minimum, and maximum. For qualitative variables, summary statistics included number and percentage of participants within each category.

Variables based upon assessment instruments administered over the course of multiple visits in a given study phase were analyzed primarily on the basis of change from baseline to end of phase scores using the Last Observation Carried Forward (LOCF) method. If a participant was missing a value for a given end of phase assessment, the data obtained at the early termination visit or the last non-missing assessment value was used. Baseline values were not carried forward to replace missing post-baseline values.

[underlined: Efficacy Phase]

Primary, secondary and tertiary efficacy continuous endpoints were analyzed as change from baseline value and assessed using analysis of covariance (ANCOVA) model, with change from baseline score as the dependent variable, baseline score as a covariate, and age strata, gender, weight strata, site, and treatment group as factors.

A sensitivity analysis was performed on the primary endpoint (change in YMRS summary score from baseline to the summary YMRS score at each visit) using a mixed effects repeated measures regression model with no LOCF. Fixed effects included baseline YMRS score, treatment, visit, age strata and treatment by visit interaction; random effects included site. An unstructured covariance matrix was used to model the repeated measures within participants. Additional sensitivity analyses were performed on the per-protocol and revised per-protocol populations using the ANCOVA model described above.

Secondary endpoints of Clinical Global Impressions Scales, (CGI-S, CGI-I) were assessed using a logistic regression model with success and failure defined in the report. Independent factors in model included age strata, gender, weight strata, and treatment group.

Secondary endpoints of response, remission, improvement, discontinuation due to any cause and discontinuation due to lack of efficacy were assessed using the Cochran-Mantel-Haenszel (CMH) test for treatment effect. Additionally, time to discontinuation due to any cause and discontinuation due to lack of efficacy were analyzed using Cox proportional hazards regression models with independent factor of treatment group. These time-to event endpoints were shown graphically using Kaplan-Meier estimates.

[underlined: Discontinuation Phase]

Analyses of this phase include participants from the COLT1 study (NICHD-2005-07-01) combined with the participants from the COLT2 study (NICHD-2005-07-2, present study).

The primary endpoint for the discontinuation phase (relative risk of discontinuation for any reason) was analyzed using the Cox proportional hazards regression model, which included treatment group as the independent factor and was stratified by age strata. Time to discontinuation for any reason during the Discontinuation Phase was shown graphically using Kaplan-Meier estimates. A sensitivity analysis was performed on the primary endpoint, grouping participants by the treatment the actually received. The primary endpoint was also evaluated using the per-protocol population and the revised per-protocol populations.

The secondary endpoint of time-to-mood episode was also evaluated using the Cox proportional hazards regression model. Fisher’s exact test was used to evaluate the treatment effect in the secondary endpoint of recurrence of mood symptoms and CGI scores. Continuous secondary endpoints were analyzed using a linear regression model that included the change score as the dependent variable, baseline score as a covariate, and age strata, gender, study (COLT1 vs. COLT2) and treatment group as factors. Secondary endpoints of response, remission, and improvement were assessed using the Cochran-Mantel-Haenszel (CMH) test for treatment effect.

Descriptive summaries are provided for the Long-Term Effectiveness Phase and Restabilization Phase. The Restabilization Phase contains participants from the COLT1 and COLT2 studies.

RESULTS:

Efficacy:

Interim conditional power analyses suggested that with a total sample size of 100 there would be 94% power to detect significant differences between treatment groups for the primary endpoint in the Efficacy Phase. The impact of reduced sample size on secondary endpoints was not evaluated.

[underlined: Efficacy Phase]

The primary efficacy endpoint for the Efficacy Phase was the change from baseline to the end of phase (Week 8/ET) YMRS (Summary) scores, based upon LOCF values. The change was a decline of 11.7 points (SD 11.4) in the lithium group and a decline of 7.8 (SD 9.8) in the placebo group. The p-value evaluating the treatment difference is significant at p=0.031 after adjusting for baseline score, age strata, gender, weight strata, and site.

The sensitivity analysis used mixed effects repeated measures regression and results found that the overall treatment effect was not significant (p=0.435); however, the visit by treatment interaction was significant at p=0.005. An examination of the change from baseline in summary YMRS score at each visit showed significant treatment differences at Week 6 (n=62, p=0.012) and Week 8 (n=58, p<0.001).

The results of analysis of the primary endpoint on the per-protocol population showed a mean decrease in YMRS score of 10.9 points (SD 12.0) for participants in the lithium group and a decrease of 7.7 points (SD 10.4) for participants in the placebo group using LOCF method. Due to the decreased sample size, only 63% of the original population was in the per protocol population; this difference was not statistically significant (p=0.295). In the Revised-PP population (including 90% of the original population), the mean change in YMRS scores from baseline to end-of-phase was a decline of 11.4 points (SD 11.6) in the lithium group and a decline of 6.6 points (SD 9.9) in the placebo group (p=0.021).

Secondary endpoints included parent YMRS: the lithium group reported mean decline of 10.9 points (SD 12.0) while the placebo group reported a 7.7 point decline (SD 10.3). The p-value was 0.052 after adjusting for baseline score, age strata, gender, weight strata, and site. The child self report of YMRS change score had smaller magnitude, but in the same direction as the parent and summary scores (p=0.277). The CGI-I score success rate was significantly higher in the lithium for mania (51% in the lithium arm vs. 29% in the placebo arm, p=0.044) and for overall illness (47% in the lithium arm vs. 21% in the placebo arm, p=0.026). The depression improvement was not statistically significant, but the lithium arm had a 40% success rate vs. 29% in the placebo arm. Other secondary endpoints showed changes in the direction of lithium benefit, but the p-values didn’t reach significance.

Tertiary endpoint Parent General Behavior Inventory-10 Item Mania Scale (PGBI-10MP showed a significant difference between the lithium treated participants and the placebo treated participants. Lithium participants had a mean decrease from baseline score of 7.7 points (SD 9.1) while the placebo participants had a mean decrease of 2.1 (SD 8.0) points, p=0.039. In general, the remaining tertiary endpoints, while not significant, showed changes in the appropriate directions.

[underlined: Long-Term Effectiveness Phase]

Descriptive summaries are provided for the Efficacy population and results are presented by Long-Term Effectiveness age strata and by Efficacy Phase randomized treatment group. The primary efficacy endpoint for the Long-Term Effectiveness Phase is the change from baseline to the end of phase in the YMRS Summary score, based upon LOCF values. Participants in the 7-11 age stratum had a mean decrease in score of 6.9 (SD 12.8) and the participants in the 12-17 age stratum had a mean decrease in score of 4.5 (SD 7.3); participants randomized to lithium during the Efficacy Phase had a mean decrease of 1.6 (SD 8.4) and participants randomized to placebo had a decrease of 16.1 (SD 10.6). Placebo non-responders and partial responders showed improvement when tapered to lithium treatment. Similar results were seen for secondary and tertiary endpoints.

[underlined: Discontinuation Phase]

The primary efficacy endpoint for the Discontinuation Phase was the relative risk of discontinuation for any reason, comparing lithium to placebo. Although 43% of the participants randomized to lithium vs. 71% of the participants randomized to placebo did not complete the Discontinuation Phase, this difference was not statistically significant: Cox regression Hazard Ratio (HR) 0.54 (compared to placebo) 95% CI (0.20, 1.49), p=0.235.

The sensitivity analysis of the primary endpoint by treatment received group show that the risk of discontinuation is significantly lower in the lithium treated participants, with HR=0.28 (compared to placebo), 95% CI (0.10, 0.78), and p=0.015.

The additional sensitivity analysis of the primary endpoint in the PP population showed the risk of discontinuation was significantly lower in the lithium arm with HR=0.27 (compared to placebo), 95% CI (0.08, 0.87), and p=0.029. The Revised-PP population was not statistically significant with HR=0.41 (compared to placebo), 95% CI (0.14, 1.15), and p=0.090.

The results of the secondary and tertiary endpoints did not reach significance but showed changes in the appropriate directions.

[underlined: Restabilization Phase]

The primary efficacy endpoint for the Restabilization Phase was the change from baseline to the end of phase in the YMRS Summary score, based upon LOCF values. The mean change from baseline to Week 8/LOCF was a decline 9.5 points (SD 10.9).

Safety:

[underlined: Efficacy Phase]

Overall, there were 521 adverse events reported in 76 of the 81 safety participants (94%). There was a similar rate of Treatment Emergent Adverse Events (TEAEs) in the lithium (94%) and placebo (93%) groups; however, the lithium-treated participants reported more TEAEs per participant (mean of 7.7) than placebo-treated participants (mean of 4.0). Of the 521 TEAEs, 404 (78%) were of mild severity, with 36% of lithium participants and 46% of the placebo participants reporting a highest severity of mild.

Overall, headache was the most frequently reported TEAE, occurring in 28 (35%) of the 81 participants (36% of the lithium-treated participants and 32% of the placebo-treated participants). Gastrointestinal disorders of nausea, vomiting, upper abdominal pain, and diarrhea were also frequently occurring TEAEs. Nausea was present in 43% of the lithium-treated participants and in 18% of the placebo-treated participants, and vomiting was present in 45% of the lithium-treated participants and in 11% of the placebo-treated participants. Upper abdominal pain was present in 31% of the participants (30% of lithium-treated and 32% of the placebo-treated participants). Other frequent TEAEs that occurred more often in the lithium arm (compared to placebo) include tremors (32% vs. 7%) thirst (28% vs. 11%), pollakiuria (26% vs. 7%), dizziness (23% vs. 7%), and increased thyroid stimulating hormone (TSH) (17% vs. 0%).

There were 7 Serious Adverse Events (SAEs) reported in 6 participants during the Efficacy Phase: 5 events in 4 lithium participants and 2 events in 2 placebo participants. Six of the 7 SAEs were psychiatric disorders, including one suicidal ideation in a lithium-treated participant.

[underlined: Long-Term Effectiveness Phase]

Overall, there were 357 adverse events reported in 38 of the 44 safety participants (86%). The rate of TEAEs across the Efficacy Phase treatment arms was 90% for lithium participants and 80% for placebo participants. The rate of TEAEs was similar in each age stratum: age 7-11 years 86% and age 12-17 years 87%. Mean number of AEs per participant was 8.1 during this phase. Of the 357 TEAEs, 274 (77%) were of mild severity, with 30% of participants reporting mild as the highest severity.

Overall, headache was the most frequently reported TEAE, occurring in 18 (41%) of the 44 participants. GI disorders of nausea, vomiting, upper abdominal pain, diarrhea, and abdominal pain were also frequently occurring TEAEs. Nausea and vomiting were each present in 34% of the participants; upper abdominal pain in 21%; and diarrhea in 18% of the participants. Other frequent TEAEs included rash (23%), tremors (18%), thirst (16%), pollakiuria (16%), enuresis (11%), and increased appetite (11%). All AEs of increased appetite occurred in the older (12-17 years) age stratum.

There were 2 SAEs reported in 2 participants during the Long-Term Effectiveness Phase; both were reported as unrelated to study medication. These 2 SAEs included suicide attempt and suicidal self-injury; both required hospitalization and both participants were terminated from the study. Both participants received lithium during the Efficacy Phase and both were in the 12-17 year age stratum.

[underlined: Discontinuation Phase]

Overall, 127 adverse events were reported in 24 of the 31 safety participants (77%), with 88% of the lithium-treated participants and 64% of the placebo-treated participants reporting at least 1 TEAE. The lithium-treated participants reported a mean of 6.0 TEAEs per participant while the placebo-treated participants reported a mean of 1.8 TEAEs. Of the 127 TEAEs, 109 (86%) were of mild severity, with 15 (48%) participants reporting mild as the most severe TEAE: 10 (59%) lithium-treated and 5 (36%) placebo-treated participants.

Overall, headache was the most frequently reported TEAE, occurring in 10 (32%) of the 31 participants (6 lithium-treated and 4 placebo-treated participants). Upper abdominal pain was the second most frequently occurring TEAE, occuring in 6 (19%) participants (5 lithium-treated and 1 placebo-treated). Initial insomnia was reported in 5 participants (3 lithium and 2 placebo). Enuresis and vomiting each in 4 (13%) participants (all lithium treated). Decreased appetite also occurred in 4 (13%) participants (2 lithium and 2 placebo).

There was 1 SAE reported during the Discontinuation Phase: aggression was reported in one participant, and was of moderate severity and possibly related to study medication. The participant received lithium treatment and was terminated from the study

[underlined: Restabilization Phase]

There were 36 adverse events reported in 10 of the 13 safety participants (77%). There was an average of 2.8 TEAEs per participant. All of the 36 TEAEs were mild (n=29) or moderate (n=7). Six participants reported a maximum severity of mild and 4 participants reported a maximum severity of moderate.

Consistent with the other phases, headache was the most frequently reported TEAE, occurring in 4 (31%) of the 13 participants. Upper abdominal pain was the second most frequently occurring TEAE in 3 (23%) participants.

There were no SAEs reported during this phase.

CONCLUSIONS:

The primary efficacy analysis in the Efficacy Phase showed that lithium was more efficacious than placebo in the acute treatment of manic/mixed states in this patient population.

In the Long-Term Effectiveness Phase, the mean YMRS score for participants who had been responders or partial responders to lithium during the randomized Efficacy Phase continued to show improvement. The effectiveness analyses in the Long-Term Effectiveness Phase also showed that lithium was effective in improving the YMRS scores of placebo non-responders or partial responders from the Efficacy Phase.

Data from the Discontinuation Phase suggest that lithium has superior efficacy (clinical but not statistical, as the study was not powered for this phase) when compared to placebo as a maintenance treatment for children and adolescents with bipolar I disorder.

Although numbers are small in the Restabilization Phase, data suggest that lithium improved YMRS scores of participants experiencing mood relapse during the Discontinuation Phase.

As shown by the safety data in the Efficacy Phase, lithium is generally safe and well-tolerated with a side-effect profile in this patient population similar to what has been described previously in adults.

The safety analyses from the Long-Term Effectiveness Phase, the Discontinuation Phase, and the Restabilization Phase provide evidence to support the conclusion that lithium is a safe and oftentimes well-tolerated treatment in this patient population with a similar safety profile compared to what has been previously reported in adults.

Overall, the data demonstrate that lithium has both acute and maintenance efficacy in children and adolescents that present with acute manic or mixed episodes. In addition, these data indicate an acceptable tolerability profile. When this protocol’s results are considered in their entirety, we conclude that lithium is an effective and generally well-tolerated treatment for manic or mixed episodes in juveniles with bipolar I disorder.