# 13 OVERALL STUDY CONCLUSIONS

This is the largest study to date that has specifically examined the efficacy, effectiveness and safety of lithium in juvenile bipolar I disorder. The data demonstrate that lithium has both acute and maintenance efficacy in children and adolescents that present with acute manic or mixed episodes. In addition, these data characterize the tolerability profile of lithium in this participant group. The results indicate an acceptable tolerability profile. When this protocol’s results are considered in their entirety, we conclude that lithium is an effective and generally well-tolerated treatment for manic or mixed episodes in juveniles with bipolar I disorder.