# 10 STUDY PARTICIPANTS

## 10.1 Disposition of Participants

An overview of the flow of participants in the second trial for the treatment of pediatric mania (COLT2) is shown in Figure 10-1. The overall disposition of participants across all phases is summarized in Tables 14.1.1.1.1-14.1.1.1.5B.

Figure 10-1 Flow of Participants

### 10.1.1 Screening Phase

A total of 153 participants were screened in the COLT2 study. Eleven sites enrolled participants in this study, as summarized in Table 14.1.1.2.1; the ▬ enrolled 49 (32%) participants into the Screening Phase. Seventy two (47%) participants failed the Screening Phase and 81 (53%) of the 153 participants were randomized into the Efficacy Phase of the protocol as shown below in Table 10-1. Reasons for participants not continuing to the Efficacy Phase are summarized below:

Table 10-1 Summary of Screening Phase Participant Disposition

| Age Strata | | Total
| 7-11 yrs | 12-17 yrs | Total
Screening Phase | 90 | 63 | 153
Screening Phase Failures | 41 (46%) | 31 (49%) | 72 (47%)
Eligible and Randomized to Efficacy Phase | 49 (54%) | 32 (51%) | 81 (53%)
Reasons for Screening Phase Failures
Adverse event | 0 | 1 (2%) | 1 (1%)
Inclusion/Exclusion criteria not met | 26 (29%) | 23 (37%) | 49 (32%)
Lost to follow-up | 1 (1%) | 3 (5%) | 4 (3%)
Investigator decision | 2 (2%) | 2 (3%) | 4 (3%)
Consent / assent withdrawn by participant / caregiver | 12 (13%) | 2 (3%) | 14 (9%)

Source: Table 14.1.1.1.1

Of the 72 screened participants that were not eligible to continue to the Efficacy Phase, 49 failed to meet inclusion/exclusion criteria; 28 of these 49 participants did not meet the DSM-IV diagnostic criteria and 8 failed to score ≥20 on the YMRS, see Table 14.1.1.1.1 for details.

### 10.1.2 Efficacy Phase

Ten sites randomized 81 participants in the Efficacy Phase. Of these 81 participants, 49 (60%) were in the 7-11 year age stratum and 32 (40%) were in 12-17 year age stratum. Fifty three (65%) were randomized to receive lithium and 28 (35%) were randomized to receive placebo (Table 10-2). All 81 participants received randomized study drug and are included in the both the efficacy and safety populations.

Table 10-2 Summary of Efficacy Phase Participant Disposition

| Efficacy Phase Randomized Treatment
| Lithium | Placebo | Total
Efficacy Phase | 53 | 28 | 81
Discontinued during Efficacy Phase (<8 weeks) | 16 (30%) | 7 (25%) | 23 (28%)
Completed Efficacy Phase but did not continue to LTE Phase | 8 (15%) | 6 (21%) | 14 (17%)
Eligible and Entered in the Long-Term Effectiveness Phase | 29 (55%) | 15 (54%) | 44 (54%)
Reasons for Discontinuing during Efficacy Phase
Lack of efficacy | 3 | 1 | 4
Protocol non-compliance | 4 | 1 | 5
Psychosis with mood symptoms | 2 | 0 | 2
Suicidal/homicidal ideation | 2 | 1 | 3
Other Adverse events | 2 | 1 | 3
Consent / assent withdrawn by participant or caregiver | 2 | 2 | 4
Lost to follow-up | 1 | 1 | 2
Reasons for not continuing to LTE Phase
Ineligible for next phase^*^ | 6 | 5 | 11
Protocol non-compliance | 2 | 1 | 3

* Ineligible for next phase included lithium participants who were non-responders defined as <25% reduction in baseline YMRS or CGI-I ≥4 and placebo participants who were responders defined as YMRS reduction ≥50% and CGI-I = 1 or 2.

Source: Table 14.1.1.1.2

As summarized in Table 14.1.1.1.2 and Table 10-2, twenty-three participants, 16 (30%) in the lithium group and 7 (25%) in the placebo group, discontinued the Efficacy Phase early (prior to completing 8 weeks). Four participants reported lack of efficacy: 3 lithium participants (1 with depression and 2 with mixed states) and 1 placebo participant (depression). Five participants (4 in the lithium group and 1 in the placebo group) were non-compliant with the protocol. In the lithium group there were 2 participants with medication non-compliance, 1 participant was prescribed risperidone for refractory mania and 1 was unable to swallow study medication. In the placebo group, one participant [▬] was seen at Day 1, Week 1, Week 2, and did not return for a final visit until Week 14. This participant was early terminated due to protocol non-compliance (visit non-adherence) and the data from the Week 14 visit is not included in these analyses. Eight participants terminated due to adverse events (6 lithium and 2 placebo): 2 lithium participants with psychosis with mood symptoms; 2 lithium participants and 1 placebo participant with suicide ideation/homicidal ideation; and 3 participants due to other adverse events (1 lithium participant for agitation, 1 lithium participant for mood instability and 1 placebo participant for aggressive behavior; all unrelated to study medication). Four participants withdrew consent: 2 in each treatment group. Two participants, 1 in each treatment group, were lost to follow-up between the Week 7 phone call and the Week 8 visit.

Participants entering the Efficacy phase completed an average of 6.8 weeks (SD 2.3 weeks) and 58/81 (72%) participants completed all 8 weeks of the phase with 44 eligible and entered the Long-Term Effectiveness (LTE) Phase. Fourteen did not continue to the LTE Phase: 8 from the lithium group and 6 from the placebo group. Eleven of the 14 participants did not continue because they were ineligible for the LTE Phase (6 lithium and 5 placebo). Ineligible for the next phase included “non-responders” from the lithium group with <25% reduction in baseline YMRS or CGI-I ≥4, and “responders” from the placebo group defined as YMRS reduction ≥50% and CGI-I = 1 or 2. Also not continuing were 3 participants who were non-compliant with the protocol (2 lithium participants with study medication non-compliance and 1 placebo participant with study medication non-compliance).

### 10.1.3 Long-Term Effectiveness (LTE) Phase

Summary of participant disposition during the LTE phase is presented in Table 10-3. Forty-four (44) participants entered the LTE Phase from 9 sites. There were 29 (66%) in the 7-11 year age stratum and 15 (34%) in the 12-17 year age stratum. All participants received study drug.

Participants entering the LTE phase completed an average of 17.4 weeks (SD 8.4 weeks) in the phase with 21/44 (48%) participants discontinuing the LTE Phase early (that is, prior to completing 24 weeks). The reasons for participants discontinuing the LTE phase are presented in Table 10-3. One (1) participant [▬] was found to be ineligible for the LTE phase (after enrollment) and was terminated; 1 participant reported a lack of efficacy (mania); and 3 participants were non-compliant with the protocol (2 with medication non-compliance and 1 with 3 reports of drug use in addition to 2 positive drug screens). Three (3) participants discontinued due to adverse events (2 suicide/homicide ideation and 1 for vomiting); 7 participants withdrew consent; 3 participants were lost to follow-up; 2 participants terminated due to study termination by sponsor; and 1 participant due to site termination.

Twenty-three participants completed all 24 weeks of the study of which 10 participants were eligible and entered the Discontinuation Phase. Thirteen did not continue to the Discontinuation Phase; 5 participants were ineligible, 4 participants withdrew consent, and 4 participants were terminated due to study termination by sponsor.

Table 10-3 Summary of Long-Term Effectiveness Phase Participant Disposition

| Age Strata
| 7-11 yrs | 12-17 yrs | Total
Long-Term Effectiveness Phase | 29 | 15 | 44
Discontinued during the LTE Phase | 12 (41%) | 9 (60%) | 21 (48%)
Completed the LTE Phase but did not continue | 10 (35%) | 3 (20%) | 13 (30%)
Eligible and Entered in the Discontinuation Phase | 7 (24%) | 3 (20%) | 10 (23%)
Reasons for Discontinuing during LTE Phase
Lack of efficacy | 0 | 1 | 1
Protocol non-compliance | 1 | 2 | 3
Suicidal/homicidal ideation | 0 | 2 | 2
Other adverse events^**^ | 1 | 0 | 1
Consent / assent withdrawn by participant or caregiver | 6 | 1 | 7
Lost to follow-up | 2 | 1 | 3
Termination of study by sponsor | 1 | 1 | 2
Site withdrew from study | 0 | 1 | 1
Ineligible for LTE phase^***^ | 1 | 0 | 1
Reasons for not continuing to Discontinuation Phase
Ineligible for next phase^*^ | 4 | 1 | 5
Consent / assent withdrawn by participant / caregiver | 3 | 1 | 4
Termination of study by sponsor | 3 | 1 | 4

* Ineligible for next phase included who did NOT complete at least 6 of last 8 consecutive weeks with complete remission of psychotic features and a remission of mood symptoms (i.e. did not have YMRS <10 AND CDRS-R <35)

** Adverse event in participant [▬] vomiting

*** Participant [▬] was ineligible for the LTE phase because he did not meet the 900 mg lithium dose limit that existed at that time.

Source: Table 14.1.1.1.3

### 10.1.4 Discontinuation Phase

Analysis of the Discontinuation Phase included 31 participants: 10 participants from the COLT2 study and 21 participants from the COLT1 study. Of the 31 participants, 14 were randomized to lithium and 17 were randomized to placebo in the Discontinuation Phase. Participant disposition is summarized in Table 14.1.1.1.4 and Table 10-4 below for all participants; Table 14.1.1.1.4A for participants from COLT2 study and Table 14.1.1.1.4B for participants from COLT1 study. All participants from both studies (N=31) received study drug.

Participants entering the Discontinuation Phase completed an average of 15.3 weeks (SD 11.6 weeks). Participants randomized to lithium completed an average of 19.3 (11.9) weeks and participants randomized to placebo completed an average of 12.0 (10.6) weeks. Of the 31 Discontinuation Phase participants, 5 (16%) participants discontinued during the phase: 3 (21%) lithium, 2 (12%) placebo; 1 (20%) from COLT2, 4 (19%) from COLT1. Table 10-4 presents the reasons for early termination of participants during the discontinuation phase; one (1) participant each early terminated due to withdrawn consent, AE (aggression), lack of efficacy, protocol non-compliance and 1 participant [▬] was found to be ineligible after randomization. Thirteen participants (42%) completed the 28 week phase: 8 (57%) lithium, 5 (29%) placebo; 6 (60%) from COLT2 study and 7 (33%) from COLT1 study. Thirteen (42%) had mood relapse and entered the Restabilization Phase: 3 (21%) lithium and 10 (59%) placebo: 3 (30%) from COLT2 and 10 (48%) from COLT1.

Table 10-4 Summary of Discontinuation Phase Participant Disposition

| Discontinuation Phase Randomized Treatment
| Lithium | Placebo | Total
Discontinuation Phase | 14 | 17 | 31
Discontinued during the Discontinuation Phase | 3 (21%) | 2 (12%) | 5 (16%)
Completed the study | 8 (57%) | 5 (29%) | 13 (42%)
Mood relapse and entered Restabilization Phase | 3 (21%) | 10 (59%) | 13 (42%)
Reasons for Discontinuing during Discontinuation Phase
Lack of efficacy | 1 | 0 | 1
Protocol non-compliance | 0 | 1 | 1
Adverse event^*^ | 1 | 0 | 1
Consent / assent withdrawn by participant or caregiver | 1 | 0 | 1
Ineligible for Discontinuation Phase | 0 | 1 | 1

* Adverse Event in participant [▬] Aggression

Source: Table 14.1.1.1.4

### 10.1.5 Restabilization Phase

Analysis of the Restabilization Phase also included participants from both the COLT1 and COLT2 studies. This phase included 3 participants from the COLT2 study and 10 participants from the COLT1 study. All participants from both studies received study drug. Participant disposition is summarized in Table 14.1.1.1.5 and Table 10-5 below and in Table 14.1.1.1.5A for participants entering from the COLT2 study and in Table 14.1.1.1.5B for participants entering from the COLT1 study.

Of the 13 participants entering Restabilization Phase, 5 participants were between 7-11 years of age and 8 were between 12-17 years of age; 9 participants completed all 8 weeks and 4 participants discontinued during the Restabilization Phase. Reasons for discontinuing during the phase included 2 participants with consent/assent withdrawn, 1 participant terminated due to non-compliance to study medication and 1 participant was lost to follow-up.

Table 10-5 Summary of Restabilization Phase Participant Disposition

| Age Strata
| 7-11 years | 12-17 years | Total
Restabilization Phase | 5 | 8 | 13
Discontinued during the Restabilization Phase | 2 (40%) | 2 (25%) | 4 (31%)
Completed the study | 3 (60%) | 6 (75%) | 9 (69%)
Reasons for Discontinuing during Restabilization Phase
Protocol non-compliance | 1 | 0 | 1
Consent / assent withdrawn by participant or caregiver | 1 | 1 | 2
Lost to follow-up | 0 | 1 | 1

Source: Table 14.1.1.1.5

## 10.2 Protocol Deviations (PD)

Table 10-6 summarizes all PDs from the COLT2 study by PD category and study phase. PDs are presented by study phase in Tables 14.1.2.1-14.1.2.5. If a PD begins in one phase and continues over to the next phase, it was only counted in the phase in which it began. Only 1 randomization error occurred in the COLT2 study; this was a participant whose baseline study procedures took longer than the protocol permitted 2 days.

COLT1 PDs occurring during the Discontinuation Phase and Restabilization Phase that were not unblinding are presented with the COLT1 CSR. Unblinding PDs related to COLT1 and documentation related to the Discontinuation Phase randomization problems for COLT1 are included in Appendix 16.4.2.2.

In the Efficacy Phase, 78/81 (96%) of the participants had at least 1 protocol deviation. There were 332 deviations reported during this phase of which 221 (67%) were categorized as protocol procedure or assessment, and 87 (26%) were categorized as study medication administration. Six participants had 8 PDs related to stopped study medication and 6 participants had concomitant treatment related PDs. Six participants had 7 unblinding PDs: 3 participants (4 PDs) were due to hospitalization, 2 were due to blinded staff receiving unblinded information and 1 participant early terminated the study and was unblinded at termination.

One hundred and fifty-six (156) PDs were reported in 41 (93%) of the 44 participants entering the LTE Phase. Protocol procedure/assessment deviations accounted for 119/156 (76%) of the total PDs for this phase. Study medication administration accounted for 28/156 (18%) of the PDs. One stopped study medication related PD was reported in one participant and concomitant treatment related PDs were reported in 3 participants.

Thirty-six (36) PDs were reported for 9 of the 10 COLT2 participants (90%) in the Discontinuation Phase with 23/36 PDs classified as related to protocol procedure/assessment and 11/36 PDs related to study medication administration.

Five PDs were reported for the 3 (100%) COLT2 participants in the Restabilization Phase. Four were classified as related to protocol procedure/assessment and 1 was related to study medication administration.

Table 10-6 Summary of Protocol Deviations for All Phases of the COLT2 Study

Protocol Deviation Category | Screening Phase | | Efficacy Phase | | Long-Term Effectiveness Phase | | Discontinuation Phase | | Restabilization Phase
Protocol Deviation Category | Pts with PD; N (%) | Total PDs; N | Pts with PD; N (%) | Total PDs; N | Pts with PD; N (%) | Total PDs; N | Pts with PD; N (%) | Total PDs; N | Pts with PD; N (%) | Total PDs; N
Number Enrolled | 153 | | 81 | | 44 | | 10 | | 3
Informed consent/assent | 3 (2%) | 4 | -- | -- | -- | -- | -- | -- | -- | --
Eligibility/ enrollment | 6 (4%) | 7 | 3 (4%) | 3 | 3 (7%) | 3 | 0 | 0 | 0 | 0
Randomization | 1 (1%) | 1 | 0 | 0 | -- | -- | 0 | 0 | -- | --
Study medication administration | -- | -- | 38 (47%) | 87 | 16 (36%) | 28 | 6 (60%) | 11 | 1 (33%) | 1
Stopped study medication | -- | -- | 6 (7%) | 8 | 1 (2%) | 1 | 0 | 0 | 0 | 0
Unblinding | -- | -- | 6 (7%) | 7 | -- | -- | 1 (10%) | 1 | -- | --
Protocol procedure/assessment | 20 (13%) | 24 | 74 (91%) | 221 | 37 (84%) | 119 | 8 (80%) | 23 | 3 (100%) | 4
Concomitant treatment | 2 (1%) | 2 | 6 (7%) | 6 | 3 (7%) | 3 | 1 (10%) | 1 | 0 | 0
Other | 0 | 0 | 0 | 0 | 2 (5%) | 2 | 0 | 0 | 0 | 0
Total | 28 (18%) | 38 | 78 (96%) | 332 | 41 (93%) | 156 | 9 (90%) | 36 | 3 (100%) | 5

Pts=Participants; PD=Protocol deviation

Source: Tables 14.1.2.1-14.1.2.5

### 10.2.1 Major Protocol Deviations (PDs)

The Efficacy Phase and Discontinuation Phase primary endpoints were also analyzed for participants in the per-protocol (PP) population. This included efficacy population participants without major protocol infractions as defined below.

Major PDs include:

1. Drug non-compliance defined as missed > 40% of the medication doses in one week during the phase.
2. Prohibited medication taken during the phase.
3. Dose exceeded 40 mg/kg/day without a waiver (with the exception of participants who weighed less than 23 kg who may receive up to 900 mg/day).
4. Received incorrect randomized study medication.

Further review indicated that the major protocol deviation definition was too stringent and a second definition of major protocol deviations was also used to create a Revised-PP population (changes made are in italics). This new definition included:

1. Drug non-compliance defined as missed > 40% of the medication doses within two consecutive weeks during the phase.
2. Prohibited medication taken during the phase.
3. Dose exceeded 50 mg/kg/day without a waiver (with the exception of participants who weighed less than 23 kg who may receive up to 900 mg/day).
4. Received incorrect randomized study medication.

#### 10.2.1.1 Efficacy Phase

Major PDs were reported for 30 (37%) of the 81 participants (Table 10-7): compliance related PDs were reported in 11 participants; recommended dose was exceeded for15 participants; 6 participants received prohibited medications (all ibuprofen); both non-compliance and dosing related deviations were reported for1 participant; and both non-compliance and received prohibited medications were reported in 1 participant. All participants received the correct randomized treatment. See Section 16.2 for a complete listing of all major PDs.

Table 10-7 Summary of Major Protocol Deviations for the Efficacy Phase

| Efficacy Phase Randomized Treatment
| Lithium | Placebo | Total
Efficacy Phase | 53 | 28 | 81
Compliance <60% for any week | 5 (9%) | 6 (21%) | 11 (14%)
Dosing >40 mg/kg/day | 10 (19%) | 5 (18%) | 15 (19%)
Prohibited concomitant medications | 2 (4%) | 4 (14%) | 6 (7%)
Received incorrect randomized treatment | 0 | 0 | 0
Total participants with major deviations | 16 (30%) | 14 (50%) | 30 (37%)

Note: Participant [▬] had both compliance and dosing deviations and Participant [▬] had both compliance and concomitant medication deviations. They are counted only once in the Total participants with major deviations row.

Source: Appendix 16.2

The revised definition of major PDs resulted in 8 (10%) participants with deviations. All participants were compliant to assigned treatment as per the revised definition of treatment non-compliance. Only two participants from the lithium group were treated with a maximum study dose >50 mg/kg/day.

Table 10-8 Summary of Revised Major Protocol Deviations for the Efficacy Phase

| Efficacy Phase Randomized Treatment
| Lithium | Placebo | Total
Efficacy Phase | 53 | 28 | 81
Compliance <60% for 2 consecutive weeks | 0 | 0 | 0
Dosing >50 mg/kg/day | 2 (4%) | 0 | 2 (2%)
Prohibited concomitant medications | 2 (4%) | 4 (14%) | 6 (7%)
Received incorrect randomized treatment | 0 | 0 | 0
Total participants with major deviations | 4 (8%) | 4 (14%) | 8 (10%)

Source: Appendix 16.2

#### 10.2.1.2 Discontinuation Phase

Major protocol deviations for the Discontinuation Phase are summarized in Table 10-9. In the COLT2 study, 2/10 (20%) participants had a major protocol deviation: 2 participants had compliance rates <60% and 1 participant [▬] also received ibuprofen during the phase.

The COLT1 study had three participants randomized to receive placebo, who actually received lithium ▬] (Appendix 16.4.2.3). In addition, one placebo randomized participant [▬] received 10 days of lithium starting at week 6 (Appendix 16.4.2.2). Participant ▬] also received study doses >40 mg/kg/day. Major deviations in participants randomized to lithium group included 2 participants with doses >40 mg/kg/day. A total of 6/21 (29%) of the COLT1 Discontinuation Phase participants had a major protocol deviation.

In summary, 8/31 (26%) of the participants randomized in the Discontinuation Phase incurred a least 1 major protocol deviation.

Table 10-9 Summary of Major Protocol Deviations for the Discontinuation Phase

| Discontinuation Phase Randomized Treatment
| Lithium | Placebo | Total
Discontinuation Phase | 14 | 17 | 31
Compliance <60% for any week | 1 (7%) | 1 (6%) | 2 (6%)
Dosing >40 mg/kg/day | 2 (14%) | 1 (6%) | 3 (10%)
Prohibited concomitant medications | 1 (7%) | 0 | 1 (3%)
Received incorrect randomized treatment | 0 | 4 (24%) | 4 (13%)
Total participants with major deviations | 3 (21%) | 5 (29%) | 8 (26%)

Note: Participant [▬] had both compliance and concomitant medication deviations, and participant [▬] had both dosing and incorrect randomized treatment. They are counted only once in the Total participants with major deviations row.

Source: Appendix 16.2

The revised definition of major protocol deviations resulted in a total of 5/31 (16%) participants as shown in Table 10-10. Included are 1 lithium participant who received a prohibited concomitant medication from COLT2 and 4 placebo participants who received incorrect randomized treatment from COLT1 as described above.

Table 10-10 Summary of Revised Major Protocol Deviations for the Discontinuation Phase

| Discontinuation Phase Randomized Treatment
| Lithium | Placebo | Total
Discontinuation Phase | 14 | 17 | 31
Compliance <60% for 2 consecutive weeks | 0 | 0 | 0
Dosing >50 mg/kg/day | 0 | 0 | 0
Prohibited concomitant medications | 1 (7%) | 0 | 1 (3%)
Received incorrect randomized treatment | 0 | 4 (24%) | 4 (13%)
Total participants with major deviations | 1 (7%) | 4 (24%) | 5 (16%)

Source: Appendix 16.2

### 10.2.2 Site Specific Protocol Deviations

Site specific protocol deviations were not visit or phase based, but were completed as needed to capture any departures from protocol-specified procedures that are not limited to a specific participant(s). Five of the 10 sites treating participants in the COLT2 study had site specific protocol deviations. All deviations are in the category product administration and were related to drug accountability at the close out visit. Reasons were research staff error at one site and hospital staff error at 4 sites. A complete listing is included in Appendix 16.2.