# 9 INVESTIGATIONAL PLAN

## 9.1 Overall Design and Plan Description

This study was a multiphase, multicenter trial to examine lithium in the treatment of pediatric participants with bipolar I disorder. To examine the treatment of bipolar I disorder with lithium, this study included four phases of treatment. The first phase, the Efficacy Phase, was an 8-week, randomized, double-blind, placebo-controlled phase that examined the efficacy of lithium in the treatment of pediatric mania. On completion of the Efficacy Phase, participants meeting response criteria were eligible to continue in the Long-Term Effectiveness (LTE) Phase and be treated for up to 24 weeks with open label lithium. Subsequently, participants meeting response criteria during the Long-Term Effectiveness Phase were eligible to continue in the Discontinuation Phase. During the Discontinuation Phase, participants were randomized to either placebo or lithium treatment for up to 28 weeks. Finally, those participants who experienced a mood relapse during the Discontinuation Phase were treated with open label lithium for up to 8 weeks in the Restabilization Phase. Figure 9-1 provides a schematic illustration of the study design.

Figure 9-1 Study Design

^1^ Partial response also included YMRS reduction ≥ 50% and CGI-I = 3

## 9.2 Discussion of Study Design and Choice of Control Groups

There have been studies on the use of lithium in bipolar children and adolescents; however, the majority of these studies were carried out in large mixed samples (with a range of diagnoses including bipolar, ADHD, and conduct disorder) and without controls (DeLong and Aldershof 1987). All of these studies suggest a beneficial effect for lithium in many of these child and adolescent participants with bipolar disorder. The goal of this study is to determine if lithium is more efficacious in reducing symptoms of mania than placebo, and safe for children and adolescents.

No long-term trials of lithium in children and adolescents have been conducted. Controlled studies of lithium in adults with bipolar disorder support a prophylactic effect for prevention of mania or depression and a similar effect may occur in children and adolescents.

## 9.3 Selection of Study Population

### 9.3.1 Inclusion Criteria

The investigator or other study site personnel documented in the source documents (e.g., the hospital chart) that informed consent was obtained. Laboratory tests or questionnaires that were performed as part of the screening procedures were completed prior to the first dose of study drug and recorded in the eCRF.

1. Participants aged 7 years to 17 years 11 months at time of first dose.
2. Participants must meet Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition (DSM-IV) diagnostic criteria, as assessed by a semi-structured assessment (Kiddie Schedule for Affective Disorders and Schizophrenia - Present and Lifetime (KSADS-PL)) and a separate clinical interview with a child/adolescent psychiatrist for manic or mixed episodes in bipolar I disorder.
3. Score of > 20 on the YMRS at screening and baseline.
4. The participant and legal guardian must understand the nature of the study and be able to comply with protocol requirements. The legal guardian must give written informed consent and the youth, written assent.
5. Participants with comorbid conditions [attention deficit hyperactivity disorder (ADHD), conduct disorder], except those listed in Exclusion Criterion 2, may participate.
6. If female: is premenarchal, or is incapable of pregnancy because of a hysterectomy, tubal ligation, or spousal/partner sterility. If sexually active and capable of pregnancy, has been using an acceptable method of contraception (hormonal contraceptives, intrauterine device, spermicide and barrier) for at least one month prior to study entry and agrees to continue to use one of these for the duration of the study. If sexually abstinent and capable of pregnancy, agrees to continued abstinence or to use of an acceptable method of birth control should sexual activity commence.
7. Has a negative quantitative serum ß-human chorionic gonadotrophin hormone pregnancy test at screening and a negative qualitative urine pregnancy test at baseline, if female.
8. Participants with a history of substance abuse may participate if they agree to continue to abstain from drugs during the trial and have a negative drug screen at screening or prior to baseline. Those with an initial positive drug screen during initial screening may have another screen done 1-3 weeks later while in screening, and a negative result will allow the participant to participate.
9. The participant is willing and clinically able to wash out of exclusion medications during the screening period unless previously approved by the Pediatric Off-Patent Drug Study (PODS) PI or a BPCA DCC Medical Monitor. Prior to the Day 0 visit, participants will have not used any of the following medications within the specified time frames:
  - Preceding 3 days: stimulants or melatonin
  - Preceding 1 week: all other psychotropic medications such as mood stabilizers, anticonvulsants, alpha-2 agonists, antipsychotics (other than aripiprazole) and/or antidepressants
  - Preceding 2 weeks: monoamine oxidase inhibitors, aripiprazole, fluoxetine or depot antipsychotics
  No stable participants will be asked to discontinue medications.
10. Electrocardiogram (ECG) and blood work including Complete Blood Count (CBC), electrolytes, etc showing no clinically significant abnormalities.

### 9.3.2 Exclusion Criteria

1. Participant who is clinically stable on current medication regimen for bipolar disorder.
2. A current or lifetime diagnosis of Schizophrenia or Schizoaffective Disorder, a Pervasive Developmental Disorder (Autism Screening Questionnaire score > 15), Anorexia Nervosa, Bulimia Nervosa, or Obsessive-Compulsive Disorder.
3. Current DSM-IV diagnosis of Substance Dependence.
4. Positive drug screen at initial screening and on retest 1-3 weeks later.
5. Participants with symptoms of mania that may be attributable to a general medical condition, or secondary to use of medications (e.g., corticosteroids).
6. Evidence of any serious, unstable neurological illness for which treatment under the auspices of this study would be contraindicated.
7. Any serious, unstable medical illness or clinically significant abnormal laboratory assessments that would adversely impact the scientific interpretability or unduly increase the risks of the protocol.
8. Current general medical condition including neurological disease, diabetes mellitus, thyroid dysfunction, or renal dysfunction that might be affected adversely by lithium, could influence the efficacy or safety of lithium, or would complicate interpretation of study results.
9. Evidence of current serious homicidal/suicidal ideation such that in the treating physician’s opinion it would not be appropriately safe for the participant to participate in this study.
10. Evidence of current active hallucinations and delusions such that in the treating physician’s opinion it would not be appropriately safe for the participant to participate in this study.
11. Concomitant prescription of over-the-counter medication or nutritional supplements (e.g., ibuprofen, naproxen, St John’s wort) that would interact with lithium or affect the participant’s physical or mental status.
12. Concomitant psychotherapy treatments provided outside the study initiated within 4 weeks prior to screening.
13. Previous adequate trial with Li^+^ (at least 4 weeks with Li^+^ serum levels between 0.8-1.2 mEq/L)
14. History of allergy to lithium or lithium intolerance
15. Psychiatric hospitalization within 1 month of screening for psychosis or serious homicidal/serious suicidal ideation
16. Clinician’s judgment that participant is not likely to be able to complete the study as an outpatient due to psychiatric reasons
17. Females who are currently pregnant or lactating
18. Sexually active females who, in the investigators’ opinion, are not using an adequate form of birth control.
19. Participants who are unable to swallow the study medication
20. Participants for whom a baseline YMRS score of < 20 is anticipated
21. Participants with an IQ less than 70 (determined using the Wechsler Abbreviated Scales of Intelligence [WASI] Vocabulary and Matrix Reasoning Subscales)

### 9.3.3 Removal of Participants from Therapy or Assessment

Participants were removed from the study if safety or study compliance concerns occurred. Participants who withdrew or were withdrawn were not replaced.

## 9.4 Treatments

### 9.4.1 Treatments Administered

The starting dose of lithium was either 600 mg/day or 900 mg/day. Participants weighing less than 30 kg received 600 mg/day as their starting dose. All other participants began lithium therapy on 900 mg/day. Dose increases of 300mg/day occurred at study visits and phone calls until any one of the following criteria was met:

1. If the participant achieved a response as measured by a rating on the Clinical Global Improvement Scale (CGI-I) of ≤ 2 and ≥ 50% decrease in the Young Mania Rating Scale (YMRS)
2. If, in the investigator’s opinion, the participant experienced uncomfortable side effects that significantly impacted functioning and were of at least moderate severity (e.g., if the participant was falling asleep in school; had a significant tremor; had daytime enuresis or protracted nausea; or did not want to take lithium anymore).
3. If the serum lithium level was >1.4 mEq/L.
4. If the dose exceeded 40 mg/kg/day (with the exception of participants weighing less than 23 kg, who could receive up to 900 mg/day)

Participants assigned to placebo were randomized in equal numbers to a maximum dose of 20, 25, 30, 35, and 40 mg/kg/day, rounded up to the next highest dose level per placebo drug supply. The placebo minimum dose was based on the participant’s baseline weight (600 mg for <30 kg vs. 900 mg for >30 kg).

### 9.4.2 Identity of Investigational Products

The lithium carbonate was supplied by West-Ward Pharmaceutical Corporation. Each immediate release hard gelatin capsule with opaque flesh cap/opaque flesh body contained 300 mg of lithium carbonate. Inactive ingredients consisted of D&C Yellow #10, FD&C Green #3, FD&C Red #40, FD&C Yellow #6, Gelatin and Titanium Dioxide in the capsule shell. The printing ink contained: D&C Yellow #10, FD&C Blue #1, FD&C Blue #2, FD&C Red #40, n-Butyl Alcohol, Pharmaceutical Glaze, Propylene Glycol, SDA-3A Alcohol, and Synthetic Black Iron Oxide. -+

The placebo for Lithium Carbonate 300 mg capsules was supplied by West-Ward Pharmaceutical Corporation. Each capsule contained Anhydrous Lactose, Talc and the capsule shell for the 300 mg potency contained: D&C Yellow #10, FD&C Green #3, FD&C Red #40, FD&C Yellow #6, Gelatin and Titanium Dioxide. The printing ink contained D&C Yellow #10, FD&C Blue #1, FD&C Blue #2, FD&C Red #40, n-Butyl Alcohol, Pharmaceutical Glaze, Propylene Glycol, SDA-3A Alcohol, and Synthetic Black Iron Oxide.

### 9.4.3 Method of Assigning Participants to Treatment Groups

Participants enrolled into the Efficacy Phase were randomized to placebo or lithium in a 2:1 (lithium: placebo) allocation ratio. Participants who enrolled in the Long Term Efficacy Phase were treated with lithium. Participants who enrolled into the Discontinuation Phase were randomized in a 1:1 (lithium: placebo) allocation ratio. COLT1 Discontinuation Phase treatment assignments are included in Appendix 16.4.2.1. Participants who enrolled into the Restabilization Phase were treated with lithium.

Site staff were required to enter participant eligibility data for each study phase. For participants who were confirmed eligible for the Efficacy Phase and the Discontinuation Phase, treatment assignments were provided by the Data Coordinating Center’s internet data entry system (AdvantageEDC), which displayed the treatment assignment for the phase. The randomization process is further detailed in Appendix 16.1.7 (Randomization Information) and Appendix 16.1.9 (Statistical Analysis Plan).

### 9.4.4 Selection of Doses in the Study

Lithium doses were based on weight and increased to meet maximum tolerance; placebo doses were randomized as noted in Section 9.4.1.

### 9.4.5 Selection and Timing of Dose for Each Participant

The daily total dose of medication was to be divided into three doses (or 2 doses if total dose is 600 mg) throughout the day. Each dose was not to differ by more than 300 mg. Dose increases in capsule number began the day after the scheduled visit or phone call.

### 9.4.6 Blinding

The study personnel design during the blinded Efficacy and Discontinuation phases was based on the study design implemented by the Research Units in Pediatric Psychopharmacology (RUPP) research group (Scahill et al., 2001). There were two groups of clinicians and coordinators at each site that included a “blinded” team and an “unblinded” team. At a minimum, each team was composed of one child and adolescent psychiatrist and one site study coordinator.

To ensure the safety of the participants and to maintain the blind during the Efficacy and Discontinuation Phases, a blinded child and adolescent psychiatrist and a blinded study coordinator performed the study procedures during these randomized phases. The unblinded team assisted with randomization and monitored blood draws and the lithium blood levels of the participants.

The “unblinded” team performed study procedures during the open-label Long-Term Effectiveness Phase and the Restabilization Phase.

The Data Coordinating Center (DCC) also included a “blinded” team and an “unblinded” team, who worked with their respective site teams to provide data and protocol oversight. At a minimum, each team was composed of a protocol specialist, data manager, and statistician. The DCC blinded team provided support regarding protocol questions, procedures, and management of data unrelated to treatment information. The DCC unblinded team provided support regarding analysis, randomization, and management of the data related to treatment information, such as lithium blood levels and adverse events.

### 9.4.7 Prior and Concomitant Therapy

Medications that did not alter the pharmacokinetics of lithium could be prescribed for episodic or chronic use at the discretion of the treating physician. Medications that were not permitted during the study are listed in Table 9-1, and medications which were to be used with caution are listed in Table 9-2.

Table 9-1 Medications Not Permitted with Lithium^*^

MEDICATION | REASON
Non-steroidal anti-inflammatories:; a. Ibuprofen; b. Indomethacin; c. Naproxen; d. Phenylbutazone; e. Oxyphenbutazone; f. Azapropazone | Decreased renal lithium clearance; increased lithium levels.
Diuretics:; a. Thiazide diuretics; b. Asmotic diuretics or methyl xanthines; c. Loop diuretics and potassium sparing agents | a. Increased lithium levels; b. Decreased lithium levels; c. Variable effects
Metronidazole | Decreased lithium clearance; increased lithium toxicity
Angiotensin-converting enzyme inhibitors:; a. Enalapril; b. Captopril | Impaired lithium elimination

* Per FDA labeling

Table 9-2 Medications to be Used with Caution^*^

MEDICATION | REASON
Anticonvulsants:; a. Phenytoin; b. Carbamazepine | May have clinically significant drug interactions
Calcium antagonists | May increase neurotoxicity

* Per FDA labeling for Lithium

During the study, lorazepam or hydroxyzine could be prescribed by the treating physician as a rescue medication for sleeplessness and agitation. Lorazepam was prescribed in 0.5 mg doses, not exceeding 1 mg/day, at doses at least 4 hours apart. Hydroxyzine was prescribed in 25 mg doses, not exceeding 50 mg/day, at doses at least 4 hours apart. Lorazepam and hydroxyzine were not prescribed or taken by participants within 12 hours of psychometric assessment and did not count toward the maximum of two allowable adjunctive medications.

If a participant was receiving psychotherapy at the time of study entry, therapy must have been initiated and been at a stable intensity more than 4 weeks prior to screening. No increase in intensity of sessions was allowed during the Efficacy Phase.

Participants in the Efficacy Phase could be prescribed a psychostimulant and/or melatonin (up to a maximum of 3mg at bedtime for insomnia) at the Week 4 visit. In order to begin treatment with a psychostimulant during the Efficacy Phase, the participant was required to be a “partial responder” (YMRS reduction 25-49% [underlined: and] CGI≤ 3 or YMRS reduction ≥ 50% [underlined: and] CGI-I =3) or “responder” (YMRS reduction of ≥ 50% [underlined: and] CGI-I 1 or 2 (with baseline as a reference point) when psychostimulant treatment was initiated. If a participant was prescribed a psychostimulant and/or melatonin during the Efficacy Phase, the participant was permitted to stay on either or both agents throughout the duration of the trial.

For participants who received active lithium during the Efficacy Phase, psychotherapy could be initiated outside of the study anytime during the first 8 weeks of the Long-Term Efficacy Phase and was required to be at stable intensity for the last 4 weeks of the Long-Term Efficacy Phase prior to enrollment into the Discontinuation Phase. For participants who received placebo during the Efficacy Phase, no increase in intensity of sessions outside of the study was allowed during the first 8 weeks of the Long-Term Efficacy Phase. Psychotherapy could be initiated outside of the study during weeks 8-16 of the Long-Term Efficacy Phase and was required to be at stable intensity for the last 4 weeks of Long-Term Efficacy Phase prior to entry into the Discontinuation Phase.

Participants could be treated with adjunctive psychotropic medication during the Long-Term Effectiveness Phase if there was a need to address symptoms for refractory psychosis; manic/mixed manic symptoms; or associated symptoms of depression, anxiety, and/or ADHD, according to the treatment management noted in Table 9-3. Psychostimulants could be initiated during the Long-Term Effectiveness Phase as noted in Table 9-3 for participants who were not “responders” in the Efficacy Phase, but who were either “partial” or “full responders” during the Long-Term Effectiveness Phase.

Participants who were prescribed a psychostimulant, an antipsychotic, or an antidepressant medication during the Long-Term Effectiveness Phase were permitted to stay on those medications at the same dose throughout their participation in the Discontinuation and Restabilization Phases of this study. No dose changes to adjunctive medications or new adjunctive medications could be prescribed in the Discontinuation Phase.

During the Discontinuation Phase, initiation of psychotherapy outside of this study and any increase in intensity of sessions was not allowed.

During the Restabilization Phase, if the response to the re-institution of lithium was inadequate, adjunctive treatment as outlined in Table 9-3 was permissible. Psychotherapy outside of this study could be initiated or increased in intensity within the first 2 weeks of entry into the Restabilization Phase.

Table 9-3 COLT Reasonable Choices for the Management of Child and Adolescent BD

Rationale | Entry Criteria | First Line | Second Line | Third Line | Monitor
Psychosis | ≥ 3 on one of the key positive psychotic items ofBPRS-C | RIS^**^ | QUE^**^ | ARI^**^ | NRS; BARS; AIMS
Refractory Mania | YMRS ≥ 12 | VPA^*^ | QUE^**^ | ARI^**^ | Height/Weight; Females: Menstruation and changes in hair growth; NRS; BARS; AIMS; VPA levels
Depressive Episode | CDRS-R > 28 X 2 Weeks | LTG | QUE^**^ | CPM | Suicidal ideation; Agitation; Behavior changes; NRS; BARS; AIMS
Comorbid Anxiety | PARS impairment score ≥ 3 | VPA^*^ | QUE^**^ | LTG | As noted above for specific agents; NRS; BARS; AIMS; VPA levels
Comorbid ADHD | Parent ADHD-RS score of ≥ 12 on H/I and/or Inattention Subscale | MPH | MAS | ATM | Worsening mania; Psychosis

* Therapeutic levels for Valproate (VPA) are 85-110 mcg/ml.

** Risperidone (RIS), Quetiapine (QUE), Aripiprazole (ARI)

Divalproex sodium (Valproate, VPA), Lamotrigine (LTG)

Citalopram (CPM), Methylphenidate (MPH) (long-acting methylphenidate-based compounds); Mixed Aphetamine Salts (MAS) (long acting preparations), Atomoxetine (ATM)

NRS = Neurologic Rating Scale (Simpson & Angus, 1970); BARS= Barnes Akathisia Rating Scale (Barnes, 1989); AIMS= Abnormal Involuntary Movement Scale (NIMH, 1985)

** NRS, BARS and AIMS should be monitoring when taking antipsychotics.

### 9.4.8 Treatment Compliance

Participants were asked to return lithium dosing diaries and study medication at each visit. Adherence was assessed by comparing the actual number of pills returned and the expected number of pills returned. Medication compliance was assessed by review of the lithium trough serum levels. Compliance was defined as taking ≥ 60% of medication in one week.

## 9.5 Efficacy and Safety Variables

### 9.5.1 Efficacy and Safety Measurements Assessed and Flow Chart

The purpose of this study was to investigate the use of lithium for the treatment of pediatric participants with mania.

A chart of safety and psychometric assessment procedures are presented in Tables 9-5 and 9-6.

Table 9-4 Safety Assessment Procedures

(GRAY BOXES = ASSESSMENTS COMPLETED ONLY FOR PARTICIPANTS RANDOMIZED TO PLACEBO IN EFFICACY PHASE)
| Efficacy Phase | | | | | | | | | | | Long-Temn Effectiveness Phase | | | | | | | | | | | | | | | | | | Discontinuation Phase | | | | | | | | | | | | Phase
Study Week | S | D0 | D3/PC | W1 | W2 | W3 | W4 | W5/PC | W6 | W7/PC | W8/ET | D3/PC | W1 | W2 | W3/PC | W4 | W5/PC | W6 | W7/PC | W8 | W10 | W12 | W14 | W16 | W16 | W18 | W20 | W22 | W24/ET | W1 | W2 | W3 | W4 | W6 | W8 | W10 | W12 | W16 | W20 | W24 | W28/ET | W1 | W2 | W3 | W4 | W6 | W8/ET
Assessments
ECG | ✕ | | | | | | | | | | ✕ | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | ✕ | | | | | | ✕
Blood pressure | ✕ | ✕ | | ✕ | ✕ | ✕ | ✕ | | ✕ | | ✕ | | ✕ | ✕ | | ✕ | | ✕ | | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕
pulse | ✕ | ✕ | | ✕ | ✕ | ✕ | ✕ | | ✕ | | ✕ | | ✕ | ✕ | | ✕ | | ✕ | | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕
height (stadiometer) | ✕ | ✕ | | | | | | | | | ✕ | | | | | | | | | | | | | | | | | | | | | | | | | | | | | | ✕ | | | | | | ✕
weight | ✕ | ✕ | | ✕ | ✕ | ✕ | ✕ | | ✕ | | ✕ | | ✕ | ✕ | | ✕ | | ✕ | | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕
Side Effect Monitoring
Neurological Examination For Lithium (NELi) | ✕ | ✕ | | ✕ | ✕ | ✕ | ✕ | | ✕ | | ✕ | | ✕ | ✕ | | ✕ | | ✕ | | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕
Adverse Events | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕
Neurological Rating Scale (NRS)^1^ | ✕ | ✕ | | ✕ | ✕ | ✕ | ✕ | | ✕ | | ✕ | | ✕ | ✕ | | ✕ | | ✕ | | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕
Laboratory Tests
Chemistry Profile^2^ | f | | | | | | ✕ | | | | f | | | | | ✕ | | | | ✕ | | | | ✕ | | | | | f | | | | | | ✕ | | | ✕ | | | f | | | | ✕ | | f
CBC w/diff^3^ | f | | | | | | ✕ | | | | f | | | | | ✕ | | | | ✕ | | | | ✕ | | | | | f | | | | | | ✕ | | | ✕ | | | f | | | | ✕ | | f
Lithium Serum Levels^6^ | f | | | ✕ | ✕ | ✕ | ✕ | | ✕ | | f | | ✕ | ✕ | | ✕ | | ✕ | | ✕ | | ✕ | | ✕ | | ✕ | | | f | ✕ | ✕ | | ✕ | | ✕ | | ✕ | ✕ | | | f | ✕ | ✕ | | ✕ | ✕ | f
Urine Toxicology Screen^4^ | f | | | | | | ✕ | | | | f | | | | | ✕ | | | | ✕ | | | | ✕ | | | | | f | | | | | | ✕ | | | ✕ | | | f | | | | ✕ | | f
Urinalysis^5^ | f | | | | | | ✕ | | | | f | | | | | ✕ | | | | ✕ | | | | ✕ | | | | | f | | | | | | ✕ | | | ✕ | | | f | | | | ✕ | | f
PT/PTT | f | | | | | | | | | | f | | | | | | | | | ✕ | | | | ✕ | | | | | f | | | | | | ✕ | | | ✕ | | | f | | | | ✕ | | f
Fibrinogen | f | | | | | | | | | | f | | | | | | | | | ✕ | | | | ✕ | | | | | f | | | | | | ✕ | | | ✕ | | | f | | | | ✕ | | f
TSH | f | | | | χ | | ✕ | | | | f | | | ✕ | | ✕ | | | | ✕ | | | | ✕ | | | | | F | | | | | | ✕ | | | ✕ | | | f | | | | ✕ | | f
T3, T4 antithyroglobulin AB, Thyroid peroxidase AB | f | | | | ✕ | | ✕ | | | | f | | | | | ✕ | | | | ✕ | | | | ✕ | | | | | f | | | | | | ✕ | | | ✕ | | | f | | | | ✕ | | f
Serum Pregnancy Test | f | | | | | | | | | | f | | | | | | | | | ✕ | | | | ✕ | | | | | f | | | | | | ✕ | | | ✕ | | | f | | | | | | f
Urine Pregnancy Test | f | ✕ | | | | | | | | | f | | | | | | | | | ✕ | | | | ✕ | | | | | f | | | | | | ✕ | | | ✕ | | | f | | | | | | f
Creatinine Clearance | | ✕ | | | | | | | | | f | | | | | | | | | ✕ | | | | ✕ | | | | | f | | | | | | | | | ✕ | | | f | | | | | | f

1 The Barnes Akathisia Rating Scale (BARS) and Abnormal Involuntary Movement-Scale (AIMS) will he administered to participants at the star of an adjunctive antipsychotic. at every study of visit while on the adjunctive medication and for four weeks after discontinuation of adjunctive antipsychotic medication.

2 Chemistry Profile includes glucose, blood urea nitrogen, sodium, potassium, chloride, bicarbonate, calcium, phosphorus, magnesium, creatinine, kinase, ALT/SGPT, GGT, alkaline phosphatase total and direct bilirubin total protein, albumin, cholesterol, triglycerides. LDL, HDL and cholesterol/HDL ratio.

3 A CBC w/diff includes: WBC. RBC, hemoglobin, hematrocrit, mean corpuscular volume, mean cell hemoglobin, mean cell hemo-globin concentration, platelets, red cell distribution width (coefficient of variation) and mean platelet volume; the differential count will include: neutrophil, lymphocyte, monocyte, eosinophil and basophil.

4 Urine Toxicology Screen includes the following qualitative tests: amphetamines, urine barbiturates, benzoiodiazepines, cannabinoids, cocain, metabolite, methadone, opiates and PCP; repeat at BL if positive at SC. If the urine toxicology screen is missed, it must he collected at the following in clinic visit.

5 Urinalysis includes pH. specific-gravity, protein, glucose, white blood cell, red blood-cell, ketones and nitrite.

6 Lithium serum levels may be drawn with in 48 hours of the visit.

7 Phase I Weeks 5 and 7 and Phase II Weeks 3, 5, and 7 are phone calls completed by the study physician. The weeks 3, 5 and 7 phone calls in phase II are optional if the participant has achived maximum dose [underlined: or] the two bottle titration has-been completed.

f Fasting labs- if possible for the early termination visit of the discontinuation phases

Table 9-5 Psychometric Assessment Procedures

| Efficacy Phase | | | | | | | | | | | Long-Term Effectiveness Phase | | | | | | | | | | | | | | | | | Discontinuation Phase | | | | | | | | | | | | Restabilization Phase
Study Week | S | D0 | D3/PC | W1 | W2 | W3 | W4 | W5/PC | W6 | W7/ET | W8/ET | D3/PC | W1 | W2 | W3/PC | W4 | W5/PC | W6 | W7/PC | W8 | W10 | W12 | W14 | W16 | W18 | W20 | W22 | W24/ET | W1 | W2 | W3 | W4 | W6 | W8 | W10 | W12 | W16 | W20 | W24 | W28/ET | W1 | W2 | W3 | W4 | W6 | W8/ET
Assessments
Young Mania Rating Scale (YMRS) | ✕ | ✕ | | ✕ | ✕ | ✕ | ✕ | | ✕ | | ✕ | | ✕ | ✕ | | ✕ | | ✕ | | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕
Parent General Behaviour Inventory-10 Item Mania Scale (PGBI-10M) | | ✕ | | | | | ✕ | | | | ✕ | | | | | ✕ | | | | ✕ | | ✕ | | ✕ | | | | ✕ | | | | ✕ | | ✕ | | | ✕ | | | ✕ | | | | ✕ | | ✕
Children Depression Rating Scale-Revised (CDRS-R) | ✕ | ✕ | | ✕ | ✕ | ✕ | ✕ | | ✕ | | ✕ | | ✕ | ✕ | | ✕ | | ✕ | | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕
Clinical Global impression Scale-Seveirity (CGI-S) | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕
Clinical Global impression Scale-Improvement (CGI-I) | | | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕
Children’s Global Assessment Scale (CGAS) | | ✕ | | | | | ✕ | | | | ✕ | | | | | ✕ | | | | ✕ | | ✕ | | ✕ | | | | ✕ | | | | ✕ | | ✕ | | | ✕ | | | ✕ | | | | ✕ | | ✕
Child Mania Rating Scale-Parent (CMRS-P) | | ✕ | | | | | ✕ | | | | ✕
ADHD Rating Scale (ARS-IV; Patent) | | ✕ | | | | | ✕ | | | | ✕ | | | | | ✕ | | | | ✕ | | ✕ | | ✕ | | | | ✕ | | | | ✕ | | ✕ | | ✕ | | | | ✕ | | | | ✕ | | ✕
Brief Psychiatric Rating Scale (BPRS) | ✕ | ✕ | | | | | ✕ | | | | ✕ | | | | | ✕ | | | | ✕ | | ✕ | | ✕ | | | | ✕ | | | | ✕ | | ✕ | | | ✕ | | | ✕ | | | | ✕ | | ✕
Pediatric Anxiety Rating Scale (PARS) | | ✕ | | | | | ✕ | | | | ✕ | | | | | ✕ | | | | ✕ | | ✕ | | ✕ | | | | ✕ | | | | ✕ | | ✕ | | | ✕ | | | ✕ | | | | ✕ | | ✕
Columbia-Suicide Severity Rating Scale-Lifetime | ✕
Columbia-Suicide Severity Rating Scale-(C-SSRS) | | ✕ | | ✕ | ✕ | ✕ | ✕ | | ✕ | | ✕ | | ✕ | ✕ | | ✕ | | ✕ | | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕
Neurocognitive Testing | | ✕ | | | | | | | | | ✕ | | | | | | | | | | | | | | | | | ✕

Phase I Weeks 5 and 7 and Phase II Weeks 3, 5, and 7 are phone calls completed by the study physician. The weeks 3, 5 and 7 phone calls in Phase II are optional if the participant has achieved maximum dose [underlined: or] the two bottle titration hat been completed.

#### 9.5.1.1 Efficacy Variables

##### 9.5.1.1.1 Primary Efficacy Endpoints

The evaluation of primary efficacy endpoints was as follows:

- For the Efficacy Phase: the change from baseline to the end of phase (Week 8/ET) YMRS (Summary) scores, based upon LOCF values.
- For the Long-Term Effectiveness Phase: the change from baseline to end of phase (Week 24/ET) YMRS (Summary) scores, based upon LOCF values.
- For the Discontinuation Phase: the relative risk of discontinuation for any reason for lithium compared to placebo, using survival analysis methods.
- For the Restabilization Phase: change from baseline to end of phase (Week 8/ET) YMRS (Summary) scores, based upon LOCF values.

##### 9.5.1.1.2 Secondary Efficacy Endpoints

The evaluation of secondary efficacy endpoints was as follows:

- For the Efficacy Phase: the change from baseline to the end of phase (Week 8/ET) of Young Mania Rating Scale (YMRS Parent and Child Scores); Children Depression Rating Scale-Revised (CDRS-R); Children’s Global Assessment Scale (CGAS); Clinical Global Impressions Scale-Severity (CGI-S); Clinical Global Impressions Scale-Improvement (CGI-I); response status; remission status; improvement status; discontinuation for any reason during the phase; and discontinuation due to lack of efficacy during the phase.
- For the Long-Term Effectiveness Phase: descriptive summaries of change from baseline to end of phase LOCF values for: Young Mania Rating Scale (YMRS, Parent and Child Scores); Children’s Global Assessment Scale (CGAS); Children Depression Rating Scale-Revised (CDRS-R); Clinical Global Impressions Scale-Severity (CGI-S); Clinical Global Impressions Scale-Improvement (CGI-I); response status; remission status; improvement status; discontinuation for any reason during the phase; and discontinuation due to lack of efficacy during the phase.
- For the Discontinuation Phase: time to discontinuation for lack of efficacy; recurrence of mood episodes; time to intervention for mood episodes; change from baseline to end of phase LOCF values for: YMRS total score; YMRS parent score; YMRS child score; Children Depression Rating Scale-Revised (CDRS-R); Children’s Global Assessment Scale (CGAS); Clinical Global Impressions Scale-Severity (CGI-S); Clinical Global Impressions Scale-Improvement (CGI-I); response status; remission status; improvement status.
- For the Restabilization Phase: descriptive summaries of change from baseline to end of phase LOCF values for Young Mania Rating Scale (YMRS Parent and Child Scores); Children Depression Rating Scale-Revised (CDRS-R); Children’s Global Assessment Scale (CGAS); Clinical Global Impressions Scale-Severity (CGI-S); Clinical Global Impressions Scale-Improvement (CGI-I); response status; remission status; improvement status; discontinuation for any reason during the phase; and discontinuation due to lack of efficacy during the phase.

##### 9.5.1.1.3 Tertiary Efficacy Endpoints

The evaluation of tertiary efficacy endpoints was as follows:

- For the Efficacy Phase: overall/total scores and subscale scores for Parent General Behavior Inventory-10 Item Mania Scale (PGBI-10M); Child Mania Rating Scale-Parent version (CMRS-P); ADHD Rating Scale (ARS-IV); Brief Psychiatric Rating Scale for Children (BPRS-C); and Pediatric Anxiety Rating Scale (PARS).
- For the Long-Term Effectiveness Phase: descriptive summaries of change from baseline to end of phase LOCF values for Parent General Behavior Inventory-10 Item Mania Scale (PGBI-10M);; ADHD Rating Scale (ARS-IV); Brief Psychiatric Rating Scale for Children (BPRS-C); and Pediatric Anxiety Rating Scale (PARS).
- For the Discontinuation Phase: overall/total scores, and subscale scores for Parent General Behavior Inventory-10 Item Mania Scale (PGBI-10M);; ADHD Rating Scale (ARS-IV); Brief Psychiatric Rating Scale for Children (BPRS-C); and Pediatric Anxiety Rating Scale (PARS)
- For the Restabilization Phase: descriptive summaries of change from baseline to end of phase LOCF values for Parent General Behavior Inventory-10 Item Mania Scale (PGBI-10M); Child Mania Rating Scale-Parent version (CMRS-P); ADHD Rating Scale (ARSIV); Brief Psychiatric Rating Scale for Children (BPRS-C); and Pediatric Anxiety Rating Scale (PARS).

#### 9.5.1.2 Safety Variables

The evaluation of safety was based upon the following variables:

- Adverse events (AEs), treatment emergent adverse events (TEAEs), serious adverse events (SAEs), and TEAEs leading to study drug discontinuation
- Deaths
- Concomitant medications
- Concomitant psychotropic medications
- Concomitant psychotherapy
- Laboratory findings
- Vital Signs
- Electrocardiogram (ECG) investigations
- Physical examination findings
- Neurological Rating Scale (NRS)
- Columbia Suicide Severity Rating Scale
- Lithium serum levels

Safety summaries are provided across study phases and for each study phase separately in Section 12. Descriptive statistics are provided overall and by treatment group during the Efficacy and Discontinuation Phases, and overall during the Long-Term Effectiveness and Restabilization Phases. Baseline for the Efficacy Phase was the first day of study treatment (before treatment began). Baselines for the other three study phases (Long-Term Effectiveness, Discontinuation, and Restabilization) were the last assessment from the previous study phase. End of study phase values were the last assessments for the current study phase.

#### 9.5.1.3 Schedule of Assessments

A chart of general study assessment procedures are presented in Table 9-6.

Table 9-6 General Assessment Procedures^†^

Efficacy Phase | | | | | | | | | | | Long-Term Effectiveness Phase | | | | | | | | | | | | | | | | | Discontinuation Phase | | | | | | | | | | | | | Restabilization Phase
Study Week | S | D0 | D3/PC | W1 | W2 | W3 | W4 | W5/PC | W6 | W7/ET | W8/ET | D3/PC | W1 | W2 | W3/PC | W4 | W5/PC | W6 | W7/PC | W8 | W10 | W12 | W14 | W16 | W18 | W20 | W22 | W24/ET | W1 | W2 | W3 | W4 | W6 | W8 | W10 | W12 | W16 | W20 | W24 | W28/ET | W1 | W2 | W3 | W4 | W6 | W8/ET
Assessments
Informed Concent And Assent | ✕
Medical History | ✕
Psychiatric History | ✕
Physical Examination | ✕ | | | | | | | | | | ✕ | | | | | | | | | | | | | | | | | ✕ | | | | | | | | | | | | ✕ | | | | | | ✕
Tanner Stage | ✕ | | | | | | | | | | ✕ | | | | | | | | | | | | | | | | | ✕ | | | | | | | | | | | | ✕ | | | | | | ✕
Initial Evaluation /MSE | ✕
Re-Evaluation/MSE | | | | | | | | | | | ✕ | | | | | | | | | | | | | | | | | ✕ | | | | | | | | | | | | ✕ | | | | | | ✕
Demographic/Course Modifiers | ✕
Inclusion/Exclusion | ✕ | ✕ | | | | | | | | | ✕ | | | | | | | | | | | | | | | | | ✕ | | | | | | | | | | | | ✕
Female Reproductive Status | ✕ | ✕ | | | | | | | | | ✕ | | | | | | | | | ✕ | | | | ✕ | | | | ✕ | | | | | | ✕ | | | ✕ | | | ✕ | | | | | | ✕
Autism Screen Questionnaire | ✕
WASI (IQ)^*^ | ✕ | | | | | | | | | | | | | | | | | | | | | | | | | | | # | # | # | # | # | # | # | # | # | # | # | # | # | # | # | # | # | # | ✕
K-SADS PL | ✕
Narrative Summary | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕
Lithium Dosing Assessment | | ✕ | | ✕ | ✕ | ✕ | ✕ | | ✕ | | ✕ | | ✕ | ✕ | | ✕ | | ✕ | | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕
Lithium Dosing Diary | | ✕ | | ✕ | ✕ | ✕ | ✕ | | ✕ | | ✕ | | ✕ | ✕ | | ✕ | | ✕ | | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕
Medication Adeherence | | | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕
Concomitant Psychotropics Assessment | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕
Concomitant Medication Assessment | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕
Concomitant Psychotherapy Assessment | ✕ | ✕ | ✕ | ✕ | ✕ | | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕ | ✕

† [underlined: FOR PARTICIPANTS RANDOMIZED TO LITHIUM IN EFFICACY PHASE]: adjunctive psychotherapy mav begin at any time during the first 8 weeks of the Long-Term Effectiveness Phase and must be of stable intensity for the last 4 weeks of LTE prior to entry into the Discontinuation Phase; [underlined: FOR PARTICIPANTS RANDOMIZED TO PLACEBO IN EFFICACY PHASE]: adjunctive psychotherapy may begin durinb weeks 8-16 of the Long-Term Effectiveness Phase and must he of stable intensity for the last 4 weeks of LTE prior to entry into the Discontinuation Phase

* vocabulary and matrix reasoning subscales only

# obtained ONLY at participant’s FINAL VISIT (if final visit is end of week 24 of the Long-Term Effectiveness Phase or anytime thereafter)

~ - if applicable

Phase I Weeks 5 and 7 and Phase II, Weeks 3, 5, and 7 are phone call 5 to the family completed hy the study physician. The weeks 3, 5 and 7 phone call 5 in Phase II are optional if the participant has achieved maximum dose [underlined: or] the two bottle titration has been completed.

### 9.5.2 Appropriateness of Measurements

The efficacy or safety assessments used in this study are clinical laboratory tests and recognized as reliable and accurate. Laboratory, physical, and psychometric measurements are based on clinical study data.

### 9.5.3 Drug Concentration Measurements

Blood serum samples were analyzed for lithium concentrations by the site local laboratories’quantitative methods. In adults, the therapeutic range is between 0.8 and 1.2 mEq/L, with 1.5 mEq/Liter representing the lower limit of risk for intoxication (Amdisen, 1980). In the pediatric population, side effects have been reported at serum levels of 0.65 to 1.37 mEq/L (Hagino et al., 1995). Specimen collection time points are detailed in Section 9.5.1.

Lithium serum levels are summarized descriptively by visit separately for each study phase.

## 9.6 Data Quality Assurance

Procedures to assure the accuracy and reliability of data included selection of qualified investigators and appropriate study centers; review of protocol procedures with investigators and associated personnel prior to the study; and ongoing review of the site data and reports by the PODS Center and by the BPCA DCC.

### 9.6.1 Site Monitoring Visits

During the study, monitoring visits to the trial sites were scheduled and conducted consistent with the BPCA DCC Dynamic Monitoring Plan to ensure that all aspects of the protocol were followed. Source documents were reviewed for verification of data collected on the Electronic Case Report Forms (eCRFs). The PODS Center and participating sites guaranteed access to source documents by BPCA DCC and the IRB, and were given access when required. Site investigators and relevant site personnel were available during monitoring visits, and they set aside sufficient time for the process.

### 9.6.2 Clinical Data Management

An eCRF was used to record participant data in the AdvantageEDC system. The eCRF was used for recording all historical participant information and study data as specified by the protocol. The eCRF was completed by designated and trained study personnel. Testing instruments had total scores, summary scores or sub-scales scores collected in the AdvantageEDC while the individual score elements were collected on provided source documents, and were not entered into the Advantage EDC system. However, for the primary endpoint, YMRS, each individual score elements was entered into the AdvantageEDC system.

Prior to the initiation of the study, the sponsor approved of the selected clinical sites that were experts in the field and fully capable of carrying out the study. The BPCA DCC trained the investigators, sub-investigators, and their study coordinators in eCRF completion, study management tools, and regulatory compliance. The study staff at ▬ (the primary clinical site) trained other site staff on the protocol and performance of study procedures. In addition to the investigators’ meeting, the study personnel at each site were trained on the study procedures by a CRA as necessary. CRAs from The Emmes Corporation monitored each site throughout the study. At each visit, data recorded in the EDC system were compared to source documentation to ensure accuracy. Quality assurance checks were performed to ensure that the investigators were complying with the protocol and all applicable regulations. The data for all primary outcomes were 100% monitored.

In addition to the quality assurance checks incorporated into the EDC system, additional logic checks were run to check for such items, such as inconsistent study dates and outlying laboratory values. Prior to study data lock, any necessary corrections were made by site staff in the eCRF and documented via audit trail.

## 9.7 Statistical Methods and Determination of Sample Size

### 9.7.1 Statistical and Analytical Plans

#### 9.7.1.1 Analysis software

Analyses was performed using SAS version 9.2 or higher.

#### 9.7.1.2 Withdrawals, Missing Data, Outliers

LOCF analyses were conducted by carrying forward the last observed value to replace the missing value for the analysis of change from baseline to end of phase endpoints. Baseline efficacy values were not carried forward. Participants without post-baseline values for a given efficacy assessment were excluded from analyses based upon that assessment. If a participant was missing a response for any item needed for the computation of efficacy scores or subscores, the corresponding total score or subscore was regarded as missing.

Participants who withdrew or were withdrawn were not replaced.

#### 9.7.1.3 Multicenter Studies

Small sites (i.e., sites that had less than 4 participants per treatment arm) were identified and the following method used for combining the data to form analysis centers. Data from all small sites (<4 participants per arm) were combined to form a single analysis center in order to obviate non-estimable situations in the evaluation of site and site interaction effects. Once combined, the analysis center remained as such for all analyses for which a site interaction effect was determined.

#### 9.7.1.4 Multiple Comparisons

The primary efficacy hypotheses associated with the Efficacy Phase and the Discontinuation Phase were independent hypothesis tests, and consequently were analyzed using an overall significance level of 0.05 (α = 0.05) for each primary efficacy endpoint for each study phase.

The secondary and tertiary efficacy endpoints were considered supportive of the primary efficacy endpoint. A significance level of 0.05 was used for these analyses; no adjustments for multiplicity was made.

#### 9.7.1.5 Planned Subgroups, Interactions and Covariates

The PP (per protocol) efficacy population was used to confirm the results of the primary efficacy analysis conducted for the efficacy population in both the Efficacy Phase and the Discontinuation Phase.

### 9.7.2 Determination of Sample Size

Sample size calculations and power estimates were conducted first and foremost to determine the number of participants needed for the Efficacy Phase of the study. Secondarily, potentially detectable differences in the primary efficacy outcome for the Discontinuation Phase were estimated given assumptions about the sample size expected for that phase of the trial.

Given the single-arm, open-label design and the descriptive and exploratory statistical objectives of the Long-Term Effectiveness and Restabilization Phases, formal sample size estimates, and power calculations were not conducted for those study phases.

A blinded sample size recalculation was conducted in September 2011. In response to the BPCA Data Monitoring Committee’s (DMC) recommendation, the sample size was re-estimated in January 2012 using the observed treatment effect. Futility and inefficacy analyses were also conducted in May 2012 and July 2012 at the request of the DMC. During each interim analysis, enrollment was continued based on the DMC recommendations.

#### 9.7.2.1 Efficacy Phase

Sample size for the Efficacy Phase was determined based upon the number of participants required to demonstrate a statistically significant difference in the mean change from baseline to Week 8/ET in YMRS (Summary) scores in the two treatment arms, based upon last observation carried forward (LOCF) values. The null and alternative hypotheses for the primary efficacy endpoint are as follows:

- H_0_: There is no difference in mean change from baseline to Week 8/ET YMRS (Summary) scores between participants randomized to lithium and participants randomized to placebo.
- H_A_: There is a difference in mean change from baseline to Week 8/ET YMRS (Summary) scores between participants randomized to lithium and participants randomized to placebo.

Sample size estimates for the Efficacy Phase were based primarily upon the following considerations. First, the YMRS is an 11-item instrument with total score ranged from 0 to 60. Change from baseline is expected to be on a continuous scale, and mean change from baseline is expected to follow a Gaussian distribution. Second, the literature was reviewed to identify treatment differences and variability seen among adults with bipolar I disorder when treated with lithium vs. placebo. Storosum et al (2007) summarized the results of six placebo-controlled studies of the effect of lithium on adult participants with moderate to severe manic episodes following three weeks of treatment. Of these, the YMRS was used as the primary outcome measure in three studies. The differences between lithium and placebo in mean change from baseline YMRS scores in these adult studies were 5.2, 5.4 and 8.5 points; SDs associated with mean change from baseline YMRS scores ranged from 11.5 to 15.4 points for the lithium and placebo treatment groups (median of approximately 12 points).

Kowatch et al (2007) reported the results of a three-arm study comparing the effects of eight weeks of treatment with lithium, divalproex, and placebo in children and adolescents with bipolar I disorder (mixed or manic episode). The difference in mean change from baseline scores for lithium vs. placebo in that trial was approximately five points, with a common SD of approximately 10 points.

Finally, interim efficacy data from the Pharmacokinetic Phase of the COLT1 study was examined to further estimate the variability that could be expected in the current study. This assessment included data from 61 pediatric participants treated with lithium for eight weeks on three different dosing arms (starting doses of 300 mg, 600 mg and 900 mg of lithium carbonate). Of the 61 participants, 60 had at least one post-baseline YMRS (Summary) assessment. LOCF methods were used to determine the mean change from baseline in YMRS scores after eight weeks of treatment. For these 60 participants, a standard deviation of 8.8 points was observed.

A 5-point difference in YMRS change scores is considered clinically meaningful. For example, a 5-point decrease on the YMRS “content” item can be associated with a near normalization of grandiose or paranoid ideas (Young et al, 1978). Similarly, a 5-point decrease in the “disruptive-aggressive behavior” item can be associated with a near normalization of a threatening, difficult to manage youngster. As this magnitude of decrement of YMRS score is clinically meaningful, this magnitude of change has been used in industry-sponsored, FDA-approved protocols in pediatric mania. Such studies have led to labeling changes for this indication (Tohen et al, 2007; Haas et al, 2009; Findling et al, 2012; Pathak et al, 2013).

Based upon these considerations, it was determined that the present study would be powered to detect a five point difference between lithium and placebo in mean change from baseline YMRS (Summary) LOCF score after eight weeks of treatment during the Efficacy Phase, assuming a common SD of 12 points and a Student’s t-distribution. With a two-sided significance level of 5% (alpha=0.05), and a 2:1 (lithium:placebo) allocation ratio, 150 participants randomized to the lithium arm and 75 randomized to the placebo arm would provide at least 80% power (actual type II error, β=0.17) to reject the null hypothesis of no difference between lithium and placebo in mean change from baseline YMRS (Summary) score after eight weeks of treatment. This sample size assumes imputation (LOCF) to account for missing data for participants who discontinued the study during the Efficacy Phase. Without assuming LOCF to account for missing data, the study would provide 62% power to reject the null hypothesis, assuming an attrition rate of 25% for the lithium arm (75% with an available YMRS summary score after eight weeks of treatment) and an attrition rate of 35% for the placebo arm.

#### 9.7.2.2 Long-Term Efficacy Phase

Due to the single-arm, open-label design, and the descriptive and exploratory statistical objectives of the Long-Term Effectiveness Phase, formal sample size estimates and power calculations were not conducted for the study phase.

#### 9.7.2.3 Discontinuation Phase

The primary efficacy endpoint for the Discontinuation Phase was time to discontinuation for any reason. The null and alternative hypotheses for the primary efficacy endpoint were as follows:

H_0_: β_lithium_ = 0

versus the alternative:

H_A_: β_lithium_ ≠ 0,

where β_lithium_ is the coefficient of the treatment arm (lithium) in a Cox proportional hazards regression model compared to the placebo group. Thus β_lithium_ represents the log of the hazard ratio for comparing lithium to placebo and is equivalent to testing that the hazard ratio for discontinuation for any reason is significantly different from 1.

The primary objective of calculations related to sample size and power for the Discontinuation Phase was to estimate the difference between lithium and placebo arms in the distributions of time to discontinuation for any reason that could be detected given the total sample size. As stated previously, this analysis dataset is comprised of the participants randomized in this phase of the current study, plus the participants randomized in the Discontinuation Phase of the COLT1 study (n=21). In designing the COLT2 study, it was assumed that approximately 60 participants would be randomized into the Discontinuation Phase of the present study, resulting in a total sample size of 81 participants for the primary analysis dataset.

Assuming a lithium:placebo hazard ratio no larger than 0.52, a two-sided significance level of 5% (α=0.05) and a 1:1 (lithium:placebo) allocation ratio, 81 total participants would provide approximately 80% power (β=0.20) to reject the null hypothesis of no difference between lithium and placebo in time to discontinuation for any reason.

#### 9.7.2.4 Restabilization Phase

Due to the single-arm, open-label design and the descriptive and exploratory statistical objectives of the Restabilization Phase, formal sample size estimates and power calculations were not conducted for the study phase.

## 9.8 Interim Analysis and Data Monitoring

Interim safety analyses were scheduled in the protocol to be submitted to the DMC after enrollment of approximately 10%, 25%, 50% and 75% of participants. In addition, blinded sample size recalculation as well as interim futility and efficacy analyses, were carried out during the study. The list of completed interim analyses and dates are presented in Table 9-7.

Table 9-7 List of Interim Analysis and Dates

Dates | Completed Interim Analysis
June 2011 | Interim safety analysis.
September 2011 | Blinded sample size recalculation.
January 2012 | Response to DMC’s recommendation to re-estimate sample size using observed treatment effect.
May 2012 | Interim safety analysis
May 2012 | Interim futility and efficacy analysis.
July 2012 | Updated interim futility and inefficacy analysis.
September 2013 | Final safety analysis

### 9.8.1 Interim Safety Analysis on June 2011

The first Unblinded Safety Report for the Efficacy Phase was presented to the DMC at the June 29, 2011 meeting after enrollment of 25 participants (approximately 10% of the initially planned 225 participants). Documents related to this interim analysis are provided in Appendix 16.4.1. The DMC expressed serious concerns about study accrual. However, the study was allowed to continue because the DMC found no serious safety concerns with the study.

### 9.8.2 Blinded Sample Size Recalculation September 2011

The protocol specified a planned interim analysis when 75% of the participants had reached the end of the efficacy phase. The purpose of this analysis was to conduct a sample size re-estimation to ensure that the study had adequate power to detect a clinically important difference without unblinding the data. Per DMC’s request the BPCA DCC used the method specified in the protocol to evaluate pooled standard deviation of the primary endpoint with the current data in addition to using the COLT1 study standard deviation and to recalculate sample size based on updated estimate of the standard deviation.

Sample size for the Efficacy Phase of the COLT2 protocol was determined based upon the number of participants required to demonstrate a statistically significant difference in the mean change from baseline to Week 8/End-of-Phase in YMRS (Summary) scores between the two treatment arms, randomized 2:1 (lithium:placebo) based upon last observation carried forward (LOCF) values.

Estimated “true” within group sample variance was calculated using the following formula:

(( n − 1 ))/(( n − 2 )) × [σ^2^ − (Δ^2^)/(4)]

The original protocol sample size requirement of 225 was based on a difference of 5 points between lithium and placebo endpoints (delta of 5). The endpoint was the change in summary YMRS score from baseline to Week 8/End-of-Phase. The sample size assumed a SD of 12.0 and 83.5% power.

During Re-estimation, the sample size was recalculated (with results shown in Table 9-8) under the following alternatives:

- Protocol criteria (delta of 5 and SD of 12.0), but using a power of 80%.
- Delta of 5, the COLT1 study pooled standard deviation of the primary endpoint from Efficacy Phase of 8.8 and a power of 80%.
- Delta of 5, COLT2 study pooled standard deviation at the time of analysis (12.4) and a power of 80%.
- Original sample size calculations using a pooled standard deviation of 12.0 and power of 83.5%.

Table 9-8 Sample Size Recalculation

Standard Deviation of Change in YMRS | Power | Alpha | Lithium Sample Size | Placebo Sample Size | Total Sample Size
12.0 | 80.3 | 0.05 | 138 | 69 | 207
8.8 | 80.9 | 0.05 | 76 | 38 | 114
12.4 | 80.5 | 0.05 | 148 | 74 | 222
12.0 | 83.5 | 0.05 | 150 | 75 | 225

The highlighted row is the COLT2 original protocol sample size requirement, based on a SD of 12.0 and 83.5% power. For a power of 80.3%, the sample size estimate was 207. Using the SD found for the COLT1 study (8.8) and a power of 80.9%, the total sample size decreased to 114. Using the current COLT2 standard deviation of 12.4, the total sample size was estimated to be 222 (for power of 80.5%). Documents related to this interim analysis are provided in Appendix 16.4.1.

The DMC made a recommendation to NICHD to conduct an interim analysis to assess the actual delta, compare it to the estimated delta, and re-estimate the sample size.

### 9.8.3 Response to DMC’s Recommendation to Re-estimate Sample Size Using Observed Treatment Effect on January 2012

Following the review of the re-estimated sample size calculations, the DMC recommended that the study’s sample size be re-estimated using the treatment effect and standard deviation observed in the data collected to date. The DMC proposed an interim assessment of futility using conditional power based method and an interim monitoring for efficacy be conducted.

The BPCA DCC responded with an alternative plan because sample size re-estimation based on un-blinded observed treatment effect estimates are generally not recommended in statistical literature due to multiple reasons, including:

1. High variability of treatment effect estimated early in the trial can lead to potentially misleading large or small treatment effect.
2. Re-estimation of sample size using an interim treatment effect will affect the overall Type I and Type II error rates of the clinical trial.
3. Controversy over appropriate statistical methods that should be used to adjust the Type I and II error rates.
4. Sample size should be chosen to detect a clinically meaningful treatment effect and the treatment effect estimated in the interim might not meet this criteria.

FDA guidance on adaptive designs recommends the use of group sequential designs to effectively decrease the sample size.

Given this background and continued concerns about enrollment into the COLT2 trial, the BPCA DCC recommended an interim assessment of futility using conditional power based method. Under this plan, as per DMC’s recommendation, the study would be stopped early if the conditional power to detect hypothesized treatment effect of 5 was below a pre-specified threshold. The assessment of conditional power for futility would lead to decrease in power of the study. However, the impact on power would be minimal, especially if the threshold chosen was small. In addition, following the recommendations of the FDA Guidance document on adaptive design, the BPCA DCC suggested implementing interim monitoring for efficacy. This plan would allow the study to be stopped early if the observed treatment effect was much larger than the hypothesized value. Documents related to this interim analysis are provided in Appendix 16.4.1. Amendment 6 of the Protocol, dated March 8, 2012, was adopted to reflect these changes in interim analyses.

### 9.8.4 Interim Safety Analysis on May 2012

The second Unblinded Safety Report on the Efficacy Phase was presented to the DMC at the May 11, 2012 meeting after the enrollment of 55 participants, with the planned safety analysis at 25% of targeted enrollment of 225. The DMC noted that there were no obvious safety concerns observed from the data, and recommended that enrollment should continue. Documents related to this interim analysis are provided in Appendix 16.4.1.

### 9.8.5 Interim Analysis for Futility and Efficacy on May 2012, Updated July 2012

The interim Analysis for Futility and Efficacy based on Protocol Amendment 6.0 was presented to the DMC at the May 11, 2012 meeting. The analyses were updated and presented again at the July 23, 2012 meeting, following correction of the YMRS data used for one participant.

As discussed above, the interim assessment of futility would have allowed the DMC to recommend stopping the study early if the conditional power to detect hypothesized treatment effect of 5 was below a pre-specified threshold. The interim assessment of efficacy would have allowed the study to stop early if the observed treatment effect was much larger than the hypothesized value.

Table 9-9 Distribution of YMRS Total Score and YMRS Change Score by Treatment

| LITHIUM | | | | PLACEBO
YMRS Total Score | N | Mean | Standard Deviation | 95% CI of mean | N | Mean | Standard Deviation | 95% CI of mean
Baseline | 38 | 29.74 | 5.56 | 27.91 – 31.56 | 16 | 31.44 | 6.56 | 27.94 – 34.93
Week 8/LOCF | 38 | 16.11 | 9.73 | 12.91 – 19.30 | 16 | 24.75 | 10.19 | 19.32 – 30.18
Change (Δ) | 38 | 13.63 | 10.09 | 10.32 – 16.95 | 16 | 6.69 | 11.00 | 0.83 – 12.55

Δ = Baseline YMRS Total Score minus the Week 8/LOCF YMRS Total Score

Table 9-10 Distribution of Difference Between Treatments in YMRS Change Score

Difference (L – P) in change (Δ) scores
Mean | Standard Deviation | 95% CI of mean
6.94 | 10.36 | 0.75 – 13.14

#### 9.8.5.1 Futility Analysis

The interim futility analysis based on conditional power (CP) was used as a guideline for early termination of the trial. Conditional power was defined as the probability that the final study result would be statistically significant, given the observed data and a specific assumption about the pattern of the data to be observed in the remainder of the study. The conditional power was calculated based on the primary efficacy endpoint (change from baseline to Week 8/LOCF in YMRS Total Score). This interim analysis was conducted after 54 participants reached the end of the efficacy phase. Conditional power was based on a target sample size of 100 participants. The DMC requested this target sample size given the rate of enrollment at the time of the interim analyses. A decision was made to stop the study (analysis of futility) and “accept” the null hypothesis (Section 9.7.2.1) if a conditional power calculated to detect the hypothesized treatment effect (a 5-point difference in YMRS change scores) fell below the pre-specified threshold of 40%, which means that if the computed conditional power fell below this value the chance of finding a significant result at the target sample size of 100 would be less than 40%.

The conditional power for some alternative effect using a critical value of Z_α/2_ for a Type I error rate of α=0.05 was computed as:

C P [Z ( 1 ) ≥ Z_α / 2_ ∣ Z ( t ) , θ] = 1 − Φ (∣ Z_α / 2_ − Z ( t ) sqrt(t) − θ ( 1 − t ) ∣ / sqrt(( 1 − t )))

; where t = n/N_o_ (N_o_ = 100 and n is total enrolled at the interim analysis, approximately 50).

The alternative θ is defined as:

θ = 1 / sqrt(2) ((μ_1_ − μ_2_)/(σ)) sqrt(N_o_)

; where μ_1_ and μ_2_ are the mean change from baseline in YMRS score for the placebo and lithium arms and σ is the common standard deviation. Results of the calculation for the conditional power of the study at N=100 is shown in Table 9-11.

Table 9-11 Conditional Power (Futility) Analysis at N=100

Alternative Hypothesis | Conditional Power
Hypothesized Mean Δ = 5; SD of Δ = 12 | 0.9390
Current Trend Mean Δ = 6.94; SD of Δ = 10.36 | 0.9971
Hypothesized Mean Δ = 5; Current SD of Δ = 10.36 | 0.9688
Under Null Hypothesis: Mean Δ = 0; SD of Δ = 12 | 0.3256

If the remaining data collected had a change in YMRS of 5 points and SD of 12 points the conditional power would be 93.9%. As this conditional power is above the selected 40% threshold, the decision was made not to stop the study due to futility.

#### 9.8.5.2 Efficacy Analysis

Simultaneous with the conditional power analysis, the first interim analysis for efficacy was completed. At the start of the study, the DMC planned to review results from an interim analysis for efficacy two times during the course of the study (after approximately 50 and 100 of the participants have reached the end of the Efficacy Phase). For the purpose of sequential monitoring, the primary efficacy endpoint was the change in YMRS Total Score from baseline YMRS score to Week 8/LOCF.

The following group sequential test plan for efficacy outcome describes how alpha (α) was spent across the two interim looks and a final look at the data. This interim analysis was performed based on the primary efficacy outcome and was unadjusted for any covariates. The interim looks and a final look were based on the group sequential procedure. The symmetric O’Brien-Fleming (1979) boundary was used as it is very conservative (requires a large treatment effect to signal stopping) during the early analyses. The alpha level or Type I error in a non-sequential design was assigned to one (final) analysis. The goal of a group sequential design was to control the overall Type I error rate.

Table 9-12 Efficacy Analysis

Current Sample Size (n) | Information Fraction (n/225) | Observed Z-Statistics | O’Brien-Fleming Boundary | Cumulative Alpha
54 | 0.24 | 2.25 | ± 4.4279 | 0.00001

Using the total planned sample size of 225, data from the 54 participants provided approximately 24% of the total information for the study. The test statistic of 2.25 at the interim look was below the conservative O’Brien-Fleming bound of 4.4279 and, therefore, the study did not meet threshold to declare the observed differences to be statistically significant and the study was not stopped early.

Based on the interim analyses, the goal was to randomize 100 participants. However, the contract for the study ended in April 2013 and the period of performance could not be extended.

The study was closed to enrollment in December 2012, with 81 participants randomized, in order to meet the timeline for the administrative closure of the study in April 2013.

### 9.8.6 Final Safety Analysis on September 2013

The final Unblinded Safety Report on the Efficacy Phase was presented to the DMC after enrollment was closed at 81 participants. Documents related to this interim analysis are provided in Appendix 16.4.1.

## 9.9 Changes in the Conduct of the Study or the Planned Analyses

### 9.9.1 Changes in Conduct of Study

There were six amendments implemented to the original protocol (dated April 8, 2009). The original protocol and the six amended protocols are provided in Appendix 16.1.1. No participants were screened or enrolled into the study under of the original protocol.

The six amendments to the protocol are summarized in this section.

#### 9.9.1.1 Protocol Amendment 1

Protocol Amendment 1, dated November 25, 2009, was issued to clarify the intent of some sections of the original protocol. Changes to the protocol affected the overall study design and study conduct. No participants were enrolled into the study under this version of the protocol. Changes made in Protocol Amendment 1 are presented in the table below.

AMENDMENT CHANGE | SECTION(S) AFFECTED BY AMENDMENT CHANGE
Subject or patient replaced with participant | All applicable sections
Minor formatting, grammatical and spelling errors replaced | All applicable sections
BPCA Coordinating Center, BPCA-CC changed to BPCA Data Coordinating Center, BPCA DCC | All applicable sections
Suicide Severity Rating Scale, SSRS changed to Columbia-Suicide Severity Rating Scale, C-SSRS | All applicable sections
Data Safety and Monitoring Board, DSMB changed to Data Monitoring Committee, DMC | All applicable sections
Number of sites changed from 9 to 10 | All applicable sections
Physician changed to Investigator | All applicable sections
CRA changed to site monitor | All applicable sections
New DCC contact information replaced prior DCC | Study Contact Information
#5: “…pre-and post-acute and open trials” changed to “…prior to treatment at baseline, at the end of week 8/early termination of the Efficacy Phase, and at the end of week 24/early termination from the Long-Term Effectiveness Phase (after 24/32 weeks of lithium treatment).” | Protocol Synopsis
Added #10: To evaluate the influence of intrinsic factors [e.g. age, gender, race, renal function, height, (measured by stadiometer) and weight] on lithium exposure. | Protocol Synopsis
Estimated start date changed from 2009 to 2010 | Protocol Synopsis
Estimated finish date changed from 2012 to 2013 | Protocol Synopsis
Added the following to the 2^nd^ paragraph, 1^st^ sentence of the Protocol Synopsis Statistical Considerations Section: … based upon last observation carried forward (LOCF) values. | Protocol Synopsis
Added abbreviations | List of Abbreviations
Made minor changes to legend for Figures 1 and 2 | Overview
Table 2 updated to reflect updated results from Study 1 | Section 2.0 Developing an Evidence-Based Dosing Strategy for Lithium
Symbol changes made in 2^nd^ paragraph, 2^nd^ entry | Section 4.1 Overall Study Design
1^st^ paragraph, 2^nd^ sentence updated to include the number of participants in each treatment arm | Section 4.1.1 Efficacy Phase (8 weeks)
Abbreviation for serious adverse events (SAE) added to last paragraph, last sentence | Section 4.4.3 Safety Assessments including Adverse Event Reporting
Deleted “weekly” from Table 6 footnotes | Section 5.0 Study Procedures
Added “legal” to 1^st^ paragraph, 1^st^ sentence; 1^st^ paragraph, last sentence; and 2^nd^ paragraph, 1^st^ sentence | Section 5.1.1 Informed Consent
Added “legal guardian” to 1^st^ paragraph, 1^st^ sentence; “legal” to 1^st^ paragraph, last sentence; and “investigator” to 3^rd^ paragraph, 3^rd^ sentence | Section 5.1.2 Screening Procedures
Added reference to the AdvantageEDC system to 2^nd^ paragraph | Section 5.2.1 Random Assignment of Participants to the Efficacy Phase
Added “allocation” to 1^st^ paragraph and “in this phase” to 2^nd^ paragraph | Section 5.2.3 Random Assignment of Participants to Discontinuation Phase
Removed reference to IVRS and added reference to AdvantageEDC | Section 5.2.3 Random Assignment of Participants to Discontinuation Phase
Added “… and 40 mg/kg/day” to be consistent with the maximum dose for the Li+ treated group | Section 5.2.5 Procedures for Maintaining the Blind during the Discontinuation Phase
Changed “… 2-bottle schema …” to “… 3-bottle schema …” | Section 5.2.7 Procedure for Administration of Placebo during the Discontinuation Phase
Deleted “Week ..” from the first row of Table 9 | Section 5.2.7 Procedure for Administration of Placebo during the Discontinuation Phase
Updated the process for reporting protocol violations | Section 5.3 Protocol Violations
Updated the section reference in last sentence from 5.6.1 to 6.4.1 | Section 6.4 Physical Examination
Noted that responses from assessments will be evaluated for reportable adverse events | Section 6.5.2 Elicitation of Adverse Events from Participants and Guardians
Added a reference to AdvantageEDC system
Added that laboratory results and physical exam findings will be captured in the AdvantageEDC system and those that the investigator considers clinically significant will also be reported as AEs
Revised definitions of AE severity | Section 6.5.3 Adverse Event Severity
Revised definitions for determining AE relation to study medication | Section 6.5.4 Adverse Event Relation to Study Medication
Code of Federal Regulations abbreviated as CFR | Section 6.5.6 Serious Adverse Event (SAE)
Deleted 3^rd^ paragraph referring to unexpected AEs
Added a new section titled “Unexpected” | Section 6.5.7 Unexpected
Sections 6.5.7 – 6.5.9 changed to 6.5.8 – 6.5.10 | Sections 6.5.8 – 6.5.10
Added a reference to AdvantageEDC system and deleted references to old system for reporting AEs | Section 6.5.8 Procedures for Assessing, Recording and Reporting SAE
Noted that outcome of a pregnancy must be reported to the BPCA DCC | Section 6.6 Pregnancy and Lithium
Added “investigator” to 1^st^ paragraph, 1^st^ sentence and added “/guardians” to 2^nd^ paragraph, 1^st^ sentence | Section 8.1.2 Efficacy Phase Baseline Procedures
Updated supply information in 2^nd^ paragraph, 4^th^ sentence | Section 8.2.2 Long-Term Effectiveness Follow-up Visits in Participants Treated with Placebo in Efficacy Phase
Added “/legal guardian” to 4^th^ paragraph, 1^st^ sentence | Section 8.2.2 Long-Term Effectiveness Follow-up Visits in Participants Treated with Placebo in Efficacy Phase
Added “/Guardians” to 6^th^ paragraph, 1^st^ sentence | Section 8.2.3 Long-Term Effectiveness Follow-up Visits in Participants that received lithium in the Efficacy Phase
Added “day” to 4^th^ paragraph, 2^nd^ sentence and added “/legal guardians” to 6^th^ paragraph, 2^nd^ sentence | Section 8.3.1 Study Visit Procedures
Specified the determination of persistent moderate symptoms of depression and mania | Section 8.3.3 Withdrawal from the Discontinuation Phase and Eligibility for Restabilization Phase
Added to last bullet: … as compared to the final open label treatment. | Section 8.3.3 Withdrawal from the Discontinuation Phase and Eligibility for Restabilization Phase
Removed specific reference to site names and PIs from the protocol; this will eliminate the need to do a protocol amendment if sites/PIs change during the course of the study | Section 9.1 Steering Committee
COLT changed to COLT2 | Section 9.2 Responsibilities of the Clinical (Principal) Investigator
Added to end of 3^rd^ paragraph: … clinical trial. | Section 9.3.2 Data Monitoring
Revised protocol to include an interim sample size re-estimation analysis | Committee (DMC)
Updated information on the investigational product | Section 9.5.1 Identity of Investigational Product
Added a reference to using AdvantageEDC for randomization and updated information on the investigational product | Section 9.5.2 Blinding and Placebo Capsules
Updated information regarding emergency unblinding procedures | Section 9.5.2 Blinding and Placebo Capsules
Added details on drug accountability and AdvantageEDC | Section 9.5.4 Drug Accountability
Added information on the sample size calculation including providing a sample size calculation that does not assume LOCF to account for missing data | Section 10.2.1 Efficacy Phase
Removed reference to assessing the treatment by center interaction for the primary efficacy analysis. The treatment by center interaction will now be part of the exploratory analyses. Also included age and weight strata as factors in the primary efficacy analysis. | Section 10.6.1 Efficacy Phase (Primary Efficacy Endpoint and Analysis)
Added a paragraph noting that the efficacy analysis will be performed on the ITT population and that similar analyses will be conducted using the PP population | Section 10.6.1 Efficacy Phase (Primary Efficacy Endpoint and Analysis)
Added specific details on the interim sample size re-estimation analysis. | Section 10.6.1 Efficacy Phase (Interim Analysis)
Added weight category as a factor for the secondary efficacy analyses | Section 10.6.1 Efficacy Phase (Secondary Efficacy Endpoints and Analyses)
Removed center as a stratification variable for secondary analyses. Center by treatment interactions will be done as exploratory analyses. | Section 10.6.1 Efficacy Phase (Secondary Efficacy Endpoints and Analyses)
Added a section on exploratory analyses | Section 10.6.1 Efficacy Phase (Exploratory Analyses)
Removed the following sentence “Analysis center will not be included as a factor in the analyses described in this section unless analyses conducted on Efficacy Phase data uncover a qualitative analysis center effect.” | Section 10.6.3 Discontinuation Phase
Revised text to note that the analysis model stratified Cox proportional hazards model | Section 10.6.3 Discontinuation Phase (Primary Efficacy Endpoint and Analysis)
Revised text to note that the analysis model will be stratified | Section 10.6.3 Discontinuation Phase (Secondary Efficacy Endpoints and Analysis)
Added information on the interim sample size re-estimation analysis | Section 10.10.3 Interim Analysis and Data Monitoring
Revised text to reference AdvantageEDC | Section 12 Data Quality Control and Assurance
Revised text to note that an AdvantageEDC and eCRFs will be used for the study | Section 12.2 Electronic Case Report Forms (eCRF)
Revised text to reference AdvantageEDC | Section 12.4 Site Monitoring Visits
| Section 12.6 Data Processing and Data Management
Revised text to update process for record retention | Section 12.9 Record Retention
Two references added | Section 15.0 References
Parent changed to parent/guardian | Appendix C: Description of Psychometric Assessments
Updated table footnotes | Appendix E: Adjunctive Medication Treatment

#### 9.9.1.2 Protocol Amendment 2

Protocol Amendment 2, dated December 23, 2009, was issued to clarify the intent of some sections of the original protocol. Changes to the protocol affected the overall study design and study conduct. No participants were screened or enrolled into the study under this version of the protocol. Changes made in Protocol Amendment 2 are presented in the table below.

AMENDMENT CHANGE | SECTION(S) AFFECTED BY AMENDMENT CHANGE
Minor formatting, grammatical and spelling errors replaced | All applicable sections
“Long Term” replaced with “Long-Term” | All applicable sections
Full address for PODS center added | Study Protocol Agreement Form
“from baseline” added to the Response section | Section 4.1 Overall Study Design
“D1” changed to “D0” | Tables 5, 6 and 7
Initial dosing day changed to “day after visit 1” | Section 5.2.4 Procedures for Administration
Statement added regarding when participants should start taking study medication | Section 8.1.2 Efficacy Phase Baseline Procedures
Statement added regarding the recording of study medication on drug accountability logs | Section 9.5.4 Drug Accountability
“Without assuming LOCF to account for missing data,” added to last paragraph | Section 10.2.1 Efficacy Phase

#### 9.9.1.3 Protocol Amendment 3

Protocol Amendment 3, dated April 28, 2010, was issued to clarify the intent of some sections of the original protocol. Changes to the protocol affected the overall study design and study conduct. No participants were enrolled into the study under this version of the protocol. Changes made in Protocol Amendment 3 are presented in the table below.

AMENDMENT CHANGE | SECTION(S) AFFECTED BY AMENDMENT CHANGE
Minor formatting, grammatical and spelling errors replaced | All applicable sections
Under Partial Responders, Deleted “YMRS reduction ≥ 50% [underlined: and] CGI-I = 3” | Figure on page 17; Section 4. 1 and the schematic in Section 4.1.1; Section 10.6.1
Clarified inclusion criteria for wash out procedures for medications | Section 4.1.2
Clarified study procedures | Sections 4.3, 8.2.2, 8.2.3, 8.3.1, 8.4
Clarified wash out procedures for medications | Section 4.2.1
Updated references | Sections 4.4.2, 15.0
Updated screening procedures to reflect change from 6 weeks to 4 weeks (decreased period need for wash out of meds) | Section 5.1.2
Added HDL, LDL and cholesterol/HDL ratio (already described in text of protocol); fixed “nitrate” typo | Table 6, Section 6.1
Deleted a stratification criterion for randomization into discontinuation | Section 5.2.3
Updated protocol deviation procedures | Section 5.3
Added “as needed for clinical care” for pregnancy and drug testing | Section 6.1
Clarified calculation for creatinine clearance | Section 6.1
Clarified procedures for reporting elicited adverse events | Section 6.5.2
Updated neurocognitive tests and procedures to reflect the current tests | Sections 8.1.5, 10.7.7; Appendices G, H
Expanded bimonthly visit window to +/− 5 days and monthly visit window to +/− 7 days | Sections 8.2.2, 8.2.3, 8.3.1, 8.4
Clarified when dose changes can start | Sections 8.2.2, 8.2.3, 8.3.1
Added procedures for unscheduled visit | Section 8.5
Added unblinding procedures | Section 9.5.2
Revised assessment subscales for Nisonger Child Behavior Rating Form | Section 10.6
Clarified Statistical Analysis | Section 10.6.1
Updated Neurocog Data Analysis | Section 10.9
Updated “Other Symptom Domains” section | Appendix C
Added NRS, BARS, AIMS monitoring for antipsychotics | Appendix E

#### 9.9.1.4 Protocol Amendment 4

Protocol Amendment 4, dated September 27, 2010, was issued to clarify the intent of some sections of the original protocol. Changes to the protocol affected the overall study design and study conduct. Changes made in Protocol Amendment 4 are presented in the table below.

AMENDMENT CHANGE | SECTION(S) AFFECTED BY AMENDMENT CHANGE
Minor formatting, grammatical and spelling errors replaced. | All applicable sections
Estimated start date changed from [underlined: January] 2010 to [underlined: April] 2010 | Protocol synopsis
“General Behavior Inventory – Parent short form (PGBI; Youngstrom et al., 2008” changed to “Parent General Behavior Inventory – [underlined: 10 Item Mania Scale] (PGBI – [underlined: 10M]; Youngstrom et al., 2008” | All applicable sections
“[underlined: EMMES]’ electronic data capture system” changed to “[underlined: BPCA DCC’s] Electronic Data Capture System” Added “EOW -End of week”,; - “MSE-Mental Status Exam”; - “TEAE- Treatment Emergent Adverse Event” | List of abbreviations
PGBI -Parent General Behavior Inventory” changed to “PGBI[underlined: -10M]-Parent General Behavior Inventory[underlined: -10 Item Mania Scale”] | All applicable sections
Deleted “BP I, 7 – 17 years old” and Added “Screening” at the top. Added “(n~225)” under Efficacy Phase | Overview- Schematic Diagram
Change under Lithium; From “Non-responders” to “Non-responders- (<25% ↓ YMRS [underlined: or] CGI-I ≥ 4).; Change under Placebo; From “Responders-CGI-I[underlined: <2;>] 50% ↓ YMRS” to (≥ 50% ↓ YMRS & CGI-I = 1 or 2 | Sections 4.1.1 Efficacy phase Schematic Diagram
Revised discontinuation Criteria f. Clarification added regarding a positive drug screen while tapering off or starting on a stimulant. | Section 4.2.3
Changed:; “Female Reproductive [underlined: Form]” to “Female Reproductive [underlined: Status]”; “Lithium Dosing Form” to “Lithium Dosing Assessment”; “Concomitant Psychotropics Form” to “Concomitant Psychotropics Assessment”; “Concomitant Medication form” to “Concomitant Medication Assessment”; “Concomitant Psychotherapy Form” to “Concomitant Psychotherapy Assessment” | Table 5
Changes in table and legend:; Symbols changed to numbers.; Changed “urea nitrogen” to “blood urea nitrogen”.; Changed “AST” and “ALT” to “AST/SGOT” and “ALT/SGPT”.; Abbreviated “white blood cell count” and “red blood cell count” as “WBC” and “RBC”. | Table 6
Further clarification added for screening urine toxicology exclusion criteria.; 2^nd^ last paragraph, “suicidality” changed to “suicidal ideation”. | Section 5.1.2
Line 3, deleted unblinded medical monitors; Line 5, changed “unblinded medical monitors” to unblinded clinicians” | Section 5.2
Clarified when dose increases and dose decreases can occur | Sections 5.2, 5.2.4, 8.2.3, 8.3.1 and 8.4
Clarified the start day of study medication after randomization into the Efficacy Phase; Changed “Participants’ maximum dosing for lithium is described below” to “Participants’ maximum dosing for lithium is in Section 5.2.6” | Section 5.2.4
Changed “…next highest dose level per [underlined: lithium] drug supply” to “…next highest dose level per [underlined: placebo] drug supply”; Deleted “lithium” from “…of 1200 mg of lithium per day)” | Section 5.2.5
Clarification added for dose increase after meeting criteria b or c; 3^rd^ paragraph after Table 8- “…unblinded clinician at each site” changed to “…unblinded investigator at each site” and deleted “the site medical monitor” | Sections 5.2.6, 8.2.2 and 8.2.3
Clarified headers in Table 9 | Section 5.2.7, Table 9
Clarified waiver procedures if the waiver is potentially unblinding | Section 5.3
Specified anti-thyroid antibodies; added specifics to the chemistry profile and elaborated on thyroid abnormalities and the process for monitoring | Section 6.1
Clarified the monitoring of lithium levels | Section 6.2
Updated the definition of Adverse Event | Section 6.5.1
Added requirement of SAE reporting to local IRBs | Section 6.5.8
Clarified Pregnancy procedures | Section 6.6
Added information on disclosing treatment at the end of the Efficacy Phase | Section 8.1.4
Updated the role of the Data Monitoring Committee | Section 9.3.2
Updated the contents of the Investigational Product and Placebo | Section 9.5.1
Updated disposition procedures for Investigational Product | Section 9.5.3
Deleted the statement “If QT data re-collected…. | Section 10.7.5
Clarified and updated “Data Quality and Assurance” section | Section 12.3
Added a statement regarding the location of the site monitoring procedures | Section 12.4

#### 9.9.1.5 Protocol Amendment 5

Protocol Amendment 5, dated July 15, 2011, was issued to clarify the intent of some sections of the original protocol. Changes to the protocol affected the overall study design and study conduct. Changes made in Protocol Amendment 5 are presented in the table below.

AMENDMENT CHANGE | SECTION(S) AFFECTED BY AMENDMENT CHANGE
Minor formatting, grammatical and spelling errors corrected | All applicable sections
Removal of the following assessments to reduce burden on the participants: The Drug Use Screening Inventory (DUSI), Irritability, Depression, Anxiety Scale (IDA), Nisonger Child Behavior Rating Form - TIQ(NCBRF-TIQ), Social Adjustment Inventory for Children and Adolescents (SAICA), The Caregiver Strain Questionnaire (CSQ), Family Environmental Scale (FES) | Protocol Synopsis, List of Abbreviations, Sections 4.4.2 Secondary Assessments, 4.4.3 Safety Assessments including Adverse Event Reporting, 10.6 Efficacy Analysis, 10.6.1 Efficacy Phase, 10.6.2 Long-Term Effectiveness Phase, 10.6.3 Discontinuation Phase, Appendix C Description Psychometric Assessments, Appendix D Psychometric Assessments, Appendix F Safety Assessments
Added “PC” as an abbreviation | List of Abbreviations
Added the statement, “Participants who turn 18 during the course of the study are permitted to continue participation”. | 4.1 Overall Study Design
Decreased the time period for washout of medications | Inclusion Criteria, Section 5.1.3 Medication Washout Procedures During the Screening Period Prior to Baseline Visit
Updated Table 5 with Updated Procedures:; Phrase added:; Phase 1 Weeks 5 and 7 and Phase 2 Weeks 3, 5, and 7 are phone calls to the family completed by the study physician. The weeks 3, 5, and 7 phone calls in Phase 2 are optional if the participant has achieved maximum dose or the two bottle titration has been completed.; Phase I; 1. Week 5 is a phone call.; 2. Week 7 is a phone call.; Phase II; 1. Week 3 phone call added.; a. Narrative summary added.; b. Medication adherence added.; c. Concomitant psychotropics assessment added.; d. Concomitant medication assessment added.; e. Concomitant psychotherapy assessment added.; 2. Week 5 phone call added.; a. Narrative summary added.; b. Medication adherence added.; c. Concomitant psychotropics assessment added.; d. Concomitant medication assessment added.; e. Concomitant psychotherapy assessment added.; 3. Week 7 phone call added.; a. Narrative summary added.; b. Medication adherence added.; c. Concomitant psychotropics assessment added.; d. Concomitant medication assessment added.; e. Concomitant psychotherapy assessment added. | Table 5 General Assessment Procedures
Phrases added:; If the urine toxicology screen is missed, it must be collected at the following in clinic visit. Lithium serum levels may be drawn within 48 hours of the visit.; Phase I Weeks 5 and 7 and Phase II Weeks 3, 5, and 7 are phone calls completed by the study physician. The weeks 3, 5 and 7 phone calls in Phase II are optional if the participant has achieved maximum dose [underlined: or] the two bottle titration has been completed.; Procedures Removed and/or added:; Global; 1. SEFCA-Plus removed; replaced by open inquiry of adverse events.; Phase I; 1. Week 2 → laboratory procedures:; a. Chemistry profile removed.; b. CBC with differential removed.; c. Urine toxicology screen removed.; d. Urinalysis removed.; e. TSH and thyroid panel added.; 2. Week 5 is a phone call.; a. Blood pressure assessment removed.; b. Pulse assessment removed.; c. Weight assessment removed.; d. Neurological Examination for Lithium (NELi) removed.; e. Neurological Rating Scale (NRS) removed.; f. Lithium serum level laboratory test removed.; 3. Week 7 is a phone call.; a. Blood pressure assessment removed.; b. Pulse assessment removed.; c. Weight assessment removed.; d. Neurological Examination for Lithium (NELi) removed.; e. Neurological Rating Scale (NRS) removed.; f. Lithium serum level laboratory test removed.; Phase II; 1. Week 2 → laboratory procedures [underlined: specific to those patients who received placebo in Phase I]:; a. Chemistry profile removed.; b. CBC with differential removed.; c. Urine toxicology screen removed.; d. Urinalysis removed.; e. TSH and thyroid panel added.; 2. Week 3 phone call added.; a. Adverse events assessment added.; 3. Week 5 phone call; a. Adverse events assessment added.; 4. Week 7 phone call; a. Adverse events assessment added.; 5. Week 10; a. Lithium serum level laboratory test ([underlined: for those patients who received placebo in Phase I]) removed.; 6. Week 12 → laboratory procedures specific to those patients who received placebo in Phase I; a. Chemistry profile removed.; b. CBC with differential removed.; c. Urine toxicology screen removed.; d. Urinalysis removed.; e. TSH and thyroid panel added. | Table 6 Safety Assessment Procedures
Updated Table 7 with Updated Procedures; Phrase added:; Phase I Weeks 5 and 7 and Phase II Weeks 3, 5, and 7 are phone calls completed by the study physician. The weeks 3, 5 and 7 phone calls in Phase II are optional if the participant has achieved maximum dose [underlined: or] the two bottle titration has been completed.; Scales Removed:; Global; 1. Nisonger Child Behavior Rating Form (NCBRF) removed.; 2. Irritability, Depression, Anxiety Scale (IDA) removed.; 3. Social Adjustment Inventory for Children and Adolescents (SAICA) removed.; 4. Caregiver Strain Questionnaire (CSQ) removed.; 5. Family Environment Scale (FES) removed.; 6. Drug Use Screening Inventory (DUSI) removed. | Table 7 Psychometric Assessment Procedures
Screening period changed from 28 days to 30 days | 5.1.2 Screening Procedures and 8.1.1 Efficacy Phase Screening Procedures (3 - 30 days)
Assessment of suicidality clarified | 5.1.2 Screening Procedures
Expanded age group in stratum to 18 years since participants that turn 18 during the study are eligible to continue | 5.2.3 Random Assignment of Participants to the Discontinuation Phase
Added phone calls as an instance where the lithium dose can be increased | 5.2.4 Procedure for Administration of Placebo and Active Medication During the Efficacy Phase
Modified Study Dosing Procedures; Added:; The participant will have their dose increased unless any one of the following criteria is or previously has been met:; Otherwise, unless the participant has been considered to have achieved their maximum dose, they will have their dose of lithium increased at each study visit or phone call.; If the dose was decreased due to an adverse event or for a safety reason, the investigator may increase the dose back up to the amount reached prior to the event.; No further dose increases beyond this are allowed. | 5.2.6 Study Dosing Procedures, 8.1.3 Weekly Visits 1 – 4, 6 and 8 (Weeks 5 and 7 phone calls) in the Efficacy Phase, 8.2.2 Long-Term Effectiveness Follow-up Visits in Participants Treated with [underlined: Placebo] in the Efficacy Phase, 8.4 Restabilization Phase Visit Procedures
Clarified the above halting criteria (b) must be at least of moderate severity | 5.2.4 Procedure for Administration of Placebo and Active Medication During the Efficacy Phase, 5.2.6 Study Dosing Procedures, 8.1.3 Weekly Visits 1 – 4, 6 and 8 (Weeks 5 and 7 phone calls) in the Efficacy Phase, 8.2.2 Long-Term Effectiveness Follow-up Visits in Participants Treated with [underlined: Placebo] in the Efficacy Phase, 8.4 Restabilization Phase Visit Procedures
Clarified that dosing remains stable in Phase 2 for participants on Lithium in Phase 1 | 5.2.6 Study Dosing Procedures
Deleted 3600 and 3900 mg from the Lithium Dosing Tables since it is not possible to reach these doses | Table 8 Lithium Dosing Regimen, Table 9 Cross Titration Schedule
Added parameters for the addition of a psychostimulant or melatonin during phase 1 and phase 2 | 5.2.9 Adjunctive Psychotropic Medication Treatments
Clarified that Appendix E algorithm for adjunctive medications is what is recommended | 5.2.9 Adjunctive Psychotropic Medication Treatments, 8.2.1 Study Visit Procedures
Updated the procedures for protocol waivers | 5.3 Protocol Deviations
Deleted propoxyphene in the urine toxicology screen; Added a statement about collecting a urine toxicology screen if a visit is missed; Deleted the statement describing the DUSI | 6.1 Safety Laboratory Tests
Added a statement that lithium levels can be obtained within 48 hours of the visit; Added a statement clarifying that investigators may use their discretion when decreasing lithium doses | 6.2 Lithium Serum Level Monitoring
Deleted: Side Effects Form for Children and Adolescents (SEFCA) and Safety Monitoring and Uniform Reform Form (SMURF) Clarified how adverse events will be elicited from participants and guardians | List of Abbreviations, 6.4.1 Assessment for Neurological Events, 6.5.2 Elicitation of Adverse Events from Participants and Guardians and Appendix F
Added lithium related adverse events that will be specifically addressed | SAFETY ASSESSMENTS
Changed the weeks 5 and 7 in-office visits in Phase 1 to Phone Calls and updated the procedures; Changed medication dispensation to accommodate phone call visits; Clarified dose increases during phone call visits: The physician may prescribe a dose increase of 300 mg based on the results of a telephone call to the participant’s parent/guardian. | 8.1.3: Weekly Visits 1 – 4, 6 and 8 (Weeks 5 and 7 phone calls) in the Efficacy Phase
Clarified procedure for participants moving from Phase 1 to Phase 2 | 8.1.4 End of Efficacy Phase Procedures
Clarified the neurocognitive testing procedures; Clarified WASI procedure:; The WASI Vocabulary and Matrix Reasoning sections are completed during the Screening period to ensure an IQ of 70 or above for inclusion into the study. | 8.1.5 Neurocognitive Testing, Table 0 Neurocognitive Assessment Procedures for Baseline, 8 Weeks, and End of Study
Added optional phone call visits to Phase 2; Clarified initial dosing with Lithium and maintaining the blind:; Participants weighing < 30 kg will begin lithium treatment at 600 mg/day; participants weighing ≥ 30 kg will begin lithium treatment at a dose of 900 mg/day. In order to maintain the blind, a two-bottle, double-blind substitution method will be used for up to 7 weeks.; Clarified dose increases in Phase 2 by phone call:; On day 3, and possibly Weeks, 3, 5 and 7, (+/− 2 days), a dose increase of 300 mg may occur based on the results of a telephone call placed by the study physician to the participant’s parent/guardian.; Doses of lithium may also be increased by 300 mg at each face-to-face study visit or phone call during the first eight weeks of the Long-Term Effectiveness Phase. | 8.2.2 Long-Term Effectiveness Follow-up Visits in Participants Treated with [underlined: Placebo] in the Efficacy Phase
Clarified medication administration and dosing procedures in Phase 2:; Youths will receive the same dosage of lithium used at the conclusion of the Efficacy Phase and dose will be maintained throughout Phase 2.; Participants will be administered medication in a two bottle titration form just as those participants who received placebo in Phase 1 to maintain the blind of the study. The total number of pills and daily dose will not change throughout this phase.; On day 3 and possibly weeks 3, 5 and 7 (± 2 days), to maintain the blind, the prescribing physician will phone the family and assess medication adherence, adverse events, and overall improvement since baseline. Adverse events that will specifically be probed for include: slurred speech, sedation, confusion, tremor, ataxia, dyspepsia, nausea, vomiting, diarrhea and rash. In addition, any and all reported adverse events will be documented at that time. The family will be advised to take another capsule from the bottle with the active lithium. The total daily dose will not change. Refer to the Manual of Procedures for the Study Drug Dispensing Guide. | 8.2.3 Long-Term Effectiveness Follow-up Visits in Participants that Received [underlined: Lithium] in the Efficacy Phase
Clarified medication administration and dosing procedures in Phase 3:; Dosing will be fixed based on the lithium dose at the end of Phase 2. How different doses of lithium will be administered throughout the course of the day is described in Table 8.; In addition, participants who received adjunctive medications for residual symptomatology in the Long-Term Effectiveness Phase may continue to receive adjunctive medications as described in Appendix E. Dosing for adjunctive medications will also be fixed based on the dose (s) at the end of Phase 2.; Adjunctive medication dosing and level monitoring (e.g., divalproex sodium) will be done by the blinded treating physician. No dose changes to adjunctive medications or new adjunctive medications may be prescribed in the Discontinuation Phase. Any potential changes in adjunctive medications must be reviewed by the Medical Monitor or the PODS PI unless the change is necessary for participant safety. | Discontinuation Phase Visit Procedures; 8.3.1 Study Visit Procedures
Clarified procedure for participant eligibility to move to Phase 4 with regard to investigator discretion | 8.3.2 Criteria for Significant Exacerbation of Symptoms During the Double-blind Discontinuation Phase
Added biweekly calls for clinical investigators | 9.2 Responsibilities of the Clinical (Principal) Investigator
Changed physical exam from baseline to “screening” | 10.7.6 Physical Examinations
Clarified informed consent and assent procedures | 11.3 Informed Consent and Assent
Updated references | 15.0 References
Comorbid ADHD entry criteria defined: Parent ADHD-RS score of ≥12 on H/I and/or Inattention Subscale | Appendix E: Adjunctive Medication Treatment

#### 9.9.1.6 Protocol Amendment 6

Protocol Amendment 6, dated March 8, 2012 was issued to clarify the intent of some sections of the original protocol and include an interim futility analysis. Changes to the protocol affected the overall study design and study conduct. Changes made in Protocol Amendment 6 are presented in the table below.

AMENDMENT CHANGE | | | | SECTION(S) AFFECTED BY AMENDMENT CHANGE
Text indicating Amendment 5, July 15, 2011 changed to Amendment 6, March 8, 2012 | | | | Title page, footers
EMMES Protocol Specialist changed from Denise King (ext. 2707) to Melinda Tibbals (ext. 2821) | | | | Study Contact Information
Page numbers updated | | | | Table of Contents
The following references were deleted:; - Gould AL (1995), Planning and revising the sample size for a trial. Statistics in Medicine 14:1039–1051 7569499; - Gould AL, Shih WJ (1992), Sample size re-estimation without unblinding for normally distributed outcomes with unknown variance. Communications in Statistics – Theory and Methodology 21:2833–2853; The following reference was added:; - O’Brien PC, Fleming TR (1979). A multiple testing procedure for clinical trials. Biometrics 35:549–556 497341 | | | | Section 15 References
[Inserted in rows below:] | | | | Section 10.6.1, Efficacy Phase, Interim Analysis
The Data Monitoring Committee requested interim analyses for futility and efficacy be added to the protocol. This section of the protocol was extensively edited to remove the interim sample size re-estimation analysis and replace with interim analyses for futility and efficacy.; Text Deleted:; The DMC will examine sample size re-estimation after approximately 75% of the participants have reached the end of the efficacy phase (Week 8). The purpose of this analysis is to conduct a sample size re-estimation without unblinding the data. The within-group variance will be re-estimated using study data to ensure that the study has adequate power to detect the difference of clinically importance. The estimate of within-group variance does not require knowledge of the treatment assignment. The estimate of the within-group variance will be done using the Gould and Shih (1992) and Gould (1995) procedure. This procedure is based on the concept of EM algorithm for estimating the variance without a value for the difference of clinically importance. The procedure is summarized as follows:; Suppose n observations on the primary endpoint have been obtained from n participants (based on LOCF values). The treatment assignments for these participants will remain blinded. We will randomly allocate the n observations to either of the two treatment groups (using the 2:1 allocation ratio) assuming that the treatment assignments are missing at random by defining the following π_i_ as the treatment indicator:; π_i_ = {1 if the treatment is the test drug 0 if the treatment is placebo; The E step will be used to obtain the provisional values of the expectation of π_i_ (i.e., the conditional probability that participant i is assigned to the test drug given y_i_), which is given by: P(π_i_ = 1 \| y_i_) = (1 + exp{(μ_1_ − μ_2_)(μ_1_ + μ_2_ − 2y_i_) / 2σ^2^})^−1^; where μ_1_ and μ_2_are the population mean of the test drug and the placebo, respectively. The M step involves the maximum likelihood estimates of μ_1_, μ_2_, and σ after updating π_i_ by their provisional values obtained from the E step in the log-likelihood function of the interim observations, which is given by:; 1 = n log σ + (∑ [π_i_ (y_i_ − μ_1_)^2^ + (1 − π_i_) (y_i_ − μ_2_)^2^])/(2 σ^2^); The E and M steps will be iterated until the values converge. Gould and Shih (1992) and Gould (1995) indicate that this procedure can estimate the within-group variance quite satisfactorily, but failed to provide a reliable estimate of μ_1_ − μ_2_, thus allowing the sample size to be adjusted if necessary without knowledge of treatment assignments (maintaining the blind).; A detailed interim analysis plan will be submitted to the FDA for review prior to conducting the interim analysis.; Text Inserted:; 9.9.1.7 Interim Analyses; Interim Analysis for Futility; An interim futility analysis based on conditional power (CP) will be used as a guideline for early termination of the trial. Conditional power is defined as the probability that the final study result will be statistically significant, given the data observed thus far and a specific assumption about the pattern of the data to be observed in the remainder of the study. The conditional power will be calculated based on the primary efficacy endpoint (change from baseline YMRS score). This analysis will be conducted after approximately 50 participants have reached the end of the efficacy phase. Conditional power will be based on a target sample size of 100 participants. The DMC requested this target sample size given the current rate of enrollment. The decision to stop the study and “accept” the null hypothesis (analysis of futility) will be based on a conditional power calculated under a parameter value falling below some pre-specified threshold. Under the proposed plan the DMC would recommend stopping the study early if the conditional power to detect the hypothesized treatment effect (a 5-point difference in YMRS change scores) is below the pre-specified threshold of 0.40.; The conditional power for some alternative effect using a critical value of Z_α/2_ for a Type I error rate of α=0.05 will be computed as:; C P [Z ( 1 ) ≥ Z_α / 2_ ∣ Z ( t ) , θ] = 1 − Φ (∣ Z_α / 2_ − Z ( t ) sqrt(t) − θ ( 1 − t ) ∣ / sqrt(( 1 − t ))); ; where t = n/N_o_ (N_o_ = 100 and n is total enrolled at the interim analysis, approximately 50).; The alternative θ is defined as:; θ = 1 / sqrt(2) ((μ_1_ − μ_2_)/(σ)) sqrt(N_o_); ; where μ_1_ and μ_2_ are the mean change from baseline in YMRS score for the placebo and lithium arms and σ is the common standard deviation.; The DMC specified a value of conditional power of 0.40 (pre-specified threshold) which would indicate that if the computed conditional power above fell below this value the chance of finding a significant result at the target sample size of 100 is less than 0.40.; Interim Analysis for Efficacy; The DMC will review results from an interim analysis for efficacy two times during the course of the study (after approximately 50 and 100 of the participants have reached the end of the efficacy phase (Week 8)). For the purpose of sequential monitoring, the primary efficacy endpoint is change from baseline YMRS score during the efficacy phase.; The following group sequential test plan for efficacy outcome describes how alpha (α) will be spent across the two interim looks and a final look at the data. This interim analysis will be performed based on the primary efficacy outcome and will be unadjusted by any covariates.; Interim analysis for futility will be conducted at the same time as the N=50 interim efficacy analysis. The interim looks and a final look will be based on the group sequential procedure. The symmetric O’Brien-Fleming (1979) boundary will be used as it is very conservative (requires a large treatment effect to signal stopping) during the early analyses. The alpha level or Type I error in a non-sequential design is assigned to one (final) analysis. In repeated interim analyses the cumulative Type I error increases with each interim evaluation. The goal of a group sequential design is to control the overall Type I error rate. Here, “overall” means accounting for interim analyses. The alpha spending function approach gives a rule for allocating some of the pre-specified Type I error to each interim analysis. This rule depends on the fraction of the total information of the trial accumulated by the time of interim analysis; For purposes of illustration, Table 12 gives the critical values for the test statistic computed at the two information time points with overall alpha level fixed at α = 0.05. In the application of this procedure, the true boundary to be computed at each time of analysis will be based on the actual number participants up to that time.; Table 12. Group Sequential Monitoring to evaluate efficacy under the O’Brien-Fleming Spending Function
Sample Size | Information Fraction (t) | O’Brien-Fleming Spending Function
Sample Size | Information Fraction (t) | Z-boundary | nominal α | Cumulative α
50 | 0.22 | ±4.637 | 0.000004 | 0.000004
100 | 0.44 | ± 3.184 | 0.0015 | 0.00146
225 | 1.00 | ±1.964 | 0.0495 | 0.05
The DMC will communicate all decisions regarding the analyses for futility and efficacy to the NICHD.

### 9.9.2 Changes in Planned Analyses

The following changes were made to the analyses after finalization of the statistical analysis plan.

1) The definition of Major Protocol Deviation was modified to include received incorrect randomized study medication. Review indicated that the major protocol deviation definition was too stringent and a second definition of major protocol deviations was also analyzed. This new definition revised the compliance criteria to missing >40% in two consecutive weeks and dose criteria to exceed 50 mg/kg/day (instead of 40 mg/kg/day). Other deviations remained the same.
2) In the analyses of YMRS response status and YMRS improvement status during the Long-Term Effectiveness Phase, Discontinuation Phase and Restabilization Phase, baseline values were re-defined to be the pre-treatment day 1 Efficacy Phase value (as defined in item 7 below).
3) Analyses by Efficacy Phase randomized treatment group were added to the Long-Term Effectiveness Phase. All tables are re-labeled with “A” for by age strata and “B” for by Efficacy Phase randomized treatment group.
4) Tertiary Endpoint of Child Mania Rating Scale – Parent Version was not collected during the Long-Term Effectiveness, Discontinuation and Restabilization Phases and will not be included in the results.
5) An additional sensitivity analysis of primary endpoint by treatment received was added to the Discontinuation Phase.
6) CGI-Severity and CGI-Improvement for the Long-Term Effectiveness Phase, Discontinuation Phase and Restabilization Phases was defined as follows:
  - CGI-Severity (Mania, Depression and Overall Illness):
    - Success: Baseline = 1 or 2 and less or same severity level at LOCF
      Baseline = 3 and less severe at LOCF
      Baseline = 4, 5, 6 and LOCF=1, 2, 3 and at least a 2 point decrease
    - Failure: Otherwise
  - CGI-Improvement (Mania, Depression and Overall Illness):
    - Success: Baseline CGI-S = 1 or 2 and LOCF CGI-I = 1,2,3,4
      Baseline CGI-S = 3 and LOCF CGI-I = 1,2,3
      Baseline CGI-S = 4, 5, 6 and LOCF CGI-I = 1,2
    - Failure: Otherwise
  P-value for the Discontinuation Phase will be calculated using Fisher’s Exact Test.
7) Response, remission and improvement status were added to the Discontinuation Phase. Definition of response for Long-Term Effectiveness Phase, Discontinuation Phase and Restabilization Phase was revised to use pre-treatment Efficacy Phase day 1 as the baseline summary YMRS value and the CGI-I (overall illness) at LOCF was modified to the CGI-S (overall illness) at LOCF. See below:
  - Response: YMRS reduction ≥ 50% from Efficacy Phase baseline and CGI-S (Overall illness) = 1 or 2 at LOCF
  - Partial response: YMRS reduction 25-49% % from Efficacy Phase baseline and CGI-S (Overall illness) ≤ 3 at LOCF OR
    YMRS reduction ≥ 50% and CGI-S (Overall illness) = 3 at LOCF
  - Non-response: YMRS reduction < 25% % from Efficacy Phase baseline or CGI-S (Overall illness) ≥ 4 at LOCF
8) Due to low accrual, exploratory analyses for all phases were not performed.
9) The adjusted and unadjusted effect size (cohen’s d) were added for the Efficacy Phase primary efficacy endpoint (Lipsey and Wilson, 2001).