# 6 INVESTIGATORS AND STUDY ADMINISTRATIVE STRUCTURE

## 6.1 Principal Investigators

The study was initiated at 11 sites in the United States. A list of investigators is provided in Appendix 16.1.4.

## 6.2 Administrative Structure

The following is a list of organizations that were critical to the conduct of the study:

IND SPONSOR | Eunice Kennedy Shriver National Institutes of Child Health and Human Development; National Institutes of Health; ▬; 31 Center Drive; Bethesda, MD 20892
Pediatric Off-Patent Drug Study (PODS) Center | Robert Findling, MD; PODS Center Investigator; Case Western Reserve University; 10524 Euclid Avenue; Cleveland, Ohio 44106
BPCA Data Coordinating Center (DCC); Project Management, Data Management, Statistical Analysis, Programming, and Medical Writing | The Emmes Corporation; 401 N. Washington Street, ▬; Rockville MD 20850