# 15 REFERENCE LIST

Amdisen A (1980), Serum concentration and clinical supervision in monitoring of lithium treatment. Ther Drug Monit, 2:73–83.6762704
Bauer MS, Callahan AM, Jampala C, Petty F, Sajatovic M, Schaefer V, Wittlin B, Powell BJ (1999). Clinical practice guidelines for bipolar disorder from the Department of Veterans Affairs. J Clin Psychiatry, 60: 9–21.
Biederman J, Faraone S, Mick E, Wozniak J, Chen L, Ouellette C, Marr A, Moore P, Garcia J, Mennin D, Lelon E (1996), Attention-deficit hyperactivity disorder and juvenile mania; an overlooked comorbidity? J Am Acad Child Adolesc Psychiatry 35:997–1008.8755796
Calil HM, Zwicker P, Klepacz S (1990), The effects of lithium carbonate on healthy volunteers: mood stabilization? Biol Psychiatry 27:711–722.2109639
Carandang CG, Maxwell DJ, Robbins DR, Oesterheld JR (2003), Lamotrigine in adolescent mood disorders. J Am Acad Child Adolesc Psychiatry 42:750–751.12819432
Carlson GA, Kelly KL (1998), Manic symptoms in psychiatrically hospitalized children-what do they mean? J Affect Disord 51:123–135.10743845
Castillo M., Kwock L, Courvoisie H, Hooper, SR (2000), Proton MR spectroscopy in children with bipolar affective disorder: Preliminary observations. AJNR 21:832–838.10815657
Chang K, Saxena K, Howe M (2006), An open-label study of lamotrigine adjunct or monotherapy for the treatment of adolescents with bipolar depression. J Am Acad Child Adolesc Psychiatry 45: 298–304.16540814
Chen YHJ, DeMets DL, Lan KKG (2004), Increasing the sample size when the unblinded interim result is promising. Stat Med 23:1023–1038.15057876
Coppen A, Abou-Saleh MT (1988), Lithium therapy from clinical trials to practical management. Acta Psychiatr Scand 78:754–762.3146892
Christodolou GN, Kokkevi A, Lykouras EP, Stefanis CN, Papadimitrious GN (1981), Effects of lithium on memory. Am J Psychiatry 138:847–848.7246822
Danielson CK, Feeny NC, Findling RL, Youngstrom EA (2004), Psychosocial treatment of bipolar disorders in adolescents: A proposed cognitive-behavioral intervention. Cognitive and Behavioral Practice 11:283–297.
DeLong GR, Aldershof AL (1987), Long-term experience with lithium treatment in childhood: correlation with clinical diagnosis. J Am Acad Child Adolesc Psychiatry 26:389–394.3597294
DeLong GR, Nieman GW (1983), Lithium-induced behavior changes in children with symptoms suggesting manic-depressive illness. Psychopharmacol Bull 19:258–265.6867235
DelBello MP, Soutullo CA, Hendricks W, Niemeier RT, McElroy SL, Strakowski SM (2001), Prior stimulant treatment in adolescents with bipolar disorder: association with age at onset. Bipolar Disord 3:53–57.11333062
Dickstein DP, Treland JE, Snow J, McClure EB, Mehta MS, Towbin KE, Pine DS, Leibenluft E (2004), Neuropsychological performance in pediatric bipolar disorder. Biol Psychiatry 55:32–39.14706422
Doyle AE, Wilens TE, Kwon A, Seidman L, Faraone SV, Fried R, Swezey A, Snyder L, Biederman J (2005), Neuropsychological functioning in youth with bipolar disorder. Biol Psychiatry 58:540–548.16199011
DuPaul GJ, Power TJ, Anastopoulos AD, Reid R (1998), ADHD Rating Scale - IV: Checklists, norms, and clinical interpretation. New York: The Guilford Press.
Faraone SV, Biederman J, Wozniak J, Mundy E, Mennin D, O’Donnell D (1997). Is comorbidity with ADHD a marker for juvenile-onset mania? J Am Acad Child Adolesc Psychiatry, 36:1046–1055.9256584
Findling, RL (2001), Paediatric psychopharmacology: closing the gap between science and practice. Expert Opin Pharmacother 2:523–525.11336602
Findling RL, Frazier JA, Kafantaris V, Kowatch, R, McClellan J, Pavuluri M, Sikich L, Hlastala S, Hooper SR, Demeter CA, Bedoya D, Brownstein B, Taylor-Zapata P (2008), The Collaborative Lithium Trials (CoLT): specific aims, methods, and implementation. Child Adolesc Psychiatry Ment Health 2(1):21.18700004
Findling RL, Gracious BL, McNamara NK, Youngstrom EA, Demeter CA, Branicky LA, Calabrese JR (2001), Rapid, continuous cycling and psychiatric comorbidity in pediatric bipolar I disorder. Bipolar Disord 3:202–210.11552959
Findling RL, Kafantaris V, Pavuluri M, McNamara NK, Frazier JA, Sikich L, Kowatch R, Rowles BM, Clemons TE, Taylor-Zapata P (2013), Post-acute effectiveness of lithium in pediatric bipolar I disorder. J Child Adolesc Psychopharmacol 23(2):80–90.23510444
Findling RL, Kafantaris V, Pavuluri M, McNamara NK, McClellan J, Frazier JA, Sikich L, Kowatch R, Lingler J, Faber J, Rowles BM, Clemons TE, Taylor-Zapata P (2011), Dosing strategies for lithium monotherapy in children and adolescents with bipolar disorder. J Child Adolesc Psychopharmacol 21(3):195–205.21663422
Findling RL, Landersdorfer CB, Kafantaris V, Pavuluri M, McNamara NK, McClellan J, Frazier JA, Sikich L, Kowatch R, Lingler J, Faber J, Taylor-Zapata P, Jusko WJ (2010), First-dose pharmacokinetics of lithium carbonate in children and adolescents. J Clin Psychopharmacol 30(4): 404–10.20531219
Findling RL, McNamara NK, Gracious BL, Youngstrom EA, Stansbrey RJ, Reed MD, Demeter CA, Branicky LA, Fisher KE, Calabrese JR (2003), Combination lithium and divalproex sodium in pediatric bipolarity. J Am Acad Child Adolesc Psychiatry 42:895–901.12874490
Findling RL, McNamara NK, Youngstrom EA, Stansbrey RJ, Gracious BL, Reed MD, Calabrese JR (2005), Double blind 18-month trial of lithium versus divalproex maintenance treatment in pediatric bipolar disorder. J Am Acad Child Adolesc Psychiatry 44:409–417.15843762
Findling RL, Reed MD, Myers C, O’Riordan MA, Fiala S, Branicky L, Waldorf B, Blumer JL (1999), Paroxetine pharmacokinetics in depressed children and adolescents. J Am Acad Child Adolesc Psychiatry 38:952–959.10434486
Freidlin E, Korn E, Gray R (2010) A general inefficacy interim monitoring rule for randomized clinical trials. Clinical Trials 7:197–208.20423925
Geddes JR, Burgess S, Hawton K, Jamison K, Goodwin GM (2004), Long-term lithium therapy for bipolar disorder: systematic review and meta-analysis of randomized controlled trials. Am J Psychiatry 161: 217–222.14754766
Geller B, Cooper TB, Sun K, Zimerman B, Frazier J, Williams M, Heath J (1998a), Double-blind and placebo-controlled study of lithium for adolescent bipolar disorders with secondary substance dependency. J Am Acad Child Adolesc Psychiatry, 37: 171–178.9473913
Geller B, Craney JL, Bolhofner K, Nickelsburg MJ, Williams M, Zimerman B (2002), Two-year prospective follow-up of children with a prepubertal and early adolescent bipolar disorder phenotype. Am J Psychiatry 159:927–933.12042179
Geller B, Luby J (1997), Child and adolescent bipolar disorder: a review of the past 10 years. J Am Acad Child Adolesc Psychiatry, 36:1168–1176.9291717
Geller B, Tillman R, Craney JL, Bolhofner K (2004), Four-year prospective outcome and natural history of mania in children with a prepubertal and early adolescent bipolar disorder phenotype. Arch Gen Psychiatry 61:459–467.15123490
Geller B, Zimerman B, Williams M, Bolhofner K, Craney JL, Delbello MP, Soutullo CA (2000), Diagnostic characteristics of 93 cases of prepubertal and early adolescent bipolar disorder phenotype by gender, puberty and comorbid attention deficit hyperactivity disorder. J Child Adolesc Psychopharmacol 10:157–164.11052405
Geller B, Warner K, Williams M, Zimerman B (1998b), Prepubertal and young adolescent bipolarity versus ADHD: assessment and validity using the WASH-U-KSADS, CBCL and TRF. J Affect Disord 51:93–100.10743842
Ghaemi SN, Hsu DJ, Soldani F, Goodwin FK (2003), Antidepressants in bipolar disorder: the case for caution. Bipolar Disord, 5: 421–433.14636365
Gitlin MJ (1993) Lithium-induced renal insufficiency. J Clin Psychopharmacol 13: 276–279 8376615
Gitlin MJ, Cochran SD, Jamison KR (1989), Maintenance lithium treatment: side effects and compliance. J Clin Psychiatry 50:127–131.2925600
Goodwin FK, Jamison KR (1990), Manic Depressive Illness. New York: Oxford University Press.
Gracious BL, Findling RL, Seman C, Youngstrom EA, Demeter CA, Calabrese JR (2004), Elevated thyrotropin in bipolar youths prescribed both lithium and divalproex sodium. J Am Acad Child Adolesc Psychiatry 43:215–220.14726729
Gram LF, Rafaelsen OJ (1972), Lithium treatment of psychotic children and adolescents: a controlled clinical trial. Acta Psychiatr Scand 48:253–260.4617490
Guyatt G, Walter S, Norman G (1987), Measuring Change Over Time: Assessing the Usefulness of Evaluative Instruments. J Chronic Dis 40:171–178.3818871
Hagino OR, Weller EB, Weller RA, Washing D, Fristad MA, Kontras SB (1995), Untoward effects of lithium treatment in children aged four through six years. J Am Acad Child Adolesc Psychiatry 34:1584–1590.8543529
Honig A, Arts BM, Ponds RW, Riedel WJ (1999), Lithium induced cognitive side-effects in bipolar disorder: a qualitative analysis and implications for daily practice. Int Clin Psychopharmacol 14:167–171.10435769
Hsu CH, Liu PY, Chen JH, Yeh TL, Tsai HY, Lin LJ (2005), Electrocardiographic abnormalities as predictors for over-range lithium levels. Cardiol 103: 101–106.
Hughes CW, Rintelmann J, Emslie GJ, Lopez M, MacCabe N (2001), A revised anchored version of the BPRS-C for childhood psychiatric disorders. J Child Adolesc Psychopharmacol 11: 77–93.11322749
Jensen, HV, Davidsen K, Toftegaard L, Mellerup ET, Plenge P, Aggernaes H, Bjørum N (1996), Double-blind comparison of the side-effect profiles of daily versus alternate-day dosing schedules in lithium maintenance treatment of manic-depressive disorder. J Affect Disord 36:89–93.8821311
Joffe R, MacDonald C, Kutcher S (1988), Lack of differential cognitive effects of lithium and carbamazepine in bipolar affective disorder. J Clin Psychopharmacol 8:425–428.3148638
Johnson GF (1987), Lithium in depression: a review of the antidepressant and prophylactic effects of lithium. Aust NZ J Psychiatry 21:356–365.
Judd LL, Akiskal HS, Schettler PJ, Endicott J, Maser J, Solomon DA, Leon AC, Rice JA, Keller MB (2002), The long-term natural history of the weekly symptomatic status of bipolar I disorder. Arch Gen Psychiatry 59:530–537.12044195
Kafantaris V, Coletti DJ, Dicker R, Padula G, Pleak RR, Alvir J, Kane JM (2004), Lithium treatment of acute mania in adolescents: A placebo-controlled discontinuation study. J Am Acad Child Adolesc Psychiatry 43:984–993.15266193
Kafantaris V, Coletti DJ, Dicker R, Padula G, Kane JM (2003), Lithium treatment of acute mania in adolescents: a large, open trial. J Am Acad Child Adolesc Psychiatry 42:1038–1045.12960703
Kafantaris V, Coletti DJ, Dicker R, Padula G, Kane JM (2001), Adjunctive antipsychotic treatment of adolescents with bipolar psychosis. J Am Acad Child Adolesc Psychopharmacol 40: 1448–1456.
Kafantaris V, Coletti DJ, Dicker R, Padula G, Pollack S (1998), Are childhood psychiatric histories of bipolar adolescents associated with family history, psychosis, and response to lithium treatment? J Affect Disord 51:153–164.10743848
Kaufman J, Birmaher B, Brent D, Rao U, Flynn C, Moreci P, Williamson D, Ryan N (1997), Schedule for Affective Disorders and Schizophrenia for School-Age Children-Present and Lifetime Version (K-SADS-PL): initial reliability and validity data. J Am Acad Child Adolesc Psychiatry 36: 980–988.9204677
Keck PE, Jr. (2004) Defining and improving response to treatment in subjects with bipolar disorder. J Clin Psychiatry 65S5:S25–S29.
Ketter TA, Wang PW, Nowakowska C, Marsh WK (2004), New medication treatment options for bipolar disorders. Acta Psychiatr Scand Suppl 422:18–33.
Klein RG, Abikoff H, Barkley RA, Campbell M, Leckman JF, Ryan ND, Solanto MV, Whalen CK (1994), Clinical trials in children and adolescents. In Clinical Evaluation of Psychotropic Drugs: Principles and Guidelines. Ed. Prien RF, Robinson DS. New York: Raven Press, Ltd. 501–546.
Kowatch RA, Findling RL, Scheffer RE, Stanford K (2007) Pediatric Bipolar Collaborative Mood Stabilizer Trial. Presented at: 54th Annual Meeting of the American Academy of Child and Adolescent Psychiatry: October 23-28, 2007; Boston, MA.
Kowatch RA, Fristad M, Birmaher B, Wagner KD, Findling RL, Hellander M and Work Group Members (2005), Treatment guidelines for children and adolescents with bipolar disorder: Child psychiatric workgroup on bipolar disorder. Special communication. J Am Acad Child Adolesc Psychiatry 44:213–235.15725966
Kowatch RA, Sethuraman G, Hume JH, Kromelis M, Weinberg WA (2003), Combination pharmacotherapy in children and adolescents with bipolar disorder. Biol Psychiatry 53:978–984.12788243
Kowatch RA, Suppes T, Carmody TJ, Bucci JP, Hume JH, Kromelis M, Emslie GJ, Weinberg WA, Rush AJ (2000), Effect size of lithium, divalproex sodium, and carbamazepine in children and adolescents with bipolar disorder. J Am Acad Child Adolesc Psychiatry 39:713–720.10846305
Kuczmarski RJ, Ogden CL, Guo SS, Grummer-Strawn LM, Flegal KM, Mei Z, Wei R, Curtin LR, Roche AF, Johnson CL (2002), 2000 CDC growth charts for the United States: Methods and development. Vital Health Stat 11 246:1–190.
Lazarus JH, McGregor AM, Ludgate M, Darke C, Creagh FM, Kingswood CJ (1986), Effect of lithium carbonate therapy on thyroid immune status in manic depressive patients: a prospective study. J Affect Disord 11:155–160.2948990
Lena B (1979), Lithium in child and adolescent psychiatry. Arch Gen Psychiatry 36:854–855 378162
Lenox RH, Manji HK (1995), Lithium. American Psychiatric Press Textbook of Psychopharmacology. CB Nemeroff, AF Schatzberg, eds. Washington, DC: American Psychiatric Press, 303–350.
Lenzer I, Eastwood D, Street P (1989), Reinterpreting memory complaints through neuropsychological assessment. Clin Gerontol 8:57–60.
Lewinsohn PM, Klein DN, Seeley JR (1995), Bipolar disorders in a community sample of older adolescents: Prevalence phenomenology, comorbidity, and course. J Am Acad Chil Adolesc Psychiatry 34:454–463.
Lingjærde O, Ahlfors U, Bech P, Dencker S, Elgen K (1987), The UKU side effect rating scale. A new comprehensive rating scale for psychotropic drugs and a cross-sectional study of side effects in neuroleptic-treated subjects. Acta Psychiatrica Scandinavica Suppl. 334:1–100.
Lipsey M, Wilson DB (2001), Practical Meta-Analysis. Thousand Oaks, CA: Sage Publications.
Lofthouse N, Fristad MA (2004), Psychosocial interventions for children with early-onset bipolar spectrum disorder. Clinical Child & Family Psychology Review 7:71–88.15255173
Loo H, Bonnel J, Etevenon P, Benyacoub J, Slowen P (1981), Intellectual efficiency in manic-depressive subjects treated with lithium: a control study. Acta Psychiatr Scandin 64:423–430.
Luciana M, Conklin HM, Hooper CJ, Yarger RS (2005), The development of nonverbal working memory and executive control processes in adolescents. Child Dev 76:697–712.15892787
Marshall WA, Tanner JM (1969) Variations in pattern of pubertal changes in girls. Arch Dis Child 44:291–303.5785179
McCarthy J, Arreses D, McGlashan A, Rappaport B, Kraseki K, Conway F, Mule C, Tucker J (2004), Sustained attention and visual processing speed in children and adolescents with bipolar disorder and other psychiatric disorders. Psychol Rep 95:39–47.15460356
McCreadie RG, McCormick M, Morrison DP (1985), The impact of lithium in southwest Scotland. III. The discontinuation study. Br J Psychiatry 146:77–80.3978347
McElroy SL, Keck PE, Jr. (2000), Pharmacologic agents for the treatment of acute bipolar mania. Biol Psychiatry, 48:539–557.11018226
McKnew, DH, Cytryn L, Buchsbaum MS, Hamovit J, Lamour M, Rapoport JL, Gershon ES (1981), Lithium in children of lithium-responding parents. Psychiatry Res 4:171–180.6939008
Meyer SE, Carlson GA, Wiggs EA, Martinez PE, Ronsaville DS, Klimes-Dougan B, Gold W, Radke-Yarrow M (2004), A prospective study of the association among impaired executive functioning, childhood attentional problems, and the development of bipolar disorder. Dev Psychopathol 16:461–476.15487606
Moran LA, Guyatt GH, Norman GR (2001), Establishing the minimal number of items for a responsive, valid, health-related quality of life instrument. J Clin Epidemiol 54:571–579.11377117
National Institute of Mental Health (1985), Clinical Global Impressions Scale. Psychopharmacol Bull 21:839–843.
O’Brien PC, Fleming TR (1979). A multiple testing procedure for clinical trials. Biometrics 35:549–556.497341
Olvera RL, Semrud-Clikeman M, Pliszka Sr, O’Donnell L (2005), Neuropsychological deficits in adolescents with conduct disorder and comorbid bipolar disorder: a pilot study. Bipolar Disord 7: 57–67.15654933
Ostrow DG, Pandey GN, Davis JM, Hurt SW, Tosteson DC (1978), A heritable disorder of lithium transport in erythrocytes of a subpopulation of manic-depressive patients. Am J Psychiatry 135:1070–1078.696928
Overholser JC, Brinkman DC, Lehnert KL, Ricciardi AM (1995), Children’s Depression Rating Scale--Revised: development of a short form. J Clin Child Psychol 24:443–452.
Pachet AK, Wisniewski AM (2003), The effects of lithium on cognition: an updated review. Psychopharmacol 170:225–234.
Pandey GN, Goel I, Davis JM (1979), Effect of neuroleptic drugs on lithium uptake by the human erythrocyte. Clin Pharmacol Ther 26:96–102.36253
Pandey, GN, Sarkadi B, Haas M, Gunn RB, Davis JM, Tosteson DC (1978), Lithium transport pathways in human red blood cells. J Gen Physiol 72:233–247.690597
Pavuluri MN, Birmaher B, Naylor MW (2005), Pediatric bipolar disorder: a review of the past 10 years. J Am Acad Child Adolesc Psychiatry 44:846–871.16113615
Pavuluri MN, Schenkel LS, Aryal S, Harral EM, Hill SK, Herbener ES, Sweeney JA (2006), Neurocognitive function in unmedicated manic and medicated euthymic pediatric bipolar patients. Am J Psychiatry 163:286–293.16449483
Posner K, Melvin GA, Stanley B, Oquendo MA, Gould M (2007), Factors in the assessment of suicidality in youth. CNS Spectr 12:156–162.17277716
Prien RF, Caffey EM Jr, Klett CJ (1972), Comparison of lithium carbonate and chlorpromazine in the treatment of mania: report of the Veterans Administration and National Institute of Mental Health Collaborative Study Group. Arch Gen Psychiatry 26:46–153.
Quiroz JA, Gould TD, Manji HK (2004), Molecular effects of lithium. Mol Interv 4:259–272.15471909
Rosenqvist M, Bergfeldt L, Aili H, Mathé AA (1993), Sinus node dysfunction during long-term lithium treatment. Br Heart J 70: 371–375.8217448
Sachs, GS, Grossman F, Ghaemi SN, Okamoto A, Bowden CL (2002), Combination of a mood stabilizer with risperidone or haloperidol for treatment of acute mania: a double-blind, placebo-controlled comparison of efficacy and safety. Am J Psychiatry 159:1146–1154.12091192
Scahill L, McCracken J, McDougle CJ, Aman M, Arnold LE, Tierney E, Cronin P, Davies M, Ghuman J, Gonzalez N, Koenig K, Lindsay R, Martin A, McGough J, Posey DJ, Swiezy N, Volkmar F, Ritz L, Vitiello B (2001), Methodological issues in designing a multisite trial of risperidone in children and adolescents with autism. J Child Adolesc Psychopharmacol. 11:377–388.11838820
Segal J, Berk M, Brook S (1998), Risperidone compared with both lithium and haloperidol in mania: a double-blind randomized controlled trial. Clin Neuropharmacol 21:176–180.9617509
Shaffer D, Gould MS, Brasic J, Ambrosini P, Fisher P, Bird H, Aluwahlia S (1983), A Children’s Global Assessment Scale (CGAS). Arch Gen Psychiatry 40:1228–1231.6639293
Sharma I, Singh P (1988), Cognitive functions in subjects of primary affective disorder on prophylactic lithium treatment. Indian J Med Res 88:246–252.3229788
Shaw E, Stokes PE, Mann J, Manevitz Z. (1987), Effects of lithium carbonate on memory and motor speed. J Abnorm Psychol 96:64–69.3104434
Simpson GM, Angus JWS (1970), A rating scale for extrapyramidal side effects. Acta Psychiatr Scand Suppl 212:1–19.
Spencer T, Biederman J, Wilens T (2000), Pharmacotherapy of attention deficit hyperactivity disorder. Child Adolesc Psychiatr Clin N Am 9:77–97.10674191
Squire LR, Judd LL, Janowsky DS, Huey LY (1980), Effects of lithium on memory and other cognitive func1tions. Am J Psychiatry 137:1042–1046.7425151
Storosum JG, Wohlfarth T, Schene A, Elferink A, van Zwieten BJ, van der Brink W (2007), Magnitude of effect of lithium in short-term efficacy studies of moderate to severe manic episode. Bipolar Disord 9:793–798.18076528
Strober M, DeAntonio M, Schmidt-Lackner S, Freeman R, Lampert C, Diamond J (1998), Early childhood attention deficit hyperactivity disorder predicts poorer response to acute lithium therapy in adolescent mania. J Affect Disord 51:145–151.10743847
Tanner JM, Whitehouse RH (1976), Clinical longitudinal standards for height, weight, height velocity, weight velocity, and stages of puberty. Arch Dis Child 51:170–179.952550
The Research Units on Pediatric Psychopharmacology Anxiety Study Group (2002), The Pediatric Anxiety Rating Scale (PARS): Development and psychometric properties. J Am Acad Child Adolesc Psychiatry 41:1061–1069.12218427
Tohen M, Chengappa KN, Suppes T, Zarate CA Jr, Calabrese JR, Bowden CL, Sachs GS, Kupfer DJ, Baker RW, Risser RC, Keeter EL, Feldman PD, Tollefson GD, Breier A (2002), Efficacy of olanzapine in combination with valproate or lithium in the treatment of mania in patients partially nonresponsive to valproate or lithium monotherapy. Arch Gen Psychiatry 59:62–69.11779284
Weller EB, Weller RA, Fristad MA (1986), Lithium dosage guide for prepubertal children: a preliminary report. J Am Acad Child Adolesc Psychiatry 25:92–95.
West SA, Strakowski SM, Sax KW, Minnery KL, McElroy SL, Keck PE, Jr. (1995), The comorbidity of attention-deficit hyperactivity disorder in adolescent mania: potential diagnostic and treatment implications. Psychopharmacol Bull 31:347–351.7491390
Wiznitzer M, Findling RL (2003) Why do psychiatric drug research in children? Lancet 361:1147–1148.12686034
Wozniak J, Biederman J, Kiely K, Ablon JS, Faraone SV, Mundy E (1995a), Mania-like symptoms suggestive of childhood-onset bipolar disorder in clinically referred children. J Am Acad Child Adolesc Psychiatry 34:867–876.7649957
Wozniak J, Biederman J, Mundy E, Mennin D, Faraone SV (1995b), A pilot family study of childhood-onset mania. J Am Acad Child Adolesc Psychiatry 34:1577–1583.8543528
Young RC, Biggs JT, Ziegler VE, Meyer DA (1978), A rating scale for mania: reliability, validity and sensitivity. British Journal of Psychiatry 133:429–435.
Youngstrom EA, Frazier TW, Demeter C, Calabrese JR, Findling RL. Developing a 10-item mania scale from the Parent General Behavior Inventory for children and adolescents. J Clin Psychiatry 2008, 69: 831–839.18452343
Zito JM, Safer DJ, dosReis S, Gardner JF, Boles M, Lynch F (2000), Trends in the prescribing of psychotropic medications to preschoolers. JAMA 283:1025–1030.10697062