# 14 TABLES, FIGURES, AND GRAPHS REFERRED TO BUT NOT INCLUDED IN THE TEXT

## 14.1 Demographic Data

Table Number | Population | Table Title / Description | Phase
14.1.1.1.1 | Safety Population | Participant Accountability and Study Disposition | Screening – All Participants
14.1.1.1.2 | Safety Population | Participant Accountability and Study Disposition | Efficacy Phase - All Participants
14.1.1.1.3 | Safety Population | Participant Accountability and Study Disposition | Long Term Effectiveness Phase - All Participants
14.1.1.1.4 | Safety Population | Participant Accountability and Study Disposition | Discontinuation Phase - All Participants
14.1.1.1.4A | Safety Population | Participant Accountability and Study Disposition | Discontinuation Phase - All COLT2 Participants
14.1.1.1.4B | Safety Population | Participant Accountability and Study Disposition | Discontinuation Phase - All COLT1 Participants
14.1.1.1.5 | Safety Population | Participant Accountability and Study Disposition | Restabilization Phase - All Participants
14.1.1.1.5A | Safety Population | Participant Accountability and Study Disposition | Restabilization Phase - All COLT2 Participants
14.1.1.1.5B | Safety Population | Participant Accountability and Study Disposition | Restabilization Phase - All COLT1 Participants
14.1.1.2.1 | Safety Population | Participant Enrollment by Site | All Participants
14.1.1.2.2 | Safety Population | Participant Enrollment by Site and Efficacy Phase Randomized Treatment Group | Efficacy Phase - All Participants
14.1.1.2.3 | Safety Population | Participant Enrollment by Site and Age Strata | Long-Term Effectiveness Phase - All Participants
14.1.1.2.4 | Safety Population | Participant Enrollment by SiteParticipant Enrollment by Site and Discontinuation Phase Randomized Treatment Group | Discontinuation Phase - All Participants
14.1.1.2.5 | Safety Population | Participant Enrollment by Site and Age Strata | Restabilization Phase - All Participants
14.1.2.1 | Safety Population | Protocol Deviations by Category and Site | Screening Phase - All Participants
14.1.2.2 | Safety Population | Protocol Deviations by Category and Site | Efficacy Phase - All Participants
14.1.2.3 | Safety Population | Protocol Deviations by Category and Site | Long Term Effectiveness Phase - All Participants
14.1.2.4 | Safety Population | Protocol Deviations by Category and Site | Discontinuation Phase - All COLT2 Participants
14.1.2.5 | Safety Population | Protocol Deviations by Category and Site | Restabilization Phase - All COLT2 Participants
14.1.3.1 | Efficacy Population | Baseline Demographics by Randomized Treatment Group | Efficacy Phase
14.1.3.2A | Efficacy Population | Baseline Demographics by Age Strata | Long-Term Effectiveness Phase
14.1.3.2B | Efficacy Population | Baseline Demographics by Efficacy Phase Randomized Treatment Group | Long-Term Effectiveness Phase
14.1.3.3 | Efficacy Population | Baseline Demographics by Randomized Treatment Group | Discontinuation Phase
14.1.3.4 | Efficacy Population | Baseline Demographics by Discontinuation Phase Randomized Treatment Group | Restabilization Phase
14.1.4 | Efficacy Population | Disease Summary by Age Strata and Randomized Treatment Group | Efficacy Phase
14.1.5.1 | Efficacy Population | Medical History by MedDRA System Organ Class, Preferred Term, Age Strata and Efficacy Phase Randomized Treatment Group | Efficacy Phase
14.1.5.2 | Efficacy Population | Surgical History by MedDRA System Organ Class, Preferred Term, Age Strata and Efficacy Phase Randomized Treatment Group | Efficacy Phase

## 14.2 Efficacy Data

Table Number | Population | Table Title / Summary | Phase
14.2.1.1.1 | Efficacy Population | Primary Efficacy Endpoint: Young Mania Rating Scale (YMRS) by Randomized Treatment Group | Efficacy Phase
14.2.1.1.2 | Per Protocol Population | Primary Efficacy Endpoint: Young Mania Rating Scale (YMRS) by Randomized Treatment Group | Efficacy Phase
14.2.1.1.3 | Revised Per Protocol Population | Primary Efficacy Endpoint: Young Mania Rating Scale (YMRS) by Randomized Treatment Group | Efficacy Phase
14.2.1.2.1 | Efficacy Population | Secondary Efficacy Endpoint: Response, Remission, Improvement and Discontinuation by Randomized Treatment Group | Efficacy Phase
14.2.1.2.2 | Efficacy Population | Secondary Efficacy Endpoint: Young Mania Rating Scale (YMRS) by Randomized Treatment Group | Efficacy Phase
14.2.1.2.3 | Efficacy Population | Secondary Efficacy Endpoint: Children Depression Rating Scale-Revised (CDRS-R) by Randomized Treatment Group | Efficacy Phase
14.2.1.2.4 | Efficacy Population | Secondary Efficacy Endpoint: Children’s Global Assessment Scale (CGAS) by Randomized Treatment Group | Efficacy Phase
14.2.1.2.5 | Efficacy Population | Secondary Efficacy Endpoint: Clinical Global Impression Scale (CGI) by Randomized Treatment Group | Efficacy Phase
14.2.1.2.6 | Efficacy Population | Secondary Efficacy Endpoint: Time to Any Discontinuation by Randomized Treatment Group | Efficacy Phase
14.2.1.2.7 | Efficacy Population | Secondary Efficacy Endpoint: Time to Discontinuation For Lack of Efficacy by Randomized Treatment Group | Efficacy Phase
14.2.1.3.1 | Efficacy Population | Tertiary Efficacy Endpoint: Parent General Behavior Inventory-10 Item Mania Scale (PGBI-10M) by Randomized Treatment Group | Efficacy Phase
14.2.1.3.2 | Efficacy Population | Tertiary Efficacy Endpoint: Child Mania Rating Scale-For Parents (CMRS-P) by Randomized Treatment Group | Efficacy Phase
14.2.1.3.3 | Efficacy Population | Tertiary Efficacy Endpoint: ADHD Rating Scale (ARS-IV) by Randomized Treatment Group | Efficacy Phase
14.2.1.3.4 | Efficacy Population | Tertiary Efficacy Endpoint: Brief Psychiatric Rating Scale-For Children (BPRS-C) by Randomized Treatment Group | Efficacy Phase
14.2.1.3.5 | Efficacy Population | Tertiary Efficacy Endpoint: Pediatric Anxiety Rating Scale (PARS) by Randomized Treatment Group | Efficacy Phase
14.2.1.4.1 | Efficacy Population | Descriptive Efficacy Endpoint: Family Environmental Scale (FES) by Randomized Treatment Group | Efficacy Phase
14.2.1.4.2 | Efficacy Population | Descriptive Efficacy Endpoint: Caregiver Strain Questionnaire (CSQ) by Randomized Treatment Group | Efficacy Phase
14.2.1.4.3 | Efficacy Population | Descriptive Efficacy Endpoint: Irritability, Depression and Anxiety (IDA) by Randomized Treatment Group | Efficacy Phase
14.2.1.4.4 | Efficacy Population | Descriptive Efficacy Endpoint: Nisonger Child Behavior Rating Form (NCBRF-TIQ) by Randomized Treatment Group | Efficacy Phase
14.2.1.4.5 | Efficacy Population | Descriptive Efficacy Endpoint: Social Adjustment Inventory for Children and Adolescents (SA/CA) by Randomized Treatment Group | Efficacy Phase
14.2.2.1A | Efficacy Population | Primary Efficacy Endpoint: Young Mania Rating Scale (YMRS) by Age Strata | Long-Term Effectiveness Phase
14.2.2.1B | Efficacy Population | Primary Efficacy Endpoint: Young Mania Rating Scale (YMRS) by Efficacy Phase Randomized Treatment Group | Long-Term Effectiveness Phase
14.2.2.2.1A | Efficacy Population | Secondary Efficacy Endpoint: Response, Remission, Improvement and Discontinuation by Age Strata | Long-Term Effectiveness Phase
14.2.2.2.1B | Efficacy Population | Secondary Efficacy Endpoint: Response, Remission, Improvement and Discontinuation by Efficacy Phase Randomized Treatment Group | Long-Term Effectiveness Phase
14.2.2.2.2A | Efficacy Population | Secondary Efficacy Endpoint: Young Mania Rating Scale (YMRS) by Age Strata | Long-Term Effectiveness Phase
14.2.2.2.2B | Efficacy Population | Secondary Efficacy Endpoint: Young Mania Rating Scale (YMRS) by Efficacy Phase Randomized Treatment Group | Long-Term Effectiveness Phase
14.2.2.2.3A | Efficacy Population | Secondary Efficacy Endpoint: Children Depression Rating Scale-Revised (CDRS-R) by Age Strata | Long-Term Effectiveness Phase
14.2.2.2.3B | Efficacy Population | Secondary Efficacy Endpoint: Children Depression Rating Scale-Revised (CDRS-R) by Efficacy Phase Randomized Treatment Group | Long-Term Effectiveness Phase
14.2.2.2.4A | Efficacy Population | Secondary Efficacy Endpoint: Children’s Global Assessment Scale (CGAS) by Age Strata | Long-Term Effectiveness Phase
14.2.2.2.4B | Efficacy Population | Secondary Efficacy Endpoint: Children’s Global Assessment Scale (CGAS) by Efficacy Phase Randomized Treatment Group | Long-Term Effectiveness Phase
14.2.2.2.5A | Efficacy Population | Secondary Efficacy Endpoint: Clinical Global Impression Scale (CGI) by Age Strata | Long-Term Effectiveness Phase
14.2.2.2.5B | Efficacy Population | Secondary Efficacy Endpoint: Clinical Global Impression Scale (CGI) by Efficacy Phase Randomized Treatment Group | Long-Term Effectiveness Phase
14.2.2.2.6A | Efficacy Population | Secondary Efficacy Endpoint: Time to Any Discontinuation by Age Strata | Long-Term Effectiveness Phase
14.2.2.2.6B | Efficacy Population | Secondary Efficacy Endpoint: Time to Any Discontinuation by Efficacy Phase Randomized Treatment Group | Long-Term Effectiveness Phase
14.2.2.2.7A | Efficacy Population | Secondary Efficacy Endpoint: Time to Discontinuation For Lack of Efficacy by Age Strata | Long-Term Effectiveness Phase
14.2.2.2.7B | Efficacy Population | Secondary Efficacy Endpoint: Time to Discontinuation For Lack of Efficacy by Efficacy Phase Randomized Treatment Group | Long-Term Effectiveness Phase
14.2.2.3.1A | Efficacy Population | Tertiary Efficacy Endpoint: Parent General Behavior Inventory-10 item Mania Scale (PGBI-10M) by Age Strata | Long-Term Effectiveness Phase
14.2.2.3.1B | Efficacy Population | Tertiary Efficacy Endpoint: Parent General Behavior Inventory-10 Item Mania Scale (PGBI-10M) by Efficacy Phase Randomized Treatment Group | Long-Term Effectiveness Phase
14.2.2.3.2A | Efficacy Population | Tertiary Efficacy Endpoint: ADHD Rating Scale (ARS-IV) by Age Strata | Long-Term Effectiveness Phase
14.2.2.3.2B | Efficacy Population | Tertiary Efficacy Endpoint: ADHD Rating Scale (ARS-IV) by Efficacy Phase Randomized Treatment Group | Long-Term Effectiveness Phase
14.2.2.3.3A | Efficacy Population | Tertiary Efficacy Endpoint: Brief Psychiatric Rating Scale-For Children (BPRS-C) by Age Strata | Long-Term Effectiveness Phase
14.2.2.3.3B | Efficacy Population | Tertiary Efficacy Endpoint: Brief Psychiatric Rating Scale-For Children (BPRS-C) by Efficacy Phase Randomized Treatment Group | Long-Term Effectiveness Phase
14.2.2.3.4A | Efficacy Population | Tertiary Efficacy Endpoint: Pediatric Anxiety Rating Scale (PARS) by Age Strata | Long-Term Effectiveness Phase
14.2.2.3.4B | Efficacy Population | Tertiary Efficacy Endpoint: Pediatric Anxiety Rating Scale (PARS) by Efficacy Phase Randomized Treatment Group | Long-Term Effectiveness Phase
14.2.2.4.1A | Efficacy Population | Descriptive Efficacy Endpoint: Family Environmental Scale (FES) by Age Strata | Long-Term Effectiveness Phase
14.2.2.4.1B | Efficacy Population | Descriptive Efficacy Endpoint: Family Environmental Scale (FES) by Efficacy Phase Randomized Treatment Group | Long-Term Effectiveness Phase
14.2.2.4.2A | Efficacy Population | Descriptive Efficacy Endpoint: Caregiver Strain Questionnaire (CSQ) by Age Strata | Long-Term Effectiveness Phase
14.2.2.4.2B | Efficacy Population | Descriptive Efficacy Endpoint: Caregiver Strain Questionnaire (CSQ) by Efficacy Phase Randomized Treatment Group | Long-Term Effectiveness Phase
14.2.2.4.3A | Efficacy Population | Descriptive Efficacy Endpoint: Irritability, Depression and Anxiety (IDA) by Age Strata | Long-Term Effectiveness Phase
14.2.2.4.3B | Efficacy Population | Descriptive Efficacy Endpoint: Irritability, Depression and Anxiety (IDA) by Efficacy Phase Randomized Treatment Group | Long-Term Effectiveness Phase
14.2.2.4.4A | Efficacy Population | Descriptive Efficacy Endpoint: Nisonger Child Behavior Rating Form (NCBRF-TIQ) by Age Strata | Long-Term Effectiveness Phase
14.2.2.4.4B | Efficacy Population | Descriptive Efficacy Endpoint: Nisonger Child Behavior Rating Form (NCBRF-TIQ) by Efficacy Phase Randomized Treatment Group | Long-Term Effectiveness Phase
14.2.2.4.5A | Efficacy Population | Descriptive Efficacy Endpoint: Social Adjustment Inventory for Children and Adolescents (SA/CA) by Age Strata | Long-Term Effectiveness Phase
14.2.2.4.5B | Efficacy Population | Descriptive Efficacy Endpoint: Social Adjustment Inventory for Children and Adolescents (SA/CA) by Efficacy Phase Randomized Treatment Group | Long-Term Effectiveness Phase
14.2.3.1.1 | Efficacy Population | Primary Efficacy Endpoint: Time to Any Discontinuation by Randomized Treatment Group | Discontinuation Phase
14.2.3.1.2 | Per Protocol Population | Primary Efficacy Endpoint: Time to Any Discontinuation by Randomized Treatment Group | Discontinuation Phase
14.2.3.1.3 | Revised Per Protocol Population | Primary Efficacy Endpoint: Time to Any Discontinuation by Randomized Treatment Group | Discontinuation Phase
14.2.3.1.4 | Efficacy Population | Primary Efficacy Endpoint: Time to Any Discontinuation by Treatment Received | Discontinuation Phase
14.2.3.2.1 | Efficacy Population | Secondary Efficacy Endpoint: Time to Discontinuation For Lack of Efficacy by Efficacy Phase Randomized Treatment Group | Discontinuation Phase
14.2.3.2.2 | Efficacy Population | Secondary Efficacy Endpoint: Response, Remission, Improvement and Discontinuation by Randomized Treatment Group | Discontinuation Phase
14.2.3.2.3 | Efficacy Population | Secondary Efficacy Endpoint: Recurrence of Mood Episodes by Randomized Treatment Group | Discontinuation Phase
14.2.3.2.4 | Efficacy Population | Secondary Efficacy Endpoint: Time to Recurrence of Mood Episodes by Randomized Treatment Group | Discontinuation Phase
14.2.3.2.5 | Efficacy Population | Secondary Efficacy Endpoint: Young Mania Rating Scale (YMRS) by Randomized Treatment Group | Discontinuation Phase
14.2.3.2.6 | Efficacy Population | Secondary Efficacy Endpoint: Children Depression Rating Scale-Revised (CDRS-R) by Randomized Treatment Group | Discontinuation Phase
14.2.3.2.7 | Efficacy Population | Secondary Efficacy Endpoint: Children’s Global Assessment Scale (CGAS) by Randomized Treatment Group | Discontinuation Phase
14.2.3.2.8 | Efficacy Population | Secondary Efficacy Endpoint: Clinical Global Impression Scale (CGI) by Randomized Treatment Group | Discontinuation Phase
14.2.3.3.1 | Efficacy Population | Tertiary Efficacy Endpoint: Parent General Behavior Inventory-10 Item Mania Scale (PGBI-10M) by Randomized Treatment Group | Discontinuation Phase
14.2.3.3.2 | Efficacy Population | Tertiary Efficacy Endpoint: ADHD Rating Scale (ARS-IV) by Randomized Treatment Group | Discontinuation Phase
14.2.3.3.3 | Efficacy Population | Tertiary Efficacy Endpoint: Brief Psychiatric Rating Scale-For Children (BPRS-C) by Randomized Treatment Group | Discontinuation Phase
14.2.3.3.4 | Efficacy Population | Tertiary Efficacy Endpoint: Pediatric Anxiety Rating Scale (PARS) by Randomized Treatment Group | Discontinuation Phase
14.2.4.1 | Efficacy Population | Primary Efficacy Endpoint: Young Mania Rating Scale (YMRS) by Discontinuation Phase Randomized Treatment Group | Restabilization Phase
14.2.4.2.1 | Efficacy Population | Secondary Efficacy Endpoint: Response, Remission, Improvement and Discontinuation by Discontinuation Phase Randomized Treatment Group | Restabilization Phase
14.2.4.2.2 | Efficacy Population | Secondary Efficacy Endpoint: Young Mania Rating Scale (YMRS) by Discontinuation Phase Randomized Treatment Group | Restabilization Phase
14.2.4.2.3 | Efficacy Population | Secondary Efficacy Endpoint: Children Depression Rating Scale-Revised (CDRS-R) by Discontinuation Phase Randomized Treatment Group | Restabilization Phase
14.2.4.2.4 | Efficacy Population | Secondary Efficacy Endpoint: Children’s Global Assessment Scale (CGAS) by Discontinuation Phase Randomized Treatment Group | Restabilization Phase
14.2.4.2.5 | Efficacy Population | Secondary Efficacy Endpoint: Clinical Global Impression Scale (CGI) by Discontinuation Phase Randomized Treatment Group | Restabilization Phase
14.2.4.3.1 | Efficacy Population | Tertiary Efficacy Endpoint: Parent General Behavior Inventory-10 Item Mania Scale (PGBI-10M) by Discontinuation Phase Randomized Treatment Group | Restabilization Phase
14.2.4.3.2 | Efficacy Population | Tertiary Efficacy Endpoint: ADHD Rating Scale (ARS-IV) by Discontinuation Phase Randomized Treatment Group | Restabilization Phase
14.2.4.3.3 | Efficacy Population | Tertiary Efficacy Endpoint: Brief Psychiatric Rating Scale-For Children (BPRS-C) by Discontinuation Phase Randomized Treatment Group | Restabilization Phase
14.2.4.3.4 | Efficacy Population | Tertiary Efficacy Endpoint: Pediatric Anxiety Rating Scale (PARS) by Discontinuation Phase Randomized Treatment Group | Restabilization Phase

## 14.3 Safety Data

Table Number | Population | Table Title / Summary | Phase
14.3.1.1.1 | Safety | Summary of Adverse Events by Age Strata and Efficacy Phase Treatment Received Group | Efficacy Phase
14.3.1.1.2A | Safety | Summary of Adverse Events by Age Strata | Long-Term Effectiveness Phase
14.3.1.1.2B | Safety | Summary of Adverse Events by Efficacy Phase Treatment Received | Long-Term Effectiveness Phase
14.3.1.1.3 | Safety | Summary of Adverse Events by Discontinuation Phase Treatment Received Group | Discontinuation Phase
14.3.1.1.4 | Safety | Summary of Adverse Events by Discontinuation Phase Treatment Received Group | Restabilization Phase
14.3.1.2.1 | Safety | Adverse Events by MedDRA System Organ Class, Preferred Term, Age Strata and Efficacy Phase Treatment Received Group | Efficacy Phase
14.3.1.2.2A | Safety | Adverse Events by MedDRA System Organ Class, Preferred Term and Age Strata | Long-Term Effectiveness Phase
14.3.1.2.2B | Safety | Adverse Events by MedDRA System Organ Class, Preferred Term and Efficacy Phase Treatment Received Group | Long-Term Effectiveness Phase
14.3.1.2.3 | Safety | Adverse Events by MedDRA System Organ Class, Preferred Term and Discontinuation Phase Treatment Received Group | Discontinuation Phase
14.3.1.2.4 | Safety | Adverse Events by MedDRA System Organ Class, Preferred Term and Discontinuation Phase Treatment Received Group | Restabilization Phase
14.3.1.3.1 | Safety | Adverse Events by MedDRA System Organ Class, Preferred Term, Intensity, Age Strata and Efficacy Phase Treatment Received Group | Efficacy Phase
14.3.1.3.2A | Safety | Adverse Events by MedDRA System Organ Class, Preferred Term, Intensity and Age Strata | Long-Term Effectiveness Phase
14.3.1.3.2B | Safety | Adverse Events by MedDRA System Organ Class, Preferred Term, Intensity and Efficacy Phase Treatment Received Group | Long-Term Effectiveness Phase
14.3.1.3.3 | Safety | Adverse Events by MedDRA System Organ Class, Preferred Term, Intensity and Discontinuation Phase Treatment Received Group | Discontinuation Phase
14.3.1.3.4 | Safety | Adverse Events by MedDRA System Organ Class, Preferred Term, Intensity and Discontinuation Phase Treatment Received Group | Restabilization Phase
14.3.1.4.1 | Safety | Adverse Events by MedDRA System Organ Class, Preferred Term, Relationship to Study Medication, Age Strata and Efficacy Phase Treatment Received Group | Efficacy Phase
14.3.1.4.2A | Safety | Adverse Events by MedDRA System Organ Class, Preferred Term, Relationship to Study Medication and Age Strata | Long-Term Effectiveness Phase
14.3.1.4.2B | Safety | Adverse Events by MedDRA System Organ Class, Preferred Term, Relationship to Study Medication and Efficacy Phase Treatment Received Group | Long-Term Effectiveness Phase
14.3.1.4.3 | Safety | Adverse Events by MedDRA System Organ Class, Preferred Term, Relationship to Study Medication and Discontinuation Phase Treatment Received Group | Discontinuation Phase
14.3.1.4.4 | Safety | Adverse Events by MedDRA System Organ Class, Preferred Term, Relationship to Study Medication and Discontinuation Phase Treatment Received Group | Restabilization Phase
14.3.1.5.1 | Safety | Serious Adverse Events by MedDRA System Organ Class, Preferred Term, Age Strata and Efficacy Phase Treatment Received Group | Efficacy Phase
14.3.1.5.2A | Safety | Serious Adverse Events by MedDRA System Organ Class, Preferred Term and Age Strata | Long-Term Effectiveness Phase
14.3.1.5.2B | Safety | Serious Adverse Events by MedDRA System Organ Class, Preferred Term and Efficacy Phase Treatment Received Group | Long-Term Effectiveness Phase
14.3.1.5.3 | Safety | Serious Adverse Events by MedDRA System Organ Class, Preferred Term and Discontinuation Phase Treatment Received Group | Discontinuation Phase
14.3.1.5.4 | Safety | Serious Adverse Events by MedDRA System Organ Class, Preferred Term and Discontinuation Phase Treatment Received Group | Restabilization Phase
14.3.1.6.1 | Safety | Adverse Events that Led to Discontinuation of Study Drug by Age Strata | Efficacy Phase
14.3.1.6.2A | Safety | Adverse Events that Led to Discontinuation of Study Drug by Efficacy Phase Treatment Received Group | Long-Term Effectiveness Phase
14.3.1.6.2B | Safety | Adverse Events that Led to Discontinuation of Study Drug by Efficacy Phase Treatment Received Group | Long-Term Effectiveness Phase
14.3.1.6.3 | Safety | Adverse Events that Led to Discontinuation of Study Drug by Discontinuation Phase Treatment Received Group | Discontinuation Phase
14.3.1.6.4 | Safety | Adverse Events that Led to Discontinuation of Study Drug by Discontinuation Phase Treatment Received Group | Restabilization Phase
14.3.1.7.1 | Safety | Deaths by MedDRA System Organ Class, Preferred Term, Age Strata and Treatment Received Group | Efficacy Phase
14.3.1.7.2A | Safety | Deaths by MedDRA System Organ Class, Preferred Term and Age Strata | Long-Term Effectiveness Phase
14.3.1.7.2B | Safety | Deaths by MedDRA System Organ Class, Preferred Term and Efficacy Phase Treatment Received Group | Long-Term Effectiveness Phase
14.3.1.7.3 | Safety | Deaths by MedDRA System Organ Class, Preferred Term and Discontinuation Phase Treatment Received Group | Discontinuation Phase
14.3.1.7.4 | Safety | Deaths by MedDRA System Organ Class, Preferred Term and Discontinuation Phase Treatment Received Group | Restabilization Phase
14.3.2.1.1 | Safety | Concomitant Medications Used During the Efficacy Phase by Age Strata and Efficacy Phase Treatment Received Group | Efficacy Phase
14.3.2.1.2A | Safety | Concomitant Medications Used During the Long-Term Effectiveness Phase by Age Strata | Long-Term Effectiveness Phase
14.3.2.1.2B | Safety | Concomitant Medications Used During the Long-Term Effectiveness Phase by Efficacy Phase Treatment Received Group | Long-Term Effectiveness Phase
14.3.2.1.3 | Safety | Concomitant Medications Used During the Discontinuation Phase by Discontinuation Phase Treatment Received Group | Discontinuation Phase
14.3.2.1.4 | Safety | Concomitant Medications Used During the Restabilization Phase by Discontinuation Phase Treatment Received Group | Restabilization Phase
14.3.2.2.1 | Safety | Concomitant Psychotropic Medications Used During the Efficacy Phase by Age Strata and Efficacy Phase Treatment Received Group | Efficacy Phase
14.3.2.2.2A | Safety | Concomitant Psychotropic Medications Used During the Long-Term Effectiveness Phase by Age Strata | Long-Term Effectiveness Phase
14.3.2.2.2B | Safety | Concomitant Psychotropic Medications Used During the Long-Term Effectiveness Phase by Efficacy Phase Treatment Received Group | Long-Term Effectiveness Phase
14.3.2.2.3 | Safety | Concomitant Psychotropic Medications Used During the Discontinuation Phase by Discontinuation Phase Treatment Received Group | Discontinuation Phase
14.3.2.2.4 | Safety | Concomitant Psychotropic Medications Used During the Restabilization Phase by Discontinuation Phase Treatment Received Group | Restabilization Phase
14.3.2.3.1 | Safety | Concomitant Psychotherapy Used During the Efficacy Phase by Age Strata and Efficacy Phase Treatment Received Group | Efficacy Phase
14.3.2.3.2A | Safety | Concomitant Psychotherapy Used During the Long-Term Effectiveness Phase by Age Strata | Long-Term Effectiveness Phase
14.3.2.3.2B | Safety | Concomitant Psychotherapy Used During the Long-Term Effectiveness Phase by Efficacy Phase Treatment Received Group | Long-Term Effectiveness Phase
14.3.2.3.3 | Safety | Concomitant Psychotherapy During the Discontinuation Phase by Discontinuation Phase Treatment Received Group | Discontinuation Phase
14.3.2.3.4 | Safety | Concomitant Psychotherapy During the Restabilization Phase by Discontinuation Phase Treatment Received Group | Restabilization Phase
14.3.3.1.1.1 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - White Blood Count (×10^3^/μL) | Efficacy Phase
14.3.3.1.1.2 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Red Blood Count (×10^6^/μL) | Efficacy Phase
14.3.3.1.1.3 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Hemoglobin (g/dL) | Efficacy Phase
14.3.3.1.1.4 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Hematocrit (%) | Efficacy Phase
14.3.3.1.1.5 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Mean Corpuscular Volume - MCV (fL) | Efficacy Phase
14.3.3.1.1.6 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Mean Corpuscular Hemoglobin - MCH (pg) | Efficacy Phase
14.3.3.1.1.7 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Mean Corpuscular Hemoglobin Concentration - MCHC (g/dL) | Efficacy Phase
14.3.3.1.1.8 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Platelets Count (×10^3^/μL) | Efficacy Phase
14.3.3.1.1.9 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Red Blood Cell Distribution Width - RDW (%) | Efficacy Phase
14.3.3.1.1.10 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Mean Platelet Volume (fL) | Efficacy Phase
14.3.3.1.1.11 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Neutrophils (%) | Efficacy Phase
14.3.3.1.1.12 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Lymphocytes (%) | Efficacy Phase
14.3.3.1.1.13 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Monocytes (%) | Efficacy Phase
14.3.3.1.1.14 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Eosinophils (%) | Efficacy Phase
14.3.3.1.1.15 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Basophils (%) | Efficacy Phase
14.3.3.1.2.1A | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata - White Blood Count (×10^3^/μL) | Long-Term Effectiveness Phase
14.3.3.1.2.2A | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata - Red Blood Count (×10^6^/μL) | Long-Term Effectiveness Phase
14.3.3.1.2.3A | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata - Hemoglobin (g/dL) | Long-Term Effectiveness Phase
14.3.3.1.2.4A | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata - Hematocrit (%) | Long-Term Effectiveness Phase
14.3.3.1.2.5A | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata - Mean Corpuscular Volume - MCV (fL) | Long-Term Effectiveness Phase
14.3.3.1.2.6A | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata - Mean Corpuscular Hemoglobin - MCH (pg) | Long-Term Effectiveness Phase
14.3.3.1.2.7A | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata - Mean Corpuscular Hemoglobin Concentration - MCHC (g/dL) | Long-Term Effectiveness Phase
14.3.3.1.2.8A | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata - Platelets Count (×10^3^/μL) | Long-Term Effectiveness Phase
14.3.3.1.2.9A | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata - Red Blood Cell Distribution Width - RDW (%) | Long-Term Effectiveness Phase
14.3.3.1.2.10A | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata - Mean Platelet Volume (fL) | Long-Term Effectiveness Phase
14.3.3.1.2.11A | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata - Neutrophils (%) | Long-Term Effectiveness Phase
14.3.3.1.2.12A | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata - Lymphocytes (%) | Long-Term Effectiveness Phase
14.3.3.1.2.13A | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata - Monocytes (%) | Long-Term Effectiveness Phase
14.3.3.1.2.14A | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata - Eosinophils (%) | Long-Term Effectiveness Phase
14.3.3.1.2.15A | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata - Basophils (%) | Long-Term Effectiveness Phase
14.3.3.1.2.1B | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received - White Blood Count (×10^3^/μL) | Long-Term Effectiveness Phase
14.3.3.1.2.2B | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received - Red Blood Count (×10^6^/μL) | Long-Term Effectiveness Phase
14.3.3.1.2.3B | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received - Hemoglobin (g/dL) | Long-Term Effectiveness Phase
14.3.3.1.2.4B | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received - Hematocrit (%) | Long-Term Effectiveness Phase
14.3.3.1.2.5B | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received - Mean Corpuscular Volume - MCV (fL) | Long-Term Effectiveness Phase
14.3.3.1.2.6B | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received - Mean Corpuscular Hemoglobin - MCH (pg) | Long-Term Effectiveness Phase
14.3.3.1.2.7B | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received - Mean Corpuscular Hemoglobin Concentration - MCHC (g/dL) | Long-Term Effectiveness Phase
14.3.3.1.2.8B | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received - Platelets Count (×10^3^/μL) | Long-Term Effectiveness Phase
14.3.3.1.2.9B | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received - Red Blood Cell Distribution Width - RDW (%) | Long-Term Effectiveness Phase
14.3.3.1.2.10B | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received - Mean Platelet Volume (fL) | Long-Term Effectiveness Phase
14.3.3.1.2.11B | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received - Neutrophils (%) | Long-Term Effectiveness Phase
14.3.3.1.2.12B | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received - Lymphocytes (%) | Long-Term Effectiveness Phase
14.3.3.1.2.13B | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received - Monocytes (%) | Long-Term Effectiveness Phase
14.3.3.1.2.14B | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received - Eosinophils (%) | Long-Term Effectiveness Phase
14.3.3.1.2.15B | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received - Basophils (%) | Long-Term Effectiveness Phase
14.3.3.1.3.1 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - White Blood Count (×10^3^/L) | Discontinuation Phase
14.3.3.1.3.2 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - Red Blood Count (×10^6^/L) | Discontinuation Phase
14.3.3.1.3.3 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - Hemoglobin (g/dL) | Discontinuation Phase
14.3.3.1.3.4 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - Hematocrit (%) | Discontinuation Phase
14.3.3.1.3.5 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - Mean Corpuscular Volume - MCV (fL) | Discontinuation Phase
14.3.3.1.3.6 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - Mean Corpuscular Hemoglobin - MCH (pg) | Discontinuation Phase
14.3.3.1.3.7 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - Mean Corpuscular Hemoglobin Concentration - MCHC (g/dL) | Discontinuation Phase
14.3.3.1.3.8 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - Platelets Count (×10^3^/L) | Discontinuation Phase
14.3.3.1.3.9 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - Red Blood Cell Distribution Width - RDW (%) | Discontinuation Phase
14.3.3.1.3.10 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - Mean Platelet Volume (fL) | Discontinuation Phase
14.3.3.1.3.11 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - Neutrophils (%) | Discontinuation Phase
14.3.3.1.3.12 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - Lymphocytes (%) | Discontinuation Phase
14.3.3.1.3.13 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - Monocytes (%) | Discontinuation Phase
14.3.3.1.3.14 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - Eosinophils (%) | Discontinuation Phase
14.3.3.1.3.15 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - Basophils (%) | Discontinuation Phase
14.3.3.1.4.1 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - White Blood Count (×10^3^/L) | Restabilization Phase
14.3.3.1.4.2 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - Red Blood Count (×10^6^/L) | Restabilization Phase
14.3.3.1.4.3 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - Hemoglobin (g/dL) | Restabilization Phase
14.3.3.1.4.4 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - Hematocrit (%) | Restabilization Phase
14.3.3.1.4.5 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - Mean Corpuscular Volume - MCV (fL) | Restabilization Phase
14.3.3.1.4.6 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - Mean Corpuscular Hemoglobin - MCH (pg) | Restabilization Phase
14.3.3.1.4.7 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - Mean Corpuscular Hemoglobin Concentration - MCHC (g/dL) | Restabilization Phase
14.3.3.1.4.8 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - Platelets Count (×10^3^/L) | Restabilization Phase
14.3.3.1.4.9 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - Red Blood Cell Distribution Width - RDW (%) | Restabilization Phase
14.3.3.1.4.10 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - Mean Platelet Volume (fL) | Restabilization Phase
14.3.3.1.4.11 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - Neutrophils (%) | Restabilization Phase
14.3.3.1.4.12 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - Lymphocytes (%) | Restabilization Phase
14.3.3.1.4.13 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - Monocytes (%) | Restabilization Phase
14.3.3.1.4.14 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - Eosinophils (%) | Restabilization Phase
14.3.3.1.4.15 | Safety | Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received - Basophils (%) | Restabilization Phase
14.3.3.2.1.1 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Albumin (g/dL) | Efficacy Phase
14.3.3.2.1.2 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Alkaline Phosphatase (U/L) | Efficacy Phase
14.3.3.2.1.3 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Alanine Aminotransferase - ALT (U/L) | Efficacy Phase
14.3.3.2.1.4 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Aspartate Aminotransferase - AST (U/L) | Efficacy Phase
14.3.3.2.1.5 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Bicarbonate (mEq/L) | Efficacy Phase
14.3.3.2.1.6 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Direct Bilirubin (mg/dL) | Efficacy Phase
14.3.3.2.1.7 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Total Bilirubin (mg/dL) | Efficacy Phase
14.3.3.2.1.8 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Calcium (mg/dL) | Efficacy Phase
14.3.3.2.1.9 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Chloride (mEq/L) | Efficacy Phase
14.3.3.2.1.10 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Cholesterol (mg/dL) | Efficacy Phase
14.3.3.2.1.11 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Creatine kinase (U/L) | Efficacy Phase
14.3.3.2.1.12 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Creatinine (mg/dL) | Efficacy Phase
14.3.3.2.1.13 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Gamma-glutamyl Transpeptidase - GGT (U/L) | Efficacy Phase
14.3.3.2.1.14 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Glucose (mg/dL) | Efficacy Phase
14.3.3.2.1.15 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - High-Density Lipoprotein - HDL (mg/dL) | Efficacy Phase
14.3.3.2.1.16 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Cholesterol/HDL Ratio | Efficacy Phase
14.3.3.2.1.17 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Low-Density Lipoprotein - LDL (mg/dL) | Efficacy Phase
14.3.3.2.1.18 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Magnesium (mg/dL) | Efficacy Phase
14.3.3.2.1.19 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Phosphorus (mg/dL) | Efficacy Phase
14.3.3.2.1.20 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Potassium (mEq/L) | Efficacy Phase
14.3.3.2.1.21 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Total Protein (g/dL) | Efficacy Phase
14.3.3.2.1.22 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Sodium (mEq/L) | Efficacy Phase
14.3.3.2.1.23 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Triglycerides (mg/dL) | Efficacy Phase
14.3.3.2.1.24 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Urea Nitrogen (mg/dL) | Efficacy Phase
14.3.3.2.1.25 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Uric Acid (mg/dL) | Efficacy Phase
14.3.3.2.1.26 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Creatinine Clearance (mL/min/1.7m^2^) | Efficacy Phase
14.3.3.2.2.1A | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata - Albumin (g/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.2A | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata - Alkaline Phosphatase (U/L) | Long-Term Effectiveness Phase
14.3.3.2.2.3A | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata - Alanine Aminotransferase - ALT (U/L) | Long-Term Effectiveness Phase
14.3.3.2.2.4A | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata - Aspartate Aminotransferase - AST (U/L) | Long-Term Effectiveness Phase
14.3.3.2.2.5A | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata - Bicarbonate (mEq/L) | Long-Term Effectiveness Phase
14.3.3.2.2.6A | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata - Direct Bilirubin (mg/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.7A | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata - Total Bilirubin (mg/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.8A | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata - Calcium (mg/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.9A | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata - Chloride (mEq/L) | Long-Term Effectiveness Phase
14.3.3.2.2.10A | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata - Cholesterol (mg/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.11A | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata - Creatine kinase (U/L) | Long-Term Effectiveness Phase
14.3.3.2.2.12A | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata - | Long-Term Effectiveness Phase
14.3.3.2.2.13A | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata - Gamma-glutamyl Transpeptidase - GGT (U/L) | Long-Term Effectiveness Phase
14.3.3.2.2.14A | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata - Glucose (mg/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.15A | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata - High-; Density Lipoprotein - HDL (mg/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.16A | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata - Cholesterol/HDL Ratio | Long-Term Effectiveness Phase
14.3.3.2.2.17A | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata - Low-; Density Lipoprotein - LDL (mg/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.18A | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata - Magnesium (mg/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.19A | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata - Phosphorus (mg/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.20A | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata - Potassium (mEq/L) | Long-Term Effectiveness Phase
14.3.3.2.2.21A | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata - Total Protein (g/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.22A | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata - Sodium (mEq/L) | Long-Term Effectiveness Phase
14.3.3.2.2.23A | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata - Triglycerides (mg/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.24A | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata - Urea Nitrogen (mg/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.25A | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata - Uric Acid (mg/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.26A | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata - Creatinine Clearance (mL/min/1.7m^2^) | Long-Term Effectiveness Phase
14.3.3.2.2.1B | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Albumin (g/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.2B | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Alkaline Phosphatase (U/L) | Long-Term Effectiveness Phase
14.3.3.2.2.3B | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Alanine Aminotransferase - ALT (U/L) | Long-Term Effectiveness Phase
14.3.3.2.2.4B | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Aspartate Aminotransferase - AST (U/L) | Long-Term Effectiveness Phase
14.3.3.2.2.5B | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Bicarbonate (mEq/L) | Long-Term Effectiveness Phase
14.3.3.2.2.6B | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Direct Bilirubin (mg/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.7B | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Total Bilirubin (mg/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.8B | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Calcium (mg/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.9B | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Chloride (mEq/L) | Long-Term Effectiveness Phase
14.3.3.2.2.10B | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Cholesterol (mg/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.11B | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Creatine kinase (U/L) | Long-Term Effectiveness Phase
14.3.3.2.2.12B | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Creatinine (mg/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.13B | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Gamma-glutamyl Transpeptidase - GGT (U/L) | Long-Term Effectiveness Phase
14.3.3.2.2.14B | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Glucose (mg/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.15B | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - High-Density Lipoprotein - HDL (mg/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.16B | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Cholesterol/HDL Ratio | Long-Term Effectiveness Phase
14.3.3.2.2.17B | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Low-Density Lipoprotein - LDL (mg/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.18B | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Magnesium (mg/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.19B | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Phosphorus (mg/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.20B | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Potassium (mEq/L) | Long-Term Effectiveness Phase
14.3.3.2.2.21B | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Total Protein (g/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.22B | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Sodium (mEq/L) | Long-Term Effectiveness Phase
14.3.3.2.2.23B | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Triglycerides (mg/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.24B | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Triglycerides (mg/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.25B | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Uric Acid (mg/dL) | Long-Term Effectiveness Phase
14.3.3.2.2.26B | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Creatinine Clearance (mL/min/1.7m^2^) | Long-Term Effectiveness Phase
14.3.3.2.3.1 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Albumin (g/dL) | Discontinuation Phase
14.3.3.2.3.2 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Alkaline Phosphatase (U/L) | Discontinuation Phase
14.3.3.2.3.3 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Alanine Aminotransferase - ALT (U/L) | Discontinuation Phase
14.3.3.2.3.4 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Aspartate Aminotransferase - AST (U/L) | Discontinuation Phase
14.3.3.2.3.5 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Bicarbonate (mEq/L) | Discontinuation Phase
14.3.3.2.3.6 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Direct Bilirubin (mg/dL) | Discontinuation Phase
14.3.3.2.3.7 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Total Bilirubin (mg/dL) | Discontinuation Phase
14.3.3.2.3.8 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Calcium (mg/dL) | Discontinuation Phase
14.3.3.2.3.9 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Chloride (mEq/L) | Discontinuation Phase
14.3.3.2.3.10 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Cholesterol (mg/dL) | Discontinuation Phase
14.3.3.2.3.11 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Creatine kinase (U/L) | Discontinuation Phase
14.3.3.2.3.12 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Creatinine (mg/dL) | Discontinuation Phase
14.3.3.2.3.13 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Gamma-glutamyl transpeptidase - GGT (U/L) | Discontinuation Phase
14.3.3.2.3.14 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Glucose (mg/dL) | Discontinuation Phase
14.3.3.2.3.15 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - High-Density Lipoprotein - HDL (mg/dL) | Discontinuation Phase
14.3.3.2.3.16 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Cholesterol/HDL Ratio | Discontinuation Phase
14.3.3.2.3.17 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Low-Density Lipoprotein - LDL (mg/dL) | Discontinuation Phase
14.3.3.2.3.18 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Magnesium (mg/dL) | Discontinuation Phase
14.3.3.2.3.19 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Phosphorus (mg/dL) | Discontinuation Phase
14.3.3.2.3.20 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Potassium (mEq/L) | Discontinuation Phase
14.3.3.2.3.21 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Total Protein (g/dL) | Discontinuation Phase
14.3.3.2.3.22 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Sodium (mEq/L) | Discontinuation Phase
14.3.3.2.3.23 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Triglycerides (mg/dL) | Discontinuation Phase
14.3.3.2.3.24 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Urea Nitrogen (mg/dL) | Discontinuation Phase
14.3.3.2.3.25 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Uric Acid (mg/dL) | Discontinuation Phase
14.3.3.2.3.26 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Creatinine Clearance (mL/min/1.7m^2^) | Discontinuation Phase
14.3.3.2.4.1 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Albumin (g/dL) | Restabilization Phase
14.3.3.2.4.2 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Alkaline Phosphatase (U/L) | Restabilization Phase
14.3.3.2.4.3 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Alanine Aminotransferase - ALT (U/L) | Restabilization Phase
14.3.3.2.4.4 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Aspartate Aminotransferase - AST (U/L) | Restabilization Phase
14.3.3.2.4.5 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Bicarbonate (mEq/L) | Restabilization Phase
14.3.3.2.4.6 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Direct Bilirubin (mg/dL) | Restabilization Phase
14.3.3.2.4.7 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Total Bilirubin (mg/dL) | Restabilization Phase
14.3.3.2.4.8 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Calcium (mg/dL) | Restabilization Phase
14.3.3.2.4.9 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Chloride (mEq/L) | Restabilization Phase
14.3.3.2.4.10 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Cholesterol (mg/dL) | Restabilization Phase
14.3.3.2.4.11 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Creatine kinase (U/L) | Restabilization Phase
14.3.3.2.4.12 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Creatinine (mg/dL) | Restabilization Phase
14.3.3.2.4.13 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Glucose Tolerance Test - GGT (U/L) | Restabilization Phase
14.3.3.2.4.14 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Glucose (mg/dL) | Restabilization Phase
14.3.3.2.4.15 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - High Density Lipoprotein - HDL (mg/dL) | Restabilization Phase
14.3.3.2.4.16 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Cholesterol/HDL Ratio | Restabilization Phase
14.3.3.2.4.17 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Low Density Lipoprotein - LDL (mg/dL) | Restabilization Phase
14.3.3.2.4.18 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Magnesium (mg/dL) | Restabilization Phase
14.3.3.2.4.19 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Phosphorus (mg/dL) | Restabilization Phase
14.3.3.2.4.20 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Potassium (mEq/L) | Restabilization Phase
14.3.3.2.4.21 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Total Protein (g/dL) | Restabilization Phase
14.3.3.2.4.22 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Sodium (mEq/L) | Restabilization Phase
14.3.3.2.4.23 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Triglycerides (mg/dL) | Restabilization Phase
14.3.3.2.4.24 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Urea Nitrogen (mg/dL) | Restabilization Phase
14.3.3.2.4.25 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Uric Acid (mg/dL) | Restabilization Phase
14.3.3.2.4.26 | Safety | Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received - Creatinine Clearance (mL/min/1.7m2) | Restabilization Phase
14.3.3.3.1.1 | Safety | Summary of Clinical Thyroid Panel by Visit, Age Strata and Efficacy Phase Treatment Received - Thyroid Stimulating Hormone - TSH (mIU/L) | Efficacy Phase
14.3.3.3.1.2 | Safety | Summary of Clinical Thyroid Panel by Visit, Age Strata and Efficacy Phase Treatment Received - Total T3 (ng/dL) | Efficacy Phase
14.3.3.3.1.3 | Safety | Summary of Clinical Thyroid Panel by Visit, Age Strata and Efficacy Phase Treatment Received - Total T4 (μg/dL) | Efficacy Phase
14.3.3.3.1.4 | Safety | Summary of Clinical Thyroid Panel by Visit, Age Strata and Efficacy Phase Treatment Received - Antithyroglobulin Ab (IU/mL) | Efficacy Phase
14.3.3.3.1.5 | Safety | Summary of Clinical Thyroid Panel by Visit, Age Strata and Efficacy Phase Treatment Received - Thyroid Peroxidase Ab (IU/mL) | Efficacy Phase
14.3.3.3.2.1A | Safety | Summary of Clinical Thyroid Panel by Visit and Age Strata - Thyroid Stimulating Hormone - TSH (mIU/L) | Long-Term Effectiveness Phase
14.3.3.3.2.2A | Safety | Summary of Clinical Thyroid Panel by Visit and Age Strata - Total T3 (ng/dL) | Long-Term Effectiveness Phase
14.3.3.3.2.3A | Safety | Summary of Clinical Thyroid Panel by Visit and Age Strata - Total T4 (μg/dL) | Long-Term Effectiveness Phase
14.3.3.3.2.4A | Safety | Summary of Clinical Thyroid Panel by Visit and Age Strata - Antithyroglobulin Ab (IU/mL) | Long-Term Effectiveness Phase
14.3.3.3.2.5A | Safety | Summary of Clinical Thyroid Panel by Visit and Age Strata - Thyroid Peroxidase Ab (IU/mL) | Long-Term Effectiveness Phase
14.3.3.3.2.1B | Safety | Summary of Clinical Thyroid Panel by Visit and Efficacy Phase Treatment Received - Thyroid Stimulating Hormone - TSH (mIU/L) | Long-Term Effectiveness Phase
14.3.3.3.2.2B | Safety | Summary of Clinical Thyroid Panel by Visit and Efficacy Phase Treatment Received - Total T3 (ng/dL) | Long-Term Effectiveness Phase
14.3.3.3.2.3B | Safety | Summary of Clinical Thyroid Panel by Visit and Efficacy Phase Treatment Received - Total T4 (μg/dL) | Long-Term Effectiveness Phase
14.3.3.3.2.4B | Safety | Summary of Clinical Thyroid Panel by Visit and Efficacy Phase Treatment Received - Antithyroglobulin Ab (IU/mL) | Long-Term Effectiveness Phase
14.3.3.3.2.5B | Safety | Summary of Clinical Thyroid Panel by Visit and Efficacy Phase Treatment Received - Thyroid Peroxidase Ab (IU/mL) | Long-Term Effectiveness Phase
14.3.3.3.3.1 | Safety | Summary of Clinical Laboratory Thyroid Panel by Visit and Discontinuation Phase Treatment Received - Thyroid Stimulating Hormone - TSH (mIU/L) | Discontinuation Phase
14.3.3.3.3.2 | Safety | Summary of Clinical Laboratory Thyroid Panel by Visit and Discontinuation Phase Treatment Received - Total T3 (ng/dL) - Safety Population | Discontinuation Phase
14.3.3.3.3.3 | Safety | Summary of Clinical Laboratory Thyroid Panel by Visit and Discontinuation Phase Treatment Received - Total T4 (μg/dL) | Discontinuation Phase
14.3.3.3.3.4 | Safety | Summary of Clinical Laboratory Thyroid Panel by Visit and Discontinuation Phase Treatment Received - Antithyroglobulin Ab (IU/mL) | Discontinuation Phase
14.3.3.3.3.5 | Safety | Summary of Clinical Laboratory Thyroid Panel by Visit and Discontinuation Phase Treatment Received - Thyroid Peroxidase Ab (IU/mL) | Discontinuation Phase
14.3.3.3.4.1 | Safety | Summary of Clinical Laboratory Thyroid Panel by Visit and Discontinuation Phase Treatment Received - Thyroid Stimulating Hormone – TSH (mIU/L) | Restabilization Phase
14.3.3.3.4.2 | Safety | Summary of Clinical Laboratory Thyroid Panel by Visit and Discontinuation Phase Treatment Received - Total T3 (ng/dL) | Restabilization Phase
14.3.3.3.4.3 | Safety | Summary of Clinical Laboratory Thyroid Panel by Visit and Discontinuation Phase Treatment Received - Total T4l (μg/dL) | Restabilization Phase
14.3.3.3.4.4 | Safety | Summary of Clinical Laboratory Thyroid Panel by Visit and Discontinuation Phase Treatment Received - Antithyroglobulin Ab (IU/mL) | Restabilization Phase
14.3.3.3.4.5 | Safety | Summary of Clinical Laboratory Thyroid Panel by Visit and Discontinuation Phase Treatment Received - Thyroid Peroxidase Ab (IU/mL) | Restabilization Phase
14.3.3.4.1.1 | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - pH | Efficacy Phase
14.3.3.4.1.2 | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Specific Gravity | Efficacy Phase
14.3.3.4.1.3 | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Protein | Efficacy Phase
14.3.3.4.1.4 | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Glucose | Efficacy Phase
14.3.3.4.1.5 | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Ketones | Efficacy Phase
14.3.3.4.1.6 | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Nitrite | Efficacy Phase
14.3.3.4.1.7 | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Leukocyte Esterase | Efficacy Phase
14.3.3.4.1.8 | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit, Age Strata and Efficacy Phase Treatment Received - Blood | Efficacy Phase
14.3.3.4.2.1A | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Age Strata - pH | Long-Term Effectiveness Phase
14.3.3.4.2.2A | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Age Strata - Specific Gravity | Long-Term Effectiveness Phase
14.3.3.4.2.3A | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Age Strata - Protein | Long-Term Effectiveness Phase
14.3.3.4.2.4A | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Age Strata - Glucose | Long-Term Effectiveness Phase
14.3.3.4.2.5A | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Age Strata - Ketones | Long-Term Effectiveness Phase
14.3.3.4.2.6A | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Age Strata - Nitrite | Long-Term Effectiveness Phase
14.3.3.4.2.7A | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Age Strata - Leukocyte Esterase | Long-Term Effectiveness Phase
14.3.3.4.2.8A | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Age Strata - Blood | Long-Term Effectiveness Phase
14.3.3.4.2.1B | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Efficacy Phase Treatment Received - pH | Long-Term Effectiveness Phase
14.3.3.4.2.2B | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Efficacy Phase Treatment Received - Specific Gravity | Long-Term Effectiveness Phase
14.3.3.4.2.3B | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Efficacy Phase Treatment Received - Protein | Long-Term Effectiveness Phase
14.3.3.4.2.4B | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Efficacy Phase Treatment Received - Glucose | Long-Term Effectiveness Phase
14.3.3.4.2.5B | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Efficacy Phase Treatment Received - Ketones | Long-Term Effectiveness Phase
14.3.3.4.2.6B | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Efficacy Phase Treatment Received - Nitrite | Long-Term Effectiveness Phase
14.3.3.4.2.7B | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Efficacy Phase Treatment Received - Leukocyte Esterase | Long-Term Effectiveness Phase
14.3.3.4.2.8B | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Efficacy Phase Treatment Received - Blood | Long-Term Effectiveness Phase
14.3.3.4.3.1 | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received - pH | Discontinuation Phase
14.3.3.4.3.2 | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received- Specific Gravity | Discontinuation Phase
14.3.3.4.3.3 | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received - Protein | Discontinuation Phase
14.3.3.4.3.4 | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received - Glucose | Discontinuation Phase
14.3.3.4.3.5 | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received - Ketones | Discontinuation Phase
14.3.3.4.3.6 | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received - Nitrite | Discontinuation Phase
14.3.3.4.3.7 | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received - Leukocyte Esterase | Discontinuation Phase
14.3.3.4.3.8 | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received - Blood | Discontinuation Phase
14.3.3.4.4.1 | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received - pH | Restabilization Phase
14.3.3.4.4.2 | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received - Specific Gravity | Restabilization Phase
14.3.3.4.4.3 | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received - Protein | Restabilization Phase
14.3.3.4.4.4 | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received - Glucose | Restabilization Phase
14.3.3.4.4.5 | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received - Ketones | Restabilization Phase
14.3.3.4.4.6 | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received - Nitrite | Restabilization Phase
14.3.3.4.4.7 | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received - Leukocyte Esterase | Restabilization Phase
14.3.3.4.4.8 | Safety | Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received - Blood | Restabilization Phase
14.3.3.5.1.1 | Safety | Summary of Clinical Laboratory Coagulation Measurements by Visit, Age Strata and Efficacy Phase Treatment Received - Fibrinogen (mg/dL) | Efficacy Phase
14.3.3.5.1.2 | Safety | Summary of Clinical Laboratory Coagulation Measurements by Visit, Age Strata and Efficacy Phase Treatment Received - Prothrombin Time - PT (Seconds) | Efficacy Phase
14.3.3.5.1.3 | Safety | Summary of Clinical Laboratory Coagulation Measurements by Visit, Age Strata and Efficacy Phase Treatment Received - Partial Thromboplastin Time - PTT (Seconds) | Efficacy Phase
14.3.3.5.2.1A | Safety | Summary of Clinical Laboratory Coagulation Measurements by Visit and Age Strata - Fibrinogen (mg/dL) | Long-Term Effectiveness Phase
14.3.3.5.2.2A | Safety | Summary of Clinical Laboratory Coagulation Measurements by Visit and Age Strata - Prothrombin Time - PT (Seconds) | Long-Term Effectiveness Phase
14.3.3.5.2.3A | Safety | Summary of Clinical Laboratory Coagulation Measurements by Visit and Age Strata - Partial Thromboplastin Time - PTT (Seconds) | Long-Term Effectiveness Phase
14.3.3.5.2.1B | Safety | Summary of Clinical Laboratory Coagulation Measurements by Visit and Efficacy Phase Treatment Received - Fibrinogen (mg/dL) | Long-Term Effectiveness Phase
14.3.3.5.2.2B | Safety | Summary of Clinical Laboratory Coagulation Measurements by Visit and Efficacy Phase Treatment Received - Prothrombin Time - PT (Seconds) | Long-Term Effectiveness Phase
14.3.3.5.2.3B | Safety | Summary of Clinical Laboratory Coagulation Measurements by Visit and Efficacy Phase Treatment Received - Partial Thromboplastin Time - PTT (Seconds) | Long-Term Effectiveness Phase
14.3.3.5.3.1 | Safety | Summary of Clinical Laboratory Coagulation Measurements by Visit and Discontinuation Phase Treatment Received - Fibrinogen (mg/dL) | Discontinuation Phase
14.3.3.5.3.2 | Safety | Summary of Clinical Laboratory Coagulation Measurements by Visit and Discontinuation Phase Treatment Received - Prothrombin Time - PT (Seconds) | Discontinuation Phase
14.3.3.5.3.3 | Safety | Summary of Clinical Laboratory Coagulation Measurements by Visit and Discontinuation Phase Treatment Received - Partial Thromboplastin Time - PTT (Seconds) | Discontinuation Phase
14.3.3.5.4.1 | Safety | Summary of Clinical Laboratory Coagulation Measurements by Visit and Discontinuation Phase Treatment Received - Fibrinogen (mg/dL) | Restabilization Phase
14.3.3.5.4.2 | Safety | Summary of Clinical Laboratory Coagulation Measurements by Visit and Discontinuation Phase Treatment Received - Prothrombin Time - PT (Seconds) | Restabilization Phase
14.3.3.5.4.3 | Safety | Summary of Clinical Laboratory Coagulation Measurements by Visit and Discontinuation Phase Treatment Received - Partial Thromboplastin Time - PTT (Seconds) | Restabilization Phase
14.3.4.1.1 | Safety | Summary of Vital Signs by Visit, Age Strata and Efficacy Phase Treatment Received - Heart Rate (beats/min) | Efficacy Phase
14.3.4.1.2 | Safety | Summary of Vital Signs by Visit, Age Strata and Efficacy Phase Treatment Received - Systolic Blood Pressure (mmHg) | Efficacy Phase
14.3.4.1.3 | Safety | Summary of Vital Signs by Visit, Age Strata and Efficacy Phase Treatment Received - Systolic Blood Pressure Z Score | Efficacy Phase
14.3.4.1.4 | Safety | Summary of Vital Signs by Visit, Age Strata and Efficacy Phase Treatment Received - Diastolic Blood Pressure (mmHg) | Efficacy Phase
14.3.4.1.5 | Safety | Summary of Vital Signs by Visit, Age Strata and Efficacy Phase Treatment Received - Diastolic Blood Pressure Z Score | Efficacy Phase
14.3.4.1.6 | Safety | Summary of Vital Signs by Visit, Age Strata and Efficacy Phase Treatment Received - Weight (kg) | Efficacy Phase
14.3.4.1.7 | Safety | Summary of Vital Signs by Visit, Age Strata and Efficacy Phase Treatment Received - Weight Z Score | Efficacy Phase
14.3.4.1.8 | Safety | Summary of Vital Signs by Visit, Age Strata and Efficacy Phase Treatment Received - Height (cm) | Efficacy Phase
14.3.4.1.9 | Safety | Summary of Vital Signs by Visit, Age Strata and Efficacy Phase Treatment Received - Height Z Score | Efficacy Phase
14.3.4.1.10 | Safety | Summary of Vital Signs by Visit, Age Strata and Efficacy Phase Treatment Received - BMI | Efficacy Phase
14.3.4.1.11 | Safety | Summary of Vital Signs by Visit, Age Strata and Efficacy Phase Treatment Received - BMI Z Score | Efficacy Phase
14.3.4.2.1A | Safety | Summary of Vital Signs by Visit and Age Strata - Heart Rate (beats/min) | Long-Term Effectiveness Phase
14.3.4.2.2A | Safety | Summary of Vital Signs by Visit and Age Strata - Systolic Blood Pressure (mmHg) | Long-Term Effectiveness Phase
14.3.4.2.3A | Safety | Summary of Vital Signs by Visit and Age Strata - Systolic Blood Pressure Z Score | Long-Term Effectiveness Phase
14.3.4.2.4A | Safety | Summary of Vital Signs by Visit and Age Strata - Diastolic Blood Pressure (mmHg) | Long-Term Effectiveness Phase
14.3.4.2.5A | Safety | Summary of Vital Signs by Visit and Age Strata - Diastolic Blood Pressure Z Score | Long-Term Effectiveness Phase
14.3.4.2.6A | Safety | Summary of Vital Signs by Visit and Age Strata - Weight (kg) | Long-Term Effectiveness Phase
14.3.4.2.7A | Safety | Summary of Vital Signs by Visit and Age Strata - Weight Z Score | Long-Term Effectiveness Phase
14.3.4.2.8A | Safety | Summary of Vital Signs by Visit and Age Strata - Height (cm) | Long-Term Effectiveness Phase
14.3.4.2.9A | Safety | Summary of Vital Signs by Visit and Age Strata - Height Z Score | Long-Term Effectiveness Phase
14.3.4.2.10A | Safety | Summary of Vital Signs by Visit and Age Strata - BMI | Long-Term Effectiveness Phase
14.3.4.2.11A | Safety | Summary of Vital Signs by Visit and Age Strata - BMI Z Score | Long-Term Effectiveness Phase
14.3.4.2.1B | Safety | Summary of Vital Signs by Visit and Efficacy Phase Treatment Received - Heart Rate (beats/min) | Long-Term Effectiveness Phase
14.3.4.2.2B | Safety | Summary of Vital Signs by Visit and Efficacy Phase Treatment Received - Systolic Blood Pressure (mmHg) | Long-Term Effectiveness Phase
14.3.4.2.3B | Safety | Summary of Vital Signs by Visit and Efficacy Phase Treatment Received - Systolic Blood Pressure Z Score | Long-Term Effectiveness Phase
14.3.4.2.4B | Safety | Summary of Vital Signs by Visit and Efficacy Phase Treatment Received - Diastolic Blood Pressure (mmHg) | Long-Term Effectiveness Phase
14.3.4.2.5B | Safety | Summary of Vital Signs by Visit and Efficacy Phase Treatment Received - Diastolic Blood Pressure Z Score | Long-Term Effectiveness Phase
14.3.4.2.6B | Safety | Summary of Vital Signs by Visit and Efficacy Phase Treatment Received - Weight (kg) | Long-Term Effectiveness Phase
14.3.4.2.7B | Safety | Summary of Vital Signs by Visit and Efficacy Phase Treatment Received - Weight Z Score | Long-Term Effectiveness Phase
14.3.4.2.8B | Safety | Summary of Vital Signs by Visit and Efficacy Phase Treatment Received - Height (cm) | Long-Term Effectiveness Phase
14.3.4.2.9B | Safety | Summary of Vital Signs by Visit and Efficacy Phase Treatment Received - Height Z Score | Long-Term Effectiveness Phase
14.3.4.2.10B | Safety | Summary of Vital Signs by Visit and Efficacy Phase Treatment Received - BMI | Long-Term Effectiveness Phase
14.3.4.2.11B | Safety | Summary of Vital Signs by Visit and Efficacy Phase Treatment Received - BMI Z Score | Long-Term Effectiveness Phase
14.3.4.3.1 | Safety | Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received - Heart Rate (beats/min) | Discontinuation Phase
14.3.4.3.2 | Safety | Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received - Systolic Blood Pressure (mmHg) | Discontinuation Phase
14.3.4.3.3 | Safety | Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received - Systolic Blood Pressure Z Score | Discontinuation Phase
14.3.4.3.4 | Safety | Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received - Diastolic Blood Pressure (mmHg) | Discontinuation Phase
14.3.4.3.5 | Safety | Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received - Diastolic Blood Pressure Z Score | Discontinuation Phase
14.3.4.3.6 | Safety | Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received - Weight (kg) | Discontinuation Phase
14.3.4.3.7 | Safety | Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received - Weight Z Score | Discontinuation Phase
14.3.4.3.8 | Safety | Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received - Height (cm) | Discontinuation Phase
14.3.4.3.9 | Safety | Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received - Height Z Score | Discontinuation Phase
14.3.4.3.10 | Safety | Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received - BMI | Discontinuation Phase
14.3.4.3.11 | Safety | Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received - BMI Z Score | Discontinuation Phase
14.3.4.4.1 | Safety | Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received - Heart Rate (beats/min) | Restabilization Phase
14.3.4.4.2 | Safety | Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received - Systolic Blood Pressure (mmHg) | Restabilization Phase
14.3.4.4.3 | Safety | Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received - Systolic Blood Pressure Z Score | Restabilization Phase
14.3.4.4.4 | Safety | Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received - Diastolic Blood Pressure (mmHg) | Restabilization Phase
14.3.4.4.5 | Safety | Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received - Diastolic Blood Pressure Z Score | Restabilization Phase
14.3.4.4.6 | Safety | Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received - Weight (kg) | Restabilization Phase
14.3.4.4.7 | Safety | Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received - Weight Z Score | Restabilization Phase
14.3.4.4.8 | Safety | Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received - Height (cm) | Restabilization Phase
14.3.4.4.9 | Safety | Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received - Height Z Score | Restabilization Phase
14.3.4.4.10 | Safety | Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received - BMI | Restabilization Phase
14.3.4.4.11 | Safety | Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received - BMI Z Score | Restabilization Phase
14.3.5.1 | Safety | Summary of ECG Results by Age Strata and Efficacy Phase Treatment Received - Safety Population | Efficacy Phase
14.3.5.2A | Safety | Summary of ECG Results by Age Strata | Long-Term Effectiveness Phase
14.3.5.2B | Safety | Summary of ECG Results by Efficacy Phase Treatment Received | Long-Term Effectiveness Phase
14.3.5.3 | Safety | Summary of ECG Results by Discontinuation Phase Treatment Received | Discontinuation Phase
14.3.5.4 | Safety | Summary of ECG Results by Discontinuation Phase Treatment Received | Restabilization Phase
14.3.6.1 | Safety | Summary of Neurologic Rating Scale by Age Strata and Efficacy Phase Treatment Received Group | Efficacy Phase
14.3.6.2A | Safety | Summary of Neurologic Rating Scale by Age Strata | Long-Term Effectiveness Phase
14.3.6.2B | Safety | Summary of Neurologic Rating Scale by Efficacy Phase Treatment Received Group | Long-Term Effectiveness Phase
14.3.6.3 | Safety | Summary of Neurologic Rating Scale by Discontinuation Phase Treatment Received Group | Discontinuation Phase
14.3.6.4 | Safety | Summary of Neurologic Rating Scale by Discontinuation Phase Treatment Received Group | Restabilization Phase
14.3.7.1.1 | Safety | Summary of SSRS-C: Columbia Suicide Severity Rating Scale by Age Strata and Efficacy Phase Treatment Received - Suicide Behavior | Efficacy Phase
14.3.7.1.2 | Safety | Summary of SSRS-C: Columbia Suicide Severity Rating Scale by Age Strata and Efficacy Phase Treatment Received - Suicide Ideation | Efficacy Phase
14.3.7.2.1A | Safety | Summary of SSRS-C: Columbia Suicide Severity Rating Scale by Age Strata - Suicide Behavior | Long-Term Effectiveness Phase
14.3.7.2.2A | Safety | Summary of SSRS-C: Columbia Suicide Severity Rating Scale by Age Strata - Suicide Ideation | Long-Term Effectiveness Phase
14.3.7.2.1B | Safety | Summary of SSRS-C: Columbia Suicide Severity Rating Scale by Efficacy Phase Treatment Received - Suicide Behavior | Long-Term Effectiveness Phase
14.3.7.2.2B | Safety | Summary of SSRS-C: Columbia Suicide Severity Rating Scale by Efficacy Phase Treatment Received - Suicide Ideation | Long-Term Effectiveness Phase
14.3.7.3.1 | Safety | Summary of SSRS-C: Columbia Suicide Severity Rating Scale by Discontinuation Phase Treatment Received - Suicide Behavior | Discontinuation Phase
14.3.7.3.2 | Safety | Summary of SSRS-C: Columbia Suicide Severity Rating Scale by Discontinuation Phase Treatment Received - Suicide Ideation | Discontinuation Phase
14.3.7.4.1 | Safety | Summary of SSRS-C: Columbia Suicide Severity Rating Scale by Discontinuation Phase Treatment Received - Suicide Behavior | Restabilization Phase
14.3.7.4.2 | Safety | Summary of SSRS-C: Columbia Suicide Severity Rating Scale by Discontinuation Phase Treatment Received - Suicide Ideation | Restabilization Phase

## 14.4 Figures

Figure Number | Population | Figure Title / Summary | Phase
14.2.1.1.1 | Efficacy Population | Young Mania Rating Scale (YMRS) by Visit and Randomized Treatment Group | Efficacy Phase - Efficacy Population
14.2.1.1.2 | Efficacy Population | Change in Young Mania Rating Scale (YMRS) by Visit and Randomized Treatment Group | Efficacy Phase - Efficacy Population
14.2.1.1.3 | Per Protocol Population | Young Mania Rating Scale (YMRS) by Visit and Randomized Treatment Group | Efficacy Phase - Per Protocol Population
14.2.1.1.4 | Per Protocol Population | Change in Young Mania Rating Scale (YMRS) by Visit and Randomized Treatment Group | Efficacy Phase - Per Protocol Population
14.2.1.1.5 | Revised Per Protocol Population | YMRS Summary Score by Visit and Randomized Treatment Group | Efficacy Phase - Revised Per Protocol Population
14.2.1.1.6 | Revised Per Protocol Population | Change in YMRS Summary Score by Visit and Randomized Treatment Group | Efficacy Phase - Revised Per Protocol Population
14.2.1.2.1 | Efficacy Population | Time to Discontinuation for Any Reason by Randomized Treatment Group | Efficacy Phase - Efficacy Population
14.2.1.2.2 | Efficacy Population | Time to Discontinuation Due to Lack of Efficacy by Randomized Treatment Group | Efficacy Phase - Efficacy Population
14.2.2.1.1 | Efficacy Population | Young Mania Rating Scale (YMRS) by Visit and Efficacy Phase Randomized Treatment Group | Long Term Effectiveness Phase - Efficacy Population
14.2.2.1.2 | Efficacy Population | Change in Young Mania Rating Scale (YMRS) by Visit and Efficacy Phase Randomized Treatment Group | Long Term Effectiveness Phase - Efficacy Population
14.2.2.2A | Efficacy Population | Time to Discontinuation for Any Reason by Age Strata | Long Term Effectiveness Phase - Efficacy Population
14.2.2.2B | Efficacy Population | Time to Discontinuation for Any Reason by Efficacy Phase Randomized Treatment Group | Long Term Effectiveness Phase - Efficacy Population
14.2.3.1.1 | Efficacy Population | Time to Discontinuation for Any Reason by Randomized Treatment | Discontinuation Phase - Efficacy Population
14.2.3.1.2 | Per Protocol Population | Time to Discontinuation for Any Reason by Randomized Treatment Group | Discontinuation Phase - Per Protocol Population
14.2.3.1.3 | Revised Per Protocol Population | Time to Discontinuation for Any Reason by Randomized Treatment Group | Discontinuation Phase - Revised Per Protocol Population
14.2.3.1.4 | Efficacy Population | Time to Discontinuation for Any Reason by Treatment Received | Discontinuation Phase - Efficacy Population
14.2.3.2.1 | Efficacy Population | Time to Recurrence of Mood Episodes by Randomized Treatment Group | Discontinuation Phase - Efficacy Population
14.2.3.2.2 | Efficacy Population | Young Mania Rating Scale (YMRS) by Visit and Randomized Treatment Group | Discontinuation Phase - Efficacy Population
14.2.3.2.3 | Efficacy Population | Change in Young Mania Rating Scale (YMRS) by Visit and Randomized Treatment Group | Discontinuation Phase - Efficacy Population
14.2.4.1.1 | Efficacy Population | Young Mania Rating Scale (YMRS) by Visit | Restabilization Phase
14.2.4.1.2 | Efficacy Population | Change in Young Mania Rating Scale (YMRS) by Visit | Restabilization Phase
14.2.4.2 | Efficacy Population | Time to Discontinuation for Any Reason | Restabilization Phase - Efficacy Population
14.3.1.1 | Safety Population | Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - White Blood Count (×10^3^/μL) | Efficacy Phase
14.3.1.2 | Safety Population | Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Neutrophils (%) | Efficacy Phase
14.3.1.3 | Safety Population | Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Lymphocytes (%) | Efficacy Phase
14.3.1.4 | Safety Population | Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received- Monocytes (%) | Efficacy Phase
14.3.1.5 | Safety Population | Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Eosinophils (%) | Efficacy Phase
14.3.1.6 | Safety Population | Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Basophils (%) | Efficacy Phase
14.3.1.7 | Safety Population | Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Creatinine (mg/dL) | Efficacy Phase
14.3.1.8 | Safety Population | Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Creatinine Clearance (mL/min/1.7m2) | Efficacy Phase
14.3.1.9 | Safety Population | Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Thyroid Stimulating Hormone - TSH (mIU/L) | Efficacy Phase
14.3.1.10 | Safety Population | Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Total T3 (ng/dL) | Efficacy Phase
14.3.1.11 | Safety Population | Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Total T4 (μg/dL) | Efficacy Phase
14.3.1.12 | Safety Population | Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Antithyroglobulin Ab (IU/mL) | Efficacy Phase
14.3.1.13 | Safety Population | Thyroid Panel Measurement by Visit and Efficacy Phase Treatment Received - Thyroid Peroxidase Ab (IU/mL) | Efficacy Phase
14.3.2.1A | Safety Population | Laboratory Chemistry Measurement by Visit and Age Strata - White Blood Count (×10^3^/μL) | Long-Term Effectiveness Phase
14.3.2.1B | Safety Population | Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - White Blood Count (×10^3^/μL) | Long-Term Effectiveness Phase
14.3.2.2A | Safety Population | Laboratory Chemistry Measurement by Visit and Age Strata - Neutrophils (%) | Long-Term Effectiveness Phase
14.3.2.2B | Safety Population | Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Neutrophils (%) | Long-Term Effectiveness Phase
14.3.2.3A | Safety Population | Laboratory Chemistry Measurement by Visit and Age Strata - Lymphocytes (%) | Long-Term Effectiveness Phase
14.3.2.3B | Safety Population | Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Lymphocytes (%) | Long-Term Effectiveness Phase
14.3.2.4A | Safety Population | Laboratory Chemistry Measurement by Visit and Age Strata - Monocytes (%) | Long-Term Effectiveness Phase
14.3.2.4B | Safety Population | Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Monocytes (%) | Long-Term Effectiveness Phase
14.3.2.5A | Safety Population | Laboratory Chemistry Measurement by Visit and Age Strata - Eosinophils (%) | Long-Term Effectiveness Phase
14.3.2.5B | Safety Population | Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Eosinophils (%) | Long-Term Effectiveness Phase
14.3.2.6A | Safety Population | Laboratory Chemistry Measurement by Visit and Age Strata - Basophils (%) | Long-Term Effectiveness Phase
14.3.2.6B | Safety Population | Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Basophils (%) | Long-Term Effectiveness Phase
14.3.2.7A | Safety Population | Laboratory Chemistry Measurement by Visit and Age Strata - Creatinine (mg/dL) | Long-Term Effectiveness Phase
14.3.2.7B | Safety Population | Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Creatinine (mg/dL) | Long-Term Effectiveness Phase
14.3.2.8A | Safety Population | Laboratory Chemistry Measurement by Visit and Age Strata - Creatinine Clearance (mL/min/1.7m2) | Long-Term Effectiveness Phase
14.3.2.8B | Safety Population | Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Creatinine Clearance (mL/min/1.7m2) | Long-Term Effectiveness Phase
14.3.2.9A | Safety Population | Laboratory Chemistry Measurement by Visit and Age Strata - Thyroid Stimulating Hormone - TSH (mIU/L) | Long-Term Effectiveness Phase
14.3.2.9B | Safety Population | Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Thyroid Stimulating Hormone - TSH (mIU/L) | Long-Term Effectiveness Phase
14.3.2.10A | Safety Population | Laboratory Chemistry Measurement by Visit and Age Strata - Total T3 (ng/dL) | Long-Term Effectiveness Phase
14.3.2.10B | Safety Population | Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Total T3 (ng/dL) | Long-Term Effectiveness Phase
14.3.2.11A | Safety Population | Laboratory Chemistry Measurement by Visit and Age Strata - Total T4 (μg/dL) | Long-Term Effectiveness Phase
14.3.2.11B | Safety Population | Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Total T4 (μg/dL) | Long-Term Effectiveness Phase
14.3.2.12A | Safety Population | Laboratory Chemistry Measurement by Visit and Age Strata - Antithyroglobulin Ab (IU/mL) | Long-Term Effectiveness Phase
14.3.2.12B | Safety Population | Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received - Antithyroglobulin Ab (IU/mL) | Long-Term Effectiveness Phase
14.3.2.13A | Safety Population | Laboratory Chemistry Measurement by Visit and Age Strata - Thyroid Peroxidase Ab (IU/mL) | Long-Term Effectiveness Phase
14.3.2.13B | Safety Population | Thyroid Panel Measurement by Visit and Efficacy Phase Treatment Received - Thyroid Peroxidase Ab (IU/mL) | Long-Term Effectiveness Phase
14.4.1 | Safety Population | Participant Profiles | Efficacy Phase
14.4.2 | Safety Population | Participant Profiles | Long-Term Effectiveness Phase

## 14.5 SAE Narratives

SAE Narratives have been redacted from this report.

Table 14.1.1.1.1 Participant Accountability and Study Disposition Screening Phase - All Participants

| Age Strata | | Total
| 7 - 11 yrs | 12 - 17 yrs | Total
Screening Phase | 90 | 63 | 153
Screening Phase Failures | 41 (45.6%) | 31 (49.2%) | 72 (47.1%)
Eligible and Randomized to Efficacy Phase | 49 (54.4%) | 32 (50.8%) | 81 (52.9%)
Reasons for Screening Phase Failures
Other adverse event | 0 | 1 (1.6%) | 1 (0.7%)
Inclusion/Exclusion criteria not met | 26 (28.9%) | 23 (36.5%) | 49 (32.0%)
Inclusion criteria not met
DSM-IV diagnostic criteria | 18 (20.0%) | 10 (15.9%) | 28 (18.3%)
Score ≥20 on YMRS | 5 (5.6%) | 3 (4.8%) | 8 (5.2%)
Informed consent/assent | 0 | 1 (1.6%) | 1 (0.7%)
No ineligible co-morbidities | 3 (3.3%) | 0 | 3 (2.0%)
Negative toxicity screen | 2 (2.2%) | 3 (4.8%) | 5 (3.3%)
Willing & able to wash out of exclusion medications | 1 (1.1%) | 0 | 1 (0.7%)
Exclusion criteria met
Diagnosis of ineligible co-morbidity | 2 (2.2%) | 0 | 2 (1.3%)
DSM-IV diagnosis of substance dependence | 0 | 1 (1.6%) | 1 (0.7%)
Positive drug screen at screening & retest | 0 | 1 (1.6%) | 1 (0.7%)
Serious unstable medical illness or laboratory finding | 1 (1.1%) | 1 (1.6%) | 2 (1.3%)
Medical condition adversely affected by lithium | 1 (1.1%) | 2 (3.2%) | 3 (2.0%)
Serious homicidal/suicidal ideation | 1 (1.1%) | 0 | 1 (0.7%)
Active hallucinations and delusions | 2 (2.2%) | 1 (1.6%) | 3 (2.0%)
Concomitant medication/suppliment Li interaction | 1 (1.1%) | 0 | 1 (0.7%)
Participant unable to swallow medication | 0 | 1 (1.6%) | 1 (0.7%)
Anticipated baseline YMRS <20 | 1 (1.1%) | 3 (4.8%) | 4 (2.6%)
IQ less than 70 | 1 (1.1%) | 1 (1.6%) | 2 (1.3%)
Lost to follow-up | 1 (1.1%) | 3 (4.8%) | 4 (2.6%)
Investigator decision | 2 (2.2%) | 2 (3.2%) | 4 (2.6%)
Consent / assent withdrawn by participant / caregiver | 12 (13.3%) | 2 (3.2%) | 14 (9.2%)

Note: Age strata is calculated at start of the phase. Denominator is the number of participants in each age strata or total.

Participants can list up to a total of 5 inclusion criteria not met or exclusion criteria met for failing the Screening Phase.

Table 14.1.1.1.2 Participant Accountability and Study Disposition Efficacy Phase - All Participants

| Efficacy Phase Randomized Treatment Group | | Total
| Lithium | Placebo | Total
Efficacy Phase | 53 | 28 | 81
Discontinued during Efficacy Phase | 16 (30.2%) | 7 (25.0%) | 23 (28.4%)
Completed Efficacy Phase but did not continue to LTE Phase | 8 (15.1%) | 6 (21.4%) | 14 (17.3%)
Eligible and Entered in LTE Phase | 29 (54.7%) | 15 (53.6%) | 44 (54.3%)
Reasons for Discontinuing during the Efficacy Phase
Lack of efficacy | 3 | 1 | 4
Lost to follow-up | 1 | 1 | 2
Protocol non-compliance | 4 | 1 | 5
Psychosis with mood symptoms | 2 | 0 | 2
Other adverse event | 2 | 1 | 3
Suicidal/homicidal ideation | 2 | 1 | 3
Consent / assent withdrawn by participant / caregiver | 2 | 2 | 4
Reasons for not continuing to Long Term Effectiveness Phase
Ineligible for next phase | 6 | 5 | 11
Protocol non-compliance | 2 | 1 | 3

Note: Denominator is the number of participants in each treatment group or total.

Table 14.1.1.1.3 Participant Accountability and Study Disposition Long Term Effectiveness Phase - All Participants

| Age Strata | | Total
| 7 - 11 yrs | 12 - 17 yrs | Total
Long Term Effectiveness Phase | 29 | 15 | 44
Discontinued during LTE Phase | 12 (41.4%) | 9 (60.0%) | 21 (47.7%)
Completed LTE Phase but did not continue to Discontinuation Phase | 10 (34.5%) | 3 (20.0%) | 13 (29.5%)
Eligible and Entered in Discontinuation Phase | 7 (24.1%) | 3 (20.0%) | 10 (22.7%)
Reasons for Discontinuing during the Long Term Effectiveness Phase
Lack of efficacy | 0 | 1 | 1
Protocol non-compliance | 1 | 2 | 3
Suicidal/homicidal ideation | 0 | 2 | 2
Other adverse event | 1 | 0 | 1
Consent / assent withdrawn by participant / caregiver | 6 | 1 | 7
Lost to follow-up | 2 | 1 | 3
Termination of study or withdrawal of participant by sponsor | 1 | 1 | 2
Other reason | 1 | 1 | 2
Reasons for not continuing to Discontinuation Phase
Ineligible for next phase | 4 | 1 | 5
Consent / assent withdrawn by participant / caregiver | 3 | 1 | 4
Termination of study or withdrawal of participant by sponsor | 3 | 1 | 4

Note: Age strata is calculated at start of the phase. Denominator is the number of participants in each age strata or total.

Other reason: Participant [▬] was found to be ineligible after enrollment.

Table 14.1.1.1.4 Participant Accountability and Study Disposition Discontinuation Phase - All Participants

| Discontinuation Phase Randomized Treatment Group | | Total
| Lithium | Placebo | Total
Discontinuation Phase | 14 | 17 | 31
Discontinued during Discontinuation Phase | 3 (21.4%) | 2 (11.8%) | 5 (16.1%)
Completed Study | 8 (57.1%) | 5 (29.4%) | 13 (41.9%)
Mood Relapse and entered Restabilization Phase | 3 (21.4%) | 10 (58.8%) | 13 (41.9%)
Reasons for Discontinuing during the Discontinuation Phase
Adverse event | 1 | 0 | 1
Lack of efficacy | 1 | 0 | 1
Protocol non-compliance | 0 | 1 | 1
Consent / assent withdrawn by participant / caregiver | 1 | 0 | 1
Other reason | 0 | 1 | 1

Note: Denominator is the number of participants in each treatment group or total.

Other reason: Participant [▬] was found to be ineligible after randomization.

Table 14.1.1.1.4A Participant Accountability and Study Disposition Discontinuation Phase - All COLT2 Participants

| Discontinuation Phase Randomized Treatment Group | | Total
| Lithium | Placebo | Total
Discontinuation Phase | 5 | 5 | 10
Discontinued during Discontinuation Phase | 1 (20.0%) | 0 | 1 (10.0%)
Completed Study | 4 (80.0%) | 2 (40.0%) | 6 (60.0%)
Mood Relapse and entered Restabilization Phase | 0 | 3 (60.0%) | 3 (30.0%)
Reasons for Discontinuing during the Discontinuation Phase
Consent / assent withdrawn by participant / caregiver | 1 | 0 | 1

Note: Denominator is the number of participants in each treatment group or total.

Table 14.1.1.1.4B Participant Accountability and Study Disposition Discontinuation Phase - All COLT1 Participants

| Discontinuation Phase Randomized Treatment Group | | Total
| Lithium | Placebo | Total
Discontinuation Phase | 9 | 12 | 21
Discontinued during Discontinuation Phase | 2 (22.2%) | 2 (16.7%) | 4 (19.0%)
Completed Study | 4 (44.4%) | 3 (25.0%) | 7 (33.3%)
Mood Relapse and entered Restabilization Phase | 3 (33.3%) | 7 (58.3%) | 10 (47.6%)
Reasons for Discontinuing during the Discontinuation Phase
Adverse event | 1 | 0 | 1
Lack of efficacy | 1 | 0 | 1
Protocol non-compliance | 0 | 1 | 1
Other reason | 0 | 1 | 1

Note: Denominator is the number of participants in each treatment group or total.

Other reason: Participant [▬] was found to be ineligible after randomization.

Table 14.1.1.1.5 Participant Accountability and Study Disposition Restabilization Phase - All Participants

| Age Strata | | Total
| 7 - 11 yrs | 12 - 17 yrs | Total
Restabilization Phase | 5 | 8 | 13
Discontinued during Restabilization Phase | 2 (40.0%) | 2 (25.0%) | 4 (30.8%)
Completed Study | 3 (60.0%) | 6 (75.0%) | 9 (69.2%)
Reasons for Discontinuing during the Restabilization Phase
Lost to follow-up | 0 | 1 | 1
Protocol non-compliance | 1 | 0 | 1
Consent / assent withdrawn by participant / caregiver | 1 | 1 | 2

Note: Age strata is calculated at start of the phase. Denominator is the number of participants in each age strata or total.

Table 14.1.1.1.5A Participant Accountability and Study Disposition Restabilization Phase - All COLT2 Participants

| Age Strata | | Total
| 7 - 11 yrs | 12 - 17 yrs | Total
Restabilization Phase | 2 | 1 | 3
Discontinued during Restabilization Phase | 1 (50.0%) | 0 | 1 (33.3%)
Completed Study | 1 (50.0%) | 1 (100.0%) | 2 (66.7%)
Reasons for Discontinuing during the Restabilization Phase
Protocol non-compliance | 1 | 0 | 1

Note: Age strata is calculated at start of the phase. Denominator is the number of participants in each age strata or total.

Table 14.1.1.1.5B Participant Accountability and Study Disposition Restabilization Phase - All COLT1 Participants

| Age Strata | | Total
| 7 - 11 yrs | 12 - 17 yrs | Total
Restabilization Phase | 3 | 7 | 10
Discontinued during Restabilization Phase | 1 (33.3%) | 2 (28.6%) | 3 (30.0%)
Completed Study | 2 (66.7%) | 5 (71.4%) | 7 (70.0%)
Reasons for Discontinuing during the Restabilization Phase
Lost to follow-up | 0 | 1 | 1
Consent / assent withdrawn by participant / caregiver | 1 | 1 | 2

Note: Age strata is calculated at start of the phase. Denominator is the number of participants in each age strata or total.

Table 14.1.1.2.1 Participant Enrollment by Site All Participants

Site | Screening; (N=153) | Efficacy Phase; (N=81) | Long-Term Effectiveness Phase; (N=44) | Discontinuation Phase; (N=31) | Restabilization Phase; (N=13)
▬ | 49 | 24 | 13 | 14 | 7
▬ | 11 | 2 | 2 | 0 | 0
▬ | 20 | 15 | 10 | 0 | 0
▬ | 7 | 5 | 3 | 1 | 0
▬ | 10 | 7 | 2 | 1 | 0
▬ | 5 | 1 | 1 | 0 | 0
▬ | 4 | 3 | 0 | 0 | 0
▬ | 17 | 10 | 4 | 12 | 4
▬ | 9 | 5 | 3 | 2 | 2
▬ | 2 | 0 | 0 | 0 | 0
▬ | 19 | 9 | 6 | 1 | 0

Table 14.1.1.2.2 Participant Enrollment by Site and Efficacy Phase Randomized Treatment Group Efficacy Phase -- All Participants

Site | Efficacy Phase Randomized Treatment Group | | Total; (N=81)
Site | Lithium; (N=53) | Placebo; (N=28) | Total; (N=81)
▬ | 14 (58.3%) | 10 (41.7%) | 24 (100.0%)
▬ | 1 (50.0%) | 1 (50.0%) | 2 (100.0%)
▬ | 9 (60.0%) | 6 (40.0%) | 15 (100.0%)
▬ | 4 (80.0%) | 1 (20.0%) | 5 (100.0%)
▬ | 4 (57.1%) | 3 (42.9%) | 7 (100.0%)
▬ | 1 (100.0%) | 0 | 1 (100.0%)
▬ | 3 (100.0%) | 0 | 3 (100.0%)
▬ | 7 (70.0%) | 3 (30.0%) | 10 (100.0%)
▬ | 5 (100.0%) | 0 | 5 (100.0%)
▬ | 5 (55.6%) | 4 (44.4%) | 9 (100.0%)

Note: N’s in the column header represent number of enrolled participants in each treatment group for all sites.

Denominator is the total number of enrolled participants at the site.

Table 14.1.1.2.3 Participant Enrollment by Site and Age Strata Long-Term Effectiveness Phase -- All Participants

Site | Age Strata | | Total; (N=44)
Site | 7-11 years; (N=29) | 12-17 years; (N=15) | Total; (N=44)
▬ | 10 (76.9%) | 3 (23.1%) | 13 (100.0%)
▬ | 1 (50.0%) | 1 (50.0%) | 2 (100.0%)
▬ | 9 (90.0%) | 1 (10.0%) | 10 (100.0%)
▬ | 1 (33.3%) | 2 (66.7%) | 3 (100.0%)
▬ | 2 (100.0%) | 0 | 2 (100.0%)
▬ | 0 | 1 (100.0%) | 1 (100.0%)
▬ | 0 | 4 (100.0%) | 4 (100.0%)
▬ | 3 (100.0%) | 0 | 3 (100.0%)
▬ | 3 (50.0%) | 3 (50.0%) | 6 (100.0%)

Note: N’s in the column header represent number of enrolled participants in each age strata for all sites.

Denominator is the total number of enrolled participants at the site.

Table 14.1.1.2.4 Participant Enrollment by Site and Discontinuation Phase Randomized Treatment Group Discontinuation Phase -- All Participants

Site | Discontinuation Phase Randomized Treatment Group | | Total; (N=31)
Site | Lithium; (N=14) | Placebo; (N=17) | Total; (N=31)
▬ | 6 (42.9%) | 8 (57.1%) | 14 (100.0%)
▬ | 1 (100.0%) | 0 | 1 (100.0%)
▬ | 1 (100.0%) | 0 | 1 (100.0%)
▬ | 6 (50.0%) | 6 (50.0%) | 12 (100.0%)
▬ | 0 | 2 (100.0%) | 2 (100.0%)
▬ | 0 | 1 (100.0%) | 1 (100.0%)

Note: N’s in the column header represent number of enrolled participants in each treatment group for all sites.

Denominator is the total number of enrolled participants at the site.

Table 14.1.1.2.5 Participant Enrollment by Site and Age Strata Restabilization Phase -- All Participants

Site | Age Strata | | Total; (N=13)
Site | 7-11 years; (N=5) | 12-17 years; (N=8) | Total; (N=13)
▬ | 1 (14.3%) | 6 (85.7%) | 7 (100.0%)
▬ | 2 (50.0%) | 2 (50.0%) | 4 (100.0%)
▬ | 2 (100.0%) | 0 | 2 (100.0%)

Note: N’s in the column header represent number of enrolled participants in each age strata for all sites.

Denominator is the total number of enrolled participants at the site.

Table 14.1.2.1 Protocol Deviations by Category and Site Screening Phase - All Participants

Site | Pts Enr | Informed consent/assent | | Eligibility/enrollment | | Randomization | | Protocol procedure/assessment | | Concomitant treatment | | Total
Site | Pts Enr | Pts with PD; N (%) | Total PDs; N | Pts with PD; N (%) | Total PDs; N | Pts with PD; N (%) | Total PDs; N | Pts with PD; N (%) | Total PDs; N | Pts with PD; N (%) | Total PDs; N | Pts with PD; N (%) | Total PDs; N
▬ | 49 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (4.1%) | 2 | 0 | 0 | 2 (4.1%) | 2
▬ | 11 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 2 | 0 | 0 | 1 (9.1%) | 2
▬ | 20 | 0 | 0 | 0 | 0 | 0 | 0 | 4 (20%) | 4 | 0 | 0 | 4 (20%) | 4
▬ | 7 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (42.9%) | 5 | 0 | 0 | 3 (42.9%) | 5
▬ | 10 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (10%) | 1 | 1 (10%) | 1 | 2 (20%) | 2
▬ | 5 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (20%) | 1 | 0 | 0 | 1 (20%) | 1
▬ | 4 | 1 (25%) | 1 | 3 (75%) | 4 | 1 (25%) | 1 | 2 (50%) | 3 | 0 | 0 | 4 (100%) | 9
▬ | 17 | 0 | 0 | 1 (5.9%) | 1 | 0 | 0 | 3 (17.6%) | 3 | 1 (5.9%) | 1 | 4 (23.5%) | 5
▬ | 9 | 0 | 0 | 2 (22.2%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (22.2%) | 2
▬ | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
▬ | 19 | 2 (10.5%) | 3 | 0 | 0 | 0 | 0 | 3 (15.8%) | 3 | 0 | 0 | 5 (26.3%) | 6
Total | 153 | 3 (2%) | 4 | 6 (3.9%) | 7 | 1 (0.7%) | 1 | 20 (13.1%) | 24 | 2 (1.3%) | 2 | 28 (18.3%) | 38

Note: Denominator is the number of participants at each site or total.

Pts=Participants Enr=Enrolled PD=Protocol Deviation

Table 14.1.2.2 Protocol Deviations by Category and Site Efficacy Phase - All Participants

Site | Pts Enr | Eligibility/enrollment | | Study medication administration | | Stopped study medication | | Unblinding | | Protocol procedure/assessment | | Concomitant treatment | | Total
Site | Pts Enr | Pts with PD; N (%) | Total PDs; N | Pts with PD; N (%) | Total PDs; N | Pts with PD; N (%) | Total PDs; N | Pts with PD; N (%) | Total PDs; N | Pts with PD; N (%) | Total PDs; N | Pts with PD; N (%) | Total PDs; N | Pts with PD; N (%) | Total PDs; N
▬ | 24 | 2 (8.3%) | 2 | 7 (29.2%) | 14 | 2 (8.3%) | 2 | 0 | 0 | 24 (100%) | 81 | 0 | 0 | 24 (100%) | 99
▬ | 2 | 0 | 0 | 2 (100%) | 3 | 0 | 0 | 0 | 0 | 2 (100%) | 4 | 0 | 0 | 2 (100%) | 7
▬ | 15 | 0 | 0 | 7 (46.7%) | 34 | 1 (6.7%) | 2 | 0 | 0 | 10 (66.7%) | 25 | 2 (13.3%) | 2 | 12 (80%) | 63
▬ | 5 | 0 | 0 | 1 (20%) | 1 | 0 | 0 | 1 (20%) | 1 | 5 (100%) | 23 | 0 | 0 | 5 (100%) | 25
▬ | 7 | 1 (14.3%) | 1 | 3 (42.9%) | 6 | 1 (14.3%) | 1 | 1 (14.3%) | 1 | 7 (100%) | 16 | 0 | 0 | 7 (100%) | 25
▬ | 1 | 0 | 0 | 1 (100%) | 3 | 0 | 0 | 0 | 0 | 1 (100%) | 4 | 0 | 0 | 1 (100%) | 7
▬ | 3 | 0 | 0 | 2 (66.7%) | 2 | 0 | 0 | 1 (33.3%) | 1 | 3 (100%) | 15 | 0 | 0 | 3 (100%) | 18
▬ | 10 | 0 | 0 | 8 (80%) | 15 | 1 (10%) | 1 | 1 (10%) | 1 | 10 (100%) | 18 | 2 (20%) | 2 | 10 (100%) | 37
▬ | 5 | 0 | 0 | 4 (80%) | 5 | 0 | 0 | 1 (20%) | 2 | 3 (60%) | 8 | 1 (20%) | 1 | 5 (100%) | 16
▬ | 9 | 0 | 0 | 3 (33.3%) | 4 | 1 (11.1%) | 2 | 1 (11.1%) | 1 | 9 (100%) | 27 | 1 (11.1%) | 1 | 9 (100%) | 35
Total | 81 | 3 (3.7%) | 3 | 38 (46.9%) | 87 | 6 (7.4%) | 8 | 6 (7.4%) | 7 | 74 (91.4%) | 221 | 6 (7.4%) | 6 | 78 (96.3%) | 332

Note: Denominator is the number of participants at each site or total.

Pts=Participants Enr=Enrolled PD=Protocol Deviation

Table 14.1.2.3 Protocol Deviations by Category and Site Long Term Effectiveness Phase - All Participants

Site | Pts Enr | Eligibility/enrollment | | Study medication administration | | Stopped study medication | | Protocol procedure/assessment | | Concomitant treatment | | Other Category | | Total
Site | Pts Enr | Pts with PD; N (%) | Total PDs; N | Pts with PD; N (%) | Total PDs; N | Pts with PD; N (%) | Total PDs; N | Pts with PD; N (%) | Total PDs; N | Pts with PD; N (%) | Total PDs; N | Pts with PD; N (%) | Total PDs; N | Pts with PD; N (%) | Total PDs; N
▬ | 13 | 1 (7.7%) | 1 | 4 (30.8%) | 5 | 0 | 0 | 12 (92.3%) | 39 | 0 | 0 | 0 | 0 | 12 (92.3%) | 45
▬ | 2 | 0 | 0 | 1 (50%) | 3 | 1 (50%) | 1 | 2 (100%) | 6 | 1 (50%) | 1 | 0 | 0 | 2 (100%) | 11
▬ | 10 | 1 (10%) | 1 | 4 (40%) | 10 | 0 | 0 | 8 (80%) | 27 | 0 | 0 | 1 (10%) | 1 | 9 (90%) | 39
▬ | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (66.7%) | 4 | 0 | 0 | 0 | 0 | 2 (66.7%) | 4
▬ | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (100%) | 7 | 0 | 0 | 0 | 0 | 2 (100%) | 7
▬ | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (100%) | 1 | 0 | 0 | 1 (100%) | 1
▬ | 4 | 0 | 0 | 2 (50%) | 5 | 0 | 0 | 4 (100%) | 10 | 0 | 0 | 0 | 0 | 4 (100%) | 15
▬ | 3 | 0 | 0 | 3 (100%) | 3 | 0 | 0 | 3 (100%) | 5 | 1 (33.3%) | 1 | 0 | 0 | 3 (100%) | 9
▬ | 6 | 1 (16.7%) | 1 | 2 (33.3%) | 2 | 0 | 0 | 4 (66.7%) | 21 | 0 | 0 | 1 (16.7%) | 1 | 6 (100%) | 25
Total | 44 | 3 (6.8%) | 3 | 16 (36.4%) | 28 | 1 (2.3%) | 1 | 37 (84.1%) | 119 | 3 (6.8%) | 3 | 2 (4.5%) | 2 | 41 (93.2%) | 156

Note: Denominator is the number of participants at each site or total.

Pts=Participants Enr=Enrolled PD=Protocol Deviation

Table 14.1.2.4 Protocol Deviations by Category and Site Discontinuation Phase - All COLT2 Participants

Site | Pts Enr | Study medication administration | | Unblinding | | Protocol procedure/assessment | | Concomitant treatment | | Total
Site | Pts Enr | Pts with PD; N (%) | Total PDs; N | Pts with PD; N (%) | Total PDs; N | Pts with PD; N (%) | Total PDs; N | Pts with PD; N (%) | Total PDs; N | Pts with PD; N (%) | Total PDs; N
▬ | 3 | 1 (33.3%) | 1 | 0 | 0 | 2 (66.7%) | 6 | 0 | 0 | 2 (66.7%) | 7
▬ | 1 | 1 (100%) | 2 | 0 | 0 | 1 (100%) | 3 | 0 | 0 | 1 (100%) | 5
▬ | 1 | 1 (100%) | 4 | 1 (100%) | 1 | 1 (100%) | 3 | 1 (100%) | 1 | 1 (100%) | 9
▬ | 3 | 2 (66.7%) | 3 | 0 | 0 | 2 (66.7%) | 6 | 0 | 0 | 3 (100%) | 9
▬ | 2 | 1 (50%) | 1 | 0 | 0 | 2 (100%) | 5 | 0 | 0 | 2 (100%) | 6
Total | 10 | 6 (60%) | 11 | 1 (10%) | 1 | 8 (80%) | 23 | 1 (10%) | 1 | 9 (90%) | 36

Note: Denominator is the number of participants at each site or total.

Pts=Participants Enr=Enrolled PD=Protocol Deviation

Does not include COLT1 participants.

Table 14.1.2.5 Protocol Deviations by Category and Site Restabilization Phase - All COLT2 Participants

Site | Pts Enr | Study medication administration | | Protocol procedure/assessment | | Total
Site | Pts Enr | Pts with PD; N (%) | Total PDs; N | Pts with PD; N (%) | Total PDs; N | Pts with PD; N (%) | Total PDs; N
▬ | 1 | 0 | 0 | 1 (100%) | 1 | 1 (100%) | 1
▬ | 2 | 1 (50%) | 1 | 2 (100%) | 3 | 2 (100%) | 4
Total | 3 | 1 (33.3%) | 1 | 3 (100%) | 4 | 3 (100%) | 5

Note: Denominator is the number of participants at each site or total.

Pts=Participants Enr=Enrolled PD=Protocol Deviation

Does not include COLT1 participants.

Table 14.1.3.1 Baseline Demographics by Randomized Treatment Group Efficacy Phase - Efficacy Population

| Randomized Treatment Group | | Total; (N=81)
| Lithium; (N=53) | Placebo; (N=28) | Total; (N=81)
Age at Baseline (years)
N | 53 | 28 | 81
Mean (SD) | 11.5 (2.9) | 11.2 (3.0) | 11.4 (2.9)
Median (Min-Max) | 11.3 (7.3 - 17.3) | 10.6 (7.0 - 16.7) | 11.3 (7.0 - 17.3)
Gender
Male | 22 (41.5%) | 15 (53.6%) | 37 (45.7%)
Female | 31 (58.5%) | 13 (46.4%) | 44 (54.3%)
Ethnicity
Hispanic or Latino | 9 (17.0%) | 3 (10.7%) | 12 (14.8%)
Not Hispanic or Latino | 43 (81.1%) | 24 (85.7%) | 67 (82.7%)
Not reported | 1 (1.9%) | 1 (3.6%) | 2 (2.5%)
Race
White or Caucasian | 30 (56.6%) | 14 (50.0%) | 44 (54.3%)
Black or African American | 15 (28.3%) | 11 (39.3%) | 26 (32.1%)
Asian | 2 (3.8%) | 0 | 2 (2.5%)
More Than 1 Race | 4 (7.5%) | 2 (7.1%) | 6 (7.4%)
Not reported | 2 (3.8%) | 1 (3.6%) | 3 (3.7%)
Tanner Stage
Stage I | 20 (37.7%) | 11 (39.3%) | 31 (38.3%)
Stage II | 7 (13.2%) | 3 (10.7%) | 10 (12.3%)
Stage III | 6 (11.3%) | 7 (25.0%) | 13 (16.0%)
Stage IV | 16 (30.2%) | 3 (10.7%) | 19 (23.5%)
Stage V | 4 (7.5%) | 4 (14.3%) | 8 (9.9%)

Note: Baseline is defined as the first visit of Efficacy Phase.

Table 14.1.3.2A Baseline Demographics by Age Strata Long-Term Effectiveness Phase - Efficacy Population

| Age Strata | | Total; (N=42)
| 7 - 11 yrs; (N=28) | 12 - 17 yrs; (N=14) | Total; (N=42)
Age at Baseline (years)
N | 28 | 14 | 42
Mean (SD) | 9.2 (1.4) | 14.4 (1.6) | 10.9 (2.9)
Median (Min-Max) | 8.8 (7.2 - 11.8) | 14.3 (12.0 - 17.2) | 10.3 (7.2 - 17.2)
Gender
Male | 14 (50.0%) | 6 (42.9%) | 20 (47.6%)
Female | 14 (50.0%) | 8 (57.1%) | 22 (52.4%)
Ethnicity
Hispanic or Latino | 5 (17.9%) | 1 (7.1%) | 6 (14.3%)
Not Hispanic or Latino | 23 (82.1%) | 12 (85.7%) | 35 (83.3%)
Not reported | 0 | 1 (7.1%) | 1 (2.4%)
Race
White or Caucasian | 18 (64.3%) | 9 (64.3%) | 27 (64.3%)
Black or African American | 8 (28.6%) | 3 (21.4%) | 11 (26.2%)
Asian | 0 | 1 (7.1%) | 1 (2.4%)
More Than 1 Race | 1 (3.6%) | 0 | 1 (2.4%)
Not reported | 1 (3.6%) | 1 (7.1%) | 2 (4.8%)
Tanner Stage
Stage I | 19 (67.9%) | 0 | 19 (45.2%)
Stage II | 2 (7.1%) | 0 | 2 (4.8%)
Stage III | 3 (10.7%) | 2 (14.3%) | 5 (11.9%)
Stage IV | 4 (14.3%) | 5 (35.7%) | 9 (21.4%)
Stage V | 0 | 6 (42.9%) | 6 (14.3%)

Note: Baseline is defined as the last visit of Efficacy Phase.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.1.3.2B Baseline Demographics by Efficacy Phase Randomized Treatment Group Long-Term Effectiveness Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=42)
| Lithium; (N=29) | Placebo; (N=13) | Total; (N=42)
Age at Baseline (years)
N | 29 | 13 | 42
Mean (SD) | 11.1 (3.1) | 10.7 (2.6) | 10.9 (2.9)
Median (Min-Max) | 10.4 (7.4 - 17.2) | 9.5 (7.2 - 14.8) | 10.3 (7.2 - 17.2)
Gender
Male | 12 (41.4%) | 8 (61.5%) | 20 (47.6%)
Female | 17 (58.6%) | 5 (38.5%) | 22 (52.4%)
Ethnicity
Hispanic or Latino | 4 (13.8%) | 2 (15.4%) | 6 (14.3%)
Not Hispanic or Latino | 25 (86.2%) | 10 (76.9%) | 35 (83.3%)
Not reported | 0 | 1 (7.7%) | 1 (2.4%)
Race
White or Caucasian | 20 (69.0%) | 7 (53.8%) | 27 (64.3%)
Black or African American | 7 (24.1%) | 4 (30.8%) | 11 (26.2%)
Asian | 1 (3.4%) | 0 | 1 (2.4%)
More Than 1 Race | 0 | 1 (7.7%) | 1 (2.4%)
Not reported | 1 (3.4%) | 1 (7.7%) | 2 (4.8%)
Tanner Stage
Stage I | 13 (44.8%) | 6 (46.2%) | 19 (45.2%)
Stage II | 1 (3.4%) | 1 (7.7%) | 2 (4.8%)
Stage III | 3 (10.3%) | 2 (15.4%) | 5 (11.9%)
Stage IV | 7 (24.1%) | 2 (15.4%) | 9 (21.4%)
Stage V | 4 (13.8%) | 2 (15.4%) | 6 (14.3%)

Note: Baseline is defined as the last visit of Efficacy Phase.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.1.3.3 Baseline Demographics by Randomized Treatment Group Discontinuation Phase - Efficacy Population

| Randomized Treatment Group | | Total; (N=31)
| Lithium; (N=14) | Placebo; (N=17) | Total; (N=31)
Age at Baseline (years)
N | 14 | 17 | 31
Mean (SD) | 11.1 (2.4) | 12.8 (2.3) | 12.0 (2.5)
Median (Min-Max) | 11.2 (8.2 - 14.3) | 12.2 (9.5 - 17.1) | 12.2 (8.2 - 17.1)
Gender
Male | 10 (71.4%) | 11 (64.7%) | 21 (67.7%)
Female | 4 (28.6%) | 6 (35.3%) | 10 (32.3%)
Ethnicity
Not Hispanic or Latino | 14 (100.0%) | 17 (100.0%) | 31 (100.0%)
Race
White or Caucasian | 13 (92.9%) | 12 (70.6%) | 25 (80.6%)
Black or African American | 1 (7.1%) | 4 (23.5%) | 5 (16.1%)
More Than 1 Race | 0 | 1 (5.9%) | 1 (3.2%)
Tanner Stage
Stage I | 5 (35.7%) | 2 (11.8%) | 7 (22.6%)
Stage II | 4 (28.6%) | 4 (23.5%) | 8 (25.8%)
Stage III | 2 (14.3%) | 5 (29.4%) | 7 (22.6%)
Stage IV | 3 (21.4%) | 3 (17.6%) | 6 (19.4%)
Stage V | 0 | 3 (17.6%) | 3 (9.7%)

Note: Baseline is defined as the last visit of the Long-Term Effectiveness Phase.

Table 14.1.3.4 Baseline Demographics by Discontinuation Phase Randomized Treatment Group Restabilization Phase - Efficacy Population

| Discontinuation Phase Randomized Treatment Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Age at Baseline (years)
N | 3 | 10 | 13
Mean (SD) | 12.0 (1.5) | 12.8 (2.5) | 12.6 (2.3)
Median (Min-Max) | 12.3 (10.3 - 13.3) | 12.9 (9.6 - 16.2) | 12.3 (9.6 - 16.2)
Gender
Male | 2 (66.7%) | 6 (60.0%) | 8 (61.5%)
Female | 1 (33.3%) | 4 (40.0%) | 5 (38.5%)
Ethnicity
Not Hispanic or Latino | 3 (100.0%) | 10 (100.0%) | 13 (100.0%)
Race
White or Caucasian | 3 (100.0%) | 9 (90.0%) | 12 (92.3%)
Black or African American | 0 | 1 (10.0%) | 1 (7.7%)
Tanner Stage
Stage I | 1 (33.3%) | 0 | 1 (7.7%)
Stage II | 1 (33.3%) | 5 (50.0%) | 6 (46.2%)
Stage III | 1 (33.3%) | 1 (10.0%) | 2 (15.4%)
Stage IV | 0 | 2 (20.0%) | 2 (15.4%)
Stage V | 0 | 2 (20.0%) | 2 (15.4%)

Note: Baseline is defined as the last visit of Discontinuation Phase.

Table 14.1.4 Disease Summary by Age Strata and Randomized Treatment Group Efficacy Phase - Efficacy Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Duration Since 1st Diagnosis (Years)
<1 year | 5 (15.6%) | 2 (11.8%) | 4 (19.0%) | 2 (18.2%) | 9 (17.0%) | 4 (14.3%)
1 | 5 (15.6%) | 4 (23.5%) | 4 (19.0%) | 3 (27.3%) | 9 (17.0%) | 7 (25.0%)
2 | 4 (12.5%) | 2 (11.8%) | 5 (23.8%) | 1 (9.1%) | 9 (17.0%) | 3 (10.7%)
3 | 11 (34.4%) | 3 (17.6%) | 1 (4.8%) | 2 (18.2%) | 12 (22.6%) | 5 (17.9%)
4 | 1 (3.1%) | 3 (17.6%) | 2 (9.5%) | 0 | 3 (5.7%) | 3 (10.7%)
5 | 4 (12.5%) | 1 (5.9%) | 0 | 0 | 4 (7.5%) | 1 (3.6%)
6 | 1 (3.1%) | 0 | 1 (4.8%) | 0 | 2 (3.8%) | 0
7 | 0 | 2 (11.8%) | 2 (9.5%) | 1 (9.1%) | 2 (3.8%) | 3 (10.7%)
8 | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
9 | 0 | 0 | 1 (4.8%) | 1 (9.1%) | 1 (1.9%) | 1 (3.6%)
10 | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
12 | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Lifetime Specifiers:
Psychotic Features
No | 29 (90.6%) | 13 (76.5%) | 18 (85.7%) | 11 (100.0%) | 47 (88.7%) | 24 (85.7%)
Yes | 3 (9.4%) | 4 (23.5%) | 3 (14.3%) | 0 | 6 (11.3%) | 4 (14.3%)
Rapid Cycling
No | 26 (81.3%) | 14 (82.4%) | 14 (66.7%) | 7 (63.6%) | 40 (75.5%) | 21 (75.0%)
Yes | 6 (18.8%) | 3 (17.6%) | 7 (33.3%) | 4 (36.4%) | 13 (24.5%) | 7 (25.0%)
Seasonal Pattern
No | 31 (96.9%) | 17 (100.0%) | 20 (95.2%) | 11 (100.0%) | 51 (96.2%) | 28 (100.0%)
Yes | 1 (3.1%) | 0 | 1 (4.8%) | 0 | 2 (3.8%) | 0
Classification of Episodes
Manic | 15 (46.9%) | 10 (58.8%) | 8 (38.1%) | 8 (72.7%) | 23 (43.4%) | 18 (64.3%)
Mixed | 17 (53.1%) | 7 (41.2%) | 13 (61.9%) | 3 (27.3%) | 30 (56.6%) | 10 (35.7%)
WASI IQ Score
Sum of T Scores
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 108.7 (30.8) | 105.3 (33.6) | 100.6 (13.6) | 97.8 (19.2) | 105.5 (25.5) | 102.4 (28.6)
Median (Min-Max) | 102.0 (73.0 - 217.0) | 91.0 (80.0 - 218.0) | 101.0 (65.0 - 129.0) | 107.0 (65.0 - 120.0) | 102.0 (65.0 - 217.0) | 98.0 (65.0 - 218.0)
IQ Score
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 102.8 (16.8) | 99.2 (15.2) | 100.7 (11.2) | 99.0 (15.2) | 101.9 (14.7) | 99.1 (14.9)
Median (Min-Max) | 100.0 (79.0 - 145.0) | 92.0 (84.0 - 145.0) | 100.0 (75.0 - 126.0) | 106.0 (75.0 - 118.0) | 100.0 (75.0 - 145.0) | 97.5 (75.0 - 145.0)
Number of Participants with Co-morbid Psychiatric Disorders | 25 (78.1%) | 13 (76.5%) | 14 (66.7%) | 6 (54.5%) | 39 (73.6%) | 19 (67.9%)

Note: The percentages are based on the total number of safety participants in each treatment group or total.

Table 14.1.5.1 Medical History by MedDRA System Organ Class, Preferred Term, Age Strata and Efficacy Phase Randomized Treatment Group Efficacy Phase - Efficacy Population

System Organ Class (SOC)/Preferred Term (PT) | 7 - 11 yrs | | 12 - 17 yrs | | Total
System Organ Class (SOC)/Preferred Term (PT) | Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Blood and lymphatic system disorders | 1 (3.1%) | 0 | 1 (4.8%) | 1 (9.1%) | 2 (3.8%) | 1 (3.6%)
Anaemia | 1 (3.1%) | 0 | 1 (4.8%) | 1 (9.1%) | 2 (3.8%) | 1 (3.6%)
Cardiac disorders | 1 (3.1%) | 2 (11.8%) | 0 | 0 | 1 (1.9%) | 2 (7.1%)
Cardiac septal defect | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Pulmonary valve stenosis | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Tachycardia | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Congenital, familial and genetic disorders | 1 (3.1%) | 0 | 1 (4.8%) | 2 (18.2%) | 2 (3.8%) | 2 (7.1%)
Heart disease congenital | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Klippel-Trenaunay syndrome | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Sickle cell trait | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Talipes | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Ear and labyrinth disorders | 0 | 3 (17.6%) | 2 (9.5%) | 0 | 2 (3.8%) | 3 (10.7%)
Cerumen impaction | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Deafness | 0 | 2 (11.8%) | 1 (4.8%) | 0 | 1 (1.9%) | 2 (7.1%)
Ear pain | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Endocrine disorders | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Thyroid disorder | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Eye disorders | 6 (18.8%) | 3 (17.6%) | 6 (28.6%) | 2 (18.2%) | 12 (22.6%) | 5 (17.9%)
Amblyopia | 1 (3.1%) | 0 | 1 (4.8%) | 0 | 2 (3.8%) | 0
Astigmatism | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Binocular eye movement disorder | 1 (3.1%) | 0 | 1 (4.8%) | 0 | 2 (3.8%) | 0
Blindness | 0 | 0 | 2 (9.5%) | 0 | 2 (3.8%) | 0
Dacryostenosis acquired | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Entropion | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Hypermetropia | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Myopia | 2 (6.3%) | 2 (11.8%) | 2 (9.5%) | 1 (9.1%) | 4 (7.5%) | 3 (10.7%)
Retinopathy of prematurity | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Gastrointestinal disorders | 8 (25.0%) | 6 (35.3%) | 2 (9.5%) | 1 (9.1%) | 10 (18.9%) | 7 (25.0%)
Abdominal pain | 1 (3.1%) | 0 | 0 | 1 (9.1%) | 1 (1.9%) | 1 (3.6%)
Abdominal pain upper | 3 (9.4%) | 0 | 0 | 0 | 3 (5.7%) | 0
Constipation | 2 (6.3%) | 1 (5.9%) | 0 | 0 | 2 (3.8%) | 1 (3.6%)
Diarrhoea | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Dyspepsia | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Flatulence | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Gastrooesophageal reflux disease | 3 (9.4%) | 3 (17.6%) | 0 | 0 | 3 (5.7%) | 3 (10.7%)
Reflux gastritis | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Umbilical hernia | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
General disorders and administration site conditions | 2 (6.3%) | 1 (5.9%) | 0 | 2 (18.2%) | 2 (3.8%) | 3 (10.7%)
Adverse drug reaction | 2 (6.3%) | 0 | 0 | 1 (9.1%) | 2 (3.8%) | 1 (3.6%)
Fatigue | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Hernia | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Immune system disorders | 12 (37.5%) | 1 (5.9%) | 5 (23.8%) | 3 (27.3%) | 17 (32.1%) | 4 (14.3%)
Allergy to animal | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Drug hypersensitivity | 0 | 0 | 0 | 2 (18.2%) | 0 | 2 (7.1%)
Food allergy | 3 (9.4%) | 0 | 1 (4.8%) | 2 (18.2%) | 4 (7.5%) | 2 (7.1%)
House dust allergy | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Hypersensitivity | 2 (6.3%) | 0 | 1 (4.8%) | 0 | 3 (5.7%) | 0
Seasonal allergy | 6 (18.8%) | 1 (5.9%) | 3 (14.3%) | 0 | 9 (17.0%) | 1 (3.6%)
Infections and infestations | 14 (43.8%) | 11 (64.7%) | 4 (19.0%) | 5 (45.5%) | 18 (34.0%) | 16 (57.1%)
Appendicitis | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Bronchitis | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Croup infectious | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Ear infection | 7 (21.9%) | 3 (17.6%) | 1 (4.8%) | 2 (18.2%) | 8 (15.1%) | 5 (17.9%)
Erythema infectiosum | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Folliculitis | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Furuncle | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Hordeolum | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Molluscum contagiosum | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Oral herpes | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Pharyngitis streptococcal | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Pneumonia | 3 (9.4%) | 2 (11.8%) | 0 | 0 | 3 (5.7%) | 2 (7.1%)
Respiratory syncytial virus infection | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Sinusitis | 3 (9.4%) | 3 (17.6%) | 2 (9.5%) | 1 (9.1%) | 5 (9.4%) | 4 (14.3%)
Tinea capitis | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Tinea infection | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Tinea versicolour | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Upper respiratory tract infection | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Urinary tract infection | 6 (18.8%) | 3 (17.6%) | 2 (9.5%) | 1 (9.1%) | 8 (15.1%) | 4 (14.3%)
Injury, poisoning and procedural complications | 7 (21.9%) | 2 (11.8%) | 5 (23.8%) | 4 (36.4%) | 12 (22.6%) | 6 (21.4%)
Animal bite | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Foot fracture | 2 (6.3%) | 1 (5.9%) | 0 | 1 (9.1%) | 2 (3.8%) | 2 (7.1%)
Hand fracture | 1 (3.1%) | 0 | 1 (4.8%) | 2 (18.2%) | 2 (3.8%) | 2 (7.1%)
Humerus fracture | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Joint dislocation | 1 (3.1%) | 0 | 1 (4.8%) | 0 | 2 (3.8%) | 0
Laceration | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Meniscus lesion | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Metal poisoning | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Tibia fracture | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Upper limb fracture | 2 (6.3%) | 0 | 1 (4.8%) | 0 | 3 (5.7%) | 0
Wrist fracture | 0 | 1 (5.9%) | 1 (4.8%) | 1 (9.1%) | 1 (1.9%) | 2 (7.1%)
Investigations | 5 (15.6%) | 2 (11.8%) | 2 (9.5%) | 3 (27.3%) | 7 (13.2%) | 5 (17.9%)
Blood cholesterol increased | 1 (3.1%) | 1 (5.9%) | 1 (4.8%) | 1 (9.1%) | 2 (3.8%) | 2 (7.1%)
Blood triglycerides increased | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Body height below normal | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Cardiac murmur | 4 (12.5%) | 1 (5.9%) | 2 (9.5%) | 1 (9.1%) | 6 (11.3%) | 2 (7.1%)
Metabolism and nutrition disorders | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Obesity | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Musculoskeletal and connective tissue disorders | 1 (3.1%) | 0 | 1 (4.8%) | 1 (9.1%) | 2 (3.8%) | 1 (3.6%)
Facial bones fracture | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Joint hyperextension | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Muscular weakness | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Nervous system disorders | 10 (31.3%) | 5 (29.4%) | 9 (42.9%) | 3 (27.3%) | 19 (35.8%) | 8 (28.6%)
Febrile convulsion | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Headache | 8 (25.0%) | 5 (29.4%) | 7 (33.3%) | 2 (18.2%) | 15 (28.3%) | 7 (25.0%)
Hypoaesthesia | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Migraine | 2 (6.3%) | 0 | 2 (9.5%) | 0 | 4 (7.5%) | 0
Migraine with aura | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Sinus headache | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Syncope | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Psychiatric disorders | 5 (15.6%) | 2 (11.8%) | 4 (19.0%) | 2 (18.2%) | 9 (17.0%) | 4 (14.3%)
Hallucination | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Insomnia | 4 (12.5%) | 1 (5.9%) | 2 (9.5%) | 0 | 6 (11.3%) | 1 (3.6%)
Intentional self-injury | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Learning disorder | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Psychotic disorder | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Tic | 0 | 1 (5.9%) | 0 | 1 (9.1%) | 0 | 2 (7.1%)
Renal and urinary disorders | 8 (25.0%) | 7 (41.2%) | 7 (33.3%) | 2 (18.2%) | 15 (28.3%) | 9 (32.1%)
Dysuria | 1 (3.1%) | 1 (5.9%) | 0 | 0 | 1 (1.9%) | 1 (3.6%)
Enuresis | 7 (21.9%) | 7 (41.2%) | 7 (33.3%) | 2 (18.2%) | 14 (26.4%) | 9 (32.1%)
Nephrolithiasis | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Pollakiuria | 1 (3.1%) | 1 (5.9%) | 0 | 0 | 1 (1.9%) | 1 (3.6%)
Reproductive system and breast disorders | 2 (6.3%) | 1 (5.9%) | 9 (42.9%) | 1 (9.1%) | 11 (20.8%) | 2 (7.1%)
Dysmenorrhoea | 2 (6.3%) | 0 | 8 (38.1%) | 1 (9.1%) | 10 (18.9%) | 1 (3.6%)
Ovarian cyst | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Testicular disorder | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Respiratory, thoracic and mediastinal disorders | 19 (59.4%) | 8 (47.1%) | 6 (28.6%) | 5 (45.5%) | 25 (47.2%) | 13 (46.4%)
Asthma | 13 (40.6%) | 5 (29.4%) | 4 (19.0%) | 3 (27.3%) | 17 (32.1%) | 8 (28.6%)
Epistaxis | 4 (12.5%) | 2 (11.8%) | 2 (9.5%) | 2 (18.2%) | 6 (11.3%) | 4 (14.3%)
Nasal congestion | 1 (3.1%) | 1 (5.9%) | 0 | 0 | 1 (1.9%) | 1 (3.6%)
Oropharyngeal pain | 2 (6.3%) | 0 | 2 (9.5%) | 2 (18.2%) | 4 (7.5%) | 2 (7.1%)
Pneumothorax | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Rhinitis allergic | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Sinus congestion | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Skin and subcutaneous tissue disorders | 10 (31.3%) | 6 (35.3%) | 5 (23.8%) | 3 (27.3%) | 15 (28.3%) | 9 (32.1%)
Acne | 0 | 1 (5.9%) | 0 | 2 (18.2%) | 0 | 3 (10.7%)
Alopecia | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Dermatitis contact | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Dry skin | 1 (3.1%) | 2 (11.8%) | 0 | 0 | 1 (1.9%) | 2 (7.1%)
Eczema | 6 (18.8%) | 3 (17.6%) | 2 (9.5%) | 0 | 8 (15.1%) | 3 (10.7%)
Rash | 1 (3.1%) | 0 | 2 (9.5%) | 0 | 3 (5.7%) | 0
Skin hypopigmentation | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Skin irritation | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Skin ulcer | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Vitiligo | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Social circumstances | 1 (3.1%) | 1 (5.9%) | 0 | 0 | 1 (1.9%) | 1 (3.6%)
Corrective lens user | 1 (3.1%) | 1 (5.9%) | 0 | 0 | 1 (1.9%) | 1 (3.6%)
Surgical and medical procedures | 2 (6.3%) | 1 (5.9%) | 2 (9.5%) | 1 (9.1%) | 4 (7.5%) | 2 (7.1%)
Antibiotic therapy | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Drug therapy | 1 (3.1%) | 1 (5.9%) | 1 (4.8%) | 1 (9.1%) | 2 (3.8%) | 2 (7.1%)
Tonsillectomy | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Vascular disorders | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Hypertension | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0

Note: The percentages are based on the total number of efficacy participants in each age/treatment group.

Participants are counted once at each SOC and PT level.

Table 14.1.5.2 Surgical History by MedDRA System Organ Class, Preferred Term, Age Strata and Efficacy Phase Randomized Treatment Group Efficacy Phase - Efficacy Population

System Organ Class (SOC)/Preferred Term (PT) | 7 - 11 yrs | | 12 - 17 yrs | | Total
System Organ Class (SOC)/Preferred Term (PT) | Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Congenital, familial and genetic disorders | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Syndactyly | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Injury, poisoning and procedural complications | 0 | 0 | 2 (9.5%) | 0 | 2 (3.8%) | 0
Hand fracture | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Skin injury | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Musculoskeletal and connective tissue disorders | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Upper limb fracture | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Reproductive system and breast disorders | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Vulvovaginal adhesion | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Surgical and medical procedures | 9 (28.1%) | 5 (29.4%) | 4 (19.0%) | 2 (18.2%) | 13 (24.5%) | 7 (25.0%)
Adenoidectomy | 1 (3.1%) | 1 (5.9%) | 0 | 0 | 1 (1.9%) | 1 (3.6%)
Adenotonsillectomy | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Appendicectomy | 2 (6.3%) | 0 | 1 (4.8%) | 0 | 3 (5.7%) | 0
Ear tube insertion | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Hernia repair | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Inguinal hernia repair | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Myringotomy | 0 | 1 (5.9%) | 0 | 1 (9.1%) | 0 | 2 (7.1%)
Rhinoplasty | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Strabismus correction | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Surgery | 2 (6.3%) | 0 | 1 (4.8%) | 0 | 3 (5.7%) | 0
Tonsillectomy | 4 (12.5%) | 0 | 1 (4.8%) | 1 (9.1%) | 5 (9.4%) | 1 (3.6%)
Ureteric repair | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0

Note: The percentages are based on the total number of efficacy participants in each age/treatment group.

Participants are counted once at each SOC and PT level.

Table 14.2.1.1.1 Primary Efficacy Endpoint: Young Mania Rating Scale (YMRS) by Efficacy Phase Randomized Treatment Group Efficacy Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=81) | P-Value^1^
| Lithium; (N=53) | Placebo; (N=28) | Total; (N=81) | P-Value^1^
YMRS Total Score at Baseline
N | 53 | 28 | 81
Mean (SD) | 29.5 (5.6) | 30.0 (6.0) | 29.7 (5.7)
Median (Min-Max) | 29.0 (21.0 - 43.0) | 29.5 (21.0 - 49.0) | 29.0 (21.0 - 49.0)
YMRS Total Score at Week 8/End-of-Phase/LOCF
N | 53 | 28 | 81
Mean (SD) | 17.8 (11.0) | 22.3 (9.7) | 19.4 (10.7)
Median (Min-Max) | 17.0 (0.0 - 49.0) | 23.5 (8.0 - 42.0) | 19.0 (0.0 - 49.0)
Change in YMRS Total Score from Baseline to Week 8/End-of-Phase
N | 53 | 28 | 81 | 0.031
Mean (SD) | −11.7 (11.4) | −7.8 (9.8) | −10.3 (11.0)
Median (Min-Max) | −13.0 (−35.0 - 28.0) | −7.5 (−27.0 - 15.0) | −10.0 (−35.0 - 28.0)

Note: Baseline is defined as the first visit of Efficacy Phase.

Change score is week 8/end of phase value minus baseline value.

1 P-value is calculated from linear model for the treatment effect of change in YMRS Total Score from Baseline to Week 8/End-of-Phase.

Table 14.2.1.1.2 Primary Efficacy Endpoint: Young Mania Rating Scale (YMRS) by Efficacy Phase Randomized Treatment Group Efficacy Phase - Per Protocol Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=51) | P-Value^1^
| Lithium; (N=37) | Placebo; (N=14) | Total; (N=51) | P-Value^1^
YMRS Total Score at Baseline
N | 37 | 14 | 51
Mean (SD) | 29.9 (6.1) | 30.8 (6.8) | 30.2 (6.3)
Median (Min-Max) | 31.0 (21.0 - 43.0) | 29.5 (21.0 - 49.0) | 30.0 (21.0 - 49.0)
YMRS Total Score at Week 8/End-of-Phase/LOCF
N | 37 | 14 | 51
Mean (SD) | 19.0 (11.3) | 23.1 (10.6) | 20.1 (11.2)
Median (Min-Max) | 20.0 (0.0 - 49.0) | 24.0 (9.0 - 42.0) | 21.0 (0.0 - 49.0)
Change in YMRS Total Score from Baseline to Week 8/End-of-Phase
N | 37 | 14 | 51 | 0.295
Mean (SD) | −10.9 (12.0) | −7.7 (10.4) | −10.0 (11.6)
Median (Min-Max) | −9.0 (−32.0 - 28.0) | −8.0 (−23.0 - 15.0) | −9.0 (−32.0 - 28.0)

Note: Baseline is defined as the first visit of Efficacy Phase.

Change score is week 8/end of phase value minus baseline value.

1 P-value is calculated from linear model for the treatment effect of change in YMRS Total Score from Baseline to Week 8/End-of-Phase.

Table 14.2.1.1.3 Primary Efficacy Endpoint: Young Mania Rating Scale (YMRS) by Efficacy Phase Randomized Treatment Group Efficacy Phase - Revised Per Protocol Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=73) | P-Value^1^
| Lithium; (N=49) | Placebo; (N=24) | Total; (N=73) | P-Value^1^
YMRS Total Score at Baseline
N | 49 | 24 | 73
Mean (SD) | 29.8 (5.7) | 30.3 (6.0) | 30.0 (5.8)
Median (Min-Max) | 29.0 (21.0 - 43.0) | 29.5 (21.0 - 49.0) | 29.0 (21.0 - 49.0)
YMRS Total Score at Week 8/End-of-Phase/LOCF
N | 49 | 24 | 73
Mean (SD) | 18.4 (11.1) | 23.7 (9.5) | 20.2 (10.9)
Median (Min-Max) | 17.0 (0.0 - 49.0) | 24.5 (9.0 - 42.0) | 20.0 (0.0 - 49.0)
Change in YMRS Total Score from Baseline to Week 8/End-of-Phase
N | 49 | 24 | 73 | 0.021
Mean (SD) | −11.4 (11.6) | −6.6 (9.9) | −9.8 (11.3)
Median (Min-Max) | −10.0 (−35.0 - 28.0) | −5.0 (−27.0 - 15.0) | −9.0 (−35.0 - 28.0)

Note: Baseline is defined as the first visit of Efficacy Phase.

Change score is week 8/end of phase value minus baseline value.

1 P-value is calculated from linear model for the treatment effect of change in YMRS Total Score from Baseline to Week 8/End-of-Phase.

Table 14.2.1.2.1 Secondary Efficacy Endpoint: Response, Remission, Improvement and Discontinuation by Efficacy Phase Randomized Treatment Group Efficacy Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=81) | P-Value^1^
| Lithium; (N=53) | Placebo; (N=28) | Total; (N=81) | P-Value^1^
YMRS Response
Non-response | 19 (35.8%) | 15 (53.6%) | 34 (42.0%) | 0.304
Partial Response | 17 (32.1%) | 7 (25.0%) | 24 (29.6%)
Complete Response | 17 (32.1%) | 6 (21.4%) | 23 (28.4%)
YMRS Remission
No remission | 39 (73.6%) | 24 (85.7%) | 63 (77.8%) | 0.215
Remission | 14 (26.4%) | 4 (14.3%) | 18 (22.2%)
YMRS Improvement
Reduction <25% | 16 (30.2%) | 15 (53.6%) | 31 (38.3%) | 0.112
Reduction = 25-49% | 17 (32.1%) | 5 (17.9%) | 22 (27.2%)
Reduction ≥50% | 20 (37.7%) | 8 (28.6%) | 28 (34.6%)
Discontinuation due to any cause during the Efficacy Phase
Completed Efficacy Phase | 37 (69.8%) | 21 (75.0%) | 58 (71.6%) | 0.624
Terminated for any reason | 16 (30.2%) | 7 (25.0%) | 23 (28.4%)
Discontinuation due to lack of efficacy during the Efficacy Phase
No termination due to lack of efficacy | 50 (94.3%) | 27 (96.4%) | 77 (95.1%) | 0.682
Terminated due to lack of efficacy | 3 (5.7%) | 1 (3.6%) | 4 (4.9%)

Note:

1 P-value is calculated from CMH Test for the treatment effect.

Table 14.2.1.2.2 Secondary Efficacy Endpoint: Young Mania Rating Scale (YMRS) by Efficacy Phase Randomized Treatment Group Efficacy Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=81) | P-Value^1^
| Lithium; (N=53) | Placebo; (N=28) | Total; (N=81) | P-Value^1^
Parent Score at Baseline
N | 53 | 27 | 80
Mean (SD) | 27.7 (6.1) | 28.6 (6.2) | 28.0 (6.1)
Median (Min-Max) | 27.0 (16.0 - 41.0) | 29.0 (16.0 - 47.0) | 27.0 (16.0 - 47.0)
Parent Score at Week 8/End-of-Phase/LOCF
N | 53 | 27 | 80
Mean (SD) | 16.8 (11.0) | 21.4 (10.9) | 18.4 (11.1)
Median (Min-Max) | 15.0 (0.0 - 49.0) | 23.0 (7.0 - 43.0) | 17.0 (0.0 - 49.0)
Change in Parent Score from Baseline to Week 8/End-of-Phase/LOCF
N | 53 | 26 | 79 | 0.052
Mean (SD) | −10.9 (12.0) | −7.7 (10.3) | −9.8 (11.5)
Median (Min-Max) | −10.0 (−35.0 - 32.0) | −5.0 (−27.0 - 15.0) | −9.0 (−35.0 - 32.0)
Child Score at Baseline
N | 52 | 28 | 80
Mean (SD) | 20.1 (10.8) | 15.0 (9.7) | 18.3 (10.7)
Median (Min-Max) | 22.0 (0.0 - 36.0) | 17.5 (0.0 - 31.0) | 21.0 (0.0 - 36.0)
Child Score at Week 8/End-of-Phase/LOCF
N | 53 | 28 | 81
Mean (SD) | 12.8 (10.9) | 12.5 (9.5) | 12.7 (10.3)
Median (Min-Max) | 11.0 (0.0 - 39.0) | 10.0 (0.0 - 32.0) | 11.0 (0.0 - 39.0)
Change in Child Score from Baseline to Week 8/End-of-Phase/LOCF
N | 52 | 28 | 80 | 0.277
Mean (SD) | −7.0 (11.3) | −2.6 (11.8) | −5.5 (11.6)
Median (Min-Max) | −6.0 (−30.0 - 39.0) | −4.0 (−17.0 - 32.0) | −4.5 (−30.0 - 39.0)

Note: Baseline is defined as the first visit of Efficacy Phase.

Change score is week 8/end of phase value minus baseline value.

1 P-value is calculated from linear model for the treatment effect of change in YMRS Score from Baseline to Week 8/End-of-Phase.

Table 14.2.1.2.3 Secondary Efficacy Endpoint: Children Depression Rating Scale-Revised (CDRS-R) by Efficacy Phase Randomized Treatment Group Efficacy Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=81) | P-Value^1^
| Lithium; (N=53) | Placebo; (N=28) | Total; (N=81) | P-Value^1^
Total Score at Baseline
N | 53 | 28 | 81
Mean (SD) | 35.8 (10.1) | 38.2 (10.2) | 36.6 (10.2)
Median (Min-Max) | 34.0 (20.0 - 65.0) | 35.0 (25.0 - 59.0) | 35.0 (20.0 - 65.0)
Total Score at Week 8/End-of-Phase/LOCF
N | 53 | 28 | 81
Mean (SD) | 30.3 (11.5) | 31.4 (11.1) | 30.7 (11.3)
Median (Min-Max) | 28.0 (17.0 - 72.0) | 26.5 (20.0 - 64.0) | 28.0 (17.0 - 72.0)
Change in Total Score from Baseline to Week 8/End-of-Phase/LOCF
N | 53 | 28 | 81 | 0.489
Mean (SD) | −5.5 (12.2) | −6.8 (8.5) | −5.9 (11.0)
Median (Min-Max) | −7.0 (−27.0 - 28.0) | −7.0 (−23.0 - 10.0) | −7.0 (−27.0 - 28.0)

Note: Baseline is defined as the first visit of Efficacy Phase.

Change score is week 8/end of phase value minus baseline value.

1 P-value is calculated from linear model for the treatment effect of change from Baseline score to Week 8/End-of-Phase score.

Table 14.2.1.2.4 Secondary Efficacy Endpoint: Children’s Global Assessment Scale (CGAS) by Efficacy Phase Randomized Treatment Group Efficacy Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=81) | P-Value^1^
| Lithium; (N=53) | Placebo; (N=28) | Total; (N=81) | P-Value^1^
Total Score at Baseline
N | 53 | 28 | 81
Mean (SD) | 49.8 (6.7) | 50.1 (6.1) | 49.9 (6.4)
Median (Min-Max) | 50.0 (38.0 - 71.0) | 50.0 (41.0 - 71.0) | 50.0 (38.0 - 71.0)
Total Score at Week 8/End-of-Phase/LOCF
N | 52 | 26 | 78
Mean (SD) | 59.5 (14.1) | 58.8 (10.5) | 59.3 (13.0)
Median (Min-Max) | 60.0 (20.0 - 90.0) | 56.5 (42.0 - 85.0) | 60.0 (20.0 - 90.0)
Change in Total Score from Baseline to Week 8/End-of-Phase/LOCF
N | 52 | 26 | 78 | 0.630
Mean (SD) | 9.5 (13.8) | 8.5 (12.1) | 9.2 (13.2)
Median (Min-Max) | 10.0 (−35.0 - 40.0) | 5.0 (−20.0 - 34.0) | 7.0 (−35.0 - 40.0)

Note: Baseline is defined as the first visit of Efficacy Phase.

Change score is week 8/end of phase value minus baseline value.

1 P-value is calculated from linear model for the treatment effect of change from Baseline score to Week 8/End-of-Phase score.

Table 14.2.1.2.5 Secondary Efficacy Endpoint: Clinical Global Impression Scale (CGI) by Efficacy Phase Randomized Treatment Group Efficacy Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=81) | P-Value^1^
| Lithium; (N=53) | Placebo; (N=28) | Total; (N=81) | P-Value^1^
CGI-Severity Mania at Baseline
3-Mildly ill | 2 (3.8%) | 1 (3.6%) | 3 (3.7%)
4-Moderately ill | 25 (47.2%) | 11 (39.3%) | 36 (44.4%)
5-Markedly ill | 22 (41.5%) | 14 (50.0%) | 36 (44.4%)
6-Severely ill | 4 (7.5%) | 2 (7.1%) | 6 (7.4%)
CGI-Severity Mania at Week 8/End-of-Phase/LOCF
1-Normal, not at all ill | 12 (22.6%) | 1 (3.6%) | 13 (16.0%)
2-Borderline ill | 7 (13.2%) | 6 (21.4%) | 13 (16.0%)
3-Mildly ill | 14 (26.4%) | 3 (10.7%) | 17 (21.0%)
4-Moderately ill | 14 (26.4%) | 12 (42.9%) | 26 (32.1%)
5-Markedly ill | 5 (9.4%) | 5 (17.9%) | 10 (12.3%)
6-Severely ill | 1 (1.9%) | 0 | 1 (1.2%)
7-Among the most extremely ill | 0 | 1 (3.6%) | 1 (1.2%)
Change in CGI-Severity Mania from Baseline to Week 8/End-of-Phase/LOCF
Failure | 30 (56.6%) | 19 (67.9%) | 49 (60.5%) | 0.368
Success | 23 (43.4%) | 9 (32.1%) | 32 (39.5%)
CGI-Severity Depression at Baseline
1-Normal, not at all ill | 3 (5.7%) | 1 (3.6%) | 4 (4.9%)
2-Borderline ill | 17 (32.1%) | 5 (17.9%) | 22 (27.2%)
3-Mildly ill | 16 (30.2%) | 11 (39.3%) | 27 (33.3%)
4-Moderately ill | 13 (24.5%) | 8 (28.6%) | 21 (25.9%)
5-Markedly ill | 4 (7.5%) | 3 (10.7%) | 7 (8.6%)
CGI-Severity Depression at Week 8/End-of-Phase/LOCF
1-Normal, not at all ill | 17 (32.1%) | 7 (25.0%) | 24 (29.6%)
2-Borderline ill | 15 (28.3%) | 6 (21.4%) | 21 (25.9%)
3-Mildly ill | 12 (22.6%) | 7 (25.0%) | 19 (23.5%)
4-Moderately ill | 4 (7.5%) | 6 (21.4%) | 10 (12.3%)
5-Markedly ill | 3 (5.7%) | 2 (7.1%) | 5 (6.2%)
6-Severely ill | 2 (3.8%) | 0 | 2 (2.5%)
Change in CGI-Severity Depression from Baseline to Week 8/End-of-Phase/LOCF
Failure | 20 (37.7%) | 15 (53.6%) | 35 (43.2%) | 0.191
Success | 33 (62.3%) | 13 (46.4%) | 46 (56.8%)
CGI-Severity Overall Illness at Baseline
4-Moderately ill | 27 (50.9%) | 12 (42.9%) | 39 (48.1%)
5-Markedly ill | 22 (41.5%) | 15 (53.6%) | 37 (45.7%)
6-Severely ill | 4 (7.5%) | 1 (3.6%) | 5 (6.2%)
CGI-Severity Overall Illness at Week 8/End-of-Phase/LOCF
1-Normal, not at all ill | 10 (18.9%) | 1 (3.6%) | 11 (13.6%)
2-Borderline ill | 5 (9.4%) | 5 (17.9%) | 10 (12.3%)
3-Mildly ill | 16 (30.2%) | 2 (7.1%) | 18 (22.2%)
4-Moderately ill | 13 (24.5%) | 15 (53.6%) | 28 (34.6%)
5-Markedly ill | 6 (11.3%) | 4 (14.3%) | 10 (12.3%)
6-Severely ill | 3 (5.7%) | 1 (3.6%) | 4 (4.9%)
Change in CGI-Severity Overall Illness from Baseline to Week 8/End-of-Phase/LOCF
Failure | 32 (60.4%) | 22 (78.6%) | 54 (66.7%) | 0.144
Success | 21 (39.6%) | 6 (21.4%) | 27 (33.3%)
CGI-Improvement Mania at Week 8/End-of-Phase/LOCF
Very much improved | 11 (20.8%) | 3 (10.7%) | 14 (17.3%)
Much improved | 16 (30.2%) | 5 (17.9%) | 21 (25.9%)
Minimally improved | 13 (24.5%) | 10 (35.7%) | 23 (28.4%)
No change | 9 (17.0%) | 6 (21.4%) | 15 (18.5%)
Minimally worse | 0 | 2 (7.1%) | 2 (2.5%)
Much worse | 4 (7.5%) | 1 (3.6%) | 5 (6.2%)
Very much worse | 0 | 1 (3.6%) | 1 (1.2%)
CGI-Improvement Mania at Week 8/End-of-Phase/LOCF
Failure | 26 (49.1%) | 20 (71.4%) | 46 (56.8%) | 0.044
Success | 27 (50.9%) | 8 (28.6%) | 35 (43.2%)
CGI-Improvement Depression at Week 8/End-of-Phase/LOCF
Very much improved | 9 (17.0%) | 2 (7.1%) | 11 (13.6%)
Much improved | 12 (22.6%) | 6 (21.4%) | 18 (22.2%)
Minimally improved | 10 (18.9%) | 6 (21.4%) | 16 (19.8%)
No change | 12 (22.6%) | 12 (42.9%) | 24 (29.6%)
Minimally worse | 7 (13.2%) | 0 | 7 (8.6%)
Much worse | 2 (3.8%) | 2 (7.1%) | 4 (4.9%)
Very much worse | 1 (1.9%) | 0 | 1 (1.2%)
CGI-Improvement Depression at Week 8/End-of-Phase/LOCF
Failure | 32 (60.4%) | 20 (71.4%) | 52 (64.2%) | 0.390
Success | 21 (39.6%) | 8 (28.6%) | 29 (35.8%)
CGI-Improvement Overall Illness at Week 8/End-of-Phase/LOCF
Very much improved | 10 (18.9%) | 2 (7.1%) | 12 (14.8%)
Much improved | 15 (28.3%) | 4 (14.3%) | 19 (23.5%)
Minimally improved | 12 (22.6%) | 11 (39.3%) | 23 (28.4%)
No change | 8 (15.1%) | 8 (28.6%) | 16 (19.8%)
Minimally worse | 1 (1.9%) | 1 (3.6%) | 2 (2.5%)
Much worse | 7 (13.2%) | 1 (3.6%) | 8 (9.9%)
Very much worse | 0 | 1 (3.6%) | 1 (1.2%)
CGI-Improvement Overall Illness at Week 8/End-of-Phase/LOCF
Failure | 28 (52.8%) | 22 (78.6%) | 50 (61.7%) | 0.026
Success | 25 (47.2%) | 6 (21.4%) | 31 (38.3%)

Note: Baseline is defined as the first visit of Efficacy Phase.

Change score is week 8/end of phase value minus baseline value.

1 P-value is calculated from Logistic Regression Model for the treatment effect.

CGI-Severity Success is defined as: baseline value of 1,2 with change to LOCF of <= 0; baseline value of 3 with change of <= −1; baseline of 4,5,6 with change of <= −2 & LOCF score of 1,2,3.

CGI-Improvement Success is defined as: LOCF score of very much improved or much improved.

Table 14.2.1.2.6 Secondary Efficacy Endpoint: Time to Any Discontinuation by Efficacy Phase Randomized Treatment Group Efficacy Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group
| Lithium; (N=53) | Placebo; (N=28)
Number of Participants
Number of Censored Participants | 37 (69.8%) | 21 (75.0%)
Number of Non Censored Participants | 16 (30.2%) | 7 (25.0%)
Time to event (Time to Any Discontinuation in Days)
Median (95% CI) | . | .
25% Percentile | 40.0 (21.00, .) | . (13.00, .)
75% Percentile | . | .
Range | (10, 56) | (9, 56)
Stratified Analysis by treatment
Hazard Ratio (Relative to Placebo) | 1.24
(95% CI) | (0.51, 3.01)
p value ^1^ | 0.6357

Note:

1 P-value is calculated from the Cox proportional hazards regression model.

Table 14.2.1.2.7 Secondary Efficacy Endpoint: Time to Discontinuation For Lack of Efficacy by Efficacy Phase Randomized Treatment Group Efficacy Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group
| Lithium; (N=53) | Placebo; (N=28)
Number of Participants
Number of Censored Participants | 50 (94.3%) | 27 (96.4%)
Number of Non Censored Participants | 3 (5.7%) | 1 (3.6%)
Time to event (Time to Any Discontinuation in Days)
Median (95% CI) | . | .
25% Percentile | . | .
75% Percentile | . | .
Range | (14, 56) | (26, 56)
Stratified Analysis by treatment
Hazard Ratio (Relative to Placebo) | 1.61
(95% CI) | (0.17, 15.46)
p value ^1^ | 0.6807

Note:

1 P-value is calculated from the Cox proportional hazards regression model.

Table 14.2.1.3.1 Tertiary Efficacy Endpoint: Parent General Behavior Inventory-10 Item Mania Scale (PGBI-10M) by Efficacy Phase Randomized Treatment Group Efficacy Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=81) | P-Value^1^
| Lithium; (N=53) | Placebo; (N=28) | Total; (N=81) | P-Value^1^
Total Score at Baseline
N | 53 | 28 | 81
Mean (SD) | 18.0 (7.1) | 17.0 (7.4) | 17.7 (7.2)
Median (Min-Max) | 18.0 (2.0 - 30.0) | 18.0 (3.0 - 30.0) | 18.0 (2.0 - 30.0)
Total Score at Week 8/End-of-Phase/LOCF
N | 52 | 25 | 77
Mean (SD) | 10.7 (7.9) | 13.8 (7.9) | 11.7 (8.0)
Median (Min-Max) | 9.0 (0.0 - 26.0) | 13.0 (2.0 - 29.0) | 10.0 (0.0 - 29.0)
Change in Total Score from Baseline to Week 8/End-of-Phase/LOCF
N | 52 | 25 | 77 | 0.039
Mean (SD) | −7.7 (9.1) | −2.1 (8.0) | −5.9 (9.1)
Median (Min-Max) | −7.0 (−30.0 - 10.0) | 0.0 (−16.0 - 13.0) | −5.0 (−30.0 - 13.0)

Note: Baseline is defined as the first visit of Efficacy Phase.

Change score is week 8/end of phase value minus baseline value.

1 P-value is calculated from linear model for the treatment effect of change from Baseline score to Week 8/End-of-Phase score.

Table 14.2.1.3.2 Tertiary Efficacy Endpoint: Child Mania Rating Scale-For Parents (CMRS-P) by Efficacy Phase Randomized Treatment Group Efficacy Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=81) | P-Value^1^
| Lithium; (N=53) | Placebo; (N=28) | Total; (N=81) | P-Value^1^
Total Score at Baseline
N | 53 | 28 | 81
Mean (SD) | 28.8 (10.6) | 32.3 (11.9) | 30.0 (11.1)
Median (Min-Max) | 29.0 (10.0 - 50.0) | 32.0 (13.0 - 59.0) | 31.0 (10.0 - 59.0)
Total Score at Week 8/End-of-Phase/LOCF
N | 52 | 25 | 77
Mean (SD) | 19.7 (13.2) | 24.4 (13.3) | 21.2 (13.3)
Median (Min-Max) | 14.5 (0.0 - 52.0) | 23.0 (2.0 - 53.0) | 17.0 (0.0 - 53.0)
Change in Total Score from Baseline to Week 8/End-of-Phase/LOCF
N | 52 | 25 | 77 | 0.134
Mean (SD) | −9.2 (11.6) | −6.3 (9.3) | −8.2 (10.9)
Median (Min-Max) | −8.0 (−42.0 - 16.0) | −3.0 (−28.0 - 6.0) | −6.0 (−42.0 - 16.0)

Note: Baseline is defined as the first visit of Efficacy Phase.

Change score is week 8/end of phase value minus baseline value.

1 P-value is calculated from linear model for the treatment effect of change from Baseline score to Week 8/End-of-Phase score.

Table 14.2.1.3.3 Tertiary Efficacy Endpoint: ADHD Rating Scale (ARS-IV) by Efficacy Phase Randomized Treatment Group Efficacy Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=81) | P-Value^1^
| Lithium; (N=53) | Placebo; (N=28) | Total; (N=81) | P-Value^1^
ADHD Total Score at Baseline
N | 52 | 28 | 80
Mean (SD) | 34.1 (12.9) | 35.4 (13.1) | 34.6 (12.9)
Median (Min-Max) | 34.5 (10.0 - 53.0) | 35.5 (3.0 - 54.0) | 34.5 (3.0 - 54.0)
ADHD Total Score at Week 8/End-of-Phase/LOCF
N | 51 | 25 | 76
Mean (SD) | 28.6 (14.1) | 30.3 (14.8) | 29.2 (14.3)
Median (Min-Max) | 27.0 (2.0 - 51.0) | 32.0 (5.0 - 53.0) | 28.5 (2.0 - 53.0)
Change in ADHD Total Score from Baseline to Week 8/End-of-Phase/LOCF
N | 51 | 25 | 76 | 0.509
Mean (SD) | −5.4 (10.2) | −3.9 (11.1) | −4.9 (10.5)
Median (Min-Max) | −3.0 (−35.0 - 15.0) | −2.0 (−25.0 - 18.0) | −3.0 (−35.0 - 18.0)
ADHD Inattention Subscale at Baseline
N | 52 | 28 | 80
Mean (SD) | 18.1 (7.4) | 18.8 (6.7) | 18.4 (7.1)
Median (Min-Max) | 20.0 (0.0 - 27.0) | 18.5 (2.0 - 27.0) | 19.5 (0.0 - 27.0)
ADHD Inattention Subscale at Week 8/End-of-Phase/LOCF
N | 51 | 25 | 76
Mean (SD) | 15.6 (7.2) | 15.9 (7.6) | 15.7 (7.3)
Median (Min-Max) | 17.0 (1.0 - 27.0) | 17.0 (4.0 - 27.0) | 17.0 (1.0 - 27.0)
Change in Inattention Subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 51 | 25 | 76 | 0.951
Mean (SD) | −2.4 (5.4) | −2.3 (5.9) | −2.4 (5.5)
Median (Min-Max) | −1.0 (−17.0 - 8.0) | −1.0 (−14.0 - 11.0) | −1.0 (−17.0 - 11.0)
ADHD Hyperactivity-Impulsivity Subscale at Baseline
N | 52 | 28 | 80
Mean (SD) | 16.0 (7.2) | 16.6 (7.0) | 16.2 (7.1)
Median (Min-Max) | 16.5 (4.0 - 27.0) | 16.5 (1.0 - 27.0) | 16.5 (1.0 - 27.0)
ADHD Hyperactivity-Impulsivity Subscale at Week 8/End-of-Phase/LOCF
N | 51 | 25 | 76
Mean (SD) | 13.0 (8.0) | 14.0 (7.5) | 13.3 (7.8)
Median (Min-Max) | 12.0 (0.0 - 27.0) | 14.0 (1.0 - 26.0) | 12.5 (0.0 - 27.0)
Change in ADHD Hyperactivity-Impulsivity Subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 51 | 25 | 76 | 0.338
Mean (SD) | −3.0 (5.5) | −2.0 (5.6) | −2.7 (5.5)
Median (Min-Max) | −2.0 (−19.0 - 13.0) | −1.0 (−12.0 - 7.0) | −2.0 (−19.0 - 13.0)

Note: Baseline is defined as the first visit of Efficacy Phase.

Change score is week 8/end of phase value minus baseline value.

1 P-value is calculated from linear model for the treatment effect of change from Baseline score to Week 8/End-of-Phase score.

Table 14.2.1.3.4 Tertiary Efficacy Endpoint: Brief Psychiatric Rating Scale-For Children (BPRS-C) by Efficacy Phase Randomized Treatment Group Efficacy Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=81) | P-Value^1^
| Lithium; (N=53) | Placebo; (N=28) | Total; (N=81) | P-Value^1^
BPRS-C Total score at Baseline
N | 53 | 28 | 81
Mean (SD) | 32.3 (11.5) | 34.6 (12.1) | 33.1 (11.7)
Median (Min-Max) | 32.0 (13.0 - 66.0) | 32.0 (17.0 - 68.0) | 32.0 (13.0 - 68.0)
BPRS-C Total score at Week 8/End-of-Phase/LOCF
N | 52 | 25 | 77
Mean (SD) | 21.6 (13.2) | 23.2 (12.3) | 22.1 (12.9)
Median (Min-Max) | 21.0 (0.0 - 62.0) | 23.0 (6.0 - 63.0) | 22.0 (0.0 - 63.0)
Change in BPRS-C Total score from Baseline to Week 8/End-of-Phase/LOCF
N | 52 | 25 | 77 | 0.763
Mean (SD) | −10.6 (14.2) | −10.8 (13.4) | −10.6 (13.8)
Median (Min-Max) | −12.0 (−39.0 - 22.0) | −7.0 (−44.0 - 9.0) | −10.0 (−44.0 - 22.0)
BPRS-C Behavior Problems subscale at Baseline
N | 53 | 28 | 81
Mean (SD) | 8.9 (3.2) | 9.4 (3.4) | 9.0 (3.3)
Median (Min-Max) | 9.0 (2.0 - 18.0) | 10.0 (0.0 - 18.0) | 9.0 (0.0 - 18.0)
BPRS-C Behavior Problems subscale at Week 8/End-of-Phase/LOCF
N | 52 | 25 | 77
Mean (SD) | 5.6 (3.8) | 6.7 (4.6) | 5.9 (4.1)
Median (Min-Max) | 6.0 (0.0 - 13.0) | 6.0 (0.0 - 18.0) | 6.0 (0.0 - 18.0)
Change in BPRS-C Behavior Problems subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 52 | 25 | 77 | 0.178
Mean (SD) | −3.2 (4.6) | −2.5 (4.0) | −3.0 (4.4)
Median (Min-Max) | −2.5 (−18.0 - 7.0) | −3.0 (−9.0 - 4.0) | −3.0 (−18.0 - 7.0)
BPRS-C Depression subscale at Baseline
N | 53 | 28 | 81
Mean (SD) | 4.1 (2.6) | 4.8 (3.2) | 4.3 (2.9)
Median (Min-Max) | 4.0 (0.0 - 11.0) | 5.0 (0.0 - 11.0) | 4.0 (0.0 - 11.0)
BPRS-C Depression subscale at Week 8/End-of-Phase/LOCF
N | 52 | 25 | 77
Mean (SD) | 3.1 (3.3) | 2.9 (2.7) | 3.0 (3.1)
Median (Min-Max) | 2.0 (0.0 - 13.0) | 2.0 (0.0 - 9.0) | 2.0 (0.0 - 13.0)
Change in BPRS-C Depression subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 52 | 25 | 77 | 0.681
Mean (SD) | −1.0 (3.7) | −1.7 (3.6) | −1.3 (3.7)
Median (Min-Max) | −1.5 (−8.0 - 11.0) | −1.0 (−8.0 - 8.0) | −1.0 (−8.0 - 11.0)
BPRS-C Thinking Disturbance subscale at Baseline
N | 53 | 28 | 81
Mean (SD) | 1.5 (2.4) | 1.8 (2.9) | 1.6 (2.6)
Median (Min-Max) | 0.0 (0.0 - 12.0) | 0.0 (0.0 - 11.0) | 0.0 (0.0 - 12.0)
BPRS-C Thinking Disturbance subscale at Week 8/End-of-Phase/LOCF
N | 52 | 25 | 77
Mean (SD) | 1.0 (2.4) | 0.9 (1.6) | 0.9 (2.2)
Median (Min-Max) | 0.0 (0.0 - 12.0) | 0.0 (0.0 - 6.0) | 0.0 (0.0 - 12.0)
Change in BPRS-C Thinking Disturbance subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 52 | 25 | 77 | 0.740
Mean (SD) | −0.4 (2.2) | −0.8 (3.1) | −0.5 (2.5)
Median (Min-Max) | 0.0 (−5.0 - 9.0) | 0.0 (−11.0 - 4.0) | 0.0 (−11.0 - 9.0)
BPRS-C Psychomotor excitation subscale at Baseline
N | 53 | 28 | 81
Mean (SD) | 9.7 (3.8) | 9.1 (2.7) | 9.5 (3.5)
Median (Min-Max) | 10.0 (0.0 - 17.0) | 9.0 (4.0 - 15.0) | 10.0 (0.0 - 17.0)
BPRS-C Psychomotor excitation subscale at Week 8/End-of-Phase/LOCF
N | 52 | 25 | 77
Mean (SD) | 6.4 (3.8) | 7.2 (3.5) | 6.6 (3.7)
Median (Min-Max) | 6.0 (0.0 - 14.0) | 7.0 (0.0 - 14.0) | 6.0 (0.0 - 14.0)
Change in BPRS-C Psychomotor excitation subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 52 | 25 | 77 | 0.156
Mean (SD) | −3.4 (4.5) | −1.9 (4.0) | −2.9 (4.4)
Median (Min-Max) | −3.0 (−15.0 - 6.0) | −1.0 (−12.0 - 6.0) | −3.0 (−15.0 - 6.0)
BPRS-C Withdrawal subscale at Baseline
N | 53 | 28 | 81
Mean (SD) | 1.8 (2.3) | 2.0 (2.4) | 1.8 (2.3)
Median (Min-Max) | 1.0 (0.0 - 8.0) | 1.0 (0.0 - 8.0) | 1.0 (0.0 - 8.0)
BPRS-C Withdrawal subscale at Week 8/End-of-Phase/LOCF
N | 52 | 25 | 77
Mean (SD) | 0.7 (1.5) | 1.2 (1.4) | 0.9 (1.5)
Median (Min-Max) | 0.0 (0.0 - 8.0) | 1.0 (0.0 - 5.0) | 0.0 (0.0 - 8.0)
Change in BPRS-C Withdrawal subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 52 | 25 | 77 | 0.423
Mean (SD) | −1.0 (1.8) | −0.6 (2.6) | −0.9 (2.1)
Median (Min-Max) | 0.0 (−8.0 - 2.0) | 0.0 (−6.0 - 5.0) | 0.0 (−8.0 - 5.0)
BPRS-C Anxiety subscale at Baseline
N | 53 | 28 | 81
Mean (SD) | 5.7 (4.0) | 6.3 (3.4) | 5.9 (3.8)
Median (Min-Max) | 6.0 (0.0 - 16.0) | 5.0 (2.0 - 15.0) | 5.0 (0.0 - 16.0)
BPRS-C Anxiety subscale at Week 8/End-of-Phase/LOCF
N | 52 | 25 | 77
Mean (SD) | 4.6 (3.6) | 3.4 (3.2) | 4.2 (3.5)
Median (Min-Max) | 4.0 (0.0 - 14.0) | 3.0 (0.0 - 13.0) | 3.0 (0.0 - 14.0)
Change in BPRS-C Anxiety subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 52 | 25 | 77 | 0.063
Mean (SD) | −1.2 (4.0) | −2.7 (3.2) | −1.7 (3.8)
Median (Min-Max) | −1.0 (−10.0 - 5.0) | −3.0 (−9.0 - 4.0) | −2.0 (−10.0 - 5.0)
BPRS-C Organicity subscale at Baseline
N | 53 | 28 | 81
Mean (SD) | 0.7 (1.6) | 1.3 (2.2) | 0.9 (1.9)
Median (Min-Max) | 0.0 (0.0 - 8.0) | 0.0 (0.0 - 8.0) | 0.0 (0.0 - 8.0)
BPRS-C Organicity subscale at Week 8/End-of-Phase/LOCF
N | 52 | 25 | 77
Mean (SD) | 0.3 (1.2) | 0.9 (1.9) | 0.5 (1.4)
Median (Min-Max) | 0.0 (0.0 - 7.0) | 0.0 (0.0 - 6.0) | 0.0 (0.0 - 7.0)
Change in BPRS-C Organicity subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 52 | 25 | 77 | 0.770
Mean (SD) | −0.4 (1.4) | −0.4 (2.0) | −0.4 (1.6)
Median (Min-Max) | 0.0 (−7.0 - 2.0) | 0.0 (−6.0 - 6.0) | 0.0 (−7.0 - 6.0)

Note: Baseline is defined as the first visit of Efficacy Phase.

Change score is week 8/end of phase value minus baseline value.

1 P-value is calculated from linear model for the treatment effect of change from Baseline score to Week 8/End-of-Phase score.P-values for Depression, Thinking, Withdrawal and Organicity are calculated from KRUSKAL-WALLIS Test for the treatment effect of change from Baseline score to Week 8/End-of-Phase score.

Table 14.2.1.3.5 Tertiary Efficacy Endpoint: Pediatric Anxiety Rating Scale (PARS) by Efficacy Phase Randomized Treatment Group Efficacy Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=81) | P-Value^1^
| Lithium; (N=53) | Placebo; (N=28) | Total; (N=81) | P-Value^1^
Total Score at Baseline
N | 52 | 28 | 80
Mean (SD) | 9.7 (7.0) | 8.1 (8.4) | 9.1 (7.6)
Median (Min-Max) | 10.5 (0.0 - 26.0) | 6.0 (0.0 - 23.0) | 10.0 (0.0 - 26.0)
Total Score at Week 8/End-of-Phase/LOCF
N | 49 | 24 | 73
Mean (SD) | 9.2 (7.6) | 8.0 (8.0) | 8.8 (7.7)
Median (Min-Max) | 10.0 (0.0 - 30.0) | 6.0 (0.0 - 29.0) | 9.0 (0.0 - 30.0)
Change in Total Score from Baseline to Week 8/End-of-Phase/LOCF
N | 48 | 24 | 72 | 0.843
Mean (SD) | −0.7 (6.4) | 0.5 (6.3) | −0.3 (6.4)
Median (Min-Max) | 0.0 (−16.0 - 12.0) | 0.0 (−10.0 - 17.0) | 0.0 (−16.0 - 17.0)
Subscale Score at Baseline
N | 52 | 28 | 80
Mean (SD) | 6.4 (5.0) | 4.9 (5.5) | 5.9 (5.2)
Median (Min-Max) | 6.0 (0.0 - 19.0) | 2.5 (0.0 - 15.0) | 5.0 (0.0 - 19.0)
Subscale Score at Week 8/End-of-Phase/LOCF
N | 49 | 24 | 73
Mean (SD) | 6.1 (5.3) | 5.5 (5.8) | 5.9 (5.4)
Median (Min-Max) | 6.0 (0.0 - 21.0) | 4.0 (0.0 - 21.0) | 6.0 (0.0 - 21.0)
Change in Subscale Score from Baseline to Week 8/End-of-Phase/LOCF
N | 48 | 24 | 72 | 0.854
Mean (SD) | −0.5 (4.7) | 1.0 (4.3) | 0.0 (4.6)
Median (Min-Max) | 0.0 (−13.0 - 9.0) | 0.0 (−6.0 - 10.0) | 0.0 (−13.0 - 10.0)

Note: Baseline is defined as the first visit of Efficacy Phase.

Change score is week 8/end of phase value minus baseline value.

1 P-value is calculated from linear model for the treatment effect of change from Baseline score to Week 8/End-of-Phase score.

Table 14.2.1.4.1 Descriptive Efficacy Endpoint: Family Environmental Scale (FES) by Efficacy Phase Randomized Treatment Group Efficacy Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=81)
| Lithium; (N=53) | Placebo; (N=28) | Total; (N=81)
Cohesion subscale at Baseline
N | 24 | 10 | 34
Mean (SD) | 6.1 (2.2) | 6.6 (2.3) | 6.3 (2.2)
Median (Min-Max) | 6.0 (2.0 - 9.0) | 7.5 (2.0 - 9.0) | 6.5 (2.0 - 9.0)
Cohesion subscale at Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | 6.4 (2.1) | 7.0 (1.2) | 6.5 (1.9)
Median (Min-Max) | 7.0 (3.0 - 9.0) | 7.0 (6.0 - 9.0) | 7.0 (3.0 - 9.0)
Change in Cohesion subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | 0.4 (1.4) | 0.2 (1.5) | 0.4 (1.4)
Median (Min-Max) | 0.0 (−3.0 - 3.0) | 0.0 (−2.0 - 2.0) | 0.0 (−3.0 - 3.0)
Expressiveness subscale at Baseline
N | 24 | 10 | 34
Mean (SD) | 6.0 (1.9) | 5.6 (1.5) | 5.9 (1.8)
Median (Min-Max) | 6.0 (0.0 - 9.0) | 6.0 (3.0 - 7.0) | 6.0 (0.0 - 9.0)
Expressiveness subscale at Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | 6.5 (1.4) | 7.2 (1.6) | 6.6 (1.4)
Median (Min-Max) | 7.0 (3.0 - 9.0) | 8.0 (5.0 - 9.0) | 7.0 (3.0 - 9.0)
Change in Expressiveness subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | 0.5 (1.6) | 2.0 (0.7) | 0.8 (1.6)
Median (Min-Max) | 0.0 (−4.0 - 3.0) | 2.0 (1.0 - 3.0) | 1.0 (−4.0 - 3.0)
Conflict subscale at Baseline
N | 24 | 10 | 34
Mean (SD) | 4.8 (1.9) | 4.1 (2.9) | 4.6 (2.2)
Median (Min-Max) | 5.0 (1.0 - 9.0) | 3.5 (0.0 - 9.0) | 5.0 (0.0 - 9.0)
Conflict subscale at Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | 3.5 (2.6) | 3.8 (2.3) | 3.6 (2.5)
Median (Min-Max) | 3.0 (0.0 - 9.0) | 4.0 (0.0 - 6.0) | 3.5 (0.0 - 9.0)
Change in Conflict subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | −1.1 (2.0) | −0.4 (4.0) | −1.0 (2.4)
Median (Min-Max) | −1.0 (−6.0 - 2.0) | 1.0 (−7.0 - 3.0) | −0.5 (−7.0 - 3.0)
Independence subscale at Baseline
N | 24 | 10 | 34
Mean (SD) | 5.8 (1.4) | 6.4 (0.7) | 6.0 (1.3)
Median (Min-Max) | 6.0 (2.0 - 8.0) | 6.0 (6.0 - 8.0) | 6.0 (2.0 - 8.0)
Independence subscale at Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | 5.6 (1.5) | 6.2 (1.5) | 5.7 (1.5)
Median (Min-Max) | 6.0 (3.0 - 8.0) | 6.0 (4.0 - 8.0) | 6.0 (3.0 - 8.0)
Change in Independence subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | −0.1 (1.6) | −0.4 (1.5) | −0.2 (1.5)
Median (Min-Max) | 0.0 (−5.0 - 2.0) | −1.0 (−2.0 - 2.0) | 0.0 (−5.0 - 2.0)
Achievement subscale at Baseline
N | 24 | 10 | 34
Mean (SD) | 5.1 (1.9) | 6.4 (1.4) | 5.5 (1.8)
Median (Min-Max) | 5.5 (1.0 - 8.0) | 6.5 (3.0 - 8.0) | 6.0 (1.0 - 8.0)
Achievement subscale at Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | 5.1 (1.8) | 6.2 (0.8) | 5.3 (1.7)
Median (Min-Max) | 5.0 (1.0 - 9.0) | 6.0 (5.0 - 7.0) | 5.5 (1.0 - 9.0)
Change in Achievement subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | 0.2 (1.6) | −0.2 (0.8) | 0.1 (1.5)
Median (Min-Max) | 0.0 (−2.0 - 4.0) | 0.0 (−1.0 - 1.0) | 0.0 (−2.0 - 4.0)
Intellectual-Cultural subscale at Baseline
N | 24 | 10 | 34
Mean (SD) | 6.1 (1.7) | 5.7 (1.6) | 6.0 (1.7)
Median (Min-Max) | 6.0 (2.0 - 9.0) | 6.0 (2.0 - 8.0) | 6.0 (2.0 - 9.0)
Intellectual-Cultural subscale at Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | 5.8 (1.9) | 6.0 (0.7) | 5.8 (1.7)
Median (Min-Max) | 6.0 (2.0 - 9.0) | 6.0 (5.0 - 7.0) | 6.0 (2.0 - 9.0)
Change in Intellectual-Cultural subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | −0.2 (1.2) | 1.2 (1.1) | 0.1 (1.3)
Median (Min-Max) | 0.0 (−3.0 - 2.0) | 1.0 (0.0 - 3.0) | 0.0 (−3.0 - 3.0)
Active-Recreational subscale at Baseline
N | 24 | 10 | 34
Mean (SD) | 4.0 (2.3) | 5.9 (2.2) | 4.6 (2.4)
Median (Min-Max) | 4.0 (0.0 - 8.0) | 5.5 (3.0 - 9.0) | 4.5 (0.0 - 9.0)
Active-Recreational subscale at Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | 4.1 (1.9) | 7.0 (0.7) | 4.7 (2.1)
Median (Min-Max) | 4.0 (0.0 - 7.0) | 7.0 (6.0 - 8.0) | 4.5 (0.0 - 8.0)
Change in Active-Recreational subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | 0.3 (1.7) | 1.0 (1.4) | 0.5 (1.7)
Median (Min-Max) | 0.0 (−2.0 - 5.0) | 0.0 (0.0 - 3.0) | 0.0 (−2.0 - 5.0)
Moral-Religious subscale at Baseline
N | 23 | 10 | 33
Mean (SD) | 5.4 (2.3) | 5.5 (1.8) | 5.4 (2.1)
Median (Min-Max) | 5.0 (2.0 - 9.0) | 5.5 (3.0 - 8.0) | 5.0 (2.0 - 9.0)
Moral-Religious subscale at Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | 5.0 (2.2) | 5.6 (2.1) | 5.2 (2.2)
Median (Min-Max) | 5.0 (2.0 - 9.0) | 6.0 (3.0 - 8.0) | 5.0 (2.0 - 9.0)
Change in Moral-Religious subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | −0.1 (1.8) | 0.2 (1.1) | −0.1 (1.6)
Median (Min-Max) | 0.0 (−5.0 - 3.0) | 0.0 (−1.0 - 2.0) | 0.0 (−5.0 - 3.0)
Organization subscale at Baseline
N | 24 | 10 | 34
Mean (SD) | 5.0 (1.7) | 5.6 (2.1) | 5.1 (1.8)
Median (Min-Max) | 5.0 (2.0 - 8.0) | 5.5 (3.0 - 9.0) | 5.0 (2.0 - 9.0)
Organization subscale at Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | 5.2 (2.5) | 5.0 (3.2) | 5.2 (2.6)
Median (Min-Max) | 6.0 (1.0 - 9.0) | 6.0 (0.0 - 8.0) | 6.0 (0.0 - 9.0)
Change in Organization subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | 0.2 (1.7) | −0.2 (3.3) | 0.2 (2.0)
Median (Min-Max) | 0.0 (−3.0 - 4.0) | 1.0 (−4.0 - 4.0) | 0.0 (−4.0 - 4.0)
Control subscale at Baseline
N | 23 | 10 | 33
Mean (SD) | 5.3 (2.0) | 5.3 (1.9) | 5.3 (1.9)
Median (Min-Max) | 5.0 (1.0 - 9.0) | 6.0 (3.0 - 8.0) | 5.0 (1.0 - 9.0)
Control subscale at Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | 5.3 (1.7) | 4.6 (1.1) | 5.2 (1.6)
Median (Min-Max) | 5.0 (3.0 - 8.0) | 5.0 (3.0 - 6.0) | 5.0 (3.0 - 8.0)
Change in Control subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 20 | 5 | 25
Mean (SD) | 0.1 (1.3) | −0.4 (2.1) | 0.0 (1.5)
Median (Min-Max) | 0.0 (−2.0 - 3.0) | −1.0 (−2.0 - 3.0) | 0.0 (−2.0 - 3.0)

Note: Baseline is defined as the first visit of Efficacy Phase.

Change score is week 8/end of phase value minus baseline value.

Table 14.2.1.4.2 Descriptive Efficacy Endpoint: Caregiver Strain Questionnaire (CSQ) by Efficacy Phase Randomized Treatment Group Efficacy Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=81)
| Lithium; (N=53) | Placebo; (N=28) | Total; (N=81)
Total Score at Baseline
N | 24 | 10 | 34
Mean (SD) | 65.6 (14.4) | 66.7 (13.1) | 65.9 (13.8)
Median (Min-Max) | 69.5 (27.0 - 86.0) | 70.0 (47.0 - 85.0) | 69.5 (27.0 - 86.0)
Total Score at Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | 51.4 (20.8) | 48.0 (11.1) | 50.7 (19.1)
Median (Min-Max) | 45.0 (22.0 - 85.0) | 52.0 (30.0 - 59.0) | 46.0 (22.0 - 85.0)
Change in Total Score from Baseline to Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | −12.2 (22.0) | −10.4 (15.3) | −11.9 (20.6)
Median (Min-Max) | −12.0 (−57.0 - 30.0) | −8.0 (−33.0 - 6.0) | −10.0 (−57.0 - 30.0)
Objective Strain at Baseline
N | 24 | 10 | 34
Mean (SD) | 34.0 (8.4) | 34.3 (7.3) | 34.1 (8.0)
Median (Min-Max) | 34.5 (15.0 - 47.0) | 35.0 (21.0 - 48.0) | 35.0 (15.0 - 48.0)
Objective Strain at Week 8/End-of-Phase/LOCF
N | 22 | 5 | 27
Mean (SD) | 27.6 (13.0) | 22.4 (8.0) | 26.7 (12.3)
Median (Min-Max) | 22.0 (11.0 - 49.0) | 25.0 (14.0 - 31.0) | 22.0 (11.0 - 49.0)
Change in Objective Strain from Baseline to Week 8/End-of-Phase/LOCF
N | 22 | 5 | 27
Mean (SD) | −5.8 (13.2) | −7.4 (10.5) | −6.1 (12.6)
Median (Min-Max) | −3.0 (−32.0 - 19.0) | −7.0 (−22.0 - 4.0) | −6.0 (−32.0 - 19.0)
Subjective Strain at Baseline
N | 24 | 10 | 34
Mean (SD) | 31.6 (7.3) | 32.4 (7.2) | 31.9 (7.2)
Median (Min-Max) | 33.0 (12.0 - 45.0) | 33.5 (20.0 - 43.0) | 33.0 (12.0 - 45.0)
Subjective Strain at Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | 24.8 (9.4) | 25.6 (6.1) | 24.9 (8.8)
Median (Min-Max) | 25.0 (11.0 - 41.0) | 28.0 (16.0 - 32.0) | 26.0 (11.0 - 41.0)
Change in Subjective Strain from Baseline to Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | −6.0 (9.5) | −3.0 (4.9) | −5.4 (8.8)
Median (Min-Max) | −4.0 (−25.0 - 11.0) | −1.0 (−11.0 - 2.0) | −4.0 (−25.0 - 11.0)
Internalized Subjective Strain at Baseline
N | 24 | 10 | 34
Mean (SD) | 21.7 (4.7) | 23.5 (4.1) | 22.2 (4.6)
Median (Min-Max) | 22.5 (8.0 - 28.0) | 24.0 (16.0 - 28.0) | 22.5 (8.0 - 28.0)
Internalized Subjective Strain at Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | 17.1 (6.9) | 17.8 (4.3) | 17.2 (6.5)
Median (Min-Max) | 19.0 (7.0 - 28.0) | 18.0 (11.0 - 23.0) | 18.5 (7.0 - 28.0)
Change in Internalized Subjective Strain from Baseline to Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | −4.1 (6.6) | −3.2 (4.4) | −4.0 (6.2)
Median (Min-Max) | −3.0 (−17.0 - 9.0) | −3.0 (−9.0 - 3.0) | −3.0 (−17.0 - 9.0)
Externalized Subjective Strain at Baseline
N | 24 | 10 | 34
Mean (SD) | 9.9 (3.3) | 8.9 (3.8) | 9.6 (3.4)
Median (Min-Max) | 9.0 (4.0 - 17.0) | 8.0 (4.0 - 16.0) | 9.0 (4.0 - 17.0)
Externalized Subjective Strain at Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | 7.7 (2.9) | 7.8 (3.8) | 7.7 (3.0)
Median (Min-Max) | 7.0 (4.0 - 13.0) | 6.0 (5.0 - 14.0) | 7.0 (4.0 - 14.0)
Change in Externalized Subjective Strain from Baseline to Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | −1.9 (3.4) | 0.2 (1.6) | −1.5 (3.2)
Median (Min-Max) | −1.0 (−10.0 - 2.0) | 1.0 (−2.0 - 2.0) | −1.0 (−10.0 - 2.0)

Note: Baseline is defined as the first visit of Efficacy Phase.

Change score is week 8/end of phase value minus baseline value.

Table 14.2.1.4.3 Descriptive Efficacy Endpoint: Irritability, Depression and Anxiety (IDA) by Efficacy Phase Randomized Treatment Group Efficacy Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=81)
| Lithium; (N=53) | Placebo; (N=28) | Total; (N=81)
Outward Irritability Score at Baseline
N | 24 | 10 | 34
Mean (SD) | 9.9 (2.1) | 10.3 (1.6) | 10.0 (1.9)
Median (Min-Max) | 10.5 (4.0 - 12.0) | 10.5 (8.0 - 12.0) | 10.5 (4.0 - 12.0)
Outward Irritability Score at Week 8/End-of-Phase/LOCF
N | 22 | 8 | 30
Mean (SD) | 6.1 (3.4) | 8.4 (3.5) | 6.7 (3.5)
Median (Min-Max) | 6.5 (0.0 - 11.0) | 9.0 (1.0 - 12.0) | 7.0 (0.0 - 12.0)
Change in Outward Irritability Score from Baseline to Week 8/End-of-Phase/LOCF
N | 22 | 8 | 30
Mean (SD) | −4.0 (3.7) | −1.6 (4.2) | −3.3 (3.9)
Median (Min-Max) | −3.0 (−12.0 - 3.0) | −0.5 (−11.0 - 3.0) | −3.0 (−12.0 - 3.0)

Note: Baseline is defined as the first visit of Efficacy Phase.

Change score is week 8/end of phase value minus baseline value.

Descriptive 14.2.1.4.4 Descriptive Efficacy Endpoint: Nisonger Child Behavior Rating Form (NCBRF-TIQ) by Efficacy Phase Randomized Treatment Group Efficacy Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=81)
| Lithium; (N=53) | Placebo; (N=28) | Total; (N=81)
Positive Social Subscale at Baseline
N | 24 | 10 | 34
Mean (SD) | 9.0 (3.0) | 10.9 (4.4) | 9.6 (3.5)
Median (Min-Max) | 9.0 (4.0 - 14.0) | 10.0 (6.0 - 21.0) | 9.0 (4.0 - 21.0)
Positive Social Subscale at Week 8/End-of-Phase/LOCF
N | 22 | 7 | 29
Mean (SD) | 13.6 (5.5) | 10.1 (3.8) | 12.8 (5.3)
Median (Min-Max) | 13.0 (5.0 - 30.0) | 11.0 (2.0 - 14.0) | 12.0 (2.0 - 30.0)
Change in Positive Social Subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 22 | 7 | 29
Mean (SD) | 4.6 (6.6) | 0.3 (3.7) | 3.6 (6.2)
Median (Min-Max) | 4.5 (−4.0 - 25.0) | 0.0 (−5.0 - 6.0) | 3.0 (−5.0 - 25.0)
Conduct Problem Subscale at Baseline
N | 24 | 10 | 34
Mean (SD) | 17.8 (7.4) | 21.8 (9.1) | 19.0 (8.0)
Median (Min-Max) | 16.5 (6.0 - 36.0) | 20.5 (9.0 - 37.0) | 18.0 (6.0 - 37.0)
Conduct Problem Subscale at Week 8/End-of-Phase/LOCF
N | 22 | 7 | 29
Mean (SD) | 11.7 (10.6) | 15.4 (8.6) | 12.6 (10.1)
Median (Min-Max) | 8.5 (0.0 - 40.0) | 13.0 (7.0 - 29.0) | 10.0 (0.0 - 40.0)
Change in Conduct Problem Subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 22 | 7 | 29
Mean (SD) | −6.2 (11.2) | −4.0 (8.9) | −5.7 (10.5)
Median (Min-Max) | −2.5 (−36.0 - 14.0) | −3.0 (−18.0 - 8.0) | −3.0 (−36.0 - 14.0)
Hyperactive Subscale at Baseline
N | 24 | 10 | 34
Mean (SD) | 8.0 (3.5) | 7.0 (3.3) | 7.7 (3.5)
Median (Min-Max) | 8.0 (0.0 - 12.0) | 7.0 (0.0 - 12.0) | 8.0 (0.0 - 12.0)
Hyperactive Subscale at Week 8/End-of-Phase/LOCF
N | 22 | 7 | 29
Mean (SD) | 5.5 (3.8) | 5.0 (2.9) | 5.3 (3.6)
Median (Min-Max) | 4.5 (0.0 - 12.0) | 4.0 (2.0 - 10.0) | 4.0 (0.0 - 12.0)
Change in Hyperactive Subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 22 | 7 | 29
Mean (SD) | −3.1 (4.0) | −1.4 (3.3) | −2.7 (3.9)
Median (Min-Max) | −2.5 (−12.0 - 3.0) | −1.0 (−6.0 - 3.0) | −2.0 (−12.0 - 3.0)
Overly Sensitive Subscale at Baseline
N | 24 | 10 | 34
Mean (SD) | 7.0 (2.7) | 7.3 (3.7) | 7.1 (3.0)
Median (Min-Max) | 7.5 (0.0 - 11.0) | 8.5 (0.0 - 12.0) | 8.0 (0.0 - 12.0)
Overly Sensitive Subscale at Week 8/End-of-Phase/LOCF
N | 22 | 7 | 29
Mean (SD) | 5.5 (3.2) | 5.0 (3.9) | 5.4 (3.3)
Median (Min-Max) | 6.0 (0.0 - 12.0) | 4.0 (0.0 - 12.0) | 6.0 (0.0 - 12.0)
Change in Overly Sensitive Subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 22 | 7 | 29
Mean (SD) | −1.6 (3.8) | −2.0 (4.0) | −1.7 (3.8)
Median (Min-Max) | −1.5 (−9.0 - 5.0) | −4.0 (−6.0 - 4.0) | −2.0 (−9.0 - 5.0)
Oppositional Behavior Subscale at Baseline
N | 24 | 10 | 34
Mean (SD) | 20.7 (5.2) | 21.6 (3.8) | 21.0 (4.8)
Median (Min-Max) | 22.0 (11.0 - 27.0) | 22.5 (14.0 - 26.0) | 22.0 (11.0 - 27.0)
Oppositional Behavior Subscale at Week 8/End-of-Phase/LOCF
N | 22 | 7 | 29
Mean (SD) | 13.3 (7.6) | 16.3 (7.8) | 14.0 (7.6)
Median (Min-Max) | 12.0 (0.0 - 26.0) | 14.0 (7.0 - 27.0) | 13.0 (0.0 - 27.0)
Change in Oppositional Behavior Subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 22 | 7 | 29
Mean (SD) | −7.1 (7.9) | −4.1 (6.7) | −6.4 (7.7)
Median (Min-Max) | −4.0 (−27.0 - 3.0) | −1.0 (−15.0 - 4.0) | −4.0 (−27.0 - 4.0)
Inattentive Subscale at Baseline
N | 24 | 10 | 34
Mean (SD) | 14.2 (5.1) | 15.1 (4.5) | 14.4 (4.9)
Median (Min-Max) | 13.5 (5.0 - 21.0) | 15.5 (8.0 - 21.0) | 14.0 (5.0 - 21.0)
Inattentive Subscale at Week 8/End-of-Phase/LOCF
N | 22 | 7 | 29
Mean (SD) | 11.3 (5.9) | 11.0 (6.1) | 11.2 (5.8)
Median (Min-Max) | 11.5 (0.0 - 19.0) | 10.0 (4.0 - 20.0) | 11.0 (0.0 - 20.0)
Change in Inattentive Subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 22 | 7 | 29
Mean (SD) | −3.7 (6.7) | −2.3 (6.0) | −3.3 (6.5)
Median (Min-Max) | −2.5 (−19.0 - 10.0) | 0.0 (−14.0 - 4.0) | −1.0 (−19.0 - 10.0)
Withdrawn/Dysphoric Subscale at Baseline
N | 24 | 10 | 34
Mean (SD) | 17.7 (8.3) | 24.1 (11.2) | 19.6 (9.6)
Median (Min-Max) | 17.5 (0.0 - 33.0) | 24.5 (3.0 - 41.0) | 19.5 (0.0 - 41.0)
Withdrawn/Dysphoric Subscale at Week 8/End-of-Phase/LOCF
N | 22 | 7 | 29
Mean (SD) | 14.8 (11.1) | 16.9 (11.7) | 15.3 (11.1)
Median (Min-Max) | 13.5 (0.0 - 42.0) | 12.0 (7.0 - 40.0) | 13.0 (0.0 - 42.0)
Change in Withdrawn/Dysphoric Subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 22 | 7 | 29
Mean (SD) | −2.9 (11.0) | −7.1 (10.0) | −3.9 (10.7)
Median (Min-Max) | −3.5 (−26.0 - 24.0) | −10.0 (−22.0 - 4.0) | −4.0 (−26.0 - 24.0)

Note: Baseline is defined as the first visit of Efficacy Phase.

Change score is week 8/end of phase value minus baseline value.

Table 14.2.1.4.5 Descriptive Efficacy Endpoint: Social Adjustment Inventory for Children and Adolescents (SA/CA) By Efficacy Phase Randomized Treatment Group Efficacy Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=81)
| Lithium; (N=53) | Placebo; (N=28) | Total; (N=81)
Academic reading/english
N | 24 | 10 | 34
Mean (SD) | 2.0 (0.9) | 2.4 (1.2) | 2.1 (1.0)
Median (Min-Max) | 2.0 (1.0 - 4.0) | 2.5 (1.0 - 4.0) | 2.0 (1.0 - 4.0)
Academic reading/english
N | 21 | 5 | 26
Mean (SD) | 2.0 (0.7) | 2.8 (0.8) | 2.2 (0.8)
Median (Min-Max) | 2.0 (1.0 - 3.0) | 3.0 (2.0 - 4.0) | 2.0 (1.0 - 4.0)
Academic reading/english
N | 21 | 5 | 26
Mean (SD) | −0.1 (0.9) | 0.2 (1.8) | 0.0 (1.1)
Median (Min-Max) | 0.0 (−2.0 - 1.0) | 0.0 (−2.0 - 3.0) | 0.0 (−2.0 - 3.0)
Academic arithmetic
N | 24 | 10 | 34
Mean (SD) | 2.4 (1.0) | 2.6 (1.1) | 2.4 (1.0)
Median (Min-Max) | 2.5 (1.0 - 4.0) | 3.0 (1.0 - 4.0) | 3.0 (1.0 - 4.0)
Academic arithmetic
N | 21 | 5 | 26
Mean (SD) | 2.0 (0.7) | 2.8 (0.8) | 2.2 (0.7)
Median (Min-Max) | 2.0 (1.0 - 3.0) | 3.0 (2.0 - 4.0) | 2.0 (1.0 - 4.0)
Academic arithmetic
N | 21 | 5 | 26
Mean (SD) | −0.3 (0.9) | −0.2 (0.4) | −0.3 (0.8)
Median (Min-Max) | 0.0 (−2.0 - 1.0) | 0.0 (−1.0 - 0.0) | 0.0 (−2.0 - 1.0)
Global rating of school behavior problems subscale at Baseline
N | 24 | 10 | 34
Mean (SD) | 2.6 (0.9) | 2.9 (0.7) | 2.7 (0.8)
Median (Min-Max) | 3.0 (1.0 - 4.0) | 3.0 (2.0 - 4.0) | 3.0 (1.0 - 4.0)
Global rating of school behavior problems subscale at Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | 2.4 (1.0) | 2.2 (0.8) | 2.3 (0.9)
Median (Min-Max) | 2.0 (1.0 - 4.0) | 2.0 (1.0 - 3.0) | 2.0 (1.0 - 4.0)
Change in Global rating of school behavior problems subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | −0.3 (1.1) | −0.4 (0.5) | −0.3 (1.0)
Median (Min-Max) | 0.0 (−3.0 - 1.0) | 0.0 (−1.0 - 0.0) | 0.0 (−3.0 - 1.0)
Global rating of spare time activities subscale at Baseline
N | 24 | 10 | 34
Mean (SD) | 2.4 (0.8) | 2.8 (0.8) | 2.5 (0.8)
Median (Min-Max) | 2.0 (1.0 - 4.0) | 3.0 (2.0 - 4.0) | 2.0 (1.0 - 4.0)
Global rating of spare time activities subscale at Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | 1.9 (0.9) | 2.6 (0.5) | 2.0 (0.9)
Median (Min-Max) | 2.0 (1.0 - 4.0) | 3.0 (2.0 - 3.0) | 2.0 (1.0 - 4.0)
Change in Global rating of spare time activities subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | −0.6 (1.0) | −0.2 (0.8) | −0.5 (1.0)
Median (Min-Max) | −1.0 (−3.0 - 1.0) | 0.0 (−1.0 - 1.0) | −0.5 (−3.0 - 1.0)
Global rating of spare time problems at Baseline
N | 24 | 10 | 34
Mean (SD) | 2.3 (0.8) | 2.5 (1.0) | 2.3 (0.8)
Median (Min-Max) | 2.0 (1.0 - 4.0) | 2.0 (1.0 - 4.0) | 2.0 (1.0 - 4.0)
Global rating of spare time problems at Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | 1.6 (0.8) | 1.6 (0.5) | 1.6 (0.8)
Median (Min-Max) | 1.0 (1.0 - 4.0) | 2.0 (1.0 - 2.0) | 1.0 (1.0 - 4.0)
Change in Global rating of spare time problems from Baseline to Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | −0.7 (0.9) | −0.8 (1.5) | −0.7 (1.0)
Median (Min-Max) | −1.0 (−2.0 - 1.0) | −1.0 (−3.0 - 1.0) | −1.0 (−3.0 - 1.0)
Global rating of activity with peers at Baseline
N | 24 | 10 | 34
Mean (SD) | 2.3 (0.9) | 2.7 (0.9) | 2.4 (0.9)
Median (Min-Max) | 2.0 (1.0 - 4.0) | 3.0 (1.0 - 4.0) | 2.5 (1.0 - 4.0)
Global rating of activity with peers at Week 8/End-of-Phase/LOCF
N | 20 | 5 | 25
Mean (SD) | 2.2 (0.9) | 2.2 (0.4) | 2.2 (0.8)
Median (Min-Max) | 2.0 (1.0 - 4.0) | 2.0 (2.0 - 3.0) | 2.0 (1.0 - 4.0)
Change in Global rating of activity with peers from Baseline to Week 8/End-of-Phase/LOCF
N | 20 | 5 | 25
Mean (SD) | −0.2 (0.7) | −0.2 (0.4) | −0.2 (0.7)
Median (Min-Max) | 0.0 (−1.0 - 2.0) | 0.0 (−1.0 - 0.0) | 0.0 (−1.0 - 2.0)
Global rating of peer problems at Baseline
N | 24 | 10 | 34
Mean (SD) | 2.2 (0.9) | 2.8 (1.0) | 2.4 (1.0)
Median (Min-Max) | 2.0 (1.0 - 4.0) | 3.0 (1.0 - 4.0) | 2.0 (1.0 - 4.0)
Global rating of peer problems at Week 8/End-of-Phase/LOCF
N | 20 | 5 | 25
Mean (SD) | 1.7 (0.9) | 1.8 (0.8) | 1.7 (0.9)
Median (Min-Max) | 1.0 (1.0 - 4.0) | 2.0 (1.0 - 3.0) | 1.0 (1.0 - 4.0)
Change in Global rating of peer problems from Baseline to Week 8/End-of-Phase/LOCF
N | 20 | 5 | 25
Mean (SD) | −0.6 (0.9) | −0.6 (1.3) | −0.6 (1.0)
Median (Min-Max) | 0.0 (−2.0 - 1.0) | 0.0 (−2.0 - 1.0) | 0.0 (−2.0 - 1.0)
Global rating of boy-girl relationships at Baseline
N | 24 | 10 | 34
Mean (SD) | 49.1 (43.2) | 53.5 (44.5) | 50.4 (43.0)
Median (Min-Max) | 88.0 (1.0 - 88.0) | 88.0 (1.0 - 88.0) | 88.0 (1.0 - 88.0)
Global rating of boy-girl relationships at Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | 51.3 (43.4) | 36.6 (46.9) | 48.5 (43.6)
Median (Min-Max) | 88.0 (1.0 - 88.0) | 3.0 (2.0 - 88.0) | 88.0 (1.0 - 88.0)
Change in Global rating of boy-girl relationships from Baseline to Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | −0.3 (0.5) | 0.6 (0.9) | −0.2 (0.7)
Median (Min-Max) | 0.0 (−1.0 - 0.0) | 0.0 (0.0 - 2.0) | 0.0 (−1.0 - 2.0)
Global rating of problems with opposite sex at Baseline
N | 24 | 10 | 34
Mean (SD) | 48.4 (44.0) | 53.2 (44.9) | 49.8 (43.6)
Median (Min-Max) | 88.0 (1.0 - 88.0) | 88.0 (1.0 - 88.0) | 88.0 (1.0 - 88.0)
Global rating of problems with opposite sex at Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | 50.8 (44.1) | 35.8 (47.7) | 47.9 (44.2)
Median (Min-Max) | 88.0 (1.0 - 88.0) | 1.0 (1.0 - 88.0) | 88.0 (1.0 - 88.0)
Change in Global rating of problems with opposite sex from Baseline to Week 8/End-of-Phase/LOCF
N | 21 | 5 | 26
Mean (SD) | −0.2 (0.4) | 0.0 (0.0) | −0.2 (0.4)
Median (Min-Max) | 0.0 (−1.0 - 0.0) | 0.0 (0.0 - 0.0) | 0.0 (−1.0 - 0.0)
Global rating of sibling relationships at Baseline
N | 24 | 10 | 34
Mean (SD) | 2.0 (1.1) | 2.2 (1.2) | 2.1 (1.2)
Median (Min-Max) | 2.0 (0.0 - 4.0) | 2.5 (0.0 - 4.0) | 2.0 (0.0 - 4.0)
Global rating of sibling relationships at Week 8/End-of-Phase/LOCF
N | 20 | 5 | 25
Mean (SD) | 1.7 (1.0) | 2.2 (0.4) | 1.8 (1.0)
Median (Min-Max) | 2.0 (0.0 - 3.0) | 2.0 (2.0 - 3.0) | 2.0 (0.0 - 3.0)
Change in Global rating of sibling relationships from Baseline to Week 8/End-of-Phase/LOCF
N | 20 | 5 | 25
Mean (SD) | −0.4 (1.2) | −0.2 (1.3) | −0.3 (1.2)
Median (Min-Max) | 0.0 (−3.0 - 2.0) | 0.0 (−2.0 - 1.0) | 0.0 (−3.0 - 2.0)
Global rating of problems with sibling(s) at Baseline
N | 24 | 10 | 34
Mean (SD) | 2.1 (1.2) | 2.3 (1.2) | 2.1 (1.2)
Median (Min-Max) | 2.0 (0.0 - 4.0) | 2.0 (0.0 - 4.0) | 2.0 (0.0 - 4.0)
Global rating of problems with sibling(s) at Week 8/End-of-Phase/LOCF
N | 20 | 5 | 25
Mean (SD) | 1.4 (0.9) | 2.2 (0.4) | 1.5 (0.9)
Median (Min-Max) | 1.0 (0.0 - 4.0) | 2.0 (2.0 - 3.0) | 2.0 (0.0 - 4.0)
Change in Global rating of problems with sibling(s) from Baseline to Week 8/End-of-Phase/LOCF
N | 20 | 5 | 25
Mean (SD) | −0.7 (1.1) | −0.6 (1.3) | −0.6 (1.1)
Median (Min-Max) | 0.0 (−3.0 - 1.0) | 0.0 (−2.0 - 1.0) | 0.0 (−3.0 - 1.0)
Global rating of relationship with mother at Baseline
N | 24 | 10 | 34
Mean (SD) | 1.6 (0.7) | 1.9 (1.2) | 1.7 (0.9)
Median (Min-Max) | 1.0 (1.0 - 3.0) | 1.5 (1.0 - 4.0) | 1.0 (1.0 - 4.0)
Global rating of relationship with mother at Week 8/End-of-Phase/LOCF
N | 20 | 5 | 25
Mean (SD) | 1.7 (0.8) | 2.6 (1.3) | 1.8 (1.0)
Median (Min-Max) | 1.0 (1.0 - 3.0) | 2.0 (1.0 - 4.0) | 2.0 (1.0 - 4.0)
Change in Global rating of relationship with mother from Baseline to Week 8/End-of-Phase/LOCF
N | 20 | 5 | 25
Mean (SD) | 0.1 (0.8) | 0.8 (0.8) | 0.2 (0.8)
Median (Min-Max) | 0.0 (−1.0 - 2.0) | 1.0 (0.0 - 2.0) | 0.0 (−1.0 - 2.0)
Global rating of relationship with father at Baseline
N | 24 | 10 | 34
Mean (SD) | 1.8 (1.3) | 2.8 (1.4) | 2.1 (1.4)
Median (Min-Max) | 2.0 (0.0 - 4.0) | 3.0 (0.0 - 4.0) | 2.0 (0.0 - 4.0)
Global rating of relationship with father at Week 8/End-of-Phase/LOCF
N | 20 | 5 | 25
Mean (SD) | 1.5 (1.1) | 2.6 (1.7) | 1.7 (1.3)
Median (Min-Max) | 1.0 (0.0 - 4.0) | 3.0 (0.0 - 4.0) | 1.0 (0.0 - 4.0)
Change in Global rating of relationship with father from Baseline to Week 8/End-of-Phase/LOCF
N | 20 | 5 | 25
Mean (SD) | −0.5 (0.8) | −0.4 (2.1) | −0.4 (1.1)
Median (Min-Max) | −0.5 (−2.0 - 1.0) | 0.0 (−3.0 - 2.0) | 0.0 (−3.0 - 2.0)
Global rating of problem(s) with parents at Baseline
N | 24 | 10 | 34
Mean (SD) | 2.5 (1.0) | 2.4 (1.0) | 2.4 (1.0)
Median (Min-Max) | 3.0 (1.0 - 4.0) | 2.5 (1.0 - 4.0) | 3.0 (1.0 - 4.0)
Global rating of problem(s) with parents at Week 8/End-of-Phase/LOCF
N | 20 | 5 | 25
Mean (SD) | 1.7 (0.9) | 1.6 (0.9) | 1.7 (0.9)
Median (Min-Max) | 1.5 (1.0 - 4.0) | 1.0 (1.0 - 3.0) | 1.0 (1.0 - 4.0)
Change in Global rating of problem(s) with parents from Baseline to Week 8/End-of-Phase/LOCF
N | 20 | 5 | 25
Mean (SD) | −0.8 (1.1) | −0.8 (1.1) | −0.8 (1.1)
Median (Min-Max) | −1.0 (−3.0 - 1.0) | 0.0 (−2.0 - 0.0) | −1.0 (−3.0 - 1.0)

Note: Baseline is defined as the first visit of Efficacy Phase.

Change score is week 8/end of phase value minus baseline value.

Table 14.2.2.1A Primary Efficacy Endpoint: Young Mania Rating Scale (YMRS) by Age Strata Long-Term Effectiveness Phase - Efficacy Population

| Age Strata | | Total; (N=42)
| 7 - 11 yrs; (N=28) | 12 - 17 yrs; (N=14) | Total; (N=42)
YMRS Total Score at Baseline
N | 28 | 14 | 42
Mean (SD) | 15.7 (9.5) | 13.4 (7.9) | 14.9 (9.0)
Median (Min-Max) | 14.5 (0.0 - 35.0) | 14.0 (3.0 - 28.0) | 14.0 (0.0 - 35.0)
YMRS Total Score at Week 24/LOCF
N | 28 | 14 | 42
Mean (SD) | 8.8 (9.3) | 8.9 (7.9) | 8.8 (8.8)
Median (Min-Max) | 5.5 (0.0 - 30.0) | 8.0 (0.0 - 27.0) | 6.5 (0.0 - 30.0)
Change in YMRS Total Score from Baseline to Week 24/End-of-Phase
N | 28 | 14 | 42
Mean (SD) | −6.9 (12.8) | −4.5 (7.3) | −6.1 (11.2)
Median (Min-Max) | −6.5 (−35.0 - 20.0) | −3.5 (−19.0 - 6.0) | −4.0 (−35.0 - 20.0)

Note: Baseline is defined as the last visit of Efficacy Phase.

Change score is week 24/LOCF value minus baseline value.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.1B Primary Efficacy Endpoint: Young Mania Rating Scale (YMRS) by Efficacy Phase Randomized Treatment Group Long-Term Effectiveness Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=42)
| Lithium; (N=29) | Placebo; (N=13) | Total; (N=42)
YMRS Total Score at Baseline
N | 29 | 13 | 42
Mean (SD) | 10.6 (6.4) | 24.6 (5.8) | 14.9 (9.0)
Median (Min-Max) | 10.0 (0.0 - 26.0) | 24.0 (14.0 - 35.0) | 14.0 (0.0 - 35.0)
YMRS Total Score at Week 24/LOCF
N | 29 | 13 | 42
Mean (SD) | 9.0 (8.6) | 8.5 (9.5) | 8.8 (8.8)
Median (Min-Max) | 8.0 (0.0 - 30.0) | 4.0 (0.0 - 27.0) | 6.5 (0.0 - 30.0)
Change in YMRS Total Score from Baseline to Week 24/End-of-Phase
N | 29 | 13 | 42
Mean (SD) | −1.6 (8.4) | −16.1 (10.6) | −6.1 (11.2)
Median (Min-Max) | −1.0 (−16.0 - 20.0) | −19.0 (−35.0 - 5.0) | −4.0 (−35.0 - 20.0)

Note: Baseline is defined as the last visit of Efficacy Phase.

Change score is week 24/LOCF value minus baseline value.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.2.1A Secondary Efficacy Endpoint: Response, Remission, Improvement and Discontinuation by Age Strata Long-Term Effectiveness Phase - Efficacy Population

| Age Strata | | Total; (N=42)
| 7 - 11 yrs; (N=28) | 12 - 17 yrs; (N=14) | Total; (N=42)
YMRS Response
Non-response | 6 (21.4%) | 2 (14.3%) | 8 (19.0%)
Partial Response | 2 (7.1%) | 4 (28.6%) | 6 (14.3%)
Complete Response | 20 (71.4%) | 8 (57.1%) | 28 (66.7%)
YMRS Remission
No remission | 9 (32.1%) | 6 (42.9%) | 15 (35.7%)
Remission | 19 (67.9%) | 8 (57.1%) | 27 (64.3%)
YMRS Improvement
Reduction <25% | 3 (10.7%) | 1 (7.1%) | 4 (9.5%)
Reduction = 25-49% | 2 (7.1%) | 1 (7.1%) | 3 (7.1%)
Reduction ≥50% | 23 (82.1%) | 12 (85.7%) | 35 (83.3%)
Discontinuation due to any cause during the Long-Term Effectiveness Phase
Completed LTE Phase | 17 (60.7%) | 6 (42.9%) | 23 (54.8%)
Terminated for any reason | 11 (39.3%) | 8 (57.1%) | 19 (45.2%)
Discontinuation due to lack of efficacy during the Long-Term Effectiveness Phase
No termination due to lack of efficacy | 28 (100.0%) | 13 (92.9%) | 41 (97.6%)
Terminated due to lack of efficacy | 0 | 1 (7.1%) | 1 (2.4%)

Note: Baseline value is the pre-dose value from day 1 of the Efficacy Phase.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.2.1B Secondary Efficacy Endpoint: Response, Remission, Improvement and Discontinuation by Efficacy Phase Randomized Treatment Group Long-Term Effectiveness Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=42)
| Lithium; (N=29) | Placebo; (N=13) | Total; (N=42)
YMRS Response
Non-response | 5 (17.2%) | 3 (23.1%) | 8 (19.0%)
Partial Response | 5 (17.2%) | 1 (7.7%) | 6 (14.3%)
Complete Response | 19 (65.5%) | 9 (69.2%) | 28 (66.7%)
YMRS Remission
No remission | 11 (37.9%) | 4 (30.8%) | 15 (35.7%)
Remission | 18 (62.1%) | 9 (69.2%) | 27 (64.3%)
YMRS Improvement
Reduction <25% | 2 (6.9%) | 2 (15.4%) | 4 (9.5%)
Reduction = 25-49% | 2 (6.9%) | 1 (7.7%) | 3 (7.1%)
Reduction ≥50% | 25 (86.2%) | 10 (76.9%) | 35 (83.3%)
Discontinuation due to any cause during the Long-Term Effectiveness Phase
Completed LTE Phase | 15 (51.7%) | 8 (61.5%) | 23 (54.8%)
Terminated for any reason | 14 (48.3%) | 5 (38.5%) | 19 (45.2%)
Discontinuation due to lack of efficacy during the Long-Term Effectiveness Phase
No termination due to lack of efficacy | 29 (100.0%) | 12 (92.3%) | 41 (97.6%)
Terminated due to lack of efficacy | 0 | 1 (7.7%) | 1 (2.4%)

Note: Baseline value is the pre-dose value from day 1 of the Efficacy Phase.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.2.2A Secondary Efficacy Endpoint: Young Mania Rating Scale (YMRS) by Age Strata Long-Term Effectiveness Phase - Efficacy Population

| Age Strata | | Total; (N=42)
| 7 - 11 yrs; (N=28) | 12 - 17 yrs; (N=14) | Total; (N=42)
Parent Score at Baseline
N | 27 | 14 | 41
Mean (SD) | 14.7 (9.6) | 12.2 (7.6) | 13.9 (8.9)
Median (Min-Max) | 15.0 (0.0 - 35.0) | 10.0 (3.0 - 26.0) | 13.0 (0.0 - 35.0)
Parent Score at Week 24/LOCF
N | 28 | 14 | 42
Mean (SD) | 8.6 (9.0) | 7.4 (7.4) | 8.2 (8.4)
Median (Min-Max) | 5.5 (0.0 - 28.0) | 5.0 (0.0 - 25.0) | 5.0 (0.0 - 28.0)
Change in Parent Score from Baseline to Week 24/LOCF
N | 27 | 14 | 41
Mean (SD) | −6.6 (12.5) | −4.8 (8.2) | −6.0 (11.2)
Median (Min-Max) | −6.0 (−35.0 - 20.0) | −3.0 (−24.0 - 4.0) | −3.0 (−35.0 - 20.0)
Child Score at Baseline
N | 28 | 14 | 42
Mean (SD) | 9.4 (8.4) | 8.4 (6.0) | 9.1 (7.6)
Median (Min-Max) | 6.5 (0.0 - 30.0) | 7.5 (0.0 - 20.0) | 7.0 (0.0 - 30.0)
Child Score at Week 24/LOCF
N | 28 | 14 | 42
Mean (SD) | 5.3 (7.5) | 5.6 (4.3) | 5.4 (6.6)
Median (Min-Max) | 2.5 (0.0 - 26.0) | 5.5 (0.0 - 13.0) | 4.0 (0.0 - 26.0)
Change in Child Score from Baseline to Week 24/LOCF
N | 28 | 14 | 42
Mean (SD) | −4.2 (11.6) | −2.8 (4.5) | −3.7 (9.8)
Median (Min-Max) | −3.5 (−30.0 - 24.0) | −1.5 (−12.0 - 3.0) | −2.5 (−30.0 - 24.0)

Note: Baseline is defined as the last visit of Efficacy Phase.

Change score is week 24/LOCF value minus baseline value.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.2.2B Secondary Efficacy Endpoint: Young Mania Rating Scale (YMRS) by Efficacy Phase Randomized Treatment Group Long-Term Effectiveness Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=42)
| Lithium; (N=29) | Placebo; (N=13) | Total; (N=42)
Parent Score at Baseline
N | 29 | 12 | 41
Mean (SD) | 10.0 (6.3) | 23.3 (7.1) | 13.9 (8.9)
Median (Min-Max) | 10.0 (0.0 - 28.0) | 23.5 (7.0 - 35.0) | 13.0 (0.0 - 35.0)
Parent Score at Week 24/LOCF
N | 29 | 13 | 42
Mean (SD) | 8.5 (8.2) | 7.5 (9.3) | 8.2 (8.4)
Median (Min-Max) | 7.0 (0.0 - 28.0) | 4.0 (0.0 - 25.0) | 5.0 (0.0 - 28.0)
Change in Parent Score from Baseline to Week 24/LOCF
N | 29 | 12 | 41
Mean (SD) | −1.4 (8.0) | −16.8 (10.4) | −6.0 (11.2)
Median (Min-Max) | 0.0 (−15.0 - 20.0) | −19.5 (−35.0 - 2.0) | −3.0 (−35.0 - 20.0)
Child Score at Baseline
N | 29 | 13 | 42
Mean (SD) | 6.1 (5.5) | 15.8 (7.6) | 9.1 (7.6)
Median (Min-Max) | 5.0 (0.0 - 20.0) | 17.0 (4.0 - 30.0) | 7.0 (0.0 - 30.0)
Child Score at Week 24/LOCF
N | 29 | 13 | 42
Mean (SD) | 5.4 (6.6) | 5.2 (6.7) | 5.4 (6.6)
Median (Min-Max) | 4.0 (0.0 - 26.0) | 4.0 (0.0 - 24.0) | 4.0 (0.0 - 26.0)
Change in Child Score from Baseline to Week 24/LOCF
N | 29 | 13 | 42
Mean (SD) | −0.7 (8.7) | −10.5 (9.0) | −3.7 (9.8)
Median (Min-Max) | −1.0 (−14.0 - 24.0) | −10.0 (−30.0 - 2.0) | −2.5 (−30.0 - 24.0)

Note: Baseline is defined as the last visit of Efficacy Phase.

Change score is week 24/LOCF value minus baseline value.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.2.3A Secondary Efficacy Endpoint: Children Depression Rating Scale-Revised (CDRS-R) by Age Strata Long-Term Effectiveness Phase - Efficacy Population

| Age Strata | | Total; (N=42)
| 7 - 11 yrs; (N=28) | 12 - 17 yrs; (N=14) | Total; (N=42)
Total Score at Baseline
N | 28 | 14 | 42
Mean (SD) | 28.4 (8.7) | 27.7 (7.2) | 28.1 (8.2)
Median (Min-Max) | 27.0 (17.0 - 48.0) | 27.5 (19.0 - 43.0) | 27.0 (17.0 - 48.0)
Total Score at Week 24/LOCF
N | 28 | 14 | 42
Mean (SD) | 23.1 (8.6) | 26.3 (10.0) | 24.2 (9.1)
Median (Min-Max) | 19.0 (17.0 - 47.0) | 24.0 (17.0 - 53.0) | 20.0 (17.0 - 53.0)
Change in Total Score from Baseline to Week 24/LOCF
N | 28 | 14 | 42
Mean (SD) | −5.2 (10.3) | −1.4 (8.2) | −4.0 (9.7)
Median (Min-Max) | −4.0 (−26.0 - 16.0) | −2.0 (−15.0 - 10.0) | −2.5 (−26.0 - 16.0)

Note: Baseline is defined as the last visit of Efficacy Phase.

Change score is week 24/LOCF value minus baseline value.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.2.3B Secondary Efficacy Endpoint: Children Depression Rating Scale-Revised (CDRS-R) by Efficacy Phase Randomized Treatment Group Long-Term Effectiveness Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=42)
| Lithium; (N=29) | Placebo; (N=13) | Total; (N=42)
Total Score at Baseline
N | 29 | 13 | 42
Mean (SD) | 26.0 (7.2) | 32.9 (8.5) | 28.1 (8.2)
Median (Min-Max) | 25.0 (17.0 - 43.0) | 34.0 (20.0 - 48.0) | 27.0 (17.0 - 48.0)
Total Score at Week 24/LOCF
N | 29 | 13 | 42
Mean (SD) | 25.2 (9.5) | 22.0 (8.1) | 24.2 (9.1)
Median (Min-Max) | 20.0 (17.0 - 53.0) | 20.0 (17.0 - 47.0) | 20.0 (17.0 - 53.0)
Change in Total Score from Baseline to Week 24/LOCF
N | 29 | 13 | 42
Mean (SD) | −0.8 (8.7) | −10.9 (8.3) | −4.0 (9.7)
Median (Min-Max) | −1.0 (−19.0 - 16.0) | −12.0 (−26.0 - 1.0) | −2.5 (−26.0 - 16.0)

Note: Baseline is defined as the last visit of Efficacy Phase.

Change score is week 24/LOCF value minus baseline value.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.2.4A Secondary Efficacy Endpoint: Children’s Global Assessment Scale (CGAS) by Age Strata Long-Term Effectiveness Phase - Efficacy Population

| Age Strata | | Total; (N=42)
| 7 - 11 yrs; (N=28) | 12 - 17 yrs; (N=14) | Total; (N=42)
Total Score at Baseline
N | 28 | 14 | 42
Mean (SD) | 61.0 (13.7) | 65.2 (13.0) | 62.4 (13.5)
Median (Min-Max) | 60.0 (20.0 - 85.0) | 60.0 (50.0 - 90.0) | 60.0 (20.0 - 90.0)
Total Score at Week 24/LOCF
N | 28 | 14 | 42
Mean (SD) | 70.5 (10.2) | 66.6 (14.2) | 69.2 (11.7)
Median (Min-Max) | 70.0 (52.0 - 88.0) | 70.0 (40.0 - 85.0) | 70.0 (40.0 - 88.0)
Change in Total Score from Baseline to Week 24/LOCF
N | 28 | 14 | 42
Mean (SD) | 9.5 (18.6) | 1.4 (16.9) | 6.8 (18.2)
Median (Min-Max) | 8.0 (−20.0 - 50.0) | 1.5 (−27.0 - 26.0) | 7.5 (−27.0 - 50.0)

Note: Baseline is defined as the last visit of Efficacy Phase.

Change score is week 24/LOCF value minus baseline value.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.2.4B Secondary Efficacy Endpoint: Children’s Global Assessment Scale (CGAS) by Efficacy Phase Randomized Treatment Group Long-Term Effectiveness Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=42)
| Lithium; (N=29) | Placebo; (N=13) | Total; (N=42)
Total Score at Baseline
N | 29 | 13 | 42
Mean (SD) | 65.2 (14.5) | 56.2 (8.1) | 62.4 (13.5)
Median (Min-Max) | 66.0 (20.0 - 90.0) | 55.0 (42.0 - 75.0) | 60.0 (20.0 - 90.0)
Total Score at Week 24/LOCF
N | 29 | 13 | 42
Mean (SD) | 67.7 (10.6) | 72.5 (13.7) | 69.2 (11.7)
Median (Min-Max) | 70.0 (40.0 - 85.0) | 79.0 (45.0 - 88.0) | 70.0 (40.0 - 88.0)
Change in Total Score from Baseline to Week 24/LOCF
N | 29 | 13 | 42
Mean (SD) | 2.5 (18.2) | 16.4 (14.9) | 6.8 (18.2)
Median (Min-Max) | −1.0 (−27.0 - 50.0) | 15.0 (−10.0 - 41.0) | 7.5 (−27.0 - 50.0)

Note: Baseline is defined as the last visit of Efficacy Phase.

Change score is week 24/LOCF value minus baseline value.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.2.5A Secondary Efficacy Endpoint: Clinical Global Impression Scale (CGI) by Age Strata Long-Term Effectiveness Phase - Efficacy Population

| Age Strata | | Total; (N=42)
| 7 - 11 yrs; (N=28) | 12 - 17 yrs; (N=14) | Total; (N=42)
CGI-Severity Mania at Baseline
1-Normal, not at all ill | 7 (25.0%) | 5 (35.7%) | 12 (28.6%)
2-Borderline ill | 3 (10.7%) | 3 (21.4%) | 6 (14.3%)
3-Mildly ill | 9 (32.1%) | 2 (14.3%) | 11 (26.2%)
4-Moderately ill | 7 (25.0%) | 4 (28.6%) | 11 (26.2%)
5-Markedly ill | 2 (7.1%) | 0 | 2 (4.8%)
CGI-Severity Mania at Week 24/LOCF
1-Normal, not at all ill | 17 (60.7%) | 7 (50.0%) | 24 (57.1%)
2-Borderline ill | 4 (14.3%) | 6 (42.9%) | 10 (23.8%)
3-Mildly ill | 1 (3.6%) | 1 (7.1%) | 2 (4.8%)
4-Moderately ill | 4 (14.3%) | 0 | 4 (9.5%)
5-Markedly ill | 2 (7.1%) | 0 | 2 (4.8%)
Change in CGI-Severity Mania from Baseline to Week 24/LOCF
Failure | 9 (32.1%) | 2 (14.3%) | 11 (26.2%)
Success | 19 (67.9%) | 12 (85.7%) | 31 (73.8%)
CGI-Severity Depression at Baseline
1-Normal, not at all ill | 9 (32.1%) | 6 (42.9%) | 15 (35.7%)
2-Borderline ill | 8 (28.6%) | 4 (28.6%) | 12 (28.6%)
3-Mildly ill | 7 (25.0%) | 3 (21.4%) | 10 (23.8%)
4-Moderately ill | 4 (14.3%) | 1 (7.1%) | 5 (11.9%)
CGI-Severity Depression at Week 24/LOCF
1-Normal, not at all ill | 21 (75.0%) | 8 (57.1%) | 29 (69.0%)
2-Borderline ill | 2 (7.1%) | 2 (14.3%) | 4 (9.5%)
3-Mildly ill | 3 (10.7%) | 3 (21.4%) | 6 (14.3%)
4-Moderately ill | 2 (7.1%) | 0 | 2 (4.8%)
6-Severely ill | 0 | 1 (7.1%) | 1 (2.4%)
Change in CGI-Severity Depression from Baseline to Week 24/LOCF
Failure | 6 (21.4%) | 4 (28.6%) | 10 (23.8%)
Success | 22 (78.6%) | 10 (71.4%) | 32 (76.2%)
CGI-Severity Overall Illness at Baseline
1-Normal, not at all ill | 7 (25.0%) | 3 (21.4%) | 10 (23.8%)
2-Borderline ill | 2 (7.1%) | 4 (28.6%) | 6 (14.3%)
3-Mildly ill | 8 (28.6%) | 3 (21.4%) | 11 (26.2%)
4-Moderately ill | 10 (35.7%) | 4 (28.6%) | 14 (33.3%)
5-Markedly ill | 1 (3.6%) | 0 | 1 (2.4%)
CGI-Severity Overall Illness at Week 24/LOCF
1-Normal, not at all ill | 15 (53.6%) | 5 (35.7%) | 20 (47.6%)
2-Borderline ill | 5 (17.9%) | 3 (21.4%) | 8 (19.0%)
3-Mildly ill | 2 (7.1%) | 4 (28.6%) | 6 (14.3%)
4-Moderately ill | 4 (14.3%) | 1 (7.1%) | 5 (11.9%)
5-Markedly ill | 2 (7.1%) | 0 | 2 (4.8%)
6-Severely ill | 0 | 1 (7.1%) | 1 (2.4%)
Change in CGI-Severity Overall Illness from Baseline to Week 24/LOCF
Failure | 10 (35.7%) | 6 (42.9%) | 16 (38.1%)
Success | 18 (64.3%) | 8 (57.1%) | 26 (61.9%)
CGI-Improvement Mania at Week 24/LOCF
Very much improved | 19 (67.9%) | 6 (42.9%) | 25 (59.5%)
Much improved | 3 (10.7%) | 5 (35.7%) | 8 (19.0%)
Minimally improved | 0 | 1 (7.1%) | 1 (2.4%)
No change | 5 (17.9%) | 2 (14.3%) | 7 (16.7%)
Much worse | 1 (3.6%) | 0 | 1 (2.4%)
CGI-Improvement Mania at Week 24/LOCF
Failure | 5 (17.9%) | 0 | 5 (11.9%)
Success | 23 (82.1%) | 14 (100.0%) | 37 (88.1%)
CGI-Improvement Depression at Week 24/LOCF
Very much improved | 17 (60.7%) | 5 (35.7%) | 22 (52.4%)
Much improved | 4 (14.3%) | 3 (21.4%) | 7 (16.7%)
Minimally improved | 1 (3.6%) | 1 (7.1%) | 2 (4.8%)
No change | 4 (14.3%) | 2 (14.3%) | 6 (14.3%)
Minimally worse | 1 (3.6%) | 1 (7.1%) | 2 (4.8%)
Much worse | 0 | 2 (14.3%) | 2 (4.8%)
Very much worse | 1 (3.6%) | 0 | 1 (2.4%)
CGI-Improvement Depression at Week 24/LOCF
Failure | 3 (10.7%) | 3 (21.4%) | 6 (14.3%)
Success | 25 (89.3%) | 11 (78.6%) | 36 (85.7%)
CGI-Improvement Overall Illness at Week 24/LOCF
Very much improved | 19 (67.9%) | 5 (35.7%) | 24 (57.1%)
Much improved | 3 (10.7%) | 3 (21.4%) | 6 (14.3%)
Minimally improved | 0 | 2 (14.3%) | 2 (4.8%)
No change | 5 (17.9%) | 1 (7.1%) | 6 (14.3%)
Minimally worse | 0 | 2 (14.3%) | 2 (4.8%)
Much worse | 1 (3.6%) | 1 (7.1%) | 2 (4.8%)
CGI-Improvement Overall Illness at Week 24/LOCF
Failure | 5 (17.9%) | 4 (28.6%) | 9 (21.4%)
Success | 23 (82.1%) | 10 (71.4%) | 33 (78.6%)

Note: Baseline is defined as the last visit of Efficacy Phase.

Change score is week 24/LOCF value minus baseline value.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

CGI-Severity Success is defined as: baseline value of 1,2 with change to LOCF of <= 0; baseline value of 3 with change of <= −1; baseline of 4,5,6 with change of <= −2 & LOCF score of 1,2,3.

CGI-Improvement Success is defined as: baseline CGI-S value of 1,2 & CGI-I <=4 at LOCF; baseline CGI-S value of 3 & CGI-I <=3 at LOCF; baseline CGI-S value of 4,5,6 & CGI-I 1,2 at LOCF.

Table 14.2.2.2.5B Secondary Efficacy Endpoint: Clinical Global Impression Scale (CGI) by Efficacy Phase Randomized Treatment Group Long-Term Effectiveness Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=42)
| Lithium; (N=29) | Placebo; (N=13) | Total; (N=42)
CGI-Severity Mania at Baseline
1-Normal, not at all ill | 12 (41.4%) | 0 | 12 (28.6%)
2-Borderline ill | 5 (17.2%) | 1 (7.7%) | 6 (14.3%)
3-Mildly ill | 9 (31.0%) | 2 (15.4%) | 11 (26.2%)
4-Moderately ill | 3 (10.3%) | 8 (61.5%) | 11 (26.2%)
5-Markedly ill | 0 | 2 (15.4%) | 2 (4.8%)
CGI-Severity Mania at Week 24/LOCF
1-Normal, not at all ill | 14 (48.3%) | 10 (76.9%) | 24 (57.1%)
2-Borderline ill | 9 (31.0%) | 1 (7.7%) | 10 (23.8%)
3-Mildly ill | 2 (6.9%) | 0 | 2 (4.8%)
4-Moderately ill | 2 (6.9%) | 2 (15.4%) | 4 (9.5%)
5-Markedly ill | 2 (6.9%) | 0 | 2 (4.8%)
Change in CGI-Severity Mania from Baseline to Week 24/LOCF
Failure | 9 (31.0%) | 2 (15.4%) | 11 (26.2%)
Success | 20 (69.0%) | 11 (84.6%) | 31 (73.8%)
CGI-Severity Depression at Baseline
1-Normal, not at all ill | 12 (41.4%) | 3 (23.1%) | 15 (35.7%)
2-Borderline ill | 10 (34.5%) | 2 (15.4%) | 12 (28.6%)
3-Mildly ill | 6 (20.7%) | 4 (30.8%) | 10 (23.8%)
4-Moderately ill | 1 (3.4%) | 4 (30.8%) | 5 (11.9%)
CGI-Severity Depression at Week 24/LOCF
1-Normal, not at all ill | 18 (62.1%) | 11 (84.6%) | 29 (69.0%)
2-Borderline ill | 3 (10.3%) | 1 (7.7%) | 4 (9.5%)
3-Mildly ill | 6 (20.7%) | 0 | 6 (14.3%)
4-Moderately ill | 1 (3.4%) | 1 (7.7%) | 2 (4.8%)
6-Severely ill | 1 (3.4%) | 0 | 1 (2.4%)
Change in CGI-Severity Depression from Baseline to Week 24/LOCF
Failure | 9 (31.0%) | 1 (7.7%) | 10 (23.8%)
Success | 20 (69.0%) | 12 (92.3%) | 32 (76.2%)
CGI-Severity Overall Illness at Baseline
1-Normal, not at all ill | 10 (34.5%) | 0 | 10 (23.8%)
2-Borderline ill | 5 (17.2%) | 1 (7.7%) | 6 (14.3%)
3-Mildly ill | 11 (37.9%) | 0 | 11 (26.2%)
4-Moderately ill | 3 (10.3%) | 11 (84.6%) | 14 (33.3%)
5-Markedly ill | 0 | 1 (7.7%) | 1 (2.4%)
CGI-Severity Overall Illness at Week 24/LOCF
1-Normal, not at all ill | 12 (41.4%) | 8 (61.5%) | 20 (47.6%)
2-Borderline ill | 7 (24.1%) | 1 (7.7%) | 8 (19.0%)
3-Mildly ill | 5 (17.2%) | 1 (7.7%) | 6 (14.3%)
4-Moderately ill | 2 (6.9%) | 3 (23.1%) | 5 (11.9%)
5-Markedly ill | 2 (6.9%) | 0 | 2 (4.8%)
6-Severely ill | 1 (3.4%) | 0 | 1 (2.4%)
Change in CGI-Severity Overall Illness from Baseline to Week 24/LOCF
Failure | 12 (41.4%) | 4 (30.8%) | 16 (38.1%)
Success | 17 (58.6%) | 9 (69.2%) | 26 (61.9%)
CGI-Improvement Mania at Week 24/LOCF
Very much improved | 15 (51.7%) | 10 (76.9%) | 25 (59.5%)
Much improved | 8 (27.6%) | 0 | 8 (19.0%)
Minimally improved | 0 | 1 (7.7%) | 1 (2.4%)
No change | 5 (17.2%) | 2 (15.4%) | 7 (16.7%)
Much worse | 1 (3.4%) | 0 | 1 (2.4%)
CGI-Improvement Mania at Week 24/LOCF
Failure | 3 (10.3%) | 2 (15.4%) | 5 (11.9%)
Success | 26 (89.7%) | 11 (84.6%) | 37 (88.1%)
CGI-Improvement Depression at Week 24/LOCF
Very much improved | 15 (51.7%) | 7 (53.8%) | 22 (52.4%)
Much improved | 3 (10.3%) | 4 (30.8%) | 7 (16.7%)
Minimally improved | 2 (6.9%) | 0 | 2 (4.8%)
No change | 4 (13.8%) | 2 (15.4%) | 6 (14.3%)
Minimally worse | 2 (6.9%) | 0 | 2 (4.8%)
Much worse | 2 (6.9%) | 0 | 2 (4.8%)
Very much worse | 1 (3.4%) | 0 | 1 (2.4%)
CGI-Improvement Depression at Week 24/LOCF
Failure | 5 (17.2%) | 1 (7.7%) | 6 (14.3%)
Success | 24 (82.8%) | 12 (92.3%) | 36 (85.7%)
CGI-Improvement Overall Illness at Week 24/LOCF
Very much improved | 15 (51.7%) | 9 (69.2%) | 24 (57.1%)
Much improved | 6 (20.7%) | 0 | 6 (14.3%)
Minimally improved | 1 (3.4%) | 1 (7.7%) | 2 (4.8%)
No change | 3 (10.3%) | 3 (23.1%) | 6 (14.3%)
Minimally worse | 2 (6.9%) | 0 | 2 (4.8%)
Much worse | 2 (6.9%) | 0 | 2 (4.8%)
CGI-Improvement Overall Illness at Week 24/LOCF
Failure | 6 (20.7%) | 3 (23.1%) | 9 (21.4%)
Success | 23 (79.3%) | 10 (76.9%) | 33 (78.6%)

Note: Baseline is defined as the last visit of Efficacy Phase.

Change score is week 24/LOCF value minus baseline value.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

CGI-Severity Success is defined as: baseline value of 1,2 with change to LOCF of <= 0; baseline value of 3 with change of <= −1; baseline of 4,5,6 with change of <= −2 & LOCF score of 1,2,3.

CGI-Improvement Success is defined as: baseline CGI-S value of 1,2 & CGI-I <=4 at LOCF; baseline CGI-S value of 3 & CGI-I <=3 at LOCF; baseline CGI-S value of 4,5,6 & CGI-I 1,2 at LOCF.

Table 14.2.2.2.6A Secondary Efficacy Endpoint: Time to Any Discontinuation by Age Strata Long-Term Effectiveness Phase - Efficacy Population

| Age Strata
| 7 - 11 yrs; (N=28) | 12 - 17 yrs; (N=14)
Number of Participants
Number of Censored Participants | 17 (60.7%) | 6 (42.9%)
Number of Non Censored Participants | 11 (39.3%) | 8 (57.1%)
Time to event (Time to Any Discontinuation in Days)
Median (95% CI) | . (125.00, .) | 102.0 (54.00, .)
25% Percentile | 110.0 (16.00, .) | 56.0 (32.00, 79.00)
75% Percentile | . | . (79.00, .)
Range | (15, 168) | (32, 168)
Stratified Analysis by treatment
Hazard Ratio (Relative to 12-17 yrs) | 0.53
(95% CI) | (0.21, 1.33)

Note: Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.2.6B Secondary Efficacy Endpoint: Time to Any Discontinuation by Efficacy Phase Randomized Treatment Group Long-Term Effectiveness Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group
| Lithium; (N=29) | Placebo; (N=13)
Number of Participants
Number of Censored Participants | 15 (51.7%) | 8 (61.5%)
Number of Non Censored Participants | 14 (48.3%) | 5 (38.5%)
Time to event (Time to Any Discontinuation in Days)
Median (95% CI) | . (102.00, .) | . (79.00, .)
25% Percentile | 61.0 (45.00, 125.00) | 85.0 (16.00, .)
75% Percentile | . | .
Range | (15, 168) | (16, 168)
Stratified Analysis by treatment
Hazard Ratio (Relative to placebo) | 1.33
(95% CI) | (0.48, 3.69)

Note: Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.2.7A Secondary Efficacy Endpoint: Time to Discontinuation For Lack of Efficacy by Age Strata Long-Term Effectiveness Phase - Efficacy Population

| Age Strata
| 7 - 11 yrs; (N=28) | 12 - 17 yrs; (N=14)
Number of Participants
Number of Censored Participants | 28 (100.0%) | 13 (92.9%)
Number of Non Censored Participants | 0 | 1 (7.1%)
Time to event (Time to Any Discontinuation in Days)
Median (95% CI) | . | . (70.00, .)
25% Percentile | . | . (70.00, .)
75% Percentile | . | .
Range | (15, 181) | (32, 172)
Stratified Analysis by treatment
Hazard Ratio (Relative to 12-17 yrs) | 0.00
(95% CI) | (0.00, .)

Note: Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.2.7B Secondary Efficacy Endpoint: Time to Discontinuation For Lack of Efficacy by Efficacy Phase Randomized Treatment Group Long-Term Effectiveness Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group
| Lithium; (N=29) | Placebo; (N=13)
Number of Participants
Number of Censored Participants | 29 (100.0%) | 12 (92.3%)
Number of Non Censored Participants | 0 | 1 (7.7%)
Time to event (Time to Any Discontinuation in Days)
Median (95% CI) | . | .
25% Percentile | . | . (70.00, .)
75% Percentile | . | .
Range | (15, 172) | (16, 181)
Stratified Analysis by treatment
Hazard Ratio (Relative to placebo) | 0.00
(95% CI) | (0.00, .)

Note: Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.3.1A Tertiary Efficacy Endpoint: Parent General Behavior Inventory-10 item Mania Scale (PGBI-10M) by Age Strata Long-Term Effectiveness Phase - Efficacy Population

| Age Strata | | Total; (N=42)
| 7 - 11 yrs; (N=28) | 12 - 17 yrs; (N=14) | Total; (N=42)
Total Score at Baseline
N | 28 | 14 | 42
Mean (SD) | 11.9 (8.5) | 7.4 (6.8) | 10.4 (8.2)
Median (Min-Max) | 9.5 (0.0 - 29.0) | 5.0 (0.0 - 20.0) | 9.0 (0.0 - 29.0)
Total Score at Week 24/LOCF
N | 27 | 14 | 41
Mean (SD) | 7.3 (8.0) | 6.1 (6.4) | 6.9 (7.5)
Median (Min-Max) | 5.0 (0.0 - 28.0) | 5.0 (0.0 - 24.0) | 5.0 (0.0 - 28.0)
Change in Total Score from Baseline to Week 24/LOCF
N | 27 | 14 | 41
Mean (SD) | −4.1 (7.0) | −1.3 (6.6) | −3.1 (6.9)
Median (Min-Max) | −5.0 (−18.0 - 7.0) | −0.5 (−13.0 - 14.0) | −2.0 (−18.0 - 14.0)

Note: Baseline is defined as the last visit of Efficacy Phase.

Change score is week 24/LOCF value minus baseline value.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.3.1B Tertiary Efficacy Endpoint: Parent General Behavior Inventory-10 Item Mania Scale (PGBI-10M) by Efficacy Phase Randomized Treatment Group Long-Term Effectiveness Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=42)
| Lithium; (N=29) | Placebo; (N=13) | Total; (N=42)
Total Score at Baseline
N | 29 | 13 | 42
Mean (SD) | 8.3 (7.8) | 15.2 (7.1) | 10.4 (8.2)
Median (Min-Max) | 7.0 (0.0 - 26.0) | 15.0 (2.0 - 29.0) | 9.0 (0.0 - 29.0)
Total Score at Week 24/LOCF
N | 28 | 13 | 41
Mean (SD) | 6.5 (7.5) | 7.6 (7.7) | 6.9 (7.5)
Median (Min-Max) | 5.0 (0.0 - 28.0) | 6.0 (0.0 - 28.0) | 5.0 (0.0 - 28.0)
Change in Total Score from Baseline to Week 24/LOCF
N | 28 | 13 | 41
Mean (SD) | −1.1 (6.7) | −7.5 (5.3) | −3.1 (6.9)
Median (Min-Max) | 0.0 (−13.0 - 14.0) | −7.0 (−18.0 - −1.0) | −2.0 (−18.0 - 14.0)

Note: Baseline is defined as the last visit of Efficacy Phase.

Change score is week 24/LOCF value minus baseline value.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.3.2A Tertiary Efficacy Endpoint: ADHD Rating Scale (ARS-IV) by Age Strata Long-Term Effectiveness Phase - Efficacy Population

| Age Strata | | Total; (N=42)
| 7 - 11 yrs; (N=28) | 12 - 17 yrs; (N=14) | Total; (N=42)
ADHD Total Score at Baseline
N | 28 | 14 | 42
Mean (SD) | 32.1 (14.4) | 21.0 (12.8) | 28.4 (14.8)
Median (Min-Max) | 34.0 (2.0 - 53.0) | 22.0 (2.0 - 44.0) | 27.0 (2.0 - 53.0)
ADHD Total Score at Week 24/LOCF
N | 27 | 14 | 41
Mean (SD) | 22.2 (13.7) | 20.2 (14.3) | 21.5 (13.8)
Median (Min-Max) | 21.0 (0.0 - 49.0) | 20.5 (0.0 - 52.0) | 21.0 (0.0 - 52.0)
Change in ADHD Total Score from Baseline to Week 24/LOCF
N | 27 | 14 | 41
Mean (SD) | −9.3 (13.6) | −0.8 (8.5) | −6.4 (12.7)
Median (Min-Max) | −9.0 (−31.0 - 32.0) | −1.5 (−18.0 - 13.0) | −7.0 (−31.0 - 32.0)
ADHD Inattention Subscale at Baseline
N | 28 | 14 | 42
Mean (SD) | 16.6 (7.5) | 12.3 (7.1) | 15.2 (7.5)
Median (Min-Max) | 18.5 (1.0 - 27.0) | 12.0 (2.0 - 25.0) | 16.5 (1.0 - 27.0)
ADHD Inattention Subscale at Week 24/LOCF
N | 27 | 14 | 41
Mean (SD) | 11.8 (7.7) | 12.7 (7.3) | 12.1 (7.5)
Median (Min-Max) | 12.0 (0.0 - 26.0) | 13.5 (0.0 - 27.0) | 12.0 (0.0 - 27.0)
Change in Inattention Subscale from Baseline to Week 24/LOCF
N | 27 | 14 | 41
Mean (SD) | −4.6 (7.1) | 0.4 (4.4) | −2.9 (6.7)
Median (Min-Max) | −6.0 (−16.0 - 15.0) | 0.5 (−8.0 - 6.0) | −3.0 (−16.0 - 15.0)
ADHD Hyperactivity-Impulsivity Subscale at Baseline
N | 28 | 14 | 42
Mean (SD) | 15.5 (7.8) | 8.0 (5.8) | 13.0 (8.0)
Median (Min-Max) | 15.5 (1.0 - 27.0) | 6.5 (0.0 - 19.0) | 11.5 (0.0 - 27.0)
ADHD Hyperactivity-Impulsivity Subscale at Week 24/LOCF
N | 27 | 14 | 41
Mean (SD) | 10.4 (7.1) | 7.5 (7.5) | 9.4 (7.3)
Median (Min-Max) | 8.0 (0.0 - 27.0) | 7.0 (0.0 - 25.0) | 8.0 (0.0 - 27.0)
Change in ADHD Hyperactivity-Impulsivity Subscale from Baseline to Week 24/LOCF
N | 27 | 14 | 41
Mean (SD) | −4.7 (7.0) | −0.5 (4.8) | −3.3 (6.6)
Median (Min-Max) | −5.0 (−15.0 - 17.0) | −1.0 (−10.0 - 9.0) | −4.0 (−15.0 - 17.0)

Note: Baseline is defined as the last visit of Efficacy Phase.

Change score is week 24/LOCF value minus baseline value.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.3.2B Tertiary Efficacy Endpoint: ADHD Rating Scale (ARS-IV) by Efficacy Phase Randomized Treatment Group Long-Term Effectiveness Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=42)
| Lithium; (N=29) | Placebo; (N=13) | Total; (N=42)
ADHD Total Score at Baseline
N | 29 | 13 | 42
Mean (SD) | 25.7 (15.8) | 34.5 (10.2) | 28.4 (14.8)
Median (Min-Max) | 23.0 (2.0 - 51.0) | 35.0 (18.0 - 53.0) | 27.0 (2.0 - 53.0)
ADHD Total Score at Week 24/LOCF
N | 28 | 13 | 41
Mean (SD) | 20.9 (14.8) | 22.8 (11.7) | 21.5 (13.8)
Median (Min-Max) | 20.5 (0.0 - 52.0) | 21.0 (4.0 - 39.0) | 21.0 (0.0 - 52.0)
Change in ADHD Total Score from Baseline to Week 24/LOCF
N | 28 | 13 | 41
Mean (SD) | −4.0 (13.6) | −11.6 (8.8) | −6.4 (12.7)
Median (Min-Max) | −4.5 (−29.0 - 32.0) | −11.0 (−31.0 - −1.0) | −7.0 (−31.0 - 32.0)
ADHD Inattention Subscale at Baseline
N | 29 | 13 | 42
Mean (SD) | 14.2 (8.2) | 17.5 (5.6) | 15.2 (7.5)
Median (Min-Max) | 16.0 (1.0 - 27.0) | 18.0 (8.0 - 27.0) | 16.5 (1.0 - 27.0)
ADHD Inattention Subscale at Week 24/LOCF
N | 28 | 13 | 41
Mean (SD) | 12.0 (7.9) | 12.5 (6.6) | 12.1 (7.5)
Median (Min-Max) | 12.0 (0.0 - 27.0) | 12.0 (2.0 - 23.0) | 12.0 (0.0 - 27.0)
Change in Inattention Subscale from Baseline to Week 24/LOCF
N | 28 | 13 | 41
Mean (SD) | −1.9 (6.9) | −5.0 (6.1) | −2.9 (6.7)
Median (Min-Max) | −2.0 (−14.0 - 15.0) | −5.0 (−16.0 - 6.0) | −3.0 (−16.0 - 15.0)
ADHD Hyperactivity-Impulsivity Subscale at Baseline
N | 29 | 13 | 42
Mean (SD) | 11.6 (8.6) | 16.2 (5.5) | 13.0 (8.0)
Median (Min-Max) | 10.0 (0.0 - 27.0) | 17.0 (8.0 - 26.0) | 11.5 (0.0 - 27.0)
ADHD Hyperactivity-Impulsivity Subscale at Week 24/LOCF
N | 28 | 13 | 41
Mean (SD) | 8.9 (8.1) | 10.4 (5.5) | 9.4 (7.3)
Median (Min-Max) | 7.0 (0.0 - 27.0) | 9.0 (2.0 - 19.0) | 8.0 (0.0 - 27.0)
Change in ADHD Hyperactivity-Impulsivity Subscale from Baseline to Week 24/LOCF
N | 28 | 13 | 41
Mean (SD) | −2.1 (7.2) | −5.8 (4.5) | −3.3 (6.6)
Median (Min-Max) | −2.5 (−15.0 - 17.0) | −6.0 (−15.0 - 3.0) | −4.0 (−15.0 - 17.0)

Note: Baseline is defined as the last visit of Efficacy Phase.

Change score is week 24/LOCF value minus baseline value.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.3.3A Tertiary Efficacy Endpoint: Brief Psychiatric Rating Scale-For Children (BPRS-C) by Age Strata Long-Term Effectiveness Phase - Efficacy Population

| Age Strata | | Total; (N=42)
| 7 - 11 yrs; (N=28) | 12 - 17 yrs; (N=14) | Total; (N=42)
BPRS-C Total score at Baseline
N | 28 | 14 | 42
Mean (SD) | 21.1 (11.6) | 13.3 (8.6) | 18.5 (11.2)
Median (Min-Max) | 21.0 (0.0 - 62.0) | 12.0 (2.0 - 28.0) | 19.0 (0.0 - 62.0)
BPRS-C Total score at Week 24/LOCF
N | 27 | 14 | 41
Mean (SD) | 15.6 (15.4) | 15.1 (12.2) | 15.4 (14.2)
Median (Min-Max) | 12.0 (0.0 - 48.0) | 13.5 (0.0 - 34.0) | 12.0 (0.0 - 48.0)
Change in BPRS-C Total score from Baseline to Week 24/LOCF
N | 27 | 14 | 41
Mean (SD) | −4.9 (18.5) | 1.9 (10.0) | −2.6 (16.3)
Median (Min-Max) | −5.0 (−38.0 - 26.0) | 2.0 (−17.0 - 16.0) | −2.0 (−38.0 - 26.0)
BPRS-C Behavior Problems subscale at Baseline
N | 28 | 14 | 42
Mean (SD) | 5.7 (3.5) | 4.0 (4.2) | 5.1 (3.7)
Median (Min-Max) | 5.5 (0.0 - 13.0) | 2.5 (0.0 - 12.0) | 4.5 (0.0 - 13.0)
BPRS-C Behavior Problems subscale at Week 24/LOCF
N | 28 | 14 | 42
Mean (SD) | 4.1 (4.8) | 3.7 (4.8) | 4.0 (4.8)
Median (Min-Max) | 1.5 (0.0 - 14.0) | 1.5 (0.0 - 15.0) | 1.5 (0.0 - 15.0)
Change in BPRS-C Behavior Problems subscale from Baseline to Week 24/LOCF
N | 28 | 14 | 42
Mean (SD) | −1.6 (5.5) | −0.3 (3.9) | −1.1 (5.0)
Median (Min-Max) | −2.5 (−11.0 - 13.0) | 0.0 (−9.0 - 5.0) | −0.5 (−11.0 - 13.0)
BPRS-C Depression subscale at Baseline
N | 28 | 14 | 42
Mean (SD) | 2.7 (2.3) | 1.9 (2.7) | 2.4 (2.5)
Median (Min-Max) | 2.5 (0.0 - 7.0) | 1.0 (0.0 - 9.0) | 2.0 (0.0 - 9.0)
BPRS-C Depression subscale at Week 24/LOCF
N | 28 | 14 | 42
Mean (SD) | 1.5 (2.4) | 2.6 (3.7) | 1.9 (2.9)
Median (Min-Max) | 0.0 (0.0 - 9.0) | 1.5 (0.0 - 13.0) | 0.0 (0.0 - 13.0)
Change in BPRS-C Depression subscale from Baseline to Week 24/LOCF
N | 28 | 14 | 42
Mean (SD) | −1.2 (3.1) | 0.8 (3.8) | −0.5 (3.4)
Median (Min-Max) | −1.0 (−6.0 - 7.0) | 0.0 (−9.0 - 7.0) | 0.0 (−9.0 - 7.0)
BPRS-C Thinking Disturbance subscale at Baseline
N | 28 | 14 | 42
Mean (SD) | 0.6 (1.3) | 0.2 (0.6) | 0.5 (1.1)
Median (Min-Max) | 0.0 (0.0 - 4.0) | 0.0 (0.0 - 2.0) | 0.0 (0.0 - 4.0)
BPRS-C Thinking Disturbance subscale at Week 24/LOCF
N | 28 | 14 | 42
Mean (SD) | 0.1 (0.4) | 0.3 (0.8) | 0.2 (0.6)
Median (Min-Max) | 0.0 (0.0 - 2.0) | 0.0 (0.0 - 3.0) | 0.0 (0.0 - 3.0)
Change in BPRS-C Thinking Disturbance subscale from Baseline to Week 24/LOCF
N | 28 | 14 | 42
Mean (SD) | −0.5 (1.4) | 0.1 (1.0) | −0.3 (1.3)
Median (Min-Max) | 0.0 (−4.0 - 2.0) | 0.0 (−2.0 - 3.0) | 0.0 (−4.0 - 3.0)
BPRS-C Psychomotor excitation subscale at Baseline
N | 28 | 14 | 42
Mean (SD) | 6.3 (3.4) | 3.9 (3.4) | 5.5 (3.6)
Median (Min-Max) | 5.0 (0.0 - 12.0) | 2.5 (0.0 - 10.0) | 5.0 (0.0 - 12.0)
BPRS-C Psychomotor excitation subscale at Week 24/LOCF
N | 28 | 14 | 42
Mean (SD) | 4.4 (4.0) | 3.8 (4.1) | 4.2 (4.0)
Median (Min-Max) | 3.0 (0.0 - 13.0) | 2.5 (0.0 - 10.0) | 3.0 (0.0 - 13.0)
Change in BPRS-C Psychomotor excitation subscale from Baseline to Week 24/LOCF
N | 28 | 14 | 42
Mean (SD) | −2.0 (4.7) | −0.1 (2.4) | −1.3 (4.1)
Median (Min-Max) | −3.0 (−11.0 - 9.0) | 0.0 (−5.0 - 5.0) | −2.0 (−11.0 - 9.0)
BPRS-C Withdrawal subscale at Baseline
N | 28 | 14 | 42
Mean (SD) | 1.3 (2.1) | 0.8 (1.1) | 1.1 (1.8)
Median (Min-Max) | 0.0 (0.0 - 8.0) | 0.0 (0.0 - 3.0) | 0.0 (0.0 - 8.0)
BPRS-C Withdrawal subscale at Week 24/LOCF
N | 28 | 14 | 42
Mean (SD) | 0.9 (2.2) | 1.4 (1.8) | 1.1 (2.1)
Median (Min-Max) | 0.0 (0.0 - 10.0) | 1.0 (0.0 - 6.0) | 0.0 (0.0 - 10.0)
Change in BPRS-C Withdrawal subscale from Baseline to Week 24/LOCF
N | 28 | 14 | 42
Mean (SD) | −0.4 (2.5) | 0.6 (1.5) | 0.0 (2.2)
Median (Min-Max) | 0.0 (−8.0 - 4.0) | 0.0 (−2.0 - 4.0) | 0.0 (−8.0 - 4.0)
BPRS-C Anxiety subscale at Baseline
N | 28 | 14 | 42
Mean (SD) | 3.7 (3.1) | 2.5 (1.3) | 3.3 (2.7)
Median (Min-Max) | 3.0 (0.0 - 12.0) | 2.5 (0.0 - 5.0) | 3.0 (0.0 - 12.0)
BPRS-C Anxiety subscale at Week 24/LOCF
N | 27 | 14 | 41
Mean (SD) | 3.9 (4.0) | 2.9 (2.4) | 3.6 (3.5)
Median (Min-Max) | 2.0 (0.0 - 14.0) | 2.5 (0.0 - 8.0) | 2.0 (0.0 - 14.0)
Change in BPRS-C Anxiety subscale from Baseline to Week 24/LOCF
N | 27 | 14 | 41
Mean (SD) | 0.3 (5.0) | 0.4 (3.0) | 0.4 (4.4)
Median (Min-Max) | 0.0 (−9.0 - 14.0) | 0.0 (−3.0 - 6.0) | 0.0 (−9.0 - 14.0)
BPRS-C Organicity subscale at Baseline
N | 28 | 14 | 42
Mean (SD) | 0.8 (1.9) | 0.1 (0.3) | 0.5 (1.5)
Median (Min-Max) | 0.0 (0.0 - 7.0) | 0.0 (0.0 - 1.0) | 0.0 (0.0 - 7.0)
BPRS-C Organicity subscale at Week 24/LOCF
N | 28 | 14 | 42
Mean (SD) | 0.4 (1.1) | 0.4 (0.9) | 0.4 (1.0)
Median (Min-Max) | 0.0 (0.0 - 5.0) | 0.0 (0.0 - 3.0) | 0.0 (0.0 - 5.0)
Change in BPRS-C Organicity subscale from Baseline to Week 24/LOCF
N | 28 | 14 | 42
Mean (SD) | −0.4 (2.3) | 0.3 (1.0) | −0.1 (1.9)
Median (Min-Max) | 0.0 (−7.0 - 5.0) | 0.0 (−1.0 - 3.0) | 0.0 (−7.0 - 5.0)

Note: Baseline is defined as the last visit of Efficacy Phase.

Change score is week 24/LOCF value minus baseline value.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.3.3B Tertiary Efficacy Endpoint: Brief Psychiatric Rating Scale-For Children (BPRS-C) by Efficacy Phase Randomized Treatment Group Long-Term Effectiveness Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=42)
| Lithium; (N=29) | Placebo; (N=13) | Total; (N=42)
BPRS-C Total score at Baseline
N | 29 | 13 | 42
Mean (SD) | 15.3 (11.7) | 25.6 (6.0) | 18.5 (11.2)
Median (Min-Max) | 14.0 (0.0 - 62.0) | 25.0 (18.0 - 38.0) | 19.0 (0.0 - 62.0)
BPRS-C Total score at Week 24/LOCF
N | 29 | 12 | 41
Mean (SD) | 16.0 (13.9) | 14.1 (15.5) | 15.4 (14.2)
Median (Min-Max) | 16.0 (0.0 - 48.0) | 6.5 (0.0 - 47.0) | 12.0 (0.0 - 48.0)
Change in BPRS-C Total score from Baseline to Week 24/LOCF
N | 29 | 12 | 41
Mean (SD) | 0.7 (14.8) | −10.5 (17.8) | −2.6 (16.3)
Median (Min-Max) | 2.0 (−38.0 - 26.0) | −17.5 (−29.0 - 26.0) | −2.0 (−38.0 - 26.0)
BPRS-C Behavior Problems subscale at Baseline
N | 29 | 13 | 42
Mean (SD) | 4.2 (3.6) | 7.2 (3.3) | 5.1 (3.7)
Median (Min-Max) | 4.0 (0.0 - 13.0) | 7.0 (2.0 - 12.0) | 4.5 (0.0 - 13.0)
BPRS-C Behavior Problems subscale at Week 24/LOCF
N | 29 | 13 | 42
Mean (SD) | 4.1 (4.5) | 3.7 (5.4) | 4.0 (4.8)
Median (Min-Max) | 2.0 (0.0 - 14.0) | 1.0 (0.0 - 15.0) | 1.5 (0.0 - 15.0)
Change in BPRS-C Behavior Problems subscale from Baseline to Week 24/LOCF
N | 29 | 13 | 42
Mean (SD) | −0.1 (4.8) | −3.5 (4.7) | −1.1 (5.0)
Median (Min-Max) | 0.0 (−11.0 - 13.0) | −4.0 (−9.0 - 4.0) | −0.5 (−11.0 - 13.0)
BPRS-C Depression subscale at Baseline
N | 29 | 13 | 42
Mean (SD) | 1.8 (2.0) | 3.8 (2.8) | 2.4 (2.5)
Median (Min-Max) | 1.0 (0.0 - 7.0) | 4.0 (0.0 - 9.0) | 2.0 (0.0 - 9.0)
BPRS-C Depression subscale at Week 24/LOCF
N | 29 | 13 | 42
Mean (SD) | 2.3 (3.2) | 0.8 (1.7) | 1.9 (2.9)
Median (Min-Max) | 1.0 (0.0 - 13.0) | 0.0 (0.0 - 5.0) | 0.0 (0.0 - 13.0)
Change in BPRS-C Depression subscale from Baseline to Week 24/LOCF
N | 29 | 13 | 42
Mean (SD) | 0.6 (2.9) | −3.0 (3.2) | −0.5 (3.4)
Median (Min-Max) | 0.0 (−5.0 - 7.0) | −4.0 (−9.0 - 2.0) | 0.0 (−9.0 - 7.0)
BPRS-C Thinking Disturbance subscale at Baseline
N | 29 | 13 | 42
Mean (SD) | 0.3 (0.8) | 1.0 (1.4) | 0.5 (1.1)
Median (Min-Max) | 0.0 (0.0 - 4.0) | 0.0 (0.0 - 4.0) | 0.0 (0.0 - 4.0)
BPRS-C Thinking Disturbance subscale at Week 24/LOCF
N | 29 | 13 | 42
Mean (SD) | 0.1 (0.4) | 0.3 (0.9) | 0.2 (0.6)
Median (Min-Max) | 0.0 (0.0 - 2.0) | 0.0 (0.0 - 3.0) | 0.0 (0.0 - 3.0)
Change in BPRS-C Thinking Disturbance subscale from Baseline to Week 24/LOCF
N | 29 | 13 | 42
Mean (SD) | −0.2 (0.9) | −0.7 (1.8) | −0.3 (1.3)
Median (Min-Max) | 0.0 (−4.0 - 2.0) | 0.0 (−4.0 - 3.0) | 0.0 (−4.0 - 3.0)
BPRS-C Psychomotor excitation subscale at Baseline
N | 29 | 13 | 42
Mean (SD) | 4.3 (3.2) | 8.1 (3.0) | 5.5 (3.6)
Median (Min-Max) | 4.0 (0.0 - 12.0) | 9.0 (1.0 - 12.0) | 5.0 (0.0 - 12.0)
BPRS-C Psychomotor excitation subscale at Week 24/LOCF
N | 29 | 13 | 42
Mean (SD) | 4.0 (4.1) | 4.5 (3.9) | 4.2 (4.0)
Median (Min-Max) | 3.0 (0.0 - 12.0) | 3.0 (0.0 - 13.0) | 3.0 (0.0 - 13.0)
Change in BPRS-C Psychomotor excitation subscale from Baseline to Week 24/LOCF
N | 29 | 13 | 42
Mean (SD) | −0.3 (3.2) | −3.5 (5.2) | −1.3 (4.1)
Median (Min-Max) | −1.0 (−5.0 - 9.0) | −5.0 (−11.0 - 8.0) | −2.0 (−11.0 - 9.0)
BPRS-C Withdrawal subscale at Baseline
N | 29 | 13 | 42
Mean (SD) | 0.9 (1.9) | 1.8 (1.5) | 1.1 (1.8)
Median (Min-Max) | 0.0 (0.0 - 8.0) | 2.0 (0.0 - 5.0) | 0.0 (0.0 - 8.0)
BPRS-C Withdrawal subscale at Week 24/LOCF
N | 29 | 13 | 42
Mean (SD) | 1.2 (2.3) | 0.8 (1.3) | 1.1 (2.1)
Median (Min-Max) | 0.0 (0.0 - 10.0) | 0.0 (0.0 - 4.0) | 0.0 (0.0 - 10.0)
Change in BPRS-C Withdrawal subscale from Baseline to Week 24/LOCF
N | 29 | 13 | 42
Mean (SD) | 0.3 (2.1) | −0.9 (2.3) | 0.0 (2.2)
Median (Min-Max) | 0.0 (−8.0 - 4.0) | 0.0 (−5.0 - 4.0) | 0.0 (−8.0 - 4.0)
BPRS-C Anxiety subscale at Baseline
N | 29 | 13 | 42
Mean (SD) | 3.5 (2.8) | 2.8 (2.4) | 3.3 (2.7)
Median (Min-Max) | 3.0 (0.0 - 12.0) | 3.0 (0.0 - 7.0) | 3.0 (0.0 - 12.0)
BPRS-C Anxiety subscale at Week 24/LOCF
N | 29 | 12 | 41
Mean (SD) | 3.9 (3.4) | 2.9 (3.9) | 3.6 (3.5)
Median (Min-Max) | 4.0 (0.0 - 11.0) | 2.0 (0.0 - 14.0) | 2.0 (0.0 - 14.0)
Change in BPRS-C Anxiety subscale from Baseline to Week 24/LOCF
N | 29 | 12 | 41
Mean (SD) | 0.3 (4.1) | 0.4 (5.1) | 0.4 (4.4)
Median (Min-Max) | 0.0 (−9.0 - 6.0) | 0.5 (−6.0 - 14.0) | 0.0 (−9.0 - 14.0)
BPRS-C Organicity subscale at Baseline
N | 29 | 13 | 42
Mean (SD) | 0.4 (1.4) | 0.8 (1.9) | 0.5 (1.5)
Median (Min-Max) | 0.0 (0.0 - 7.0) | 0.0 (0.0 - 6.0) | 0.0 (0.0 - 7.0)
BPRS-C Organicity subscale at Week 24/LOCF
N | 29 | 13 | 42
Mean (SD) | 0.4 (1.1) | 0.4 (0.9) | 0.4 (1.0)
Median (Min-Max) | 0.0 (0.0 - 5.0) | 0.0 (0.0 - 3.0) | 0.0 (0.0 - 5.0)
Change in BPRS-C Organicity subscale from Baseline to Week 24/LOCF
N | 29 | 13 | 42
Mean (SD) | 0.0 (1.8) | −0.5 (2.3) | −0.1 (1.9)
Median (Min-Max) | 0.0 (−7.0 - 5.0) | 0.0 (−6.0 - 3.0) | 0.0 (−7.0 - 5.0)

Note: Baseline is defined as the last visit of Efficacy Phase.

Change score is week 24/LOCF value minus baseline value.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.3.4A Tertiary Efficacy Endpoint: Pediatric Anxiety Rating Scale (PARS) by Age Strata Long-Term Effectiveness Phase - Efficacy Population

| Age Strata | | Total; (N=42)
| 7 - 11 yrs; (N=28) | 12 - 17 yrs; (N=14) | Total; (N=42)
Total Score at Baseline
N | 27 | 14 | 41
Mean (SD) | 9.7 (7.3) | 7.8 (5.8) | 9.0 (6.8)
Median (Min-Max) | 10.0 (0.0 - 21.0) | 6.0 (0.0 - 19.0) | 10.0 (0.0 - 21.0)
Total Score at Week 24/LOCF
N | 27 | 14 | 41
Mean (SD) | 5.5 (7.3) | 5.8 (6.6) | 5.6 (7.0)
Median (Min-Max) | 3.0 (0.0 - 26.0) | 3.5 (0.0 - 19.0) | 3.0 (0.0 - 26.0)
Change in Total Score from Baseline to Week 24/LOCF
N | 26 | 14 | 40
Mean (SD) | −3.9 (9.7) | −2.0 (4.3) | −3.2 (8.2)
Median (Min-Max) | −5.5 (−19.0 - 15.0) | −0.5 (−15.0 - 2.0) | −1.0 (−19.0 - 15.0)
Subscale Score at Baseline
N | 27 | 14 | 41
Mean (SD) | 6.5 (5.0) | 5.6 (4.7) | 6.2 (4.9)
Median (Min-Max) | 6.0 (0.0 - 15.0) | 4.5 (0.0 - 14.0) | 6.0 (0.0 - 15.0)
Subscale Score at Week 24/LOCF
N | 27 | 14 | 41
Mean (SD) | 3.4 (4.7) | 3.6 (4.2) | 3.5 (4.5)
Median (Min-Max) | 2.0 (0.0 - 17.0) | 2.0 (0.0 - 12.0) | 2.0 (0.0 - 17.0)
Change in Subscale Score from Baseline to Week 24/LOCF
N | 26 | 14 | 40
Mean (SD) | −2.9 (6.3) | −2.0 (3.6) | −2.6 (5.5)
Median (Min-Max) | −5.5 (−13.0 - 9.0) | −1.0 (−13.0 - 1.0) | −2.0 (−13.0 - 9.0)

Note: Baseline is defined as the last visit of Efficacy Phase.

Change score is week 24/LOCF value minus baseline value.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.3.4B Tertiary Efficacy Endpoint: Pediatric Anxiety Rating Scale (PARS) by Efficacy Phase Randomized Treatment Group Long-Term Effectiveness Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=42)
| Lithium; (N=29) | Placebo; (N=13) | Total; (N=42)
Total Score at Baseline
N | 28 | 13 | 41
Mean (SD) | 9.1 (6.7) | 8.8 (7.4) | 9.0 (6.8)
Median (Min-Max) | 10.0 (0.0 - 20.0) | 9.0 (0.0 - 21.0) | 10.0 (0.0 - 21.0)
Total Score at Week 24/LOCF
N | 28 | 13 | 41
Mean (SD) | 6.9 (7.7) | 2.8 (4.2) | 5.6 (7.0)
Median (Min-Max) | 5.0 (0.0 - 26.0) | 0.0 (0.0 - 14.0) | 3.0 (0.0 - 26.0)
Change in Total Score from Baseline to Week 24/LOCF
N | 27 | 13 | 40
Mean (SD) | −1.9 (8.1) | −6.0 (8.0) | −3.2 (8.2)
Median (Min-Max) | 0.0 (−19.0 - 15.0) | −4.0 (−18.0 - 8.0) | −1.0 (−19.0 - 15.0)
Subscale Score at Baseline
N | 28 | 13 | 41
Mean (SD) | 6.2 (4.8) | 6.1 (5.2) | 6.2 (4.9)
Median (Min-Max) | 6.0 (0.0 - 14.0) | 6.0 (0.0 - 15.0) | 6.0 (0.0 - 15.0)
Subscale Score at Week 24/LOCF
N | 28 | 13 | 41
Mean (SD) | 4.4 (4.9) | 1.6 (2.7) | 3.5 (4.5)
Median (Min-Max) | 3.0 (0.0 - 17.0) | 0.0 (0.0 - 9.0) | 2.0 (0.0 - 17.0)
Change in Subscale Score from Baseline to Week 24/LOCF
N | 27 | 13 | 40
Mean (SD) | −1.7 (5.5) | −4.5 (5.2) | −2.6 (5.5)
Median (Min-Max) | 0.0 (−13.0 - 9.0) | −3.0 (−13.0 - 5.0) | −2.0 (−13.0 - 9.0)

Note: Baseline is defined as the last visit of Efficacy Phase.

Change score is week 24/LOCF value minus baseline value.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.4.1A Descriptive Efficacy Endpoint: Family Environmental Scale (FES) by Age Strata Long-Term Effectiveness Phase - Efficacy Population

| Age Strata | | Total; (N=42)
| 7 - 11 yrs; (N=28) | 12 - 17 yrs; (N=14) | Total; (N=42)
Cohesion subscale at Baseline
N | 13 | 9 | 22
Mean (SD) | 6.9 (1.7) | 5.3 (2.3) | 6.3 (2.1)
Median (Min-Max) | 7.0 (3.0 - 9.0) | 6.0 (2.0 - 9.0) | 6.5 (2.0 - 9.0)
Cohesion subscale at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 7.1 (1.1) | 5.6 (2.2) | 6.4 (1.9)
Median (Min-Max) | 7.0 (6.0 - 9.0) | 6.0 (2.0 - 9.0) | 6.5 (2.0 - 9.0)
Change in Cohesion subscale from Baseline to Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 0.0 (1.2) | 0.3 (2.0) | 0.1 (1.6)
Median (Min-Max) | 0.0 (−2.0 - 1.0) | 0.0 (−2.0 - 4.0) | 0.0 (−2.0 - 4.0)
Expressiveness subscale at Baseline
N | 13 | 9 | 22
Mean (SD) | 6.4 (1.1) | 7.2 (1.1) | 6.7 (1.2)
Median (Min-Max) | 7.0 (5.0 - 8.0) | 7.0 (5.0 - 9.0) | 7.0 (5.0 - 9.0)
Expressiveness subscale at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 6.3 (1.6) | 6.9 (1.9) | 6.6 (1.7)
Median (Min-Max) | 7.0 (4.0 - 8.0) | 8.0 (4.0 - 9.0) | 7.0 (4.0 - 9.0)
Change in Expressiveness subscale from Baseline to Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | −0.1 (0.7) | −0.4 (1.9) | −0.3 (1.4)
Median (Min-Max) | 0.0 (−1.0 - 1.0) | 0.0 (−3.0 - 3.0) | 0.0 (−3.0 - 3.0)
Conflict subscale at Baseline
N | 13 | 9 | 22
Mean (SD) | 3.7 (2.3) | 4.8 (2.7) | 4.1 (2.5)
Median (Min-Max) | 3.0 (0.0 - 9.0) | 4.0 (0.0 - 9.0) | 4.0 (0.0 - 9.0)
Conflict subscale at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 5.4 (3.0) | 4.4 (1.6) | 4.9 (2.4)
Median (Min-Max) | 7.0 (0.0 - 8.0) | 4.0 (2.0 - 6.0) | 5.5 (0.0 - 8.0)
Change in Conflict subscale from Baseline to Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 1.3 (2.1) | 0.1 (2.0) | 0.7 (2.1)
Median (Min-Max) | 1.0 (−1.0 - 5.0) | 0.0 (−3.0 - 3.0) | 0.5 (−3.0 - 5.0)
Independence subscale at Baseline
N | 13 | 9 | 22
Mean (SD) | 5.9 (1.4) | 5.3 (1.0) | 5.7 (1.3)
Median (Min-Max) | 6.0 (3.0 - 8.0) | 5.0 (4.0 - 7.0) | 6.0 (3.0 - 8.0)
Independence subscale at Week 24/LOCF
N | 7 | 6 | 13
Mean (SD) | 5.4 (1.4) | 6.0 (1.5) | 5.7 (1.4)
Median (Min-Max) | 5.0 (4.0 - 8.0) | 6.0 (4.0 - 8.0) | 5.0 (4.0 - 8.0)
Change in Independence subscale from Baseline to Week 24/LOCF
N | 7 | 6 | 13
Mean (SD) | −0.6 (1.5) | 0.8 (1.3) | 0.1 (1.6)
Median (Min-Max) | −1.0 (−2.0 - 2.0) | 1.0 (−1.0 - 3.0) | 0.0 (−2.0 - 3.0)
Achievement subscale at Baseline
N | 13 | 9 | 22
Mean (SD) | 5.5 (1.3) | 5.0 (2.3) | 5.3 (1.8)
Median (Min-Max) | 6.0 (3.0 - 8.0) | 5.0 (1.0 - 9.0) | 5.0 (1.0 - 9.0)
Achievement subscale at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 6.7 (1.6) | 4.7 (2.3) | 5.7 (2.2)
Median (Min-Max) | 7.0 (4.0 - 9.0) | 4.0 (2.0 - 7.0) | 6.5 (2.0 - 9.0)
Change in Achievement subscale from Baseline to Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 1.4 (1.3) | −0.4 (1.7) | 0.5 (1.7)
Median (Min-Max) | 2.0 (−1.0 - 3.0) | 0.0 (−3.0 - 2.0) | 1.0 (−3.0 - 3.0)
Intellectual-Cultural subscale at Baseline
N | 13 | 9 | 22
Mean (SD) | 5.9 (1.4) | 6.0 (1.9) | 6.0 (1.6)
Median (Min-Max) | 6.0 (3.0 - 9.0) | 6.0 (2.0 - 9.0) | 6.0 (2.0 - 9.0)
Intellectual-Cultural subscale at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 4.9 (1.7) | 5.6 (1.7) | 5.2 (1.7)
Median (Min-Max) | 5.0 (2.0 - 7.0) | 6.0 (3.0 - 8.0) | 5.5 (2.0 - 8.0)
Change in Intellectual-Cultural subscale from Baseline to Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | −0.6 (1.4) | 0.0 (0.8) | −0.3 (1.1)
Median (Min-Max) | −1.0 (−3.0 - 1.0) | 0.0 (−1.0 - 1.0) | 0.0 (−3.0 - 1.0)
Active-Recreational subscale at Baseline
N | 13 | 9 | 22
Mean (SD) | 5.2 (2.1) | 3.6 (2.3) | 4.5 (2.3)
Median (Min-Max) | 5.0 (2.0 - 9.0) | 3.0 (0.0 - 7.0) | 4.0 (0.0 - 9.0)
Active-Recreational subscale at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 4.9 (2.9) | 2.9 (2.9) | 3.9 (3.0)
Median (Min-Max) | 4.0 (1.0 - 9.0) | 2.0 (0.0 - 7.0) | 4.0 (0.0 - 9.0)
Change in Active-Recreational subscale from Baseline to Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | −0.3 (2.6) | −0.3 (1.4) | −0.3 (2.0)
Median (Min-Max) | 0.0 (−5.0 - 2.0) | 0.0 (−2.0 - 2.0) | 0.0 (−5.0 - 2.0)
Moral-Religious subscale at Baseline
N | 12 | 9 | 21
Mean (SD) | 6.6 (1.6) | 3.8 (1.6) | 5.4 (2.1)
Median (Min-Max) | 7.0 (4.0 - 9.0) | 3.0 (2.0 - 7.0) | 6.0 (2.0 - 9.0)
Moral-Religious subscale at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 7.0 (2.0) | 4.4 (1.5) | 5.7 (2.2)
Median (Min-Max) | 8.0 (4.0 - 9.0) | 4.0 (3.0 - 7.0) | 5.5 (3.0 - 9.0)
Change in Moral-Religious subscale from Baseline to Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | −0.1 (1.6) | 0.9 (1.2) | 0.4 (1.4)
Median (Min-Max) | 0.0 (−2.0 - 2.0) | 0.0 (0.0 - 3.0) | 0.0 (−2.0 - 3.0)
Organization subscale at Baseline
N | 13 | 9 | 22
Mean (SD) | 5.6 (2.3) | 4.0 (2.2) | 5.0 (2.3)
Median (Min-Max) | 6.0 (1.0 - 9.0) | 3.0 (1.0 - 7.0) | 5.0 (1.0 - 9.0)
Organization subscale at Week 24/LOCF
N | 7 | 6 | 13
Mean (SD) | 7.3 (1.5) | 4.3 (1.9) | 5.9 (2.2)
Median (Min-Max) | 7.0 (5.0 - 9.0) | 4.0 (2.0 - 7.0) | 6.0 (2.0 - 9.0)
Change in Organization subscale from Baseline to Week 24/LOCF
N | 7 | 6 | 13
Mean (SD) | 0.9 (1.2) | 0.5 (1.2) | 0.7 (1.2)
Median (Min-Max) | 1.0 (−1.0 - 3.0) | 0.0 (0.0 - 3.0) | 0.0 (−1.0 - 3.0)
Control subscale at Baseline
N | 13 | 9 | 22
Mean (SD) | 5.5 (1.5) | 5.0 (1.9) | 5.3 (1.6)
Median (Min-Max) | 5.0 (3.0 - 8.0) | 5.0 (3.0 - 8.0) | 5.0 (3.0 - 8.0)
Control subscale at Week 24/LOCF
N | 7 | 6 | 13
Mean (SD) | 6.3 (1.5) | 4.0 (1.4) | 5.2 (1.8)
Median (Min-Max) | 7.0 (3.0 - 7.0) | 4.0 (2.0 - 6.0) | 6.0 (2.0 - 7.0)
Change in Control subscale from Baseline to Week 24/LOCF
N | 7 | 6 | 13
Mean (SD) | 0.1 (1.2) | −0.5 (0.8) | −0.2 (1.1)
Median (Min-Max) | 0.0 (−2.0 - 2.0) | 0.0 (−2.0 - 0.0) | 0.0 (−2.0 - 2.0)

Note: Baseline is defined as the last visit of Efficacy Phase.

Change score is week 24/LOCF value minus baseline value.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.4.1B Descriptive Efficacy Endpoint: Family Environmental Scale (FES) by Efficacy Phase Randomized Treatment Group Long-Term Effectiveness Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=42)
| Lithium; (N=29) | Placebo; (N=13) | Total; (N=42)
Cohesion subscale at Baseline
N | 18 | 4 | 22
Mean (SD) | 6.4 (2.0) | 5.5 (2.5) | 6.3 (2.1)
Median (Min-Max) | 7.0 (3.0 - 9.0) | 6.0 (2.0 - 8.0) | 6.5 (2.0 - 9.0)
Cohesion subscale at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 6.4 (2.0) | 6.0 (1.4) | 6.4 (1.9)
Median (Min-Max) | 6.5 (2.0 - 9.0) | 6.0 (5.0 - 7.0) | 6.5 (2.0 - 9.0)
Change in Cohesion subscale from Baseline to Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 0.2 (1.6) | 0.0 (1.4) | 0.1 (1.6)
Median (Min-Max) | 0.0 (−2.0 - 4.0) | 0.0 (−1.0 - 1.0) | 0.0 (−2.0 - 4.0)
Expressiveness subscale at Baseline
N | 18 | 4 | 22
Mean (SD) | 6.8 (1.2) | 6.5 (1.3) | 6.7 (1.2)
Median (Min-Max) | 7.0 (5.0 - 9.0) | 6.5 (5.0 - 8.0) | 7.0 (5.0 - 9.0)
Expressiveness subscale at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 6.7 (1.6) | 6.0 (2.8) | 6.6 (1.7)
Median (Min-Max) | 7.0 (4.0 - 9.0) | 6.0 (4.0 - 8.0) | 7.0 (4.0 - 9.0)
Change in Expressiveness subscale from Baseline to Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | −0.3 (1.5) | −0.5 (0.7) | −0.3 (1.4)
Median (Min-Max) | 0.0 (−3.0 - 3.0) | −0.5 (−1.0 - 0.0) | 0.0 (−3.0 - 3.0)
Conflict subscale at Baseline
N | 18 | 4 | 22
Mean (SD) | 3.9 (2.4) | 5.3 (3.0) | 4.1 (2.5)
Median (Min-Max) | 3.5 (0.0 - 9.0) | 5.0 (2.0 - 9.0) | 4.0 (0.0 - 9.0)
Conflict subscale at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 4.7 (2.5) | 6.5 (0.7) | 4.9 (2.4)
Median (Min-Max) | 4.5 (0.0 - 8.0) | 6.5 (6.0 - 7.0) | 5.5 (0.0 - 8.0)
Change in Conflict subscale from Baseline to Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 0.6 (2.1) | 1.5 (2.1) | 0.7 (2.1)
Median (Min-Max) | 0.5 (−3.0 - 5.0) | 1.5 (0.0 - 3.0) | 0.5 (−3.0 - 5.0)
Independence subscale at Baseline
N | 18 | 4 | 22
Mean (SD) | 5.6 (1.4) | 6.0 (0.0) | 5.7 (1.3)
Median (Min-Max) | 6.0 (3.0 - 8.0) | 6.0 (6.0 - 6.0) | 6.0 (3.0 - 8.0)
Independence subscale at Week 24/LOCF
N | 11 | 2 | 13
Mean (SD) | 5.6 (1.5) | 6.0 (1.4) | 5.7 (1.4)
Median (Min-Max) | 5.0 (4.0 - 8.0) | 6.0 (5.0 - 7.0) | 5.0 (4.0 - 8.0)
Change in Independence subscale from Baseline to Week 24/LOCF
N | 11 | 2 | 13
Mean (SD) | 0.1 (1.6) | 0.0 (1.4) | 0.1 (1.6)
Median (Min-Max) | 0.0 (−2.0 - 3.0) | 0.0 (−1.0 - 1.0) | 0.0 (−2.0 - 3.0)
Achievement subscale at Baseline
N | 18 | 4 | 22
Mean (SD) | 5.3 (1.8) | 5.0 (1.4) | 5.3 (1.8)
Median (Min-Max) | 5.0 (1.0 - 9.0) | 5.5 (3.0 - 6.0) | 5.0 (1.0 - 9.0)
Achievement subscale at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 5.3 (2.1) | 8.0 (1.4) | 5.7 (2.2)
Median (Min-Max) | 6.0 (2.0 - 8.0) | 8.0 (7.0 - 9.0) | 6.5 (2.0 - 9.0)
Change in Achievement subscale from Baseline to Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 0.2 (1.6) | 2.5 (0.7) | 0.5 (1.7)
Median (Min-Max) | 0.5 (−3.0 - 2.0) | 2.5 (2.0 - 3.0) | 1.0 (−3.0 - 3.0)
Intellectual-Cultural subscale at Baseline
N | 18 | 4 | 22
Mean (SD) | 5.8 (1.8) | 6.5 (0.6) | 6.0 (1.6)
Median (Min-Max) | 6.0 (2.0 - 9.0) | 6.5 (6.0 - 7.0) | 6.0 (2.0 - 9.0)
Intellectual-Cultural subscale at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 5.0 (1.6) | 6.5 (2.1) | 5.2 (1.7)
Median (Min-Max) | 5.5 (2.0 - 7.0) | 6.5 (5.0 - 8.0) | 5.5 (2.0 - 8.0)
Change in Intellectual-Cultural subscale from Baseline to Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | −0.3 (1.2) | 0.0 (1.4) | −0.3 (1.1)
Median (Min-Max) | 0.0 (−3.0 - 1.0) | 0.0 (−1.0 - 1.0) | 0.0 (−3.0 - 1.0)
Active-Recreational subscale at Baseline
N | 18 | 4 | 22
Mean (SD) | 4.1 (2.0) | 6.8 (2.6) | 4.5 (2.3)
Median (Min-Max) | 4.0 (0.0 - 7.0) | 7.5 (3.0 - 9.0) | 4.0 (0.0 - 9.0)
Active-Recreational subscale at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 3.3 (2.9) | 7.0 (0.0) | 3.9 (3.0)
Median (Min-Max) | 3.0 (0.0 - 9.0) | 7.0 (7.0 - 7.0) | 4.0 (0.0 - 9.0)
Change in Active-Recreational subscale from Baseline to Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | −0.3 (2.2) | −0.5 (0.7) | −0.3 (2.0)
Median (Min-Max) | 0.0 (−5.0 - 2.0) | −0.5 (−1.0 - 0.0) | 0.0 (−5.0 - 2.0)
Moral-Religious subscale at Baseline
N | 17 | 4 | 21
Mean (SD) | 5.2 (2.2) | 6.3 (1.7) | 5.4 (2.1)
Median (Min-Max) | 5.0 (2.0 - 9.0) | 6.5 (4.0 - 8.0) | 6.0 (2.0 - 9.0)
Moral-Religious subscale at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 5.6 (2.1) | 6.5 (3.5) | 5.7 (2.2)
Median (Min-Max) | 5.5 (3.0 - 9.0) | 6.5 (4.0 - 9.0) | 5.5 (3.0 - 9.0)
Change in Moral-Religious subscale from Baseline to Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 0.3 (1.6) | 0.5 (0.7) | 0.4 (1.4)
Median (Min-Max) | 0.0 (−2.0 - 3.0) | 0.5 (0.0 - 1.0) | 0.0 (−2.0 - 3.0)
Organization subscale at Baseline
N | 18 | 4 | 22
Mean (SD) | 4.9 (2.5) | 5.0 (1.8) | 5.0 (2.3)
Median (Min-Max) | 5.0 (1.0 - 9.0) | 5.0 (3.0 - 7.0) | 5.0 (1.0 - 9.0)
Organization subscale at Week 24/LOCF
N | 11 | 2 | 13
Mean (SD) | 6.0 (2.3) | 5.5 (2.1) | 5.9 (2.2)
Median (Min-Max) | 6.0 (2.0 - 9.0) | 5.5 (4.0 - 7.0) | 6.0 (2.0 - 9.0)
Change in Organization subscale from Baseline to Week 24/LOCF
N | 11 | 2 | 13
Mean (SD) | 0.7 (1.3) | 0.5 (0.7) | 0.7 (1.2)
Median (Min-Max) | 0.0 (−1.0 - 3.0) | 0.5 (0.0 - 1.0) | 0.0 (−1.0 - 3.0)
Control subscale at Baseline
N | 18 | 4 | 22
Mean (SD) | 5.5 (1.6) | 4.5 (1.9) | 5.3 (1.6)
Median (Min-Max) | 5.5 (3.0 - 8.0) | 4.0 (3.0 - 7.0) | 5.0 (3.0 - 8.0)
Control subscale at Week 24/LOCF
N | 11 | 2 | 13
Mean (SD) | 5.4 (1.6) | 4.5 (3.5) | 5.2 (1.8)
Median (Min-Max) | 6.0 (3.0 - 7.0) | 4.5 (2.0 - 7.0) | 6.0 (2.0 - 7.0)
Change in Control subscale from Baseline to Week 24/LOCF
N | 11 | 2 | 13
Mean (SD) | −0.3 (0.9) | 0.5 (2.1) | −0.2 (1.1)
Median (Min-Max) | 0.0 (−2.0 - 1.0) | 0.5 (−1.0 - 2.0) | 0.0 (−2.0 - 2.0)

Note: Baseline is defined as the last visit of Efficacy Phase.

Change score is week 24/LOCF value minus baseline value.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.4.2A Descriptive Efficacy Endpoint: Caregiver Strain Questionnaire (CSQ) by Age Strata Long-Term Effectiveness Phase - Efficacy Population

| Age Strata | | Total; (N=42)
| 7 - 11 yrs; (N=28) | 12 - 17 yrs; (N=14) | Total; (N=42)
Total Score at Baseline
N | 13 | 9 | 22
Mean (SD) | 59.4 (22.6) | 47.4 (17.0) | 54.5 (20.9)
Median (Min-Max) | 70.0 (22.0 - 85.0) | 45.0 (28.0 - 73.0) | 49.5 (22.0 - 85.0)
Total Score at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 52.0 (19.2) | 43.1 (17.5) | 47.6 (18.2)
Median (Min-Max) | 50.0 (30.0 - 73.0) | 48.0 (22.0 - 68.0) | 48.5 (22.0 - 73.0)
Change in Total Score from Baseline to Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | −4.3 (10.4) | −2.9 (10.4) | −3.6 (10.1)
Median (Min-Max) | −8.0 (−15.0 - 16.0) | −3.0 (−18.0 - 14.0) | −7.0 (−18.0 - 16.0)
Objective Strain at Baseline
N | 13 | 9 | 22
Mean (SD) | 30.6 (13.3) | 23.6 (9.1) | 27.7 (12.1)
Median (Min-Max) | 37.0 (11.0 - 49.0) | 21.0 (15.0 - 39.0) | 23.5 (11.0 - 49.0)
Objective Strain at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 26.6 (11.5) | 21.7 (7.8) | 24.1 (9.8)
Median (Min-Max) | 26.0 (11.0 - 41.0) | 23.0 (12.0 - 32.0) | 24.5 (11.0 - 41.0)
Change in Objective Strain from Baseline to Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | −3.6 (6.5) | −0.7 (6.8) | −2.1 (6.5)
Median (Min-Max) | −5.0 (−11.0 - 7.0) | −4.0 (−7.0 - 11.0) | −4.5 (−11.0 - 11.0)
Subjective Strain at Baseline
N | 13 | 9 | 22
Mean (SD) | 28.8 (10.3) | 23.9 (8.5) | 26.8 (9.7)
Median (Min-Max) | 30.0 (11.0 - 41.0) | 24.0 (12.0 - 36.0) | 27.5 (11.0 - 41.0)
Subjective Strain at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 25.4 (8.3) | 21.4 (10.3) | 23.4 (9.2)
Median (Min-Max) | 24.0 (15.0 - 37.0) | 22.0 (10.0 - 39.0) | 23.0 (10.0 - 39.0)
Change in Subjective Strain from Baseline to Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | −0.7 (5.9) | −2.1 (5.0) | −1.4 (5.3)
Median (Min-Max) | 1.0 (−9.0 - 9.0) | −1.0 (−11.0 - 3.0) | −1.0 (−11.0 - 9.0)
Internalized Subjective Strain at Baseline
N | 13 | 9 | 22
Mean (SD) | 20.1 (7.6) | 16.4 (6.1) | 18.6 (7.1)
Median (Min-Max) | 23.0 (7.0 - 28.0) | 16.0 (8.0 - 25.0) | 20.5 (7.0 - 28.0)
Internalized Subjective Strain at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 18.1 (5.9) | 15.0 (7.7) | 16.6 (6.8)
Median (Min-Max) | 17.0 (10.0 - 25.0) | 16.0 (6.0 - 27.0) | 16.5 (6.0 - 27.0)
Change in Internalized Subjective Strain from Baseline to Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | −0.9 (5.4) | −1.6 (3.4) | −1.2 (4.4)
Median (Min-Max) | 0.0 (−10.0 - 8.0) | −1.0 (−8.0 - 2.0) | −1.0 (−10.0 - 8.0)
Externalized Subjective Strain at Baseline
N | 13 | 9 | 22
Mean (SD) | 8.7 (3.3) | 7.4 (2.9) | 8.2 (3.2)
Median (Min-Max) | 8.0 (4.0 - 14.0) | 8.0 (4.0 - 12.0) | 8.0 (4.0 - 14.0)
Externalized Subjective Strain at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 7.3 (2.7) | 6.4 (3.0) | 6.9 (2.8)
Median (Min-Max) | 7.0 (4.0 - 12.0) | 5.0 (4.0 - 12.0) | 6.0 (4.0 - 12.0)
Change in Externalized Subjective Strain from Baseline to Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 0.1 (1.6) | −0.6 (1.7) | −0.2 (1.6)
Median (Min-Max) | 1.0 (−2.0 - 2.0) | 0.0 (−3.0 - 1.0) | 0.0 (−3.0 - 2.0)

Note: Baseline is defined as the last visit of Efficacy Phase.

Change score is week 24/LOCF value minus baseline value.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.4.2B Descriptive Efficacy Endpoint: Caregiver Strain Questionnaire (CSQ) by Efficacy Phase Randomized Treatment Group Long-Term Effectiveness Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=42)
| Lithium; (N=29) | Placebo; (N=13) | Total; (N=42)
Total Score at Baseline
N | 18 | 4 | 22
Mean (SD) | 52.1 (22.0) | 65.5 (11.4) | 54.5 (20.9)
Median (Min-Max) | 44.5 (22.0 - 85.0) | 66.0 (53.0 - 77.0) | 49.5 (22.0 - 85.0)
Total Score at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 48.3 (19.6) | 43.0 (7.1) | 47.6 (18.2)
Median (Min-Max) | 49.5 (22.0 - 73.0) | 43.0 (38.0 - 48.0) | 48.5 (22.0 - 73.0)
Change in Total Score from Baseline to Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | −2.0 (10.0) | −13.0 (2.8) | −3.6 (10.1)
Median (Min-Max) | −4.5 (−18.0 - 16.0) | −13.0 (−15.0 - −11.0) | −7.0 (−18.0 - 16.0)
Objective Strain at Baseline
N | 18 | 4 | 22
Mean (SD) | 26.5 (12.8) | 33.3 (6.6) | 27.7 (12.1)
Median (Min-Max) | 21.5 (11.0 - 49.0) | 34.5 (25.0 - 39.0) | 23.5 (11.0 - 49.0)
Objective Strain at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 24.4 (10.5) | 22.5 (4.9) | 24.1 (9.8)
Median (Min-Max) | 24.5 (11.0 - 41.0) | 22.5 (19.0 - 26.0) | 24.5 (11.0 - 41.0)
Change in Objective Strain from Baseline to Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | −1.6 (6.9) | −5.5 (0.7) | −2.1 (6.5)
Median (Min-Max) | −3.0 (−11.0 - 11.0) | −5.5 (−6.0 - −5.0) | −4.5 (−11.0 - 11.0)
Subjective Strain at Baseline
N | 18 | 4 | 22
Mean (SD) | 25.6 (10.1) | 32.3 (5.3) | 26.8 (9.7)
Median (Min-Max) | 24.5 (11.0 - 41.0) | 31.0 (28.0 - 39.0) | 27.5 (11.0 - 41.0)
Subjective Strain at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 23.9 (9.9) | 20.5 (2.1) | 23.4 (9.2)
Median (Min-Max) | 25.0 (10.0 - 39.0) | 20.5 (19.0 - 22.0) | 23.0 (10.0 - 39.0)
Change in Subjective Strain from Baseline to Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | −0.4 (5.0) | −7.5 (2.1) | −1.4 (5.3)
Median (Min-Max) | 0.0 (−11.0 - 9.0) | −7.5 (−9.0 - −6.0) | −1.0 (−11.0 - 9.0)
Internalized Subjective Strain at Baseline
N | 18 | 4 | 22
Mean (SD) | 17.6 (7.4) | 23.0 (3.7) | 18.6 (7.1)
Median (Min-Max) | 17.5 (7.0 - 28.0) | 22.5 (19.0 - 28.0) | 20.5 (7.0 - 28.0)
Internalized Subjective Strain at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 16.9 (7.3) | 14.5 (2.1) | 16.6 (6.8)
Median (Min-Max) | 17.5 (6.0 - 27.0) | 14.5 (13.0 - 16.0) | 16.5 (6.0 - 27.0)
Change in Internalized Subjective Strain from Baseline to Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | −0.3 (3.8) | −6.5 (4.9) | −1.2 (4.4)
Median (Min-Max) | −0.5 (−8.0 - 8.0) | −6.5 (−10.0 - −3.0) | −1.0 (−10.0 - 8.0)
Externalized Subjective Strain at Baseline
N | 18 | 4 | 22
Mean (SD) | 7.9 (3.2) | 9.3 (3.1) | 8.2 (3.2)
Median (Min-Max) | 7.5 (4.0 - 14.0) | 10.0 (5.0 - 12.0) | 8.0 (4.0 - 14.0)
Externalized Subjective Strain at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 7.0 (3.0) | 6.0 (0.0) | 6.9 (2.8)
Median (Min-Max) | 6.0 (4.0 - 12.0) | 6.0 (6.0 - 6.0) | 6.0 (4.0 - 12.0)
Change in Externalized Subjective Strain from Baseline to Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | −0.1 (1.5) | −1.0 (2.8) | −0.2 (1.6)
Median (Min-Max) | 0.0 (−3.0 - 2.0) | −1.0 (−3.0 - 1.0) | 0.0 (−3.0 - 2.0)

Note: Baseline is defined as the last visit of Efficacy Phase.

Change score is week 24/LOCF value minus baseline value.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.4.3A Descriptive Efficacy Endpoint: Irritability, Depression and Anxiety (IDA) by Age Strata Long-Term Effectiveness Phase - Efficacy Population

| Age Strata | | Total; (N=42)
| 7 - 11 yrs; (N=28) | 12 - 17 yrs; (N=14) | Total; (N=42)
Outward Irritability Score at Baseline
N | 13 | 9 | 22
Mean (SD) | 6.5 (3.7) | 5.7 (3.5) | 6.2 (3.5)
Median (Min-Max) | 7.0 (1.0 - 11.0) | 5.0 (0.0 - 11.0) | 6.5 (0.0 - 11.0)
Outward Irritability Score at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 5.6 (4.1) | 5.0 (3.9) | 5.3 (3.9)
Median (Min-Max) | 7.0 (1.0 - 10.0) | 2.0 (2.0 - 10.0) | 4.5 (1.0 - 10.0)
Change in Outward Irritability Score from Baseline to Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 0.0 (3.9) | 0.0 (2.3) | 0.0 (3.1)
Median (Min-Max) | 0.0 (−6.0 - 6.0) | 0.0 (−3.0 - 3.0) | 0.0 (−6.0 - 6.0)

Note: Baseline is defined as the last visit of Efficacy Phase.

Change score is week 24/LOCF value minus baseline value.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.4.3B Descriptive Efficacy Endpoint: Irritability, Depression and Anxiety (IDA) by Efficacy Phase Randomized Treatment Group Long-Term Effectiveness Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=42)
| Lithium; (N=29) | Placebo; (N=13) | Total; (N=42)
Outward Irritability Score at Baseline
N | 18 | 4 | 22
Mean (SD) | 5.6 (3.5) | 9.0 (1.8) | 6.2 (3.5)
Median (Min-Max) | 5.0 (0.0 - 11.0) | 9.0 (7.0 - 11.0) | 6.5 (0.0 - 11.0)
Outward Irritability Score at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 4.8 (3.9) | 8.5 (2.1) | 5.3 (3.9)
Median (Min-Max) | 2.0 (1.0 - 10.0) | 8.5 (7.0 - 10.0) | 4.5 (1.0 - 10.0)
Change in Outward Irritability Score from Baseline to Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 0.1 (3.3) | −0.5 (0.7) | 0.0 (3.1)
Median (Min-Max) | 0.5 (−6.0 - 6.0) | −0.5 (−1.0 - 0.0) | 0.0 (−6.0 - 6.0)

Note: Baseline is defined as the last visit of Efficacy Phase.

Change score is week 24/LOCF value minus baseline value.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.4.4A Descriptive Efficacy Endpoint: Nisonger Child Behavior Rating Form (NCBRF-TIQ) by Age Strata Long-Term Effectiveness Phase - Efficacy Population

| Age Strata | | Total; (N=42)
| 7 - 11 yrs; (N=28) | 12 - 17 yrs; (N=14) | Total; (N=42)
Positive Social Subscale at Baseline
N | 13 | 9 | 22
Mean (SD) | 12.8 (3.9) | 16.0 (6.5) | 14.1 (5.2)
Median (Min-Max) | 12.0 (5.0 - 20.0) | 14.0 (8.0 - 30.0) | 13.0 (5.0 - 30.0)
Positive Social Subscale at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 14.4 (4.4) | 13.9 (6.3) | 14.1 (5.2)
Median (Min-Max) | 15.0 (9.0 - 20.0) | 11.0 (9.0 - 27.0) | 13.0 (9.0 - 27.0)
Change in Positive Social Subscale from Baseline to Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 2.1 (4.9) | −1.9 (3.7) | 0.1 (4.7)
Median (Min-Max) | 1.0 (−4.0 - 10.0) | −3.0 (−7.0 - 3.0) | 0.0 (−7.0 - 10.0)
Conduct Problem Subscale at Baseline
N | 13 | 9 | 22
Mean (SD) | 11.6 (10.0) | 9.0 (6.0) | 10.5 (8.6)
Median (Min-Max) | 7.0 (0.0 - 34.0) | 10.0 (0.0 - 19.0) | 8.5 (0.0 - 34.0)
Conduct Problem Subscale at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 9.4 (9.8) | 7.1 (7.0) | 8.3 (8.3)
Median (Min-Max) | 7.0 (0.0 - 23.0) | 5.0 (0.0 - 19.0) | 6.0 (0.0 - 23.0)
Change in Conduct Problem Subscale from Baseline to Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | −1.1 (10.0) | 0.1 (3.4) | −0.5 (7.2)
Median (Min-Max) | −3.0 (−13.0 - 19.0) | 0.0 (−5.0 - 6.0) | −0.5 (−13.0 - 19.0)
Hyperactive Subscale at Baseline
N | 13 | 9 | 22
Mean (SD) | 5.0 (3.8) | 3.2 (2.0) | 4.3 (3.3)
Median (Min-Max) | 4.0 (0.0 - 12.0) | 4.0 (0.0 - 6.0) | 4.0 (0.0 - 12.0)
Hyperactive Subscale at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 4.4 (4.0) | 3.6 (3.2) | 4.0 (3.5)
Median (Min-Max) | 4.0 (0.0 - 12.0) | 3.0 (0.0 - 8.0) | 3.5 (0.0 - 12.0)
Change in Hyperactive Subscale from Baseline to Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | −1.4 (3.9) | 0.6 (2.4) | −0.4 (3.3)
Median (Min-Max) | −1.0 (−9.0 - 2.0) | 0.0 (−3.0 - 4.0) | 0.0 (−9.0 - 4.0)
Overly Sensitive Subscale at Baseline
N | 13 | 9 | 22
Mean (SD) | 5.9 (3.1) | 3.4 (2.9) | 4.9 (3.2)
Median (Min-Max) | 6.0 (0.0 - 11.0) | 4.0 (0.0 - 7.0) | 5.0 (0.0 - 11.0)
Overly Sensitive Subscale at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 3.1 (3.6) | 3.4 (3.4) | 3.3 (3.3)
Median (Min-Max) | 1.0 (0.0 - 8.0) | 4.0 (0.0 - 9.0) | 2.5 (0.0 - 9.0)
Change in Overly Sensitive Subscale from Baseline to Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | −2.6 (2.7) | 0.0 (1.9) | −1.3 (2.6)
Median (Min-Max) | −2.0 (−7.0 - 2.0) | 0.0 (−3.0 - 2.0) | −2.0 (−7.0 - 2.0)
Oppositional Behavior Subscale at Baseline
N | 13 | 9 | 22
Mean (SD) | 15.1 (8.5) | 12.4 (7.7) | 14.0 (8.1)
Median (Min-Max) | 14.0 (1.0 - 26.0) | 11.0 (0.0 - 26.0) | 13.0 (0.0 - 26.0)
Oppositional Behavior Subscale at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 11.3 (10.0) | 11.7 (7.1) | 11.5 (8.4)
Median (Min-Max) | 10.0 (0.0 - 26.0) | 9.0 (4.0 - 24.0) | 9.5 (0.0 - 26.0)
Change in Oppositional Behavior Subscale from Baseline to Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | −3.6 (8.9) | 0.9 (5.9) | −1.4 (7.6)
Median (Min-Max) | −1.0 (−20.0 - 8.0) | 3.0 (−8.0 - 7.0) | −0.5 (−20.0 - 8.0)
Inattentive Subscale at Baseline
N | 13 | 9 | 22
Mean (SD) | 10.8 (5.6) | 9.4 (5.7) | 10.3 (5.6)
Median (Min-Max) | 11.0 (0.0 - 19.0) | 10.0 (0.0 - 17.0) | 10.5 (0.0 - 19.0)
Inattentive Subscale at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 8.7 (6.4) | 12.3 (6.3) | 10.5 (6.4)
Median (Min-Max) | 7.0 (0.0 - 19.0) | 14.0 (2.0 - 18.0) | 12.5 (0.0 - 19.0)
Change in Inattentive Subscale from Baseline to Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | −4.0 (3.6) | 3.0 (4.0) | −0.5 (5.2)
Median (Min-Max) | −4.0 (−10.0 - 0.0) | 3.0 (−2.0 - 8.0) | −1.0 (−10.0 - 8.0)
Withdrawn/Dysphoric Subscale at Baseline
N | 13 | 9 | 22
Mean (SD) | 15.4 (11.2) | 9.9 (5.7) | 13.1 (9.6)
Median (Min-Max) | 13.0 (0.0 - 42.0) | 13.0 (1.0 - 17.0) | 13.0 (0.0 - 42.0)
Withdrawn/Dysphoric Subscale at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 9.4 (7.6) | 8.4 (7.3) | 8.9 (7.2)
Median (Min-Max) | 9.0 (0.0 - 21.0) | 6.0 (2.0 - 23.0) | 7.0 (0.0 - 23.0)
Change in Withdrawn/Dysphoric Subscale from Baseline to Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | −4.7 (6.1) | −0.6 (4.2) | −2.6 (5.5)
Median (Min-Max) | −5.0 (−13.0 - 4.0) | −1.0 (−8.0 - 6.0) | −1.5 (−13.0 - 6.0)

Note: Baseline is defined as the last visit of Efficacy Phase.

Change score is week 24/LOCF value minus baseline value.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.4.4B Descriptive Efficacy Endpoint: Nisonger Child Behavior Rating Form (NCBRF-TIQ) by Efficacy Phase Randomized Treatment Group Long-Term Effectiveness Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=42)
| Lithium; (N=29) | Placebo; (N=13) | Total; (N=42)
Positive Social Subscale at Baseline
N | 18 | 4 | 22
Mean (SD) | 14.0 (5.5) | 14.5 (4.5) | 14.1 (5.2)
Median (Min-Max) | 13.0 (5.0 - 30.0) | 13.0 (11.0 - 21.0) | 13.0 (5.0 - 30.0)
Positive Social Subscale at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 14.6 (5.6) | 11.5 (0.7) | 14.1 (5.2)
Median (Min-Max) | 14.5 (9.0 - 27.0) | 11.5 (11.0 - 12.0) | 13.0 (9.0 - 27.0)
Change in Positive Social Subscale from Baseline to Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 0.2 (5.1) | 0.0 (0.0) | 0.1 (4.7)
Median (Min-Max) | −0.5 (−7.0 - 10.0) | 0.0 (0.0 - 0.0) | 0.0 (−7.0 - 10.0)
Conduct Problem Subscale at Baseline
N | 18 | 4 | 22
Mean (SD) | 9.9 (9.2) | 13.3 (4.9) | 10.5 (8.6)
Median (Min-Max) | 6.5 (0.0 - 34.0) | 13.5 (7.0 - 19.0) | 8.5 (0.0 - 34.0)
Conduct Problem Subscale at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 7.5 (8.3) | 13.0 (8.5) | 8.3 (8.3)
Median (Min-Max) | 5.0 (0.0 - 23.0) | 13.0 (7.0 - 19.0) | 6.0 (0.0 - 23.0)
Change in Conduct Problem Subscale from Baseline to Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | −0.5 (7.3) | −0.5 (9.2) | −0.5 (7.2)
Median (Min-Max) | −0.5 (−13.0 - 19.0) | −0.5 (−7.0 - 6.0) | −0.5 (−13.0 - 19.0)
Hyperactive Subscale at Baseline
N | 18 | 4 | 22
Mean (SD) | 4.3 (3.6) | 4.0 (1.2) | 4.3 (3.3)
Median (Min-Max) | 4.0 (0.0 - 12.0) | 4.0 (3.0 - 5.0) | 4.0 (0.0 - 12.0)
Hyperactive Subscale at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 4.0 (3.7) | 4.0 (1.4) | 4.0 (3.5)
Median (Min-Max) | 3.5 (0.0 - 12.0) | 4.0 (3.0 - 5.0) | 3.5 (0.0 - 12.0)
Change in Hyperactive Subscale from Baseline to Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | −0.7 (3.4) | 1.0 (1.4) | −0.4 (3.3)
Median (Min-Max) | −0.5 (−9.0 - 4.0) | 1.0 (0.0 - 2.0) | 0.0 (−9.0 - 4.0)
Overly Sensitive Subscale at Baseline
N | 18 | 4 | 22
Mean (SD) | 5.2 (3.2) | 3.8 (3.3) | 4.9 (3.2)
Median (Min-Max) | 6.0 (0.0 - 11.0) | 3.5 (0.0 - 8.0) | 5.0 (0.0 - 11.0)
Overly Sensitive Subscale at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 3.8 (3.4) | 0.5 (0.7) | 3.3 (3.3)
Median (Min-Max) | 4.0 (0.0 - 9.0) | 0.5 (0.0 - 1.0) | 2.5 (0.0 - 9.0)
Change in Overly Sensitive Subscale from Baseline to Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | −1.3 (2.6) | −1.5 (3.5) | −1.3 (2.6)
Median (Min-Max) | −2.0 (−7.0 - 2.0) | −1.5 (−4.0 - 1.0) | −2.0 (−7.0 - 2.0)
Oppositional Behavior Subscale at Baseline
N | 18 | 4 | 22
Mean (SD) | 13.0 (8.3) | 18.5 (6.1) | 14.0 (8.1)
Median (Min-Max) | 10.5 (0.0 - 26.0) | 17.5 (13.0 - 26.0) | 13.0 (0.0 - 26.0)
Oppositional Behavior Subscale at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 10.6 (8.2) | 17.0 (9.9) | 11.5 (8.4)
Median (Min-Max) | 8.0 (0.0 - 26.0) | 17.0 (10.0 - 24.0) | 9.5 (0.0 - 26.0)
Change in Oppositional Behavior Subscale from Baseline to Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | −1.5 (8.1) | −0.5 (4.9) | −1.4 (7.6)
Median (Min-Max) | −0.5 (−20.0 - 8.0) | −0.5 (−4.0 - 3.0) | −0.5 (−20.0 - 8.0)
Inattentive Subscale at Baseline
N | 18 | 4 | 22
Mean (SD) | 9.9 (5.9) | 11.8 (3.9) | 10.3 (5.6)
Median (Min-Max) | 10.5 (0.0 - 19.0) | 11.0 (8.0 - 17.0) | 10.5 (0.0 - 19.0)
Inattentive Subscale at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 10.4 (6.7) | 11.0 (5.7) | 10.5 (6.4)
Median (Min-Max) | 12.5 (0.0 - 19.0) | 11.0 (7.0 - 15.0) | 12.5 (0.0 - 19.0)
Change in Inattentive Subscale from Baseline to Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | −0.8 (5.5) | 1.0 (2.8) | −0.5 (5.2)
Median (Min-Max) | −1.5 (−10.0 - 8.0) | 1.0 (−1.0 - 3.0) | −1.0 (−10.0 - 8.0)
Withdrawn/Dysphoric Subscale at Baseline
N | 18 | 4 | 22
Mean (SD) | 13.0 (10.1) | 13.8 (7.9) | 13.1 (9.6)
Median (Min-Max) | 13.0 (0.0 - 42.0) | 11.5 (7.0 - 25.0) | 13.0 (0.0 - 42.0)
Withdrawn/Dysphoric Subscale at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 9.8 (7.4) | 4.0 (4.2) | 8.9 (7.2)
Median (Min-Max) | 8.0 (0.0 - 23.0) | 4.0 (1.0 - 7.0) | 7.0 (0.0 - 23.0)
Change in Withdrawn/Dysphoric Subscale from Baseline to Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | −2.3 (5.6) | −4.5 (6.4) | −2.6 (5.5)
Median (Min-Max) | −1.5 (−13.0 - 6.0) | −4.5 (−9.0 - 0.0) | −1.5 (−13.0 - 6.0)

Note: Baseline is defined as the last visit of Efficacy Phase.

Change score is week 24/LOCF value minus baseline value.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.4.5A Descriptive Efficacy Endpoint: Social Adjustment Inventory for Children and Adolescents (SA/CA) by Age Strata Long-Term Effectiveness Phase - Efficacy Population

| Age Strata | | Total; (N=42)
| 7 - 11 yrs; (N=28) | 12 - 17 yrs; (N=14) | Total; (N=42)
Academic reading/english
N | 13 | 9 | 22
Mean (SD) | 1.9 (0.8) | 2.1 (0.9) | 2.0 (0.8)
Median (Min-Max) | 2.0 (1.0 - 3.0) | 2.0 (1.0 - 4.0) | 2.0 (1.0 - 4.0)
Academic reading/english
N | 7 | 7 | 14
Mean (SD) | 2.4 (1.0) | 2.1 (0.9) | 2.3 (0.9)
Median (Min-Max) | 2.0 (1.0 - 4.0) | 2.0 (1.0 - 3.0) | 2.0 (1.0 - 4.0)
Academic reading/english
N | 7 | 7 | 14
Mean (SD) | 0.1 (0.9) | 0.0 (1.3) | 0.1 (1.1)
Median (Min-Max) | 0.0 (−1.0 - 1.0) | 0.0 (−2.0 - 2.0) | 0.0 (−2.0 - 2.0)
Academic arithmetic
N | 13 | 9 | 22
Mean (SD) | 2.1 (0.8) | 1.8 (0.4) | 2.0 (0.7)
Median (Min-Max) | 2.0 (1.0 - 3.0) | 2.0 (1.0 - 2.0) | 2.0 (1.0 - 3.0)
Academic arithmetic
N | 7 | 7 | 14
Mean (SD) | 2.4 (1.0) | 2.1 (0.9) | 2.3 (0.9)
Median (Min-Max) | 2.0 (1.0 - 4.0) | 2.0 (1.0 - 3.0) | 2.0 (1.0 - 4.0)
Academic arithmetic
N | 7 | 7 | 14
Mean (SD) | 0.0 (0.8) | 0.4 (1.0) | 0.2 (0.9)
Median (Min-Max) | 0.0 (−1.0 - 1.0) | 0.0 (−1.0 - 2.0) | 0.0 (−1.0 - 2.0)
Global rating of school behavior problems subscale at Baseline
N | 13 | 9 | 22
Mean (SD) | 2.3 (0.9) | 2.1 (0.9) | 2.2 (0.9)
Median (Min-Max) | 2.0 (1.0 - 4.0) | 2.0 (1.0 - 4.0) | 2.0 (1.0 - 4.0)
Global rating of school behavior problems subscale at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 2.0 (0.8) | 2.0 (0.8) | 2.0 (0.8)
Median (Min-Max) | 2.0 (1.0 - 3.0) | 2.0 (1.0 - 3.0) | 2.0 (1.0 - 3.0)
Change in Global rating of school behavior problems subscale from Baseline to Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | −0.6 (0.8) | 0.3 (1.0) | −0.1 (0.9)
Median (Min-Max) | 0.0 (−2.0 - 0.0) | 0.0 (−1.0 - 2.0) | 0.0 (−2.0 - 2.0)
Global rating of spare time activities subscale at Baseline
N | 13 | 9 | 22
Mean (SD) | 1.7 (0.9) | 2.2 (1.0) | 1.9 (0.9)
Median (Min-Max) | 2.0 (1.0 - 4.0) | 2.0 (1.0 - 4.0) | 2.0 (1.0 - 4.0)
Global rating of spare time activities subscale at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 1.6 (0.5) | 2.0 (0.8) | 1.8 (0.7)
Median (Min-Max) | 2.0 (1.0 - 2.0) | 2.0 (1.0 - 3.0) | 2.0 (1.0 - 3.0)
Change in Global rating of spare time activities subscale from Baseline to Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | −0.1 (0.9) | −0.1 (0.7) | −0.1 (0.8)
Median (Min-Max) | 0.0 (−2.0 - 1.0) | 0.0 (−1.0 - 1.0) | 0.0 (−2.0 - 1.0)
Global rating of spare time problems at Baseline
N | 13 | 9 | 22
Mean (SD) | 1.5 (0.9) | 1.4 (0.5) | 1.5 (0.7)
Median (Min-Max) | 1.0 (1.0 - 4.0) | 1.0 (1.0 - 2.0) | 1.0 (1.0 - 4.0)
Global rating of spare time problems at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 1.4 (0.8) | 2.1 (0.9) | 1.8 (0.9)
Median (Min-Max) | 1.0 (1.0 - 3.0) | 2.0 (1.0 - 3.0) | 1.5 (1.0 - 3.0)
Change in Global rating of spare time problems from Baseline to Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 0.1 (0.9) | 0.7 (0.8) | 0.4 (0.9)
Median (Min-Max) | 0.0 (−1.0 - 2.0) | 1.0 (0.0 - 2.0) | 0.0 (−1.0 - 2.0)
Global rating of activity with peers at Baseline
N | 12 | 9 | 21
Mean (SD) | 2.2 (0.9) | 2.2 (1.2) | 2.2 (1.0)
Median (Min-Max) | 2.0 (1.0 - 4.0) | 2.0 (1.0 - 4.0) | 2.0 (1.0 - 4.0)
Global rating of activity with peers at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 2.1 (1.3) | 1.9 (0.9) | 2.0 (1.1)
Median (Min-Max) | 2.0 (1.0 - 4.0) | 2.0 (1.0 - 3.0) | 2.0 (1.0 - 4.0)
Change in Global rating of activity with peers from Baseline to Week 24/LOCF
N | 6 | 7 | 13
Mean (SD) | −0.2 (1.0) | 0.1 (0.7) | 0.0 (0.8)
Median (Min-Max) | −0.5 (−1.0 - 1.0) | 0.0 (−1.0 - 1.0) | 0.0 (−1.0 - 1.0)
Global rating of peer problems at Baseline
N | 12 | 9 | 21
Mean (SD) | 1.5 (0.8) | 1.9 (1.1) | 1.7 (0.9)
Median (Min-Max) | 1.0 (1.0 - 3.0) | 2.0 (1.0 - 4.0) | 1.0 (1.0 - 4.0)
Global rating of peer problems at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 1.6 (0.8) | 1.6 (0.8) | 1.6 (0.8)
Median (Min-Max) | 1.0 (1.0 - 3.0) | 1.0 (1.0 - 3.0) | 1.0 (1.0 - 3.0)
Change in Global rating of peer problems from Baseline to Week 24/LOCF
N | 6 | 7 | 13
Mean (SD) | 0.2 (0.8) | 0.1 (0.9) | 0.2 (0.8)
Median (Min-Max) | 0.0 (−1.0 - 1.0) | 0.0 (−1.0 - 2.0) | 0.0 (−1.0 - 2.0)
Global rating of boy-girl relationships at Baseline
N | 13 | 9 | 22
Mean (SD) | 88.0 (0.0) | 2.4 (1.0) | 53.0 (43.1)
Median (Min-Max) | 88.0 (88.0 - 88.0) | 3.0 (1.0 - 4.0) | 88.0 (1.0 - 88.0)
Global rating of boy-girl relationships at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 88.0 (0.0) | 2.1 (0.9) | 45.1 (44.6)
Median (Min-Max) | 88.0 (88.0 - 88.0) | 2.0 (1.0 - 3.0) | 45.5 (1.0 - 88.0)
Change in Global rating of boy-girl relationships from Baseline to Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 0.0 (0.0) | 0.0 (1.2) | 0.0 (0.8)
Median (Min-Max) | 0.0 (0.0 - 0.0) | 0.0 (−2.0 - 1.0) | 0.0 (−2.0 - 1.0)
Global rating of problems with opposite sex at Baseline
N | 13 | 9 | 22
Mean (SD) | 88.0 (0.0) | 1.1 (0.3) | 52.5 (43.7)
Median (Min-Max) | 88.0 (88.0 - 88.0) | 1.0 (1.0 - 2.0) | 88.0 (1.0 - 88.0)
Global rating of problems with opposite sex at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 88.0 (0.0) | 1.3 (0.8) | 44.6 (45.0)
Median (Min-Max) | 88.0 (88.0 - 88.0) | 1.0 (1.0 - 3.0) | 45.5 (1.0 - 88.0)
Change in Global rating of problems with opposite sex from Baseline to Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 0.0 (0.0) | 0.1 (0.9) | 0.1 (0.6)
Median (Min-Max) | 0.0 (0.0 - 0.0) | 0.0 (−1.0 - 2.0) | 0.0 (−1.0 - 2.0)
Global rating of sibling relationships at Baseline
N | 12 | 9 | 21
Mean (SD) | 1.8 (1.0) | 2.0 (1.0) | 1.9 (1.0)
Median (Min-Max) | 2.0 (0.0 - 3.0) | 2.0 (0.0 - 3.0) | 2.0 (0.0 - 3.0)
Global rating of sibling relationships at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 1.9 (1.1) | 1.4 (1.0) | 1.6 (1.0)
Median (Min-Max) | 2.0 (0.0 - 3.0) | 1.0 (0.0 - 3.0) | 2.0 (0.0 - 3.0)
Change in Global rating of sibling relationships from Baseline to Week 24/LOCF
N | 6 | 7 | 13
Mean (SD) | 0.2 (1.2) | −0.4 (0.8) | −0.2 (1.0)
Median (Min-Max) | 0.0 (−1.0 - 2.0) | 0.0 (−2.0 - 0.0) | 0.0 (−2.0 - 2.0)
Global rating of problems with sibling(s) at Baseline
N | 12 | 9 | 21
Mean (SD) | 1.8 (1.1) | 1.3 (0.7) | 1.6 (0.9)
Median (Min-Max) | 2.0 (0.0 - 4.0) | 1.0 (0.0 - 2.0) | 2.0 (0.0 - 4.0)
Global rating of problems with sibling(s) at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 1.7 (1.1) | 1.4 (0.8) | 1.6 (0.9)
Median (Min-Max) | 2.0 (0.0 - 3.0) | 2.0 (0.0 - 2.0) | 2.0 (0.0 - 3.0)
Change in Global rating of problems with sibling(s) from Baseline to Week 24/LOCF
N | 6 | 7 | 13
Mean (SD) | 0.0 (1.4) | 0.3 (0.5) | 0.2 (1.0)
Median (Min-Max) | 0.0 (−2.0 - 2.0) | 0.0 (0.0 - 1.0) | 0.0 (−2.0 - 2.0)
Global rating of relationship with mother at Baseline
N | 12 | 9 | 21
Mean (SD) | 1.5 (0.8) | 2.1 (1.3) | 1.8 (1.0)
Median (Min-Max) | 1.0 (1.0 - 3.0) | 2.0 (1.0 - 4.0) | 1.0 (1.0 - 4.0)
Global rating of relationship with mother at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 1.3 (0.8) | 1.9 (0.9) | 1.6 (0.9)
Median (Min-Max) | 1.0 (1.0 - 3.0) | 2.0 (1.0 - 3.0) | 1.0 (1.0 - 3.0)
Change in Global rating of relationship with mother from Baseline to Week 24/LOCF
N | 6 | 7 | 13
Mean (SD) | −0.2 (1.3) | −0.1 (1.5) | −0.2 (1.3)
Median (Min-Max) | 0.0 (−2.0 - 2.0) | 0.0 (−2.0 - 2.0) | 0.0 (−2.0 - 2.0)
Global rating of relationship with father at Baseline
N | 12 | 9 | 21
Mean (SD) | 1.8 (1.2) | 2.0 (1.6) | 1.9 (1.3)
Median (Min-Max) | 1.5 (0.0 - 4.0) | 2.0 (0.0 - 4.0) | 2.0 (0.0 - 4.0)
Global rating of relationship with father at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 1.9 (1.2) | 2.0 (1.5) | 1.9 (1.3)
Median (Min-Max) | 1.0 (1.0 - 4.0) | 2.0 (0.0 - 4.0) | 2.0 (0.0 - 4.0)
Change in Global rating of relationship with father from Baseline to Week 24/LOCF
N | 6 | 7 | 13
Mean (SD) | −0.3 (1.5) | 0.1 (0.7) | −0.1 (1.1)
Median (Min-Max) | 0.0 (−2.0 - 2.0) | 0.0 (−1.0 - 1.0) | 0.0 (−2.0 - 2.0)
Global rating of problem(s) with parents at Baseline
N | 12 | 9 | 21
Mean (SD) | 1.7 (1.0) | 1.8 (1.1) | 1.7 (1.0)
Median (Min-Max) | 1.0 (1.0 - 4.0) | 1.0 (1.0 - 4.0) | 1.0 (1.0 - 4.0)
Global rating of problem(s) with parents at Week 24/LOCF
N | 7 | 7 | 14
Mean (SD) | 1.7 (1.0) | 1.6 (0.8) | 1.6 (0.8)
Median (Min-Max) | 1.0 (1.0 - 3.0) | 1.0 (1.0 - 3.0) | 1.0 (1.0 - 3.0)
Change in Global rating of problem(s) with parents from Baseline to Week 24/LOCF
N | 6 | 7 | 13
Mean (SD) | 0.0 (1.3) | 0.1 (0.7) | 0.1 (1.0)
Median (Min-Max) | 0.0 (−2.0 - 2.0) | 0.0 (−1.0 - 1.0) | 0.0 (−2.0 - 2.0)

Note: Baseline is defined as the last visit of Efficacy Phase.

Change score is week 24/LOCF value minus baseline value.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.2.4.5B Descriptive Efficacy Endpoint: Social Adjustment Inventory for Children and Adolescents (SA/CA) by Efficacy Phase Randomized Treatment Group Long-Term Effectiveness Phase - Efficacy Population

| Efficacy Phase Randomized Treatment Group | | Total; (N=42)
| Lithium; (N=29) | Placebo; (N=13) | Total; (N=42)
Academic reading/english
N | 18 | 4 | 22
Mean (SD) | 1.9 (0.7) | 2.5 (1.3) | 2.0 (0.8)
Median (Min-Max) | 2.0 (1.0 - 3.0) | 2.5 (1.0 - 4.0) | 2.0 (1.0 - 4.0)
Academic reading/english
N | 12 | 2 | 14
Mean (SD) | 2.2 (0.8) | 3.0 (1.4) | 2.3 (0.9)
Median (Min-Max) | 2.0 (1.0 - 3.0) | 3.0 (2.0 - 4.0) | 2.0 (1.0 - 4.0)
Academic reading/english
N | 12 | 2 | 14
Mean (SD) | 0.2 (0.9) | −0.5 (2.1) | 0.1 (1.1)
Median (Min-Max) | 0.0 (−1.0 - 2.0) | −0.5 (−2.0 - 1.0) | 0.0 (−2.0 - 2.0)
Academic arithmetic
N | 18 | 4 | 22
Mean (SD) | 1.9 (0.6) | 2.0 (0.8) | 2.0 (0.7)
Median (Min-Max) | 2.0 (1.0 - 3.0) | 2.0 (1.0 - 3.0) | 2.0 (1.0 - 3.0)
Academic arithmetic
N | 12 | 2 | 14
Mean (SD) | 2.2 (0.8) | 3.0 (1.4) | 2.3 (0.9)
Median (Min-Max) | 2.0 (1.0 - 3.0) | 3.0 (2.0 - 4.0) | 2.0 (1.0 - 4.0)
Academic arithmetic
N | 12 | 2 | 14
Mean (SD) | 0.2 (0.9) | 0.5 (0.7) | 0.2 (0.9)
Median (Min-Max) | 0.0 (−1.0 - 2.0) | 0.5 (0.0 - 1.0) | 0.0 (−1.0 - 2.0)
Global rating of school behavior problems subscale at Baseline
N | 18 | 4 | 22
Mean (SD) | 2.2 (0.9) | 2.5 (0.6) | 2.2 (0.9)
Median (Min-Max) | 2.0 (1.0 - 4.0) | 2.5 (2.0 - 3.0) | 2.0 (1.0 - 4.0)
Global rating of school behavior problems subscale at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 2.0 (0.9) | 2.0 (0.0) | 2.0 (0.8)
Median (Min-Max) | 2.0 (1.0 - 3.0) | 2.0 (2.0 - 2.0) | 2.0 (1.0 - 3.0)
Change in Global rating of school behavior problems subscale from Baseline to Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | −0.1 (1.0) | −0.5 (0.7) | −0.1 (0.9)
Median (Min-Max) | 0.0 (−2.0 - 2.0) | −0.5 (−1.0 - 0.0) | 0.0 (−2.0 - 2.0)
Global rating of spare time activities subscale at Baseline
N | 18 | 4 | 22
Mean (SD) | 1.8 (0.9) | 2.5 (0.6) | 1.9 (0.9)
Median (Min-Max) | 2.0 (1.0 - 4.0) | 2.5 (2.0 - 3.0) | 2.0 (1.0 - 4.0)
Global rating of spare time activities subscale at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 1.8 (0.8) | 2.0 (0.0) | 1.8 (0.7)
Median (Min-Max) | 2.0 (1.0 - 3.0) | 2.0 (2.0 - 2.0) | 2.0 (1.0 - 3.0)
Change in Global rating of spare time activities subscale from Baseline to Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | −0.1 (0.8) | −0.5 (0.7) | −0.1 (0.8)
Median (Min-Max) | 0.0 (−2.0 - 1.0) | −0.5 (−1.0 - 0.0) | 0.0 (−2.0 - 1.0)
Global rating of spare time problems at Baseline
N | 18 | 4 | 22
Mean (SD) | 1.4 (0.8) | 1.8 (0.5) | 1.5 (0.7)
Median (Min-Max) | 1.0 (1.0 - 4.0) | 2.0 (1.0 - 2.0) | 1.0 (1.0 - 4.0)
Global rating of spare time problems at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 1.8 (0.9) | 2.0 (1.4) | 1.8 (0.9)
Median (Min-Max) | 1.5 (1.0 - 3.0) | 2.0 (1.0 - 3.0) | 1.5 (1.0 - 3.0)
Change in Global rating of spare time problems from Baseline to Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 0.4 (0.9) | 0.5 (0.7) | 0.4 (0.9)
Median (Min-Max) | 0.0 (−1.0 - 2.0) | 0.5 (0.0 - 1.0) | 0.0 (−1.0 - 2.0)
Global rating of activity with peers at Baseline
N | 17 | 4 | 21
Mean (SD) | 2.2 (1.0) | 2.3 (1.3) | 2.2 (1.0)
Median (Min-Max) | 2.0 (1.0 - 4.0) | 2.0 (1.0 - 4.0) | 2.0 (1.0 - 4.0)
Global rating of activity with peers at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 2.1 (1.2) | 1.5 (0.7) | 2.0 (1.1)
Median (Min-Max) | 2.0 (1.0 - 4.0) | 1.5 (1.0 - 2.0) | 2.0 (1.0 - 4.0)
Change in Global rating of activity with peers from Baseline to Week 24/LOCF
N | 11 | 2 | 13
Mean (SD) | 0.1 (0.8) | −0.5 (0.7) | 0.0 (0.8)
Median (Min-Max) | 0.0 (−1.0 - 1.0) | −0.5 (−1.0 - 0.0) | 0.0 (−1.0 - 1.0)
Global rating of peer problems at Baseline
N | 17 | 4 | 21
Mean (SD) | 1.6 (0.9) | 2.0 (0.8) | 1.7 (0.9)
Median (Min-Max) | 1.0 (1.0 - 4.0) | 2.0 (1.0 - 3.0) | 1.0 (1.0 - 4.0)
Global rating of peer problems at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 1.6 (0.8) | 1.5 (0.7) | 1.6 (0.8)
Median (Min-Max) | 1.0 (1.0 - 3.0) | 1.5 (1.0 - 2.0) | 1.0 (1.0 - 3.0)
Change in Global rating of peer problems from Baseline to Week 24/LOCF
N | 11 | 2 | 13
Mean (SD) | 0.3 (0.8) | −0.5 (0.7) | 0.2 (0.8)
Median (Min-Max) | 0.0 (−1.0 - 2.0) | −0.5 (−1.0 - 0.0) | 0.0 (−1.0 - 2.0)
Global rating of boy-girl relationships at Baseline
N | 18 | 4 | 22
Mean (SD) | 54.7 (43.0) | 45.5 (49.1) | 53.0 (43.1)
Median (Min-Max) | 88.0 (1.0 - 88.0) | 45.5 (3.0 - 88.0) | 88.0 (1.0 - 88.0)
Global rating of boy-girl relationships at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 45.2 (44.7) | 44.5 (61.5) | 45.1 (44.6)
Median (Min-Max) | 45.5 (1.0 - 88.0) | 44.5 (1.0 - 88.0) | 45.5 (1.0 - 88.0)
Change in Global rating of boy-girl relationships from Baseline to Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 0.2 (0.6) | −1.0 (1.4) | 0.0 (0.8)
Median (Min-Max) | 0.0 (−1.0 - 1.0) | −1.0 (−2.0 - 0.0) | 0.0 (−2.0 - 1.0)
Global rating of problems with opposite sex at Baseline
N | 18 | 4 | 22
Mean (SD) | 54.2 (43.6) | 44.5 (50.2) | 52.5 (43.7)
Median (Min-Max) | 88.0 (1.0 - 88.0) | 44.5 (1.0 - 88.0) | 88.0 (1.0 - 88.0)
Global rating of problems with opposite sex at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 44.7 (45.3) | 44.5 (61.5) | 44.6 (45.0)
Median (Min-Max) | 45.5 (1.0 - 88.0) | 44.5 (1.0 - 88.0) | 45.5 (1.0 - 88.0)
Change in Global rating of problems with opposite sex from Baseline to Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 0.1 (0.7) | 0.0 (0.0) | 0.1 (0.6)
Median (Min-Max) | 0.0 (−1.0 - 2.0) | 0.0 (0.0 - 0.0) | 0.0 (−1.0 - 2.0)
Global rating of sibling relationships at Baseline
N | 17 | 4 | 21
Mean (SD) | 1.6 (0.9) | 2.8 (0.5) | 1.9 (1.0)
Median (Min-Max) | 2.0 (0.0 - 3.0) | 3.0 (2.0 - 3.0) | 2.0 (0.0 - 3.0)
Global rating of sibling relationships at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 1.7 (1.1) | 1.5 (0.7) | 1.6 (1.0)
Median (Min-Max) | 2.0 (0.0 - 3.0) | 1.5 (1.0 - 2.0) | 2.0 (0.0 - 3.0)
Change in Global rating of sibling relationships from Baseline to Week 24/LOCF
N | 11 | 2 | 13
Mean (SD) | 0.0 (0.9) | −1.0 (1.4) | −0.2 (1.0)
Median (Min-Max) | 0.0 (−1.0 - 2.0) | −1.0 (−2.0 - 0.0) | 0.0 (−2.0 - 2.0)
Global rating of problems with sibling(s) at Baseline
N | 17 | 4 | 21
Mean (SD) | 1.5 (1.0) | 2.0 (0.0) | 1.6 (0.9)
Median (Min-Max) | 1.0 (0.0 - 4.0) | 2.0 (2.0 - 2.0) | 2.0 (0.0 - 4.0)
Global rating of problems with sibling(s) at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 1.5 (1.0) | 2.0 (0.0) | 1.6 (0.9)
Median (Min-Max) | 1.5 (0.0 - 3.0) | 2.0 (2.0 - 2.0) | 2.0 (0.0 - 3.0)
Change in Global rating of problems with sibling(s) from Baseline to Week 24/LOCF
N | 11 | 2 | 13
Mean (SD) | 0.2 (1.1) | 0.0 (0.0) | 0.2 (1.0)
Median (Min-Max) | 0.0 (−2.0 - 2.0) | 0.0 (0.0 - 0.0) | 0.0 (−2.0 - 2.0)
Global rating of relationship with mother at Baseline
N | 17 | 4 | 21
Mean (SD) | 1.6 (0.8) | 2.5 (1.7) | 1.8 (1.0)
Median (Min-Max) | 1.0 (1.0 - 3.0) | 2.5 (1.0 - 4.0) | 1.0 (1.0 - 4.0)
Global rating of relationship with mother at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 1.6 (0.9) | 1.5 (0.7) | 1.6 (0.9)
Median (Min-Max) | 1.0 (1.0 - 3.0) | 1.5 (1.0 - 2.0) | 1.0 (1.0 - 3.0)
Change in Global rating of relationship with mother from Baseline to Week 24/LOCF
N | 11 | 2 | 13
Mean (SD) | 0.0 (1.3) | −1.0 (1.4) | −0.2 (1.3)
Median (Min-Max) | 0.0 (−2.0 - 2.0) | −1.0 (−2.0 - 0.0) | 0.0 (−2.0 - 2.0)
Global rating of relationship with father at Baseline
N | 17 | 4 | 21
Mean (SD) | 1.5 (1.2) | 3.5 (0.6) | 1.9 (1.3)
Median (Min-Max) | 1.0 (0.0 - 4.0) | 3.5 (3.0 - 4.0) | 2.0 (0.0 - 4.0)
Global rating of relationship with father at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 1.9 (1.4) | 2.0 (1.4) | 1.9 (1.3)
Median (Min-Max) | 2.0 (0.0 - 4.0) | 2.0 (1.0 - 3.0) | 2.0 (0.0 - 4.0)
Change in Global rating of relationship with father from Baseline to Week 24/LOCF
N | 11 | 2 | 13
Mean (SD) | 0.2 (1.0) | −1.5 (0.7) | −0.1 (1.1)
Median (Min-Max) | 0.0 (−2.0 - 2.0) | 1.5 (−2.0 - −1.0) | 0.0 (−2.0 - 2.0)
Global rating of problem(s) with parents at Baseline
N | 17 | 4 | 21
Mean (SD) | 1.5 (0.9) | 2.5 (1.3) | 1.7 (1.0)
Median (Min-Max) | 1.0 (1.0 - 4.0) | 2.5 (1.0 - 4.0) | 1.0 (1.0 - 4.0)
Global rating of problem(s) with parents at Week 24/LOCF
N | 12 | 2 | 14
Mean (SD) | 1.6 (0.8) | 2.0 (1.4) | 1.6 (0.8)
Median (Min-Max) | 1.0 (1.0 - 3.0) | 2.0 (1.0 - 3.0) | 1.0 (1.0 - 3.0)
Change in Global rating of problem(s) with parents from Baseline to Week 24/LOCF
N | 11 | 2 | 13
Mean (SD) | 0.1 (1.0) | 0.0 (0.0) | 0.1 (1.0)
Median (Min-Max) | 0.0 (−2.0 - 2.0) | 0.0 (0.0 - 0.0) | 0.0 (−2.0 - 2.0)

Note: Baseline is defined as the last visit of Efficacy Phase.

Change score is week 24/LOCF value minus baseline value.

Two participants entering the Long-Term Effectiveness Phase are not included in the Efficacy population.

Table 14.2.3.1.1 Primary Efficacy Endpoint: Time to Any Discontinuation by Discontinuation Phase Randomized Treatment Group Discontinuation Phase - Efficacy Population

| Discontinuation Phase Randomized Treatment Group
| Lithium; (N=14) | Placebo; (N=17)
Participants Status during Discontinuation Phase
Discontinued during Discontinuation Phase | 3 (21.4%) | 2 (11.8%)
Completed Study | 8 (57.1%) | 5 (29.4%)
Mood Relapse and entered Restabilization Phase | 3 (21.4%) | 10 (58.8%)
Number of Participants
Number of Censored Participants (completed phase) | 8 (57.1%) | 5 (29.4%)
Number of Failure Participants (discontinued) | 6 (42.9%) | 12 (70.6%)
Time to event (Time to Any Discontinuation in Weeks)
Median (95% CI) | . (3.1, .) | 6.0 (4.1, .)
25% Percentile | 4.1 (2.0, .) | 4.4 (2.1, 5.7)
75% Percentile | | . (6.0, .)
Range | (2, 29) | (2, 29)
Stratified Analysis by Age Group
Hazard Ratio (Relative to Placebo) | 0.54
(95% CI) | (0.20, 1.49)
P value ^1^ | 0.2349

Note:

1 P-value is calculated from the Cox proportional hazards regression model.

Table 14.2.3.1.2 Primary Efficacy Endpoint: Time to Any Discontinuation by Discontinuation Phase Randomized Treatment Group Discontinuation Phase - Per Protocol Population

| Discontinuation Phase Randomized Treatment Group
| Lithium; (N=11) | Placebo; (N=12)
Participants Status during Discontinuation Phase
Discontinued during Discontinuation Phase | 3 (27.3%) | 2 (16.7%)
Completed Study | 6 (54.5%) | 1 (8.3%)
Mood Relapse and entered Restabilization Phase | 2 (18.2%) | 9 (75.0%)
Number of Participants
Number of Censored Participants (completed phase) | 6 (54.5%) | 1 (8.3%)
Number of Failure Participants (discontinued) | 5 (45.5%) | 11 (91.7%)
Time to event (Time to Any Discontinuation in Weeks)
Median (95% CI) | . (3.1, .) | 5.3 (3.9, 6.3)
25% Percentile | 4.1 (2.6, .) | 4.1 (2.1, 5.0)
75% Percentile | . (25.3, .) | 6.1 (5.0, .)
Range | (3, 29) | (2, 29)
Stratified Analysis by Age Group
Hazard Ratio (Relative to Placebo) | 0.27
(95% CI) | (0.08, 0.87)
P value ^1^ | 0.0288

Note:

1 P-value is calculated from the Cox proportional hazards regression model.

Table 14.2.3.1.3 Primary Efficacy Endpoint: Time to Any Discontinuation by Discontinuation Phase Randomized Treatment Group Discontinuation Phase - Revised Per Protocol Population

| Discontinuation Phase Randomized Treatment Group
| Lithium; (N=13) | Placebo; (N=13)
Participants Status during Discontinuation Phase
Discontinued during Discontinuation Phase | 3 (23.1%) | 2 (15.4%)
Completed Study | 7 (53.8%) | 2 (15.4%)
Mood Relapse and entered Restabilization Phase | 3 (23.1%) | 9 (69.2%)
Number of Participants
Number of Censored Participants (completed phase) | 7 (53.8%) | 2 (15.4%)
Number of Failure Participants (discontinued) | 6 (46.2%) | 11 (84.6%)
Time to event (Time to Any Discontinuation in Weeks)
Median (95% CI) | . (3.1, .) | 5.6 (4.1, 6.3)
25% Percentile | 4.1 (2.0, .) | 4.1 (2.1, 5.6)
75% Percentile | . (25.3, .) | 6.3 (5.0, .)
Range | (2, 29) | (2, 29)
Stratified Analysis by Age Group
Hazard Ratio (Relative to Placebo) | 0.41
(95% CI) | (0.14, 1.15)
P value ^1^ | 0.0898

Note:

1 P-value is calculated from the Cox proportional hazards regression model.

Table 14.2.3.1.4 Primary Efficacy Endpoint: Time to Any Discontinuation by Discontinuation Phase Treatment Received Group Discontinuation Phase - Efficacy Population

| Discontinuation Phase Treatment Received Group
| Lithium; (N=17) | Placebo; (N=14)
Participants Status during Discontinuation Phase
Discontinued during Discontinuation Phase | 3 (17.6%) | 2 (14.3%)
Completed Study | 11 (64.7%) | 2 (14.3%)
Mood Relapse and entered Restabilization Phase | 3 (17.6%) | 10 (71.4%)
Number of Participants
Number of Censored Participants (completed phase) | 11 (64.7%) | 2 (14.3%)
Number of Failure Participants (discontinued) | 6 (35.3%) | 12 (85.7%)
Time to event (Time to Any Discontinuation in Weeks)
Median (95% CI) | . (4.1, .) | 5.6 (4.1, 7.4)
25% Percentile | 8.1 (2.0, .) | 4.1 (2.1, 5.6)
75% Percentile | . | 7.4 (5.6, .)
Range | (2, 29) | (2, 29)
Stratified Analysis by Age Group
Hazard Ratio (Relative to Placebo) | 0.28
(95% CI) | (0.10, 0.78)
P value ^1^ | 0.0150

Note:

1 P-value is calculated from the Cox proportional hazards regression model.

Table 14.2.3.2.1 Secondary Efficacy Endpoint: Time to Discontinuation For Lack of Efficacy by Discontinuation Phase Randomized Treatment Group Discontinuation Phase - Efficacy Population

| Discontinuation Phase Randomized Treatment Group
| Lithium; (N=14) | Placebo; (N=17)
Number of Participants
Number of Censored Participants | 13 (92.9%) | 17 (100.0%)
Number of Non Censored Participants | 1 (7.1%) | 0
Time to event (Time to Any Discontinuation in Days)
Median (95% CI) | . (177.00, .) | .
25% Percentile | . (177.00, .) | .
75% Percentile | . | .
Range | (14, 196) | (15, 196)
Stratified Analysis by treatment
Hazard Ratio (Relative to Placebo) | 503E5
(95% CI) | (0.00, .)
P value ^1^ | 0.9985

Note:

1 P-value is calculated from the Cox proportional hazards regression model.

Table 14.2.3.2.2 Secondary Efficacy Endpoint: Response, Remission, Improvement and Discontinuation by Discontinuation Phase Randomized Treatment Group Discontinuation Phase - Efficacy Population

| Discontinuation Phase Randomized Treatment Group | | Total; (N=31) | P-Value^1^
| Lithium; (N=14) | Placebo; (N=17) | Total; (N=31) | P-Value^1^
YMRS Response
Non-response | 3 (21.4%) | 7 (41.2%) | 10 (32.3%) | 0.295
Partial Response | 3 (21.4%) | 5 (29.4%) | 8 (25.8%)
Complete Response | 8 (57.1%) | 5 (29.4%) | 13 (41.9%)
YMRS Remission
No remission | 6 (42.9%) | 12 (70.6%) | 18 (58.1%) | 0.126
Remission | 8 (57.1%) | 5 (29.4%) | 13 (41.9%)
YMRS Improvement
Reduction <25% | 3 (21.4%) | 2 (11.8%) | 5 (16.1%) | 0.393
Reduction = 25-49% | 2 (14.3%) | 6 (35.3%) | 8 (25.8%)
Reduction ≥50% | 9 (64.3%) | 9 (52.9%) | 18 (58.1%)
Discontinuation due to any cause during the Discontinuation Phase
Completed study | 8 (57.1%) | 5 (29.4%) | 13 (41.9%) | 0.126
Terminated for any reason | 6 (42.9%) | 12 (70.6%) | 18 (58.1%)
Discontinuation due to lack of efficacy during the Discontinuation Phase
No termination due to lack of efficacy | 13 (92.9%) | 17 (100.0%) | 30 (96.8%) | 0.270
Terminated due to lack of efficacy | 1 (7.1%) | 0 | 1 (3.2%)

Note:

1 P-value is calculated from CMH Test for the treatment effect.

Baseline value is the pre-dose value from day 1 of the Efficacy Phase(COLT2) or Pharmacokinetic Phase(COLTI).

Table 14.2.3.2.3 Secondary Efficacy Endpoint: Recurrence of Mood Episodes by Discontinuation Phase Randomized Treatment Group Discontinuation Phase - Efficacy Population

| Discontinuation Phase Randomized Treatment Group | | Total | P-Value ^1^
| Lithium; (N=14) | Placebo; (N=17) | Total | P-Value ^1^
Participants with Recurrence of Mood Episodes
No | 9 (64.3%) | 6 (35.3%) | 15 (48.4%) | 0.156
Yes | 5 (35.7%) | 11 (64.7%) | 16 (51.6%)
Concomitant Stimulant Treatment | 0 | 0 | 0
Concomitant Antipsychotic Medication or Mood Stabilizer
No | 14 (100.0%) | 16 (94.1%) | 30 (96.8%)
Yes | 0 | 1 (5.9%) | 1 (3.2%)
Gender
Male | 10 (71.4%) | 11 (64.7%) | 21 (67.7%)
Female | 4 (28.6%) | 6 (35.3%) | 10 (32.3%)
Site
CASE | 6 (42.9%) | 8 (47.1%) | 14 (45.2%)
Combined(ZUC,KUM,UMA,COU) | 2 (14.3%) | 3 (17.6%) | 5 (16.1%)
UIC | 6 (42.9%) | 6 (35.3%) | 12 (38.7%)
Age
N | 14 | 17 | 31
Mean (SD) | 11.1 (2.4) | 12.8 (2.3) | 12.0 (2.5)
Median (Min-Max) | 11.2 (8.2 - 14.3) | 12.2 (9.5 - 17.1) | 12.2 (8.2 - 17.1)

Note:

1 P-value for Recurrence of Mood Episodes is calculated from Fisher’s Exact Test.

Table 14.2.3.2.4 Secondary Efficacy Endpoint: Time to Recurrence of Mood Episodes by Discontinuation Phase Randomized Treatment Group Discontinuation Phase - Efficacy Population

| Discontinuation Phase Randomized Treatment Group
| Lithium; (N=14) | Placebo; (N=17)
Number of Participants
Number of Censored Participants | 9 (64.3%) | 7 (41.2%)
Number of Non Censored Participants | 5 (35.7%) | 10 (58.8%)
Time to event (Time to Recurrence of Mood Episodes in Days)
Median (95% CI) | . (57.0, .) | 42.0 (31.0, .)
25% Percentile | 146.0 (14.0, .) | 35.0 (15.0, 42.0)
75% Percentile | . | . (42.0, .)
Range | (14, 202) | (15, 204)
Stratified Analysis by Age Group
Hazard Ratio (Relative to Placebo) | 0.4
(95% CI) | (0.1, 1.4)
P value ^1^ | 0.1656

Note:

1 P-value is calculated from the Cox proportional hazards regression model.

Table 14.2.3.2.5 Secondary Efficacy Endpoint: Young Mania Rating Scale (YMRS) by Discontinuation Phase Randomized Treatment Group Discontinuation Phase - Efficacy Population

| Discontinuation Phase Randomized Treatment Group | | Total; (N=31) | P-Value^1^
| Lithium; (N=14) | Placebo; (N=17) | Total; (N=31) | P-Value^1^
Summary Score at Baseline
N | 14 | 17 | 31
Mean (SD) | 4.6 (3.3) | 5.9 (2.2) | 5.3 (2.8)
Median (Min-Max) | 5.0 (0.0 - 10.0) | 6.0 (0.0 - 10.0) | 6.0 (0.0 - 10.0)
Summary Score at Week 28/End-of-Phase/LOCF
N | 14 | 17 | 31
Mean (SD) | 9.6 (9.6) | 14.9 (8.9) | 12.5 (9.5)
Median (Min-Max) | 6.5 (0.0 - 30.0) | 16.0 (3.0 - 33.0) | 12.0 (0.0 - 33.0)
Change in Summary Score from Baseline to Week 28/End-of-Phase/LOCF
N | 14 | 17 | 31 | 0.127
Mean (SD) | 5.1 (10.4) | 9.0 (9.6) | 7.2 (10.0)
Median (Min-Max) | 1.0 (−8.0 - 25.0) | 9.0 (−4.0 - 26.0) | 5.0 (−8.0 - 26.0)
Parent Score at Baseline
N | 14 | 17 | 31
Mean (SD) | 4.6 (3.3) | 5.6 (2.8) | 5.1 (3.1)
Median (Min-Max) | 5.0 (0.0 - 10.0) | 6.0 (0.0 - 10.0) | 5.0 (0.0 - 10.0)
Parent Score at Week 28/End-of-Phase/LOCF
N | 14 | 17 | 31
Mean (SD) | 9.7 (9.6) | 14.6 (9.3) | 12.4 (9.6)
Median (Min-Max) | 6.5 (0.0 - 30.0) | 16.0 (0.0 - 33.0) | 12.0 (0.0 - 33.0)
Change in Parent Score from Baseline to Week 28/End-of-Phase/LOCF
N | 14 | 17 | 31 | 0.183
Mean (SD) | 5.1 (10.3) | 9.1 (10.0) | 7.3 (10.2)
Median (Min-Max) | 1.0 (−8.0 - 25.0) | 9.0 (−10.0 - 26.0) | 8.0 (−10.0 - 26.0)
Child Score at Baseline
N | 14 | 17 | 31
Mean (SD) | 3.8 (3.5) | 5.8 (2.8) | 4.9 (3.2)
Median (Min-Max) | 3.5 (0.0 - 10.0) | 6.0 (0.0 - 11.0) | 5.0 (0.0 - 11.0)
Child Score at Week 28/End-of-Phase/LOCF
N | 14 | 17 | 31
Mean (SD) | 6.5 (8.0) | 10.7 (8.8) | 8.8 (8.6)
Median (Min-Max) | 2.0 (0.0 - 21.0) | 9.0 (0.0 - 31.0) | 4.0 (0.0 - 31.0)
Change in Child Score from Baseline to Week 28/End-of-Phase/LOCF
N | 14 | 17 | 31 | 0.251
Mean (SD) | 2.7 (8.5) | 4.9 (9.2) | 3.9 (8.8)
Median (Min-Max) | 0.0 (−8.0 - 21.0) | 3.0 (−7.0 - 24.0) | 1.0 (−8.0 - 24.0)

Note: Baseline is defined as the last visit of Long-Term Effectiveness Phase.

Change score is week 28/end of phase value minus baseline value.

1 P-value is calculated from linear model for the treatment effect of change in YMRS Total Score from Baseline to Week 28/End-of-Phase.

Table 14.2.3.2.6 Secondary Efficacy Endpoint: Children Depression Rating Scale-Revised (CDRS-R) by Discontinuation Phase Randomized Treatment Group Discontinuation Phase - Efficacy Population

| Discontinuation Phase Randomized Treatment Group | | Total; (N=31) | P-Value^1^
| Lithium; (N=14) | Placebo; (N=17) | Total; (N=31) | P-Value^1^
Total Score at Baseline
N | 14 | 17 | 31
Mean (SD) | 19.4 (2.9) | 22.6 (5.7) | 21.2 (4.9)
Median (Min-Max) | 18.0 (17.0 - 26.0) | 22.0 (17.0 - 34.0) | 19.0 (17.0 - 34.0)
Total Score at Week 28/End-of-Phase/LOCF
N | 14 | 17 | 31
Mean (SD) | 21.8 (5.1) | 26.6 (10.6) | 24.5 (8.8)
Median (Min-Max) | 19.0 (17.0 - 32.0) | 23.0 (17.0 - 64.0) | 22.0 (17.0 - 64.0)
Change in Total Score from Baseline to Week 28/End-of-Phase/LOCF
N | 14 | 17 | 31 | 0.257
Mean (SD) | 2.4 (6.1) | 4.0 (10.3) | 3.3 (8.6)
Median (Min-Max) | 0.0 (−7.0 - 14.0) | 3.0 (−9.0 - 35.0) | 1.0 (−9.0 - 35.0)

Note: Baseline is defined as the last visit of Long-Term Effectiveness Phase.

Change score is week 28/end of phase value minus baseline value.

1 P-value is calculated from linear model for the treatment effect of change from Baseline score to Week 28/End-of-Phase score.

Table 14.2.3.2.7 Secondary Efficacy Endpoint: Children’s Global Assessment Scale (CGAS) by Discontinuation Phase Randomized Treatment Group Discontinuation Phase - Efficacy Population

| Discontinuation Phase Randomized Treatment Group | | Total; (N=31) | P-Value^1^
| Lithium; (N=14) | Placebo; (N=17) | Total; (N=31) | P-Value^1^
Total Score at Baseline
N | 14 | 17 | 31
Mean (SD) | 74.4 (12.6) | 72.4 (14.0) | 73.3 (13.2)
Median (Min-Max) | 80.0 (50.0 - 90.0) | 73.0 (50.0 - 91.0) | 80.0 (50.0 - 91.0)
Total Score at Week 28/End-of-Phase/LOCF
N | 13 | 16 | 29
Mean (SD) | 73.9 (11.0) | 63.8 (15.6) | 68.3 (14.5)
Median (Min-Max) | 75.0 (55.0 - 90.0) | 56.5 (50.0 - 95.0) | 70.0 (50.0 - 95.0)
Change in Total Score from Baseline to Week 28/End-of-Phase/LOCF
N | 13 | 16 | 29 | 0.123
Mean (SD) | −1.6 (20.9) | −7.6 (12.9) | −4.9 (16.9)
Median (Min-Max) | 5.0 (−35.0 - 30.0) | −9.5 (−27.0 - 13.0) | −5.0 (−35.0 - 30.0)

Note: Baseline is defined as the last visit of Long-Term Effectiveness Phase.

Change score is week 28/end of phase value minus baseline value.

1 P-value is calculated from linear model for the treatment effect of change from Baseline score to Week 28/End-of-Phase score.

Table 14.2.3.2.8 Secondary Efficacy Endpoint: Clinical Global Impression Scale (CGI) by Discontinuation Phase Randomized Treatment Group Discontinuation Phase - Efficacy Population

| Discontinuation Phase Randomized Treatment Group | | Total; (N=31) | P-Value^1^
| Lithium; (N=14) | Placebo; (N=17) | Total; (N=31) | P-Value^1^
CGI-Severity Mania at Baseline
1-Normal, not at all ill | 8 (57.1%) | 8 (47.1%) | 16 (51.6%)
2-Borderline ill | 4 (28.6%) | 4 (23.5%) | 8 (25.8%)
3-Mildly ill | 2 (14.3%) | 5 (29.4%) | 7 (22.6%)
CGI-Severity Mania at Week 28/End-of-Phase/LOCF
1-Normal, not at all ill | 6 (42.9%) | 4 (23.5%) | 10 (32.3%)
2-Borderline ill | 3 (21.4%) | 1 (5.9%) | 4 (12.9%)
3-Mildly ill | 3 (21.4%) | 6 (35.3%) | 9 (29.0%)
4-Moderately ill | 1 (7.1%) | 4 (23.5%) | 5 (16.1%)
5-Markedly ill | 1 (7.1%) | 2 (11.8%) | 3 (9.7%)
Change in CGI-Severity Mania from Baseline to Week 28/End-of-Phase/LOCF
Failure | 6 (42.9%) | 12 (70.6%) | 18 (58.1%) | 0.157
Success | 8 (57.1%) | 5 (29.4%) | 13 (41.9%)
CGI-Severity Depression at Baseline
1-Normal, not at all ill | 9 (64.3%) | 10 (58.8%) | 19 (61.3%)
2-Borderline ill | 3 (21.4%) | 2 (11.8%) | 5 (16.1%)
3-Mildly ill | 2 (14.3%) | 5 (29.4%) | 7 (22.6%)
CGI-Severity Depression at Week 28/End-of-Phase/LOCF
1-Normal, not at all ill | 6 (42.9%) | 7 (41.2%) | 13 (41.9%)
2-Borderline ill | 7 (50.0%) | 2 (11.8%) | 9 (29.0%)
3-Mildly ill | 1 (7.1%) | 4 (23.5%) | 5 (16.1%)
4-Moderately ill | 0 | 3 (17.6%) | 3 (9.7%)
6-Severely ill | 0 | 1 (5.9%) | 1 (3.2%)
Change in CGI-Severity Depression from Baseline to Week 28/End-of-Phase/LOCF
Failure | 5 (35.7%) | 10 (58.8%) | 15 (48.4%) | 0.285
Success | 9 (64.3%) | 7 (41.2%) | 16 (51.6%)
CGI-Severity Overall Illness at Baseline
1-Normal, not at all ill | 8 (57.1%) | 8 (47.1%) | 16 (51.6%)
2-Borderline ill | 4 (28.6%) | 4 (23.5%) | 8 (25.8%)
3-Mildly ill | 2 (14.3%) | 5 (29.4%) | 7 (22.6%)
CGI-Severity Overall Illness at Week 28/End-of-Phase/LOCF
1-Normal, not at all ill | 6 (42.9%) | 4 (23.5%) | 10 (32.3%)
2-Borderline ill | 3 (21.4%) | 1 (5.9%) | 4 (12.9%)
3-Mildly ill | 3 (21.4%) | 5 (29.4%) | 8 (25.8%)
4-Moderately ill | 1 (7.1%) | 6 (35.3%) | 7 (22.6%)
5-Markedly ill | 1 (7.1%) | 0 | 1 (3.2%)
6-Severely ill | 0 | 1 (5.9%) | 1 (3.2%)
Change in CGI-Severity Overall Illness from Baseline to Week 28/End-of-Phase/LOCF
Failure | 6 (42.9%) | 12 (70.6%) | 18 (58.1%) | 0.157
Success | 8 (57.1%) | 5 (29.4%) | 13 (41.9%)
CGI-Improvement Mania at Week 28/End-of-Phase/LOCF
Very much improved | 4 (28.6%) | 0 | 4 (12.9%)
Much improved | 5 (35.7%) | 3 (17.6%) | 8 (25.8%)
Minimally improved | 0 | 3 (17.6%) | 3 (9.7%)
No change | 2 (14.3%) | 4 (23.5%) | 6 (19.4%)
Minimally worse | 0 | 2 (11.8%) | 2 (6.5%)
Much worse | 1 (7.1%) | 1 (5.9%) | 2 (6.5%)
Very much worse | 2 (14.3%) | 4 (23.5%) | 6 (19.4%)
CGI-Improvement Mania at Week 28/End-of-Phase/LOCF
Failure | 3 (21.4%) | 8 (47.1%) | 11 (35.5%) | 0.258
Success | 11 (78.6%) | 9 (52.9%) | 20 (64.5%)
CGI-Improvement Depression at Week 28/End-of-Phase/LOCF
Very much improved | 4 (28.6%) | 0 | 4 (12.9%)
Much improved | 5 (35.7%) | 3 (17.6%) | 8 (25.8%)
Minimally improved | 0 | 3 (17.6%) | 3 (9.7%)
No change | 2 (14.3%) | 6 (35.3%) | 8 (25.8%)
Minimally worse | 3 (21.4%) | 2 (11.8%) | 5 (16.1%)
Much worse | 0 | 2 (11.8%) | 2 (6.5%)
Very much worse | 0 | 1 (5.9%) | 1 (3.2%)
CGI-Improvement Depression at Week 28/End-of-Phase/LOCF
Failure | 3 (21.4%) | 6 (35.3%) | 9 (29.0%) | 0.456
Success | 11 (78.6%) | 11 (64.7%) | 22 (71.0%)
CGI-Improvement Overall Illness at Week 28/End-of-Phase/LOCF
Very much improved | 4 (28.6%) | 0 | 4 (12.9%)
Much improved | 5 (35.7%) | 3 (17.6%) | 8 (25.8%)
Minimally improved | 0 | 3 (17.6%) | 3 (9.7%)
No change | 2 (14.3%) | 4 (23.5%) | 6 (19.4%)
Minimally worse | 0 | 1 (5.9%) | 1 (3.2%)
Much worse | 1 (7.1%) | 3 (17.6%) | 4 (12.9%)
Very much worse | 2 (14.3%) | 3 (17.6%) | 5 (16.1%)
CGI-Improvement Overall Illness at Week 28/End-of-Phase/LOCF
Failure | 3 (21.4%) | 8 (47.1%) | 11 (35.5%) | 0.258
Success | 11 (78.6%) | 9 (52.9%) | 20 (64.5%)

Note: Baseline is defined as the last visit of Long-Term Effectiveness Phase.

Change score is week 28/end of phase value minus baseline value.

1 P-value is calculated from Fisher’s Exact test for the treatment effect.

CGI-Severity Success is defined as: baseline value of 1,2 with change to LOCF of <= 0; baseline value of 3 with change of <= −1; baseline of 4,5,6 with change of <= −2 & LOCF score of 1,2,3.

CGI-Improvement Success is defined as: baseline CGI-S value of 1,2 & CGI-I <=4 at LOCF; baseline CGI-S value of 3 & CGI-I <=3 at LOCF; baseline CGI-S value of 4,5,6 & CGI-I 1,2 at LOCF.

Table 14.2.3.3.1 Tertiary Efficacy Endpoint: Parent General Behavior Inventory-10 Item Mania Scale (PGBI-10M) by Discontinuation Phase Randomized Treatment Group Discontinuation Phase - Efficacy Population

| Discontinuation Phase Randomized Treatment Group | | Total; (N=31) | P-Value^1^
| Lithium; (N=14) | Placebo; (N=17) | Total; (N=31) | P-Value^1^
Total Score at Baseline
N | 14 | 17 | 31
Mean (SD) | 5.4 (4.4) | 5.4 (6.3) | 5.4 (5.5)
Median (Min-Max) | 4.5 (0.0 - 15.0) | 3.0 (0.0 - 23.0) | 3.0 (0.0 - 23.0)
Total Score at Week 28/End-of-Phase/LOCF
N | 13 | 16 | 29
Mean (SD) | 6.2 (7.0) | 10.4 (9.2) | 8.6 (8.4)
Median (Min-Max) | 3.0 (0.0 - 26.0) | 8.5 (0.0 - 29.0) | 7.0 (0.0 - 29.0)
Change in Total Score from Baseline to Week 28/End-of-Phase/LOCF
N | 13 | 16 | 29 | 0.175
Mean (SD) | 0.9 (8.0) | 5.0 (8.0) | 3.2 (8.2)
Median (Min-Max) | 2.0 (−12.0 - 16.0) | 1.5 (−2.0 - 24.0) | 2.0 (−12.0 - 24.0)

Note: Baseline is defined as the last visit of Long-Term Effectiveness Phase.

Change score is week 28/end of phase value minus baseline value.

1 P-value is calculated from linear model for the treatment effect of change from Baseline score to Week 28/End-of-Phase score.

Table 14.2.3.3.2 Tertiary Efficacy Endpoint: ADHD Rating Scale (ARS-IV) by Discontinuation Phase Randomized Treatment Group Discontinuation Phase - Efficacy Population

| Discontinuation Phase Randomized Treatment Group | | Total; (N=31) | P-Value^1^
| Lithium; (N=14) | Placebo; (N=17) | Total; (N=31) | P-Value^1^
ADHD Total Score at Baseline
N | 14 | 17 | 31
Mean (SD) | 20.7 (13.2) | 23.4 (13.3) | 22.2 (13.1)
Median (Min-Max) | 18.5 (0.0 - 42.0) | 22.0 (1.0 - 41.0) | 20.0 (0.0 - 42.0)
ADHD Total Score at Week 28/End-of-Phase/LOCF
N | 13 | 16 | 29
Mean (SD) | 19.2 (13.3) | 23.6 (15.2) | 21.6 (14.3)
Median (Min-Max) | 18.0 (0.0 - 46.0) | 21.5 (3.0 - 45.0) | 18.0 (0.0 - 46.0)
Change in ADHD Total Score from Baseline to Week 28/End-of-Phase/LOCF
N | 13 | 16 | 29 | 0.662
Mean (SD) | 0.0 (14.1) | 1.3 (9.2) | 0.7 (11.4)
Median (Min-Max) | 2.0 (−24.0 - 29.0) | 2.5 (−18.0 - 16.0) | 2.0 (−24.0 - 29.0)
ADHD Inattention Subscale at Baseline
N | 14 | 17 | 31
Mean (SD) | 12.3 (6.6) | 14.2 (7.1) | 13.3 (6.8)
Median (Min-Max) | 12.0 (0.0 - 25.0) | 16.0 (1.0 - 24.0) | 13.0 (0.0 - 25.0)
ADHD Inattention Subscale at Week 28/End-of-Phase/LOCF
N | 13 | 16 | 29
Mean (SD) | 9.9 (6.3) | 13.8 (8.0) | 12.1 (7.5)
Median (Min-Max) | 10.0 (0.0 - 23.0) | 14.5 (1.0 - 26.0) | 12.0 (0.0 - 26.0)
Change in Inattention Subscale from Baseline to Week 28/End-of-Phase/LOCF
N | 13 | 16 | 29 | 0.335
Mean (SD) | −1.4 (7.3) | 0.3 (4.7) | −0.5 (5.9)
Median (Min-Max) | 0.0 (−13.0 - 13.0) | 1.5 (−8.0 - 9.0) | 1.0 (−13.0 - 13.0)
ADHD Hyperactivity-Impulsivity Subscale at Baseline
N | 14 | 17 | 31
Mean (SD) | 8.4 (7.3) | 9.2 (6.9) | 8.8 (7.0)
Median (Min-Max) | 6.0 (0.0 - 20.0) | 8.0 (0.0 - 21.0) | 7.0 (0.0 - 21.0)
ADHD Hyperactivity-Impulsivity Subscale at Week 28/End-of-Phase/LOCF
N | 13 | 16 | 29
Mean (SD) | 9.2 (7.4) | 9.8 (7.6) | 9.5 (7.4)
Median (Min-Max) | 8.0 (0.0 - 23.0) | 9.0 (0.0 - 23.0) | 8.0 (0.0 - 23.0)
Change in ADHD Hyperactivity-Impulsivity Subscale from Baseline to Week 28/End-of-Phase/LOCF
N | 13 | 16 | 29 | 0.968
Mean (SD) | 1.4 (7.1) | 1.1 (5.8) | 1.2 (6.3)
Median (Min-Max) | 2.0 (−11.0 - 16.0) | 1.5 (−15.0 - 10.0) | 2.0 (−15.0 - 16.0)

Note: Baseline is defined as the last visit of Long-Term Effectiveness Phase.

Change score is week 28/end of phase value minus baseline value.

1 P-value is calculated from linear model for the treatment effect of change from Baseline score to Week 28/End-of-Phase score.

Table 14.2.3.3.3 Tertiary Efficacy Endpoint: Brief Psychiatric Rating Scale-For Children (BPRS-C) by Discontinuation Phase Randomized Treatment Group Discontinuation Phase - Efficacy Population

| Discontinuation Phase Randomized Treatment Group | | Total; (N=31) | P-Value^1^
| Lithium; (N=14) | Placebo; (N=17) | Total; (N=31) | P-Value^1^
BPRS-C Total score at Baseline
N | 14 | 16 | 30
Mean (SD) | 8.1 (6.6) | 11.3 (13.7) | 9.8 (10.9)
Median (Min-Max) | 7.5 (0.0 - 23.0) | 6.0 (0.0 - 53.0) | 6.5 (0.0 - 53.0)
BPRS-C Total score at Week 28/End-of-Phase/LOCF
N | 13 | 16 | 29
Mean (SD) | 9.8 (10.4) | 16.6 (9.4) | 13.5 (10.3)
Median (Min-Max) | 3.0 (0.0 - 28.0) | 17.0 (1.0 - 38.0) | 14.0 (0.0 - 38.0)
Change in BPRS-C Total score from Baseline to Week 28/End-of-Phase/LOCF
N | 13 | 15 | 28 | 0.128
Mean (SD) | 1.4 (14.0) | 3.8 (16.3) | 2.7 (15.1)
Median (Min-Max) | −5.0 (−19.0 - 28.0) | 5.0 (−33.0 - 24.0) | 3.0 (−33.0 - 28.0)
BPRS-C Behavior Problems subscale at Baseline
N | 14 | 17 | 31
Mean (SD) | 3.1 (3.9) | 3.6 (4.7) | 3.4 (4.3)
Median (Min-Max) | 2.0 (0.0 - 14.0) | 2.0 (0.0 - 17.0) | 2.0 (0.0 - 17.0)
BPRS-C Behavior Problems subscale at Week 28/End-of-Phase/LOCF
N | 13 | 16 | 29
Mean (SD) | 3.8 (4.4) | 5.8 (4.1) | 4.9 (4.3)
Median (Min-Max) | 3.0 (0.0 - 13.0) | 5.5 (0.0 - 14.0) | 4.0 (0.0 - 14.0)
Change in BPRS-C Behavior Problems subscale from Baseline to Week 28/End-of-Phase/LOCF
N | 13 | 16 | 29 | 0.237
Mean (SD) | 0.8 (5.7) | 1.9 (3.4) | 1.4 (4.5)
Median (Min-Max) | −1.0 (−9.0 - 9.0) | 1.0 (−3.0 - 8.0) | 0.0 (−9.0 - 9.0)
BPRS-C Depression subscale at Baseline
N | 14 | 17 | 31
Mean (SD) | 0.3 (0.7) | 1.7 (2.4) | 1.1 (1.9)
Median (Min-Max) | 0.0 (0.0 - 2.0) | 0.0 (0.0 - 7.0) | 0.0 (0.0 - 7.0)
BPRS-C Depression subscale at Week 28/End-of-Phase/LOCF
N | 13 | 16 | 29
Mean (SD) | 1.4 (2.2) | 1.9 (2.8) | 1.7 (2.5)
Median (Min-Max) | 0.0 (0.0 - 6.0) | 0.0 (0.0 - 8.0) | 0.0 (0.0 - 8.0)
Change in BPRS-C Depression subscale from Baseline to Week 28/End-of-Phase/LOCF
N | 13 | 16 | 29 | 0.354
Mean (SD) | 1.1 (2.5) | 0.1 (3.8) | 0.6 (3.3)
Median (Min-Max) | 0.0 (−2.0 - 6.0) | 0.0 (−7.0 - 6.0) | 0.0 (−7.0 - 6.0)
BPRS-C Thinking Disturbance subscale at Baseline
N | 14 | 17 | 31
Mean (SD) | 0.0 (0.0) | 0.0 (0.0) | 0.0 (0.0)
Median (Min-Max) | 0.0 (0.0 - 0.0) | 0.0 (0.0 - 0.0) | 0.0 (0.0 - 0.0)
BPRS-C Thinking Disturbance subscale at Week 28/End-of-Phase/LOCF
N | 13 | 16 | 29
Mean (SD) | 0.0 (0.0) | 0.1 (0.3) | 0.1 (0.3)
Median (Min-Max) | 0.0 (0.0 - 0.0) | 0.0 (0.0 - 1.0) | 0.0 (0.0 - 1.0)
Change in BPRS-C Thinking Disturbance subscale from Baseline to Week 28/End-of-Phase/LOCF
N | 13 | 16 | 29 | 0.194
Mean (SD) | 0.0 (0.0) | 0.1 (0.3) | 0.1 (0.3)
Median (Min-Max) | 0.0 (0.0 - 0.0) | 0.0 (0.0 - 1.0) | 0.0 (0.0 - 1.0)
BPRS-C Psychomotor excitation subscale at Baseline
N | 14 | 17 | 31
Mean (SD) | 3.5 (4.5) | 3.4 (4.1) | 3.4 (4.2)
Median (Min-Max) | 2.0 (0.0 - 15.0) | 2.0 (0.0 - 15.0) | 2.0 (0.0 - 15.0)
BPRS-C Psychomotor excitation subscale at Week 28/End-of-Phase/LOCF
N | 13 | 16 | 29
Mean (SD) | 3.1 (3.6) | 4.9 (3.8) | 4.1 (3.7)
Median (Min-Max) | 2.0 (0.0 - 11.0) | 4.5 (0.0 - 13.0) | 3.0 (0.0 - 13.0)
Change in BPRS-C Psychomotor excitation subscale from Baseline to Week 28/End-of-Phase/LOCF
N | 13 | 16 | 29 | 0.266
Mean (SD) | −0.7 (6.1) | 1.3 (6.4) | 0.4 (6.2)
Median (Min-Max) | 0.0 (−15.0 - 7.0) | 3.0 (−12.0 - 12.0) | 1.0 (−15.0 - 12.0)
BPRS-C Withdrawal subscale at Baseline
N | 14 | 17 | 31
Mean (SD) | 0.0 (0.0) | 0.1 (0.2) | 0.0 (0.2)
Median (Min-Max) | 0.0 (0.0 - 0.0) | 0.0 (0.0 - 1.0) | 0.0 (0.0 - 1.0)
BPRS-C Withdrawal subscale at Week 28/End-of-Phase/LOCF
N | 13 | 16 | 29
Mean (SD) | 1.0 (1.9) | 1.4 (1.7) | 1.2 (1.8)
Median (Min-Max) | 0.0 (0.0 - 5.0) | 0.5 (0.0 - 5.0) | 0.0 (0.0 - 5.0)
Change in BPRS-C Withdrawal subscale from Baseline to Week 28/End-of-Phase/LOCF
N | 13 | 16 | 29 | 0.476
Mean (SD) | 1.0 (1.9) | 1.3 (1.8) | 1.2 (1.8)
Median (Min-Max) | 0.0 (0.0 - 5.0) | 0.5 (−1.0 - 5.0) | 0.0 (−1.0 - 5.0)
BPRS-C Anxiety subscale at Baseline
N | 14 | 16 | 30
Mean (SD) | 1.1 (1.7) | 2.3 (4.0) | 1.8 (3.1)
Median (Min-Max) | 0.0 (0.0 - 5.0) | 0.0 (0.0 - 14.0) | 0.0 (0.0 - 14.0)
BPRS-C Anxiety subscale at Week 28/End-of-Phase/LOCF
N | 13 | 16 | 29
Mean (SD) | 0.5 (0.9) | 2.3 (3.2) | 1.4 (2.6)
Median (Min-Max) | 0.0 (0.0 - 3.0) | 0.0 (0.0 - 10.0) | 0.0 (0.0 - 10.0)
Change in BPRS-C Anxiety subscale from Baseline to Week 28/End-of-Phase/LOCF
N | 13 | 15 | 28 | 0.555
Mean (SD) | −0.8 (2.1) | −0.4 (4.4) | −0.6 (3.4)
Median (Min-Max) | 0.0 (−5.0 - 3.0) | 0.0 (−11.0 - 8.0) | 0.0 (−11.0 - 8.0)
BPRS-C Organicity subscale at Baseline
N | 14 | 17 | 31
Mean (SD) | 0.0 (0.0) | 0.0 (0.0) | 0.0 (0.0)
Median (Min-Max) | 0.0 (0.0 - 0.0) | 0.0 (0.0 - 0.0) | 0.0 (0.0 - 0.0)
BPRS-C Organicity subscale at Week 28/End-of-Phase/LOCF
N | 13 | 16 | 29
Mean (SD) | 0.0 (0.0) | 0.3 (1.0) | 0.1 (0.7)
Median (Min-Max) | 0.0 (0.0 - 0.0) | 0.0 (0.0 - 4.0) | 0.0 (0.0 - 4.0)
Change in BPRS-C Organicity subscale from Baseline to Week 28/End-of-Phase/LOCF
N | 13 | 16 | 29 | 0.367
Mean (SD) | 0.0 (0.0) | 0.3 (1.0) | 0.1 (0.7)
Median (Min-Max) | 0.0 (0.0 - 0.0) | 0.0 (0.0 - 4.0) | 0.0 (0.0 - 4.0)

Note: Baseline is defined as the last visit of Long-Term Effectiveness Phase.

Change score is week 28/end of phase value minus baseline value.

1 P-value is calculated from linear model for the treatment effect of change from Baseline score to Week 28/End-of-Phase score.P-values for Depression, Thinking, Withdrawal, Anxiety and Organicity are calculated from Kruskal-Wallis Test for the treatment effect of change from Baseline score to Week 28/End-of-Phase score.

Table 14.2.3.3.4 Tertiary Efficacy Endpoint: Pediatric Anxiety Rating Scale (PARS) by Discontinuation Phase Randomized Treatment Group Discontinuation Phase - Efficacy Population

| Discontinuation Phase Randomized Treatment Group | | Total; (N=31) | P-Value^1^
| Lithium; (N=14) | Placebo; (N=17) | Total; (N=31) | P-Value^1^
Total Score at Baseline
N | 14 | 17 | 31
Mean (SD) | 1.7 (5.0) | 2.4 (5.2) | 2.1 (5.0)
Median (Min-Max) | 0.0 (0.0 - 18.0) | 0.0 (0.0 - 18.0) | 0.0 (0.0 - 18.0)
Total Score at Week 28/End-of-Phase/LOCF
N | 13 | 16 | 29
Mean (SD) | 0.7 (2.5) | 2.9 (6.4) | 1.9 (5.1)
Median (Min-Max) | 0.0 (0.0 - 9.0) | 0.0 (0.0 - 21.0) | 0.0 (0.0 - 21.0)
Change in Total Score from Baseline to Week 28/End-of-Phase/LOCF
N | 13 | 16 | 29 | 0.640
Mean (SD) | −1.2 (2.9) | 0.4 (5.7) | −0.3 (4.7)
Median (Min-Max) | 0.0 (−9.0 - 0.0) | 0.0 (−11.0 - 16.0) | 0.0 (−11.0 - 16.0)
Sub Score at Baseline
N | 14 | 17 | 31
Mean (SD) | 1.1 (3.7) | 1.8 (4.0) | 1.5 (3.8)
Median (Min-Max) | 0.0 (0.0 - 14.0) | 0.0 (0.0 - 12.0) | 0.0 (0.0 - 14.0)
Sub Score at Week 28/End-of-Phase/LOCF
N | 13 | 16 | 29
Mean (SD) | 0.4 (1.4) | 2.3 (4.9) | 1.4 (3.8)
Median (Min-Max) | 0.0 (0.0 - 5.0) | 0.0 (0.0 - 17.0) | 0.0 (0.0 - 17.0)
Change in Sub Score from Baseline to Week 28/End-of-Phase/LOCF
N | 13 | 16 | 29 | 0.255
Mean (SD) | −0.8 (2.5) | 0.4 (3.7) | −0.2 (3.3)
Median (Min-Max) | 0.0 (−9.0 - 0.0) | 0.0 (−7.0 - 11.0) | 0.0 (−9.0 - 11.0)

Note: Baseline is defined as the last visit of Long-Term Effectiveness Phase.

Change score is week 28/end of phase value minus baseline value.

1 P-value is calculated from Kruskal-Wallis Test for the treatment effect of change from Baseline score to Week 28/End-of-Phase score.

Table 14.2.4.1 Primary Efficacy Endpoint: Young Mania Rating Scale (YMRS) by Discontinuation Phase Randomized Treatment Group Restabilization Phase - Efficacy Population

| Discontinuation Phase Randomized Treatment Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
YMRS Total Score at Baseline
N | 3 | 10 | 13
Mean (SD) | 23.0 (6.2) | 20.2 (6.9) | 20.8 (6.6)
Median (Min-Max) | 21.0 (18.0 - 30.0) | 19.0 (10.0 - 33.0) | 19.0 (10.0 - 33.0)
YMRS Total Score at Week 8/End-of-Phase/LOCF
N | 3 | 10 | 13
Mean (SD) | 7.7 (7.2) | 12.4 (7.8) | 11.3 (7.6)
Median (Min-Max) | 4.0 (3.0 - 16.0) | 10.5 (2.0 - 27.0) | 9.0 (2.0 - 27.0)
Change in YMRS Total Score from Baseline to Week 8/End-of-Phase
N | 3 | 10 | 13
Mean (SD) | −15.3 (1.5) | −7.8 (12.0) | −9.5 (10.9)
Median (Min-Max) | −15.0 (−17.0 - −14.0) | −10.0 (−21.0 - 12.0) | −14.0 (−21.0 - 12.0)

Note: Baseline is defined as the last visit of Discontinuation Phase.

Change score is week 8/LOCF value minus baseline value.

Table 14.2.4.2.1 Secondary Efficacy Endpoint: Response, Remission, Improvement and Discontinuation by Discontinuation Phase Randomized Treatment Group Restabilization Phase - Efficacy Population

| Discontinuation Phase Randomized Treatment Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
YMRS Response
Non-response | 1 (33.3%) | 4 (40.0%) | 5 (38.5%)
Partial Response | 0 | 2 (20.0%) | 2 (15.4%)
Complete Response | 2 (66.7%) | 4 (40.0%) | 6 (46.2%)
YMRS Remission
No remission | 1 (33.3%) | 6 (60.0%) | 7 (53.8%)
Remission | 2 (66.7%) | 4 (40.0%) | 6 (46.2%)
YMRS Improvement
Reduction <25% | 0 | 1 (10.0%) | 1 (7.7%)
Reduction = 25-49% | 0 | 2 (20.0%) | 2 (15.4%)
Reduction ≥50% | 3 (100.0%) | 7 (70.0%) | 10 (76.9%)
Discontinuation due to any cause during the Restabilization Phase
Completed Study | 2 (66.7%) | 7 (70.0%) | 9 (69.2%)
Terminated for any reason | 1 (33.3%) | 3 (30.0%) | 4 (30.8%)

Note: Baseline value is the pre-dose value from day 1 of the Efficacy Phase or Pharmacokinetic Phase.

Table 14.2.4.2.2 Secondary Efficacy Endpoint: Young Mania Rating Scale (YMRS) by Discontinuation Phase Randomized Treatment Group Restabilization Phase - Efficacy Population

| Discontinuation Phase Randomized Treatment Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Parent Score at Baseline
N | 3 | 10 | 13
Mean (SD) | 23.0 (6.2) | 20.2 (6.9) | 20.8 (6.6)
Median (Min-Max) | 21.0 (18.0 - 30.0) | 19.0 (10.0 - 33.0) | 19.0 (10.0 - 33.0)
Parent Score at Week 8/End-of-Phase/LOCF
N | 3 | 10 | 13
Mean (SD) | 7.7 (7.2) | 12.3 (7.8) | 11.2 (7.6)
Median (Min-Max) | 4.0 (3.0 - 16.0) | 10.0 (2.0 - 27.0) | 9.0 (2.0 - 27.0)
Change in Parent Score from Baseline to Week 8/End-of-Phase/LOCF
N | 3 | 10 | 13
Mean (SD) | −15.3 (1.5) | −7.9 (12.0) | −9.6 (10.9)
Median (Min-Max) | −15.0 (−17.0 - −14.0) | −10.0 (−21.0 - 12.0) | −14.0 (−21.0 - 12.0)
Child Score at Baseline
N | 3 | 10 | 13
Mean (SD) | 12.0 (10.8) | 13.5 (9.7) | 13.2 (9.5)
Median (Min-Max) | 15.0 (0.0 - 21.0) | 15.5 (0.0 - 31.0) | 15.0 (0.0 - 31.0)
Child Score at Week 8/End-of-Phase/LOCF
N | 3 | 10 | 13
Mean (SD) | 3.7 (3.5) | 12.2 (7.6) | 10.2 (7.7)
Median (Min-Max) | 4.0 (0.0 - 7.0) | 10.5 (2.0 - 27.0) | 9.0 (0.0 - 27.0)
Change in Child Score from Baseline to Week 8/End-of-Phase/LOCF
N | 3 | 10 | 13
Mean (SD) | −8.3 (8.5) | −1.3 (12.4) | −2.9 (11.7)
Median (Min-Max) | −8.0 (−17.0 - 0.0) | 1.0 (−19.0 - 18.0) | −3.0 (−19.0 - 18.0)

Note: Baseline is defined as the last visit of Discontinuation Phase.

Change score is week 8/end of phase value minus baseline value.

Table 14.2.4.2.3 Secondary Efficacy Endpoint: Children Depression Rating Scale-Revised (CDRS-R) by Discontinuation Phase Randomized Treatment Group Restabilization Phase - Efficacy Population

| Discontinuation Phase Randomized Treatment Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Total Score at Baseline
N | 3 | 10 | 13
Mean (SD) | 27.7 (1.2) | 30.3 (12.6) | 29.7 (11.0)
Median (Min-Max) | 27.0 (27.0 - 29.0) | 28.5 (20.0 - 64.0) | 27.0 (20.0 - 64.0)
Total Score at Week 8/End-of-Phase/LOCF
N | 3 | 10 | 13
Mean (SD) | 20.0 (3.0) | 28.6 (10.2) | 26.6 (9.7)
Median (Min-Max) | 20.0 (17.0 - 23.0) | 25.5 (19.0 - 50.0) | 23.0 (17.0 - 50.0)
Change in Total Score from Baseline to Week 8/End-of-Phase/LOCF
N | 3 | 10 | 13
Mean (SD) | −7.7 (3.2) | −1.7 (14.9) | −3.1 (13.2)
Median (Min-Max) | −9.0 (−10.0 - −4.0) | −2.0 (−33.0 - 18.0) | −3.0 (−33.0 - 18.0)

Note: Baseline is defined as the last visit of Discontinuation Phase.

Change score is week 8/end of phase value minus baseline value.

Table 14.2.4.2.4 Secondary Efficacy Endpoint: Children’s Global Assessment Scale (CGAS) by Discontinuation Phase Randomized Treatment Group Restabilization Phase - Efficacy Population

| Discontinuation Phase Randomized Treatment Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Total Score at Baseline
N | 3 | 10 | 13
Mean (SD) | 60.0 (8.7) | 55.2 (6.3) | 56.3 (6.8)
Median (Min-Max) | 55.0 (55.0 - 70.0) | 54.0 (50.0 - 70.0) | 55.0 (50.0 - 70.0)
Total Score at Week 8/End-of-Phase/LOCF
N | 2 | 10 | 12
Mean (SD) | 78.0 (9.9) | 63.3 (14.9) | 65.8 (15.0)
Median (Min-Max) | 78.0 (71.0 - 85.0) | 65.5 (40.0 - 85.0) | 70.0 (40.0 - 85.0)
Change in Total Score from Baseline to Week 8/End-of-Phase/LOCF
N | 2 | 10 | 12
Mean (SD) | 15.5 (0.7) | 8.1 (11.7) | 9.3 (10.9)
Median (Min-Max) | 15.5 (15.0 - 16.0) | 9.5 (−10.0 - 32.0) | 10.5 (−10.0 - 32.0)

Note: Baseline is defined as the last visit of Discontinuation Phase.

Change score is week 8/end of phase value minus baseline value.

Table 14.2.4.2.5 Secondary Efficacy Endpoint: Clinical Global Impression Scale (CGI) by Discontinuation Phase Randomized Treatment Group Restabilization Phase - Efficacy Population

| Discontinuation Phase Randomized Treatment Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
CGI-Severity Mania at Baseline
3-Mildly ill | 1 (33.3%) | 4 (40.0%) | 5 (38.5%)
4-Moderately ill | 1 (33.3%) | 4 (40.0%) | 5 (38.5%)
5-Markedly ill | 1 (33.3%) | 2 (20.0%) | 3 (23.1%)
CGI-Severity Mania at Week 8/End-of-Phase/LOCF
1-Normal, not at all ill | 0 | 2 (20.0%) | 2 (15.4%)
2-Borderline ill | 2 (66.7%) | 3 (30.0%) | 5 (38.5%)
3-Mildly ill | 0 | 4 (40.0%) | 4 (30.8%)
4-Moderately ill | 0 | 1 (10.0%) | 1 (7.7%)
5-Markedly ill | 1 (33.3%) | 0 | 1 (7.7%)
Change in CGI-Severity Mania from Baseline to Week 8/End-of-Phase/LOCF
Failure | 1 (33.3%) | 4 (40.0%) | 5 (38.5%)
Success | 2 (66.7%) | 6 (60.0%) | 8 (61.5%)
CGI-Severity Depression at Baseline
1-Normal, not at all ill | 0 | 2 (20.0%) | 2 (15.4%)
2-Borderline ill | 3 (100.0%) | 1 (10.0%) | 4 (30.8%)
3-Mildly ill | 0 | 3 (30.0%) | 3 (23.1%)
4-Moderately ill | 0 | 3 (30.0%) | 3 (23.1%)
6-Severely ill | 0 | 1 (10.0%) | 1 (7.7%)
CGI-Severity Depression at Week 8/End-of-Phase/LOCF
1-Normal, not at all ill | 2 (66.7%) | 2 (20.0%) | 4 (30.8%)
2-Borderline ill | 1 (33.3%) | 3 (30.0%) | 4 (30.8%)
3-Mildly ill | 0 | 2 (20.0%) | 2 (15.4%)
4-Moderately ill | 0 | 3 (30.0%) | 3 (23.1%)
Change in CGI-Severity Depression from Baseline to Week 8/End-of-Phase/LOCF
Failure | 0 | 4 (40.0%) | 4 (30.8%)
Success | 3 (100.0%) | 6 (60.0%) | 9 (69.2%)
CGI-Severity Overall Illness at Baseline
3-Mildly ill | 1 (33.3%) | 3 (30.0%) | 4 (30.8%)
4-Moderately ill | 1 (33.3%) | 6 (60.0%) | 7 (53.8%)
5-Markedly ill | 1 (33.3%) | 0 | 1 (7.7%)
6-Severely ill | 0 | 1 (10.0%) | 1 (7.7%)
CGI-Severity Overall Illness at Week 8/End-of-Phase/LOCF
1-Normal, not at all ill | 0 | 1 (10.0%) | 1 (7.7%)
2-Borderline ill | 2 (66.7%) | 3 (30.0%) | 5 (38.5%)
3-Mildly ill | 0 | 3 (30.0%) | 3 (23.1%)
4-Moderately ill | 0 | 3 (30.0%) | 3 (23.1%)
5-Markedly ill | 1 (33.3%) | 0 | 1 (7.7%)
Change in CGI-Severity Overall Illness from Baseline to Week 8/End-of-Phase/LOCF
Failure | 1 (33.3%) | 5 (50.0%) | 6 (46.2%)
Success | 2 (66.7%) | 5 (50.0%) | 7 (53.8%)
CGI-Improvement Mania at Week 8/End-of-Phase/LOCF
Very much improved | 1 (33.3%) | 4 (40.0%) | 5 (38.5%)
Much improved | 1 (33.3%) | 3 (30.0%) | 4 (30.8%)
Minimally improved | 1 (33.3%) | 1 (10.0%) | 2 (15.4%)
No change | 0 | 2 (20.0%) | 2 (15.4%)
CGI-Improvement Mania at Week 8/End-of-Phase/LOCF
Failure | 1 (33.3%) | 2 (20.0%) | 3 (23.1%)
Success | 2 (66.7%) | 8 (80.0%) | 10 (76.9%)
CGI-Improvement Depression at Week 8/End-of-Phase/LOCF
Very much improved | 2 (66.7%) | 2 (20.0%) | 4 (30.8%)
Much improved | 0 | 2 (20.0%) | 2 (15.4%)
Minimally improved | 0 | 3 (30.0%) | 3 (23.1%)
No change | 1 (33.3%) | 2 (20.0%) | 3 (23.1%)
Much worse | 0 | 1 (10.0%) | 1 (7.7%)
CGI-Improvement Depression at Week 8/End-of-Phase/LOCF
Failure | 0 | 4 (40.0%) | 4 (30.8%)
Success | 3 (100.0%) | 6 (60.0%) | 9 (69.2%)
CGI-Improvement Overall Illness at Week 8/End-of-Phase/LOCF
Very much improved | 1 (33.3%) | 3 (30.0%) | 4 (30.8%)
Much improved | 1 (33.3%) | 4 (40.0%) | 5 (38.5%)
Minimally improved | 1 (33.3%) | 1 (10.0%) | 2 (15.4%)
No change | 0 | 1 (10.0%) | 1 (7.7%)
Minimally worse | 0 | 1 (10.0%) | 1 (7.7%)
CGI-Improvement Overall Illness at Week 8/End-of-Phase/LOCF
Failure | 1 (33.3%) | 3 (30.0%) | 4 (30.8%)
Success | 2 (66.7%) | 7 (70.0%) | 9 (69.2%)

Note: Baseline is defined as the last visit of Discontinuation Phase.

Change score is week 8/end of phase value minus baseline value.

CGI-Severity Success is defined as: baseline value of 1,2 with change to LOCF of <= 0; baseline value of 3 with change of <= −1; baseline of 4,5,6 with change of <= −2 & LOCF score of 1,2,3.

CGI-Improvement Success is defined as: baseline CGI-S value of 1,2 & CGI-I <=4 at LOCF; baseline CGI-S value of 3 & CGI-I <=3 at LOCF; baseline CGI-S value of 4,5,6 & CGI-I 1,2 at LOCF.

Table 14.2.4.3.1 Tertiary Efficacy Endpoint: Parent General Behavior Inventory-10 Item Mania Scale (PGBI-10M) by Discontinuation Phase Randomized Treatment Group Restabilization Phase - Efficacy Population

| Discontinuation Phase Randomized Treatment Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Total Score at Baseline
N | 3 | 10 | 13
Mean (SD) | 13.3 (11.2) | 11.1 (9.9) | 11.6 (9.8)
Median (Min-Max) | 9.0 (5.0 - 26.0) | 8.5 (0.0 - 29.0) | 9.0 (0.0 - 29.0)
Total Score at Week 8/End-of-Phase/LOCF
N | 2 | 10 | 12
Mean (SD) | 2.0 (2.8) | 7.6 (7.6) | 6.7 (7.3)
Median (Min-Max) | 2.0 (0.0 - 4.0) | 8.0 (0.0 - 20.0) | 5.0 (0.0 - 20.0)
Change in Total Score from Baseline to Week 8/End-of-Phase/LOCF
N | 2 | 10 | 12
Mean (SD) | −5.0 (0.0) | −3.5 (5.1) | −3.8 (4.7)
Median (Min-Max) | −5.0 (−5.0 - −5.0) | −2.0 (−11.0 - 4.0) | −3.5 (−11.0 - 4.0)

Note: Baseline is defined as the last visit of Discontinuation Phase.

Change score is week 8/end of phase value minus baseline value.

Table 14.2.4.3.2 Tertiary Efficacy Endpoint: ADHD Rating Scale (ARS-IV) by Discontinuation Phase Randomized Treatment Group Restabilization Phase - Efficacy Population

| Discontinuation Phase Randomized Treatment Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
ADHD Total Score at Baseline
N | 3 | 10 | 13
Mean (SD) | 24.3 (19.3) | 28.6 (15.8) | 27.6 (15.9)
Median (Min-Max) | 18.0 (9.0 - 46.0) | 33.0 (3.0 - 45.0) | 30.0 (3.0 - 46.0)
ADHD Total Score at Week 8/End-of-Phase/LOCF
N | 2 | 8 | 10
Mean (SD) | 17.0 (0.0) | 24.1 (15.6) | 22.7 (14.0)
Median (Min-Max) | 17.0 (17.0 - 17.0) | 25.5 (3.0 - 44.0) | 20.0 (3.0 - 44.0)
Change in ADHD Total Score from Baseline to Week 8/End-of-Phase/LOCF
N | 2 | 8 | 10
Mean (SD) | 3.5 (6.4) | −5.4 (4.7) | −3.6 (6.0)
Median (Min-Max) | 3.5 (−1.0 - 8.0) | −5.5 (−14.0 - 0.0) | −3.0 (−14.0 - 8.0)
ADHD Inattention Subscale at Baseline
N | 3 | 10 | 13
Mean (SD) | 13.3 (9.1) | 16.5 (8.3) | 15.8 (8.2)
Median (Min-Max) | 12.0 (5.0 - 23.0) | 19.0 (1.0 - 26.0) | 18.0 (1.0 - 26.0)
ADHD Inattention Subscale at Week 8/End-of-Phase/LOCF
N | 2 | 8 | 10
Mean (SD) | 11.0 (0.0) | 13.9 (8.9) | 13.3 (7.9)
Median (Min-Max) | 11.0 (11.0 - 11.0) | 15.0 (1.0 - 25.0) | 12.5 (1.0 - 25.0)
Change in Inattention Subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 2 | 8 | 10
Mean (SD) | 2.5 (4.9) | −2.5 (2.6) | −1.5 (3.5)
Median (Min-Max) | 2.5 (−1.0 - 6.0) | −1.5 (−7.0 - 0.0) | −1.0 (−7.0 - 6.0)
ADHD Hyperactivity-Impulsivity Subscale at Baseline
N | 3 | 10 | 13
Mean (SD) | 11.0 (10.4) | 12.1 (8.0) | 11.8 (8.1)
Median (Min-Max) | 6.0 (4.0 - 23.0) | 13.5 (0.0 - 23.0) | 12.0 (0.0 - 23.0)
ADHD Hyperactivity-Impulsivity Subscale at Week 8/End-of-Phase/LOCF
N | 2 | 8 | 10
Mean (SD) | 6.0 (0.0) | 10.3 (7.2) | 9.4 (6.6)
Median (Min-Max) | 6.0 (6.0 - 6.0) | 10.5 (0.0 - 19.0) | 7.5 (0.0 - 19.0)
Change in ADHD Hyperactivity-Impulsivity Subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 2 | 8 | 10
Mean (SD) | 1.0 (1.4) | −2.9 (2.7) | −2.1 (3.0)
Median (Min-Max) | 1.0 (0.0 - 2.0) | −3.0 (−7.0 - 0.0) | −1.5 (−7.0 - 2.0)

Note: Baseline is defined as the last visit of Discontinuation Phase.

Change score is week 8/end of phase value minus baseline value.

Table 14.2.4.3.3 Tertiary Efficacy Endpoint: Brief Psychiatric Rating Scale-For Children (BPRS-C) by Discontinuation Phase Randomized Treatment Group Restabilization Phase - Efficacy Population

| Discontinuation Phase Randomized Treatment Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
BPRS-C Total score at Baseline
N | 3 | 10 | 13
Mean (SD) | 24.7 (3.5) | 18.6 (9.3) | 20.0 (8.6)
Median (Min-Max) | 25.0 (21.0 - 28.0) | 17.5 (7.0 - 38.0) | 19.0 (7.0 - 38.0)
BPRS-C Total score at Week 8/End-of-Phase/LOCF
N | 2 | 10 | 12
Mean (SD) | 3.0 (0.0) | 15.4 (7.5) | 13.3 (8.4)
Median (Min-Max) | 3.0 (3.0 - 3.0) | 17.0 (4.0 - 24.0) | 13.5 (3.0 - 24.0)
Change in BPRS-C Total score from Baseline to Week 8/End-of-Phase/LOCF
N | 2 | 10 | 12
Mean (SD) | −21.5 (4.9) | −3.2 (13.8) | −6.3 (14.5)
Median (Min-Max) | −21.5 (−25.0 - −18.0) | −2.0 (−22.0 - 13.0) | −10.0 (−25.0 - 13.0)
BPRS-C Behavior Problems subscale at Baseline
N | 3 | 10 | 13
Mean (SD) | 9.0 (4.0) | 6.5 (3.7) | 7.1 (3.8)
Median (Min-Max) | 9.0 (5.0 - 13.0) | 8.0 (0.0 - 11.0) | 8.0 (0.0 - 13.0)
BPRS-C Behavior Problems subscale at Week 8/End-of-Phase/LOCF
N | 2 | 10 | 12
Mean (SD) | 0.5 (0.7) | 5.7 (4.6) | 4.8 (4.6)
Median (Min-Max) | 0.5 (0.0 - 1.0) | 4.0 (0.0 - 15.0) | 4.0 (0.0 - 15.0)
Change in BPRS-C Behavior Problems subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 2 | 10 | 12
Mean (SD) | −6.5 (2.1) | −0.8 (4.4) | −1.8 (4.6)
Median (Min-Max) | −6.5 (−8.0 - −5.0) | −0.5 (−7.0 - 6.0) | −2.5 (−8.0 - 6.0)
BPRS-C Depression subscale at Baseline
N | 3 | 10 | 13
Mean (SD) | 3.3 (3.1) | 2.7 (3.1) | 2.8 (3.0)
Median (Min-Max) | 4.0 (0.0 - 6.0) | 1.5 (0.0 - 8.0) | 3.0 (0.0 - 8.0)
BPRS-C Depression subscale at Week 8/End-of-Phase/LOCF
N | 2 | 10 | 12
Mean (SD) | 0.0 (0.0) | 1.1 (1.9) | 0.9 (1.8)
Median (Min-Max) | 0.0 (0.0 - 0.0) | 0.0 (0.0 - 5.0) | 0.0 (0.0 - 5.0)
Change in BPRS-C Depression subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 2 | 10 | 12
Mean (SD) | −5.0 (1.4) | −1.6 (2.8) | −2.2 (2.9)
Median (Min-Max) | −5.0 (−6.0 - −4.0) | 0.0 (−6.0 - 1.0) | 0.0 (−6.0 - 1.0)
BPRS-C Thinking Disturbance subscale at Baseline
N | 3 | 10 | 13
Mean (SD) | 0.0 (0.0) | 0.1 (0.3) | 0.1 (0.3)
Median (Min-Max) | 0.0 (0.0 - 0.0) | 0.0 (0.0 - 1.0) | 0.0 (0.0 - 1.0)
BPRS-C Thinking Disturbance subscale at Week 8/End-of-Phase/LOCF
N | 2 | 10 | 12
Mean (SD) | 0.0 (0.0) | 0.1 (0.3) | 0.1 (0.3)
Median (Min-Max) | 0.0 (0.0 - 0.0) | 0.0 (0.0 - 1.0) | 0.0 (0.0 - 1.0)
Change in BPRS-C Thinking Disturbance subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 2 | 10 | 12
Mean (SD) | 0.0 (0.0) | 0.0 (0.5) | 0.0 (0.4)
Median (Min-Max) | 0.0 (0.0 - 0.0) | 0.0 (−1.0 - 1.0) | 0.0 (−1.0 - 1.0)
BPRS-C Psychomotor excitation subscale at Baseline
N | 3 | 10 | 13
Mean (SD) | 8.0 (2.6) | 5.4 (4.5) | 6.0 (4.2)
Median (Min-Max) | 7.0 (6.0 - 11.0) | 4.5 (0.0 - 13.0) | 6.0 (0.0 - 13.0)
BPRS-C Psychomotor excitation subscale at Week 8/End-of-Phase/LOCF
N | 2 | 10 | 12
Mean (SD) | 1.5 (2.1) | 4.0 (2.7) | 3.6 (2.7)
Median (Min-Max) | 1.5 (0.0 - 3.0) | 4.5 (0.0 - 8.0) | 3.5 (0.0 - 8.0)
Change in BPRS-C Psychomotor excitation subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 2 | 10 | 12
Mean (SD) | −5.0 (2.8) | −1.4 (4.6) | −2.0 (4.5)
Median (Min-Max) | −5.0 (−7.0 - −3.0) | −0.5 (−9.0 - 5.0) | −1.5 (−9.0 - 5.0)
BPRS-C Withdrawal subscale at Baseline
N | 3 | 10 | 13
Mean (SD) | 3.0 (2.6) | 1.6 (1.8) | 1.9 (2.0)
Median (Min-Max) | 4.0 (0.0 - 5.0) | 1.0 (0.0 - 5.0) | 2.0 (0.0 - 5.0)
BPRS-C Withdrawal subscale at Week 8/End-of-Phase/LOCF
N | 2 | 10 | 12
Mean (SD) | 0.0 (0.0) | 1.1 (2.0) | 0.9 (1.8)
Median (Min-Max) | 0.0 (0.0 - 0.0) | 0.0 (0.0 - 6.0) | 0.0 (0.0 - 6.0)
Change in BPRS-C Withdrawal subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 2 | 10 | 12
Mean (SD) | −4.5 (0.7) | −0.5 (2.1) | −1.2 (2.5)
Median (Min-Max) | −4.5 (−5.0 - −4.0) | 0.0 (−3.0 - 3.0) | −1.0 (−5.0 - 3.0)
BPRS-C Anxiety subscale at Baseline
N | 3 | 10 | 13
Mean (SD) | 1.3 (1.5) | 2.3 (3.7) | 2.1 (3.3)
Median (Min-Max) | 1.0 (0.0 - 3.0) | 0.0 (0.0 - 10.0) | 0.0 (0.0 - 10.0)
BPRS-C Anxiety subscale at Week 8/End-of-Phase/LOCF
N | 2 | 10 | 12
Mean (SD) | 1.0 (1.4) | 3.4 (1.9) | 3.0 (2.0)
Median (Min-Max) | 1.0 (0.0 - 2.0) | 2.5 (2.0 - 7.0) | 2.0 (0.0 - 7.0)
Change in BPRS-C Anxiety subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 2 | 10 | 12
Mean (SD) | −0.5 (0.7) | 1.1 (3.9) | 0.8 (3.6)
Median (Min-Max) | −0.5 (−1.0 - 0.0) | 2.0 (−6.0 - 7.0) | 1.0 (−6.0 - 7.0)
BPRS-C Organicity subscale at Baseline
N | 3 | 10 | 13
Mean (SD) | 0.0 (0.0) | 0.0 (0.0) | 0.0 (0.0)
Median (Min-Max) | 0.0 (0.0 - 0.0) | 0.0 (0.0 - 0.0) | 0.0 (0.0 - 0.0)
BPRS-C Organicity subscale at Week 8/End-of-Phase/LOCF
N | 2 | 10 | 12
Mean (SD) | 0.0 (0.0) | 0.0 (0.0) | 0.0 (0.0)
Median (Min-Max) | 0.0 (0.0 - 0.0) | 0.0 (0.0 - 0.0) | 0.0 (0.0 - 0.0)
Change in BPRS-C Organicity subscale from Baseline to Week 8/End-of-Phase/LOCF
N | 2 | 10 | 12
Mean (SD) | 0.0 (0.0) | 0.0 (0.0) | 0.0 (0.0)
Median (Min-Max) | 0.0 (0.0 - 0.0) | 0.0 (0.0 - 0.0) | 0.0 (0.0 - 0.0)

Note: Baseline is defined as the last visit of Discontinuation Phase.

Change score is week 8/end of phase value minus baseline value.

Table 14.2.4.3.4 Tertiary Efficacy Endpoint: Pediatric Anxiety Rating Scale (PARS) by Discontinuation Phase Randomized Treatment Group Restabilization Phase - Efficacy Population

| Discontinuation Phase Randomized Treatment Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Total Score at Baseline
N | 3 | 10 | 13
Mean (SD) | 0.0 (0.0) | 4.0 (7.8) | 3.1 (7.0)
Median (Min-Max) | 0.0 (0.0 - 0.0) | 0.0 (0.0 - 21.0) | 0.0 (0.0 - 21.0)
Total Score at Week 28/End-of-Phase/LOCF
N | 2 | 10 | 12
Mean (SD) | 0.0 (0.0) | 3.3 (7.0) | 2.8 (6.5)
Median (Min-Max) | 0.0 (0.0 - 0.0) | 0.0 (0.0 - 18.0) | 0.0 (0.0 - 18.0)
Change in Total Score from Baseline to Week 28/End-of-Phase/LOCF
N | 2 | 10 | 12
Mean (SD) | 0.0 (0.0) | −0.7 (7.5) | −0.6 (6.8)
Median (Min-Max) | 0.0 (0.0 - 0.0) | 0.0 (−16.0 - 15.0) | 0.0 (−16.0 - 15.0)
Sub Score at Baseline
N | 3 | 10 | 13
Mean (SD) | 0.0 (0.0) | 3.1 (6.0) | 2.4 (5.4)
Median (Min-Max) | 0.0 (0.0 - 0.0) | 0.0 (0.0 - 17.0) | 0.0 (0.0 - 17.0)
Sub Score at Week 28/End-of-Phase/LOCF
N | 2 | 10 | 12
Mean (SD) | 0.0 (0.0) | 2.2 (4.7) | 1.8 (4.3)
Median (Min-Max) | 0.0 (0.0 - 0.0) | 0.0 (0.0 - 12.0) | 0.0 (0.0 - 12.0)
Change in Sub Score from Baseline to Week 28/End-of-Phase/LOCF
N | 2 | 10 | 12
Mean (SD) | 0.0 (0.0) | −0.9 (5.2) | −0.8 (4.7)
Median (Min-Max) | 0.0 (0.0 - 0.0) | 0.0 (−11.0 - 9.0) | 0.0 (−11.0 - 9.0)

Note: Baseline is defined as the last visit of Discontinuation Phase.

Change score is week 8/end of phase value minus baseline value.

Table 14.3.1.1.1 Summary of Adverse Events by Age Strata and Efficacy Phase Treatment Received Group Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Number of Events/Participants
Number of Adverse Events | 263 | 64 | 147 | 47 | 410 | 111
Participants with at least one AE | 31 (96.9%) | 16 (94.1%) | 19 (90.5%) | 10 (90.9%) | 50 (94.3%) | 26 (92.9%)
Number of SAEs | 2 | 2 | 3 | 0 | 5 | 2
Participants with at least one SAE | 1 (3.1%) | 2 (11.8%) | 3 (14.3%) | 0 | 4 (7.5%) | 2 (7.1%)
Severity (All AEs)
Mild | 201 | 55 | 106 | 42 | 307 | 97
Moderate | 55 | 7 | 35 | 5 | 90 | 12
Severe | 7 | 2 | 6 | 0 | 13 | 2
Highest Severity Per Participant
Mild | 13 (40.6%) | 7 (41.2%) | 6 (28.6%) | 6 (54.5%) | 19 (35.8%) | 13 (46.4%)
Moderate | 13 (40.6%) | 7 (41.2%) | 7 (33.3%) | 4 (36.4%) | 20 (37.7%) | 11 (39.3%)
Severe | 5 (15.6%) | 2 (11.8%) | 6 (28.6%) | 0 | 11 (20.8%) | 2 (7.1%)
Relationship (All AEs)
Unrelated | 82 | 28 | 31 | 16 | 113 | 44
Possibly related | 106 | 32 | 82 | 29 | 188 | 61
Probably related | 71 | 4 | 33 | 2 | 104 | 6
Definitely related | 4 | 0 | 1 | 0 | 5 | 0
Strongest Relationship Per Participant
Unrelated | 2 (6.3%) | 3 (17.6%) | 2 (9.5%) | 1 (9.1%) | 4 (7.5%) | 4 (14.3%)
Possibly related | 10 (31.3%) | 11 (64.7%) | 6 (28.6%) | 7 (63.6%) | 16 (30.2%) | 18 (64.3%)
Probably related | 15 (46.9%) | 2 (11.8%) | 10 (47.6%) | 2 (18.2%) | 25 (47.2%) | 4 (14.3%)
Definitely related | 4 (12.5%) | 0 | 1 (4.8%) | 0 | 5 (9.4%) | 0
Severity (All SAEs)
Moderate | 0 | 1 | 1 | 0 | 1 | 1
Severe | 2 | 1 | 2 | 0 | 4 | 1
Relationship (All SAEs)
Unrelated | 2 | 2 | 3 | 0 | 5 | 2

Table 14.3.1.1.2A Summary of Adverse Events by Age Strata Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Number of Events/Participants
Number of Adverse Events | 233 | 124 | 357
Participants with at least one AE | 25 (86.2%) | 13 (86.7%) | 38 (86.4%)
Number of SAEs | 0 | 2 | 2
Participants with at least one SAE | 0 | 2 (13.3%) | 2 (4.5%)
Severity (All AEs)
Mild | 178 | 96 | 274
Moderate | 52 | 25 | 77
Severe | 3 | 2 | 5
Life threatening | 0 | 1 | 1
Highest Severity Per Participant
Mild | 9 (31.0%) | 4 (26.7%) | 13 (29.5%)
Moderate | 15 (51.7%) | 6 (40.0%) | 21 (47.7%)
Severe | 1 (3.4%) | 2 (13.3%) | 3 (6.8%)
Life threatening | 0 | 1 (6.7%) | 1 (2.3%)
Relationship (All AEs)
Unrelated | 130 | 38 | 168
Possibly related | 52 | 59 | 111
Probably related | 43 | 27 | 70
Definitely related | 8 | 0 | 8
Strongest Relationship Per Participant
Unrelated | 5 (17.2%) | 1 (6.7%) | 6 (13.6%)
Possibly related | 5 (17.2%) | 3 (20.0%) | 8 (18.2%)
Probably related | 10 (34.5%) | 9 (60.0%) | 19 (43.2%)
Definitely related | 5 (17.2%) | 0 | 5 (11.4%)
Severity (All SAEs)
Severe | 0 | 1 | 1
Life threatening | 0 | 1 | 1
Relationship (All SAEs)
Unrelated | 0 | 2 | 2

Table 14.3.1.1.2B Summary of Adverse Events by Efficacy Phase Treatment Received Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Number of Events/Participants
Number of Adverse Events | 237 | 120 | 357
Participants with at least one AE | 26 (89.7%) | 12 (80.0%) | 38 (86.4%)
Number of SAEs | 2 | 0 | 2
Participants with at least one SAE | 2 (6.9%) | 0 | 2 (4.5%)
Severity (All AEs)
Mild | 176 | 98 | 274
Moderate | 55 | 22 | 77
Severe | 5 | 0 | 5
Life threatening | 1 | 0 | 1
Highest Severity Per Participant
Mild | 9 (31.0%) | 4 (26.7%) | 13 (29.5%)
Moderate | 13 (44.8%) | 8 (53.3%) | 21 (47.7%)
Severe | 3 (10.3%) | 0 | 3 (6.8%)
Life threatening | 1 (3.4%) | 0 | 1 (2.3%)
Relationship (All AEs)
Unrelated | 123 | 45 | 168
Possibly related | 65 | 46 | 111
Probably related | 44 | 26 | 70
Definitely related | 5 | 3 | 8
Strongest Relationship Per Participant
Unrelated | 4 (13.8%) | 2 (13.3%) | 6 (13.6%)
Possibly related | 7 (24.1%) | 1 (6.7%) | 8 (18.2%)
Probably related | 12 (41.4%) | 7 (46.7%) | 19 (43.2%)
Definitely related | 3 (10.3%) | 2 (13.3%) | 5 (11.4%)
Severity (All SAEs)
Severe | 1 | 0 | 1
Life threatening | 1 | 0 | 1
Relationship (All SAEs)
Unrelated | 2 | 0 | 2

Table 14.3.1.1.3 Summary of Adverse Events by Discontinuation Phase Treatment Received Group Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Number of Events/Participants
Number of Adverse Events | 102 | 25 | 127
Participants with at least one AE | 15 (88.2%) | 9 (64.3%) | 24 (77.4%)
Number of SAEs | 1 | 0 | 1
Participants with at least one SAE | 1 (5.9%) | 0 | 1 (3.2%)
Severity (All AEs)
Mild | 90 | 19 | 109
Moderate | 9 | 6 | 15
Severe | 3 | 0 | 3
Highest Severity Per Participant
Mild | 10 (58.8%) | 5 (35.7%) | 15 (48.4%)
Moderate | 3 (17.6%) | 4 (28.6%) | 7 (22.6%)
Severe | 2 (11.8%) | 0 | 2 (6.5%)
Relationship (All AEs)
Unrelated | 55 | 17 | 72
Possibly related | 44 | 8 | 52
Probably related | 3 | 0 | 3
Strongest Relationship Per Participant
Unrelated | 4 (23.5%) | 3 (21.4%) | 7 (22.6%)
Possibly related | 9 (52.9%) | 6 (42.9%) | 15 (48.4%)
Probably related | 2 (11.8%) | 0 | 2 (6.5%)
Severity (All SAEs)
Moderate | 1 | 0 | 1
Relationship (All SAEs)
Possibly related | 1 | 0 | 1

Table 14.3.1.1.4 Summary of Adverse Events by Discontinuation Phase Treatment Received Group Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Number of Events/Participants
Number of Adverse Events | 10 | 26 | 36
Participants with at least one AE | 3 (100.0%) | 7 (70.0%) | 10 (76.9%)
Severity (All AEs)
Mild | 6 | 23 | 29
Moderate | 4 | 3 | 7
Highest Severity Per Participant
Mild | 1 (33.3%) | 5 (50.0%) | 6 (46.2%)
Moderate | 2 (66.7%) | 2 (20.0%) | 4 (30.8%)
Relationship (All AEs)
Unrelated | 8 | 11 | 19
Possibly related | 2 | 15 | 17
Strongest Relationship Per Participant
Unrelated | 2 (66.7%) | 2 (20.0%) | 4 (30.8%)
Possibly related | 1 (33.3%) | 5 (50.0%) | 6 (46.2%)

Table 14.3.1.2.1 Adverse Events by MedDRA System Organ Class, Preferred Term, Age Strata and Efficacy Phase Treatment Received Group Efficacy Phase - Safety Population

System Organ Class (SOC)/Preferred Term (PT) | 7 - 11 yrs | | 12 - 17 yrs | | Total
System Organ Class (SOC)/Preferred Term (PT) | Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Blood and lymphatic system disorders | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Thrombocytopenia | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Cardiac disorders | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Palpitations | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Eye disorders | 5 (15.6%) | 1 (5.9%) | 1 (4.8%) | 1 (9.1%) | 6 (11.3%) | 2 (7.1%)
Conjunctivitis | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Eye irritation | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Eye pain | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Eye pruritus | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Vision blurred | 4 (12.5%) | 0 | 1 (4.8%) | 0 | 5 (9.4%) | 0
Gastrointestinal disorders | 28 (87.5%) | 13 (76.5%) | 15 (71.4%) | 6 (54.5%) | 43 (81.1%) | 19 (67.9%)
Abdominal discomfort | 1 (3.1%) | 1 (5.9%) | 3 (14.3%) | 1 (9.1%) | 4 (7.5%) | 2 (7.1%)
Abdominal distension | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Abdominal pain | 4 (12.5%) | 0 | 2 (9.5%) | 1 (9.1%) | 6 (11.3%) | 1 (3.6%)
Abdominal pain upper | 9 (28.1%) | 6 (35.3%) | 7 (33.3%) | 3 (27.3%) | 16 (30.2%) | 9 (32.1%)
Constipation | 3 (9.4%) | 2 (11.8%) | 1 (4.8%) | 0 | 4 (7.5%) | 2 (7.1%)
Diarrhoea | 10 (31.3%) | 3 (17.6%) | 5 (23.8%) | 1 (9.1%) | 15 (28.3%) | 4 (14.3%)
Dry mouth | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Dyspepsia | 6 (18.8%) | 2 (11.8%) | 1 (4.8%) | 1 (9.1%) | 7 (13.2%) | 3 (10.7%)
Frequent bowel movements | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Nausea | 12 (37.5%) | 3 (17.6%) | 11 (52.4%) | 2 (18.2%) | 23 (43.4%) | 5 (17.9%)
Salivary hypersecretion | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Toothache | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Vomiting | 15 (46.9%) | 3 (17.6%) | 9 (42.9%) | 0 | 24 (45.3%) | 3 (10.7%)
General disorders and administration site conditions | 13 (40.6%) | 2 (11.8%) | 10 (47.6%) | 5 (45.5%) | 23 (43.4%) | 7 (25.0%)
Asthenia | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Chest pain | 1 (3.1%) | 0 | 2 (9.5%) | 1 (9.1%) | 3 (5.7%) | 1 (3.6%)
Fatigue | 0 | 0 | 5 (23.8%) | 1 (9.1%) | 5 (9.4%) | 1 (3.6%)
Feeling hot | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Pyrexia | 2 (6.3%) | 2 (11.8%) | 1 (4.8%) | 0 | 3 (5.7%) | 2 (7.1%)
Thirst | 12 (37.5%) | 0 | 3 (14.3%) | 3 (27.3%) | 15 (28.3%) | 3 (10.7%)
Infections and infestations | 3 (9.4%) | 3 (17.6%) | 4 (19.0%) | 3 (27.3%) | 7 (13.2%) | 6 (21.4%)
Ear infection | 0 | 2 (11.8%) | 0 | 0 | 0 | 2 (7.1%)
Gastroenteritis | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Gastroenteritis viral | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Nasopharyngitis | 2 (6.3%) | 1 (5.9%) | 0 | 1 (9.1%) | 2 (3.8%) | 2 (7.1%)
Otitis externa | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Pharyngitis | 1 (3.1%) | 0 | 1 (4.8%) | 0 | 2 (3.8%) | 0
Upper respiratory tract infection | 0 | 0 | 2 (9.5%) | 1 (9.1%) | 2 (3.8%) | 1 (3.6%)
Injury, poisoning and procedural complications | 3 (9.4%) | 1 (5.9%) | 2 (9.5%) | 0 | 5 (9.4%) | 1 (3.6%)
Contusion | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Excoriation | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Joint injury | 0 | 1 (5.9%) | 1 (4.8%) | 0 | 1 (1.9%) | 1 (3.6%)
Tooth injury | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Upper limb fracture | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Investigations | 6 (18.8%) | 1 (5.9%) | 7 (33.3%) | 1 (9.1%) | 13 (24.5%) | 2 (7.1%)
Blood thyroid stimulating hormone increased | 4 (12.5%) | 0 | 5 (23.8%) | 0 | 9 (17.0%) | 0
Protein urine present | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Thyroid function test abnormal | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Thyroxine decreased | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Weight increased | 2 (6.3%) | 1 (5.9%) | 0 | 1 (9.1%) | 2 (3.8%) | 2 (7.1%)
Metabolism and nutrition disorders | 10 (31.3%) | 3 (17.6%) | 3 (14.3%) | 3 (27.3%) | 13 (24.5%) | 6 (21.4%)
Decreased appetite | 5 (15.6%) | 1 (5.9%) | 0 | 0 | 5 (9.4%) | 1 (3.6%)
Increased appetite | 9 (28.1%) | 2 (11.8%) | 1 (4.8%) | 3 (27.3%) | 10 (18.9%) | 5 (17.9%)
Polydipsia | 1 (3.1%) | 0 | 3 (14.3%) | 0 | 4 (7.5%) | 0
Musculoskeletal and connective tissue disorders | 4 (12.5%) | 3 (17.6%) | 2 (9.5%) | 0 | 6 (11.3%) | 3 (10.7%)
Arthralgia | 1 (3.1%) | 1 (5.9%) | 0 | 0 | 1 (1.9%) | 1 (3.6%)
Back pain | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Muscle rigidity | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Muscle spasms | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Muscular weakness | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Musculoskeletal chest pain | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Musculoskeletal stiffness | 0 | 1 (5.9%) | 1 (4.8%) | 0 | 1 (1.9%) | 1 (3.6%)
Neck pain | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Sensation of heaviness | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Nervous system disorders | 20 (62.5%) | 7 (41.2%) | 17 (81.0%) | 6 (54.5%) | 37 (69.8%) | 13 (46.4%)
Ataxia | 3 (9.4%) | 0 | 0 | 0 | 3 (5.7%) | 0
Cerebellar ataxia | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Cerebellar syndrome | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Coordination abnormal | 1 (3.1%) | 0 | 1 (4.8%) | 0 | 2 (3.8%) | 0
Dizziness | 7 (21.9%) | 0 | 5 (23.8%) | 2 (18.2%) | 12 (22.6%) | 2 (7.1%)
Dysarthria | 3 (9.4%) | 0 | 0 | 0 | 3 (5.7%) | 0
Dysgeusia | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Dyskinesia | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Glabellar reflex abnormal | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Headache | 11 (34.4%) | 5 (29.4%) | 8 (38.1%) | 4 (36.4%) | 19 (35.8%) | 9 (32.1%)
Hypersomnia | 0 | 0 | 1 (4.8%) | 2 (18.2%) | 1 (1.9%) | 2 (7.1%)
Hypotonia | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Memory impairment | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Migraine | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Nystagmus | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Sedation | 6 (18.8%) | 0 | 0 | 0 | 6 (11.3%) | 0
Somnolence | 4 (12.5%) | 1 (5.9%) | 2 (9.5%) | 1 (9.1%) | 6 (11.3%) | 2 (7.1%)
Speech disorder | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Tremor | 9 (28.1%) | 2 (11.8%) | 8 (38.1%) | 0 | 17 (32.1%) | 2 (7.1%)
Psychiatric disorders | 6 (18.8%) | 3 (17.6%) | 7 (33.3%) | 2 (18.2%) | 13 (24.5%) | 5 (17.9%)
Aggression | 2 (6.3%) | 1 (5.9%) | 0 | 0 | 2 (3.8%) | 1 (3.6%)
Agitation | 0 | 1 (5.9%) | 2 (9.5%) | 0 | 2 (3.8%) | 1 (3.6%)
Anger | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Bipolar disorder | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Confusional state | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Disorientation | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Dyssomnia | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Hallucination, auditory | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Hallucination, visual | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Initial insomnia | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Insomnia | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Mood altered | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Psychotic disorder | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Suicidal behaviour | 0 | 0 | 2 (9.5%) | 0 | 2 (3.8%) | 0
Suicidal ideation | 0 | 0 | 2 (9.5%) | 0 | 2 (3.8%) | 0
Tic | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Violence-related symptom | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Renal and urinary disorders | 14 (43.8%) | 2 (11.8%) | 6 (28.6%) | 3 (27.3%) | 20 (37.7%) | 5 (17.9%)
Enuresis | 5 (15.6%) | 1 (5.9%) | 0 | 1 (9.1%) | 5 (9.4%) | 2 (7.1%)
Micturition urgency | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Nocturia | 0 | 1 (5.9%) | 2 (9.5%) | 0 | 2 (3.8%) | 1 (3.6%)
Pollakiuria | 10 (31.3%) | 0 | 4 (19.0%) | 2 (18.2%) | 14 (26.4%) | 2 (7.1%)
Polyuria | 1 (3.1%) | 0 | 2 (9.5%) | 0 | 3 (5.7%) | 0
Urinary incontinence | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Respiratory, thoracic and mediastinal disorders | 6 (18.8%) | 2 (11.8%) | 2 (9.5%) | 0 | 8 (15.1%) | 2 (7.1%)
Cough | 1 (3.1%) | 1 (5.9%) | 1 (4.8%) | 0 | 2 (3.8%) | 1 (3.6%)
Epistaxis | 2 (6.3%) | 2 (11.8%) | 0 | 0 | 2 (3.8%) | 2 (7.1%)
Nasal congestion | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Oropharyngeal pain | 0 | 1 (5.9%) | 1 (4.8%) | 0 | 1 (1.9%) | 1 (3.6%)
Rhinorrhoea | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Skin and subcutaneous tissue disorders | 8 (25.0%) | 0 | 4 (19.0%) | 0 | 12 (22.6%) | 0
Acne | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Dry skin | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Eczema | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Heat rash | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Hyperhidrosis | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Pruritus | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Rash | 3 (9.4%) | 0 | 3 (14.3%) | 0 | 6 (11.3%) | 0
Swelling face | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Vascular disorders | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Pallor | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0

Note: The percentages are based on the total number of safety participants in each age/treatment group.

Participants are counted once at each SOC and PT level.

Table 14.3.1.2.2A Adverse Events by MedDRA System Organ Class, Preferred Term and Age Strata Long-Term Effectiveness Phase - Safety Population

System Organ Class (SOC)/Preferred Term (PT) | Age Strata | | Total; (N=44)
System Organ Class (SOC)/Preferred Term (PT) | 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Ear and labyrinth disorders | 1 (3.4%) | 0 | 1 (2.3%)
Ear pain | 1 (3.4%) | 0 | 1 (2.3%)
Endocrine disorders | 1 (3.4%) | 0 | 1 (2.3%)
Hypothyroidism | 1 (3.4%) | 0 | 1 (2.3%)
Eye disorders | 1 (3.4%) | 2 (13.3%) | 3 (6.8%)
Eye swelling | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Vision blurred | 0 | 2 (13.3%) | 2 (4.5%)
Gastrointestinal disorders | 20 (69.0%) | 10 (66.7%) | 30 (68.2%)
Abdominal discomfort | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Abdominal pain | 5 (17.2%) | 2 (13.3%) | 7 (15.9%)
Abdominal pain upper | 7 (24.1%) | 2 (13.3%) | 9 (20.5%)
Constipation | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Diarrhoea | 6 (20.7%) | 2 (13.3%) | 8 (18.2%)
Dry mouth | 0 | 3 (20.0%) | 3 (6.8%)
Dyspepsia | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Flatulence | 1 (3.4%) | 0 | 1 (2.3%)
Gingival pain | 1 (3.4%) | 0 | 1 (2.3%)
Nausea | 11 (37.9%) | 4 (26.7%) | 15 (34.1%)
Vomiting | 11 (37.9%) | 4 (26.7%) | 15 (34.1%)
General disorders and administration site conditions | 9 (31.0%) | 6 (40.0%) | 15 (34.1%)
Chest pain | 0 | 1 (6.7%) | 1 (2.3%)
Fatigue | 2 (6.9%) | 2 (13.3%) | 4 (9.1%)
Feeling hot | 1 (3.4%) | 0 | 1 (2.3%)
Gait disturbance | 1 (3.4%) | 0 | 1 (2.3%)
Irritability | 2 (6.9%) | 2 (13.3%) | 4 (9.1%)
Mucosal ulceration | 0 | 1 (6.7%) | 1 (2.3%)
Pyrexia | 3 (10.3%) | 0 | 3 (6.8%)
Thirst | 4 (13.8%) | 3 (20.0%) | 7 (15.9%)
Vessel puncture site pain | 1 (3.4%) | 0 | 1 (2.3%)
Immune system disorders | 1 (3.4%) | 0 | 1 (2.3%)
Hypersensitivity | 1 (3.4%) | 0 | 1 (2.3%)
Infections and infestations | 16 (55.2%) | 4 (26.7%) | 20 (45.5%)
Bronchitis | 1 (3.4%) | 0 | 1 (2.3%)
Ear infection | 3 (10.3%) | 0 | 3 (6.8%)
Gastroenteritis | 1 (3.4%) | 0 | 1 (2.3%)
Gastroenteritis viral | 3 (10.3%) | 0 | 3 (6.8%)
Hordeolum | 1 (3.4%) | 0 | 1 (2.3%)
Influenza | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Nasopharyngitis | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Otitis externa | 1 (3.4%) | 0 | 1 (2.3%)
Pharyngitis streptococcal | 1 (3.4%) | 0 | 1 (2.3%)
Sinusitis | 1 (3.4%) | 0 | 1 (2.3%)
Upper respiratory tract infection | 2 (6.9%) | 2 (13.3%) | 4 (9.1%)
Urinary tract infection | 1 (3.4%) | 0 | 1 (2.3%)
Vulvovaginal candidiasis | 1 (3.4%) | 0 | 1 (2.3%)
Injury, poisoning and procedural complications | 5 (17.2%) | 0 | 5 (11.4%)
Contusion | 1 (3.4%) | 0 | 1 (2.3%)
Excoriation | 1 (3.4%) | 0 | 1 (2.3%)
Foot fracture | 1 (3.4%) | 0 | 1 (2.3%)
Head injury | 1 (3.4%) | 0 | 1 (2.3%)
Limb injury | 1 (3.4%) | 0 | 1 (2.3%)
Muscle strain | 1 (3.4%) | 0 | 1 (2.3%)
Investigations | 3 (10.3%) | 3 (20.0%) | 6 (13.6%)
Activated partial thromboplastin time abnormal | 1 (3.4%) | 0 | 1 (2.3%)
Alanine aminotransferase increased | 1 (3.4%) | 0 | 1 (2.3%)
Blood creatine phosphokinase increased | 1 (3.4%) | 0 | 1 (2.3%)
Blood sodium decreased | 1 (3.4%) | 0 | 1 (2.3%)
Blood thyroid stimulating hormone abnormal | 1 (3.4%) | 0 | 1 (2.3%)
Blood thyroid stimulating hormone increased | 0 | 2 (13.3%) | 2 (4.5%)
Blood triglycerides abnormal | 1 (3.4%) | 0 | 1 (2.3%)
Blood triglycerides increased | 2 (6.9%) | 0 | 2 (4.5%)
Blood urea decreased | 0 | 1 (6.7%) | 1 (2.3%)
Blood uric acid increased | 0 | 1 (6.7%) | 1 (2.3%)
Gamma-glutamyltransferase increased | 1 (3.4%) | 0 | 1 (2.3%)
Thyroxine abnormal | 1 (3.4%) | 0 | 1 (2.3%)
Metabolism and nutrition disorders | 5 (17.2%) | 5 (33.3%) | 10 (22.7%)
Decreased appetite | 3 (10.3%) | 0 | 3 (6.8%)
Hyperinsulinaemia | 1 (3.4%) | 0 | 1 (2.3%)
Hypophagia | 1 (3.4%) | 0 | 1 (2.3%)
Increased appetite | 0 | 5 (33.3%) | 5 (11.4%)
Musculoskeletal and connective tissue disorders | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Muscular weakness | 1 (3.4%) | 0 | 1 (2.3%)
Musculoskeletal pain | 1 (3.4%) | 0 | 1 (2.3%)
Musculoskeletal stiffness | 0 | 1 (6.7%) | 1 (2.3%)
Myalgia | 1 (3.4%) | 0 | 1 (2.3%)
Neck pain | 1 (3.4%) | 0 | 1 (2.3%)
Nervous system disorders | 16 (55.2%) | 11 (73.3%) | 27 (61.4%)
Burning sensation | 0 | 1 (6.7%) | 1 (2.3%)
Disturbance in attention | 1 (3.4%) | 3 (20.0%) | 4 (9.1%)
Dizziness | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Dysarthria | 0 | 1 (6.7%) | 1 (2.3%)
Dyskinesia | 1 (3.4%) | 0 | 1 (2.3%)
Headache | 11 (37.9%) | 7 (46.7%) | 18 (40.9%)
Lethargy | 0 | 1 (6.7%) | 1 (2.3%)
Memory impairment | 0 | 1 (6.7%) | 1 (2.3%)
Sedation | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Somnolence | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Tremor | 6 (20.7%) | 2 (13.3%) | 8 (18.2%)
Psychiatric disorders | 4 (13.8%) | 7 (46.7%) | 11 (25.0%)
Agitation | 0 | 1 (6.7%) | 1 (2.3%)
Anxiety | 1 (3.4%) | 2 (13.3%) | 3 (6.8%)
Confusional state | 0 | 1 (6.7%) | 1 (2.3%)
Depression | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Initial insomnia | 2 (6.9%) | 2 (13.3%) | 4 (9.1%)
Insomnia | 1 (3.4%) | 3 (20.0%) | 4 (9.1%)
Restlessness | 0 | 1 (6.7%) | 1 (2.3%)
Self injurious behaviour | 0 | 1 (6.7%) | 1 (2.3%)
Somnambulism | 1 (3.4%) | 0 | 1 (2.3%)
Stress | 0 | 1 (6.7%) | 1 (2.3%)
Suicidal ideation | 1 (3.4%) | 0 | 1 (2.3%)
Suicide attempt | 0 | 1 (6.7%) | 1 (2.3%)
Tic | 1 (3.4%) | 0 | 1 (2.3%)
Renal and urinary disorders | 8 (27.6%) | 5 (33.3%) | 13 (29.5%)
Enuresis | 5 (17.2%) | 0 | 5 (11.4%)
Micturition disorder | 0 | 1 (6.7%) | 1 (2.3%)
Micturition urgency | 1 (3.4%) | 0 | 1 (2.3%)
Nocturia | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Pollakiuria | 4 (13.8%) | 3 (20.0%) | 7 (15.9%)
Polyuria | 1 (3.4%) | 0 | 1 (2.3%)
Respiratory, thoracic and mediastinal disorders | 8 (27.6%) | 2 (13.3%) | 10 (22.7%)
Asthma | 1 (3.4%) | 0 | 1 (2.3%)
Cough | 2 (6.9%) | 0 | 2 (4.5%)
Epistaxis | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Oropharyngeal pain | 1 (3.4%) | 0 | 1 (2.3%)
Respiratory disorder | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Upper respiratory tract congestion | 1 (3.4%) | 0 | 1 (2.3%)
Skin and subcutaneous tissue disorders | 10 (34.5%) | 5 (33.3%) | 15 (34.1%)
Acne | 0 | 2 (13.3%) | 2 (4.5%)
Alopecia | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Dermatitis allergic | 1 (3.4%) | 0 | 1 (2.3%)
Dermatitis contact | 1 (3.4%) | 0 | 1 (2.3%)
Pruritus | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Rash | 7 (24.1%) | 3 (20.0%) | 10 (22.7%)
Vascular disorders | 0 | 1 (6.7%) | 1 (2.3%)
Hot flush | 0 | 1 (6.7%) | 1 (2.3%)

Note: The percentages are based on the total number of safety participants in each age strata or total.

Participants are counted once at each SOC and PT level.

Table 14.3.1.2.2B Adverse Events by MedDRA System Organ Class, Preferred Term and Efficacy Phase Treatment Received Group Long-Term Effectiveness Phase - Safety Population

System Organ Class (SOC)/Preferred Term (PT) | Efficacy Phase Treatment Received Group | | Total; (N=44)
System Organ Class (SOC)/Preferred Term (PT) | Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Ear and labyrinth disorders | 1 (3.4%) | 0 | 1 (2.3%)
Ear pain | 1 (3.4%) | 0 | 1 (2.3%)
Endocrine disorders | 1 (3.4%) | 0 | 1 (2.3%)
Hypothyroidism | 1 (3.4%) | 0 | 1 (2.3%)
Eye disorders | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Eye swelling | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Vision blurred | 2 (6.9%) | 0 | 2 (4.5%)
Gastrointestinal disorders | 19 (65.5%) | 11 (73.3%) | 30 (68.2%)
Abdominal discomfort | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Abdominal pain | 6 (20.7%) | 1 (6.7%) | 7 (15.9%)
Abdominal pain upper | 5 (17.2%) | 4 (26.7%) | 9 (20.5%)
Constipation | 3 (10.3%) | 0 | 3 (6.8%)
Diarrhoea | 5 (17.2%) | 3 (20.0%) | 8 (18.2%)
Dry mouth | 3 (10.3%) | 0 | 3 (6.8%)
Dyspepsia | 3 (10.3%) | 0 | 3 (6.8%)
Flatulence | 1 (3.4%) | 0 | 1 (2.3%)
Gingival pain | 0 | 1 (6.7%) | 1 (2.3%)
Nausea | 9 (31.0%) | 6 (40.0%) | 15 (34.1%)
Vomiting | 8 (27.6%) | 7 (46.7%) | 15 (34.1%)
General disorders and administration site conditions | 9 (31.0%) | 6 (40.0%) | 15 (34.1%)
Chest pain | 1 (3.4%) | 0 | 1 (2.3%)
Fatigue | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Feeling hot | 1 (3.4%) | 0 | 1 (2.3%)
Gait disturbance | 1 (3.4%) | 0 | 1 (2.3%)
Irritability | 4 (13.8%) | 0 | 4 (9.1%)
Mucosal ulceration | 1 (3.4%) | 0 | 1 (2.3%)
Pyrexia | 1 (3.4%) | 2 (13.3%) | 3 (6.8%)
Thirst | 3 (10.3%) | 4 (26.7%) | 7 (15.9%)
Vessel puncture site pain | 0 | 1 (6.7%) | 1 (2.3%)
Immune system disorders | 1 (3.4%) | 0 | 1 (2.3%)
Hypersensitivity | 1 (3.4%) | 0 | 1 (2.3%)
Infections and infestations | 13 (44.8%) | 7 (46.7%) | 20 (45.5%)
Bronchitis | 1 (3.4%) | 0 | 1 (2.3%)
Ear infection | 1 (3.4%) | 2 (13.3%) | 3 (6.8%)
Gastroenteritis | 0 | 1 (6.7%) | 1 (2.3%)
Gastroenteritis viral | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Hordeolum | 1 (3.4%) | 0 | 1 (2.3%)
Influenza | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Nasopharyngitis | 4 (13.8%) | 0 | 4 (9.1%)
Otitis externa | 1 (3.4%) | 0 | 1 (2.3%)
Pharyngitis streptococcal | 1 (3.4%) | 0 | 1 (2.3%)
Sinusitis | 0 | 1 (6.7%) | 1 (2.3%)
Upper respiratory tract infection | 2 (6.9%) | 2 (13.3%) | 4 (9.1%)
Urinary tract infection | 1 (3.4%) | 0 | 1 (2.3%)
Vulvovaginal candidiasis | 1 (3.4%) | 0 | 1 (2.3%)
Injury, poisoning and procedural complications | 3 (10.3%) | 2 (13.3%) | 5 (11.4%)
Contusion | 1 (3.4%) | 0 | 1 (2.3%)
Excoriation | 1 (3.4%) | 0 | 1 (2.3%)
Foot fracture | 1 (3.4%) | 0 | 1 (2.3%)
Head injury | 1 (3.4%) | 0 | 1 (2.3%)
Limb injury | 0 | 1 (6.7%) | 1 (2.3%)
Muscle strain | 0 | 1 (6.7%) | 1 (2.3%)
Investigations | 5 (17.2%) | 1 (6.7%) | 6 (13.6%)
Activated partial thromboplastin time abnormal | 0 | 1 (6.7%) | 1 (2.3%)
Alanine aminotransferase increased | 1 (3.4%) | 0 | 1 (2.3%)
Blood creatine phosphokinase increased | 1 (3.4%) | 0 | 1 (2.3%)
Blood sodium decreased | 1 (3.4%) | 0 | 1 (2.3%)
Blood thyroid stimulating hormone abnormal | 0 | 1 (6.7%) | 1 (2.3%)
Blood thyroid stimulating hormone increased | 2 (6.9%) | 0 | 2 (4.5%)
Blood triglycerides abnormal | 0 | 1 (6.7%) | 1 (2.3%)
Blood triglycerides increased | 2 (6.9%) | 0 | 2 (4.5%)
Blood urea decreased | 1 (3.4%) | 0 | 1 (2.3%)
Blood uric acid increased | 1 (3.4%) | 0 | 1 (2.3%)
Gamma-glutamyltransferase increased | 1 (3.4%) | 0 | 1 (2.3%)
Thyroxine abnormal | 0 | 1 (6.7%) | 1 (2.3%)
Metabolism and nutrition disorders | 8 (27.6%) | 2 (13.3%) | 10 (22.7%)
Decreased appetite | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Hyperinsulinaemia | 1 (3.4%) | 0 | 1 (2.3%)
Hypophagia | 1 (3.4%) | 0 | 1 (2.3%)
Increased appetite | 4 (13.8%) | 1 (6.7%) | 5 (11.4%)
Musculoskeletal and connective tissue disorders | 2 (6.9%) | 2 (13.3%) | 4 (9.1%)
Muscular weakness | 0 | 1 (6.7%) | 1 (2.3%)
Musculoskeletal pain | 1 (3.4%) | 0 | 1 (2.3%)
Musculoskeletal stiffness | 0 | 1 (6.7%) | 1 (2.3%)
Myalgia | 0 | 1 (6.7%) | 1 (2.3%)
Neck pain | 1 (3.4%) | 0 | 1 (2.3%)
Nervous system disorders | 17 (58.6%) | 10 (66.7%) | 27 (61.4%)
Burning sensation | 1 (3.4%) | 0 | 1 (2.3%)
Disturbance in attention | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Dizziness | 3 (10.3%) | 0 | 3 (6.8%)
Dysarthria | 1 (3.4%) | 0 | 1 (2.3%)
Dyskinesia | 0 | 1 (6.7%) | 1 (2.3%)
Headache | 11 (37.9%) | 7 (46.7%) | 18 (40.9%)
Lethargy | 1 (3.4%) | 0 | 1 (2.3%)
Memory impairment | 1 (3.4%) | 0 | 1 (2.3%)
Sedation | 2 (6.9%) | 0 | 2 (4.5%)
Somnolence | 2 (6.9%) | 2 (13.3%) | 4 (9.1%)
Tremor | 6 (20.7%) | 2 (13.3%) | 8 (18.2%)
Psychiatric disorders | 9 (31.0%) | 2 (13.3%) | 11 (25.0%)
Agitation | 0 | 1 (6.7%) | 1 (2.3%)
Anxiety | 3 (10.3%) | 0 | 3 (6.8%)
Confusional state | 1 (3.4%) | 0 | 1 (2.3%)
Depression | 3 (10.3%) | 0 | 3 (6.8%)
Initial insomnia | 4 (13.8%) | 0 | 4 (9.1%)
Insomnia | 4 (13.8%) | 0 | 4 (9.1%)
Restlessness | 1 (3.4%) | 0 | 1 (2.3%)
Self injurious behaviour | 1 (3.4%) | 0 | 1 (2.3%)
Somnambulism | 1 (3.4%) | 0 | 1 (2.3%)
Stress | 1 (3.4%) | 0 | 1 (2.3%)
Suicidal ideation | 0 | 1 (6.7%) | 1 (2.3%)
Suicide attempt | 1 (3.4%) | 0 | 1 (2.3%)
Tic | 1 (3.4%) | 0 | 1 (2.3%)
Renal and urinary disorders | 9 (31.0%) | 4 (26.7%) | 13 (29.5%)
Enuresis | 3 (10.3%) | 2 (13.3%) | 5 (11.4%)
Micturition disorder | 1 (3.4%) | 0 | 1 (2.3%)
Micturition urgency | 1 (3.4%) | 0 | 1 (2.3%)
Nocturia | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Pollakiuria | 5 (17.2%) | 2 (13.3%) | 7 (15.9%)
Polyuria | 0 | 1 (6.7%) | 1 (2.3%)
Respiratory, thoracic and mediastinal disorders | 5 (17.2%) | 5 (33.3%) | 10 (22.7%)
Asthma | 1 (3.4%) | 0 | 1 (2.3%)
Cough | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Epistaxis | 1 (3.4%) | 2 (13.3%) | 3 (6.8%)
Oropharyngeal pain | 0 | 1 (6.7%) | 1 (2.3%)
Respiratory disorder | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Upper respiratory tract congestion | 1 (3.4%) | 0 | 1 (2.3%)
Skin and subcutaneous tissue disorders | 11 (37.9%) | 4 (26.7%) | 15 (34.1%)
Acne | 2 (6.9%) | 0 | 2 (4.5%)
Alopecia | 3 (10.3%) | 0 | 3 (6.8%)
Dermatitis allergic | 0 | 1 (6.7%) | 1 (2.3%)
Dermatitis contact | 1 (3.4%) | 0 | 1 (2.3%)
Pruritus | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Rash | 7 (24.1%) | 3 (20.0%) | 10 (22.7%)
Vascular disorders | 0 | 1 (6.7%) | 1 (2.3%)
Hot flush | 0 | 1 (6.7%) | 1 (2.3%)

Note: The percentages are based on the total number of safety participants in each treatment group or total.

Participants are counted once at each SOC and PT level.

Table 14.3.1.2.3 Adverse Events by MedDRA System Organ Class, Preferred Term and Discontinuation Phase Treatment Received Group Discontinuation Phase - Safety Population

System Organ Class (SOC)/Preferred Term (PT) | Discontinuation Phase Treatment Received Group | | Total; (N=31)
System Organ Class (SOC)/Preferred Term (PT) | Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Endocrine disorders | 1 (5.9%) | 0 | 1 (3.2%)
Hypothyroidism | 1 (5.9%) | 0 | 1 (3.2%)
Eye disorders | 1 (5.9%) | 0 | 1 (3.2%)
Vision blurred | 1 (5.9%) | 0 | 1 (3.2%)
Gastrointestinal disorders | 9 (52.9%) | 4 (28.6%) | 13 (41.9%)
Abdominal discomfort | 2 (11.8%) | 0 | 2 (6.5%)
Abdominal pain | 1 (5.9%) | 0 | 1 (3.2%)
Abdominal pain lower | 0 | 1 (7.1%) | 1 (3.2%)
Abdominal pain upper | 5 (29.4%) | 1 (7.1%) | 6 (19.4%)
Diarrhoea | 2 (11.8%) | 0 | 2 (6.5%)
Dyspepsia | 0 | 1 (7.1%) | 1 (3.2%)
Nausea | 0 | 1 (7.1%) | 1 (3.2%)
Salivary hypersecretion | 1 (5.9%) | 0 | 1 (3.2%)
Vomiting | 4 (23.5%) | 0 | 4 (12.9%)
General disorders and administration site conditions | 2 (11.8%) | 0 | 2 (6.5%)
Feeling hot | 1 (5.9%) | 0 | 1 (3.2%)
Irritability | 1 (5.9%) | 0 | 1 (3.2%)
Immune system disorders | 1 (5.9%) | 0 | 1 (3.2%)
Allergy to arthropod bite | 1 (5.9%) | 0 | 1 (3.2%)
Infections and infestations | 5 (29.4%) | 2 (14.3%) | 7 (22.6%)
Ear infection | 2 (11.8%) | 0 | 2 (6.5%)
Gastroenteritis viral | 1 (5.9%) | 0 | 1 (3.2%)
Nasopharyngitis | 2 (11.8%) | 1 (7.1%) | 3 (9.7%)
Upper respiratory tract infection | 3 (17.6%) | 0 | 3 (9.7%)
Viral infection | 1 (5.9%) | 1 (7.1%) | 2 (6.5%)
Injury, poisoning and procedural complications | 4 (23.5%) | 1 (7.1%) | 5 (16.1%)
Arthropod bite | 1 (5.9%) | 0 | 1 (3.2%)
Arthropod sting | 2 (11.8%) | 0 | 2 (6.5%)
Excoriation | 0 | 1 (7.1%) | 1 (3.2%)
Ligament sprain | 1 (5.9%) | 0 | 1 (3.2%)
Investigations | 2 (11.8%) | 0 | 2 (6.5%)
Lymphocyte count decreased | 1 (5.9%) | 0 | 1 (3.2%)
Protein urine present | 2 (11.8%) | 0 | 2 (6.5%)
Urine ketone body present | 1 (5.9%) | 0 | 1 (3.2%)
Metabolism and nutrition disorders | 2 (11.8%) | 3 (21.4%) | 5 (16.1%)
Decreased appetite | 2 (11.8%) | 2 (14.3%) | 4 (12.9%)
Increased appetite | 0 | 1 (7.1%) | 1 (3.2%)
Musculoskeletal and connective tissue disorders | 5 (29.4%) | 1 (7.1%) | 6 (19.4%)
Arthralgia | 1 (5.9%) | 1 (7.1%) | 2 (6.5%)
Back pain | 1 (5.9%) | 0 | 1 (3.2%)
Muscle twitching | 1 (5.9%) | 0 | 1 (3.2%)
Musculoskeletal pain | 1 (5.9%) | 0 | 1 (3.2%)
Pain in extremity | 1 (5.9%) | 0 | 1 (3.2%)
Nervous system disorders | 8 (47.1%) | 4 (28.6%) | 12 (38.7%)
Disturbance in attention | 1 (5.9%) | 0 | 1 (3.2%)
Dizziness | 2 (11.8%) | 0 | 2 (6.5%)
Headache | 6 (35.3%) | 4 (28.6%) | 10 (32.3%)
Sedation | 1 (5.9%) | 0 | 1 (3.2%)
Sinus headache | 1 (5.9%) | 0 | 1 (3.2%)
Somnolence | 0 | 1 (7.1%) | 1 (3.2%)
Tremor | 1 (5.9%) | 0 | 1 (3.2%)
Psychiatric disorders | 5 (29.4%) | 3 (21.4%) | 8 (25.8%)
Aggression | 1 (5.9%) | 0 | 1 (3.2%)
Depression | 1 (5.9%) | 0 | 1 (3.2%)
Initial insomnia | 3 (17.6%) | 2 (14.3%) | 5 (16.1%)
Insomnia | 1 (5.9%) | 0 | 1 (3.2%)
Panic attack | 0 | 1 (7.1%) | 1 (3.2%)
Somnambulism | 1 (5.9%) | 0 | 1 (3.2%)
Renal and urinary disorders | 4 (23.5%) | 0 | 4 (12.9%)
Enuresis | 4 (23.5%) | 0 | 4 (12.9%)
Proteinuria | 1 (5.9%) | 0 | 1 (3.2%)
Respiratory, thoracic and mediastinal disorders | 3 (17.6%) | 1 (7.1%) | 4 (12.9%)
Cough | 1 (5.9%) | 0 | 1 (3.2%)
Epistaxis | 1 (5.9%) | 0 | 1 (3.2%)
Nasal congestion | 1 (5.9%) | 0 | 1 (3.2%)
Oropharyngeal pain | 1 (5.9%) | 1 (7.1%) | 2 (6.5%)
Skin and subcutaneous tissue disorders | 1 (5.9%) | 1 (7.1%) | 2 (6.5%)
Alopecia | 0 | 1 (7.1%) | 1 (3.2%)
Rash | 1 (5.9%) | 0 | 1 (3.2%)
Vascular disorders | 1 (5.9%) | 0 | 1 (3.2%)
Hot flush | 1 (5.9%) | 0 | 1 (3.2%)

Note: The percentages are based on the total number of safety participants in each treatment group or total.

Participants are counted once at each SOC and PT level.

Table 14.3.1.2.4 Adverse Events by MedDRA System Organ Class, Preferred Term and Discontinuation Phase Treatment Received Group Restabilization Phase - Safety Population

System Organ Class (SOC)/Preferred Term (PT) | Discontinuation Phase Treatment Received Group | | Total; (N=13)
System Organ Class (SOC)/Preferred Term (PT) | Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Gastrointestinal disorders | 2 (66.7%) | 5 (50.0%) | 7 (53.8%)
Abdominal pain lower | 0 | 1 (10.0%) | 1 (7.7%)
Abdominal pain upper | 1 (33.3%) | 2 (20.0%) | 3 (23.1%)
Diarrhoea | 1 (33.3%) | 0 | 1 (7.7%)
Dysphagia | 0 | 1 (10.0%) | 1 (7.7%)
Gastrooesophageal reflux disease | 0 | 2 (20.0%) | 2 (15.4%)
Nausea | 0 | 1 (10.0%) | 1 (7.7%)
Salivary hypersecretion | 0 | 1 (10.0%) | 1 (7.7%)
Vomiting | 1 (33.3%) | 1 (10.0%) | 2 (15.4%)
General disorders and administration site conditions | 0 | 1 (10.0%) | 1 (7.7%)
Fatigue | 0 | 1 (10.0%) | 1 (7.7%)
Infections and infestations | 1 (33.3%) | 2 (20.0%) | 3 (23.1%)
Nasopharyngitis | 1 (33.3%) | 1 (10.0%) | 2 (15.4%)
Viral infection | 0 | 1 (10.0%) | 1 (7.7%)
Injury, poisoning and procedural complications | 1 (33.3%) | 1 (10.0%) | 2 (15.4%)
Contusion | 1 (33.3%) | 0 | 1 (7.7%)
Post-traumatic pain | 0 | 1 (10.0%) | 1 (7.7%)
Investigations | 0 | 1 (10.0%) | 1 (7.7%)
Blood thyroid stimulating hormone increased | 0 | 1 (10.0%) | 1 (7.7%)
Blood urea nitrogen/creatinine ratio | 0 | 1 (10.0%) | 1 (7.7%)
Blood uric acid | 0 | 1 (10.0%) | 1 (7.7%)
Thyroglobulin | 0 | 1 (10.0%) | 1 (7.7%)
Nervous system disorders | 1 (33.3%) | 5 (50.0%) | 6 (46.2%)
Headache | 1 (33.3%) | 3 (30.0%) | 4 (30.8%)
Somnolence | 0 | 1 (10.0%) | 1 (7.7%)
Tremor | 0 | 2 (20.0%) | 2 (15.4%)
Renal and urinary disorders | 1 (33.3%) | 0 | 1 (7.7%)
Enuresis | 1 (33.3%) | 0 | 1 (7.7%)

Note: The percentages are based on the total number of safety participants in each treatment group or total.

Participants are counted once at each SOC and PT level.

Table 14.3.1.3.1 Adverse Events by MedDRA System Organ Class, Preferred Term, Intensity, Age Strata and Efficacy Phase Treatment Received Group Efficacy Phase - Safety Population

System Organ Class (SOC)/Preferred Term (PT) | Severity | 7 - 11 yrs | | 12 - 17 yrs | | Total
System Organ Class (SOC)/Preferred Term (PT) | Severity | Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Blood and lymphatic system disorders | Moderate | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Thrombocytopenia | Moderate | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Cardiac disorders | Mild | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Palpitations | Mild | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Eye disorders | Mild | 5 (15.6%) | 1 (5.9%) | 1 (4.8%) | 1 (9.1%) | 6 (11.3%) | 2 (7.1%)
Conjunctivitis | Mild | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Eye irritation | Mild | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Eye pain | Mild | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Eye pruritus | Mild | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Vision blurred | Mild | 4 (12.5%) | 0 | 1 (4.8%) | 0 | 5 (9.4%) | 0
Gastrointestinal disorders | Mild | 19 (59.4%) | 8 (47.1%) | 8 (38.1%) | 5 (45.5%) | 27 (50.9%) | 13 (46.4%)
Gastrointestinal disorders | Moderate | 7 (21.9%) | 5 (29.4%) | 6 (28.6%) | 1 (9.1%) | 13 (24.5%) | 6 (21.4%)
Gastrointestinal disorders | Severe | 2 (6.3%) | 0 | 1 (4.8%) | 0 | 3 (5.7%) | 0
Abdominal discomfort | Mild | 1 (3.1%) | 0 | 2 (9.5%) | 1 (9.1%) | 3 (5.7%) | 1 (3.6%)
Abdominal discomfort | Moderate | 0 | 1 (5.9%) | 1 (4.8%) | 0 | 1 (1.9%) | 1 (3.6%)
Abdominal distension | Mild | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Abdominal pain | Mild | 3 (9.4%) | 0 | 1 (4.8%) | 1 (9.1%) | 4 (7.5%) | 1 (3.6%)
Abdominal pain | Moderate | 1 (3.1%) | 0 | 1 (4.8%) | 0 | 2 (3.8%) | 0
Abdominal pain upper | Mild | 9 (28.1%) | 4 (23.5%) | 5 (23.8%) | 3 (27.3%) | 14 (26.4%) | 7 (25.0%)
Abdominal pain upper | Moderate | 0 | 2 (11.8%) | 1 (4.8%) | 0 | 1 (1.9%) | 2 (7.1%)
Abdominal pain upper | Severe | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Constipation | Mild | 3 (9.4%) | 1 (5.9%) | 1 (4.8%) | 0 | 4 (7.5%) | 1 (3.6%)
Constipation | Moderate | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Diarrhoea | Mild | 6 (18.8%) | 3 (17.6%) | 2 (9.5%) | 1 (9.1%) | 8 (15.1%) | 4 (14.3%)
Diarrhoea | Moderate | 3 (9.4%) | 0 | 3 (14.3%) | 0 | 6 (11.3%) | 0
Diarrhoea | Severe | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Dry mouth | Mild | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Dyspepsia | Mild | 6 (18.8%) | 2 (11.8%) | 1 (4.8%) | 1 (9.1%) | 7 (13.2%) | 3 (10.7%)
Frequent bowel movements | Mild | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Nausea | Mild | 5 (15.6%) | 3 (17.6%) | 4 (19.0%) | 1 (9.1%) | 9 (17.0%) | 4 (14.3%)
Nausea | Moderate | 6 (18.8%) | 0 | 7 (33.3%) | 1 (9.1%) | 13 (24.5%) | 1 (3.6%)
Nausea | Severe | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Salivary hypersecretion | Mild | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Toothache | Mild | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Vomiting | Mild | 9 (28.1%) | 2 (11.8%) | 5 (23.8%) | 0 | 14 (26.4%) | 2 (7.1%)
Vomiting | Moderate | 5 (15.6%) | 1 (5.9%) | 4 (19.0%) | 0 | 9 (17.0%) | 1 (3.6%)
Vomiting | Severe | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
General disorders and administration site conditions | Mild | 8 (25.0%) | 2 (11.8%) | 7 (33.3%) | 5 (45.5%) | 15 (28.3%) | 7 (25.0%)
General disorders and administration site conditions | Moderate | 5 (15.6%) | 0 | 2 (9.5%) | 0 | 7 (13.2%) | 0
General disorders and administration site conditions | Severe | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Asthenia | Mild | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Chest pain | Mild | 1 (3.1%) | 0 | 1 (4.8%) | 1 (9.1%) | 2 (3.8%) | 1 (3.6%)
Chest pain | Severe | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Fatigue | Mild | 0 | 0 | 4 (19.0%) | 1 (9.1%) | 4 (7.5%) | 1 (3.6%)
Fatigue | Moderate | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Feeling hot | Mild | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Pyrexia | Mild | 1 (3.1%) | 2 (11.8%) | 0 | 0 | 1 (1.9%) | 2 (7.1%)
Pyrexia | Moderate | 1 (3.1%) | 0 | 1 (4.8%) | 0 | 2 (3.8%) | 0
Thirst | Mild | 8 (25.0%) | 0 | 3 (14.3%) | 3 (27.3%) | 11 (20.8%) | 3 (10.7%)
Thirst | Moderate | 4 (12.5%) | 0 | 0 | 0 | 4 (7.5%) | 0
Infections and infestations | Mild | 2 (6.3%) | 2 (11.8%) | 1 (4.8%) | 2 (18.2%) | 3 (5.7%) | 4 (14.3%)
Infections and infestations | Moderate | 1 (3.1%) | 1 (5.9%) | 3 (14.3%) | 1 (9.1%) | 4 (7.5%) | 2 (7.1%)
Ear infection | Mild | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Ear infection | Moderate | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Gastroenteritis | Moderate | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Gastroenteritis viral | Moderate | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Nasopharyngitis | Mild | 2 (6.3%) | 1 (5.9%) | 0 | 1 (9.1%) | 2 (3.8%) | 2 (7.1%)
Otitis externa | Mild | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Pharyngitis | Moderate | 1 (3.1%) | 0 | 1 (4.8%) | 0 | 2 (3.8%) | 0
Upper respiratory tract infection | Mild | 0 | 0 | 1 (4.8%) | 1 (9.1%) | 1 (1.9%) | 1 (3.6%)
Upper respiratory tract infection | Moderate | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Injury, poisoning and procedural complications | Mild | 1 (3.1%) | 1 (5.9%) | 1 (4.8%) | 0 | 2 (3.8%) | 1 (3.6%)
Injury, poisoning and procedural complications | Moderate | 2 (6.3%) | 0 | 1 (4.8%) | 0 | 3 (5.7%) | 0
Contusion | Moderate | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Excoriation | Mild | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Joint injury | Mild | 0 | 1 (5.9%) | 1 (4.8%) | 0 | 1 (1.9%) | 1 (3.6%)
Tooth injury | Moderate | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Upper limb fracture | Moderate | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Investigations | Mild | 5 (15.6%) | 1 (5.9%) | 7 (33.3%) | 1 (9.1%) | 12 (22.6%) | 2 (7.1%)
Investigations | Moderate | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Blood thyroid stimulating hormone increased | Mild | 3 (9.4%) | 0 | 5 (23.8%) | 0 | 8 (15.1%) | 0
Blood thyroid stimulating hormone increased | Moderate | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Protein urine present | Mild | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Thyroid function test abnormal | Mild | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Thyroxine decreased | Mild | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Weight increased | Mild | 2 (6.3%) | 1 (5.9%) | 0 | 1 (9.1%) | 2 (3.8%) | 2 (7.1%)
Metabolism and nutrition disorders | Mild | 8 (25.0%) | 3 (17.6%) | 2 (9.5%) | 3 (27.3%) | 10 (18.9%) | 6 (21.4%)
Metabolism and nutrition disorders | Moderate | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Metabolism and nutrition disorders | Severe | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Decreased appetite | Mild | 4 (12.5%) | 1 (5.9%) | 0 | 0 | 4 (7.5%) | 1 (3.6%)
Decreased appetite | Moderate | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Increased appetite | Mild | 8 (25.0%) | 2 (11.8%) | 1 (4.8%) | 3 (27.3%) | 9 (17.0%) | 5 (17.9%)
Increased appetite | Moderate | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Polydipsia | Mild | 1 (3.1%) | 0 | 2 (9.5%) | 0 | 3 (5.7%) | 0
Polydipsia | Severe | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Musculoskeletal and connective tissue disorders | Mild | 3 (9.4%) | 3 (17.6%) | 2 (9.5%) | 0 | 5 (9.4%) | 3 (10.7%)
Musculoskeletal and connective tissue disorders | Moderate | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Arthralgia | Mild | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Arthralgia | Moderate | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Back pain | Mild | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Muscle rigidity | Mild | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Muscle spasms | Mild | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Muscular weakness | Mild | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Musculoskeletal chest pain | Mild | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Musculoskeletal stiffness | Mild | 0 | 1 (5.9%) | 1 (4.8%) | 0 | 1 (1.9%) | 1 (3.6%)
Neck pain | Mild | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Sensation of heaviness | Mild | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Nervous system disorders | Mild | 10 (31.3%) | 7 (41.2%) | 14 (66.7%) | 5 (45.5%) | 24 (45.3%) | 12 (42.9%)
Nervous system disorders | Moderate | 9 (28.1%) | 0 | 3 (14.3%) | 1 (9.1%) | 12 (22.6%) | 1 (3.6%)
Nervous system disorders | Severe | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Ataxia | Mild | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Ataxia | Moderate | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Cerebellar ataxia | Mild | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Cerebellar syndrome | Mild | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Coordination abnormal | Mild | 1 (3.1%) | 0 | 1 (4.8%) | 0 | 2 (3.8%) | 0
Dizziness | Mild | 4 (12.5%) | 0 | 5 (23.8%) | 1 (9.1%) | 9 (17.0%) | 1 (3.6%)
Dizziness | Moderate | 3 (9.4%) | 0 | 0 | 1 (9.1%) | 3 (5.7%) | 1 (3.6%)
Dysarthria | Moderate | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Dysarthria | Severe | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Dysgeusia | Mild | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Dyskinesia | Mild | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Glabellar reflex abnormal | Mild | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Headache | Mild | 7 (21.9%) | 5 (29.4%) | 6 (28.6%) | 4 (36.4%) | 13 (24.5%) | 9 (32.1%)
Headache | Moderate | 4 (12.5%) | 0 | 2 (9.5%) | 0 | 6 (11.3%) | 0
Hypersomnia | Mild | 0 | 0 | 1 (4.8%) | 2 (18.2%) | 1 (1.9%) | 2 (7.1%)
Hypotonia | Mild | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Memory impairment | Mild | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Migraine | Mild | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Migraine | Moderate | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Nystagmus | Mild | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Sedation | Mild | 4 (12.5%) | 0 | 0 | 0 | 4 (7.5%) | 0
Sedation | Moderate | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Somnolence | Mild | 4 (12.5%) | 1 (5.9%) | 1 (4.8%) | 1 (9.1%) | 5 (9.4%) | 2 (7.1%)
Somnolence | Moderate | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Speech disorder | Mild | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Tremor | Mild | 6 (18.8%) | 2 (11.8%) | 8 (38.1%) | 0 | 14 (26.4%) | 2 (7.1%)
Tremor | Moderate | 3 (9.4%) | 0 | 0 | 0 | 3 (5.7%) | 0
Psychiatric disorders | Mild | 3 (9.4%) | 0 | 2 (9.5%) | 1 (9.1%) | 5 (9.4%) | 1 (3.6%)
Psychiatric disorders | Moderate | 1 (3.1%) | 1 (5.9%) | 2 (9.5%) | 1 (9.1%) | 3 (5.7%) | 2 (7.1%)
Psychiatric disorders | Severe | 2 (6.3%) | 2 (11.8%) | 3 (14.3%) | 0 | 5 (9.4%) | 2 (7.1%)
Aggression | Moderate | 1 (3.1%) | 1 (5.9%) | 0 | 0 | 1 (1.9%) | 1 (3.6%)
Aggression | Severe | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Agitation | Mild | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Agitation | Moderate | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Agitation | Severe | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Anger | Moderate | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Bipolar disorder | Severe | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Confusional state | Mild | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Confusional state | Moderate | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Disorientation | Mild | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Dyssomnia | Mild | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Hallucination, auditory | Severe | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Hallucination, visual | Moderate | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Initial insomnia | Mild | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Insomnia | Mild | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Mood altered | Severe | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Psychotic disorder | Severe | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Suicidal behaviour | Moderate | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Suicidal behaviour | Severe | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Suicidal ideation | Moderate | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Suicidal ideation | Severe | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Tic | Mild | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Violence-related symptom | Mild | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Renal and urinary disorders | Mild | 11 (34.4%) | 2 (11.8%) | 4 (19.0%) | 3 (27.3%) | 15 (28.3%) | 5 (17.9%)
Renal and urinary disorders | Moderate | 3 (9.4%) | 0 | 2 (9.5%) | 0 | 5 (9.4%) | 0
Enuresis | Mild | 5 (15.6%) | 1 (5.9%) | 0 | 1 (9.1%) | 5 (9.4%) | 2 (7.1%)
Micturition urgency | Moderate | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Nocturia | Mild | 0 | 1 (5.9%) | 1 (4.8%) | 0 | 1 (1.9%) | 1 (3.6%)
Nocturia | Moderate | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Pollakiuria | Mild | 7 (21.9%) | 0 | 2 (9.5%) | 2 (18.2%) | 9 (17.0%) | 2 (7.1%)
Pollakiuria | Moderate | 3 (9.4%) | 0 | 2 (9.5%) | 0 | 5 (9.4%) | 0
Polyuria | Mild | 1 (3.1%) | 0 | 2 (9.5%) | 0 | 3 (5.7%) | 0
Urinary incontinence | Mild | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Respiratory, thoracic and mediastinal disorders | Mild | 6 (18.8%) | 2 (11.8%) | 2 (9.5%) | 0 | 8 (15.1%) | 2 (7.1%)
Cough | Mild | 1 (3.1%) | 1 (5.9%) | 1 (4.8%) | 0 | 2 (3.8%) | 1 (3.6%)
Epistaxis | Mild | 2 (6.3%) | 2 (11.8%) | 0 | 0 | 2 (3.8%) | 2 (7.1%)
Nasal congestion | Mild | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Oropharyngeal pain | Mild | 0 | 1 (5.9%) | 1 (4.8%) | 0 | 1 (1.9%) | 1 (3.6%)
Rhinorrhoea | Mild | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Skin and subcutaneous tissue disorders | Mild | 6 (18.8%) | 0 | 4 (19.0%) | 0 | 10 (18.9%) | 0
Skin and subcutaneous tissue disorders | Moderate | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Acne | Mild | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Dry skin | Mild | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Eczema | Mild | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Eczema | Moderate | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Heat rash | Mild | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Hyperhidrosis | Mild | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Hyperhidrosis | Moderate | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Pruritus | Mild | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Rash | Mild | 3 (9.4%) | 0 | 3 (14.3%) | 0 | 6 (11.3%) | 0
Swelling face | Mild | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Vascular disorders | Mild | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Pallor | Mild | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0

Note: The percentages are based on the total number of safety participants in each age strata/treatment group.

Participants are only counted once at each SOC and PT level, using the most severe intensity.

Table 14.3.1.3.2A Adverse Events by MedDRA System Organ Class, Preferred Term, Intensity and Age Strata Long-Term Effectiveness Phase - Safety Population

System Organ Class (SOC)/Preferred Term (PT) | Severity | Age Strata | | Total; (N=44)
System Organ Class (SOC)/Preferred Term (PT) | Severity | 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Ear and labyrinth disorders | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Ear pain | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Endocrine disorders | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Hypothyroidism | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Eye disorders | Mild | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Eye disorders | Moderate | 0 | 1 (6.7%) | 1 (2.3%)
Eye swelling | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Eye swelling | Moderate | 0 | 1 (6.7%) | 1 (2.3%)
Vision blurred | Mild | 0 | 2 (13.3%) | 2 (4.5%)
Gastrointestinal disorders | Mild | 12 (41.4%) | 4 (26.7%) | 16 (36.4%)
Gastrointestinal disorders | Moderate | 7 (24.1%) | 6 (40.0%) | 13 (29.5%)
Gastrointestinal disorders | Severe | 1 (3.4%) | 0 | 1 (2.3%)
Abdominal discomfort | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Abdominal discomfort | Moderate | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Abdominal pain | Mild | 2 (6.9%) | 2 (13.3%) | 4 (9.1%)
Abdominal pain | Moderate | 2 (6.9%) | 0 | 2 (4.5%)
Abdominal pain | Severe | 1 (3.4%) | 0 | 1 (2.3%)
Abdominal pain upper | Mild | 7 (24.1%) | 1 (6.7%) | 8 (18.2%)
Abdominal pain upper | Moderate | 0 | 1 (6.7%) | 1 (2.3%)
Constipation | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Constipation | Moderate | 0 | 1 (6.7%) | 1 (2.3%)
Constipation | Severe | 1 (3.4%) | 0 | 1 (2.3%)
Diarrhoea | Mild | 4 (13.8%) | 1 (6.7%) | 5 (11.4%)
Diarrhoea | Moderate | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Dry mouth | Mild | 0 | 3 (20.0%) | 3 (6.8%)
Dyspepsia | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Dyspepsia | Moderate | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Flatulence | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Gingival pain | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Nausea | Mild | 8 (27.6%) | 2 (13.3%) | 10 (22.7%)
Nausea | Moderate | 3 (10.3%) | 2 (13.3%) | 5 (11.4%)
Vomiting | Mild | 8 (27.6%) | 2 (13.3%) | 10 (22.7%)
Vomiting | Moderate | 3 (10.3%) | 2 (13.3%) | 5 (11.4%)
General disorders and administration site conditions | Mild | 6 (20.7%) | 5 (33.3%) | 11 (25.0%)
General disorders and administration site conditions | Moderate | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Chest pain | Moderate | 0 | 1 (6.7%) | 1 (2.3%)
Fatigue | Mild | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Fatigue | Moderate | 0 | 1 (6.7%) | 1 (2.3%)
Feeling hot | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Gait disturbance | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Irritability | Mild | 1 (3.4%) | 2 (13.3%) | 3 (6.8%)
Irritability | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Mucosal ulceration | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Pyrexia | Mild | 2 (6.9%) | 0 | 2 (4.5%)
Pyrexia | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Thirst | Mild | 3 (10.3%) | 3 (20.0%) | 6 (13.6%)
Thirst | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Vessel puncture site pain | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Immune system disorders | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Hypersensitivity | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Infections and infestations | Mild | 10 (34.5%) | 3 (20.0%) | 13 (29.5%)
Infections and infestations | Moderate | 6 (20.7%) | 1 (6.7%) | 7 (15.9%)
Bronchitis | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Ear infection | Mild | 2 (6.9%) | 0 | 2 (4.5%)
Ear infection | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Gastroenteritis | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Gastroenteritis viral | Mild | 3 (10.3%) | 0 | 3 (6.8%)
Hordeolum | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Influenza | Mild | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Nasopharyngitis | Mild | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Otitis externa | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Pharyngitis streptococcal | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Sinusitis | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Upper respiratory tract infection | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Upper respiratory tract infection | Moderate | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Urinary tract infection | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Vulvovaginal candidiasis | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Injury, poisoning and procedural complications | Mild | 4 (13.8%) | 0 | 4 (9.1%)
Injury, poisoning and procedural complications | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Contusion | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Excoriation | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Foot fracture | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Head injury | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Limb injury | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Muscle strain | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Investigations | Mild | 1 (3.4%) | 3 (20.0%) | 4 (9.1%)
Investigations | Moderate | 2 (6.9%) | 0 | 2 (4.5%)
Activated partial thromboplastin time abnormal | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Alanine aminotransferase increased | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Blood creatine phosphokinase increased | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Blood sodium decreased | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Blood thyroid stimulating hormone abnormal | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Blood thyroid stimulating hormone increased | Mild | 0 | 2 (13.3%) | 2 (4.5%)
Blood triglycerides abnormal | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Blood triglycerides increased | Moderate | 2 (6.9%) | 0 | 2 (4.5%)
Blood urea decreased | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Blood uric acid increased | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Gamma-glutamyltransferase increased | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Thyroxine abnormal | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Metabolism and nutrition disorders | Mild | 3 (10.3%) | 4 (26.7%) | 7 (15.9%)
Metabolism and nutrition disorders | Moderate | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Decreased appetite | Mild | 2 (6.9%) | 0 | 2 (4.5%)
Decreased appetite | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Hyperinsulinaemia | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Hypophagia | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Increased appetite | Mild | 0 | 4 (26.7%) | 4 (9.1%)
Increased appetite | Moderate | 0 | 1 (6.7%) | 1 (2.3%)
Musculoskeletal and connective tissue disorders | Mild | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Musculoskeletal and connective tissue disorders | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Muscular weakness | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Musculoskeletal pain | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Musculoskeletal stiffness | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Myalgia | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Neck pain | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Nervous system disorders | Mild | 10 (34.5%) | 8 (53.3%) | 18 (40.9%)
Nervous system disorders | Moderate | 5 (17.2%) | 3 (20.0%) | 8 (18.2%)
Nervous system disorders | Severe | 1 (3.4%) | 0 | 1 (2.3%)
Burning sensation | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Disturbance in attention | Mild | 1 (3.4%) | 3 (20.0%) | 4 (9.1%)
Dizziness | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Dizziness | Moderate | 0 | 1 (6.7%) | 1 (2.3%)
Dizziness | Severe | 1 (3.4%) | 0 | 1 (2.3%)
Dysarthria | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Dyskinesia | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Headache | Mild | 10 (34.5%) | 6 (40.0%) | 16 (36.4%)
Headache | Moderate | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Lethargy | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Memory impairment | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Sedation | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Sedation | Moderate | 0 | 1 (6.7%) | 1 (2.3%)
Somnolence | Mild | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Somnolence | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Tremor | Mild | 4 (13.8%) | 2 (13.3%) | 6 (13.6%)
Tremor | Moderate | 2 (6.9%) | 0 | 2 (4.5%)
Psychiatric disorders | Mild | 2 (6.9%) | 2 (13.3%) | 4 (9.1%)
Psychiatric disorders | Moderate | 2 (6.9%) | 3 (20.0%) | 5 (11.4%)
Psychiatric disorders | Severe | 0 | 1 (6.7%) | 1 (2.3%)
Psychiatric disorders | Life threatening | 0 | 1 (6.7%) | 1 (2.3%)
Agitation | Moderate | 0 | 1 (6.7%) | 1 (2.3%)
Anxiety | Mild | 0 | 2 (13.3%) | 2 (4.5%)
Anxiety | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Confusional state | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Depression | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Depression | Moderate | 2 (6.9%) | 0 | 2 (4.5%)
Initial insomnia | Mild | 1 (3.4%) | 2 (13.3%) | 3 (6.8%)
Initial insomnia | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Insomnia | Mild | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Insomnia | Moderate | 0 | 2 (13.3%) | 2 (4.5%)
Restlessness | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Self injurious behaviour | Severe | 0 | 1 (6.7%) | 1 (2.3%)
Somnambulism | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Stress | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Suicidal ideation | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Suicide attempt | Life threatening | 0 | 1 (6.7%) | 1 (2.3%)
Tic | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Renal and urinary disorders | Mild | 5 (17.2%) | 4 (26.7%) | 9 (20.5%)
Renal and urinary disorders | Moderate | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Enuresis | Mild | 3 (10.3%) | 0 | 3 (6.8%)
Enuresis | Moderate | 2 (6.9%) | 0 | 2 (4.5%)
Micturition disorder | Moderate | 0 | 1 (6.7%) | 1 (2.3%)
Micturition urgency | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Nocturia | Mild | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Pollakiuria | Mild | 2 (6.9%) | 3 (20.0%) | 5 (11.4%)
Pollakiuria | Moderate | 2 (6.9%) | 0 | 2 (4.5%)
Polyuria | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Respiratory, thoracic and mediastinal disorders | Mild | 7 (24.1%) | 2 (13.3%) | 9 (20.5%)
Respiratory, thoracic and mediastinal disorders | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Asthma | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Cough | Mild | 2 (6.9%) | 0 | 2 (4.5%)
Epistaxis | Mild | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Oropharyngeal pain | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Respiratory disorder | Mild | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Upper respiratory tract congestion | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Skin and subcutaneous tissue disorders | Mild | 8 (27.6%) | 4 (26.7%) | 12 (27.3%)
Skin and subcutaneous tissue disorders | Moderate | 2 (6.9%) | 0 | 2 (4.5%)
Skin and subcutaneous tissue disorders | Severe | 0 | 1 (6.7%) | 1 (2.3%)
Acne | Mild | 0 | 2 (13.3%) | 2 (4.5%)
Alopecia | Mild | 2 (6.9%) | 0 | 2 (4.5%)
Alopecia | Severe | 0 | 1 (6.7%) | 1 (2.3%)
Dermatitis allergic | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Dermatitis contact | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Pruritus | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Pruritus | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Rash | Mild | 6 (20.7%) | 3 (20.0%) | 9 (20.5%)
Rash | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Vascular disorders | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Hot flush | Mild | 0 | 1 (6.7%) | 1 (2.3%)

Note: The percentages are based on the total number of safety participants in each age strata or total.

Participants are counted once at each SOC and PT level, using the most severe intensity.

Table 14.3.1.3.2B Adverse Events by MedDRA System Organ Class, Preferred Term, Intensity and Efficacy Phase Treatment Received Group Long-Term Effectiveness Phase - Safety Population

System Organ Class (SOC)/Preferred Term (PT) | Severity | Efficacy Phase Treatment Received Group | | Total; (N=44)
System Organ Class (SOC)/Preferred Term (PT) | Severity | Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Ear and labyrinth disorders | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Ear pain | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Endocrine disorders | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Hypothyroidism | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Eye disorders | Mild | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Eye disorders | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Eye swelling | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Eye swelling | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Vision blurred | Mild | 2 (6.9%) | 0 | 2 (4.5%)
Gastrointestinal disorders | Mild | 10 (34.5%) | 6 (40.0%) | 16 (36.4%)
Gastrointestinal disorders | Moderate | 8 (27.6%) | 5 (33.3%) | 13 (29.5%)
Gastrointestinal disorders | Severe | 1 (3.4%) | 0 | 1 (2.3%)
Abdominal discomfort | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Abdominal discomfort | Moderate | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Abdominal pain | Mild | 4 (13.8%) | 0 | 4 (9.1%)
Abdominal pain | Moderate | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Abdominal pain | Severe | 1 (3.4%) | 0 | 1 (2.3%)
Abdominal pain upper | Mild | 5 (17.2%) | 3 (20.0%) | 8 (18.2%)
Abdominal pain upper | Moderate | 0 | 1 (6.7%) | 1 (2.3%)
Constipation | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Constipation | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Constipation | Severe | 1 (3.4%) | 0 | 1 (2.3%)
Diarrhoea | Mild | 3 (10.3%) | 2 (13.3%) | 5 (11.4%)
Diarrhoea | Moderate | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Dry mouth | Mild | 3 (10.3%) | 0 | 3 (6.8%)
Dyspepsia | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Dyspepsia | Moderate | 2 (6.9%) | 0 | 2 (4.5%)
Flatulence | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Gingival pain | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Nausea | Mild | 5 (17.2%) | 5 (33.3%) | 10 (22.7%)
Nausea | Moderate | 4 (13.8%) | 1 (6.7%) | 5 (11.4%)
Vomiting | Mild | 6 (20.7%) | 4 (26.7%) | 10 (22.7%)
Vomiting | Moderate | 2 (6.9%) | 3 (20.0%) | 5 (11.4%)
General disorders and administration site conditions | Mild | 6 (20.7%) | 5 (33.3%) | 11 (25.0%)
General disorders and administration site conditions | Moderate | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Chest pain | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Fatigue | Mild | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Fatigue | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Feeling hot | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Gait disturbance | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Irritability | Mild | 3 (10.3%) | 0 | 3 (6.8%)
Irritability | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Mucosal ulceration | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Pyrexia | Mild | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Pyrexia | Moderate | 0 | 1 (6.7%) | 1 (2.3%)
Thirst | Mild | 2 (6.9%) | 4 (26.7%) | 6 (13.6%)
Thirst | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Vessel puncture site pain | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Immune system disorders | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Hypersensitivity | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Infections and infestations | Mild | 7 (24.1%) | 6 (40.0%) | 13 (29.5%)
Infections and infestations | Moderate | 6 (20.7%) | 1 (6.7%) | 7 (15.9%)
Bronchitis | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Ear infection | Mild | 0 | 2 (13.3%) | 2 (4.5%)
Ear infection | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Gastroenteritis | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Gastroenteritis viral | Mild | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Hordeolum | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Influenza | Mild | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Nasopharyngitis | Mild | 4 (13.8%) | 0 | 4 (9.1%)
Otitis externa | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Pharyngitis streptococcal | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Sinusitis | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Upper respiratory tract infection | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Upper respiratory tract infection | Moderate | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Urinary tract infection | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Vulvovaginal candidiasis | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Injury, poisoning and procedural complications | Mild | 2 (6.9%) | 2 (13.3%) | 4 (9.1%)
Injury, poisoning and procedural complications | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Contusion | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Excoriation | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Foot fracture | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Head injury | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Limb injury | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Muscle strain | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Investigations | Mild | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Investigations | Moderate | 2 (6.9%) | 0 | 2 (4.5%)
Activated partial thromboplastin time abnormal | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Alanine aminotransferase increased | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Blood creatine phosphokinase increased | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Blood sodium decreased | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Blood thyroid stimulating hormone abnormal | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Blood thyroid stimulating hormone increased | Mild | 2 (6.9%) | 0 | 2 (4.5%)
Blood triglycerides abnormal | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Blood triglycerides increased | Moderate | 2 (6.9%) | 0 | 2 (4.5%)
Blood urea decreased | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Blood uric acid increased | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Gamma-glutamyltransferase increased | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Thyroxine abnormal | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Metabolism and nutrition disorders | Mild | 6 (20.7%) | 1 (6.7%) | 7 (15.9%)
Metabolism and nutrition disorders | Moderate | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Decreased appetite | Mild | 2 (6.9%) | 0 | 2 (4.5%)
Decreased appetite | Moderate | 0 | 1 (6.7%) | 1 (2.3%)
Hyperinsulinaemia | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Hypophagia | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Increased appetite | Mild | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Increased appetite | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Musculoskeletal and connective tissue disorders | Mild | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Musculoskeletal and connective tissue disorders | Moderate | 0 | 1 (6.7%) | 1 (2.3%)
Muscular weakness | Moderate | 0 | 1 (6.7%) | 1 (2.3%)
Musculoskeletal pain | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Musculoskeletal stiffness | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Myalgia | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Neck pain | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Nervous system disorders | Mild | 11 (37.9%) | 7 (46.7%) | 18 (40.9%)
Nervous system disorders | Moderate | 5 (17.2%) | 3 (20.0%) | 8 (18.2%)
Nervous system disorders | Severe | 1 (3.4%) | 0 | 1 (2.3%)
Burning sensation | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Disturbance in attention | Mild | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Dizziness | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Dizziness | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Dizziness | Severe | 1 (3.4%) | 0 | 1 (2.3%)
Dysarthria | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Dyskinesia | Moderate | 0 | 1 (6.7%) | 1 (2.3%)
Headache | Mild | 10 (34.5%) | 6 (40.0%) | 16 (36.4%)
Headache | Moderate | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Lethargy | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Memory impairment | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Sedation | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Sedation | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Somnolence | Mild | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Somnolence | Moderate | 0 | 1 (6.7%) | 1 (2.3%)
Tremor | Mild | 4 (13.8%) | 2 (13.3%) | 6 (13.6%)
Tremor | Moderate | 2 (6.9%) | 0 | 2 (4.5%)
Psychiatric disorders | Mild | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Psychiatric disorders | Moderate | 4 (13.8%) | 1 (6.7%) | 5 (11.4%)
Psychiatric disorders | Severe | 1 (3.4%) | 0 | 1 (2.3%)
Psychiatric disorders | Life threatening | 1 (3.4%) | 0 | 1 (2.3%)
Agitation | Moderate | 0 | 1 (6.7%) | 1 (2.3%)
Anxiety | Mild | 2 (6.9%) | 0 | 2 (4.5%)
Anxiety | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Confusional state | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Depression | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Depression | Moderate | 2 (6.9%) | 0 | 2 (4.5%)
Initial insomnia | Mild | 3 (10.3%) | 0 | 3 (6.8%)
Initial insomnia | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Insomnia | Mild | 2 (6.9%) | 0 | 2 (4.5%)
Insomnia | Moderate | 2 (6.9%) | 0 | 2 (4.5%)
Restlessness | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Self injurious behaviour | Severe | 1 (3.4%) | 0 | 1 (2.3%)
Somnambulism | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Stress | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Suicidal ideation | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Suicide attempt | Life threatening | 1 (3.4%) | 0 | 1 (2.3%)
Tic | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Renal and urinary disorders | Mild | 6 (20.7%) | 3 (20.0%) | 9 (20.5%)
Renal and urinary disorders | Moderate | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Enuresis | Mild | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Enuresis | Moderate | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Micturition disorder | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Micturition urgency | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Nocturia | Mild | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Pollakiuria | Mild | 3 (10.3%) | 2 (13.3%) | 5 (11.4%)
Pollakiuria | Moderate | 2 (6.9%) | 0 | 2 (4.5%)
Polyuria | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Respiratory, thoracic and mediastinal disorders | Mild | 4 (13.8%) | 5 (33.3%) | 9 (20.5%)
Respiratory, thoracic and mediastinal disorders | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Asthma | Moderate | 1 (3.4%) | 0 | 1 (2.3%)
Cough | Mild | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Epistaxis | Mild | 1 (3.4%) | 2 (13.3%) | 3 (6.8%)
Oropharyngeal pain | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Respiratory disorder | Mild | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Upper respiratory tract congestion | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Skin and subcutaneous tissue disorders | Mild | 10 (34.5%) | 2 (13.3%) | 12 (27.3%)
Skin and subcutaneous tissue disorders | Moderate | 0 | 2 (13.3%) | 2 (4.5%)
Skin and subcutaneous tissue disorders | Severe | 1 (3.4%) | 0 | 1 (2.3%)
Acne | Mild | 2 (6.9%) | 0 | 2 (4.5%)
Alopecia | Mild | 2 (6.9%) | 0 | 2 (4.5%)
Alopecia | Severe | 1 (3.4%) | 0 | 1 (2.3%)
Dermatitis allergic | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Dermatitis contact | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Pruritus | Mild | 1 (3.4%) | 0 | 1 (2.3%)
Pruritus | Moderate | 0 | 1 (6.7%) | 1 (2.3%)
Rash | Mild | 7 (24.1%) | 2 (13.3%) | 9 (20.5%)
Rash | Moderate | 0 | 1 (6.7%) | 1 (2.3%)
Vascular disorders | Mild | 0 | 1 (6.7%) | 1 (2.3%)
Hot flush | Mild | 0 | 1 (6.7%) | 1 (2.3%)

Note: The percentages are based on the total number of safety participants in each treatment group or total.

Participants are counted once at each SOC and PT level, using the most severe intensity.

Table 14.3.1.3.3 Adverse Events by MedDRA System Organ Class, Preferred Term, Intensity and Discontinuation Phase Treatment Received Group Discontinuation Phase - Safety Population

System Organ Class (SOC)/Preferred Term (PT) | Severity | Discontinuation Phase Treatment Received Group | | Total; (N=31)
System Organ Class (SOC)/Preferred Term (PT) | Severity | Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Endocrine disorders | Mild | 1 (5.9%) | 0 | 1 (3.2%)
Hypothyroidism | Mild | 1 (5.9%) | 0 | 1 (3.2%)
Eye disorders | Mild | 1 (5.9%) | 0 | 1 (3.2%)
Vision blurred | Mild | 1 (5.9%) | 0 | 1 (3.2%)
Gastrointestinal disorders | Mild | 7 (41.2%) | 4 (28.6%) | 11 (35.5%)
Gastrointestinal disorders | Moderate | 2 (11.8%) | 0 | 2 (6.5%)
Abdominal discomfort | Mild | 2 (11.8%) | 0 | 2 (6.5%)
Abdominal pain | Moderate | 1 (5.9%) | 0 | 1 (3.2%)
Abdominal pain lower | Mild | 0 | 1 (7.1%) | 1 (3.2%)
Abdominal pain upper | Mild | 5 (29.4%) | 1 (7.1%) | 6 (19.4%)
Diarrhoea | Mild | 2 (11.8%) | 0 | 2 (6.5%)
Dyspepsia | Mild | 0 | 1 (7.1%) | 1 (3.2%)
Nausea | Mild | 0 | 1 (7.1%) | 1 (3.2%)
Salivary hypersecretion | Moderate | 1 (5.9%) | 0 | 1 (3.2%)
Vomiting | Mild | 4 (23.5%) | 0 | 4 (12.9%)
General disorders and administration site conditions | Mild | 1 (5.9%) | 0 | 1 (3.2%)
General disorders and administration site conditions | Severe | 1 (5.9%) | 0 | 1 (3.2%)
Feeling hot | Mild | 1 (5.9%) | 0 | 1 (3.2%)
Irritability | Severe | 1 (5.9%) | 0 | 1 (3.2%)
Immune system disorders | Mild | 1 (5.9%) | 0 | 1 (3.2%)
Allergy to arthropod bite | Mild | 1 (5.9%) | 0 | 1 (3.2%)
Infections and infestations | Mild | 3 (17.6%) | 2 (14.3%) | 5 (16.1%)
Infections and infestations | Moderate | 2 (11.8%) | 0 | 2 (6.5%)
Ear infection | Moderate | 2 (11.8%) | 0 | 2 (6.5%)
Gastroenteritis viral | Mild | 1 (5.9%) | 0 | 1 (3.2%)
Nasopharyngitis | Mild | 2 (11.8%) | 1 (7.1%) | 3 (9.7%)
Upper respiratory tract infection | Mild | 2 (11.8%) | 0 | 2 (6.5%)
Upper respiratory tract infection | Moderate | 1 (5.9%) | 0 | 1 (3.2%)
Viral infection | Mild | 1 (5.9%) | 1 (7.1%) | 2 (6.5%)
Injury, poisoning and procedural complications | Mild | 4 (23.5%) | 0 | 4 (12.9%)
Injury, poisoning and procedural complications | Moderate | 0 | 1 (7.1%) | 1 (3.2%)
Arthropod bite | Mild | 1 (5.9%) | 0 | 1 (3.2%)
Arthropod sting | Mild | 2 (11.8%) | 0 | 2 (6.5%)
Excoriation | Moderate | 0 | 1 (7.1%) | 1 (3.2%)
Ligament sprain | Mild | 1 (5.9%) | 0 | 1 (3.2%)
Investigations | Mild | 2 (11.8%) | 0 | 2 (6.5%)
Lymphocyte count decreased | Mild | 1 (5.9%) | 0 | 1 (3.2%)
Protein urine present | Mild | 2 (11.8%) | 0 | 2 (6.5%)
Urine ketone body present | Mild | 1 (5.9%) | 0 | 1 (3.2%)
Metabolism and nutrition disorders | Mild | 2 (11.8%) | 3 (21.4%) | 5 (16.1%)
Decreased appetite | Mild | 2 (11.8%) | 2 (14.3%) | 4 (12.9%)
Increased appetite | Mild | 0 | 1 (7.1%) | 1 (3.2%)
Musculoskeletal and connective tissue disorders | Mild | 5 (29.4%) | 1 (7.1%) | 6 (19.4%)
Arthralgia | Mild | 1 (5.9%) | 1 (7.1%) | 2 (6.5%)
Back pain | Mild | 1 (5.9%) | 0 | 1 (3.2%)
Muscle twitching | Mild | 1 (5.9%) | 0 | 1 (3.2%)
Musculoskeletal pain | Mild | 1 (5.9%) | 0 | 1 (3.2%)
Pain in extremity | Mild | 1 (5.9%) | 0 | 1 (3.2%)
Nervous system disorders | Mild | 7 (41.2%) | 2 (14.3%) | 9 (29.0%)
Nervous system disorders | Moderate | 0 | 2 (14.3%) | 2 (6.5%)
Nervous system disorders | Severe | 1 (5.9%) | 0 | 1 (3.2%)
Disturbance in attention | Severe | 1 (5.9%) | 0 | 1 (3.2%)
Dizziness | Mild | 2 (11.8%) | 0 | 2 (6.5%)
Headache | Mild | 6 (35.3%) | 2 (14.3%) | 8 (25.8%)
Headache | Moderate | 0 | 2 (14.3%) | 2 (6.5%)
Sedation | Mild | 1 (5.9%) | 0 | 1 (3.2%)
Sinus headache | Mild | 1 (5.9%) | 0 | 1 (3.2%)
Somnolence | Mild | 0 | 1 (7.1%) | 1 (3.2%)
Tremor | Mild | 1 (5.9%) | 0 | 1 (3.2%)
Psychiatric disorders | Mild | 3 (17.6%) | 1 (7.1%) | 4 (12.9%)
Psychiatric disorders | Moderate | 2 (11.8%) | 2 (14.3%) | 4 (12.9%)
Aggression | Moderate | 1 (5.9%) | 0 | 1 (3.2%)
Depression | Moderate | 1 (5.9%) | 0 | 1 (3.2%)
Initial insomnia | Mild | 3 (17.6%) | 1 (7.1%) | 4 (12.9%)
Initial insomnia | Moderate | 0 | 1 (7.1%) | 1 (3.2%)
Insomnia | Mild | 1 (5.9%) | 0 | 1 (3.2%)
Panic attack | Moderate | 0 | 1 (7.1%) | 1 (3.2%)
Somnambulism | Mild | 1 (5.9%) | 0 | 1 (3.2%)
Renal and urinary disorders | Mild | 3 (17.6%) | 0 | 3 (9.7%)
Renal and urinary disorders | Severe | 1 (5.9%) | 0 | 1 (3.2%)
Enuresis | Mild | 3 (17.6%) | 0 | 3 (9.7%)
Enuresis | Severe | 1 (5.9%) | 0 | 1 (3.2%)
Proteinuria | Moderate | 1 (5.9%) | 0 | 1 (3.2%)
Respiratory, thoracic and mediastinal disorders | Mild | 3 (17.6%) | 0 | 3 (9.7%)
Respiratory, thoracic and mediastinal disorders | Moderate | 0 | 1 (7.1%) | 1 (3.2%)
Cough | Mild | 1 (5.9%) | 0 | 1 (3.2%)
Epistaxis | Mild | 1 (5.9%) | 0 | 1 (3.2%)
Nasal congestion | Mild | 1 (5.9%) | 0 | 1 (3.2%)
Oropharyngeal pain | Mild | 1 (5.9%) | 0 | 1 (3.2%)
Oropharyngeal pain | Moderate | 0 | 1 (7.1%) | 1 (3.2%)
Skin and subcutaneous tissue disorders | Mild | 0 | 1 (7.1%) | 1 (3.2%)
Skin and subcutaneous tissue disorders | Moderate | 1 (5.9%) | 0 | 1 (3.2%)
Alopecia | Mild | 0 | 1 (7.1%) | 1 (3.2%)
Rash | Moderate | 1 (5.9%) | 0 | 1 (3.2%)
Vascular disorders | Mild | 1 (5.9%) | 0 | 1 (3.2%)
Hot flush | Mild | 1 (5.9%) | 0 | 1 (3.2%)

Note: The percentages are based on the total number of safety participants in each treatment group or total.

Participants are only counted once at each SOC and PT level, using the most severe intensity.

Table 14.3.1.3.4 Adverse Events by MedDRA System Organ Class, Preferred Term, Intensity and Discontinuation Phase Treatment Received Group Restabilization Phase - Safety Population

System Organ Class (SOC)/Preferred Term (PT) | Severity | Discontinuation Phase Treatment Received Group | | Total; (N=13)
System Organ Class (SOC)/Preferred Term (PT) | Severity | Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Gastrointestinal disorders | Mild | 1 (33.3%) | 3 (30.0%) | 4 (30.8%)
Gastrointestinal disorders | Moderate | 1 (33.3%) | 2 (20.0%) | 3 (23.1%)
Abdominal pain lower | Moderate | 0 | 1 (10.0%) | 1 (7.7%)
Abdominal pain upper | Mild | 1 (33.3%) | 1 (10.0%) | 2 (15.4%)
Abdominal pain upper | Moderate | 0 | 1 (10.0%) | 1 (7.7%)
Diarrhoea | Moderate | 1 (33.3%) | 0 | 1 (7.7%)
Dysphagia | Mild | 0 | 1 (10.0%) | 1 (7.7%)
Gastrooesophageal reflux disease | Mild | 0 | 1 (10.0%) | 1 (7.7%)
Gastrooesophageal reflux disease | Moderate | 0 | 1 (10.0%) | 1 (7.7%)
Nausea | Mild | 0 | 1 (10.0%) | 1 (7.7%)
Salivary hypersecretion | Mild | 0 | 1 (10.0%) | 1 (7.7%)
Vomiting | Mild | 0 | 1 (10.0%) | 1 (7.7%)
Vomiting | Moderate | 1 (33.3%) | 0 | 1 (7.7%)
General disorders and administration site conditions | Mild | 0 | 1 (10.0%) | 1 (7.7%)
Fatigue | Mild | 0 | 1 (10.0%) | 1 (7.7%)
Infections and infestations | Mild | 1 (33.3%) | 2 (20.0%) | 3 (23.1%)
Nasopharyngitis | Mild | 1 (33.3%) | 1 (10.0%) | 2 (15.4%)
Viral infection | Mild | 0 | 1 (10.0%) | 1 (7.7%)
Injury, poisoning and procedural complications | Mild | 0 | 1 (10.0%) | 1 (7.7%)
Injury, poisoning and procedural complications | Moderate | 1 (33.3%) | 0 | 1 (7.7%)
Contusion | Moderate | 1 (33.3%) | 0 | 1 (7.7%)
Post-traumatic pain | Mild | 0 | 1 (10.0%) | 1 (7.7%)
Investigations | Mild | 0 | 1 (10.0%) | 1 (7.7%)
Blood thyroid stimulating hormone increased | Mild | 0 | 1 (10.0%) | 1 (7.7%)
Blood urea nitrogen/creatinine ratio | Mild | 0 | 1 (10.0%) | 1 (7.7%)
Blood uric acid | Mild | 0 | 1 (10.0%) | 1 (7.7%)
Thyroglobulin | Mild | 0 | 1 (10.0%) | 1 (7.7%)
Nervous system disorders | Mild | 1 (33.3%) | 5 (50.0%) | 6 (46.2%)
Headache | Mild | 1 (33.3%) | 3 (30.0%) | 4 (30.8%)
Somnolence | Mild | 0 | 1 (10.0%) | 1 (7.7%)
Tremor | Mild | 0 | 2 (20.0%) | 2 (15.4%)
Renal and urinary disorders | Moderate | 1 (33.3%) | 0 | 1 (7.7%)
Enuresis | Moderate | 1 (33.3%) | 0 | 1 (7.7%)

Note: The percentages are based on the total number of safety participants in each treatment group or total.

Participants are counted once at each SOC and PT level, using the most severe intensity.

Table 14.3.1.4.1 Adverse Events by MedDRA System Organ Class, Preferred Term, Relationship to Study Medication, Age Strata and Efficacy Phase Treatment Received Group Efficacy Phase - Safety Population

System Organ Class (SOC)/Preferred Term (PT) | Relationship | 7 - 11 yrs | | 12 - 17 yrs | | Total
System Organ Class (SOC)/Preferred Term (PT) | Relationship | Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Blood and lymphatic system disorders | Unrelated | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Thrombocytopenia | Unrelated | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Cardiac disorders | Unrelated | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Palpitations | Unrelated | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Eye disorders | Unrelated | 2 (6.3%) | 1 (5.9%) | 0 | 0 | 2 (3.8%) | 1 (3.6%)
Eye disorders | Possibly related | 3 (9.4%) | 0 | 1 (4.8%) | 1 (9.1%) | 4 (7.5%) | 1 (3.6%)
Conjunctivitis | Unrelated | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Eye irritation | Unrelated | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Eye pain | Possibly related | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Eye pruritus | Unrelated | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Vision blurred | Unrelated | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Vision blurred | Possibly related | 3 (9.4%) | 0 | 1 (4.8%) | 0 | 4 (7.5%) | 0
Gastrointestinal disorders | Unrelated | 4 (12.5%) | 4 (23.5%) | 0 | 0 | 4 (7.5%) | 4 (14.3%)
Gastrointestinal disorders | Possibly related | 15 (46.9%) | 7 (41.2%) | 9 (42.9%) | 5 (45.5%) | 24 (45.3%) | 12 (42.9%)
Gastrointestinal disorders | Probably related | 8 (25.0%) | 2 (11.8%) | 6 (28.6%) | 1 (9.1%) | 14 (26.4%) | 3 (10.7%)
Gastrointestinal disorders | Definitely related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Abdominal discomfort | Unrelated | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Abdominal discomfort | Possibly related | 0 | 1 (5.9%) | 1 (4.8%) | 1 (9.1%) | 1 (1.9%) | 2 (7.1%)
Abdominal discomfort | Probably related | 1 (3.1%) | 0 | 1 (4.8%) | 0 | 2 (3.8%) | 0
Abdominal distension | Possibly related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Abdominal pain | Possibly related | 3 (9.4%) | 0 | 1 (4.8%) | 1 (9.1%) | 4 (7.5%) | 1 (3.6%)
Abdominal pain | Probably related | 1 (3.1%) | 0 | 1 (4.8%) | 0 | 2 (3.8%) | 0
Abdominal pain upper | Unrelated | 1 (3.1%) | 1 (5.9%) | 0 | 0 | 1 (1.9%) | 1 (3.6%)
Abdominal pain upper | Possibly related | 7 (21.9%) | 4 (23.5%) | 6 (28.6%) | 3 (27.3%) | 13 (24.5%) | 7 (25.0%)
Abdominal pain upper | Probably related | 1 (3.1%) | 1 (5.9%) | 1 (4.8%) | 0 | 2 (3.8%) | 1 (3.6%)
Constipation | Unrelated | 2 (6.3%) | 1 (5.9%) | 0 | 0 | 2 (3.8%) | 1 (3.6%)
Constipation | Possibly related | 1 (3.1%) | 1 (5.9%) | 0 | 0 | 1 (1.9%) | 1 (3.6%)
Constipation | Probably related | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Diarrhoea | Unrelated | 3 (9.4%) | 2 (11.8%) | 1 (4.8%) | 0 | 4 (7.5%) | 2 (7.1%)
Diarrhoea | Possibly related | 6 (18.8%) | 1 (5.9%) | 3 (14.3%) | 1 (9.1%) | 9 (17.0%) | 2 (7.1%)
Diarrhoea | Probably related | 1 (3.1%) | 0 | 1 (4.8%) | 0 | 2 (3.8%) | 0
Dry mouth | Unrelated | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Dry mouth | Probably related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Dyspepsia | Unrelated | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Dyspepsia | Possibly related | 2 (6.3%) | 2 (11.8%) | 1 (4.8%) | 1 (9.1%) | 3 (5.7%) | 3 (10.7%)
Dyspepsia | Probably related | 3 (9.4%) | 0 | 0 | 0 | 3 (5.7%) | 0
Frequent bowel movements | Unrelated | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Nausea | Unrelated | 3 (9.4%) | 0 | 0 | 0 | 3 (5.7%) | 0
Nausea | Possibly related | 2 (6.3%) | 1 (5.9%) | 7 (33.3%) | 1 (9.1%) | 9 (17.0%) | 2 (7.1%)
Nausea | Probably related | 7 (21.9%) | 2 (11.8%) | 4 (19.0%) | 1 (9.1%) | 11 (20.8%) | 3 (10.7%)
Salivary hypersecretion | Unrelated | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Toothache | Unrelated | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Vomiting | Unrelated | 5 (15.6%) | 1 (5.9%) | 0 | 0 | 5 (9.4%) | 1 (3.6%)
Vomiting | Possibly related | 3 (9.4%) | 1 (5.9%) | 5 (23.8%) | 0 | 8 (15.1%) | 1 (3.6%)
Vomiting | Probably related | 6 (18.8%) | 1 (5.9%) | 4 (19.0%) | 0 | 10 (18.9%) | 1 (3.6%)
Vomiting | Definitely related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
General disorders and administration site conditions | Unrelated | 2 (6.3%) | 2 (11.8%) | 3 (14.3%) | 2 (18.2%) | 5 (9.4%) | 4 (14.3%)
General disorders and administration site conditions | Possibly related | 3 (9.4%) | 0 | 5 (23.8%) | 3 (27.3%) | 8 (15.1%) | 3 (10.7%)
General disorders and administration site conditions | Probably related | 8 (25.0%) | 0 | 2 (9.5%) | 0 | 10 (18.9%) | 0
Asthenia | Possibly related | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Chest pain | Unrelated | 1 (3.1%) | 0 | 0 | 1 (9.1%) | 1 (1.9%) | 1 (3.6%)
Chest pain | Possibly related | 0 | 0 | 2 (9.5%) | 0 | 2 (3.8%) | 0
Fatigue | Unrelated | 0 | 0 | 2 (9.5%) | 1 (9.1%) | 2 (3.8%) | 1 (3.6%)
Fatigue | Possibly related | 0 | 0 | 3 (14.3%) | 0 | 3 (5.7%) | 0
Feeling hot | Unrelated | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Pyrexia | Unrelated | 2 (6.3%) | 2 (11.8%) | 1 (4.8%) | 0 | 3 (5.7%) | 2 (7.1%)
Thirst | Unrelated | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Thirst | Possibly related | 3 (9.4%) | 0 | 1 (4.8%) | 3 (27.3%) | 4 (7.5%) | 3 (10.7%)
Thirst | Probably related | 8 (25.0%) | 0 | 2 (9.5%) | 0 | 10 (18.9%) | 0
Infections and infestations | Unrelated | 3 (9.4%) | 3 (17.6%) | 4 (19.0%) | 3 (27.3%) | 7 (13.2%) | 6 (21.4%)
Ear infection | Unrelated | 0 | 2 (11.8%) | 0 | 0 | 0 | 2 (7.1%)
Gastroenteritis | Unrelated | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Gastroenteritis viral | Unrelated | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Nasopharyngitis | Unrelated | 2 (6.3%) | 1 (5.9%) | 0 | 1 (9.1%) | 2 (3.8%) | 2 (7.1%)
Otitis externa | Unrelated | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Pharyngitis | Unrelated | 1 (3.1%) | 0 | 1 (4.8%) | 0 | 2 (3.8%) | 0
Upper respiratory tract infection | Unrelated | 0 | 0 | 2 (9.5%) | 1 (9.1%) | 2 (3.8%) | 1 (3.6%)
Injury, poisoning and procedural complications | Unrelated | 3 (9.4%) | 1 (5.9%) | 2 (9.5%) | 0 | 5 (9.4%) | 1 (3.6%)
Contusion | Unrelated | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Excoriation | Unrelated | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Joint injury | Unrelated | 0 | 1 (5.9%) | 1 (4.8%) | 0 | 1 (1.9%) | 1 (3.6%)
Tooth injury | Unrelated | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Upper limb fracture | Unrelated | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Investigations | Possibly related | 3 (9.4%) | 1 (5.9%) | 4 (19.0%) | 1 (9.1%) | 7 (13.2%) | 2 (7.1%)
Investigations | Probably related | 2 (6.3%) | 0 | 2 (9.5%) | 0 | 4 (7.5%) | 0
Investigations | Definitely related | 1 (3.1%) | 0 | 1 (4.8%) | 0 | 2 (3.8%) | 0
Blood thyroid stimulating hormone increased | Possibly related | 1 (3.1%) | 0 | 2 (9.5%) | 0 | 3 (5.7%) | 0
Blood thyroid stimulating hormone increased | Probably related | 2 (6.3%) | 0 | 2 (9.5%) | 0 | 4 (7.5%) | 0
Blood thyroid stimulating hormone increased | Definitely related | 1 (3.1%) | 0 | 1 (4.8%) | 0 | 2 (3.8%) | 0
Protein urine present | Possibly related | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Thyroid function test abnormal | Possibly related | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Thyroxine decreased | Possibly related | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Weight increased | Possibly related | 2 (6.3%) | 1 (5.9%) | 0 | 1 (9.1%) | 2 (3.8%) | 2 (7.1%)
Metabolism and nutrition disorders | Possibly related | 6 (18.8%) | 3 (17.6%) | 2 (9.5%) | 3 (27.3%) | 8 (15.1%) | 6 (21.4%)
Metabolism and nutrition disorders | Probably related | 4 (12.5%) | 0 | 1 (4.8%) | 0 | 5 (9.4%) | 0
Decreased appetite | Possibly related | 3 (9.4%) | 1 (5.9%) | 0 | 0 | 3 (5.7%) | 1 (3.6%)
Decreased appetite | Probably related | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Increased appetite | Possibly related | 8 (25.0%) | 2 (11.8%) | 1 (4.8%) | 3 (27.3%) | 9 (17.0%) | 5 (17.9%)
Increased appetite | Probably related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Polydipsia | Possibly related | 0 | 0 | 2 (9.5%) | 0 | 2 (3.8%) | 0
Polydipsia | Probably related | 1 (3.1%) | 0 | 1 (4.8%) | 0 | 2 (3.8%) | 0
Musculoskeletal and connective tissue disorders | Unrelated | 3 (9.4%) | 2 (11.8%) | 0 | 0 | 3 (5.7%) | 2 (7.1%)
Musculoskeletal and connective tissue disorders | Possibly related | 1 (3.1%) | 1 (5.9%) | 1 (4.8%) | 0 | 2 (3.8%) | 1 (3.6%)
Musculoskeletal and connective tissue disorders | Probably related | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Arthralgia | Unrelated | 1 (3.1%) | 1 (5.9%) | 0 | 0 | 1 (1.9%) | 1 (3.6%)
Back pain | Unrelated | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Muscle rigidity | Probably related | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Muscle spasms | Possibly related | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Muscular weakness | Unrelated | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Muscular weakness | Possibly related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Musculoskeletal chest pain | Unrelated | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Musculoskeletal stiffness | Unrelated | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Musculoskeletal stiffness | Probably related | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Neck pain | Unrelated | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Sensation of heaviness | Possibly related | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Nervous system disorders | Unrelated | 4 (12.5%) | 1 (5.9%) | 1 (4.8%) | 2 (18.2%) | 5 (9.4%) | 3 (10.7%)
Nervous system disorders | Possibly related | 8 (25.0%) | 6 (35.3%) | 10 (47.6%) | 3 (27.3%) | 18 (34.0%) | 9 (32.1%)
Nervous system disorders | Probably related | 7 (21.9%) | 0 | 6 (28.6%) | 1 (9.1%) | 13 (24.5%) | 1 (3.6%)
Nervous system disorders | Definitely related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Ataxia | Unrelated | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Ataxia | Possibly related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Ataxia | Probably related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Cerebellar ataxia | Probably related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Cerebellar syndrome | Probably related | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Coordination abnormal | Unrelated | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Coordination abnormal | Probably related | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Dizziness | Unrelated | 2 (6.3%) | 0 | 0 | 2 (18.2%) | 2 (3.8%) | 2 (7.1%)
Dizziness | Possibly related | 3 (9.4%) | 0 | 5 (23.8%) | 0 | 8 (15.1%) | 0
Dizziness | Probably related | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Dysarthria | Possibly related | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Dysarthria | Definitely related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Dysgeusia | Probably related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Dyskinesia | Probably related | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Glabellar reflex abnormal | Probably related | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Headache | Unrelated | 4 (12.5%) | 1 (5.9%) | 0 | 1 (9.1%) | 4 (7.5%) | 2 (7.1%)
Headache | Possibly related | 5 (15.6%) | 4 (23.5%) | 7 (33.3%) | 3 (27.3%) | 12 (22.6%) | 7 (25.0%)
Headache | Probably related | 2 (6.3%) | 0 | 1 (4.8%) | 0 | 3 (5.7%) | 0
Hypersomnia | Possibly related | 0 | 0 | 1 (4.8%) | 2 (18.2%) | 1 (1.9%) | 2 (7.1%)
Hypotonia | Possibly related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Memory impairment | Possibly related | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Migraine | Unrelated | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Nystagmus | Possibly related | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Sedation | Possibly related | 5 (15.6%) | 0 | 0 | 0 | 5 (9.4%) | 0
Sedation | Probably related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Somnolence | Unrelated | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Somnolence | Possibly related | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Somnolence | Probably related | 3 (9.4%) | 0 | 2 (9.5%) | 1 (9.1%) | 5 (9.4%) | 1 (3.6%)
Speech disorder | Unrelated | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Tremor | Unrelated | 1 (3.1%) | 0 | 1 (4.8%) | 0 | 2 (3.8%) | 0
Tremor | Possibly related | 5 (15.6%) | 2 (11.8%) | 4 (19.0%) | 0 | 9 (17.0%) | 2 (7.1%)
Tremor | Probably related | 3 (9.4%) | 0 | 3 (14.3%) | 0 | 6 (11.3%) | 0
Psychiatric disorders | Unrelated | 2 (6.3%) | 2 (11.8%) | 6 (28.6%) | 1 (9.1%) | 8 (15.1%) | 3 (10.7%)
Psychiatric disorders | Possibly related | 2 (6.3%) | 1 (5.9%) | 1 (4.8%) | 1 (9.1%) | 3 (5.7%) | 2 (7.1%)
Psychiatric disorders | Probably related | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Aggression | Unrelated | 1 (3.1%) | 1 (5.9%) | 0 | 0 | 1 (1.9%) | 1 (3.6%)
Aggression | Possibly related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Agitation | Unrelated | 0 | 1 (5.9%) | 1 (4.8%) | 0 | 1 (1.9%) | 1 (3.6%)
Agitation | Possibly related | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Anger | Unrelated | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Bipolar disorder | Unrelated | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Confusional state | Unrelated | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Confusional state | Possibly related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Disorientation | Unrelated | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Dyssomnia | Possibly related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Hallucination, auditory | Unrelated | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Hallucination, visual | Unrelated | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Initial insomnia | Possibly related | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Insomnia | Possibly related | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Mood altered | Unrelated | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Psychotic disorder | Probably related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Suicidal behaviour | Unrelated | 0 | 0 | 2 (9.5%) | 0 | 2 (3.8%) | 0
Suicidal ideation | Unrelated | 0 | 0 | 2 (9.5%) | 0 | 2 (3.8%) | 0
Tic | Probably related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Violence-related symptom | Unrelated | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Renal and urinary disorders | Unrelated | 1 (3.1%) | 0 | 0 | 1 (9.1%) | 1 (1.9%) | 1 (3.6%)
Renal and urinary disorders | Possibly related | 6 (18.8%) | 2 (11.8%) | 4 (19.0%) | 2 (18.2%) | 10 (18.9%) | 4 (14.3%)
Renal and urinary disorders | Probably related | 6 (18.8%) | 0 | 2 (9.5%) | 0 | 8 (15.1%) | 0
Renal and urinary disorders | Definitely related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Enuresis | Unrelated | 1 (3.1%) | 0 | 0 | 1 (9.1%) | 1 (1.9%) | 1 (3.6%)
Enuresis | Possibly related | 2 (6.3%) | 1 (5.9%) | 0 | 0 | 2 (3.8%) | 1 (3.6%)
Enuresis | Probably related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Enuresis | Definitely related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Micturition urgency | Possibly related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Micturition urgency | Probably related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Nocturia | Possibly related | 0 | 1 (5.9%) | 2 (9.5%) | 0 | 2 (3.8%) | 1 (3.6%)
Pollakiuria | Unrelated | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Pollakiuria | Possibly related | 5 (15.6%) | 0 | 2 (9.5%) | 2 (18.2%) | 7 (13.2%) | 2 (7.1%)
Pollakiuria | Probably related | 4 (12.5%) | 0 | 2 (9.5%) | 0 | 6 (11.3%) | 0
Polyuria | Possibly related | 0 | 0 | 2 (9.5%) | 0 | 2 (3.8%) | 0
Polyuria | Probably related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Urinary incontinence | Unrelated | 0 | 0 | 0 | 1 (9.1%) | 0 | 1 (3.6%)
Respiratory, thoracic and mediastinal disorders | Unrelated | 5 (15.6%) | 1 (5.9%) | 2 (9.5%) | 0 | 7 (13.2%) | 1 (3.6%)
Respiratory, thoracic and mediastinal disorders | Possibly related | 1 (3.1%) | 1 (5.9%) | 0 | 0 | 1 (1.9%) | 1 (3.6%)
Cough | Unrelated | 1 (3.1%) | 1 (5.9%) | 1 (4.8%) | 0 | 2 (3.8%) | 1 (3.6%)
Epistaxis | Unrelated | 1 (3.1%) | 1 (5.9%) | 0 | 0 | 1 (1.9%) | 1 (3.6%)
Epistaxis | Possibly related | 1 (3.1%) | 1 (5.9%) | 0 | 0 | 1 (1.9%) | 1 (3.6%)
Nasal congestion | Unrelated | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Oropharyngeal pain | Unrelated | 0 | 1 (5.9%) | 1 (4.8%) | 0 | 1 (1.9%) | 1 (3.6%)
Rhinorrhoea | Unrelated | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Skin and subcutaneous tissue disorders | Unrelated | 2 (6.3%) | 0 | 2 (9.5%) | 0 | 4 (7.5%) | 0
Skin and subcutaneous tissue disorders | Possibly related | 4 (12.5%) | 0 | 2 (9.5%) | 0 | 6 (11.3%) | 0
Skin and subcutaneous tissue disorders | Probably related | 2 (6.3%) | 0 | 0 | 0 | 2 (3.8%) | 0
Acne | Possibly related | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Dry skin | Probably related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Eczema | Unrelated | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Eczema | Possibly related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Heat rash | Unrelated | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Hyperhidrosis | Unrelated | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Hyperhidrosis | Probably related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Pruritus | Unrelated | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Rash | Unrelated | 1 (3.1%) | 0 | 2 (9.5%) | 0 | 3 (5.7%) | 0
Rash | Possibly related | 2 (6.3%) | 0 | 1 (4.8%) | 0 | 3 (5.7%) | 0
Swelling face | Possibly related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Vascular disorders | Probably related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Pallor | Probably related | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0

Note: The percentages are based on the total number of safety participants in each age strata/treatment group.

Participants are counted once at each SOC and PT level, using the strongest relationship to study medication.

Table 14.3.1.4.2A Adverse Events by MedDRA System Organ Class, Preferred Term, Relationship to Study Medication and Age Strata Long-Term Effectiveness Phase - Safety Population

System Organ Class (SOC)/Preferred Term | Relationship | Age Strata | | Total; (N=44)
System Organ Class (SOC)/Preferred Term | Relationship | 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Ear and labyrinth disorders | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Ear pain | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Endocrine disorders | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Hypothyroidism | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Eye disorders | Unrelated | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Eye disorders | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Eye swelling | Unrelated | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Vision blurred | Unrelated | 0 | 1 (6.7%) | 1 (2.3%)
Vision blurred | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Gastrointestinal disorders | Unrelated | 7 (24.1%) | 1 (6.7%) | 8 (18.2%)
Gastrointestinal disorders | Possibly related | 1 (3.4%) | 5 (33.3%) | 6 (13.6%)
Gastrointestinal disorders | Probably related | 8 (27.6%) | 4 (26.7%) | 12 (27.3%)
Gastrointestinal disorders | Definitely related | 4 (13.8%) | 0 | 4 (9.1%)
Abdominal discomfort | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Abdominal discomfort | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Abdominal discomfort | Definitely related | 1 (3.4%) | 0 | 1 (2.3%)
Abdominal pain | Unrelated | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Abdominal pain | Probably related | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Abdominal pain | Definitely related | 1 (3.4%) | 0 | 1 (2.3%)
Abdominal pain upper | Unrelated | 4 (13.8%) | 0 | 4 (9.1%)
Abdominal pain upper | Possibly related | 2 (6.9%) | 2 (13.3%) | 4 (9.1%)
Abdominal pain upper | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Constipation | Unrelated | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Diarrhoea | Unrelated | 3 (10.3%) | 2 (13.3%) | 5 (11.4%)
Diarrhoea | Possibly related | 2 (6.9%) | 0 | 2 (4.5%)
Diarrhoea | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Dry mouth | Unrelated | 0 | 1 (6.7%) | 1 (2.3%)
Dry mouth | Probably related | 0 | 2 (13.3%) | 2 (4.5%)
Dyspepsia | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Dyspepsia | Probably related | 2 (6.9%) | 0 | 2 (4.5%)
Flatulence | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Gingival pain | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Nausea | Unrelated | 2 (6.9%) | 0 | 2 (4.5%)
Nausea | Possibly related | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Nausea | Probably related | 4 (13.8%) | 3 (20.0%) | 7 (15.9%)
Nausea | Definitely related | 2 (6.9%) | 0 | 2 (4.5%)
Vomiting | Unrelated | 5 (17.2%) | 1 (6.7%) | 6 (13.6%)
Vomiting | Possibly related | 0 | 2 (13.3%) | 2 (4.5%)
Vomiting | Probably related | 4 (13.8%) | 1 (6.7%) | 5 (11.4%)
Vomiting | Definitely related | 2 (6.9%) | 0 | 2 (4.5%)
General disorders and administration site conditions | Unrelated | 4 (13.8%) | 2 (13.3%) | 6 (13.6%)
General disorders and administration site conditions | Possibly related | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
General disorders and administration site conditions | Probably related | 3 (10.3%) | 3 (20.0%) | 6 (13.6%)
Chest pain | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Fatigue | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Fatigue | Possibly related | 0 | 2 (13.3%) | 2 (4.5%)
Fatigue | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Feeling hot | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Gait disturbance | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Irritability | Unrelated | 2 (6.9%) | 2 (13.3%) | 4 (9.1%)
Mucosal ulceration | Unrelated | 0 | 1 (6.7%) | 1 (2.3%)
Pyrexia | Unrelated | 3 (10.3%) | 0 | 3 (6.8%)
Thirst | Possibly related | 2 (6.9%) | 0 | 2 (4.5%)
Thirst | Probably related | 2 (6.9%) | 3 (20.0%) | 5 (11.4%)
Vessel puncture site pain | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Immune system disorders | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Hypersensitivity | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Infections and infestations | Unrelated | 15 (51.7%) | 4 (26.7%) | 19 (43.2%)
Infections and infestations | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Bronchitis | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Ear infection | Unrelated | 3 (10.3%) | 0 | 3 (6.8%)
Gastroenteritis | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Gastroenteritis viral | Unrelated | 3 (10.3%) | 0 | 3 (6.8%)
Hordeolum | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Influenza | Unrelated | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Nasopharyngitis | Unrelated | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Otitis externa | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Pharyngitis streptococcal | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Sinusitis | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Upper respiratory tract infection | Unrelated | 2 (6.9%) | 2 (13.3%) | 4 (9.1%)
Urinary tract infection | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Vulvovaginal candidiasis | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Injury, poisoning and procedural complications | Unrelated | 5 (17.2%) | 0 | 5 (11.4%)
Contusion | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Excoriation | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Foot fracture | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Head injury | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Limb injury | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Muscle strain | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Investigations | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Investigations | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Investigations | Probably related | 1 (3.4%) | 3 (20.0%) | 4 (9.1%)
Activated partial thromboplastin time abnormal | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Alanine aminotransferase increased | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Blood creatine phosphokinase increased | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Blood sodium decreased | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Blood thyroid stimulating hormone abnormal | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Blood thyroid stimulating hormone increased | Probably related | 0 | 2 (13.3%) | 2 (4.5%)
Blood triglycerides abnormal | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Blood triglycerides increased | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Blood triglycerides increased | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Blood urea decreased | Probably related | 0 | 1 (6.7%) | 1 (2.3%)
Blood uric acid increased | Probably related | 0 | 1 (6.7%) | 1 (2.3%)
Gamma-glutamyltransferase increased | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Thyroxine abnormal | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Metabolism and nutrition disorders | Unrelated | 4 (13.8%) | 0 | 4 (9.1%)
Metabolism and nutrition disorders | Possibly related | 1 (3.4%) | 3 (20.0%) | 4 (9.1%)
Metabolism and nutrition disorders | Probably related | 0 | 2 (13.3%) | 2 (4.5%)
Decreased appetite | Unrelated | 2 (6.9%) | 0 | 2 (4.5%)
Decreased appetite | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Hyperinsulinaemia | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Hypophagia | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Increased appetite | Possibly related | 0 | 3 (20.0%) | 3 (6.8%)
Increased appetite | Probably related | 0 | 2 (13.3%) | 2 (4.5%)
Musculoskeletal and connective tissue disorders | Unrelated | 2 (6.9%) | 0 | 2 (4.5%)
Musculoskeletal and connective tissue disorders | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Musculoskeletal and connective tissue disorders | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Muscular weakness | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Musculoskeletal pain | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Musculoskeletal stiffness | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Myalgia | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Neck pain | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Nervous system disorders | Unrelated | 5 (17.2%) | 1 (6.7%) | 6 (13.6%)
Nervous system disorders | Possibly related | 6 (20.7%) | 8 (53.3%) | 14 (31.8%)
Nervous system disorders | Probably related | 4 (13.8%) | 2 (13.3%) | 6 (13.6%)
Nervous system disorders | Definitely related | 1 (3.4%) | 0 | 1 (2.3%)
Burning sensation | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Disturbance in attention | Unrelated | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Disturbance in attention | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Disturbance in attention | Probably related | 0 | 1 (6.7%) | 1 (2.3%)
Dizziness | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Dizziness | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Dizziness | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Dysarthria | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Dyskinesia | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Headache | Unrelated | 5 (17.2%) | 2 (13.3%) | 7 (15.9%)
Headache | Possibly related | 5 (17.2%) | 4 (26.7%) | 9 (20.5%)
Headache | Probably related | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Lethargy | Unrelated | 0 | 1 (6.7%) | 1 (2.3%)
Memory impairment | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Sedation | Possibly related | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Somnolence | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Somnolence | Possibly related | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Somnolence | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Tremor | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Tremor | Possibly related | 2 (6.9%) | 2 (13.3%) | 4 (9.1%)
Tremor | Probably related | 2 (6.9%) | 0 | 2 (4.5%)
Tremor | Definitely related | 1 (3.4%) | 0 | 1 (2.3%)
Psychiatric disorders | Unrelated | 3 (10.3%) | 4 (26.7%) | 7 (15.9%)
Psychiatric disorders | Possibly related | 1 (3.4%) | 2 (13.3%) | 3 (6.8%)
Psychiatric disorders | Probably related | 0 | 1 (6.7%) | 1 (2.3%)
Agitation | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Anxiety | Unrelated | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Anxiety | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Confusional state | Unrelated | 0 | 1 (6.7%) | 1 (2.3%)
Depression | Unrelated | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Initial insomnia | Unrelated | 2 (6.9%) | 2 (13.3%) | 4 (9.1%)
Insomnia | Unrelated | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Insomnia | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Insomnia | Probably related | 0 | 1 (6.7%) | 1 (2.3%)
Restlessness | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Self injurious behaviour | Unrelated | 0 | 1 (6.7%) | 1 (2.3%)
Somnambulism | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Stress | Unrelated | 0 | 1 (6.7%) | 1 (2.3%)
Suicidal ideation | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Suicide attempt | Unrelated | 0 | 1 (6.7%) | 1 (2.3%)
Tic | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Renal and urinary disorders | Possibly related | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Renal and urinary disorders | Probably related | 5 (17.2%) | 4 (26.7%) | 9 (20.5%)
Enuresis | Possibly related | 2 (6.9%) | 0 | 2 (4.5%)
Enuresis | Probably related | 3 (10.3%) | 0 | 3 (6.8%)
Micturition disorder | Probably related | 0 | 1 (6.7%) | 1 (2.3%)
Micturition urgency | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Nocturia | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Nocturia | Probably related | 0 | 1 (6.7%) | 1 (2.3%)
Pollakiuria | Possibly related | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Pollakiuria | Probably related | 3 (10.3%) | 2 (13.3%) | 5 (11.4%)
Polyuria | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Respiratory, thoracic and mediastinal disorders | Unrelated | 8 (27.6%) | 1 (6.7%) | 9 (20.5%)
Respiratory, thoracic and mediastinal disorders | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Asthma | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Cough | Unrelated | 2 (6.9%) | 0 | 2 (4.5%)
Epistaxis | Unrelated | 2 (6.9%) | 0 | 2 (4.5%)
Epistaxis | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Oropharyngeal pain | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Respiratory disorder | Unrelated | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Upper respiratory tract congestion | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Skin and subcutaneous tissue disorders | Unrelated | 4 (13.8%) | 0 | 4 (9.1%)
Skin and subcutaneous tissue disorders | Possibly related | 5 (17.2%) | 4 (26.7%) | 9 (20.5%)
Skin and subcutaneous tissue disorders | Probably related | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Acne | Possibly related | 0 | 2 (13.3%) | 2 (4.5%)
Alopecia | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Alopecia | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Alopecia | Probably related | 0 | 1 (6.7%) | 1 (2.3%)
Dermatitis allergic | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Dermatitis contact | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Pruritus | Unrelated | 0 | 1 (6.7%) | 1 (2.3%)
Pruritus | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Rash | Unrelated | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Rash | Possibly related | 3 (10.3%) | 2 (13.3%) | 5 (11.4%)
Rash | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Vascular disorders | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Hot flush | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)

Note: The percentages are based on the total number of safety participants in each age strata or total.

Participants are counted once at each SOC and PT level, using the strongest relationship to study medication.

Table 14.3.1.4.2B Adverse Events by MedDRA System Organ Class, Preferred Term, Relationship to Study Medication and Efficacy Phase Treatment Received Group Long-Term Effectiveness Phase - Safety Population

System Organ Class (SOC)/Preferred Term (PT) | Relationship | Efficacy Phase Treatment Received Group | | Total; (N=44)
System Organ Class (SOC)/Preferred Term (PT) | Relationship | Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Ear and labyrinth disorders | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Ear pain | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Endocrine disorders | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Hypothyroidism | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Eye disorders | Unrelated | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Eye disorders | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Eye swelling | Unrelated | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Vision blurred | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Vision blurred | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Gastrointestinal disorders | Unrelated | 7 (24.1%) | 1 (6.7%) | 8 (18.2%)
Gastrointestinal disorders | Possibly related | 4 (13.8%) | 2 (13.3%) | 6 (13.6%)
Gastrointestinal disorders | Probably related | 6 (20.7%) | 6 (40.0%) | 12 (27.3%)
Gastrointestinal disorders | Definitely related | 2 (6.9%) | 2 (13.3%) | 4 (9.1%)
Abdominal discomfort | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Abdominal discomfort | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Abdominal discomfort | Definitely related | 0 | 1 (6.7%) | 1 (2.3%)
Abdominal pain | Unrelated | 4 (13.8%) | 0 | 4 (9.1%)
Abdominal pain | Probably related | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Abdominal pain | Definitely related | 1 (3.4%) | 0 | 1 (2.3%)
Abdominal pain upper | Unrelated | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Abdominal pain upper | Possibly related | 2 (6.9%) | 2 (13.3%) | 4 (9.1%)
Abdominal pain upper | Probably related | 0 | 1 (6.7%) | 1 (2.3%)
Constipation | Unrelated | 3 (10.3%) | 0 | 3 (6.8%)
Diarrhoea | Unrelated | 3 (10.3%) | 2 (13.3%) | 5 (11.4%)
Diarrhoea | Possibly related | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Diarrhoea | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Dry mouth | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Dry mouth | Probably related | 2 (6.9%) | 0 | 2 (4.5%)
Dyspepsia | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Dyspepsia | Probably related | 2 (6.9%) | 0 | 2 (4.5%)
Flatulence | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Gingival pain | Unrelated | 0 | 1 (6.7%) | 1 (2.3%)
Nausea | Unrelated | 2 (6.9%) | 0 | 2 (4.5%)
Nausea | Possibly related | 2 (6.9%) | 2 (13.3%) | 4 (9.1%)
Nausea | Probably related | 4 (13.8%) | 3 (20.0%) | 7 (15.9%)
Nausea | Definitely related | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Vomiting | Unrelated | 4 (13.8%) | 2 (13.3%) | 6 (13.6%)
Vomiting | Possibly related | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Vomiting | Probably related | 2 (6.9%) | 3 (20.0%) | 5 (11.4%)
Vomiting | Definitely related | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
General disorders and administration site conditions | Unrelated | 4 (13.8%) | 2 (13.3%) | 6 (13.6%)
General disorders and administration site conditions | Possibly related | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
General disorders and administration site conditions | Probably related | 3 (10.3%) | 3 (20.0%) | 6 (13.6%)
Chest pain | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Fatigue | Unrelated | 0 | 1 (6.7%) | 1 (2.3%)
Fatigue | Possibly related | 2 (6.9%) | 0 | 2 (4.5%)
Fatigue | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Feeling hot | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Gait disturbance | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Irritability | Unrelated | 4 (13.8%) | 0 | 4 (9.1%)
Mucosal ulceration | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Pyrexia | Unrelated | 1 (3.4%) | 2 (13.3%) | 3 (6.8%)
Thirst | Possibly related | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Thirst | Probably related | 2 (6.9%) | 3 (20.0%) | 5 (11.4%)
Vessel puncture site pain | Unrelated | 0 | 1 (6.7%) | 1 (2.3%)
Immune system disorders | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Hypersensitivity | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Infections and infestations | Unrelated | 12 (41.4%) | 7 (46.7%) | 19 (43.2%)
Infections and infestations | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Bronchitis | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Ear infection | Unrelated | 1 (3.4%) | 2 (13.3%) | 3 (6.8%)
Gastroenteritis | Unrelated | 0 | 1 (6.7%) | 1 (2.3%)
Gastroenteritis viral | Unrelated | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Hordeolum | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Influenza | Unrelated | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Nasopharyngitis | Unrelated | 4 (13.8%) | 0 | 4 (9.1%)
Otitis externa | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Pharyngitis streptococcal | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Sinusitis | Unrelated | 0 | 1 (6.7%) | 1 (2.3%)
Upper respiratory tract infection | Unrelated | 2 (6.9%) | 2 (13.3%) | 4 (9.1%)
Urinary tract infection | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Vulvovaginal candidiasis | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Injury, poisoning and procedural complications | Unrelated | 3 (10.3%) | 2 (13.3%) | 5 (11.4%)
Contusion | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Excoriation | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Foot fracture | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Head injury | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Limb injury | Unrelated | 0 | 1 (6.7%) | 1 (2.3%)
Muscle strain | Unrelated | 0 | 1 (6.7%) | 1 (2.3%)
Investigations | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Investigations | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Investigations | Probably related | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Activated partial thromboplastin time abnormal | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Alanine aminotransferase increased | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Blood creatine phosphokinase increased | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Blood sodium decreased | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Blood thyroid stimulating hormone abnormal | Probably related | 0 | 1 (6.7%) | 1 (2.3%)
Blood thyroid stimulating hormone increased | Probably related | 2 (6.9%) | 0 | 2 (4.5%)
Blood triglycerides abnormal | Unrelated | 0 | 1 (6.7%) | 1 (2.3%)
Blood triglycerides increased | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Blood triglycerides increased | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Blood urea decreased | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Blood uric acid increased | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Gamma-glutamyltransferase increased | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Thyroxine abnormal | Probably related | 0 | 1 (6.7%) | 1 (2.3%)
Metabolism and nutrition disorders | Unrelated | 4 (13.8%) | 0 | 4 (9.1%)
Metabolism and nutrition disorders | Possibly related | 2 (6.9%) | 2 (13.3%) | 4 (9.1%)
Metabolism and nutrition disorders | Probably related | 2 (6.9%) | 0 | 2 (4.5%)
Decreased appetite | Unrelated | 2 (6.9%) | 0 | 2 (4.5%)
Decreased appetite | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Hyperinsulinaemia | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Hypophagia | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Increased appetite | Possibly related | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Increased appetite | Probably related | 2 (6.9%) | 0 | 2 (4.5%)
Musculoskeletal and connective tissue disorders | Unrelated | 2 (6.9%) | 0 | 2 (4.5%)
Musculoskeletal and connective tissue disorders | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Musculoskeletal and connective tissue disorders | Probably related | 0 | 1 (6.7%) | 1 (2.3%)
Muscular weakness | Probably related | 0 | 1 (6.7%) | 1 (2.3%)
Musculoskeletal pain | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Musculoskeletal stiffness | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Myalgia | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Neck pain | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Nervous system disorders | Unrelated | 4 (13.8%) | 2 (13.3%) | 6 (13.6%)
Nervous system disorders | Possibly related | 8 (27.6%) | 6 (40.0%) | 14 (31.8%)
Nervous system disorders | Probably related | 4 (13.8%) | 2 (13.3%) | 6 (13.6%)
Nervous system disorders | Definitely related | 1 (3.4%) | 0 | 1 (2.3%)
Burning sensation | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Disturbance in attention | Unrelated | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Disturbance in attention | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Disturbance in attention | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Dizziness | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Dizziness | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Dizziness | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Dysarthria | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Dyskinesia | Probably related | 0 | 1 (6.7%) | 1 (2.3%)
Headache | Unrelated | 6 (20.7%) | 1 (6.7%) | 7 (15.9%)
Headache | Possibly related | 4 (13.8%) | 5 (33.3%) | 9 (20.5%)
Headache | Probably related | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Lethargy | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Memory impairment | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Sedation | Possibly related | 2 (6.9%) | 0 | 2 (4.5%)
Somnolence | Unrelated | 0 | 1 (6.7%) | 1 (2.3%)
Somnolence | Possibly related | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Somnolence | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Tremor | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Tremor | Possibly related | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Tremor | Probably related | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Tremor | Definitely related | 1 (3.4%) | 0 | 1 (2.3%)
Psychiatric disorders | Unrelated | 6 (20.7%) | 1 (6.7%) | 7 (15.9%)
Psychiatric disorders | Possibly related | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Psychiatric disorders | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Agitation | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Anxiety | Unrelated | 2 (6.9%) | 0 | 2 (4.5%)
Anxiety | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Confusional state | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Depression | Unrelated | 3 (10.3%) | 0 | 3 (6.8%)
Initial insomnia | Unrelated | 4 (13.8%) | 0 | 4 (9.1%)
Insomnia | Unrelated | 2 (6.9%) | 0 | 2 (4.5%)
Insomnia | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Insomnia | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Restlessness | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Self injurious behaviour | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Somnambulism | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Stress | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Suicidal ideation | Unrelated | 0 | 1 (6.7%) | 1 (2.3%)
Suicide attempt | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Tic | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Renal and urinary disorders | Possibly related | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Renal and urinary disorders | Probably related | 6 (20.7%) | 3 (20.0%) | 9 (20.5%)
Enuresis | Possibly related | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Enuresis | Probably related | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
Micturition disorder | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Micturition urgency | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Nocturia | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Nocturia | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Pollakiuria | Possibly related | 2 (6.9%) | 0 | 2 (4.5%)
Pollakiuria | Probably related | 3 (10.3%) | 2 (13.3%) | 5 (11.4%)
Polyuria | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Respiratory, thoracic and mediastinal disorders | Unrelated | 5 (17.2%) | 4 (26.7%) | 9 (20.5%)
Respiratory, thoracic and mediastinal disorders | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Asthma | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Cough | Unrelated | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Epistaxis | Unrelated | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Epistaxis | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Oropharyngeal pain | Unrelated | 0 | 1 (6.7%) | 1 (2.3%)
Respiratory disorder | Unrelated | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
Upper respiratory tract congestion | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Skin and subcutaneous tissue disorders | Unrelated | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Skin and subcutaneous tissue disorders | Possibly related | 6 (20.7%) | 3 (20.0%) | 9 (20.5%)
Skin and subcutaneous tissue disorders | Probably related | 2 (6.9%) | 0 | 2 (4.5%)
Acne | Possibly related | 2 (6.9%) | 0 | 2 (4.5%)
Alopecia | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Alopecia | Possibly related | 1 (3.4%) | 0 | 1 (2.3%)
Alopecia | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Dermatitis allergic | Unrelated | 0 | 1 (6.7%) | 1 (2.3%)
Dermatitis contact | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Pruritus | Unrelated | 1 (3.4%) | 0 | 1 (2.3%)
Pruritus | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Rash | Unrelated | 3 (10.3%) | 1 (6.7%) | 4 (9.1%)
Rash | Possibly related | 3 (10.3%) | 2 (13.3%) | 5 (11.4%)
Rash | Probably related | 1 (3.4%) | 0 | 1 (2.3%)
Vascular disorders | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)
Hot flush | Possibly related | 0 | 1 (6.7%) | 1 (2.3%)

Note: The percentages are based on the total number of safety participants in each treatment group or total.

Participants are counted once at each SOC and PT level, using the strongest relationship to study medication.

Table 14.3.1.4.3 Adverse Events by MedDRA System Organ Class, Preferred Term, Relationship to Study Medication and Discontinuation Phase Treatment Received Group Discontinuation Phase - Safety Population

System Organ Class (SOC)/Preferred Term (PT) | Relationship | Discontinuation Phase Treatment Received Group | | Total; (N=31)
System Organ Class (SOC)/Preferred Term (PT) | Relationship | Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Endocrine disorders | Probably related | 1 (5.9%) | 0 | 1 (3.2%)
Hypothyroidism | Probably related | 1 (5.9%) | 0 | 1 (3.2%)
Eye disorders | Possibly related | 1 (5.9%) | 0 | 1 (3.2%)
Vision blurred | Possibly related | 1 (5.9%) | 0 | 1 (3.2%)
Gastrointestinal disorders | Unrelated | 3 (17.6%) | 3 (21.4%) | 6 (19.4%)
Gastrointestinal disorders | Possibly related | 6 (35.3%) | 1 (7.1%) | 7 (22.6%)
Abdominal discomfort | Unrelated | 1 (5.9%) | 0 | 1 (3.2%)
Abdominal discomfort | Possibly related | 1 (5.9%) | 0 | 1 (3.2%)
Abdominal pain | Possibly related | 1 (5.9%) | 0 | 1 (3.2%)
Abdominal pain lower | Possibly related | 0 | 1 (7.1%) | 1 (3.2%)
Abdominal pain upper | Unrelated | 2 (11.8%) | 1 (7.1%) | 3 (9.7%)
Abdominal pain upper | Possibly related | 3 (17.6%) | 0 | 3 (9.7%)
Diarrhoea | Unrelated | 1 (5.9%) | 0 | 1 (3.2%)
Diarrhoea | Possibly related | 1 (5.9%) | 0 | 1 (3.2%)
Dyspepsia | Unrelated | 0 | 1 (7.1%) | 1 (3.2%)
Nausea | Unrelated | 0 | 1 (7.1%) | 1 (3.2%)
Salivary hypersecretion | Possibly related | 1 (5.9%) | 0 | 1 (3.2%)
Vomiting | Unrelated | 2 (11.8%) | 0 | 2 (6.5%)
Vomiting | Possibly related | 2 (11.8%) | 0 | 2 (6.5%)
General disorders and administration site conditions | Unrelated | 1 (5.9%) | 0 | 1 (3.2%)
General disorders and administration site conditions | Possibly related | 1 (5.9%) | 0 | 1 (3.2%)
Feeling hot | Unrelated | 1 (5.9%) | 0 | 1 (3.2%)
Irritability | Possibly related | 1 (5.9%) | 0 | 1 (3.2%)
Immune system disorders | Unrelated | 1 (5.9%) | 0 | 1 (3.2%)
Allergy to arthropod bite | Unrelated | 1 (5.9%) | 0 | 1 (3.2%)
Infections and infestations | Unrelated | 5 (29.4%) | 2 (14.3%) | 7 (22.6%)
Ear infection | Unrelated | 2 (11.8%) | 0 | 2 (6.5%)
Gastroenteritis viral | Unrelated | 1 (5.9%) | 0 | 1 (3.2%)
Nasopharyngitis | Unrelated | 2 (11.8%) | 1 (7.1%) | 3 (9.7%)
Upper respiratory tract infection | Unrelated | 3 (17.6%) | 0 | 3 (9.7%)
Viral infection | Unrelated | 1 (5.9%) | 1 (7.1%) | 2 (6.5%)
Injury, poisoning and procedural complications | Unrelated | 4 (23.5%) | 1 (7.1%) | 5 (16.1%)
Arthropod bite | Unrelated | 1 (5.9%) | 0 | 1 (3.2%)
Arthropod sting | Unrelated | 2 (11.8%) | 0 | 2 (6.5%)
Excoriation | Unrelated | 0 | 1 (7.1%) | 1 (3.2%)
Ligament sprain | Unrelated | 1 (5.9%) | 0 | 1 (3.2%)
Investigations | Unrelated | 1 (5.9%) | 0 | 1 (3.2%)
Investigations | Possibly related | 1 (5.9%) | 0 | 1 (3.2%)
Lymphocyte count decreased | Possibly related | 1 (5.9%) | 0 | 1 (3.2%)
Protein urine present | Unrelated | 1 (5.9%) | 0 | 1 (3.2%)
Protein urine present | Possibly related | 1 (5.9%) | 0 | 1 (3.2%)
Urine ketone body present | Unrelated | 1 (5.9%) | 0 | 1 (3.2%)
Metabolism and nutrition disorders | Unrelated | 0 | 1 (7.1%) | 1 (3.2%)
Metabolism and nutrition disorders | Possibly related | 2 (11.8%) | 2 (14.3%) | 4 (12.9%)
Decreased appetite | Unrelated | 0 | 1 (7.1%) | 1 (3.2%)
Decreased appetite | Possibly related | 2 (11.8%) | 1 (7.1%) | 3 (9.7%)
Increased appetite | Possibly related | 0 | 1 (7.1%) | 1 (3.2%)
Musculoskeletal and connective tissue disorders | Unrelated | 4 (23.5%) | 1 (7.1%) | 5 (16.1%)
Musculoskeletal and connective tissue disorders | Possibly related | 1 (5.9%) | 0 | 1 (3.2%)
Arthralgia | Unrelated | 1 (5.9%) | 1 (7.1%) | 2 (6.5%)
Back pain | Unrelated | 1 (5.9%) | 0 | 1 (3.2%)
Muscle twitching | Unrelated | 1 (5.9%) | 0 | 1 (3.2%)
Musculoskeletal pain | Unrelated | 1 (5.9%) | 0 | 1 (3.2%)
Pain in extremity | Possibly related | 1 (5.9%) | 0 | 1 (3.2%)
Nervous system disorders | Unrelated | 3 (17.6%) | 2 (14.3%) | 5 (16.1%)
Nervous system disorders | Possibly related | 4 (23.5%) | 2 (14.3%) | 6 (19.4%)
Nervous system disorders | Probably related | 1 (5.9%) | 0 | 1 (3.2%)
Disturbance in attention | Possibly related | 1 (5.9%) | 0 | 1 (3.2%)
Dizziness | Unrelated | 1 (5.9%) | 0 | 1 (3.2%)
Dizziness | Possibly related | 1 (5.9%) | 0 | 1 (3.2%)
Headache | Unrelated | 2 (11.8%) | 2 (14.3%) | 4 (12.9%)
Headache | Possibly related | 4 (23.5%) | 2 (14.3%) | 6 (19.4%)
Sedation | Unrelated | 1 (5.9%) | 0 | 1 (3.2%)
Sinus headache | Unrelated | 1 (5.9%) | 0 | 1 (3.2%)
Somnolence | Possibly related | 0 | 1 (7.1%) | 1 (3.2%)
Tremor | Probably related | 1 (5.9%) | 0 | 1 (3.2%)
Psychiatric disorders | Unrelated | 1 (5.9%) | 1 (7.1%) | 2 (6.5%)
Psychiatric disorders | Possibly related | 4 (23.5%) | 2 (14.3%) | 6 (19.4%)
Aggression | Possibly related | 1 (5.9%) | 0 | 1 (3.2%)
Depression | Possibly related | 1 (5.9%) | 0 | 1 (3.2%)
Initial insomnia | Unrelated | 1 (5.9%) | 0 | 1 (3.2%)
Initial insomnia | Possibly related | 2 (11.8%) | 2 (14.3%) | 4 (12.9%)
Insomnia | Possibly related | 1 (5.9%) | 0 | 1 (3.2%)
Panic attack | Unrelated | 0 | 1 (7.1%) | 1 (3.2%)
Somnambulism | Possibly related | 1 (5.9%) | 0 | 1 (3.2%)
Renal and urinary disorders | Possibly related | 3 (17.6%) | 0 | 3 (9.7%)
Renal and urinary disorders | Probably related | 1 (5.9%) | 0 | 1 (3.2%)
Enuresis | Possibly related | 3 (17.6%) | 0 | 3 (9.7%)
Enuresis | Probably related | 1 (5.9%) | 0 | 1 (3.2%)
Proteinuria | Possibly related | 1 (5.9%) | 0 | 1 (3.2%)
Respiratory, thoracic and mediastinal disorders | Unrelated | 3 (17.6%) | 1 (7.1%) | 4 (12.9%)
Cough | Unrelated | 1 (5.9%) | 0 | 1 (3.2%)
Epistaxis | Unrelated | 1 (5.9%) | 0 | 1 (3.2%)
Nasal congestion | Unrelated | 1 (5.9%) | 0 | 1 (3.2%)
Oropharyngeal pain | Unrelated | 1 (5.9%) | 1 (7.1%) | 2 (6.5%)
Skin and subcutaneous tissue disorders | Unrelated | 1 (5.9%) | 1 (7.1%) | 2 (6.5%)
Alopecia | Unrelated | 0 | 1 (7.1%) | 1 (3.2%)
Rash | Unrelated | 1 (5.9%) | 0 | 1 (3.2%)
Vascular disorders | Possibly related | 1 (5.9%) | 0 | 1 (3.2%)
Hot flush | Possibly related | 1 (5.9%) | 0 | 1 (3.2%)

Note: The percentages are based on the total number of safety participants in each treatment group or total.

Participants are counted once at each SOC and PT level, using the strongest relationship to study medication.

Table 14.3.1.4.4 Adverse Events by MedDRA System Organ Class, Preferred Term, Relationship to Study Medication and Discontinuation Phase Treatment Received Group Restabilization Phase - Safety Population

System Organ Class (SOC)/Preferred Term | Relationship | Discontinuation Phase Treatment Received Group | | Total; (N=13)
System Organ Class (SOC)/Preferred Term | Relationship | Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Gastrointestinal disorders | Unrelated | 1 (33.3%) | 2 (20.0%) | 3 (23.1%)
Gastrointestinal disorders | Possibly related | 1 (33.3%) | 3 (30.0%) | 4 (30.8%)
Abdominal pain lower | Possibly related | 0 | 1 (10.0%) | 1 (7.7%)
Abdominal pain upper | Unrelated | 1 (33.3%) | 0 | 1 (7.7%)
Abdominal pain upper | Possibly related | 0 | 2 (20.0%) | 2 (15.4%)
Diarrhoea | Unrelated | 1 (33.3%) | 0 | 1 (7.7%)
Dysphagia | Unrelated | 0 | 1 (10.0%) | 1 (7.7%)
Gastrooesophageal reflux disease | Unrelated | 0 | 2 (20.0%) | 2 (15.4%)
Nausea | Unrelated | 0 | 1 (10.0%) | 1 (7.7%)
Salivary hypersecretion | Possibly related | 0 | 1 (10.0%) | 1 (7.7%)
Vomiting | Unrelated | 0 | 1 (10.0%) | 1 (7.7%)
Vomiting | Possibly related | 1 (33.3%) | 0 | 1 (7.7%)
General disorders and administration site conditions | Unrelated | 0 | 1 (10.0%) | 1 (7.7%)
Fatigue | Unrelated | 0 | 1 (10.0%) | 1 (7.7%)
Infections and infestations | Unrelated | 1 (33.3%) | 2 (20.0%) | 3 (23.1%)
Nasopharyngitis | Unrelated | 1 (33.3%) | 1 (10.0%) | 2 (15.4%)
Viral infection | Unrelated | 0 | 1 (10.0%) | 1 (7.7%)
Injury, poisoning and procedural complications | Unrelated | 1 (33.3%) | 1 (10.0%) | 2 (15.4%)
Contusion | Unrelated | 1 (33.3%) | 0 | 1 (7.7%)
Post-traumatic pain | Unrelated | 0 | 1 (10.0%) | 1 (7.7%)
Investigations | Possibly related | 0 | 1 (10.0%) | 1 (7.7%)
Blood thyroid stimulating hormone increased | Possibly related | 0 | 1 (10.0%) | 1 (7.7%)
Blood urea nitrogen/creatinine ratio | Possibly related | 0 | 1 (10.0%) | 1 (7.7%)
Blood uric acid | Possibly related | 0 | 1 (10.0%) | 1 (7.7%)
Thyroglobulin | Possibly related | 0 | 1 (10.0%) | 1 (7.7%)
Nervous system disorders | Unrelated | 1 (33.3%) | 1 (10.0%) | 2 (15.4%)
Nervous system disorders | Possibly related | 0 | 4 (40.0%) | 4 (30.8%)
Headache | Unrelated | 1 (33.3%) | 1 (10.0%) | 2 (15.4%)
Headache | Possibly related | 0 | 2 (20.0%) | 2 (15.4%)
Somnolence | Possibly related | 0 | 1 (10.0%) | 1 (7.7%)
Tremor | Possibly related | 0 | 2 (20.0%) | 2 (15.4%)
Renal and urinary disorders | Possibly related | 1 (33.3%) | 0 | 1 (7.7%)
Enuresis | Possibly related | 1 (33.3%) | 0 | 1 (7.7%)

Note: The percentages are based on the total number of safety participants in each treatment group or total.

Participants are counted once at each SOC and PT level, using the strongest relationship to study medication.

Table 14.3.1.5.1 Serious Adverse Events by MedDRA System Organ Class, Preferred Term, Age Strata and Efficacy Phase Treatment Received Group Efficacy Phase - Safety Population

System Organ Class (SOC)/Preferred Term (PT) | 7 - 11 yrs | | 12 - 17 yrs | | Total
System Organ Class (SOC)/Preferred Term (PT) | Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Injury, poisoning and procedural complications | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Upper limb fracture | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Psychiatric disorders | 1 (3.1%) | 2 (11.8%) | 2 (9.5%) | 0 | 3 (5.7%) | 2 (7.1%)
Aggression | 1 (3.1%) | 1 (5.9%) | 0 | 0 | 1 (1.9%) | 1 (3.6%)
Bipolar disorder | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Hallucination, auditory | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Mood altered | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Suicidal ideation | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0

Note: The percentages are based on the total number of safety participants in each age strata/treatment group.

Participants are counted once at each SOC and PT level.

Table 14.3.1.5.2A Serious Adverse Events by MedDRA System Organ Class, Preferred Term and Age Strata Long-Term Effectiveness Phase - Safety Population

System Organ Class (SOC)/Preferred Term (PT) | Age Strata | | Total; (N=44)
System Organ Class (SOC)/Preferred Term (PT) | 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Psychiatric disorders | 0 | 2 (13.3%) | 2 (4.5%)
Self injurious behaviour | 0 | 1 (6.7%) | 1 (2.3%)
Suicide attempt | 0 | 1 (6.7%) | 1 (2.3%)

Note: The percentages are based on the total number of safety participants in each age strata or total.

Participants are counted once at each SOC and PT level.

Table 14.3.1.5.2B Serious Adverse Events by MedDRA System Organ Class, Preferred Term and Efficacy Phase Treatment Received Group Long-Term Effectiveness Phase - Safety Population

System Organ Class (SOC)/Preferred Term (PT) | Efficacy Phase Treatment Received Group | | Total; (N=44)
System Organ Class (SOC)/Preferred Term (PT) | Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Psychiatric disorders | 2 (6.9%) | 0 | 2 (4.5%)
Self injurious behaviour | 1 (3.4%) | 0 | 1 (2.3%)
Suicide attempt | 1 (3.4%) | 0 | 1 (2.3%)

Note: The percentages are based on the total number of safety participants in each treatment group or total.

Participants are counted once at each SOC and PT level.

Table 14.3.1.5.3 Serious Adverse Events by MedDRA System Organ Class, Preferred Term and Discontinuation Phase Treatment Received Group Discontinuation Phase - Safety Population

System Organ Class (SOC)/Preferred Term (PT) | Discontinuation Phase Treatment Received Group | | Total; (N=31)
System Organ Class (SOC)/Preferred Term (PT) | Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Psychiatric disorders | 1 (5.9%) | 0 | 1 (3.2%)
Aggression | 1 (5.9%) | 0 | 1 (3.2%)

Note: The percentages are based on the total number of safety participants in each treatment group or total.

Participants are counted once at each SOC and PT level.

Table 14.3.1.5.4 Serious Adverse Events by MedDRA System Organ Class, Preferred Term and Discontinuation Phase Treatment Received Group Restabilization Phase - Safety Population

No Serious Adverse Events were reported during this phase.

Table 14.3.1.6.1 Adverse Events that Led to Discontinuation of Study Drug by Age Strata and Efficacy Phase Treatment Received Group Efficacy Phase - Safety Population

System Organ Class (SOC)/Preferred Term | 7 - 11 yrs | | 12 - 17 yrs | | Total
System Organ Class (SOC)/Preferred Term | Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Number of Participants | 2 (6.3%) | 2 (11.8%) | 4 (19.0%) | 0 | 6 (11.3%) | 2 (7.1%)
Gastrointestinal disorders | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Nausea | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Nervous system disorders | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Hypotonia | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Sedation | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Tremor | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Psychiatric disorders | 2 (6.3%) | 2 (11.8%) | 4 (19.0%) | 0 | 6 (11.3%) | 2 (7.1%)
Aggression | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Agitation | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Bipolar disorder | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.6%)
Hallucination, auditory | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Mood altered | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Psychotic disorder | 1 (3.1%) | 0 | 0 | 0 | 1 (1.9%) | 0
Suicidal behaviour | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Suicidal ideation | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0

Note: The percentages are based on the total number of safety participants in each age/treatment group.

Participants are counted once at each SOC and PT level.

Includes temporarily stopped product, permanently stopped product or terminated study.

Table 14.3.1.6.2A Adverse Events that Led to Discontinuation of Study Drug by Age Strata Long-Term Effectiveness Phase - Safety Population

System Organ Class (SOC)/Preferred Term (PT) | Age Strata | | Total; (N=44)
System Organ Class (SOC)/Preferred Term (PT) | 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Number of Participants | 3 (10.3%) | 2 (13.3%) | 5 (11.4%)
Gastrointestinal disorders | 2 (6.9%) | 0 | 2 (4.5%)
Vomiting | 2 (6.9%) | 0 | 2 (4.5%)
Infections and infestations | 1 (3.4%) | 0 | 1 (2.3%)
Gastroenteritis | 1 (3.4%) | 0 | 1 (2.3%)
Psychiatric disorders | 0 | 2 (13.3%) | 2 (4.5%)
Self injurious behaviour | 0 | 1 (6.7%) | 1 (2.3%)
Suicide attempt | 0 | 1 (6.7%) | 1 (2.3%)

Note: The percentages are based on the total number of safety participants in each age strata or total.

Participants are counted once at each SOC and PT level.

Includes temporarily stopped product, permanently stopped product or terminated study.

Participant [▬] terminated the study due to the AE described as suicide attempt, action taken with study product is changed from no action to study termination for this table.

Table 14.3.1.6.2B Adverse Events that Led to Discontinuation of Study Drug by Efficacy Phase Treatment Received Group Long-Term Effectiveness Phase - Safety Population

System Organ Class (SOC)/Preferred Term (PT) | Efficacy Phase Treatment Received Group | | Total; (N=44)
System Organ Class (SOC)/Preferred Term (PT) | Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Number of Participants | 2 (6.9%) | 3 (20.0%) | 5 (11.4%)
Gastrointestinal disorders | 0 | 2 (13.3%) | 2 (4.5%)
Vomiting | 0 | 2 (13.3%) | 2 (4.5%)
Infections and infestations | 0 | 1 (6.7%) | 1 (2.3%)
Gastroenteritis | 0 | 1 (6.7%) | 1 (2.3%)
Psychiatric disorders | 2 (6.9%) | 0 | 2 (4.5%)
Self injurious behaviour | 1 (3.4%) | 0 | 1 (2.3%)
Suicide attempt | 1 (3.4%) | 0 | 1 (2.3%)

Note: The percentages are based on the total number of safety participants in each treatment group or total.

Participants are counted once at each SOC and PT level.

Includes temporarily stopped product, permanently stopped product or terminated study.

Participant ▬ terminated the study due to the AE described as suicide attempt, action taken with study product is changed from no action to study termination for this table.

Table 14.3.1.6.3 Adverse Events that Led to Discontinuation of Study Drug by Discontinuation Phase Treatment Received Group Discontinuation Phase - Safety Population

System Organ Class (SOC)/Preferred Term (PT) | Discontinuation Phase Treatment Received Group | | Total; (N=31)
System Organ Class (SOC)/Preferred Term (PT) | Lithium; (N=14) | Placebo; (N=17) | Total; (N=31)
Psychiatric disorders | 1 (5.9%) | 0 | 1 (3.2%)
Aggression | 1 (5.9%) | 0 | 1 (3.2%)

Note: The percentages are based on the total number of safety participants in each treatment group or total.

Participants are counted once at each SOC and PT level.

Includes temporarily stopped product, permanently stopped product or terminated study.

Table 14.3.1.6.4 Adverse Events that Led to Discontinuation of Study Drug by Discontinuation Phase Treatment Received Group Restabilization Phase - Safety Population

No Adverse Events were reported that led to discontinuation of study drug during this phase.

Table 14.3.1.7.1 Deaths by MedDRA System Organ Class, Preferred Term, Age Strata and Treatment Received Group Efficacy Phase - Safety Population

No deaths were reported during this phase.

Table 14.3.1.7.2A Deaths by MedDRA System Organ Class, Preferred Term and Age Strata Long-Term Effectiveness Phase - Safety Population

No deaths were reported during this phase.

Table 14.3.1.7.2B Deaths by MedDRA System Organ Class, Preferred Term and Efficacy Phase Treatment Received Group Long-Term Effectiveness Phase - Safety Population

No deaths were reported during this phase.

Table 14.3.1.7.3 Deaths by MedDRA System Organ Class, Preferred Term and Discontinuation Phase Treatment Received Group Discontinuation Phase - Safety Population

No deaths were reported during this phase.

Table 14.3.1.7.4 Deaths by MedDRA System Organ Class, Preferred Term and Discontinuation Phase Treatment Received Group Restabilization Phase - Safety Population

No deaths were reported during this phase.

Table 14.3.2.1.1 Concomitant Medications Used During the Efficacy Phase by Age Strata and Efficacy Phase Treatment Received Group Efficacy Phase - Safety Population

WHO Class; Medication Name | 7-11 years | | | | 12-17 years | | | | Total
WHO Class; Medication Name | Lithium; (N=32) | | Placebo; (N=17) | | Lithium; (N=21) | | Placebo; (N=11) | | Lithium; (N=53) | | Placebo; (N=28)
WHO Class; Medication Name | Pts With Medn; N (%) | Total Medns; N | Pts With Medn; N (%) | Total Medns; N | Pts With Medn; N (%) | Total Medns; N | Pts With Medn; N (%) | Total Medns; N | Pts With Medn; N (%) | Total Medns; N | Pts With Medn; N (%) | Total Medns; N
ALIMENTARY TRACT AND METABOLISM | 9 (28.1%) | 19 | 3 (17.6%) | 4 | 1 (4.8%) | 1 | 0 | 0 | 10 (18.9%) | 20 | 3 (10.7%) | 4
BISACODYL | 2 (6.3%) | 5 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (3.8%) | 5 | 0 | 0
BISMUTH SUBSALICYLATE | 3 (9.4%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (5.7%) | 3 | 0 | 0
CALCIUM | 1 (3.1%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1 | 0 | 0
COLECALCIFEROL | 0 | 0 | 1 (5.9%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.6%) | 1
FAMOTIDINE | 1 (3.1%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1 | 0 | 0
LACTOBACILLUS ACIDOPHILUS | 0 | 0 | 1 (5.9%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.6%) | 1
MACROGOL | 1 (3.1%) | 2 | 1 (5.9%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 2 | 1 (3.6%) | 1
MULTIVITAMIN /05516001/ | 3 (9.4%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (5.7%) | 3 | 0 | 0
MULTIVITAMINS | 0 | 0 | 1 (5.9%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.6%) | 1
OMEPRAZOLE | 1 (3.1%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1 | 0 | 0
ONDANSETRON HYDROCHLORIDE | 0 | 0 | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 1 (1.9%) | 1 | 0 | 0
RANITIDINE | 1 (3.1%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1 | 0 | 0
TUMS /00193601/ | 2 (6.3%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2 | 0 | 0
ANTIINFECTIVES FOR SYSTEMIC USE | 1 (3.1%) | 2 | 3 (17.6%) | 3 | 2 (9.5%) | 2 | 2 (18.2%) | 2 | 3 (5.7%) | 4 | 5 (17.9%) | 5
AMOXICILLIN | 1 (3.1%) | 1 | 3 (17.6%) | 3 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1 | 3 (10.7%) | 3
BACTRIM | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (3.6%) | 1
CEFOTAXIME SODIUM | 1 (3.1%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1 | 0 | 0
HUMAN PAPILLOMA VACCINE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (3.6%) | 1
INFLUENZA VACCINE | 0 | 0 | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 1 (1.9%) | 1 | 0 | 0
NITROFURANTOIN | 0 | 0 | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 1 (1.9%) | 1 | 0 | 0
DERMATOLOGICALS | 6 (18.8%) | 12 | 1 (5.9%) | 1 | 3 (14.3%) | 3 | 0 | 0 | 9 (17%) | 15 | 1 (3.6%) | 1
AMMONIUM LACTATE | 0 | 0 | 1 (5.9%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.6%) | 1
AQUAPHOR /01181901/ | 1 (3.1%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1 | 0 | 0
CETAPHIL /02314901/ | 1 (3.1%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 2 | 0 | 0
DESONIDE | 1 (3.1%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 2 | 0 | 0
EMLA /00675501/ | 2 (6.3%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2 | 0 | 0
GRISEOFULVIN | 1 (3.1%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 2 | 0 | 0
HYDROCORTISONE | 1 (3.1%) | 1 | 0 | 0 | 3 (14.3%) | 3 | 0 | 0 | 4 (7.5%) | 4 | 0 | 0
NEOSPORIN /00130801/ | 1 (3.1%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1 | 0 | 0
TRIAMCINOLONE | 1 (3.1%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1 | 0 | 0
GENITO URINARY SYSTEM AND SEX HORMONES | 0 | 0 | 0 | 0 | 3 (14.3%) | 3 | 3 (27.3%) | 4 | 3 (5.7%) | 3 | 3 (10.7%) | 4
CONTRACEPTIVES | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (3.6%) | 1
MARVELON | 0 | 0 | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 1 (1.9%) | 1 | 0 | 0
MEDROXYPROGESTERONE ACETATE | 0 | 0 | 0 | 0 | 0 | 0 | 2 (18.2%) | 3 | 0 | 0 | 2 (7.1%) | 3
NORETHISTERONE | 0 | 0 | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 1 (1.9%) | 1 | 0 | 0
OXYBUTYNIN | 0 | 0 | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 1 (1.9%) | 1 | 0 | 0
MUSCULO-SKELETAL SYSTEM | 2 (6.3%) | 2 | 1 (5.9%) | 1 | 0 | 0 | 4 (36.4%) | 5 | 2 (3.8%) | 2 | 5 (17.9%) | 6
IBUPROFEN | 2 (6.3%) | 2 | 1 (5.9%) | 1 | 0 | 0 | 3 (27.3%) | 4 | 2 (3.8%) | 2 | 4 (14.3%) | 5
NAPROXEN SODIUM | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (3.6%) | 1
NERVOUS SYSTEM | 11 (34.4%) | 25 | 6 (35.3%) | 10 | 8 (38.1%) | 15 | 2 (18.2%) | 2 | 19 (35.8%) | 40 | 8 (28.6%) | 12
BUTORPHANOL | 1 (3.1%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1 | 0 | 0
DOZOL | 1 (3.1%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1 | 0 | 0
PARACETAMOL | 10 (31.3%) | 23 | 5 (29.4%) | 9 | 7 (33.3%) | 12 | 2 (18.2%) | 2 | 17 (32.1%) | 35 | 7 (25%) | 11
VICKS FORMULA 44M /01056501/ | 0 | 0 | 1 (5.9%) | 1 | 2 (9.5%) | 2 | 0 | 0 | 2 (3.8%) | 2 | 1 (3.6%) | 1
VICODIN | 0 | 0 | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 1 (1.9%) | 1 | 0 | 0
RESPIRATORY SYSTEM | 11 (34.4%) | 20 | 2 (11.8%) | 2 | 6 (28.6%) | 11 | 2 (18.2%) | 4 | 17 (32.1%) | 31 | 4 (14.3%) | 6
BENADRYL /01563701/ | 1 (3.1%) | 1 | 0 | 0 | 2 (9.5%) | 2 | 0 | 0 | 3 (5.7%) | 3 | 0 | 0
CETIRIZINE HYDROCHLORIDE | 2 (6.3%) | 2 | 1 (5.9%) | 1 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2 | 1 (3.6%) | 1
COUGH SYRUP | 0 | 0 | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 1 (1.9%) | 1 | 0 | 0
DEXTROMETHORPHAN | 1 (3.1%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1 | 0 | 0
DEXTROMETHORPHAN W/PHENYLEPHRINE | 0 | 0 | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 1 (1.9%) | 1 | 0 | 0
DIPHENHYDRAMINE | 1 (3.1%) | 2 | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 2 (3.8%) | 3 | 0 | 0
FEXOFENADINE HYDROCHLORIDE | 1 (3.1%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1 | 0 | 0
FLUTICASONE | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 1 | 0 | 0 | 1 (3.6%) | 1
FLUTICASONE PROPIONATE | 1 (3.1%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1 | 0 | 0
GUAIFENESIN | 2 (6.3%) | 2 | 0 | 0 | 1 (4.8%) | 2 | 0 | 0 | 3 (5.7%) | 4 | 0 | 0
LORATADINE | 2 (6.3%) | 2 | 0 | 0 | 1 (4.8%) | 1 | 1 (9.1%) | 1 | 3 (5.7%) | 3 | 1 (3.6%) | 1
MONTELUKAST SODIUM | 3 (9.4%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (5.7%) | 3 | 0 | 0
PROCATEROL HYDROCHLORIDE | 3 (9.4%) | 3 | 0 | 0 | 0 | 0 | 0 | 0 | 3 (5.7%) | 3 | 0 | 0
ROBITUSSIN /00288801/ | 0 | 0 | 0 | 0 | 0 | 0 | 1 (9.1%) | 2 | 0 | 0 | 1 (3.6%) | 2
SALBUTAMOL | 1 (3.1%) | 1 | 0 | 0 | 1 (4.8%) | 2 | 0 | 0 | 2 (3.8%) | 3 | 0 | 0
TRIAMINIC EXPECTORANT /00539501/ | 1 (3.1%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1 | 0 | 0
TUSSIN /03054701/ | 0 | 0 | 1 (5.9%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.6%) | 1
VICK VAPOUR-RUB | 0 | 0 | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 1 (1.9%) | 1 | 0 | 0
SENSORY ORGANS | 0 | 0 | 2 (11.8%) | 2 | 0 | 0 | 0 | 0 | 0 | 0 | 2 (7.1%) | 2
OFLOXACIN | 0 | 0 | 1 (5.9%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.6%) | 1
TOBRAMYCIN | 0 | 0 | 1 (5.9%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (3.6%) | 1
SYSTEMIC HORMONAL PREPARATIONS, EXCL. SEX HORMONES AND INSULINS | 1 (3.1%) | 1 | 0 | 0 | 2 (9.5%) | 2 | 0 | 0 | 3 (5.7%) | 3 | 0 | 0
LEVOTHYROXINE | 1 (3.1%) | 1 | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 2 (3.8%) | 2 | 0 | 0
LEVOTHYROXINE SODIUM | 0 | 0 | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 1 (1.9%) | 1 | 0 | 0

Note: The percentages are based on the total number of safety participants in each age/treatment group..

Pts = Participants; Medn = medication; Medns = medications;

Participants are counted once at each WHO Class (ATC1 level) and medication name.

Table 14.3.2.1.2A Concomitant Medications Used During the Long-Term Effectiveness Phase by Age Strata Long-Term Effectiveness Phase - Safety Population

WHO Class; Medication Name | 7 - 11 yrs; (N=29) | | 12 - 17 yrs; (N=15) | | Total; (N=44)
WHO Class; Medication Name | Pts With Medn; N (%) | Total Medns; N | Pts With Medn; N (%) | Total Medns; N | Pts With Medn; N (%) | Total Medns; N
ALIMENTARY TRACT AND METABOLISM | 9 (31%) | 23 | 2 (13.3%) | 3 | 11 (25%) | 26
ASCORBIC ACID | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
BISACODYL | 1 (3.4%) | 2 | 0 | 0 | 1 (2.3%) | 2
BISMUTH SUBSALICYLATE | 4 (13.8%) | 4 | 0 | 0 | 4 (9.1%) | 4
COLECALCIFEROL | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
DICYCLOVERINE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
DOCUSATE W/SENNOSIDE A+B | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
FAMOTIDINE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
MACROGOL | 2 (6.9%) | 7 | 0 | 0 | 2 (4.5%) | 7
MAGNESIUM HYDROXIDE | 0 | 0 | 1 (6.7%) | 2 | 1 (2.3%) | 2
MULTIVITAMIN /05516001/ | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
ONDANSETRON | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
SIMETICONE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
SUCRALFATE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
TUMS /00193601/ | 1 (3.4%) | 1 | 1 (6.7%) | 1 | 2 (4.5%) | 2
ANTIINFECTIVES FOR SYSTEMIC USE | 10 (34.5%) | 14 | 0 | 0 | 10 (22.7%) | 14
AMOXICILLIN | 6 (20.7%) | 8 | 0 | 0 | 6 (13.6%) | 8
AZITHROMYCIN | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
BENZYLPENICILLIN | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
CEFDINIR | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
CEFRADINE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
INFLUENZA VACCINE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
OSELTAMIVIR PHOSPHATE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
DERMATOLOGICALS | 6 (20.7%) | 13 | 0 | 0 | 6 (13.6%) | 13
AMMONIUM LACTATE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
AQUAPHOR /01181901/ | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
CALAMINE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
CETAPHIL /02314901/ | 1 (3.4%) | 2 | 0 | 0 | 1 (2.3%) | 2
DESONIDE | 1 (3.4%) | 2 | 0 | 0 | 1 (2.3%) | 2
DIPHENHYDRAMINE HYDROCHLORIDE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
EMLA /00675501/ | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
GRISEOFULVIN | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
NEOSPORIN /00130801/ | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
PREDNISOLONE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
TRIAMCINOLONE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
GENITO URINARY SYSTEM AND SEX HORMONES | 1 (3.4%) | 1 | 2 (13.3%) | 2 | 3 (6.8%) | 3
MARVELON | 0 | 0 | 1 (6.7%) | 1 | 1 (2.3%) | 1
NYSTATIN | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
OXYBUTYNIN | 0 | 0 | 1 (6.7%) | 1 | 1 (2.3%) | 1
MUSCULO-SKELETAL SYSTEM | 0 | 0 | 1 (6.7%) | 1 | 1 (2.3%) | 1
NAPROXEN | 0 | 0 | 1 (6.7%) | 1 | 1 (2.3%) | 1
NERVOUS SYSTEM | 11 (37.9%) | 27 | 10 (66.7%) | 21 | 21 (47.7%) | 48
DIMENHYDRINATE | 0 | 0 | 1 (6.7%) | 1 | 1 (2.3%) | 1
MIDOL /00095101/ | 0 | 0 | 1 (6.7%) | 1 | 1 (2.3%) | 1
PARACETAMOL | 10 (34.5%) | 26 | 10 (66.7%) | 18 | 20 (45.5%) | 44
VICKS FORMULA 44M /01056501/ | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
VICODIN | 0 | 0 | 1 (6.7%) | 1 | 1 (2.3%) | 1
RESPIRATORY SYSTEM | 14 (48.3%) | 36 | 3 (20%) | 4 | 17 (38.6%) | 40
BENADRYL /01563701/ | 3 (10.3%) | 4 | 1 (6.7%) | 1 | 4 (9.1%) | 5
CETIRIZINE HYDROCHLORIDE | 3 (10.3%) | 4 | 0 | 0 | 3 (6.8%) | 4
CHLORPHENAMINE W/DEXTROMETHORPHAN | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
DALLERGY /07736901/ | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
DEXTROMETHORPHAN | 0 | 0 | 1 (6.7%) | 1 | 1 (2.3%) | 1
DIMETAPP /00127601/ | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
FEXOFENADINE HYDROCHLORIDE | 1 (3.4%) | 2 | 0 | 0 | 1 (2.3%) | 2
FLUTICASONE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
FLUTICASONE PROPIONATE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
GUAIFENESIN | 1 (3.4%) | 2 | 1 (6.7%) | 1 | 2 (4.5%) | 3
GUAIFENESIN W/DEXTROMETHORPHAN | 1 (3.4%) | 3 | 0 | 0 | 1 (2.3%) | 3
LORATADINE | 3 (10.3%) | 3 | 0 | 0 | 3 (6.8%) | 3
MONTELUKAST SODIUM | 2 (6.9%) | 2 | 0 | 0 | 2 (4.5%) | 2
PROCATEROL HYDROCHLORIDE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
PROMETHAZINE - CODEINE /02239701/ | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
ROBITUSSIN /00288801/ | 0 | 0 | 1 (6.7%) | 1 | 1 (2.3%) | 1
SALBUTAMOL | 4 (13.8%) | 5 | 0 | 0 | 4 (9.1%) | 5
TRIAMINIC EXPECTORANT /00539501/ | 2 (6.9%) | 2 | 0 | 0 | 2 (4.5%) | 2
VICKS FORMULA 44 /02685101/ | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
ZINC | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
SENSORY ORGANS | 2 (6.9%) | 2 | 0 | 0 | 2 (4.5%) | 2
OFLOXACIN | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
POLYMYXIN B | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
SYSTEMIC HORMONAL PREPARATIONS, EXCL. SEX HORMONES AND INSULINS | 4 (13.8%) | 4 | 3 (20%) | 3 | 7 (15.9%) | 7
DESMOPRESSIN | 0 | 0 | 1 (6.7%) | 1 | 1 (2.3%) | 1
LEVOTHYROXINE | 2 (6.9%) | 2 | 1 (6.7%) | 1 | 3 (6.8%) | 3
LEVOTHYROXINE SODIUM | 1 (3.4%) | 1 | 1 (6.7%) | 1 | 2 (4.5%) | 2
PREDNISONE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1

Note: The percentages are based on the total number of safety participants in each treatment group or total.

Pts = Participants; Medn = medication; Medns = medications;

Participants are counted once at each WHO Class (ATC1 level) and medication name.

Table 14.3.2.1.2B Concomitant Medications Used During the Long-Term Effectiveness Phase by Efficacy Phase Treatment Received Group Long-Term Effectiveness Phase - Safety Population

WHO Class; Medication Name | Lithium; (N=29) | | Placebo; (N=15) | | Total; (N=44)
WHO Class; Medication Name | Pts With Medn; N (%) | Total Medns; N | Pts With Medn; N (%) | Total Medns; N | Pts With Medn; N (%) | Total Medns; N
ALIMENTARY TRACT AND METABOLISM | 7 (24.1%) | 20 | 4 (26.7%) | 6 | 11 (25%) | 26
ASCORBIC ACID | 0 | 0 | 1 (6.7%) | 1 | 1 (2.3%) | 1
BISACODYL | 1 (3.4%) | 2 | 0 | 0 | 1 (2.3%) | 2
BISMUTH SUBSALICYLATE | 2 (6.9%) | 2 | 2 (13.3%) | 2 | 4 (9.1%) | 4
COLECALCIFEROL | 0 | 0 | 1 (6.7%) | 1 | 1 (2.3%) | 1
DICYCLOVERINE | 0 | 0 | 1 (6.7%) | 1 | 1 (2.3%) | 1
DOCUSATE W/SENNOSIDE A+B | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
FAMOTIDINE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
MACROGOL | 2 (6.9%) | 7 | 0 | 0 | 2 (4.5%) | 7
MAGNESIUM HYDROXIDE | 1 (3.4%) | 2 | 0 | 0 | 1 (2.3%) | 2
MULTIVITAMIN /05516001/ | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
ONDANSETRON | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
SIMETICONE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
SUCRALFATE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
TUMS /00193601/ | 1 (3.4%) | 1 | 1 (6.7%) | 1 | 2 (4.5%) | 2
ANTIINFECTIVES FOR SYSTEMIC USE | 7 (24.1%) | 10 | 3 (20%) | 4 | 10 (22.7%) | 14
AMOXICILLIN | 4 (13.8%) | 6 | 2 (13.3%) | 2 | 6 (13.6%) | 8
AZITHROMYCIN | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
BENZYLPENICILLIN | 0 | 0 | 1 (6.7%) | 1 | 1 (2.3%) | 1
CEFDINIR | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
CEFRADINE | 0 | 0 | 1 (6.7%) | 1 | 1 (2.3%) | 1
INFLUENZA VACCINE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
OSELTAMIVIR PHOSPHATE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
DERMATOLOGICALS | 4 (13.8%) | 11 | 2 (13.3%) | 2 | 6 (13.6%) | 13
AMMONIUM LACTATE | 0 | 0 | 1 (6.7%) | 1 | 1 (2.3%) | 1
AQUAPHOR /01181901/ | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
CALAMINE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
CETAPHIL /02314901/ | 1 (3.4%) | 2 | 0 | 0 | 1 (2.3%) | 2
DESONIDE | 1 (3.4%) | 2 | 0 | 0 | 1 (2.3%) | 2
DIPHENHYDRAMINE HYDROCHLORIDE | 0 | 0 | 1 (6.7%) | 1 | 1 (2.3%) | 1
EMLA /00675501/ | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
GRISEOFULVIN | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
NEOSPORIN /00130801/ | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
PREDNISOLONE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
TRIAMCINOLONE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
GENITO URINARY SYSTEM AND SEX HORMONES | 3 (10.3%) | 3 | 0 | 0 | 3 (6.8%) | 3
MARVELON | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
NYSTATIN | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
OXYBUTYNIN | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
MUSCULO-SKELETAL SYSTEM | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
NAPROXEN | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
NERVOUS SYSTEM | 13 (44.8%) | 32 | 8 (53.3%) | 16 | 21 (47.7%) | 48
DIMENHYDRINATE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
MIDOL /00095101/ | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
PARACETAMOL | 13 (44.8%) | 29 | 7 (46.7%) | 15 | 20 (45.5%) | 44
VICKS FORMULA 44M /01056501/ | 0 | 0 | 1 (6.7%) | 1 | 1 (2.3%) | 1
VICODIN | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
RESPIRATORY SYSTEM | 13 (44.8%) | 31 | 4 (26.7%) | 9 | 17 (38.6%) | 40
BENADRYL /01563701/ | 2 (6.9%) | 2 | 2 (13.3%) | 3 | 4 (9.1%) | 5
CETIRIZINE HYDROCHLORIDE | 2 (6.9%) | 2 | 1 (6.7%) | 2 | 3 (6.8%) | 4
CHLORPHENAMINE W/DEXTROMETHORPHAN | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
DALLERGY /07736901/ | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
DEXTROMETHORPHAN | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
DIMETAPP /00127601/ | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
FEXOFENADINE HYDROCHLORIDE | 1 (3.4%) | 2 | 0 | 0 | 1 (2.3%) | 2
FLUTICASONE | 0 | 0 | 1 (6.7%) | 1 | 1 (2.3%) | 1
FLUTICASONE PROPIONATE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
GUAIFENESIN | 2 (6.9%) | 3 | 0 | 0 | 2 (4.5%) | 3
GUAIFENESIN W/DEXTROMETHORPHAN | 1 (3.4%) | 3 | 0 | 0 | 1 (2.3%) | 3
LORATADINE | 2 (6.9%) | 2 | 1 (6.7%) | 1 | 3 (6.8%) | 3
MONTELUKAST SODIUM | 2 (6.9%) | 2 | 0 | 0 | 2 (4.5%) | 2
PROCATEROL HYDROCHLORIDE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
PROMETHAZINE - CODEINE /02239701/ | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
ROBITUSSIN /00288801/ | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
SALBUTAMOL | 4 (13.8%) | 5 | 0 | 0 | 4 (9.1%) | 5
TRIAMINIC EXPECTORANT /00539501/ | 2 (6.9%) | 2 | 0 | 0 | 2 (4.5%) | 2
VICKS FORMULA 44 /02685101/ | 0 | 0 | 1 (6.7%) | 1 | 1 (2.3%) | 1
ZINC | 0 | 0 | 1 (6.7%) | 1 | 1 (2.3%) | 1
SENSORY ORGANS | 2 (6.9%) | 2 | 0 | 0 | 2 (4.5%) | 2
OFLOXACIN | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
POLYMYXIN B | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
SYSTEMIC HORMONAL PREPARATIONS, EXCL. SEX HORMONES AND INSULINS | 6 (20.7%) | 6 | 1 (6.7%) | 1 | 7 (15.9%) | 7
DESMOPRESSIN | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
LEVOTHYROXINE | 2 (6.9%) | 2 | 1 (6.7%) | 1 | 3 (6.8%) | 3
LEVOTHYROXINE SODIUM | 2 (6.9%) | 2 | 0 | 0 | 2 (4.5%) | 2
PREDNISONE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1

Note: The percentages are based on the total number of safety participants in each age strata or total.

Pts = Participants; Medn = medication; Medns = medications;

Participants are counted once at each WHO Class (ATC1 level) and medication name.

Table 14.3.2.1.3 Concomitant Medications Used During the Discontinuation Phase by Discontinuation Phase Treatment Received Group Discontinuation Phase - Safety Population

WHO Class; Medication Name | Discontinuation Phase Treatment Received Group | | | | Total; (N=31)
WHO Class; Medication Name | Lithium; (N=17) | | Placebo; (N=14) | | Total; (N=31)
WHO Class; Medication Name | Pts With Medn; N (%) | Total Medns; N | Pts With Medn; N (%) | Total Medns; N | Pts With Medn; N (%) | Total Medns; N
ALIMENTARY TRACT AND METABOLISM | 3 (17.6%) | 10 | 2 (14.3%) | 2 | 5 (16.1%) | 12
BISMUTH SUBSALICYLATE | 0 | 0 | 1 (7.1%) | 1 | 1 (3.2%) | 1
CAMALOX | 1 (5.9%) | 8 | 0 | 0 | 1 (3.2%) | 8
ESOMEPRAZOLE MAGNESIUM | 1 (5.9%) | 1 | 0 | 0 | 1 (3.2%) | 1
MACROGOL | 0 | 0 | 1 (7.1%) | 1 | 1 (3.2%) | 1
MULTIVITAMINS | 1 (5.9%) | 1 | 0 | 0 | 1 (3.2%) | 1
ANTIINFECTIVES FOR SYSTEMIC USE | 3 (17.6%) | 7 | 1 (7.1%) | 1 | 4 (12.9%) | 8
AMOXICILLIN | 2 (11.8%) | 3 | 0 | 0 | 2 (6.5%) | 3
AMOXICILLIN W/CLAVULANATE POTASSIUM | 1 (5.9%) | 1 | 0 | 0 | 1 (3.2%) | 1
CEFALEXIN | 1 (5.9%) | 1 | 0 | 0 | 1 (3.2%) | 1
CEFDINIR | 2 (11.8%) | 2 | 0 | 0 | 2 (6.5%) | 2
HUMAN PAPILLOMA VACCINE | 0 | 0 | 1 (7.1%) | 1 | 1 (3.2%) | 1
DERMATOLOGICALS | 4 (23.5%) | 7 | 0 | 0 | 4 (12.9%) | 7
BENZOYL PEROXIDE | 1 (5.9%) | 1 | 0 | 0 | 1 (3.2%) | 1
EMOLLIENTS AND PROTECTIVES | 1 (5.9%) | 2 | 0 | 0 | 1 (3.2%) | 2
MOMETASONE | 1 (5.9%) | 2 | 0 | 0 | 1 (3.2%) | 2
OTHER ANTIBIOTICS FOR TOPICAL USE | 1 (5.9%) | 1 | 0 | 0 | 1 (3.2%) | 1
TRIAMCINOLONE | 1 (5.9%) | 1 | 0 | 0 | 1 (3.2%) | 1
GENITO URINARY SYSTEM AND SEX HORMONES | 1 (5.9%) | 1 | 1 (7.1%) | 1 | 2 (6.5%) | 2
DROSPIRENONE W/ETHINYLESTRADIOL | 0 | 0 | 1 (7.1%) | 1 | 1 (3.2%) | 1
OXYBUTYNIN | 1 (5.9%) | 1 | 0 | 0 | 1 (3.2%) | 1
MUSCULO-SKELETAL SYSTEM | 1 (5.9%) | 1 | 0 | 0 | 1 (3.2%) | 1
IBUPROFEN | 1 (5.9%) | 1 | 0 | 0 | 1 (3.2%) | 1
NERVOUS SYSTEM | 3 (17.6%) | 6 | 6 (42.9%) | 7 | 9 (29%) | 13
ACETAMINOPHEN W/CODEINE | 0 | 0 | 1 (7.1%) | 1 | 1 (3.2%) | 1
ANILIDES | 1 (5.9%) | 2 | 0 | 0 | 1 (3.2%) | 2
PARACETAMOL | 2 (11.8%) | 4 | 4 (28.6%) | 5 | 6 (19.4%) | 9
ZOLPIDEM TARTRATE | 0 | 0 | 1 (7.1%) | 1 | 1 (3.2%) | 1
RESPIRATORY SYSTEM | 6 (35.3%) | 14 | 3 (21.4%) | 4 | 9 (29%) | 18
CETIRIZINE HYDROCHLORIDE | 0 | 0 | 2 (14.3%) | 2 | 2 (6.5%) | 2
COUGH AND COLD PREPARATIONS | 1 (5.9%) | 2 | 0 | 0 | 1 (3.2%) | 2
DEXTROMETHORPHAN HYDROBROMIDE | 1 (5.9%) | 1 | 0 | 0 | 1 (3.2%) | 1
DIPHENHYDRAMINE HYDROCHLORIDE | 2 (11.8%) | 2 | 1 (7.1%) | 1 | 3 (9.7%) | 3
HYDROXYZINE | 1 (5.9%) | 1 | 0 | 0 | 1 (3.2%) | 1
LORATADINE | 1 (5.9%) | 1 | 0 | 0 | 1 (3.2%) | 1
MOMETASONE FUROATE | 1 (5.9%) | 1 | 0 | 0 | 1 (3.2%) | 1
MONTELUKAST SODIUM | 1 (5.9%) | 1 | 0 | 0 | 1 (3.2%) | 1
NASAL PREPARATIONS | 1 (5.9%) | 2 | 0 | 0 | 1 (3.2%) | 2
OTHER RESPIRATORY SYSTEM PRODUCTS | 1 (5.9%) | 1 | 0 | 0 | 1 (3.2%) | 1
PHENOL | 0 | 0 | 1 (7.1%) | 1 | 1 (3.2%) | 1
PROMETHAZINE DM | 1 (5.9%) | 1 | 0 | 0 | 1 (3.2%) | 1
SALBUTAMOL | 1 (5.9%) | 1 | 0 | 0 | 1 (3.2%) | 1
SYSTEMIC HORMONAL PREPARATIONS, EXCL. SEX HORMONES AND INSULINS | 2 (11.8%) | 2 | 2 (14.3%) | 2 | 4 (12.9%) | 4
LEVOTHYROXINE | 1 (5.9%) | 1 | 1 (7.1%) | 1 | 2 (6.5%) | 2
LEVOTHYROXINE SODIUM | 1 (5.9%) | 1 | 1 (7.1%) | 1 | 2 (6.5%) | 2

Note: The percentages are based on the total number of safety participants in each treatment group or total.

Pts = Participants; Medn = medication; Medns = medications;

Participants are counted once at each WHO Class (ATC1 level) and medication name.

Table 14.3.2.1.4 Concomitant Medications Used During the Restabilization Phase by Discontinuation Phase Treatment Received Group Restabilization Phase - Safety Population

WHO Class; Medication Name | Discontinuation Phase Treatment Received Group | | | | Total; (N=13)
WHO Class; Medication Name | Lithium; (N=3) | | Placebo; (N=10) | | Total; (N=13)
WHO Class; Medication Name | Pts With Medn; N (%) | Total Medns; N | Pts With Medn; N (%) | Total Medns; N | Pts With Medn; N (%) | Total Medns; N
ALIMENTARY TRACT AND METABOLISM | 1 (33.3%) | 1 | 3 (30%) | 5 | 4 (30.8%) | 6
BISMUTH SUBSALICYLATE | 0 | 0 | 1 (10%) | 1 | 1 (7.7%) | 1
CAMALOX | 0 | 0 | 1 (10%) | 1 | 1 (7.7%) | 1
LOPERAMIDE HYDROCHLORIDE | 1 (33.3%) | 1 | 0 | | 1 (7.7%) | 1
MACROGOL | 0 | 0 | 1 (10%) | 1 | 1 (7.7%) | 1
OMEPRAZOLE | 0 | 0 | 1 (10%) | 1 | 1 (7.7%) | 1
TUMS /00193601/ | 0 | 0 | 1 (10%) | 1 | 1 (7.7%) | 1
DERMATOLOGICALS | 1 (33.3%) | 1 | 1 (10%) | 1 | 2 (15.4%)
ANTI-ACNE PREPARATIONS | 0 | 0 | 1 (10%) | 1 | 1 (7.7%) | 1
BENZOYL PEROXIDE | 1 (33.3%) | 1 | 0 | | 1 (7.7%) | 1
GENITO URINARY SYSTEM AND SEX HORMONES | 0 | 0 | 1 (10%) | 1 | 1 (7.7%) | 1
DROSPIRENONE W/ETHINYLESTRADIOL | 0 | 0 | 1 (10%) | 1 | 1 (7.7%) | 1
MUSCULO-SKELETAL SYSTEM | 0 | 0 | 1 (10%) | 1 | 1 (7.7%) | 1
IBUPROFEN | 0 | 0 | 1 (10%) | 1 | 1 (7.7%) | 1
NERVOUS SYSTEM | 1 (33.3%) | 2 | 5 (50%) | 11 | 6 (46.2%) | 13
BENZATROPINE MESILATE | 0 | 0 | 1 (10%) | 1 | 1 (7.7%) | 1
DIPHENHYDRAMINE HYDROCHLORIDE | 1 (33.3%) | 1 | 1 (10%) | 1 | 2 (15.4%) | 2
PARACETAMOL | 1 (33.3%) | 1 | 5 (50%) | 9 | 6 (46.2%) | 10
RESPIRATORY SYSTEM | 1 (33.3%) | 1 | 4 (40%) | 4 | 5 (38.5%) | 5
BENADRYL /01563701/ | 0 | 0 | 1 (10%) | 1 | 1 (7.7%) | 1
CETIRIZINE HYDROCHLORIDE | 0 | 0 | 2 (20%) | 2 | 2 (15.4%) | 2
CO-TYLENOL | 1 (33.3%) | 1 | 0 | 0 | 1 (7.7%) | 1
LORATADINE | 0 | 0 | 1 (10%) | 1 | 1 (7.7%) | 1
SYSTEMIC HORMONAL PREPARATIONS, EXCL. SEX HORMONES AND INSULINS | 0 | 0 | 2 (20%) | 2 | 2 (15.4%) | 2
LEVOTHYROXINE | 0 | 0 | 1 (10%) | 1 | 1 (7.7%) | 1
LEVOTHYROXINE SODIUM | 0 | 0 | 1 (10%) | 1 | 1 (7.7%) | 1

Note: The percentages are based on the number of safety participants in each treatment group or total.

Pts = Participants; Medn = medication; Medns = medications;

Participants are counted once at each WHO Class (ATC1 level) and medication name.

Table 14.3.2.2.1 Concomitant Psychotropic Medications Used During the Efficacy Phase by Age Strata and Efficacy Phase Treatment Received Group Efficacy Phase - Safety Population

WHO Class; Medication Name | 7-11 years | | | | 12-17 years | | | | Total
WHO Class; Medication Name | Lithium; (N=32) | | Placebo; (N=17) | | Lithium; (N=21) | | Placebo; (N=11) | | Lithium; (N=53) | | Placebo; (N=28)
WHO Class; Medication Name | Pts With Medn; N (%) | Total Medns; N | Pts With Medn; N (%) | Total Medns; N | Pts With Medn; N (%) | Total Medns; N | Pts With Medn; N (%) | Total Medns; N | Pts With Medn; N (%) | Total Medns; N | Pts With Medn; N (%) | Total Medns; N
NERVOUS SYSTEM | 14 (43.8%) | 27 | 12 (70.6%) | 26 | 8 (38.1%) | 19 | 3 (27.3%) | 6 | 22 (41.5%) | 46 | 15 (53.6%) | 32
HYDROXYZINE | 9 (28.1%) | 14 | 6 (35.3%) | 7 | 2 (9.5%) | 3 | 2 (18.2%) | 3 | 11 (20.8%) | 17 | 8 (28.6%) | 10
HYDROXYZINE HYDROCHLORIDE | 2 (6.3%) | 2 | 1 (5.9%) | 1 | 0 | 0 | 0 | 0 | 2 (3.8%) | 2 | 1 (3.6%) | 1
LORAZEPAM | 7 (21.9%) | 7 | 8 (47.1%) | 16 | 7 (33.3%) | 13 | 1 (9.1%) | 1 | 14 (26.4%) | 20 | 9 (32.1%) | 17
METHYLPHENIDATE | 3 (9.4%) | 3 | 2 (11.8%) | 2 | 1 (4.8%) | 2 | 1 (9.1%) | 2 | 4 (7.5%) | 5 | 3 (10.7%) | 4
RISPERIDONE | 1 (3.1%) | 1 | 0 | 0 | 1 (4.8%) | 1 | 0 | 0 | 2 (3.8%) | 2 | 0 | 0

Note: The percentages are based on the total number of safety participants in each age/treatment group.

Pts = Participants; Medn = medication; Medns = medications;

Participants are counted once at each WHO Class (ATC1 level) and medication name.

Table 14.3.2.2.2A Concomitant Psychotropic Medications Used During the Long-Term Effectiveness Phase by Age Strata Long-Term Effectiveness Phase - Safety Population

WHO Class; Medication Name | 7 - 11 yrs; (N=29) | | 12 - 17 yrs; (N=15) | | Total; (N=44)
WHO Class; Medication Name | Pts With Medn; N (%) | Total Medns; N | Pts With Medn; N (%) | Total Medns; N | Pts With Medn; N (%) | Total Medns; N
NERVOUS SYSTEM | 23 (79.3%) | 114 | 11 (73.3%) | 39 | 34 (77.3%) | 153
AMFETAMINE | 3 (10.3%) | 4 | 0 | 0 | 3 (6.8%) | 4
ARIPIPRAZOLE | 2 (6.9%) | 7 | 1 (6.7%) | 4 | 3 (6.8%) | 11
ATOMOXETINE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
BENZATROPINE MESILATE | 0 | 0 | 1 (6.7%) | 1 | 1 (2.3%) | 1
GUANFACINE | 2 (6.9%) | 2 | 1 (6.7%) | 1 | 3 (6.8%) | 3
HYDROXYZINE | 9 (31%) | 11 | 4 (26.7%) | 6 | 13 (29.5%) | 17
HYDROXYZINE HYDROCHLORIDE | 1 (3.4%) | 2 | 1 (6.7%) | 1 | 2 (4.5%) | 3
LAMOTRIGINE | 2 (6.9%) | 10 | 3 (20%) | 9 | 5 (11.4%) | 19
LORAZEPAM | 3 (10.3%) | 4 | 4 (26.7%) | 5 | 7 (15.9%) | 9
MELATONIN | 1 (3.4%) | 1 | 1 (6.7%) | 1 | 2 (4.5%) | 2
METHYLPHENIDATE | 16 (55.2%) | 26 | 2 (13.3%) | 4 | 18 (40.9%) | 30
QUETIAPINE | 5 (17.2%) | 20 | 3 (20%) | 4 | 8 (18.2%) | 24
RISPERIDONE | 1 (3.4%) | 1 | 1 (6.7%) | 1 | 2 (4.5%) | 2
VALPROATE SODIUM | 7 (24.1%) | 25 | 1 (6.7%) | 2 | 8 (18.2%) | 27

Note: The percentages are based on the number of safety participants in each age strata or total.

Pts = Participants; Medn = medication; Medns = medications;

Participants are counted once at each WHO Class (ATC1 level) and medication name.

Table 14.3.2.2.2B Concomitant Psychotropic Medications Used During the Long-Term Effectiveness Phase by Efficacy Phase Treatment Received Group Long-Term Effectiveness Phase - Safety Population

WHO Class; Medication Name | Lithium; (N=29) | | Placebo; (N=15) | | Total; (N=44)
WHO Class; Medication Name | Pts With Medn; N (%) | Total Medns; N | Pts With Medn; N (%) | Total Medns; N | Pts With Medn; N (%) | Total Medns; N
NERVOUS SYSTEM | 25 (86.2%) | 127 | 9 (60%) | 26 | 34 (77.3%) | 153
AMFETAMINE | 1 (3.4%) | 1 | 2 (13.3%) | 3 | 3 (6.8%) | 4
ARIPIPRAZOLE | 2 (6.9%) | 7 | 1 (6.7%) | 4 | 3 (6.8%) | 11
ATOMOXETINE | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
BENZATROPINE MESILATE | 0 | 0 | 1 (6.7%) | 1 | 1 (2.3%) | 1
GUANFACINE | 1 (3.4%) | 1 | 2 (13.3%) | 2 | 3 (6.8%) | 3
HYDROXYZINE | 9 (31%) | 13 | 4 (26.7%) | 4 | 13 (29.5%) | 17
HYDROXYZINE HYDROCHLORIDE | 2 (6.9%) | 3 | 0 | 0 | 2 (4.5%) | 3
LAMOTRIGINE | 5 (17.2%) | 19 | 0 | 0 | 5 (11.4%) | 19
LORAZEPAM | 5 (17.2%) | 6 | 2 (13.3%) | 3 | 7 (15.9%) | 9
MELATONIN | 2 (6.9%) | 2 | 0 | 0 | 2 (4.5%) | 2
METHYLPHENIDATE | 14 (48.3%) | 25 | 4 (26.7%) | 5 | 18 (40.9%) | 30
QUETIAPINE | 7 (24.1%) | 23 | 1 (6.7%) | 1 | 8 (18.2%) | 24
RISPERIDONE | 1 (3.4%) | 1 | 1 (6.7%) | 1 | 2 (4.5%) | 2
VALPROATE SODIUM | 7 (24.1%) | 25 | 1 (6.7%) | 2 | 8 (18.2%) | 27

Note: The percentages are based on the total number of safety participants in each treatment group or total.

Pts = Participants; Medn = medication; Medns = medications;

Participants are counted once at each WHO Class (ATC1 level) and medication name.

Table 14.3.2.2.3 Concomitant Psychotropic Medications Used During the Discontinuation Phase by Discontinuation Phase Treatment Received Group Discontinuation Phase - Safety Population

WHO Class; Medication Name | Discontinuation Phase Treatment Received Group | | | | Total; (N=31)
WHO Class; Medication Name | Lithium; (N=17) | | Placebo; (N=14) | | Total; (N=31)
WHO Class; Medication Name | Pts With Medn; N (%) | Total Medns; N | Pts With Medn; N (%) | Total Medns; N | Pts With Medn; N (%) | Total Medns; N
NERVOUS SYSTEM | 8 (47.1%) | 17 | 9 (64.3%) | 19 | 17 (54.8%) | 36
AMFETAMINE SULFATE | 1 (5.9%) | 1 | 3 (21.4%) | 3 | 4 (12.9%) | 4
ARIPIPRAZOLE | 0 | 0 | 1 (7.1%) | 1 | 1 (3.2%) | 1
ATOMOXETINE | 1 (5.9%) | 3 | 0 | 0 | 1 (3.2%) | 3
GUANFACINE | 0 | 0 | 1 (7.1%) | 1 | 1 (3.2%) | 1
HYDROXYZINE | 2 (11.8%) | 2 | 3 (21.4%) | 3 | 5 (16.1%) | 5
HYDROXYZINE HYDROCHLORIDE | 1 (5.9%) | 2 | 0 | 0 | 1 (3.2%) | 2
LAMOTRIGINE | 0 | 0 | 1 (7.1%) | 1 | 1 (3.2%) | 1
LORAZEPAM | 0 | 0 | 1 (7.1%) | 1 | 1 (3.2%) | 1
METHYLPHENIDATE | 1 (5.9%) | 1 | 1 (7.1%) | 1 | 2 (6.5%) | 2
METHYLPHENIDATE HYDROCHLORIDE | 2 (11.8%) | 2 | 1 (7.1%) | 1 | 3 (9.7%) | 3
QUETIAPINE | 1 (5.9%) | 2 | 2 (14.3%) | 2 | 3 (9.7%) | 4
QUETIAPINE FUMARATE | 1 (5.9%) | 1 | 1 (7.1%) | 1 | 2 (6.5%) | 2
RISPERIDONE | 0 | 0 | 1 (7.1%) | 1 | 1 (3.2%) | 1
VALPROATE SEMISODIUM | 1 (5.9%) | 1 | 2 (14.3%) | 3 | 3 (9.7%) | 4
VALPROATE SODIUM | 1 (5.9%) | 2 | 0 | 0 | 1 (3.2%) | 2

Note: The percentages are based on the total number of safety participants in each treatment group or total.

Pts = Participants; Medn = medication; Medns = medications;

Participants are counted once at each WHO Class (ATC1 level) and medication name.

Table 14.3.2.2.4 Concomitant Psychotropic Medications Used During the Restabilization Phase by Discontinuation Phase Treatment Received Group Restabilization Phase - Safety Population

WHO Class; Medication Name | Discontinuation Phase Treatment Received Group | | | | Total; (N=13)
WHO Class; Medication Name | Lithium; (N=3) | | Placebo; (N=10) | | Total; (N=13)
WHO Class; Medication Name | Pts With Medn; N (%) | Total Medns; N | Pts With Medn; N (%) | Total Medns; N | Pts With Medn; N (%) | Total Medns; N
NERVOUS SYSTEM | 1 (33.3%) | 3 | 7 (70%) | 19 | 8 (61.5%) | 22
AMFETAMINE SULFATE | 0 | 0 | 2 (20%) | 2 | 2 (15.4%) | 2
ARIPIPRAZOLE | 0 | 0 | 2 (20%) | 4 | 2 (15.4%) | 4
GUANFACINE | 0 | 0 | 1 (10%) | 1 | 1 (7.7%) | 1
HYDROXYZINE | 0 | 0 | 2 (20%) | 2 | 2 (15.4%) | 2
LAMOTRIGINE | 0 | 0 | 1 (10%) | 1 | 1 (7.7%) | 1
LORAZEPAM | 0 | 0 | 1 (10%) | 1 | 1 (7.7%) | 1
QUETIAPINE | 0 | 0 | 2 (20%) | 3 | 2 (15.4%) | 3
RISPERIDONE | 0 | 0 | 1 (10%) | 1 | 1 (7.7%) | 1
VALPROATE SEMISODIUM | 1 (33.3%) | 3 | 3 (30%) | 4 | 4 (30.8%) | 7

Note: The percentages are based on the number of safety participants in each treatment group or total.

Pts = Participants; Medn = medication; Medns = medications;

Participants are counted once at each WHO Class (ATC1 level) and medication name.

Table 14.3.2.3.1 Concomitant Psychotherapy Used During the Efficacy Phase by Age Strata and Efficacy Phase Treatment Received Group Efficacy Phase - Safety Population

Type of Therapy; Group | 7-11 years | | | | 12-17 years | | | | Total
Type of Therapy; Group | Lithium; (N=32) | | Placebo; (N=17) | | Lithium; (N=21) | | Placebo; (N=11) | | Lithium; (N=53) | | Placebo; (N=28)
Type of Therapy; Group | Pts With Therapy; N (%) | Total Therapys; N | Pts With Therapy; N (%) | Total Therapys; N | Pts With Therapy; N (%) | Total Therapys; N | Pts With Therapy; N (%) | Total Therapys; N | Pts With Therapy; N (%) | Total Therapys; N | Pts With Therapy; N (%) | Total Therapys; N
Received any Therapy | 10 (31.3%) | 12 | 7 (41.2%) | 8 | 7 (33.3%) | 10 | 0 | 0 | 17 (32.1%) | 22 | 7 (25%) | 8
Individual | 10 (31.3%) | 11 | 7 (41.2%) | 8 | 6 (28.6%) | 8 | 0 | 0 | 16 (30.2%) | 19 | 7 (25%) | 8
Group | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Family | 1 (3.1%) | 1 | 0 | 0 | 2 (9.5%) | 2 | 0 | 0 | 3 (5.7%) | 3 | 0 | 0
Behavioral | 6 (18.8%) | 8 | 4 (23.5%) | 4 | 4 (19%) | 4 | 0 | 0 | 10 (18.9%) | 12 | 4 (14.3%) | 4
Individual | 6 (18.8%) | 7 | 4 (23.5%) | 4 | 4 (19%) | 4 | 0 | 0 | 10 (18.9%) | 11 | 4 (14.3%) | 4
Group | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Family | 1 (3.1%) | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1 | 0 | 0
Cognitive | 1 (3.1%) | 1 | 1 (5.9%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1 | 1 (3.6%) | 1
Individual | 1 (3.1%) | 1 | 1 (5.9%) | 1 | 0 | 0 | 0 | 0 | 1 (1.9%) | 1 | 1 (3.6%) | 1
Group | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Family | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Other Therapy | 2 (6.3%) | 2 | 2 (11.8%) | 2 | 3 (14.3%) | 3 | 0 | 0 | 5 (9.4%) | 5 | 2 (7.1%) | 2
Individual | 2 (6.3%) | 2 | 2 (11.8%) | 2 | 3 (14.3%) | 3 | 0 | 0 | 5 (9.4%) | 5 | 2 (7.1%) | 2
Group | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Family | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Unknown Therapy | 1 (3.1%) | 1 | 1 (5.9%) | 1 | 3 (14.3%) | 3 | 0 | 0 | 4 (7.5%) | 4 | 1 (3.6%) | 1
Individual | 1 (3.1%) | 1 | 1 (5.9%) | 1 | 1 (4.8%) | 1 | 0 | 0 | 2 (3.8%) | 2 | 1 (3.6%) | 1
Group | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
Family | 0 | 0 | 0 | 0 | 2 (9.5%) | 2 | 0 | 0 | 2 (3.8%) | 2 | 0 | 0

Note: The percentages are based on the total number of safety participants in each age/treatment group.

Participants are counted only once in each therapy type/group combination

Other psychotherapy includes supportive (N=3), behavioral/cognitive (N=2), play (N=1) and theraputic mentor (N=1).

Table 14.3.2.3.2A Concomitant Psychotherapy Used During the Long-Term Effectiveness Phase by Age Strata Long-Term Effectiveness Phase - Safety Population

Type of Therapy; Group | 7 - 11 yrs; (N=29) | | 12 - 17 yrs; (N=15) | | Total; (N=44)
Type of Therapy; Group | Pts With Therapy; N (%) | Total Therapys; N | Pts With Therapy; N (%) | Total Therapys; N | Pts With Therapy; N (%) | Total Therapys; N
Received any Therapy | 13 (44.8%) | 19 | 5 (33.3%) | 6 | 18 (40.9%) | 25
Individual | 13 (44.8%) | 18 | 2 (13.3%) | 2 | 15 (34.1%) | 20
Group | 0 | 0 | 0 | 0 | 0 | 0
Family | 1 (3.4%) | 1 | 4 (26.7%) | 4 | 5 (11.4%) | 5
Behavioral | 7 (24.1%) | 11 | 0 | 0 | 7 (15.9%) | 11
Individual | 7 (24.1%) | 10 | 0 | 0 | 7 (15.9%) | 10
Group | 0 | 0 | 0 | 0 | 0 | 0
Family | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
Cognitive | 1 (3.4%) | 1 | 1 (6.7%) | 1 | 2 (4.5%) | 2
Individual | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
Group | 0 | 0 | 0 | 0 | 0 | 0
Family | 0 | 0 | 1 (6.7%) | 1 | 1 (2.3%) | 1
Other Therapy | 4 (13.8%) | 4 | 4 (26.7%) | 4 | 8 (18.2%) | 8
Individual | 4 (13.8%) | 4 | 2 (13.3%) | 2 | 6 (13.6%) | 6
Group | 0 | 0 | 0 | 0 | 0 | 0
Family | 0 | 0 | 2 (13.3%) | 2 | 2 (4.5%) | 2
Unknown Therapy | 3 (10.3%) | 3 | 1 (6.7%) | 1 | 4 (9.1%) | 4
Individual | 3 (10.3%) | 3 | 0 | 0 | 3 (6.8%) | 3
Group | 0 | 0 | 0 | 0 | 0 | 0
Family | 0 | 0 | 1 (6.7%) | 1 | 1 (2.3%) | 1

Note: The percentages are based on the total number of safety participants in each age strata or total.

Participants are counted only once in each therapy type/group combination.

Other therapies include: behavioral/cognitive(3), supportive(3), family focused therapy(1) and CBT(1).

Table 14.3.2.3.2B Concomitant Psychotherapy Used During the Long-Term Effectiveness Phase by Efficacy Phase Treatment Received Group Long-Term Effectiveness Phase - Safety Population

Type of Therapy; Group | Lithium; (N=29) | | Placebo; (N=15) | | Total; (N=44)
Type of Therapy; Group | Pts With Therapy; N (%) | Total Therapys; N | Pts With Therapy; N (%) | Total Therapys; N | Pts With Therapy; N (%) | Total Therapys; N
Received any Therapy | 15 (51.7%) | 21 | 3 (20%) | 4 | 18 (40.9%) | 25
Individual | 12 (41.4%) | 16 | 3 (20%) | 4 | 15 (34.1%) | 20
Group | 0 | 0 | 0 | 0 | 0 | 0
Family | 5 (17.2%) | 5 | 0 | 0 | 5 (11.4%) | 5
Behavioral | 6 (20.7%) | 9 | 1 (6.7%) | 2 | 7 (15.9%) | 11
Individual | 6 (20.7%) | 8 | 1 (6.7%) | 2 | 7 (15.9%) | 10
Group | 0 | 0 | 0 | 0 | 0 | 0
Family | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
Cognitive | 2 (6.9%) | 2 | 0 | 0 | 2 (4.5%) | 2
Individual | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
Group | 0 | 0 | 0 | 0 | 0 | 0
Family | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1
Other Therapy | 8 (27.6%) | 8 | 0 | 0 | 8 (18.2%) | 8
Individual | 6 (20.7%) | 6 | 0 | 0 | 6 (13.6%) | 6
Group | 0 | 0 | 0 | 0 | 0 | 0
Family | 2 (6.9%) | 2 | 0 | 0 | 2 (4.5%) | 2
Unknown Therapy | 2 (6.9%) | 2 | 2 (13.3%) | 2 | 4 (9.1%) | 4
Individual | 1 (3.4%) | 1 | 2 (13.3%) | 2 | 3 (6.8%) | 3
Group | 0 | 0 | 0 | 0 | 0 | 0
Family | 1 (3.4%) | 1 | 0 | 0 | 1 (2.3%) | 1

Note: The percentages are based on the number of safety participants in each treatment group or total.

Participants are counted only once in each therapy type/group combination.

Other therapies include: behavioral/cognitive(3), supportive(3), family focused therapy(1) and CBT(1).

Table 14.3.2.3.3 Concomitant Psychotherapy During the Discontinuation Phase by Discontinuation Phase Treatment Received Group Discontinuation Phase - Safety Population

Type of Therapy; Group | Discontinuation Phase Treatment Received Group | | | | Total; (N=31)
Type of Therapy; Group | Lithium; (N=17) | | Placebo; (N=14) | | Total; (N=31)
Type of Therapy; Group | Pts With Therapy; N (%) | Total Therapys; N | Pts With Therapy; N (%) | Total Therapys; N | Pts With Therapy; N (%) | Total Therapys; N
Received any Therapy | 5 (29.4%) | 6 | 6 (42.9%) | 7 | 11 (35.5%) | 13
Individual | 5 (29.4%) | 6 | 5 (35.7%) | 6 | 10 (32.3%) | 12
Group | 0 | 0 | 0 | 0 | 0 | 0
Family | 0 | 0 | 1 (7.1%) | 1 | 1 (3.2%) | 1
Behavioral | 2 (11.8%) | 2 | 2 (14.3%) | 3 | 4 (12.9%) | 5
Individual | 2 (11.8%) | 2 | 2 (14.3%) | 3 | 4 (12.9%) | 5
Group | 0 | 0 | 0 | 0 | 0 | 0
Family | 0 | 0 | 0 | 0 | 0 | 0
Cognitive | 3 (17.6%) | 4 | 4 (28.6%) | 4 | 7 (22.6%) | 8
Individual | 3 (17.6%) | 4 | 3 (21.4%) | 3 | 6 (19.4%) | 7
Group | 0 | 0 | 0 | 0 | 0 | 0
Family | 0 | 0 | 1 (7.1%) | 1 | 1 (3.2%) | 1
Other Therapy | 0 | 0 | 0 | 0 | 0 | 0
Individual | 0 | 0 | 0 | 0 | 0 | 0
Group | 0 | 0 | 0 | 0 | 0 | 0
Family | 0 | 0 | 0 | 0 | 0 | 0
Unknown Therapy | 0 | 0 | 0 | 0 | 0 | 0
Individual | 0 | 0 | 0 | 0 | 0 | 0
Group | 0 | 0 | 0 | 0 | 0 | 0
Family | 0 | 0 | 0 | 0 | 0 | 0

Note: The percentages are based on the total number of safety participants in each treatment group or total.

Participants are counted only once in each therapy type/group combination.

Table 14.3.2.3.4 Concomitant Psychotherapy During the Restabilization Phase by Discontinuation Phase Treatment Received Group Restabilization Phase - Safety Population

Type of Therapy; Group | Discontinuation Phase Treatment Received Group | | | | Total; (N=13)
Type of Therapy; Group | Lithium; (N=3) | | Placebo; (N=10) | | Total; (N=13)
Type of Therapy; Group | Pts With Therapy; N (%) | Total Therapys; N | Pts With Therapy; N (%) | Total Therapys; N | Pts With Therapy; N (%) | Total Therapys; N
Received any Therapy | 1 (33.3%) | 1 | 4 (40%) | 5 | 5 (38.5%) | 6
Individual | 1 (33.3%) | 1 | 4 (40%) | 5 | 5 (38.5%) | 6
Group | 0 | 0 | 0 | 0 | 0 | 0
Family | 0 | 0 | 0 | 0 | 0 | 0
Behavioral | 0 | 0 | 2 (20%) | 3 | 2 (15.4%) | 3
Individual | 0 | 0 | 2 (20%) | 3 | 2 (15.4%) | 3
Group | 0 | 0 | 0 | 0 | 0 | 0
Family | 0 | 0 | 0 | 0 | 0 | 0
Cognitive | 1 (33.3%) | 1 | 2 (20%) | 2 | 3 (23.1%) | 3
Individual | 1 (33.3%) | 1 | 2 (20%) | 2 | 3 (23.1%) | 3
Group | 0 | 0 | 0 | 0 | 0 | 0
Family | 0 | 0 | 0 | 0 | 0 | 0
Other Therapy | 0 | 0 | 0 | 0 | 0 | 0
Individual | 0 | 0 | 0 | 0 | 0 | 0
Group | 0 | 0 | 0 | 0 | 0 | 0
Family | 0 | 0 | 0 | 0 | 0 | 0
Unknown Therapy | 0 | 0 | 0 | 0 | 0 | 0
Individual | 0 | 0 | 0 | 0 | 0 | 0
Group | 0 | 0 | 0 | 0 | 0 | 0
Family | 0 | 0 | 0 | 0 | 0 | 0

Note: The percentages are based on the number of safety participants in each treatment group or total.

Participants are counted only once in each therapy type/group combination.

Table 14.3.3.1.1.1 Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group White Blood Count (×10^3^μL) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 6.6 (2.6) | 6.4 (1.5) | 6.7 (2.3) | 5.8 (1.7) | 6.6 (2.5) | 6.1 (1.6)
Median (Min-Max) | 6.1 (3.1 - 16.4) | 6.6 (3.5 - 9.1) | 6.5 (3.2 - 13.9) | 5.3 (3.4 - 7.8) | 6.4 (3.1 - 16.4) | 6.2 (3.4 - 9.1)
Week 2
N | 14 | 5 | 6 | 2 | 20 | 7
Mean (SD) | 7.2 (2.1) | 7.0 (2.3) | 6.7 (1.2) | 4.9 (0.7) | 7.0 (1.8) | 6.4 (2.2)
Median (Min-Max) | 7.0 (3.4 - 10.4) | 6.1 (5.3 - 11.1) | 7.2 (4.7 - 7.9) | 4.9 (4.4 - 5.4) | 7.2 (3.4 - 10.4) | 6.0 (4.4 - 11.1)
Week 4
N | 25 | 11 | 14 | 10 | 39 | 21
Mean (SD) | 8.7 (2.6) | 8.2 (1.8) | 8.5 (2.3) | 5.4 (1.7) | 8.6 (2.5) | 6.9 (2.2)
Median (Min-Max) | 9.5 (3.6 - 14.1) | 8.7 (4.2 - 11.2) | 8.0 (5.7 - 14.1) | 5.5 (2.9 - 8.4) | 8.5 (3.6 - 14.1) | 7.2 (2.9 - 11.2)
Week 8
N | 28 | 12 | 20 | 10 | 48 | 22
Mean (SD) | 7.6 (2.0) | 6.7 (1.6) | 8.9 (2.8) | 4.9 (1.5) | 8.2 (2.4) | 5.9 (1.7)
Median (Min-Max) | 7.4 (4.0 - 12.4) | 7.2 (3.1 - 8.3) | 8.3 (4.7 - 18.5) | 4.5 (2.7 - 7.7) | 7.9 (4.0 - 18.5) | 6.2 (2.7 - 8.3)
LOCF
N | 30 | 16 | 21 | 10 | 51 | 26
Mean (SD) | 7.5 (2.1) | 6.7 (1.4) | 8.9 (2.8) | 4.9 (1.5) | 8.1 (2.4) | 6.0 (1.7)
Median (Min-Max) | 7.4 (3.6 - 12.4) | 7.2 (3.1 - 8.3) | 8.2 (4.7 - 18.5) | 4.5 (2.7 - 7.7) | 7.7 (3.6 - 18.5) | 6.9 (2.7 - 8.3)
Change from Baseline to LOCF
N | 30 | 16 | 21 | 10 | 51 | 26
Mean (SD) | 1.0 (2.3) | 0.3 (1.3) | 2.1 (3.0) | −0.7 (0.9) | 1.5 (2.7) | −0.1 (1.3)
Median (Min-Max) | 1.1 (−7.9 - 5.0) | 0.5 (−2.1 - 2.1) | 1.8 (−6.9 - 10.0) | −0.5 (−2.3 - 0.5) | 1.4 (−7.9 - 10.0) | −0.1 (−2.3 - 2.1)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.1.1.2 Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Red Blood Count (×10^6^/μL) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 27 | 16 | 20 | 9 | 47 | 25
Mean (SD) | 4.7 (0.3) | 4.9 (0.3) | 4.6 (0.4) | 4.6 (0.4) | 4.7 (0.4) | 4.8 (0.4)
Median (Min-Max) | 4.7 (4.3 - 5.7) | 4.9 (4.4 - 5.4) | 4.6 (3.8 - 5.5) | 4.6 (4.0 - 5.2) | 4.7 (3.8 - 5.7) | 4.8 (4.0 - 5.4)
Week 2
N | 13 | 5 | 6 | 2 | 19 | 7
Mean (SD) | 4.5 (0.4) | 4.9 (0.2) | 4.4 (0.4) | 4.2 (0.1) | 4.5 (0.4) | 4.7 (0.4)
Median (Min-Max) | 4.5 (4.1 - 5.3) | 4.9 (4.7 - 5.2) | 4.5 (3.6 - 4.8) | 4.2 (4.1 - 4.3) | 4.5 (3.6 - 5.3) | 4.8 (4.1 - 5.2)
Week 4
N | 21 | 10 | 13 | 9 | 34 | 19
Mean (SD) | 4.6 (0.4) | 4.8 (0.2) | 4.5 (0.4) | 4.4 (0.4) | 4.6 (0.4) | 4.6 (0.4)
Median (Min-Max) | 4.5 (4.0 - 5.5) | 4.9 (4.5 - 5.2) | 4.4 (3.9 - 5.4) | 4.3 (4.0 - 5.1) | 4.5 (3.9 - 5.5) | 4.8 (4.0 - 5.2)
Week 8
N | 27 | 9 | 18 | 9 | 45 | 18
Mean (SD) | 4.5 (0.3) | 4.7 (0.2) | 4.4 (0.4) | 4.6 (0.4) | 4.5 (0.3) | 4.6 (0.3)
Median (Min-Max) | 4.4 (4.1 - 5.5) | 4.7 (4.3 - 5.0) | 4.4 (3.8 - 5.2) | 4.5 (4.0 - 5.3) | 4.4 (3.8 - 5.5) | 4.7 (4.0 - 5.3)
LOCF
N | 29 | 13 | 19 | 9 | 48 | 22
Mean (SD) | 4.5 (0.3) | 4.8 (0.2) | 4.4 (0.4) | 4.6 (0.4) | 4.5 (0.3) | 4.7 (0.3)
Median (Min-Max) | 4.5 (4.1 - 5.5) | 4.8 (4.3 - 5.2) | 4.4 (3.8 - 5.2) | 4.5 (4.0 - 5.3) | 4.4 (3.8 - 5.5) | 4.7 (4.0 - 5.3)
Change from Baseline to LOCF
N | 25 | 13 | 19 | 8 | 44 | 21
Mean (SD) | −0.2 (0.2) | −0.1 (0.3) | −0.2 (0.2) | 0.0 (0.3) | −0.2 (0.2) | −0.1 (0.3)
Median (Min-Max) | −0.2 (−0.6 - 0.2) | 0.0 (−0.6 - 0.2) | −0.2 (−0.6 - 0.2) | 0.1 (−0.3 - 0.5) | −0.2 (−0.6 - 0.2) | 0.0 (−0.6 - 0.5)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.1.1.3 Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Hemoglobin (g/dL) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 13.2 (0.8) | 13.5 (0.5) | 13.3 (1.0) | 13.8 (1.5) | 13.2 (0.9) | 13.6 (1.0)
Median (Min-Max) | 13.1 (11.9 - 15.0) | 13.6 (12.8 - 14.4) | 13.2 (11.8 - 15.4) | 12.9 (12.3 - 15.7) | 13.2 (11.8 - 15.4) | 13.3 (12.3 - 15.7)
Week 2
N | 14 | 5 | 6 | 2 | 20 | 7
Mean (SD) | 12.5 (0.7) | 13.4 (0.6) | 13.2 (1.2) | 12.8 (0.4) | 12.7 (0.9) | 13.2 (0.6)
Median (Min-Max) | 12.6 (11.3 - 13.6) | 13.6 (12.7 - 14.0) | 13.2 (11.3 - 15.0) | 12.8 (12.5 - 13.0) | 12.7 (11.3 - 15.0) | 13.0 (12.5 - 14.0)
Week 4
N | 25 | 11 | 14 | 10 | 39 | 21
Mean (SD) | 12.7 (1.0) | 13.2 (0.9) | 13.1 (0.8) | 13.2 (1.4) | 12.8 (0.9) | 13.2 (1.1)
Median (Min-Max) | 12.5 (11.3 - 15.0) | 13.3 (11.6 - 14.5) | 13.3 (11.4 - 14.5) | 12.5 (11.8 - 15.6) | 12.8 (11.3 - 15.0) | 13.3 (11.6 - 15.6)
Week 8
N | 28 | 12 | 20 | 10 | 48 | 22
Mean (SD) | 12.7 (0.7) | 13.2 (0.8) | 12.8 (0.7) | 13.6 (1.1) | 12.7 (0.7) | 13.4 (0.9)
Median (Min-Max) | 12.7 (11.5 - 14.4) | 13.2 (12.0 - 14.5) | 12.8 (11.5 - 13.9) | 13.2 (12.4 - 15.4) | 12.8 (11.5 - 14.4) | 13.2 (12.0 - 15.4)
LOCF
N | 30 | 16 | 21 | 10 | 51 | 26
Mean (SD) | 12.7 (0.7) | 13.3 (0.7) | 12.9 (0.9) | 13.6 (1.1) | 12.8 (0.8) | 13.4 (0.9)
Median (Min-Max) | 12.7 (11.5 - 14.4) | 13.3 (12.0 - 14.5) | 12.8 (11.5 - 15.0) | 13.2 (12.4 - 15.4) | 12.8 (11.5 - 15.0) | 13.3 (12.0 - 15.4)
Change from Baseline to LOCF
N | 30 | 16 | 21 | 10 | 51 | 26
Mean (SD) | −0.5 (0.6) | −0.3 (0.8) | −0.5 (0.6) | 0.0 (0.6) | −0.5 (0.6) | −0.2 (0.7)
Median (Min-Max) | −0.4 (−1.6 - 0.8) | −0.3 (−1.8 - 1.0) | −0.5 (−1.5 - 0.7) | 0.0 (−1.2 - 1.2) | −0.5 (−1.6 - 0.8) | −0.1 (−1.8 - 1.2)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.1.1.4 Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Hematocrit (%) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 38.8 (1.7) | 39.8 (2.3) | 39.6 (3.1) | 40.4 (3.3) | 39.1 (2.4) | 40.0 (2.7)
Median (Min-Max) | 39.1 (35.9 - 41.7) | 40.5 (35.6 - 42.8) | 38.8 (34.9 - 45.0) | 39.2 (35.5 - 45.8) | 39.0 (34.9 - 45.0) | 40.1 (35.5 - 45.8)
Week 2
N | 14 | 5 | 6 | 2 | 20 | 7
Mean (SD) | 37.6 (2.0) | 39.9 (1.1) | 38.5 (2.9) | 37.7 (1.4) | 37.9 (2.3) | 39.3 (1.5)
Median (Min-Max) | 37.6 (34.6 - 41.7) | 39.4 (38.7 - 41.4) | 38.5 (33.7 - 42.8) | 37.7 (36.7 - 38.7) | 37.9 (33.7 - 42.8) | 39.3 (36.7 - 41.4)
Week 4
N | 25 | 11 | 14 | 10 | 39 | 21
Mean (SD) | 38.2 (2.3) | 38.6 (2.0) | 39.5 (2.9) | 39.0 (3.4) | 38.6 (2.6) | 38.8 (2.7)
Median (Min-Max) | 37.5 (34.2 - 43.2) | 39.5 (35.9 - 41.6) | 38.7 (35.2 - 44.8) | 37.8 (35.4 - 44.8) | 38.3 (34.2 - 44.8) | 38.3 (35.4 - 44.8)
Week 8
N | 28 | 12 | 20 | 10 | 48 | 22
Mean (SD) | 37.8 (1.8) | 39.0 (2.0) | 38.7 (2.5) | 40.0 (2.6) | 38.2 (2.2) | 39.4 (2.3)
Median (Min-Max) | 38.0 (34.3 - 42.9) | 38.8 (36.5 - 42.6) | 39.0 (34.8 - 43.2) | 39.3 (36.3 - 44.2) | 38.5 (34.3 - 43.2) | 39.1 (36.3 - 44.2)
LOCF
N | 30 | 16 | 21 | 10 | 51 | 26
Mean (SD) | 37.8 (1.9) | 39.1 (1.7) | 38.9 (2.6) | 40.0 (2.6) | 38.3 (2.3) | 39.4 (2.1)
Median (Min-Max) | 38.0 (34.3 - 42.9) | 39.4 (36.5 - 42.6) | 39.1 (34.8 - 43.2) | 39.3 (36.3 - 44.2) | 38.5 (34.3 - 43.2) | 39.4 (36.3 - 44.2)
Change from Baseline to LOCF
N | 30 | 16 | 21 | 10 | 51 | 26
Mean (SD) | −0.9 (2.1) | −0.9 (2.3) | −0.7 (2.1) | −0.1 (1.8) | −0.8 (2.1) | −0.6 (2.2)
Median (Min-Max) | −0.5 (−5.0 - 3.9) | −0.8 (−6.1 - 2.9) | −1.0 (−3.5 - 3.1) | −0.2 (−3.7 - 3.5) | −0.8 (−5.0 - 3.9) | −0.5 (−6.1 - 3.5)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.1.1.5 Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Mean Corpuscular Volume - MCV (fL) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 82.6 (5.0) | 81.6 (2.4) | 86.2 (4.4) | 87.5 (3.7) | 84.0 (5.1) | 83.9 (4.1)
Median (Min-Max) | 82.8 (64.3 - 93.5) | 81.5 (75.3 - 85.0) | 86.0 (77.3 - 91.9) | 88.3 (81.0 - 93.0) | 84.1 (64.3 - 93.5) | 83.1 (75.3 - 93.0)
Week 2
N | 14 | 5 | 6 | 2 | 20 | 7
Mean (SD) | 83.5 (6.1) | 81.7 (1.8) | 87.8 (3.2) | 89.8 (1.1) | 84.8 (5.7) | 84.0 (4.3)
Median (Min-Max) | 84.3 (65.0 - 89.7) | 81.1 (80.0 - 84.0) | 87.4 (84.7 - 92.4) | 89.8 (89.0 - 90.6) | 85.1 (65.0 - 92.4) | 83.0 (80.0 - 90.6)
Week 4
N | 25 | 11 | 14 | 10 | 39 | 21
Mean (SD) | 83.8 (5.4) | 81.0 (2.7) | 87.0 (4.2) | 87.4 (4.4) | 85.0 (5.2) | 84.0 (4.8)
Median (Min-Max) | 85.2 (64.8 - 89.6) | 81.0 (75.8 - 85.0) | 87.5 (80.0 - 92.9) | 88.2 (80.1 - 93.0) | 86.0 (64.8 - 92.9) | 82.0 (75.8 - 93.0)
Week 8
N | 28 | 12 | 20 | 10 | 48 | 22
Mean (SD) | 84.2 (5.1) | 82.5 (2.2) | 88.4 (4.2) | 86.5 (4.8) | 86.0 (5.1) | 84.3 (4.1)
Median (Min-Max) | 85.6 (65.6 - 91.4) | 82.0 (78.0 - 87.0) | 89.2 (80.0 - 94.6) | 86.6 (78.6 - 94.0) | 86.0 (65.6 - 94.6) | 82.3 (78.0 - 94.0)
LOCF
N | 30 | 16 | 21 | 10 | 51 | 26
Mean (SD) | 84.1 (5.1) | 81.8 (2.6) | 88.4 (4.1) | 86.5 (4.8) | 85.9 (5.1) | 83.6 (4.2)
Median (Min-Max) | 85.3 (65.6 - 91.4) | 82.0 (75.8 - 87.0) | 89.3 (80.0 - 94.6) | 86.6 (78.6 - 94.0) | 86.0 (65.6 - 94.6) | 82.0 (75.8 - 94.0)
Change from Baseline to LOCF
N | 30 | 16 | 21 | 10 | 51 | 26
Mean (SD) | 1.6 (1.8) | 0.4 (1.7) | 2.3 (2.4) | −1.1 (2.1) | 1.9 (2.1) | −0.2 (2.0)
Median (Min-Max) | 2.0 (−2.1 - 5.0) | 0.4 (−3.1 - 3.7) | 2.6 (−2.4 - 7.6) | −2.0 (−2.4 - 4.5) | 2.1 (−2.4 - 7.6) | 0.0 (−3.1 - 4.5)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.1.1.6 Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Mean Corpuscular Hemoglobin - MCH (pg) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 28.0 (2.2) | 27.7 (1.1) | 29.0 (1.9) | 29.8 (1.4) | 28.4 (2.1) | 28.5 (1.6)
Median (Min-Max) | 28.1 (21.2 - 32.3) | 27.6 (26.0 - 29.9) | 29.7 (25.1 - 31.5) | 30.0 (27.2 - 31.4) | 28.5 (21.2 - 32.3) | 28.4 (26.0 - 31.4)
Week 2
N | 14 | 5 | 6 | 2 | 20 | 7
Mean (SD) | 27.7 (2.3) | 27.4 (0.9) | 30.2 (1.3) | 30.4 (0.1) | 28.4 (2.3) | 28.2 (1.6)
Median (Min-Max) | 28.1 (21.4 - 30.3) | 27.1 (26.3 - 28.5) | 30.3 (28.6 - 31.4) | 30.4 (30.3 - 30.4) | 28.7 (21.4 - 31.4) | 28.1 (26.3 - 30.4)
Week 4
N | 25 | 11 | 14 | 10 | 39 | 21
Mean (SD) | 27.9 (2.2) | 27.7 (1.1) | 28.9 (2.0) | 29.3 (1.4) | 28.3 (2.2) | 28.5 (1.4)
Median (Min-Max) | 28.1 (20.9 - 31.5) | 27.5 (26.0 - 29.7) | 29.0 (25.7 - 32.1) | 29.6 (26.8 - 30.9) | 28.5 (20.9 - 32.1) | 28.4 (26.0 - 30.9)
Week 8
N | 28 | 12 | 20 | 9 | 48 | 21
Mean (SD) | 28.3 (2.0) | 27.9 (1.1) | 29.2 (1.8) | 29.3 (1.5) | 28.6 (2.0) | 28.5 (1.4)
Median (Min-Max) | 28.6 (21.1 - 31.1) | 28.0 (25.9 - 29.3) | 29.4 (25.9 - 32.0) | 29.9 (26.6 - 30.8) | 28.8 (21.1 - 32.0) | 28.7 (25.9 - 30.8)
LOCF
N | 30 | 16 | 21 | 9 | 51 | 25
Mean (SD) | 28.2 (2.0) | 27.7 (1.1) | 29.3 (1.8) | 29.3 (1.5) | 28.6 (2.0) | 28.3 (1.4)
Median (Min-Max) | 28.4 (21.1 - 31.1) | 27.8 (25.9 - 29.3) | 29.4 (25.9 - 32.0) | 29.9 (26.6 - 30.8) | 28.7 (21.1 - 32.0) | 28.0 (25.9 - 30.8)
Change from Baseline to LOCF
N | 30 | 16 | 21 | 9 | 51 | 25
Mean (SD) | 0.1 (0.7) | 0.2 (0.5) | 0.2 (0.6) | −0.1 (0.5) | 0.2 (0.7) | 0.1 (0.5)
Median (Min-Max) | 0.1 (−1.7 - 2.1) | 0.2 (−0.9 - 1.1) | 0.2 (−0.9 - 1.3) | −0.4 (−0.6 - 0.8) | 0.1 (−1.7 - 2.1) | 0.0 (−0.9 - 1.1)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.1.1.7 Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Mean Corpuscular Hemoglobin Concentration - MCHC (g/dL) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 33.9 (1.4) | 33.9 (1.2) | 33.7 (1.1) | 34.0 (1.3) | 33.8 (1.3) | 34.0 (1.2)
Median (Min-Max) | 33.8 (31.0 - 37.1) | 33.5 (32.1 - 36.1) | 33.8 (31.1 - 35.3) | 34.3 (32.3 - 36.6) | 33.8 (31.0 - 37.1) | 33.7 (32.1 - 36.6)
Week 2
N | 14 | 5 | 6 | 2 | 20 | 7
Mean (SD) | 33.1 (1.2) | 33.6 (1.1) | 34.4 (0.6) | 33.9 (0.4) | 33.5 (1.2) | 33.7 (0.9)
Median (Min-Max) | 32.9 (31.7 - 35.8) | 33.5 (32.3 - 35.2) | 34.6 (33.6 - 35.0) | 33.9 (33.6 - 34.1) | 33.6 (31.7 - 35.8) | 33.6 (32.3 - 35.2)
Week 4
N | 25 | 11 | 14 | 10 | 39 | 21
Mean (SD) | 33.2 (1.2) | 34.3 (1.6) | 33.2 (1.3) | 33.7 (1.0) | 33.2 (1.3) | 34.0 (1.4)
Median (Min-Max) | 32.8 (31.3 - 35.7) | 34.3 (32.0 - 36.4) | 33.2 (31.1 - 34.9) | 33.9 (32.0 - 35.1) | 32.9 (31.1 - 35.7) | 34.0 (32.0 - 36.4)
Week 8
N | 28 | 12 | 20 | 10 | 48 | 22
Mean (SD) | 33.6 (1.3) | 33.9 (1.3) | 33.0 (1.4) | 33.9 (1.0) | 33.3 (1.4) | 33.9 (1.1)
Median (Min-Max) | 33.6 (31.7 - 36.3) | 33.7 (31.8 - 35.8) | 33.0 (30.7 - 35.2) | 34.2 (32.7 - 35.0) | 33.6 (30.7 - 36.3) | 33.9 (31.8 - 35.8)
LOCF
N | 30 | 16 | 21 | 10 | 51 | 26
Mean (SD) | 33.5 (1.2) | 33.9 (1.2) | 33.1 (1.5) | 33.9 (1.0) | 33.3 (1.3) | 33.9 (1.1)
Median (Min-Max) | 33.4 (31.7 - 36.3) | 33.7 (31.8 - 35.8) | 33.5 (30.7 - 35.2) | 34.2 (32.7 - 35.0) | 33.5 (30.7 - 36.3) | 33.9 (31.8 - 35.8)
Change from Baseline to LOCF
N | 30 | 16 | 21 | 10 | 51 | 26
Mean (SD) | −0.5 (1.0) | 0.1 (0.6) | −0.6 (1.0) | 0.1 (0.4) | −0.5 (1.0) | 0.1 (0.5)
Median (Min-Max) | −0.5 (−3.1 - 1.7) | 0.0 (−0.8 - 1.5) | −0.6 (−2.9 - 1.4) | 0.1 (−0.7 - 0.7) | −0.5 (−3.1 - 1.7) | 0.1 (−0.8 - 1.5)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.1.1.8 Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Platelets Count (×10^3^/μL) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 282.2 (50.4) | 300.1 (80.2) | 274.9 (65.1) | 265.8 (55.8) | 279.3 (56.2) | 286.6 (72.5)
Median (Min-Max) | 275.0 (192.0 - 376.0) | 272.0 (130.0 - 471.0) | 263.0 (175.0 - 428.0) | 262.0 (175.0 - 362.0) | 270.0 (175.0 - 428.0) | 269.5 (130.0 - 471.0)
Week 2
N | 14 | 5 | 6 | 2 | 20 | 7
Mean (SD) | 302.4 (45.5) | 309.6 (20.5) | 278.7 (33.2) | 250.5 (3.5) | 295.3 (42.8) | 292.7 (33.4)
Median (Min-Max) | 301.5 (209.0 - 370.0) | 310.0 (290.0 - 338.0) | 275.5 (231.0 - 320.0) | 250.5 (248.0 - 253.0) | 296.0 (209.0 - 370.0) | 290.0 (248.0 - 338.0)
Week 4
N | 25 | 11 | 14 | 10 | 39 | 21
Mean (SD) | 330.8 (63.5) | 316.1 (56.9) | 317.9 (64.3) | 254.0 (50.8) | 326.2 (63.3) | 286.5 (61.6)
Median (Min-Max) | 333.0 (241.0 - 452.0) | 304.0 (244.0 - 403.0) | 301.5 (237.0 - 466.0) | 250.0 (160.0 - 329.0) | 332.0 (237.0 - 466.0) | 272.0 (160.0 - 403.0)
Week 8
N | 28 | 12 | 20 | 10 | 48 | 22
Mean (SD) | 305.8 (55.9) | 270.8 (56.6) | 303.3 (68.3) | 269.5 (88.0) | 304.8 (60.7) | 270.2 (70.7)
Median (Min-Max) | 307.0 (210.0 - 408.0) | 274.5 (138.0 - 372.0) | 299.0 (205.0 - 439.0) | 271.0 (74.0 - 379.0) | 307.0 (205.0 - 439.0) | 274.5 (74.0 - 379.0)
LOCF
N | 30 | 16 | 21 | 10 | 51 | 26
Mean (SD) | 304.6 (55.4) | 287.8 (62.0) | 303.6 (66.5) | 269.5 (88.0) | 304.2 (59.6) | 280.7 (71.9)
Median (Min-Max) | 307.0 (210.0 - 408.0) | 278.0 (138.0 - 403.0) | 309.0 (205.0 - 439.0) | 271.0 (74.0 - 379.0) | 308.0 (205.0 - 439.0) | 278.0 (74.0 - 403.0)
Change from Baseline to LOCF
N | 30 | 16 | 21 | 10 | 51 | 26
Mean (SD) | 22.2 (47.9) | −9.3 (43.4) | 28.7 (43.2) | −1.6 (61.5) | 24.9 (45.7) | −6.3 (50.1)
Median (Min-Max) | 14.0 (−46.0 - 152.0) | −10.0 (−78.0 - 56.0) | 29.0 (−37.0 - 110.0) | −4.0 (−101 - 110.0) | 17.0 (−46.0 - 152.0) | −8.5 (−101 - 110.0)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.1.1.9 Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Red Blood Cell Distribution Width - RDW (%) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 19.0 (10.5) | 20.1 (11.4) | 14.2 (5.7) | 15.2 (8.3) | 17.1 (9.2) | 18.2 (10.4)
Median (Min-Max) | 13.3 (11.7 - 39.6) | 13.5 (11.5 - 39.0) | 12.8 (11.8 - 38.9) | 12.8 (12.1 - 40.2) | 13.1 (11.7 - 39.6) | 13.1 (11.5 - 40.2)
Week 2
N | 14 | 5 | 6 | 2 | 20 | 7
Mean (SD) | 18.3 (10.0) | 13.1 (1.1) | 12.3 (0.4) | 13.0 (0.2) | 16.5 (8.7) | 13.0 (0.9)
Median (Min-Max) | 13.7 (11.3 - 38.0) | 13.0 (11.7 - 14.4) | 12.3 (11.9 - 12.7) | 13.0 (12.8 - 13.1) | 13.1 (11.3 - 38.0) | 13.0 (11.7 - 14.4)
Week 4
N | 25 | 11 | 14 | 10 | 39 | 21
Mean (SD) | 17.2 (9.1) | 22.0 (12.1) | 15.4 (7.6) | 15.5 (8.4) | 16.6 (8.5) | 18.9 (10.8)
Median (Min-Max) | 13.4 (11.8 - 38.7) | 13.9 (11.6 - 39.6) | 13.4 (12.2 - 41.6) | 13.0 (12.1 - 39.5) | 13.4 (11.8 - 41.6) | 13.2 (11.6 - 39.6)
Week 8
N | 28 | 12 | 20 | 10 | 48 | 22
Mean (SD) | 20.5 (11.8) | 21.2 (12.3) | 14.8 (6.6) | 15.5 (8.4) | 18.1 (10.3) | 18.6 (10.9)
Median (Min-Max) | 13.6 (11.5 - 41.0) | 13.4 (11.6 - 39.8) | 13.4 (12.1 - 42.8) | 12.7 (12.0 - 39.3) | 13.4 (11.5 - 42.8) | 13.3 (11.6 - 39.8)
LOCF
N | 30 | 16 | 21 | 10 | 51 | 26
Mean (SD) | 20.1 (11.5) | 20.8 (11.7) | 14.6 (6.5) | 15.5 (8.4) | 17.8 (10.0) | 18.8 (10.7)
Median (Min-Max) | 13.6 (11.5 - 41.0) | 13.6 (11.6 - 39.8) | 13.4 (11.9 - 42.8) | 12.7 (12.0 - 39.3) | 13.4 (11.5 - 42.8) | 13.4 (11.6 - 39.8)
Change from Baseline to LOCF
N | 30 | 16 | 21 | 10 | 51 | 26
Mean (SD) | 0.7 (1.3) | 0.2 (0.8) | 0.4 (1.2) | 0.1 (0.6) | 0.6 (1.2) | 0.1 (0.7)
Median (Min-Max) | 0.5 (−1.2 - 4.2) | 0.1 (−1.5 - 2.4) | 0.3 (−1.4 - 3.9) | 0.1 (−0.9 - 0.8) | 0.5 (−1.4 - 4.2) | 0.1 (−1.5 - 2.4)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.1.1.10 Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Mean Platelet Volume (fL) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 31 | 17 | 18 | 10 | 49 | 27
Mean (SD) | 9.8 (1.0) | 10.2 (1.1) | 9.4 (1.6) | 9.8 (1.7) | 9.7 (1.2) | 10.0 (1.3)
Median (Min-Max) | 9.9 (6.9 - 11.8) | 10.2 (7.5 - 12.2) | 9.4 (6.4 - 12.1) | 10.1 (7.2 - 11.8) | 9.8 (6.4 - 12.1) | 10.2 (7.2 - 12.2)
Week 2
N | 14 | 5 | 5 | 2 | 19 | 7
Mean (SD) | 9.8 (1.0) | 10.0 (1.9) | 9.6 (1.5) | 10.1 (0.1) | 9.8 (1.1) | 10.0 (1.5)
Median (Min-Max) | 10.0 (8.2 - 11.3) | 9.8 (7.7 - 12.9) | 9.5 (7.9 - 11.2) | 10.1 (10.0 - 10.2) | 9.8 (7.9 - 11.3) | 10.0 (7.7 - 12.9)
Week 4
N | 25 | 10 | 13 | 10 | 38 | 20
Mean (SD) | 9.8 (1.2) | 10.4 (1.4) | 9.6 (1.9) | 9.6 (1.5) | 9.7 (1.4) | 10.0 (1.5)
Median (Min-Max) | 9.9 (7.1 - 11.6) | 10.2 (8.1 - 12.4) | 9.7 (5.9 - 12.8) | 9.5 (7.1 - 12.0) | 9.9 (5.9 - 12.8) | 9.7 (7.1 - 12.4)
Week 8
N | 28 | 11 | 18 | 8 | 46 | 19
Mean (SD) | 9.9 (0.9) | 10.1 (1.3) | 9.6 (1.7) | 9.2 (1.6) | 9.7 (1.3) | 9.7 (1.5)
Median (Min-Max) | 9.9 (7.1 - 11.9) | 9.9 (7.7 - 12.6) | 9.7 (6.2 - 13.7) | 9.4 (7.0 - 11.3) | 9.9 (6.2 - 13.7) | 9.7 (7.0 - 12.6)
LOCF
N | 30 | 15 | 19 | 8 | 49 | 23
Mean (SD) | 9.8 (1.1) | 10.1 (1.2) | 9.7 (1.7) | 9.2 (1.6) | 9.8 (1.3) | 9.8 (1.4)
Median (Min-Max) | 9.9 (7.1 - 11.9) | 9.9 (7.7 - 12.6) | 9.9 (6.2 - 13.7) | 9.4 (7.0 - 11.3) | 9.9 (6.2 - 13.7) | 9.7 (7.0 - 12.6)
Change from Baseline to LOCF
N | 30 | 15 | 18 | 7 | 48 | 22
Mean (SD) | 0.0 (0.6) | 0.0 (0.3) | 0.2 (0.7) | −0.2 (0.3) | 0.1 (0.7) | −0.1 (0.3)
Median (Min-Max) | −0.1 (−1.4 - 1.4) | −0.1 (−0.6 - 0.6) | −0.1 (−0.9 - 1.6) | −0.1 (−0.6 - 0.1) | −0.1 (−1.4 - 1.6) | −0.1 (−0.6 - 0.6)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.1.1.11 Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Neutrophils (%) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 31 | 16 | 19 | 11 | 50 | 27
Mean (SD) | 43.4 (12.6) | 43.5 (9.0) | 51.7 (12.4) | 50.5 (9.9) | 46.5 (13.1) | 46.4 (9.8)
Median (Min-Max) | 43.9 (3.1 - 78.5) | 44.0 (25.5 - 56.4) | 56.0 (27.0 - 72.6) | 53.8 (33.7 - 68.0) | 46.6 (3.1 - 78.5) | 45.4 (25.5 - 68.0)
Week 2
N | 14 | 4 | 4 | 2 | 18 | 6
Mean (SD) | 51.8 (8.8) | 38.0 (5.3) | 56.1 (6.9) | 40.2 (9.4) | 52.7 (8.5) | 38.7 (6.0)
Median (Min-Max) | 54.6 (34.3 - 65.3) | 39.2 (30.6 - 43.0) | 57.1 (48.1 - 62.0) | 40.2 (33.5 - 46.8) | 54.6 (34.3 - 65.3) | 39.2 (30.6 - 46.8)
Week 4
N | 25 | 10 | 13 | 10 | 38 | 20
Mean (SD) | 57.4 (8.6) | 55.5 (10.0) | 65.3 (8.0) | 50.0 (10.1) | 60.1 (9.1) | 52.7 (10.2)
Median (Min-Max) | 58.2 (37.5 - 69.0) | 55.5 (40.6 - 71.3) | 66.2 (51.9 - 76.3) | 52.6 (32.9 - 62.9) | 60.1 (37.5 - 76.3) | 53.6 (32.9 - 71.3)
Week 8
N | 28 | 11 | 17 | 10 | 45 | 21
Mean (SD) | 56.3 (8.4) | 45.0 (11.0) | 65.9 (9.6) | 46.6 (10.5) | 59.9 (10.0) | 45.8 (10.5)
Median (Min-Max) | 56.9 (34.5 - 70.5) | 46.7 (23.5 - 63.7) | 69.0 (42.7 - 82.2) | 50.7 (32.5 - 62.6) | 59.4 (34.5 - 82.2) | 46.7 (23.5 - 63.7)
LOCF
N | 30 | 15 | 18 | 10 | 48 | 25
Mean (SD) | 56.2 (8.1) | 46.1 (10.7) | 65.7 (9.4) | 46.6 (10.5) | 59.8 (9.7) | 46.3 (10.4)
Median (Min-Max) | 56.9 (34.5 - 70.5) | 46.7 (23.5 - 63.7) | 68.0 (42.7 - 82.2) | 50.7 (32.5 - 62.6) | 59.4 (34.5 - 82.2) | 46.7 (23.5 - 63.7)
Change from Baseline to LOCF
N | 30 | 15 | 17 | 10 | 47 | 25
Mean (SD) | 12.5 (14.3) | 2.6 (5.7) | 12.9 (14.3) | −2.2 (7.5) | 12.7 (14.1) | 0.7 (6.8)
Median (Min-Max) | 12.4 (−28.5 - 56.3) | 2.9 (−11.2 - 10.5) | 10.7 (−9.9 - 41.6) | −1.2 (−19.6 - 5.7) | 11.9 (−28.5 - 56.3) | 1.5 (−19.6 - 10.5)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.1.1.12 Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Lymphocytes (%) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 31 | 17 | 20 | 11 | 51 | 28
Mean (SD) | 44.2 (9.8) | 42.3 (9.3) | 38.6 (11.9) | 33.3 (13.6) | 42.0 (10.9) | 38.7 (11.8)
Median (Min-Max) | 43.8 (15.0 - 63.9) | 43.3 (29.0 - 62.6) | 36.9 (18.1 - 67.0) | 33.7 (2.2 - 53.8) | 41.9 (15.0 - 67.0) | 37.3 (2.2 - 62.6)
Week 2
N | 14 | 5 | 5 | 2 | 19 | 7
Mean (SD) | 35.2 (7.6) | 43.7 (10.6) | 31.6 (7.7) | 44.6 (3.4) | 34.2 (7.6) | 43.9 (8.8)
Median (Min-Max) | 34.5 (23.1 - 49.0) | 45.3 (27.0 - 56.2) | 33.5 (19.2 - 40.0) | 44.6 (42.2 - 47.0) | 33.5 (19.2 - 49.0) | 45.3 (27.0 - 56.2)
Week 4
N | 25 | 11 | 14 | 10 | 39 | 21
Mean (SD) | 31.8 (7.8) | 32.5 (9.2) | 24.8 (7.6) | 37.6 (9.0) | 29.3 (8.4) | 34.9 (9.2)
Median (Min-Max) | 31.0 (17.7 - 48.4) | 32.4 (16.4 - 51.1) | 24.2 (15.3 - 38.4) | 36.8 (24.4 - 54.1) | 28.8 (15.3 - 48.4) | 34.8 (16.4 - 54.1)
Week 8
N | 28 | 12 | 18 | 10 | 46 | 22
Mean (SD) | 32.7 (7.8) | 41.6 (10.8) | 23.8 (9.0) | 40.3 (9.9) | 29.2 (9.3) | 41.0 (10.2)
Median (Min-Max) | 32.8 (18.6 - 48.8) | 40.8 (22.0 - 62.9) | 23.4 (10.8 - 44.6) | 36.0 (28.6 - 55.7) | 28.2 (10.8 - 48.8) | 39.1 (22.0 - 62.9)
LOCF
N | 30 | 16 | 19 | 10 | 49 | 26
Mean (SD) | 32.7 (7.5) | 40.9 (10.5) | 24.1 (8.9) | 40.3 (9.9) | 29.4 (9.0) | 40.6 (10.1)
Median (Min-Max) | 32.8 (18.6 - 48.8) | 40.8 (22.0 - 62.9) | 23.9 (10.8 - 44.6) | 36.0 (28.6 - 55.7) | 28.9 (10.8 - 48.8) | 39.1 (22.0 - 62.9)
Change from Baseline to LOCF
N | 30 | 16 | 18 | 10 | 48 | 26
Mean (SD) | −11.2 (11.2) | −1.3 (5.9) | −13.3 (12.8) | 5.8 (14.8) | −12.0 (11.7) | 1.4 (10.6)
Median (Min-Max) | −11.5 (−24.4 - 24.6) | −3.2 (−7.1 - 13.0) | −12.2 (−39.5 - 5.3) | −0.4 (−4.6 - 43.2) | −12.0 (−39.5 - 24.6) | −1.6 (−7.1 - 43.2)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.1.1.13 Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Monocytes (%) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 31 | 17 | 20 | 11 | 51 | 28
Mean (SD) | 7.2 (2.0) | 8.2 (2.0) | 6.6 (2.0) | 7.1 (3.2) | 7.0 (2.0) | 7.8 (2.6)
Median (Min-Max) | 6.9 (4.4 - 14.0) | 8.4 (4.3 - 13.7) | 6.7 (3.0 - 11.6) | 7.3 (0.4 - 12.7) | 6.8 (3.0 - 14.0) | 7.9 (0.4 - 13.7)
Week 2
N | 14 | 5 | 5 | 2 | 19 | 7
Mean (SD) | 7.3 (1.6) | 8.2 (1.5) | 8.3 (2.5) | 11.4 (3.9) | 7.6 (1.9) | 9.1 (2.5)
Median (Min-Max) | 7.5 (4.7 - 9.8) | 8.2 (6.0 - 10.3) | 7.0 (6.0 - 11.5) | 11.4 (8.6 - 14.1) | 7.3 (4.7 - 11.5) | 8.3 (6.0 - 14.1)
Week 4
N | 25 | 11 | 14 | 10 | 39 | 21
Mean (SD) | 6.1 (1.3) | 8.1 (2.0) | 6.5 (1.9) | 8.2 (2.1) | 6.2 (1.5) | 8.2 (2.0)
Median (Min-Max) | 5.9 (4.4 - 9.0) | 8.0 (6.0 - 12.0) | 7.0 (3.6 - 10.7) | 8.5 (5.6 - 12.1) | 6.1 (3.6 - 10.7) | 8.0 (5.6 - 12.1)
Week 8
N | 28 | 12 | 18 | 10 | 46 | 22
Mean (SD) | 6.9 (1.5) | 7.2 (2.1) | 6.5 (2.0) | 7.7 (2.2) | 6.7 (1.7) | 7.4 (2.1)
Median (Min-Max) | 7.0 (3.8 - 9.9) | 6.7 (4.4 - 10.6) | 6.0 (4.0 - 11.1) | 7.6 (4.2 - 11.9) | 6.6 (3.8 - 11.1) | 7.3 (4.2 - 11.9)
LOCF
N | 30 | 16 | 19 | 10 | 49 | 26
Mean (SD) | 6.8 (1.5) | 7.4 (2.2) | 6.4 (1.9) | 7.7 (2.2) | 6.7 (1.7) | 7.5 (2.2)
Median (Min-Max) | 7.0 (3.8 - 9.9) | 6.8 (4.4 - 12.0) | 6.0 (4.0 - 11.1) | 7.6 (4.2 - 11.9) | 6.5 (3.8 - 11.1) | 7.3 (4.2 - 12.0)
Change from Baseline to LOCF
N | 30 | 16 | 18 | 10 | 48 | 26
Mean (SD) | −0.4 (1.9) | −0.9 (2.3) | −0.2 (1.9) | 0.7 (5.0) | −0.3 (1.9) | −0.3 (3.5)
Median (Min-Max) | −0.3 (−5.0 - 3.2) | −1.1 (−4.2 - 3.0) | −0.3 (−5.0 - 3.0) | 0.2 (−5.8 - 11.5) | −0.3 (−5.0 - 3.2) | −0.1 (−5.8 - 11.5)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.1.1.14 Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Eosinophils (%) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 31 | 17 | 20 | 11 | 51 | 28
Mean (SD) | 3.1 (1.8) | 4.3 (2.9) | 2.8 (2.4) | 3.6 (1.7) | 3.0 (2.0) | 4.0 (2.5)
Median (Min-Max) | 2.8 (0.4 - 8.4) | 3.4 (0.3 - 12.5) | 2.2 (0.8 - 12.3) | 3.6 (1.6 - 6.4) | 2.5 (0.4 - 12.3) | 3.5 (0.3 - 12.5)
Week 2
N | 14 | 5 | 5 | 2 | 19 | 7
Mean (SD) | 4.7 (2.1) | 4.6 (2.8) | 4.8 (2.9) | 3.0 (1.8) | 4.7 (2.2) | 4.1 (2.6)
Median (Min-Max) | 4.3 (0.2 - 8.5) | 4.0 (2.0 - 9.4) | 5.1 (1.0 - 8.2) | 3.0 (1.7 - 4.3) | 4.3 (0.2 - 8.5) | 4.0 (1.7 - 9.4)
Week 4
N | 25 | 11 | 14 | 10 | 39 | 21
Mean (SD) | 4.0 (1.6) | 2.9 (2.0) | 3.8 (1.8) | 3.8 (2.7) | 3.9 (1.6) | 3.3 (2.4)
Median (Min-Max) | 3.7 (1.5 - 8.0) | 2.1 (0.8 - 7.4) | 4.0 (1.1 - 7.0) | 2.8 (1.3 - 8.7) | 3.8 (1.1 - 8.0) | 2.7 (0.8 - 8.7)
Week 8
N | 28 | 12 | 18 | 10 | 46 | 22
Mean (SD) | 3.5 (1.8) | 4.5 (3.4) | 3.6 (1.9) | 4.6 (2.5) | 3.5 (1.8) | 4.6 (3.0)
Median (Min-Max) | 3.1 (0.2 - 7.0) | 3.7 (1.3 - 12.5) | 3.2 (0.5 - 8.8) | 3.5 (2.1 - 9.2) | 3.2 (0.2 - 8.8) | 3.5 (1.3 - 12.5)
LOCF
N | 30 | 16 | 19 | 10 | 49 | 26
Mean (SD) | 3.5 (1.7) | 4.3 (3.4) | 3.4 (2.0) | 4.6 (2.5) | 3.5 (1.8) | 4.4 (3.0)
Median (Min-Max) | 3.3 (0.2 - 7.0) | 3.2 (1.2 - 12.5) | 3.1 (0.5 - 8.8) | 3.5 (2.1 - 9.2) | 3.2 (0.2 - 8.8) | 3.3 (1.2 - 12.5)
Change from Baseline to LOCF
N | 30 | 16 | 18 | 10 | 48 | 26
Mean (SD) | 0.5 (1.9) | 0.0 (2.2) | 0.5 (3.0) | 0.8 (2.4) | 0.5 (2.3) | 0.3 (2.3)
Median (Min-Max) | 0.2 (−1.9 - 6.0) | −0.6 (−4.3 - 4.2) | 0.8 (−7.1 - 6.9) | 0.8 (−2.2 - 6.5) | 0.4 (−7.1 - 6.9) | −0.3 (−4.3 - 6.5)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.1.1.15 Summary of Clinical Laboratory Hematology Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Basophils (%) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 31 | 17 | 20 | 11 | 51 | 28
Mean (SD) | 0.5 (0.4) | 0.7 (0.3) | 0.4 (0.3) | 0.6 (0.4) | 0.5 (0.4) | 0.7 (0.4)
Median (Min-Max) | 0.4 (0.0 - 1.5) | 0.8 (0.3 - 1.4) | 0.4 (0.0 - 1.0) | 0.5 (0.2 - 1.3) | 0.4 (0.0 - 1.5) | 0.7 (0.2 - 1.4)
Week 2
N | 14 | 5 | 5 | 2 | 19 | 7
Mean (SD) | 0.6 (0.4) | 0.7 (0.4) | 0.8 (0.3) | 0.8 (0.1) | 0.7 (0.4) | 0.7 (0.4)
Median (Min-Max) | 0.6 (0.2 - 1.7) | 0.8 (0.0 - 1.1) | 0.9 (0.4 - 1.0) | 0.8 (0.7 - 0.9) | 0.6 (0.2 - 1.7) | 0.8 (0.0 - 1.1)
Week 4
N | 24 | 11 | 14 | 10 | 38 | 21
Mean (SD) | 0.5 (0.4) | 0.5 (0.4) | 0.5 (0.3) | 0.5 (0.2) | 0.5 (0.4) | 0.5 (0.3)
Median (Min-Max) | 0.4 (0.0 - 1.7) | 0.4 (0.0 - 1.1) | 0.3 (0.0 - 1.0) | 0.4 (0.2 - 1.0) | 0.4 (0.0 - 1.7) | 0.4 (0.0 - 1.1)
Week 8
N | 27 | 12 | 18 | 10 | 45 | 22
Mean (SD) | 0.4 (0.3) | 0.6 (0.3) | 0.5 (0.4) | 0.7 (0.4) | 0.4 (0.3) | 0.6 (0.3)
Median (Min-Max) | 0.4 (0.0 - 1.1) | 0.6 (0.0 - 1.2) | 0.4 (0.0 - 1.2) | 0.5 (0.2 - 1.3) | 0.4 (0.0 - 1.2) | 0.5 (0.0 - 1.3)
LOCF
N | 29 | 16 | 19 | 10 | 48 | 26
Mean (SD) | 0.4 (0.3) | 0.6 (0.3) | 0.5 (0.4) | 0.7 (0.4) | 0.5 (0.4) | 0.6 (0.3)
Median (Min-Max) | 0.4 (0.0 - 1.7) | 0.6 (0.0 - 1.2) | 0.4 (0.0 - 1.2) | 0.5 (0.2 - 1.3) | 0.4 (0.0 - 1.7) | 0.5 (0.0 - 1.3)
Change from Baseline to LOCF
N | 29 | 16 | 18 | 10 | 47 | 26
Mean (SD) | −0.1 (0.4) | −0.2 (0.3) | 0.0 (0.4) | 0.1 (0.3) | −0.1 (0.4) | 0.0 (0.3)
Median (Min-Max) | 0.0 (−1.0 - 0.5) | −0.1 (−1.0 - 0.3) | 0.0 (−0.7 - 1.0) | 0.2 (−0.2 - 0.6) | 0.0 (−1.0 - 1.0) | 0.0 (−1.0 - 0.6)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.1.2.1A Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata White Blood Count (×10^3^/μL) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 28 | 15 | 43
Mean (SD) | 7.4 (1.9) | 7.9 (3.8) | 7.6 (2.7)
Median (Min-Max) | 7.2 (3.1 - 12.4) | 7.7 (2.7 - 18.5) | 7.2 (2.7 - 18.5)
Week 4
N | 24 | 14 | 38
Mean (SD) | 9.3 (2.3) | 8.1 (3.2) | 8.9 (2.7)
Median (Min-Max) | 9.4 (4.9 - 12.9) | 6.9 (3.5 - 14.5) | 8.9 (3.5 - 14.5)
Week 8
N | 25 | 13 | 38
Mean (SD) | 9.1 (3.5) | 8.9 (3.3) | 9.0 (3.4)
Median (Min-Max) | 9.0 (3.9 - 22.0) | 9.3 (4.0 - 14.6) | 9.1 (3.9 - 22.0)
Week 16
N | 21 | 7 | 28
Mean (SD) | 8.9 (2.5) | 9.5 (2.8) | 9.1 (2.6)
Median (Min-Max) | 8.9 (5.5 - 15.7) | 8.1 (6.8 - 13.7) | 8.8 (5.5 - 15.7)
Week 24
N | 17 | 6 | 23
Mean (SD) | 7.4 (1.8) | 7.6 (3.0) | 7.4 (2.1)
Median (Min-Max) | 6.9 (4.2 - 11.3) | 6.7 (4.8 - 11.8) | 6.9 (4.2 - 11.8)
LOCF
N | 27 | 14 | 41
Mean (SD) | 7.7 (1.9) | 7.5 (2.8) | 7.6 (2.2)
Median (Min-Max) | 7.0 (4.2 - 11.3) | 7.1 (3.6 - 12.5) | 7.0 (3.6 - 12.5)
Change from Baseline to LOCF
N | 26 | 14 | 40
Mean (SD) | 0.2 (1.6) | −0.6 (2.8) | −0.1 (2.1)
Median (Min-Max) | 0.2 (−3.6 - 3.5) | −0.3 (−6.0 - 3.2) | 0.2 (−6.0 - 3.5)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.2A Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata Red Blood Count (×10^6^/μL) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 28 | 15 | 43
Mean (SD) | 4.6 (0.3) | 4.6 (0.5) | 4.6 (0.4)
Median (Min-Max) | 4.5 (4.1 - 5.5) | 4.5 (3.8 - 5.3) | 4.5 (3.8 - 5.5)
Week 4
N | 24 | 14 | 38
Mean (SD) | 4.4 (0.4) | 4.5 (0.4) | 4.5 (0.4)
Median (Min-Max) | 4.5 (3.8 - 5.6) | 4.6 (3.8 - 5.1) | 4.5 (3.8 - 5.6)
Week 8
N | 25 | 13 | 38
Mean (SD) | 4.5 (0.3) | 4.6 (0.4) | 4.5 (0.4)
Median (Min-Max) | 4.5 (4.0 - 5.5) | 4.7 (4.0 - 5.2) | 4.5 (4.0 - 5.5)
Week 16
N | 21 | 7 | 28
Mean (SD) | 4.5 (0.4) | 4.6 (0.5) | 4.5 (0.4)
Median (Min-Max) | 4.4 (3.8 - 5.8) | 4.4 (4.1 - 5.3) | 4.4 (3.8 - 5.8)
Week 24
N | 17 | 6 | 23
Mean (SD) | 4.6 (0.5) | 4.7 (0.5) | 4.7 (0.5)
Median (Min-Max) | 4.6 (4.0 - 5.9) | 4.6 (3.9 - 5.3) | 4.6 (3.9 - 5.9)
LOCF
N | 27 | 14 | 41
Mean (SD) | 4.6 (0.4) | 4.7 (0.4) | 4.6 (0.4)
Median (Min-Max) | 4.5 (4.0 - 5.9) | 4.7 (3.9 - 5.3) | 4.6 (3.9 - 5.9)
Change from Baseline to LOCF
N | 26 | 14 | 40
Mean (SD) | 0.0 (0.4) | 0.1 (0.2) | 0.1 (0.3)
Median (Min-Max) | 0.0 (−1.4 - 0.9) | 0.1 (−0.3 - 0.6) | 0.1 (−1.4 - 0.9)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.3A Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata Hemoglobin (g/dL) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 28 | 15 | 43
Mean (SD) | 12.9 (0.8) | 13.2 (1.2) | 13.0 (0.9)
Median (Min-Max) | 12.9 (11.5 - 14.5) | 13.1 (11.5 - 15.4) | 12.9 (11.5 - 15.4)
Week 4
N | 24 | 14 | 38
Mean (SD) | 12.4 (0.8) | 13.0 (0.6) | 12.6 (0.8)
Median (Min-Max) | 12.5 (10.5 - 14.3) | 13.0 (12.2 - 14.4) | 12.7 (10.5 - 14.4)
Week 8
N | 25 | 13 | 38
Mean (SD) | 12.7 (0.8) | 13.3 (0.9) | 12.9 (0.9)
Median (Min-Max) | 12.7 (11.0 - 14.0) | 13.4 (12.2 - 15.0) | 12.9 (11.0 - 15.0)
Week 16
N | 21 | 7 | 28
Mean (SD) | 12.6 (0.8) | 13.3 (0.8) | 12.8 (0.8)
Median (Min-Max) | 12.4 (10.8 - 13.9) | 12.9 (12.8 - 15.1) | 12.8 (10.8 - 15.1)
Week 24
N | 17 | 6 | 23
Mean (SD) | 13.0 (1.3) | 13.7 (1.0) | 13.2 (1.2)
Median (Min-Max) | 12.8 (11.5 - 17.0) | 13.7 (12.6 - 14.9) | 13.0 (11.5 - 17.0)
LOCF
N | 27 | 14 | 41
Mean (SD) | 12.8 (1.1) | 13.4 (1.0) | 13.0 (1.1)
Median (Min-Max) | 12.6 (11.5 - 17.0) | 13.3 (11.8 - 15.0) | 12.8 (11.5 - 17.0)
Change from Baseline to LOCF
N | 26 | 14 | 40
Mean (SD) | 0.0 (0.8) | 0.4 (0.6) | 0.2 (0.8)
Median (Min-Max) | −0.2 (−2.3 - 2.5) | 0.4 (−0.5 - 1.9) | 0.1 (−2.3 - 2.5)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.4A Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata Hematocrit (%) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 28 | 15 | 43
Mean (SD) | 38.2 (2.0) | 39.4 (3.1) | 38.6 (2.5)
Median (Min-Max) | 38.0 (35.0 - 42.9) | 38.6 (34.8 - 44.2) | 38.4 (34.8 - 44.2)
Week 4
N | 24 | 14 | 38
Mean (SD) | 37.3 (2.1) | 39.3 (2.9) | 38.0 (2.6)
Median (Min-Max) | 37.6 (33.4 - 41.5) | 40.0 (34.5 - 43.3) | 37.8 (33.4 - 43.3)
Week 8
N | 25 | 13 | 38
Mean (SD) | 38.1 (1.8) | 40.6 (3.9) | 39.0 (2.9)
Median (Min-Max) | 38.7 (34.9 - 41.4) | 40.1 (34.2 - 47.4) | 38.7 (34.2 - 47.4)
Week 16
N | 21 | 7 | 28
Mean (SD) | 38.0 (2.0) | 40.5 (3.7) | 38.6 (2.7)
Median (Min-Max) | 37.7 (33.1 - 40.9) | 39.4 (36.3 - 46.7) | 38.1 (33.1 - 46.7)
Week 24
N | 17 | 6 | 23
Mean (SD) | 39.0 (3.0) | 40.9 (4.4) | 39.5 (3.4)
Median (Min-Max) | 38.4 (36.4 - 48.6) | 41.4 (34.6 - 46.7) | 38.6 (34.6 - 48.6)
LOCF
N | 27 | 14 | 41
Mean (SD) | 38.8 (2.6) | 41.0 (3.9) | 39.6 (3.2)
Median (Min-Max) | 38.6 (34.5 - 48.6) | 40.9 (34.6 - 47.4) | 39.0 (34.5 - 48.6)
Change from Baseline to LOCF
N | 26 | 14 | 40
Mean (SD) | 0.8 (2.3) | 1.9 (2.0) | 1.2 (2.2)
Median (Min-Max) | 0.6 (−5.9 - 7.3) | 1.4 (−2.1 - 6.3) | 1.0 (−5.9 - 7.3)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.5A Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata Mean Corpuscular Volume - MCV (fL) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 28 | 15 | 43
Mean (SD) | 83.7 (4.8) | 86.8 (4.4) | 84.8 (4.8)
Median (Min-Max) | 84.6 (65.6 - 90.1) | 86.0 (81.3 - 94.0) | 85.0 (65.6 - 94.0)
Week 4
N | 24 | 14 | 38
Mean (SD) | 84.4 (5.0) | 87.6 (4.4) | 85.5 (5.0)
Median (Min-Max) | 84.8 (65.4 - 90.3) | 87.2 (81.1 - 95.5) | 85.9 (65.4 - 95.5)
Week 8
N | 25 | 13 | 38
Mean (SD) | 84.6 (5.0) | 88.9 (4.6) | 86.1 (5.2)
Median (Min-Max) | 86.0 (64.9 - 90.2) | 89.6 (81.3 - 97.0) | 86.4 (64.9 - 97.0)
Week 16
N | 21 | 7 | 28
Mean (SD) | 84.6 (5.2) | 88.0 (4.1) | 85.4 (5.1)
Median (Min-Max) | 85.4 (64.7 - 89.2) | 87.2 (82.4 - 95.4) | 86.2 (64.7 - 95.4)
Week 24
N | 17 | 6 | 23
Mean (SD) | 84.7 (6.3) | 87.1 (4.2) | 85.3 (5.8)
Median (Min-Max) | 85.6 (64.8 - 93.4) | 86.2 (82.9 - 94.6) | 85.6 (64.8 - 94.6)
LOCF
N | 27 | 14 | 41
Mean (SD) | 84.9 (5.3) | 88.1 (4.8) | 86.0 (5.3)
Median (Min-Max) | 86.0 (64.8 - 93.4) | 86.8 (81.2 - 97.0) | 86.0 (64.8 - 97.0)
Change from Baseline to LOCF
N | 26 | 14 | 40
Mean (SD) | 1.5 (3.0) | 1.2 (3.1) | 1.4 (3.0)
Median (Min-Max) | 1.0 (−2.1 - 13.2) | 1.3 (−4.4 - 5.6) | 1.0 (−4.4 - 13.2)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.6A Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata Mean Corpuscular Hemoglobin - MCH (pg) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 28 | 14 | 42
Mean (SD) | 28.3 (1.9) | 29.0 (2.0) | 28.5 (1.9)
Median (Min-Max) | 28.7 (21.1 - 30.9) | 29.1 (26.1 - 32.0) | 28.7 (21.1 - 32.0)
Week 4
N | 24 | 14 | 38
Mean (SD) | 28.0 (1.9) | 29.2 (1.9) | 28.5 (1.9)
Median (Min-Max) | 28.2 (21.4 - 31.2) | 29.4 (26.6 - 31.9) | 28.3 (21.4 - 31.9)
Week 8
N | 25 | 13 | 38
Mean (SD) | 28.1 (1.7) | 29.3 (2.0) | 28.5 (1.9)
Median (Min-Max) | 28.3 (21.2 - 30.3) | 29.8 (26.4 - 32.1) | 28.4 (21.2 - 32.1)
Week 16
N | 20 | 7 | 27
Mean (SD) | 28.1 (1.9) | 28.9 (2.3) | 28.3 (2.0)
Median (Min-Max) | 28.5 (21.3 - 30.4) | 29.1 (25.8 - 31.3) | 28.7 (21.3 - 31.3)
Week 24
N | 17 | 6 | 23
Mean (SD) | 28.1 (2.1) | 29.2 (2.5) | 28.4 (2.2)
Median (Min-Max) | 28.6 (20.9 - 30.2) | 28.3 (26.4 - 32.7) | 28.6 (20.9 - 32.7)
LOCF
N | 27 | 14 | 41
Mean (SD) | 28.1 (1.8) | 28.9 (2.1) | 28.4 (1.9)
Median (Min-Max) | 28.6 (20.9 - 30.2) | 28.3 (26.1 - 32.7) | 28.6 (20.9 - 32.7)
Change from Baseline to LOCF
N | 26 | 14 | 40
Mean (SD) | −0.1 (0.9) | −0.1 (0.8) | −0.1 (0.9)
Median (Min-Max) | −0.2 (−1.6 - 3.3) | −0.1 (−1.6 - 1.9) | −0.1 (−1.6 - 3.3)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.7A Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata Mean Corpuscular Hemoglobin Concentration - MCHC (g/dL) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 28 | 15 | 43
Mean (SD) | 33.8 (1.2) | 33.4 (1.4) | 33.6 (1.3)
Median (Min-Max) | 33.7 (31.7 - 35.8) | 33.9 (31.2 - 35.2) | 33.8 (31.2 - 35.8)
Week 4
N | 24 | 14 | 38
Mean (SD) | 33.3 (1.1) | 33.3 (1.5) | 33.3 (1.3)
Median (Min-Max) | 33.2 (30.9 - 34.9) | 32.9 (31.1 - 35.8) | 33.1 (30.9 - 35.8)
Week 8
N | 25 | 13 | 38
Mean (SD) | 33.2 (1.0) | 33.0 (1.7) | 33.1 (1.3)
Median (Min-Max) | 33.1 (31.5 - 35.2) | 33.2 (29.5 - 35.6) | 33.2 (29.5 - 35.6)
Week 16
N | 21 | 7 | 28
Mean (SD) | 33.2 (1.1) | 32.8 (1.8) | 33.1 (1.2)
Median (Min-Max) | 33.3 (31.4 - 35.0) | 32.7 (30.0 - 35.2) | 33.1 (30.0 - 35.2)
Week 24
N | 17 | 6 | 23
Mean (SD) | 33.2 (1.2) | 33.6 (1.7) | 33.3 (1.3)
Median (Min-Max) | 33.6 (31.3 - 35.2) | 33.4 (31.8 - 36.3) | 33.6 (31.3 - 36.3)
LOCF
N | 27 | 14 | 41
Mean (SD) | 33.1 (1.1) | 32.8 (1.7) | 33.0 (1.3)
Median (Min-Max) | 32.9 (31.3 - 35.2) | 32.3 (29.5 - 36.3) | 32.8 (29.5 - 36.3)
Change from Baseline to LOCF
N | 26 | 14 | 40
Mean (SD) | −0.6 (0.5) | −0.5 (1.3) | −0.6 (0.9)
Median (Min-Max) | −0.6 (−1.5 - 0.5) | −0.6 (−3.0 - 1.6) | −0.6 (−3.0 - 1.6)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.8A Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata Platelets Count (×10^3^/μL) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 28 | 15 | 43
Mean (SD) | 296.8 (52.8) | 284.5 (78.6) | 292.5 (62.3)
Median (Min-Max) | 297.0 (210.0 - 408.0) | 286.0 (74.0 - 381.0) | 288.0 (74.0 - 408.0)
Week 4
N | 24 | 14 | 38
Mean (SD) | 319.3 (63.5) | 279.1 (42.8) | 304.5 (59.5)
Median (Min-Max) | 309.0 (229.0 - 447.0) | 292.0 (202.0 - 338.0) | 299.5 (202.0 - 447.0)
Week 8
N | 25 | 13 | 38
Mean (SD) | 332.4 (62.0) | 307.1 (66.7) | 323.7 (63.9)
Median (Min-Max) | 319.0 (222.0 - 460.0) | 314.0 (190.0 - 479.0) | 318.5 (190.0 - 479.0)
Week 16
N | 21 | 7 | 28
Mean (SD) | 329.4 (67.8) | 297.4 (50.7) | 321.4 (64.6)
Median (Min-Max) | 315.0 (216.0 - 482.0) | 300.0 (199.0 - 353.0) | 313.0 (199.0 - 482.0)
Week 24
N | 17 | 6 | 23
Mean (SD) | 312.2 (57.1) | 278.5 (51.7) | 303.4 (56.7)
Median (Min-Max) | 314.0 (228.0 - 409.0) | 295.0 (178.0 - 322.0) | 298.0 (178.0 - 409.0)
LOCF
N | 27 | 14 | 41
Mean (SD) | 318.6 (59.7) | 284.5 (46.3) | 307.0 (57.3)
Median (Min-Max) | 315.0 (228.0 - 422.0) | 289.5 (178.0 - 370.0) | 301.0 (178.0 - 422.0)
Change from Baseline to LOCF
N | 26 | 14 | 40
Mean (SD) | 19.4 (43.5) | 0.3 (67.5) | 12.7 (53.1)
Median (Min-Max) | 14.0 (−56.0 - 108.0) | 16.5 (−151 - 104.0) | 14.0 (−151 - 108.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.9A Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata Red Blood Cell Distribution Width - RDW (%) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 28 | 15 | 43
Mean (SD) | 21.4 (12.2) | 15.1 (7.7) | 19.2 (11.1)
Median (Min-Max) | 13.6 (11.6 - 41.0) | 13.5 (12.1 - 42.8) | 13.5 (11.6 - 42.8)
Week 4
N | 24 | 14 | 38
Mean (SD) | 20.6 (11.6) | 15.4 (7.8) | 18.7 (10.6)
Median (Min-Max) | 13.8 (11.6 - 41.4) | 13.4 (12.4 - 42.4) | 13.6 (11.6 - 42.4)
Week 8
N | 25 | 13 | 38
Mean (SD) | 20.1 (11.4) | 15.0 (7.8) | 18.4 (10.5)
Median (Min-Max) | 13.6 (11.6 - 43.3) | 13.1 (11.8 - 41.0) | 13.5 (11.6 - 43.3)
Week 16
N | 21 | 7 | 28
Mean (SD) | 20.3 (11.9) | 12.8 (0.9) | 18.5 (10.8)
Median (Min-Max) | 13.5 (11.4 - 43.4) | 12.7 (11.5 - 14.1) | 13.3 (11.4 - 43.4)
Week 24
N | 17 | 6 | 23
Mean (SD) | 20.4 (11.6) | 12.8 (0.7) | 18.4 (10.5)
Median (Min-Max) | 13.2 (11.7 - 40.3) | 12.9 (12.0 - 13.5) | 13.2 (11.7 - 40.3)
LOCF
N | 27 | 14 | 41
Mean (SD) | 20.4 (11.5) | 15.1 (7.9) | 18.6 (10.6)
Median (Min-Max) | 13.4 (11.7 - 40.3) | 13.2 (12.0 - 42.5) | 13.2 (11.7 - 42.5)
Change from Baseline to LOCF
N | 26 | 14 | 40
Mean (SD) | −0.3 (1.2) | −0.2 (0.5) | −0.3 (1.0)
Median (Min-Max) | −0.1 (−3.3 - 2.0) | −0.2 (−0.8 - 0.9) | −0.2 (−3.3 - 2.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.10A Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata Mean Platelet Volume (fL) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 27 | 13 | 40
Mean (SD) | 10.0 (1.2) | 9.3 (1.5) | 9.8 (1.3)
Median (Min-Max) | 9.9 (7.1 - 12.6) | 9.4 (6.2 - 11.6) | 9.9 (6.2 - 12.6)
Week 4
N | 23 | 14 | 37
Mean (SD) | 10.3 (1.1) | 9.8 (1.6) | 10.1 (1.4)
Median (Min-Max) | 10.1 (7.3 - 12.0) | 9.9 (6.0 - 11.7) | 10.1 (6.0 - 12.0)
Week 8
N | 24 | 13 | 37
Mean (SD) | 10.1 (1.1) | 9.6 (1.6) | 9.9 (1.3)
Median (Min-Max) | 10.1 (7.4 - 12.0) | 9.9 (6.2 - 12.1) | 9.9 (6.2 - 12.1)
Week 16
N | 20 | 7 | 27
Mean (SD) | 10.1 (1.2) | 9.2 (2.1) | 9.9 (1.5)
Median (Min-Max) | 10.4 (7.3 - 12.4) | 8.3 (6.4 - 12.3) | 10.3 (6.4 - 12.4)
Week 24
N | 16 | 6 | 22
Mean (SD) | 10.0 (1.5) | 8.6 (1.5) | 9.6 (1.6)
Median (Min-Max) | 10.1 (7.1 - 12.1) | 8.5 (6.4 - 10.7) | 9.9 (6.4 - 12.1)
LOCF
N | 26 | 14 | 40
Mean (SD) | 10.1 (1.2) | 9.6 (1.3) | 9.9 (1.3)
Median (Min-Max) | 10.2 (7.1 - 12.1) | 10.0 (6.4 - 11.0) | 10.1 (6.4 - 12.1)
Change from Baseline to LOCF
N | 24 | 13 | 37
Mean (SD) | 0.1 (0.5) | 0.2 (0.4) | 0.2 (0.5)
Median (Min-Max) | 0.3 (−0.6 - 1.1) | 0.2 (−0.6 - 0.8) | 0.2 (−0.6 - 1.1)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.11A Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata Neutrophils (%) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 27 | 13 | 40
Mean (SD) | 54.7 (9.3) | 57.5 (14.6) | 55.6 (11.1)
Median (Min-Max) | 56.6 (33.2 - 68.0) | 54.9 (33.2 - 82.2) | 56.4 (33.2 - 82.2)
Week 4
N | 23 | 13 | 36
Mean (SD) | 58.4 (10.4) | 61.1 (10.7) | 59.4 (10.5)
Median (Min-Max) | 62.6 (36.5 - 73.6) | 63.3 (40.7 - 75.0) | 62.9 (36.5 - 75.0)
Week 8
N | 23 | 12 | 35
Mean (SD) | 55.5 (15.0) | 63.9 (10.0) | 58.4 (13.9)
Median (Min-Max) | 58.4 (2.7 - 79.0) | 65.2 (46.9 - 76.4) | 60.8 (2.7 - 79.0)
Week 16
N | 20 | 6 | 26
Mean (SD) | 59.4 (7.6) | 65.8 (8.5) | 60.9 (8.1)
Median (Min-Max) | 58.0 (46.7 - 80.7) | 69.5 (52.1 - 74.0) | 59.9 (46.7 - 80.7)
Week 24
N | 16 | 5 | 21
Mean (SD) | 57.8 (9.3) | 63.6 (7.2) | 59.2 (9.1)
Median (Min-Max) | 60.3 (39.7 - 70.4) | 65.8 (56.0 - 72.6) | 60.6 (39.7 - 72.6)
LOCF
N | 25 | 12 | 37
Mean (SD) | 58.5 (9.0) | 61.0 (9.4) | 59.3 (9.1)
Median (Min-Max) | 60.0 (39.7 - 72.2) | 62.1 (41.9 - 74.3) | 60.0 (39.7 - 74.3)
Change from Baseline to LOCF
N | 24 | 12 | 36
Mean (SD) | 4.1 (9.6) | 3.1 (11.4) | 3.7 (10.1)
Median (Min-Max) | 4.9 (−14.7 - 22.7) | 3.3 (−17.9 - 28.8) | 4.0 (−17.9 - 28.8)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.12A Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata Lymphocytes (%) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 28 | 14 | 42
Mean (SD) | 33.9 (9.0) | 31.3 (12.9) | 33.0 (10.4)
Median (Min-Max) | 34.0 (18.6 - 55.5) | 30.5 (10.8 - 54.5) | 32.8 (10.8 - 55.5)
Week 4
N | 24 | 14 | 38
Mean (SD) | 29.4 (9.6) | 28.1 (8.5) | 28.9 (9.1)
Median (Min-Max) | 27.2 (13.4 - 50.2) | 27.6 (17.6 - 42.3) | 27.2 (13.4 - 50.2)
Week 8
N | 24 | 13 | 37
Mean (SD) | 30.7 (9.0) | 26.0 (8.4) | 29.0 (8.9)
Median (Min-Max) | 29.1 (11.7 - 46.9) | 23.0 (14.6 - 41.4) | 28.1 (11.7 - 46.9)
Week 16
N | 21 | 7 | 28
Mean (SD) | 29.6 (7.8) | 25.8 (8.6) | 28.7 (8.0)
Median (Min-Max) | 30.9 (9.4 - 42.6) | 20.6 (18.2 - 38.0) | 30.0 (9.4 - 42.6)
Week 24
N | 17 | 6 | 23
Mean (SD) | 30.5 (8.8) | 30.5 (10.8) | 30.5 (9.1)
Median (Min-Max) | 30.1 (19.0 - 49.3) | 27.4 (20.5 - 50.0) | 30.1 (19.0 - 50.0)
LOCF
N | 26 | 13 | 39
Mean (SD) | 30.2 (8.5) | 29.6 (10.0) | 30.0 (8.9)
Median (Min-Max) | 30.3 (17.2 - 49.3) | 24.5 (19.6 - 50.0) | 30.1 (17.2 - 50.0)
Change from Baseline to LOCF
N | 25 | 13 | 38
Mean (SD) | −4.0 (8.1) | −1.6 (12.7) | −3.2 (9.8)
Median (Min-Max) | −3.3 (−18.0 - 10.8) | −2.9 (−24.5 - 21.0) | −3.1 (−24.5 - 21.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.13A Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata Monocytes (%) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 28 | 14 | 42
Mean (SD) | 7.0 (1.7) | 6.5 (1.9) | 6.8 (1.7)
Median (Min-Max) | 7.0 (4.4 - 10.6) | 6.1 (4.2 - 11.1) | 6.7 (4.2 - 11.1)
Week 4
N | 24 | 14 | 38
Mean (SD) | 7.7 (1.7) | 6.6 (2.0) | 7.3 (1.9)
Median (Min-Max) | 7.9 (4.4 - 12.0) | 7.2 (3.7 - 9.3) | 7.7 (3.7 - 12.0)
Week 8
N | 24 | 13 | 37
Mean (SD) | 7.3 (2.0) | 6.8 (2.5) | 7.1 (2.1)
Median (Min-Max) | 7.0 (3.3 - 12.3) | 6.7 (3.5 - 11.5) | 6.9 (3.3 - 12.3)
Week 16
N | 21 | 7 | 28
Mean (SD) | 7.0 (1.4) | 6.3 (0.9) | 6.8 (1.3)
Median (Min-Max) | 7.0 (4.0 - 9.0) | 6.4 (5.2 - 7.7) | 6.9 (4.0 - 9.0)
Week 24
N | 17 | 6 | 23
Mean (SD) | 6.6 (1.4) | 6.4 (1.3) | 6.5 (1.3)
Median (Min-Max) | 6.3 (4.3 - 8.6) | 6.5 (4.3 - 8.0) | 6.3 (4.3 - 8.6)
LOCF
N | 26 | 13 | 39
Mean (SD) | 6.6 (1.4) | 6.9 (2.6) | 6.7 (1.8)
Median (Min-Max) | 6.2 (4.3 - 8.7) | 6.6 (3.9 - 13.3) | 6.3 (3.9 - 13.3)
Change from Baseline to LOCF
N | 25 | 13 | 38
Mean (SD) | −0.4 (1.7) | 0.5 (2.0) | −0.1 (1.9)
Median (Min-Max) | −0.5 (−3.0 - 3.2) | 0.9 (−2.6 - 3.9) | −0.2 (−3.0 - 3.9)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.14A Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata Eosinophils (%) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 28 | 14 | 42
Mean (SD) | 3.6 (1.9) | 3.9 (2.5) | 3.7 (2.1)
Median (Min-Max) | 3.3 (0.2 - 9.2) | 2.8 (1.4 - 9.2) | 3.1 (0.2 - 9.2)
Week 4
N | 24 | 14 | 38
Mean (SD) | 3.3 (1.5) | 3.8 (2.1) | 3.5 (1.7)
Median (Min-Max) | 3.2 (1.0 - 6.1) | 3.3 (1.0 - 8.7) | 3.2 (1.0 - 8.7)
Week 8
N | 24 | 13 | 37
Mean (SD) | 3.5 (2.4) | 3.4 (1.5) | 3.5 (2.1)
Median (Min-Max) | 3.3 (0.0 - 11.6) | 3.3 (1.4 - 6.2) | 3.3 (0.0 - 11.6)
Week 16
N | 21 | 7 | 28
Mean (SD) | 3.0 (1.4) | 3.5 (1.5) | 3.1 (1.4)
Median (Min-Max) | 3.1 (0.6 - 5.1) | 3.0 (1.6 - 6.2) | 3.1 (0.6 - 6.2)
Week 24
N | 17 | 6 | 23
Mean (SD) | 3.6 (1.9) | 3.5 (1.3) | 3.6 (1.7)
Median (Min-Max) | 3.2 (0.4 - 8.1) | 3.3 (2.0 - 5.7) | 3.2 (0.4 - 8.1)
LOCF
N | 26 | 13 | 39
Mean (SD) | 3.5 (1.9) | 3.6 (1.3) | 3.5 (1.7)
Median (Min-Max) | 3.2 (0.4 - 8.1) | 3.4 (1.8 - 6.1) | 3.2 (0.4 - 8.1)
Change from Baseline to LOCF
N | 25 | 13 | 38
Mean (SD) | −0.1 (2.5) | 0.0 (2.0) | −0.1 (2.3)
Median (Min-Max) | 0.1 (−6.6 - 3.7) | 0.6 (−6.2 - 1.4) | 0.4 (−6.6 - 3.7)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.15A Summary of Clinical Laboratory Hematology Measurement by Visit and Age Strata Basophils (%) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 27 | 14 | 41
Mean (SD) | 0.5 (0.3) | 0.5 (0.4) | 0.5 (0.3)
Median (Min-Max) | 0.4 (0.0 - 1.2) | 0.4 (0.0 - 1.3) | 0.4 (0.0 - 1.3)
Week 4
N | 24 | 14 | 38
Mean (SD) | 0.5 (0.3) | 0.5 (0.3) | 0.5 (0.3)
Median (Min-Max) | 0.5 (0.0 - 1.3) | 0.4 (0.0 - 1.2) | 0.4 (0.0 - 1.3)
Week 8
N | 24 | 13 | 37
Mean (SD) | 0.5 (0.4) | 0.6 (0.4) | 0.6 (0.4)
Median (Min-Max) | 0.5 (0.0 - 1.5) | 0.6 (0.2 - 1.2) | 0.5 (0.0 - 1.5)
Week 16
N | 21 | 7 | 28
Mean (SD) | 0.5 (0.4) | 1.8 (3.4) | 0.8 (1.7)
Median (Min-Max) | 0.4 (0.0 - 1.3) | 0.3 (0.0 - 9.4) | 0.4 (0.0 - 9.4)
Week 24
N | 17 | 6 | 23
Mean (SD) | 0.4 (0.3) | 0.4 (0.3) | 0.4 (0.3)
Median (Min-Max) | 0.4 (0.0 - 1.0) | 0.4 (0.0 - 0.9) | 0.4 (0.0 - 1.0)
LOCF
N | 26 | 13 | 39
Mean (SD) | 0.5 (0.3) | 0.5 (0.4) | 0.5 (0.3)
Median (Min-Max) | 0.4 (0.0 - 1.4) | 0.4 (0.0 - 1.2) | 0.4 (0.0 - 1.4)
Change from Baseline to LOCF
N | 24 | 13 | 37
Mean (SD) | 0.1 (0.4) | 0.0 (0.3) | 0.0 (0.4)
Median (Min-Max) | 0.0 (−1.0 - 1.0) | 0.0 (−0.4 - 0.7) | 0.0 (−1.0 - 1.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.1B Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received Group White Blood Count (×10^3^/μL) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 28 | 15 | 43
Mean (SD) | 8.5 (2.7) | 6.0 (1.8) | 7.6 (2.7)
Median (Min-Max) | 7.8 (5.2 - 18.5) | 7.0 (2.7 - 8.1) | 7.2 (2.7 - 18.5)
Week 4
N | 26 | 12 | 38
Mean (SD) | 8.9 (2.3) | 8.8 (3.6) | 8.9 (2.7)
Median (Min-Max) | 8.9 (5.9 - 13.0) | 9.5 (3.5 - 14.5) | 8.9 (3.5 - 14.5)
Week 8
N | 27 | 11 | 38
Mean (SD) | 9.4 (3.5) | 8.1 (3.1) | 9.0 (3.4)
Median (Min-Max) | 9.3 (4.8 - 22.0) | 8.1 (3.9 - 14.6) | 9.1 (3.9 - 22.0)
Week 16
N | 19 | 9 | 28
Mean (SD) | 9.1 (2.7) | 8.9 (2.5) | 9.1 (2.6)
Median (Min-Max) | 8.9 (5.5 - 15.7) | 8.7 (5.6 - 13.7) | 8.8 (5.5 - 15.7)
Week 24
N | 15 | 8 | 23
Mean (SD) | 7.7 (2.1) | 6.8 (1.9) | 7.4 (2.1)
Median (Min-Max) | 7.0 (4.8 - 11.8) | 6.7 (4.2 - 10.5) | 6.9 (4.2 - 11.8)
LOCF
N | 28 | 13 | 41
Mean (SD) | 8.0 (2.3) | 6.7 (1.9) | 7.6 (2.2)
Median (Min-Max) | 7.2 (4.8 - 12.5) | 6.8 (3.6 - 10.5) | 7.0 (3.6 - 12.5)
Change from Baseline to LOCF
N | 27 | 13 | 40
Mean (SD) | −0.4 (2.4) | 0.7 (1.3) | −0.1 (2.1)
Median (Min-Max) | −0.5 (−6.0 - 3.5) | 0.9 (−1.5 - 2.8) | 0.2 (−6.0 - 3.5)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.2B Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received Group Red Blood Count (×10^6^/μL) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 28 | 15 | 43
Mean (SD) | 4.5 (0.4) | 4.7 (0.3) | 4.6 (0.4)
Median (Min-Max) | 4.4 (3.8 - 5.5) | 4.7 (4.0 - 5.3) | 4.5 (3.8 - 5.5)
Week 4
N | 26 | 12 | 38
Mean (SD) | 4.4 (0.4) | 4.6 (0.3) | 4.5 (0.4)
Median (Min-Max) | 4.4 (3.8 - 5.6) | 4.6 (4.2 - 5.0) | 4.5 (3.8 - 5.6)
Week 8
N | 27 | 11 | 38
Mean (SD) | 4.5 (0.4) | 4.6 (0.3) | 4.5 (0.4)
Median (Min-Max) | 4.5 (4.0 - 5.5) | 4.6 (4.0 - 5.0) | 4.5 (4.0 - 5.5)
Week 16
N | 19 | 9 | 28
Mean (SD) | 4.5 (0.4) | 4.7 (0.3) | 4.5 (0.4)
Median (Min-Max) | 4.4 (3.8 - 5.8) | 4.7 (4.1 - 5.3) | 4.4 (3.8 - 5.8)
Week 24
N | 15 | 8 | 23
Mean (SD) | 4.5 (0.5) | 4.8 (0.5) | 4.7 (0.5)
Median (Min-Max) | 4.5 (3.9 - 5.7) | 4.7 (4.3 - 5.9) | 4.6 (3.9 - 5.9)
LOCF
N | 28 | 13 | 41
Mean (SD) | 4.5 (0.4) | 4.7 (0.4) | 4.6 (0.4)
Median (Min-Max) | 4.5 (3.9 - 5.7) | 4.7 (4.3 - 5.9) | 4.6 (3.9 - 5.9)
Change from Baseline to LOCF
N | 27 | 13 | 40
Mean (SD) | 0.1 (0.4) | 0.1 (0.3) | 0.1 (0.3)
Median (Min-Max) | 0.1 (−1.4 - 0.7) | 0.0 (−0.3 - 0.9) | 0.1 (−1.4 - 0.9)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.3B Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received Group Hemoglobin (g/dL) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 28 | 15 | 43
Mean (SD) | 12.7 (0.7) | 13.5 (1.1) | 13.0 (0.9)
Median (Min-Max) | 12.8 (11.5 - 14.0) | 13.3 (12.0 - 15.4) | 12.9 (11.5 - 15.4)
Week 4
N | 26 | 12 | 38
Mean (SD) | 12.5 (0.8) | 13.0 (0.8) | 12.6 (0.8)
Median (Min-Max) | 12.5 (10.5 - 14.0) | 13.1 (11.3 - 14.4) | 12.7 (10.5 - 14.4)
Week 8
N | 27 | 11 | 38
Mean (SD) | 12.9 (0.9) | 13.0 (0.9) | 12.9 (0.9)
Median (Min-Max) | 12.9 (11.0 - 15.0) | 12.9 (11.6 - 14.3) | 12.9 (11.0 - 15.0)
Week 16
N | 19 | 9 | 28
Mean (SD) | 12.6 (0.7) | 13.2 (0.9) | 12.8 (0.8)
Median (Min-Max) | 12.8 (10.8 - 13.5) | 12.9 (12.1 - 15.1) | 12.8 (10.8 - 15.1)
Week 24
N | 15 | 8 | 23
Mean (SD) | 12.8 (0.8) | 13.9 (1.6) | 13.2 (1.2)
Median (Min-Max) | 12.7 (11.5 - 14.0) | 13.5 (12.4 - 17.0) | 13.0 (11.5 - 17.0)
LOCF
N | 28 | 13 | 41
Mean (SD) | 12.8 (0.9) | 13.5 (1.3) | 13.0 (1.1)
Median (Min-Max) | 12.7 (11.5 - 15.0) | 13.2 (12.4 - 17.0) | 12.8 (11.5 - 17.0)
Change from Baseline to LOCF
N | 27 | 13 | 40
Mean (SD) | 0.1 (0.7) | 0.2 (0.9) | 0.2 (0.8)
Median (Min-Max) | 0.0 (−2.3 - 1.9) | 0.1 (−1.0 - 2.5) | 0.1 (−2.3 - 2.5)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.4B Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received Group Hematocrit (%) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 28 | 15 | 43
Mean (SD) | 38.0 (2.2) | 39.7 (2.6) | 38.6 (2.5)
Median (Min-Max) | 37.7 (34.8 - 43.2) | 39.2 (36.5 - 44.2) | 38.4 (34.8 - 44.2)
Week 4
N | 26 | 12 | 38
Mean (SD) | 37.6 (2.7) | 38.9 (2.2) | 38.0 (2.6)
Median (Min-Max) | 37.4 (33.4 - 42.9) | 38.6 (35.0 - 43.3) | 37.8 (33.4 - 43.3)
Week 8
N | 27 | 11 | 38
Mean (SD) | 38.9 (3.1) | 39.1 (2.4) | 39.0 (2.9)
Median (Min-Max) | 38.7 (34.2 - 47.4) | 39.6 (36.1 - 42.9) | 38.7 (34.2 - 47.4)
Week 16
N | 19 | 9 | 28
Mean (SD) | 38.1 (2.4) | 39.7 (3.1) | 38.6 (2.7)
Median (Min-Max) | 37.7 (33.1 - 44.3) | 39.4 (36.0 - 46.7) | 38.1 (33.1 - 46.7)
Week 24
N | 15 | 8 | 23
Mean (SD) | 38.6 (2.4) | 41.2 (4.5) | 39.5 (3.4)
Median (Min-Max) | 37.6 (34.6 - 44.0) | 40.4 (36.4 - 48.6) | 38.6 (34.6 - 48.6)
LOCF
N | 28 | 13 | 41
Mean (SD) | 39.0 (2.9) | 40.8 (3.7) | 39.6 (3.2)
Median (Min-Max) | 38.7 (34.5 - 47.4) | 40.9 (36.4 - 48.6) | 39.0 (34.5 - 48.6)
Change from Baseline to LOCF
N | 27 | 13 | 40
Mean (SD) | 1.0 (2.3) | 1.6 (2.2) | 1.2 (2.2)
Median (Min-Max) | 1.0 (−5.9 - 6.3) | 0.8 (−1.2 - 7.3) | 1.0 (−5.9 - 7.3)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.5B Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received Group Mean Corpuscular Volume - MCV (fL) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 28 | 15 | 43
Mean (SD) | 85.2 (5.3) | 83.9 (4.0) | 84.8 (4.8)
Median (Min-Max) | 86.0 (65.6 - 92.3) | 82.2 (78.0 - 94.0) | 85.0 (65.6 - 94.0)
Week 4
N | 26 | 12 | 38
Mean (SD) | 85.8 (5.3) | 85.1 (4.4) | 85.5 (5.0)
Median (Min-Max) | 86.9 (65.4 - 92.0) | 84.0 (80.9 - 95.5) | 85.9 (65.4 - 95.5)
Week 8
N | 27 | 11 | 38
Mean (SD) | 86.4 (5.5) | 85.3 (4.6) | 86.1 (5.2)
Median (Min-Max) | 87.0 (64.9 - 97.0) | 84.0 (79.2 - 93.8) | 86.4 (64.9 - 97.0)
Week 16
N | 19 | 9 | 28
Mean (SD) | 85.4 (5.5) | 85.5 (4.4) | 85.4 (5.1)
Median (Min-Max) | 86.5 (64.7 - 90.8) | 84.1 (80.0 - 95.4) | 86.2 (64.7 - 95.4)
Week 24
N | 15 | 8 | 23
Mean (SD) | 85.4 (6.5) | 85.1 (4.7) | 85.3 (5.8)
Median (Min-Max) | 87.0 (64.8 - 93.4) | 84.7 (78.8 - 94.6) | 85.6 (64.8 - 94.6)
LOCF
N | 28 | 13 | 41
Mean (SD) | 86.0 (5.7) | 86.1 (4.6) | 86.0 (5.3)
Median (Min-Max) | 86.5 (64.8 - 97.0) | 85.2 (78.8 - 95.6) | 86.0 (64.8 - 97.0)
Change from Baseline to LOCF
N | 27 | 13 | 40
Mean (SD) | 0.8 (3.3) | 2.6 (1.7) | 1.4 (3.0)
Median (Min-Max) | 0.1 (−4.4 - 13.2) | 2.4 (0.4 - 5.6) | 1.0 (−4.4 - 13.2)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.6B Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received Group Mean Corpuscular Hemoglobin - MCH (pg) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 28 | 14 | 42
Mean (SD) | 28.5 (2.2) | 28.4 (1.4) | 28.5 (1.9)
Median (Min-Max) | 28.8 (21.1 - 32.0) | 28.7 (25.9 - 30.8) | 28.7 (21.1 - 32.0)
Week 4
N | 26 | 12 | 38
Mean (SD) | 28.5 (2.2) | 28.4 (1.3) | 28.5 (1.9)
Median (Min-Max) | 28.3 (21.4 - 31.9) | 28.4 (26.8 - 31.6) | 28.3 (21.4 - 31.9)
Week 8
N | 27 | 11 | 38
Mean (SD) | 28.5 (2.0) | 28.4 (1.6) | 28.5 (1.9)
Median (Min-Max) | 28.7 (21.2 - 32.1) | 28.3 (26.0 - 31.8) | 28.4 (21.2 - 32.1)
Week 16
N | 19 | 8 | 27
Mean (SD) | 28.3 (2.2) | 28.5 (1.3) | 28.3 (2.0)
Median (Min-Max) | 28.8 (21.3 - 31.3) | 28.5 (26.8 - 31.2) | 28.7 (21.3 - 31.3)
Week 24
N | 15 | 8 | 23
Mean (SD) | 28.3 (2.5) | 28.6 (1.8) | 28.4 (2.2)
Median (Min-Max) | 28.7 (20.9 - 31.9) | 28.2 (26.5 - 32.7) | 28.6 (20.9 - 32.7)
LOCF
N | 28 | 13 | 41
Mean (SD) | 28.3 (2.0) | 28.5 (1.7) | 28.4 (1.9)
Median (Min-Max) | 28.6 (20.9 - 31.9) | 27.8 (26.5 - 32.7) | 28.6 (20.9 - 32.7)
Change from Baseline to LOCF
N | 27 | 13 | 40
Mean (SD) | −0.2 (0.9) | 0.1 (0.7) | −0.1 (0.9)
Median (Min-Max) | −0.1 (−1.6 - 3.3) | 0.0 (−0.8 - 1.9) | −0.1 (−1.6 - 3.3)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.7B Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received Group Mean Corpuscular Hemoglobin Concentration - MCHC (g/dL) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 28 | 15 | 43
Mean (SD) | 33.5 (1.3) | 34.0 (1.2) | 33.6 (1.3)
Median (Min-Max) | 33.7 (31.2 - 35.8) | 34.0 (31.8 - 35.8) | 33.8 (31.2 - 35.8)
Week 4
N | 26 | 12 | 38
Mean (SD) | 33.2 (1.4) | 33.4 (1.0) | 33.3 (1.3)
Median (Min-Max) | 32.9 (30.9 - 35.8) | 33.3 (31.5 - 34.8) | 33.1 (30.9 - 35.8)
Week 8
N | 27 | 11 | 38
Mean (SD) | 33.0 (1.4) | 33.3 (1.1) | 33.1 (1.3)
Median (Min-Max) | 33.1 (29.5 - 35.6) | 33.2 (31.9 - 35.2) | 33.2 (29.5 - 35.6)
Week 16
N | 19 | 9 | 28
Mean (SD) | 33.1 (1.2) | 33.1 (1.3) | 33.1 (1.2)
Median (Min-Max) | 33.3 (30.0 - 35.2) | 32.7 (31.4 - 35.0) | 33.1 (30.0 - 35.2)
Week 24
N | 15 | 8 | 23
Mean (SD) | 33.1 (1.3) | 33.7 (1.3) | 33.3 (1.3)
Median (Min-Max) | 32.9 (31.3 - 36.3) | 33.8 (31.8 - 35.2) | 33.6 (31.3 - 36.3)
LOCF
N | 28 | 13 | 41
Mean (SD) | 32.9 (1.4) | 33.2 (1.3) | 33.0 (1.3)
Median (Min-Max) | 32.8 (29.5 - 36.3) | 32.7 (31.5 - 35.2) | 32.8 (29.5 - 36.3)
Change from Baseline to LOCF
N | 27 | 13 | 40
Mean (SD) | −0.5 (0.8) | −0.8 (0.9) | −0.6 (0.9)
Median (Min-Max) | −0.5 (−2.4 - 1.6) | −0.7 (−3.0 - 0.5) | −0.6 (−3.0 - 1.6)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.8B Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received Group Platelets Count (×10^3^/μL) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 28 | 15 | 43
Mean (SD) | 299.8 (54.4) | 278.9 (75.2) | 292.5 (62.3)
Median (Min-Max) | 305.5 (210.0 - 408.0) | 279.0 (74.0 - 379.0) | 288.0 (74.0 - 408.0)
Week 4
N | 26 | 12 | 38
Mean (SD) | 299.5 (52.3) | 315.3 (74.2) | 304.5 (59.5)
Median (Min-Max) | 299.5 (218.0 - 447.0) | 302.5 (202.0 - 442.0) | 299.5 (202.0 - 447.0)
Week 8
N | 27 | 11 | 38
Mean (SD) | 319.4 (50.7) | 334.5 (90.8) | 323.7 (63.9)
Median (Min-Max) | 319.0 (222.0 - 422.0) | 308.0 (190.0 - 479.0) | 318.5 (190.0 - 479.0)
Week 16
N | 19 | 9 | 28
Mean (SD) | 318.6 (56.1) | 327.3 (83.3) | 321.4 (64.6)
Median (Min-Max) | 315.0 (216.0 - 435.0) | 308.0 (199.0 - 482.0) | 313.0 (199.0 - 482.0)
Week 24
N | 15 | 8 | 23
Mean (SD) | 307.7 (55.4) | 295.4 (61.9) | 303.4 (56.7)
Median (Min-Max) | 298.0 (228.0 - 409.0) | 294.0 (178.0 - 389.0) | 298.0 (178.0 - 409.0)
LOCF
N | 28 | 13 | 41
Mean (SD) | 307.5 (56.5) | 305.9 (61.3) | 307.0 (57.3)
Median (Min-Max) | 295.0 (228.0 - 422.0) | 314.0 (178.0 - 389.0) | 301.0 (178.0 - 422.0)
Change from Baseline to LOCF
N | 27 | 13 | 40
Mean (SD) | 3.8 (42.9) | 31.2 (67.9) | 12.7 (53.1)
Median (Min-Max) | 5.0 (−89.0 - 92.0) | 42.0 (−151 - 108.0) | 14.0 (−151 - 108.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.9B Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received Group Red Blood Cell Distribution Width - RDW (%) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 28 | 15 | 43
Mean (SD) | 18.9 (11.2) | 19.6 (11.4) | 19.2 (11.1)
Median (Min-Max) | 13.6 (11.9 - 42.8) | 13.5 (11.6 - 39.8) | 13.5 (11.6 - 42.8)
Week 4
N | 26 | 12 | 38
Mean (SD) | 18.3 (10.5) | 19.6 (11.2) | 18.7 (10.6)
Median (Min-Max) | 13.4 (11.8 - 42.4) | 13.9 (11.6 - 39.4) | 13.6 (11.6 - 42.4)
Week 8
N | 27 | 11 | 38
Mean (SD) | 17.8 (10.3) | 19.9 (11.3) | 18.4 (10.5)
Median (Min-Max) | 13.2 (11.6 - 43.3) | 13.6 (11.9 - 38.8) | 13.5 (11.6 - 43.3)
Week 16
N | 19 | 9 | 28
Mean (SD) | 17.2 (10.0) | 21.1 (12.4) | 18.5 (10.8)
Median (Min-Max) | 13.1 (11.4 - 43.4) | 13.5 (11.7 - 39.3) | 13.3 (11.4 - 43.4)
Week 24
N | 15 | 8 | 23
Mean (SD) | 16.3 (8.5) | 22.3 (13.1) | 18.4 (10.5)
Median (Min-Max) | 13.2 (11.7 - 38.8) | 13.4 (12.0 - 40.3) | 13.2 (11.7 - 40.3)
LOCF
N | 28 | 13 | 41
Mean (SD) | 17.5 (9.8) | 21.0 (12.2) | 18.6 (10.6)
Median (Min-Max) | 13.2 (11.7 - 42.5) | 13.5 (12.0 - 40.3) | 13.2 (11.7 - 42.5)
Change from Baseline to LOCF
N | 27 | 13 | 40
Mean (SD) | −0.5 (1.0) | 0.3 (0.7) | −0.3 (1.0)
Median (Min-Max) | −0.4 (−3.3 - 1.2) | 0.1 (−0.6 - 2.0) | −0.2 (−3.3 - 2.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.10B Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received Group Mean Platelet Volume (fL) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 28 | 12 | 40
Mean (SD) | 9.7 (1.3) | 9.9 (1.4) | 9.8 (1.3)
Median (Min-Max) | 9.9 (6.2 - 11.9) | 9.8 (7.7 - 12.6) | 9.9 (6.2 - 12.6)
Week 4
N | 25 | 12 | 37
Mean (SD) | 9.9 (1.5) | 10.4 (1.0) | 10.1 (1.4)
Median (Min-Max) | 10.1 (6.0 - 12.0) | 10.3 (8.6 - 11.9) | 10.1 (6.0 - 12.0)
Week 8
N | 26 | 11 | 37
Mean (SD) | 10.0 (1.4) | 9.9 (1.1) | 9.9 (1.3)
Median (Min-Max) | 10.1 (6.2 - 12.1) | 9.6 (7.8 - 11.8) | 9.9 (6.2 - 12.1)
Week 16
N | 19 | 8 | 27
Mean (SD) | 9.8 (1.5) | 10.1 (1.4) | 9.9 (1.5)
Median (Min-Max) | 10.3 (6.4 - 12.3) | 10.2 (8.3 - 12.4) | 10.3 (6.4 - 12.4)
Week 24
N | 14 | 8 | 22
Mean (SD) | 9.6 (1.6) | 9.6 (1.5) | 9.6 (1.6)
Median (Min-Max) | 9.9 (6.4 - 11.8) | 9.7 (7.1 - 12.1) | 9.9 (6.4 - 12.1)
LOCF
N | 27 | 13 | 40
Mean (SD) | 9.9 (1.2) | 10.0 (1.4) | 9.9 (1.3)
Median (Min-Max) | 10.1 (6.4 - 11.8) | 10.2 (7.1 - 12.1) | 10.1 (6.4 - 12.1)
Change from Baseline to LOCF
N | 26 | 11 | 37
Mean (SD) | 0.3 (0.4) | 0.0 (0.5) | 0.2 (0.5)
Median (Min-Max) | 0.3 (−0.6 - 0.9) | 0.0 (−0.6 - 1.1) | 0.2 (−0.6 - 1.1)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.11B Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received Group Neutrophils (%) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 26 | 14 | 40
Mean (SD) | 60.0 (9.2) | 47.4 (10.0) | 55.6 (11.1)
Median (Min-Max) | 59.2 (42.7 - 82.2) | 48.0 (33.2 - 63.7) | 56.4 (33.2 - 82.2)
Week 4
N | 25 | 11 | 36
Mean (SD) | 59.6 (10.0) | 58.7 (11.9) | 59.4 (10.5)
Median (Min-Max) | 63.2 (36.5 - 75.0) | 61.4 (40.7 - 74.3) | 62.9 (36.5 - 75.0)
Week 8
N | 25 | 10 | 35
Mean (SD) | 58.3 (14.7) | 58.6 (12.5) | 58.4 (13.9)
Median (Min-Max) | 60.8 (2.7 - 79.0) | 61.3 (38.2 - 76.3) | 60.8 (2.7 - 79.0)
Week 16
N | 18 | 8 | 26
Mean (SD) | 60.6 (8.9) | 61.5 (6.6) | 60.9 (8.1)
Median (Min-Max) | 59.9 (46.7 - 80.7) | 61.1 (51.1 - 70.9) | 59.9 (46.7 - 80.7)
Week 24
N | 14 | 7 | 21
Mean (SD) | 59.1 (8.3) | 59.3 (11.2) | 59.2 (9.1)
Median (Min-Max) | 59.5 (44.4 - 72.6) | 63.3 (39.7 - 70.0) | 60.6 (39.7 - 72.6)
LOCF
N | 25 | 12 | 37
Mean (SD) | 60.4 (8.7) | 57.1 (9.8) | 59.3 (9.1)
Median (Min-Max) | 60.0 (44.4 - 74.3) | 59.5 (39.7 - 70.0) | 60.0 (39.7 - 74.3)
Change from Baseline to LOCF
N | 24 | 12 | 36
Mean (SD) | 0.6 (9.2) | 9.9 (9.3) | 3.7 (10.1)
Median (Min-Max) | 0.7 (−17.9 - 22.7) | 6.7 (−1.2 - 28.8) | 4.0 (−17.9 - 28.8)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.12B Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received Group Lymphocytes (%) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 27 | 15 | 42
Mean (SD) | 29.1 (8.7) | 40.0 (9.6) | 33.0 (10.4)
Median (Min-Max) | 28.9 (10.8 - 44.6) | 40.0 (22.0 - 55.5) | 32.8 (10.8 - 55.5)
Week 4
N | 26 | 12 | 38
Mean (SD) | 29.1 (8.8) | 28.4 (10.3) | 28.9 (9.1)
Median (Min-Max) | 27.2 (18.8 - 50.2) | 26.1 (13.4 - 46.2) | 27.2 (13.4 - 50.2)
Week 8
N | 26 | 11 | 37
Mean (SD) | 29.4 (8.6) | 28.2 (10.0) | 29.0 (8.9)
Median (Min-Max) | 28.7 (11.7 - 45.3) | 23.0 (14.6 - 46.9) | 28.1 (11.7 - 46.9)
Week 16
N | 19 | 9 | 28
Mean (SD) | 29.3 (8.8) | 27.3 (6.3) | 28.7 (8.0)
Median (Min-Max) | 32.3 (9.4 - 42.6) | 27.4 (18.2 - 38.4) | 30.0 (9.4 - 42.6)
Week 24
N | 15 | 8 | 23
Mean (SD) | 31.3 (8.8) | 29.1 (10.1) | 30.5 (9.1)
Median (Min-Max) | 31.3 (19.0 - 50.0) | 23.8 (21.7 - 49.3) | 30.1 (19.0 - 50.0)
LOCF
N | 26 | 13 | 39
Mean (SD) | 29.6 (8.9) | 30.7 (9.2) | 30.0 (8.9)
Median (Min-Max) | 30.6 (17.2 - 50.0) | 27.6 (21.7 - 49.3) | 30.1 (17.2 - 50.0)
Change from Baseline to LOCF
N | 25 | 13 | 38
Mean (SD) | 0.2 (9.2) | −9.7 (7.5) | −3.2 (9.8)
Median (Min-Max) | −0.7 (−18.0 - 21.0) | −8.0 (−24.5 - 1.1) | −3.1 (−24.5 - 21.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.13B Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received Group Monocytes (%) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 27 | 15 | 42
Mean (SD) | 6.6 (1.5) | 7.1 (2.1) | 6.8 (1.7)
Median (Min-Max) | 6.5 (4.7 - 11.1) | 6.9 (4.2 - 10.6) | 6.7 (4.2 - 11.1)
Week 4
N | 26 | 12 | 38
Mean (SD) | 7.4 (2.1) | 7.1 (1.4) | 7.3 (1.9)
Median (Min-Max) | 8.0 (3.7 - 12.0) | 7.3 (4.3 - 9.0) | 7.7 (3.7 - 12.0)
Week 8
N | 26 | 11 | 37
Mean (SD) | 6.9 (2.1) | 7.7 (2.3) | 7.1 (2.1)
Median (Min-Max) | 6.8 (3.5 - 12.3) | 8.0 (3.3 - 11.5) | 6.9 (3.3 - 12.3)
Week 16
N | 19 | 9 | 28
Mean (SD) | 6.9 (1.4) | 6.7 (1.2) | 6.8 (1.3)
Median (Min-Max) | 7.0 (4.0 - 9.0) | 6.7 (5.1 - 8.2) | 6.9 (4.0 - 9.0)
Week 24
N | 15 | 8 | 23
Mean (SD) | 6.5 (1.4) | 6.6 (1.3) | 6.5 (1.3)
Median (Min-Max) | 6.3 (4.3 - 8.3) | 6.3 (5.0 - 8.6) | 6.3 (4.3 - 8.6)
LOCF
N | 26 | 13 | 39
Mean (SD) | 6.5 (1.6) | 7.1 (2.3) | 6.7 (1.8)
Median (Min-Max) | 6.3 (3.9 - 9.1) | 6.6 (5.0 - 13.3) | 6.3 (3.9 - 13.3)
Change from Baseline to LOCF
N | 25 | 13 | 38
Mean (SD) | −0.1 (1.6) | 0.0 (2.4) | −0.1 (1.9)
Median (Min-Max) | −0.5 (−3.0 - 3.2) | 0.1 (−3.0 - 3.9) | −0.2 (−3.0 - 3.9)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.14B Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received Group Eosinophils (%) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 27 | 15 | 42
Mean (SD) | 3.5 (1.7) | 4.1 (2.7) | 3.7 (2.1)
Median (Min-Max) | 3.0 (0.2 - 7.0) | 3.3 (1.3 - 9.2) | 3.1 (0.2 - 9.2)
Week 4
N | 26 | 12 | 38
Mean (SD) | 3.1 (1.6) | 4.4 (1.7) | 3.5 (1.7)
Median (Min-Max) | 2.8 (1.0 - 6.4) | 3.9 (2.4 - 8.7) | 3.2 (1.0 - 8.7)
Week 8
N | 26 | 11 | 37
Mean (SD) | 3.1 (1.7) | 4.3 (2.7) | 3.5 (2.1)
Median (Min-Max) | 3.0 (0.0 - 6.9) | 4.0 (1.5 - 11.6) | 3.3 (0.0 - 11.6)
Week 16
N | 19 | 9 | 28
Mean (SD) | 3.0 (1.4) | 3.3 (1.3) | 3.1 (1.4)
Median (Min-Max) | 3.0 (0.6 - 6.2) | 3.2 (1.3 - 5.0) | 3.1 (0.6 - 6.2)
Week 24
N | 15 | 8 | 23
Mean (SD) | 3.7 (2.0) | 3.4 (1.1) | 3.6 (1.7)
Median (Min-Max) | 3.2 (0.4 - 8.1) | 3.3 (2.0 - 5.6) | 3.2 (0.4 - 8.1)
LOCF
N | 26 | 13 | 39
Mean (SD) | 3.5 (1.9) | 3.6 (1.3) | 3.5 (1.7)
Median (Min-Max) | 3.2 (0.4 - 8.1) | 3.6 (2.0 - 6.1) | 3.2 (0.4 - 8.1)
Change from Baseline to LOCF
N | 25 | 13 | 38
Mean (SD) | 0.0 (2.2) | −0.2 (2.6) | −0.1 (2.3)
Median (Min-Max) | 0.4 (−6.6 - 3.7) | 0.6 (−6.2 - 2.8) | 0.4 (−6.6 - 3.7)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.2.15B Summary of Clinical Laboratory Hematology Measurement by Visit and Efficacy Phase Treatment Received Group Basophils (%) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 26 | 15 | 41
Mean (SD) | 0.4 (0.3) | 0.6 (0.4) | 0.5 (0.3)
Median (Min-Max) | 0.3 (0.0 - 1.2) | 0.6 (0.0 - 1.3) | 0.4 (0.0 - 1.3)
Week 4
N | 26 | 12 | 38
Mean (SD) | 0.5 (0.4) | 0.6 (0.2) | 0.5 (0.3)
Median (Min-Max) | 0.4 (0.0 - 1.3) | 0.6 (0.3 - 1.0) | 0.4 (0.0 - 1.3)
Week 8
N | 26 | 11 | 37
Mean (SD) | 0.6 (0.4) | 0.5 (0.3) | 0.6 (0.4)
Median (Min-Max) | 0.6 (0.1 - 1.5) | 0.4 (0.0 - 1.0) | 0.5 (0.0 - 1.5)
Week 16
N | 19 | 9 | 28
Mean (SD) | 0.5 (0.4) | 1.4 (3.0) | 0.8 (1.7)
Median (Min-Max) | 0.3 (0.0 - 1.4) | 0.4 (0.0 - 9.4) | 0.4 (0.0 - 9.4)
Week 24
N | 15 | 8 | 23
Mean (SD) | 0.4 (0.3) | 0.4 (0.3) | 0.4 (0.3)
Median (Min-Max) | 0.4 (0.0 - 1.0) | 0.4 (0.0 - 1.0) | 0.4 (0.0 - 1.0)
LOCF
N | 26 | 13 | 39
Mean (SD) | 0.5 (0.4) | 0.5 (0.3) | 0.5 (0.3)
Median (Min-Max) | 0.4 (0.0 - 1.4) | 0.4 (0.0 - 1.0) | 0.4 (0.0 - 1.4)
Change from Baseline to LOCF
N | 24 | 13 | 37
Mean (SD) | 0.1 (0.3) | −0.1 (0.5) | 0.0 (0.4)
Median (Min-Max) | 0.1 (−0.3 - 0.9) | −0.1 (−1.0 - 1.0) | 0.0 (−1.0 - 1.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.1.3.1 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group White Blood Count (×10^3^/L) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 7.3 (2.1) | 8.5 (2.1) | 7.8 (2.1)
Median (Min-Max) | 7.0 (4.8 - 12.7) | 8.3 (4.6 - 11.8) | 7.5 (4.6 - 12.7)
Week 8
N | 13 | 3 | 16
Mean (SD) | 8.2 (2.1) | 5.7 (0.9) | 7.7 (2.2)
Median (Min-Max) | 8.5 (4.9 - 13.0) | 5.6 (4.9 - 6.7) | 7.6 (4.9 - 13.0)
Week 16
N | 12 | 2 | 14
Mean (SD) | 8.0 (2.3) | 9.2 (0.3) | 8.2 (2.2)
Median (Min-Max) | 8.7 (4.5 - 13.3) | 9.2 (9.0 - 9.4) | 8.8 (4.5 - 13.3)
Week 20
N | 8 | 0 | 8
Mean (SD) | 8.5 (1.9) | 0 | 8.5 (1.9)
Median (Min-Max) | 8.4 (6.2 - 12.5) | 0 | 8.4 (6.2 - 12.5)
Week 28
N | 11 | 2 | 13
Mean (SD) | 8.6 (2.5) | 7.4 (0.8) | 8.4 (2.3)
Median (Min-Max) | 9.3 (3.4 - 11.9) | 7.4 (6.8 - 7.9) | 8.2 (3.4 - 11.9)
LOCF
N | 15 | 12 | 27
Mean (SD) | 8.3 (2.2) | 7.1 (1.3) | 7.8 (2.0)
Median (Min-Max) | 8.2 (3.4 - 11.9) | 7.0 (4.9 - 9.8) | 7.6 (3.4 - 11.9)
Change from Baseline to LOCF
N | 15 | 12 | 27
Mean (SD) | 0.9 (1.7) | −1.7 (1.5) | −0.3 (2.0)
Median (Min-Max) | 0.9 (−1.6 - 4.5) | −1.9 (−3.9 - 0.4) | −0.1 (−3.9 - 4.5)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.1.3.2 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group Red Blood Count (×10^6^/L) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 16 | 14 | 30
Mean (SD) | 4.7 (0.3) | 4.7 (0.4) | 4.7 (0.3)
Median (Min-Max) | 4.7 (4.2 - 5.2) | 4.6 (4.0 - 5.3) | 4.7 (4.0 - 5.3)
Week 8
N | 13 | 3 | 16
Mean (SD) | 4.6 (0.2) | 4.9 (0.8) | 4.7 (0.4)
Median (Min-Max) | 4.7 (4.2 - 5.0) | 4.9 (4.1 - 5.6) | 4.7 (4.1 - 5.6)
Week 16
N | 12 | 2 | 14
Mean (SD) | 4.6 (0.2) | 5.3 (0.8) | 4.7 (0.4)
Median (Min-Max) | 4.6 (4.2 - 4.8) | 5.3 (4.7 - 5.9) | 4.6 (4.2 - 5.9)
Week 20
N | 8 | 0 | 8
Mean (SD) | 4.5 (0.3) | 0 | 4.5 (0.3)
Median (Min-Max) | 4.6 (4.0 - 4.8) | 0 | 4.6 (4.0 - 4.8)
Week 28
N | 11 | 2 | 13
Mean (SD) | 4.7 (0.3) | 5.2 (0.7) | 4.8 (0.3)
Median (Min-Max) | 4.7 (4.4 - 5.2) | 5.2 (4.7 - 5.6) | 4.7 (4.4 - 5.6)
LOCF
N | 14 | 12 | 26
Mean (SD) | 4.7 (0.2) | 4.4 (1.0) | 4.6 (0.7)
Median (Min-Max) | 4.7 (4.4 - 5.2) | 4.7 (1.4 - 5.6) | 4.7 (1.4 - 5.6)
Change from Baseline to LOCF
N | 14 | 12 | 26
Mean (SD) | 0.0 (0.2) | −0.2 (1.0) | −0.1 (0.7)
Median (Min-Max) | 0.0 (−0.4 - 0.5) | 0.0 (−3.2 - 0.4) | 0.0 (−3.2 - 0.5)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.1.3.3 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group Hemoglobin (g/dL) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 13.2 (0.8) | 13.4 (0.8) | 13.3 (0.8)
Median (Min-Max) | 13.3 (11.5 - 14.7) | 13.6 (11.7 - 14.9) | 13.5 (11.5 - 14.9)
Week 8
N | 13 | 3 | 16
Mean (SD) | 13.1 (0.8) | 12.8 (1.7) | 13.1 (0.9)
Median (Min-Max) | 13.2 (11.7 - 14.2) | 12.8 (11.1 - 14.5) | 13.2 (11.1 - 14.5)
Week 16
N | 12 | 2 | 14
Mean (SD) | 13.0 (0.7) | 13.7 (1.8) | 13.1 (0.8)
Median (Min-Max) | 13.2 (11.6 - 13.8) | 13.7 (12.4 - 14.9) | 13.2 (11.6 - 14.9)
Week 20
N | 8 | 0 | 8
Mean (SD) | 12.7 (0.9) | 0 | 12.7 (0.9)
Median (Min-Max) | 12.8 (11.2 - 13.8) | 0 | 12.8 (11.2 - 13.8)
Week 28
N | 11 | 2 | 13
Mean (SD) | 13.2 (0.8) | 13.5 (1.4) | 13.3 (0.8)
Median (Min-Max) | 13.0 (12.0 - 14.4) | 13.5 (12.5 - 14.5) | 13.0 (12.0 - 14.5)
LOCF
N | 15 | 12 | 27
Mean (SD) | 13.2 (0.9) | 13.3 (1.0) | 13.2 (0.9)
Median (Min-Max) | 13.1 (11.0 - 14.4) | 13.4 (11.1 - 14.9) | 13.2 (11.0 - 14.9)
Change from Baseline to LOCF
N | 15 | 12 | 27
Mean (SD) | −0.1 (0.7) | 0.0 (0.4) | −0.1 (0.6)
Median (Min-Max) | −0.1 (−1.2 - 1.2) | −0.1 (−0.6 - 0.8) | −0.1 (−1.2 - 1.2)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.1.3.4 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group Hematocrit (%) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 40.0 (2.4) | 40.1 (2.9) | 40.0 (2.6)
Median (Min-Max) | 40.5 (35.8 - 45.6) | 40.0 (35.9 - 46.7) | 40.1 (35.8 - 46.7)
Week 8
N | 13 | 3 | 16
Mean (SD) | 39.4 (2.3) | 39.8 (5.7) | 39.5 (2.9)
Median (Min-Max) | 39.9 (35.7 - 42.6) | 38.2 (35.0 - 46.1) | 39.9 (35.0 - 46.1)
Week 16
N | 12 | 2 | 14
Mean (SD) | 38.6 (2.4) | 42.7 (5.9) | 39.2 (3.1)
Median (Min-Max) | 38.9 (34.4 - 41.5) | 42.7 (38.5 - 46.9) | 39.0 (34.4 - 46.9)
Week 20
N | 8 | 0 | 8
Mean (SD) | 37.9 (2.3) | 0 | 37.9 (2.3)
Median (Min-Max) | 38.6 (33.9 - 40.5) | 0 | 38.6 (33.9 - 40.5)
Week 28
N | 11 | 2 | 13
Mean (SD) | 39.9 (1.9) | 41.5 (3.9) | 40.2 (2.2)
Median (Min-Max) | 40.6 (36.3 - 42.1) | 41.5 (38.7 - 44.2) | 40.6 (36.3 - 44.2)
LOCF
N | 15 | 12 | 27
Mean (SD) | 39.9 (2.0) | 40.1 (3.0) | 40.0 (2.4)
Median (Min-Max) | 40.6 (36.3 - 42.1) | 40.2 (34.6 - 45.2) | 40.3 (34.6 - 45.2)
Change from Baseline to LOCF
N | 15 | 12 | 27
Mean (SD) | −0.5 (2.1) | 0.0 (1.1) | −0.2 (1.7)
Median (Min-Max) | −0.5 (−3.5 - 3.3) | 0.1 (−1.5 - 2.5) | −0.1 (−3.5 - 3.3)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.1.3.5 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group Mean Corpuscular Volume - MCV (fL) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 86.1 (3.1) | 86.0 (4.9) | 86.1 (4.0)
Median (Min-Max) | 86.2 (80.0 - 91.0) | 85.8 (79.6 - 96.0) | 86.1 (79.6 - 96.0)
Week 8
N | 13 | 3 | 16
Mean (SD) | 85.2 (3.4) | 81.8 (2.8) | 84.6 (3.5)
Median (Min-Max) | 85.0 (80.0 - 90.0) | 81.8 (79.0 - 84.6) | 84.6 (79.0 - 90.0)
Week 16
N | 12 | 2 | 14
Mean (SD) | 84.7 (2.9) | 80.9 (1.6) | 84.2 (3.0)
Median (Min-Max) | 84.6 (81.0 - 89.4) | 80.9 (79.7 - 82.0) | 84.1 (79.7 - 89.4)
Week 20
N | 8 | 0 | 8
Mean (SD) | 84.6 (3.5) | 0 | 84.6 (3.5)
Median (Min-Max) | 84.1 (81.0 - 90.1) | 0 | 84.1 (81.0 - 90.1)
Week 28
N | 11 | 2 | 13
Mean (SD) | 85.0 (3.3) | 80.8 (3.2) | 84.3 (3.5)
Median (Min-Max) | 83.5 (80.0 - 91.5) | 80.8 (78.5 - 83.0) | 83.4 (78.5 - 91.5)
LOCF
N | 15 | 12 | 27
Mean (SD) | 86.3 (4.1) | 85.8 (5.4) | 86.1 (4.7)
Median (Min-Max) | 85.6 (80.0 - 95.0) | 84.4 (78.5 - 97.0) | 85.0 (78.5 - 97.0)
Change from Baseline to LOCF
N | 15 | 12 | 27
Mean (SD) | −0.2 (2.8) | −0.8 (3.1) | −0.5 (2.9)
Median (Min-Max) | −1.1 (−4.0 - 5.4) | 0.2 (−7.9 - 3.0) | −0.4 (−7.9 - 5.4)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.1.3.6 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group Mean Corpuscular Hemoglobin - MCH (pg) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 28.4 (1.2) | 28.7 (1.7) | 28.5 (1.4)
Median (Min-Max) | 28.6 (26.0 - 30.2) | 28.7 (26.4 - 32.2) | 28.6 (26.0 - 32.2)
Week 8
N | 13 | 3 | 16
Mean (SD) | 28.4 (1.0) | 26.3 (0.6) | 28.0 (1.3)
Median (Min-Max) | 28.5 (26.7 - 30.1) | 26.4 (25.7 - 26.9) | 28.3 (25.7 - 30.1)
Week 16
N | 12 | 2 | 14
Mean (SD) | 28.4 (0.5) | 25.8 (0.7) | 28.0 (1.1)
Median (Min-Max) | 28.4 (27.9 - 29.3) | 25.8 (25.3 - 26.3) | 28.3 (25.3 - 29.3)
Week 20
N | 8 | 0 | 8
Mean (SD) | 28.2 (0.5) | 0 | 28.2 (0.5)
Median (Min-Max) | 28.3 (27.4 - 28.9) | 0 | 28.3 (27.4 - 28.9)
Week 28
N | 11 | 2 | 13
Mean (SD) | 28.2 (0.9) | 26.3 (0.6) | 27.9 (1.1)
Median (Min-Max) | 28.3 (26.7 - 29.7) | 26.3 (25.8 - 26.7) | 28.3 (25.8 - 29.7)
LOCF
N | 15 | 12 | 27
Mean (SD) | 28.4 (0.9) | 28.4 (1.7) | 28.4 (1.3)
Median (Min-Max) | 28.5 (26.7 - 30.1) | 28.8 (25.8 - 30.9) | 28.6 (25.8 - 30.9)
Change from Baseline to LOCF
N | 15 | 12 | 27
Mean (SD) | 0.0 (0.6) | −0.3 (1.1) | −0.1 (0.8)
Median (Min-Max) | −0.1 (−1.1 - 0.8) | −0.1 (−2.9 - 1.4) | −0.1 (−2.9 - 1.4)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.1.3.7 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group Mean Corpuscular Hemoglobin Concentration - MCHC (g/dL) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 33.0 (1.0) | 33.4 (1.0) | 33.2 (1.0)
Median (Min-Max) | 32.7 (31.3 - 35.1) | 33.7 (31.8 - 34.9) | 32.9 (31.3 - 35.1)
Week 8
N | 13 | 3 | 16
Mean (SD) | 33.4 (1.4) | 32.2 (1.1) | 33.2 (1.4)
Median (Min-Max) | 33.4 (31.4 - 36.2) | 31.8 (31.4 - 33.5) | 33.2 (31.4 - 36.2)
Week 16
N | 12 | 2 | 14
Mean (SD) | 33.6 (1.0) | 32.0 (0.3) | 33.4 (1.1)
Median (Min-Max) | 33.7 (31.8 - 35.1) | 32.0 (31.8 - 32.2) | 33.5 (31.8 - 35.1)
Week 20
N | 8 | 0 | 8
Mean (SD) | 33.4 (1.1) | 0 | 33.4 (1.1)
Median (Min-Max) | 33.7 (31.5 - 34.8) | 0 | 33.7 (31.5 - 34.8)
Week 28
N | 11 | 2 | 13
Mean (SD) | 33.2 (1.1) | 32.6 (0.4) | 33.1 (1.1)
Median (Min-Max) | 33.1 (30.9 - 34.7) | 32.6 (32.3 - 32.9) | 32.9 (30.9 - 34.7)
LOCF
N | 15 | 12 | 27
Mean (SD) | 33.0 (1.3) | 33.2 (1.0) | 33.1 (1.1)
Median (Min-Max) | 33.1 (30.1 - 34.7) | 33.1 (31.7 - 34.5) | 33.1 (30.1 - 34.7)
Change from Baseline to LOCF
N | 15 | 12 | 27
Mean (SD) | 0.1 (0.8) | 0.0 (0.7) | 0.0 (0.7)
Median (Min-Max) | 0.0 (−1.2 - 1.6) | −0.1 (−1.2 - 1.1) | 0.0 (−1.2 - 1.6)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.1.3.8 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group Platelets Count (×10^3^/L) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 310.1 (52.0) | 324.1 (46.3) | 316.4 (49.2)
Median (Min-Max) | 310.0 (213.0 - 394.0) | 322.0 (244.0 - 402.0) | 315.0 (213.0 - 402.0)
Week 8
N | 13 | 3 | 16
Mean (SD) | 339.2 (58.0) | 300.0 (66.0) | 331.8 (59.3)
Median (Min-Max) | 336.0 (214.0 - 424.0) | 326.0 (225.0 - 349.0) | 336.0 (214.0 - 424.0)
Week 16
N | 12 | 2 | 14
Mean (SD) | 334.8 (80.8) | 302.0 (86.3) | 330.1 (79.0)
Median (Min-Max) | 337.5 (189.0 - 461.0) | 302.0 (241.0 - 363.0) | 337.5 (189.0 - 461.0)
Week 20
N | 8 | 0 | 8
Mean (SD) | 335.0 (68.7) | 0 | 335.0 (68.7)
Median (Min-Max) | 354.0 (209.0 - 409.0) | 0 | 354.0 (209.0 - 409.0)
Week 28
N | 11 | 2 | 13
Mean (SD) | 317.6 (66.2) | 300.0 (91.9) | 314.9 (66.3)
Median (Min-Max) | 311.0 (188.0 - 404.0) | 300.0 (235.0 - 365.0) | 311.0 (188.0 - 404.0)
LOCF
N | 15 | 12 | 27
Mean (SD) | 308.8 (61.6) | 279.5 (87.7) | 295.8 (74.3)
Median (Min-Max) | 300.0 (188.0 - 404.0) | 274.0 (83.2 - 437.0) | 287.0 (83.2 - 437.0)
Change from Baseline to LOCF
N | 15 | 12 | 27
Mean (SD) | −0.7 (16.2) | −47.7 (70.9) | −21.6 (53.2)
Median (Min-Max) | 4.0 (−36.0 - 20.0) | −53.0 (−232 - 65.0) | −7.0 (−232 - 65.0)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.1.3.9 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group Red Blood Cell Distribution Width - RDW (%) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 13.1 (0.7) | 13.1 (0.8) | 13.1 (0.7)
Median (Min-Max) | 13.1 (11.6 - 14.6) | 13.1 (12.3 - 15.4) | 13.1 (11.6 - 15.4)
Week 8
N | 13 | 3 | 16
Mean (SD) | 12.8 (0.8) | 12.9 (1.8) | 12.8 (1.0)
Median (Min-Max) | 12.7 (11.3 - 14.7) | 13.3 (11.0 - 14.5) | 12.8 (11.0 - 14.7)
Week 16
N | 12 | 2 | 14
Mean (SD) | 13.3 (1.7) | 13.6 (0.1) | 13.4 (1.6)
Median (Min-Max) | 12.9 (11.6 - 18.3) | 13.6 (13.5 - 13.6) | 13.0 (11.6 - 18.3)
Week 20
N | 8 | 0 | 8
Mean (SD) | 13.1 (0.3) | 0 | 13.1 (0.3)
Median (Min-Max) | 13.1 (12.4 - 13.4) | 0 | 13.1 (12.4 - 13.4)
Week 28
N | 11 | 2 | 13
Mean (SD) | 13.0 (0.5) | 14.2 (0.8) | 13.2 (0.7)
Median (Min-Max) | 13.0 (12.4 - 14.0) | 14.2 (13.6 - 14.8) | 13.0 (12.4 - 14.8)
LOCF
N | 15 | 12 | 27
Mean (SD) | 13.0 (0.6) | 13.4 (0.8) | 13.2 (0.7)
Median (Min-Max) | 13.0 (12.2 - 14.0) | 13.6 (11.8 - 14.8) | 13.2 (11.8 - 14.8)
Change from Baseline to LOCF
N | 15 | 12 | 27
Mean (SD) | −0.1 (0.5) | 0.2 (0.8) | 0.0 (0.7)
Median (Min-Max) | −0.2 (−0.9 - 0.8) | 0.3 (−1.7 - 1.5) | 0.0 (−1.7 - 1.5)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.1.3.10 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group Mean Platelet Volume (fL) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 9.7 (1.8) | 9.5 (1.4) | 9.6 (1.6)
Median (Min-Max) | 10.3 (6.2 - 12.1) | 9.8 (7.2 - 12.6) | 9.9 (6.2 - 12.6)
Week 8
N | 13 | 3 | 16
Mean (SD) | 9.6 (1.8) | 10.2 (0.5) | 9.8 (1.6)
Median (Min-Max) | 10.3 (6.9 - 12.2) | 10.2 (9.7 - 10.7) | 10.3 (6.9 - 12.2)
Week 16
N | 12 | 2 | 14
Mean (SD) | 9.7 (1.6) | 10.7 (0.9) | 9.8 (1.5)
Median (Min-Max) | 9.7 (7.8 - 12.6) | 10.7 (10.0 - 11.3) | 9.9 (7.8 - 12.6)
Week 20
N | 8 | 0 | 8
Mean (SD) | 8.7 (1.6) | 0 | 8.7 (1.6)
Median (Min-Max) | 8.9 (6.5 - 10.6) | 0 | 8.9 (6.5 - 10.6)
Week 28
N | 11 | 2 | 13
Mean (SD) | 9.6 (1.8) | 9.9 (0.5) | 9.7 (1.6)
Median (Min-Max) | 9.9 (6.7 - 12.4) | 9.9 (9.5 - 10.2) | 9.9 (6.7 - 12.4)
LOCF
N | 15 | 12 | 27
Mean (SD) | 9.8 (1.7) | 9.3 (1.4) | 9.6 (1.5)
Median (Min-Max) | 10.4 (6.7 - 12.4) | 9.4 (6.9 - 11.8) | 9.7 (6.7 - 12.4)
Change from Baseline to LOCF
N | 15 | 12 | 27
Mean (SD) | 0.0 (0.5) | 0.0 (0.5) | 0.0 (0.5)
Median (Min-Max) | −0.1 (−0.7 - 1.1) | −0.2 (−0.8 - 0.7) | −0.1 (−0.8 - 1.1)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.1.3.11 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group Neutrophils (%) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 53.8 (16.1) | 59.8 (10.5) | 56.5 (14.0)
Median (Min-Max) | 55.9 (2.0 - 72.4) | 61.0 (38.4 - 79.4) | 58.2 (2.0 - 79.4)
Week 8
N | 13 | 3 | 16
Mean (SD) | 54.5 (9.3) | 48.1 (13.7) | 53.3 (10.0)
Median (Min-Max) | 53.5 (36.7 - 69.3) | 50.4 (33.4 - 60.5) | 52.7 (33.4 - 69.3)
Week 16
N | 12 | 2 | 14
Mean (SD) | 54.6 (10.2) | 61.8 (1.1) | 55.6 (9.8)
Median (Min-Max) | 56.7 (34.3 - 69.1) | 61.8 (61.0 - 62.5) | 58.0 (34.3 - 69.1)
Week 20
N | 8 | 0 | 8
Mean (SD) | 57.8 (7.4) | 0 | 57.8 (7.4)
Median (Min-Max) | 56.4 (49.7 - 70.7) | 0 | 56.4 (49.7 - 70.7)
Week 28
N | 11 | 2 | 13
Mean (SD) | 59.1 (11.4) | 62.9 (2.2) | 59.7 (10.6)
Median (Min-Max) | 63.7 (33.5 - 69.0) | 62.9 (61.3 - 64.4) | 63.7 (33.5 - 69.0)
LOCF
N | 17 | 14 | 31
Mean (SD) | 54.8 (16.3) | 49.7 (15.3) | 52.5 (15.8)
Median (Min-Max) | 57.8 (3.6 - 69.0) | 56.0 (3.6 - 64.4) | 56.3 (3.6 - 69.0)
Change from Baseline to LOCF
N | 17 | 14 | 31
Mean (SD) | 1.0 (19.0) | −10.1 (17.8) | −4.0 (19.0)
Median (Min-Max) | 0.2 (−57.4 - 31.5) | −8.1 (−59.7 - 18.3) | −2.2 (−59.7 - 31.5)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.1.3.12 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group Lymphocytes (%) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 30.2 (10.7) | 28.1 (8.5) | 29.3 (9.6)
Median (Min-Max) | 30.6 (2.4 - 45.3) | 29.1 (10.2 - 48.7) | 29.8 (2.4 - 48.7)
Week 8
N | 13 | 3 | 16
Mean (SD) | 35.0 (8.9) | 38.9 (6.3) | 35.7 (8.5)
Median (Min-Max) | 32.5 (22.9 - 50.2) | 41.1 (31.8 - 43.9) | 34.3 (22.9 - 50.2)
Week 16
N | 12 | 2 | 14
Mean (SD) | 35.3 (10.0) | 31.3 (0.8) | 34.7 (9.4)
Median (Min-Max) | 32.6 (22.4 - 56.8) | 31.3 (30.7 - 31.8) | 31.8 (22.4 - 56.8)
Week 20
N | 8 | 0 | 8
Mean (SD) | 33.2 (6.2) | 0 | 33.2 (6.2)
Median (Min-Max) | 35.5 (21.4 - 40.5) | 0 | 35.5 (21.4 - 40.5)
Week 28
N | 11 | 2 | 13
Mean (SD) | 31.2 (12.6) | 30.3 (1.5) | 31.1 (11.5)
Median (Min-Max) | 27.0 (19.2 - 59.8) | 30.3 (29.2 - 31.3) | 29.2 (19.2 - 59.8)
LOCF
N | 15 | 12 | 27
Mean (SD) | 31.3 (11.0) | 31.7 (10.1) | 31.5 (10.4)
Median (Min-Max) | 30.8 (19.2 - 59.8) | 32.5 (2.2 - 43.1) | 31.9 (2.2 - 59.8)
Change from Baseline to LOCF
N | 15 | 12 | 27
Mean (SD) | 1.3 (18.1) | 5.9 (12.4) | 3.3 (15.7)
Median (Min-Max) | 0.4 (−19.5 - 57.4) | 8.6 (−27.6 - 26.8) | 2.3 (−27.6 - 57.4)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.1.3.13 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group Monocytes (%) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 6.3 (2.2) | 7.0 (2.0) | 6.6 (2.1)
Median (Min-Max) | 6.4 (0.4 - 10.8) | 6.4 (4.3 - 11.0) | 6.4 (0.4 - 11.0)
Week 8
N | 13 | 3 | 16
Mean (SD) | 6.4 (1.4) | 6.9 (3.2) | 6.5 (1.7)
Median (Min-Max) | 6.4 (4.2 - 8.9) | 5.6 (4.6 - 10.6) | 6.3 (4.2 - 10.6)
Week 16
N | 12 | 2 | 14
Mean (SD) | 6.5 (1.7) | 5.3 (1.1) | 6.3 (1.7)
Median (Min-Max) | 6.4 (3.9 - 9.8) | 5.3 (4.5 - 6.0) | 6.3 (3.9 - 9.8)
Week 20
N | 8 | 0 | 8
Mean (SD) | 6.1 (1.3) | 0 | 6.1 (1.3)
Median (Min-Max) | 6.1 (4.1 - 8.1) | 0 | 6.1 (4.1 - 8.1)
Week 28
N | 11 | 2 | 13
Mean (SD) | 6.2 (1.0) | 5.2 (0.9) | 6.1 (1.1)
Median (Min-Max) | 6.1 (4.3 - 7.9) | 5.2 (4.5 - 5.8) | 5.8 (4.3 - 7.9)
LOCF
N | 15 | 12 | 27
Mean (SD) | 6.5 (1.3) | 7.2 (3.2) | 6.8 (2.3)
Median (Min-Max) | 6.6 (4.3 - 9.3) | 7.7 (0.1 - 13.3) | 6.6 (0.1 - 13.3)
Change from Baseline to LOCF
N | 15 | 12 | 27
Mean (SD) | 0.2 (1.9) | 0.2 (1.8) | 0.2 (1.8)
Median (Min-Max) | −0.2 (−2.9 - 5.4) | 0.4 (−4.5 - 2.3) | 0.2 (−4.5 - 5.4)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.1.3.14 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group Eosinophils (%) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 3.5 (2.0) | 4.7 (4.0) | 4.0 (3.1)
Median (Min-Max) | 3.2 (0.1 - 8.1) | 3.6 (1.4 - 16.6) | 3.6 (0.1 - 16.6)
Week 8
N | 13 | 3 | 16
Mean (SD) | 3.6 (1.9) | 5.5 (5.3) | 4.0 (2.7)
Median (Min-Max) | 4.0 (0.4 - 6.0) | 2.6 (2.3 - 11.7) | 3.4 (0.4 - 11.7)
Week 16
N | 12 | 2 | 14
Mean (SD) | 3.1 (1.6) | 1.4 (1.1) | 2.9 (1.6)
Median (Min-Max) | 3.3 (1.0 - 5.3) | 1.4 (0.6 - 2.1) | 2.7 (0.6 - 5.3)
Week 20
N | 8 | 0 | 8
Mean (SD) | 2.7 (1.6) | 0 | 2.7 (1.6)
Median (Min-Max) | 2.3 (0.9 - 5.6) | 0 | 2.3 (0.9 - 5.6)
Week 28
N | 11 | 2 | 13
Mean (SD) | 3.0 (1.9) | 1.4 (0.5) | 2.7 (1.9)
Median (Min-Max) | 3.0 (0.9 - 7.8) | 1.4 (1.0 - 1.7) | 2.0 (0.9 - 7.8)
LOCF
N | 15 | 12 | 27
Mean (SD) | 3.5 (1.9) | 4.2 (4.0) | 3.8 (2.9)
Median (Min-Max) | 3.4 (0.9 - 7.8) | 3.4 (0.1 - 15.3) | 3.4 (0.1 - 15.3)
Change from Baseline to LOCF
N | 15 | 12 | 27
Mean (SD) | −0.1 (1.2) | −0.6 (1.8) | −0.3 (1.5)
Median (Min-Max) | −0.3 (−2.3 - 1.8) | −1.0 (−3.4 - 3.9) | −0.5 (−3.4 - 3.9)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.1.3.15 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group Basophils (%) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 0.5 (0.3) | 0.5 (0.3) | 0.5 (0.3)
Median (Min-Max) | 0.4 (0.0 - 1.1) | 0.4 (0.1 - 1.0) | 0.4 (0.0 - 1.1)
Week 8
N | 13 | 3 | 16
Mean (SD) | 0.6 (0.4) | 0.4 (0.1) | 0.5 (0.3)
Median (Min-Max) | 0.5 (0.2 - 1.3) | 0.4 (0.4 - 0.5) | 0.5 (0.2 - 1.3)
Week 16
N | 12 | 2 | 14
Mean (SD) | 0.6 (0.4) | 0.3 (0.1) | 0.5 (0.4)
Median (Min-Max) | 0.4 (0.2 - 1.3) | 0.3 (0.2 - 0.4) | 0.4 (0.2 - 1.3)
Week 20
N | 8 | 0 | 8
Mean (SD) | 0.3 (0.2) | 0 | 0.3 (0.2)
Median (Min-Max) | 0.3 (0.1 - 0.7) | 0 | 0.3 (0.1 - 0.7)
Week 28
N | 11 | 2 | 13
Mean (SD) | 0.3 (0.3) | 0.3 (0.1) | 0.3 (0.2)
Median (Min-Max) | 0.2 (0.0 - 0.8) | 0.3 (0.2 - 0.3) | 0.2 (0.0 - 0.8)
LOCF
N | 15 | 12 | 27
Mean (SD) | 0.3 (0.2) | 0.5 (0.3) | 0.4 (0.3)
Median (Min-Max) | 0.4 (0.0 - 0.8) | 0.4 (0.0 - 1.2) | 0.4 (0.0 - 1.2)
Change from Baseline to LOCF
N | 15 | 12 | 27
Mean (SD) | −0.2 (0.4) | 0.1 (0.2) | −0.1 (0.3)
Median (Min-Max) | −0.1 (−1.0 - 0.4) | 0.1 (−0.3 - 0.4) | 0.0 (−1.0 - 0.4)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.1.4.1 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group White Blood Count (×10^3^/μL) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 2 | 10 | 12
Mean (SD) | 8.7 (1.1) | 7.0 (1.4) | 7.3 (1.5)
Median (Min-Max) | 8.7 (7.9 - 9.5) | 7.0 (4.9 - 9.8) | 7.4 (4.9 - 9.8)
Week 4
N | 2 | 8 | 10
Mean (SD) | 8.2 (0.6) | 9.4 (2.0) | 9.2 (1.8)
Median (Min-Max) | 8.2 (7.8 - 8.6) | 8.6 (7.6 - 12.4) | 8.5 (7.6 - 12.4)
Week 8
N | 2 | 7 | 9
Mean (SD) | 8.2 (2.6) | 10.3 (1.5) | 9.8 (1.9)
Median (Min-Max) | 8.2 (6.3 - 10.0) | 10.2 (7.9 - 13.0) | 10.2 (6.3 - 13.0)
LOCF
N | 2 | 10 | 12
Mean (SD) | 8.2 (2.6) | 9.9 (2.1) | 9.6 (2.2)
Median (Min-Max) | 8.2 (6.3 - 10.0) | 10.2 (6.2 - 13.0) | 10.1 (6.2 - 13.0)
Change from Baseline to LOCF
N | 1 | 10 | 11
Mean (SD) | 0.5 | 2.9 (1.5) | 2.6 (1.6)
Median (Min-Max) | 0.5 | 3.0 (−0.1 - 4.9) | 2.9 (−0.1 - 4.9)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.1.4.2 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group Red Blood Count (×10^6^/μL) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 2 | 10 | 12
Mean (SD) | 4.5 (0.2) | 4.3 (1.1) | 4.3 (1.0)
Median (Min-Max) | 4.5 (4.4 - 4.6) | 4.6 (1.4 - 5.1) | 4.6 (1.4 - 5.1)
Week 4
N | 2 | 8 | 10
Mean (SD) | 4.5 (0.5) | 4.5 (0.3) | 4.5 (0.3)
Median (Min-Max) | 4.5 (4.2 - 4.8) | 4.5 (4.2 - 5.2) | 4.5 (4.2 - 5.2)
Week 8
N | 2 | 7 | 9
Mean (SD) | 4.9 (0.1) | 4.6 (0.3) | 4.7 (0.3)
Median (Min-Max) | 4.9 (4.8 - 4.9) | 4.6 (4.2 - 5.0) | 4.7 (4.2 - 5.0)
LOCF
N | 2 | 10 | 12
Mean (SD) | 4.9 (0.1) | 4.5 (0.3) | 4.6 (0.3)
Median (Min-Max) | 4.9 (4.8 - 4.9) | 4.5 (4.2 - 5.0) | 4.6 (4.2 - 5.0)
Change from Baseline to LOCF
N | 1 | 10 | 11
Mean (SD) | 0.5 | 0.3 (0.9) | 0.3 (0.9)
Median (Min-Max) | 0.5 | −0.1 (−0.4 - 2.8) | −0.1 (−0.4 - 2.8)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.1.4.3 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group Hemoglobin (g/dL) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 2 | 10 | 12
Mean (SD) | 13.3 (0.3) | 13.3 (1.0) | 13.3 (0.9)
Median (Min-Max) | 13.3 (13.1 - 13.5) | 13.4 (11.1 - 14.9) | 13.4 (11.1 - 14.9)
Week 4
N | 2 | 8 | 10
Mean (SD) | 12.1 (0.3) | 13.1 (1.2) | 12.9 (1.1)
Median (Min-Max) | 12.1 (11.9 - 12.3) | 13.3 (11.2 - 14.8) | 13.0 (11.2 - 14.8)
Week 8
N | 2 | 7 | 9
Mean (SD) | 13.6 (0.9) | 13.5 (1.1) | 13.5 (1.0)
Median (Min-Max) | 13.6 (12.9 - 14.2) | 13.2 (12.3 - 15.5) | 13.2 (12.3 - 15.5)
LOCF
N | 2 | 10 | 12
Mean (SD) | 13.6 (0.9) | 13.1 (1.2) | 13.2 (1.1)
Median (Min-Max) | 13.6 (12.9 - 14.2) | 13.2 (11.2 - 15.5) | 13.2 (11.2 - 15.5)
Change from Baseline to LOCF
N | 1 | 10 | 11
Mean (SD) | 1.1 | −0.1 (0.8) | 0.0 (0.9)
Median (Min-Max) | 1.1 | −0.5 (−0.9 - 2.0) | −0.4 (−0.9 - 2.0)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.1.4.4 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group Hematocrit (%) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 2 | 10 | 12
Mean (SD) | 40.7 (2.1) | 39.8 (3.0) | 40.0 (2.8)
Median (Min-Max) | 40.7 (39.2 - 42.1) | 40.2 (34.6 - 45.2) | 40.2 (34.6 - 45.2)
Week 4
N | 2 | 8 | 10
Mean (SD) | 37.2 (0.4) | 39.7 (3.9) | 39.2 (3.6)
Median (Min-Max) | 37.2 (36.9 - 37.5) | 40.5 (33.6 - 44.6) | 39.1 (33.6 - 44.6)
Week 8
N | 2 | 7 | 9
Mean (SD) | 41.0 (2.3) | 40.6 (3.1) | 40.7 (2.8)
Median (Min-Max) | 41.0 (39.3 - 42.6) | 40.2 (34.9 - 44.7) | 40.2 (34.9 - 44.7)
LOCF
N | 2 | 10 | 12
Mean (SD) | 41.0 (2.3) | 39.3 (3.7) | 39.6 (3.5)
Median (Min-Max) | 41.0 (39.3 - 42.6) | 40.2 (33.6 - 44.7) | 40.2 (33.6 - 44.7)
Change from Baseline to LOCF
N | 1 | 10 | 11
Mean (SD) | 3.4 | −0.5 (1.6) | −0.2 (1.9)
Median (Min-Max) | 3.4 | −0.5 (−3.5 - 2.1) | −0.4 (−3.5 - 3.4)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.1.4.5 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group Mean Corpuscular Volume MCV (fL) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 2 | 10 | 12
Mean (SD) | 90.5 (0.7) | 86.8 (5.3) | 87.4 (5.0)
Median (Min-Max) | 90.5 (90.0 - 91.0) | 86.1 (79.2 - 97.0) | 87.6 (79.2 - 97.0)
Week 4
N | 2 | 8 | 10
Mean (SD) | 83.0 (8.5) | 87.2 (4.5) | 86.4 (5.2)
Median (Min-Max) | 83.0 (77.0 - 89.0) | 88.0 (80.8 - 93.0) | 88.0 (77.0 - 93.0)
Week 8
N | 2 | 7 | 9
Mean (SD) | 84.0 (5.7) | 88.1 (5.1) | 87.2 (5.2)
Median (Min-Max) | 84.0 (80.0 - 88.0) | 89.0 (77.5 - 94.0) | 88.0 (77.5 - 94.0)
LOCF
N | 2 | 10 | 12
Mean (SD) | 84.0 (5.7) | 86.5 (5.0) | 86.1 (4.9)
Median (Min-Max) | 84.0 (80.0 - 88.0) | 88.0 (77.5 - 94.0) | 88.0 (77.5 - 94.0)
Change from Baseline to LOCF
N | 1 | 10 | 11
Mean (SD) | −2.0 | −0.3 (3.1) | −0.4 (3.0)
Median (Min-Max) | −2.0 | 0.5 (−8.0 - 3.0) | 0.2 (−8.0 - 3.0)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.1.4.6 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group Mean Corpuscular Hemoglobin MCH (pg) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 2 | 10 | 12
Mean (SD) | 29.7 (0.6) | 28.9 (1.4) | 29.0 (1.4)
Median (Min-Max) | 29.7 (29.2 - 30.1) | 29.1 (26.4 - 30.9) | 29.2 (26.4 - 30.9)
Week 4
N | 2 | 8 | 10
Mean (SD) | 27.1 (2.3) | 28.9 (1.3) | 28.5 (1.5)
Median (Min-Max) | 27.1 (25.4 - 28.7) | 29.1 (26.9 - 30.2) | 28.6 (25.4 - 30.2)
Week 8
N | 2 | 7 | 9
Mean (SD) | 27.9 (2.2) | 29.3 (1.2) | 29.0 (1.5)
Median (Min-Max) | 27.9 (26.3 - 29.4) | 29.5 (27.3 - 30.8) | 29.4 (26.3 - 30.8)
LOCF
N | 2 | 10 | 12
Mean (SD) | 27.9 (2.2) | 28.9 (1.3) | 28.7 (1.4)
Median (Min-Max) | 27.9 (26.3 - 29.4) | 29.0 (26.9 - 30.8) | 29.0 (26.3 - 30.8)
Change from Baseline to LOCF
N | 1 | 10 | 11
Mean (SD) | −0.7 | 0.0 (0.5) | −0.1 (0.5)
Median (Min-Max) | −0.7 | 0.2 (−0.9 - 0.6) | 0.1 (−0.9 - 0.6)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.1.4.7 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group Mean Corpuscular Hemoglobin Concentration MCHC (g/dL) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 2 | 10 | 12
Mean (SD) | 32.8 (0.9) | 33.3 (1.0) | 33.2 (1.0)
Median (Min-Max) | 32.8 (32.1 - 33.4) | 33.5 (31.7 - 34.5) | 33.4 (31.7 - 34.5)
Week 4
N | 2 | 8 | 10
Mean (SD) | 32.5 (0.4) | 33.1 (0.7) | 33.0 (0.7)
Median (Min-Max) | 32.5 (32.2 - 32.8) | 33.2 (32.0 - 34.2) | 33.0 (32.0 - 34.2)
Week 8
N | 2 | 7 | 9
Mean (SD) | 33.1 (0.4) | 33.3 (1.4) | 33.3 (1.2)
Median (Min-Max) | 33.1 (32.8 - 33.3) | 32.8 (31.9 - 35.3) | 32.8 (31.9 - 35.3)
LOCF
N | 2 | 10 | 12
Mean (SD) | 33.1 (0.4) | 33.5 (1.2) | 33.4 (1.1)
Median (Min-Max) | 33.1 (32.8 - 33.3) | 33.4 (31.9 - 35.3) | 33.3 (31.9 - 35.3)
Change from Baseline to LOCF
N | 1 | 10 | 11
Mean (SD) | −0.1 | 0.2 (1.3) | 0.1 (1.2)
Median (Min-Max) | −0.1 | −0.3 (−1.2 - 3.0) | −0.1 (−1.2 - 3.0)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.1.4.8 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group Platelet Count (×10^3^/μL) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 2 | 10 | 12
Mean (SD) | 282.5 (77.1) | 275.4 (91.4) | 276.6 (85.9)
Median (Min-Max) | 282.5 (228.0 - 337.0) | 274.0 (83.2 - 437.0) | 274.0 (83.2 - 437.0)
Week 4
N | 2 | 8 | 10
Mean (SD) | 297.5 (48.8) | 346.8 (55.2) | 336.9 (55.4)
Median (Min-Max) | 297.5 (263.0 - 332.0) | 345.5 (255.0 - 410.0) | 338.5 (255.0 - 410.0)
Week 8
N | 2 | 7 | 9
Mean (SD) | 321.5 (96.9) | 330.3 (52.4) | 328.3 (57.0)
Median (Min-Max) | 321.5 (253.0 - 390.0) | 331.0 (245.0 - 404.0) | 331.0 (245.0 - 404.0)
LOCF
N | 2 | 10 | 12
Mean (SD) | 321.5 (96.9) | 334.5 (54.6) | 332.3 (57.6)
Median (Min-Max) | 321.5 (253.0 - 390.0) | 345.0 (245.0 - 405.0) | 345.0 (245.0 - 405.0)
Change from Baseline to LOCF
N | 1 | 10 | 11
Mean (SD) | 53.0 | 59.1 (61.2) | 58.5 (58.1)
Median (Min-Max) | 53.0 | 45.5 (−32.0 - 183.8) | 53.0 (−32.0 - 183.8)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.1.4.9 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group Red Blood Cell Distribution Width RDW (%) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 2 | 10 | 12
Mean (SD) | 13.1 (1.2) | 13.2 (0.8) | 13.2 (0.8)
Median (Min-Max) | 13.1 (12.2 - 13.9) | 13.5 (11.8 - 14.3) | 13.5 (11.8 - 14.3)
Week 4
N | 2 | 8 | 10
Mean (SD) | 14.1 (2.1) | 13.3 (0.9) | 13.4 (1.1)
Median (Min-Max) | 14.1 (12.6 - 15.5) | 13.3 (11.9 - 15.0) | 13.3 (11.9 - 15.5)
Week 8
N | 2 | 7 | 9
Mean (SD) | 14.3 (2.2) | 13.2 (0.7) | 13.4 (1.1)
Median (Min-Max) | 14.3 (12.7 - 15.8) | 13.3 (11.8 - 14.1) | 13.3 (11.8 - 15.8)
LOCF
N | 2 | 10 | 12
Mean (SD) | 14.3 (2.2) | 13.4 (0.8) | 13.5 (1.0)
Median (Min-Max) | 14.3 (12.7 - 15.8) | 13.3 (11.8 - 15.0) | 13.3 (11.8 - 15.8)
Change from Baseline to LOCF
N | 1 | 10 | 11
Mean (SD) | 0.5 | 0.1 (0.8) | 0.2 (0.8)
Median (Min-Max) | 0.5 | 0.2 (−1.0 - 1.5) | 0.4 (−1.0 - 1.5)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.1.4.10 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group Mean Platelet Volume (fL) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 2 | 10 | 12
Mean (SD) | 10.6 (0.3) | 9.2 (1.5) | 9.5 (1.4)
Median (Min-Max) | 10.6 (10.4 - 10.8) | 9.1 (6.9 - 11.8) | 9.5 (6.9 - 11.8)
Week 4
N | 2 | 8 | 10
Mean (SD) | 9.9 (0.0) | 9.8 (1.3) | 9.9 (1.1)
Median (Min-Max) | 9.9 (9.9 - 9.9) | 9.4 (8.2 - 12.3) | 9.7 (8.2 - 12.3)
Week 8
N | 2 | 7 | 9
Mean (SD) | 10.4 (0.5) | 9.7 (1.4) | 9.8 (1.3)
Median (Min-Max) | 10.4 (10.0 - 10.7) | 9.1 (8.1 - 12.5) | 9.9 (8.1 - 12.5)
LOCF
N | 2 | 10 | 12
Mean (SD) | 10.4 (0.5) | 9.2 (1.5) | 9.4 (1.5)
Median (Min-Max) | 10.4 (10.0 - 10.7) | 9.1 (7.1 - 12.5) | 9.3 (7.1 - 12.5)
Change from Baseline to LOCF
N | 1 | 10 | 11
Mean (SD) | −0.4 | 0.0 (0.5) | −0.1 (0.5)
Median (Min-Max) | −0.4 | −0.2 (−0.9 - 0.7) | −0.2 (−0.9 - 0.7)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.1.4.11 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group Neutrophils (%) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 2 | 10 | 12
Mean (SD) | 59.2 (7.7) | 45.7 (16.4) | 48.0 (15.9)
Median (Min-Max) | 59.2 (53.7 - 64.6) | 50.7 (3.6 - 59.0) | 53.6 (3.6 - 64.6)
Week 4
N | 2 | 8 | 10
Mean (SD) | 55.9 (9.6) | 60.7 (10.5) | 59.8 (10.0)
Median (Min-Max) | 55.9 (49.1 - 62.7) | 61.0 (44.7 - 73.8) | 61.0 (44.7 - 73.8)
Week 8
N | 2 | 7 | 9
Mean (SD) | 58.0 (15.2) | 61.5 (7.9) | 60.7 (8.8)
Median (Min-Max) | 58.0 (47.2 - 68.7) | 62.1 (49.9 - 74.2) | 62.1 (47.2 - 74.2)
LOCF
N | 2 | 10 | 12
Mean (SD) | 58.0 (15.2) | 61.4 (7.7) | 60.8 (8.4)
Median (Min-Max) | 58.0 (47.2 - 68.7) | 60.2 (49.9 - 74.2) | 60.2 (47.2 - 74.2)
Change from Baseline to LOCF
N | 1 | 10 | 11
Mean (SD) | 4.1 | 15.7 (16.5) | 14.6 (16.0)
Median (Min-Max) | 4.1 | 9.6 (−0.6 - 54.6) | 9.5 (−0.6 - 54.6)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.1.4.12 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group Lymphocytes (%) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 2 | 10 | 12
Mean (SD) | 27.4 (6.3) | 32.0 (11.2) | 31.2 (10.4)
Median (Min-Max) | 27.4 (22.9 - 31.8) | 33.1 (2.2 - 43.1) | 32.5 (2.2 - 43.1)
Week 4
N | 2 | 8 | 10
Mean (SD) | 31.3 (10.0) | 25.3 (7.8) | 26.5 (8.0)
Median (Min-Max) | 31.3 (24.2 - 38.4) | 25.7 (14.1 - 35.5) | 25.7 (14.1 - 38.4)
Week 8
N | 2 | 7 | 9
Mean (SD) | 29.3 (16.2) | 25.9 (6.7) | 26.6 (8.3)
Median (Min-Max) | 29.3 (17.8 - 40.7) | 28.1 (15.2 - 33.5) | 28.1 (15.2 - 40.7)
LOCF
N | 2 | 10 | 12
Mean (SD) | 29.3 (16.2) | 26.2 (7.6) | 26.7 (8.5)
Median (Min-Max) | 29.3 (17.8 - 40.7) | 29.1 (14.1 - 33.5) | 29.1 (14.1 - 40.7)
Change from Baseline to LOCF
N | 1 | 10 | 11
Mean (SD) | −5.1 | −5.8 (14.6) | −5.7 (13.8)
Median (Min-Max) | −5.1 | −8.3 (−23.2 - 30.7) | −7.0 (−23.2 - 30.7)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.1.4.13 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group Monocytes (%) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 2 | 10 | 12
Mean (SD) | 8.0 (1.9) | 7.6 (3.3) | 7.7 (3.1)
Median (Min-Max) | 8.0 (6.6 - 9.3) | 8.1 (0.1 - 13.3) | 8.1 (0.1 - 13.3)
Week 4
N | 2 | 8 | 10
Mean (SD) | 7.6 (0.1) | 7.5 (1.9) | 7.6 (1.7)
Median (Min-Max) | 7.6 (7.5 - 7.7) | 7.2 (5.3 - 10.7) | 7.5 (5.3 - 10.7)
Week 8
N | 2 | 7 | 9
Mean (SD) | 7.5 (0.1) | 7.2 (0.9) | 7.2 (0.8)
Median (Min-Max) | 7.5 (7.4 - 7.6) | 7.4 (6.0 - 8.2) | 7.4 (6.0 - 8.2)
LOCF
N | 2 | 10 | 12
Mean (SD) | 7.5 (0.1) | 7.0 (0.8) | 7.1 (0.7)
Median (Min-Max) | 7.5 (7.4 - 7.6) | 7.1 (6.0 - 8.2) | 7.4 (6.0 - 8.2)
Change from Baseline to LOCF
N | 1 | 10 | 11
Mean (SD) | 0.8 | −0.6 (2.9) | −0.5 (2.8)
Median (Min-Max) | 0.8 | −0.6 (−5.4 - 6.2) | −0.5 (−5.4 - 6.2)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.1.4.14 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group Eosinophils (%) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 2 | 10 | 12
Mean (SD) | 5.3 (0.6) | 4.8 (4.1) | 4.9 (3.7)
Median (Min-Max) | 5.3 (4.8 - 5.7) | 3.8 (0.1 - 15.3) | 4.5 (0.1 - 15.3)
Week 4
N | 2 | 8 | 10
Mean (SD) | 4.8 (0.7) | 6.0 (3.2) | 5.8 (2.9)
Median (Min-Max) | 4.8 (4.3 - 5.3) | 5.1 (2.9 - 13.1) | 5.1 (2.9 - 13.1)
Week 8
N | 2 | 7 | 9
Mean (SD) | 4.7 (1.6) | 5.1 (1.6) | 5.0 (1.5)
Median (Min-Max) | 4.7 (3.6 - 5.8) | 4.7 (3.3 - 8.2) | 4.7 (3.3 - 8.2)
LOCF
N | 2 | 10 | 12
Mean (SD) | 4.7 (1.6) | 5.0 (1.9) | 5.0 (1.8)
Median (Min-Max) | 4.7 (3.6 - 5.8) | 4.5 (2.3 - 8.2) | 4.5 (2.3 - 8.2)
Change from Baseline to LOCF
N | 1 | 10 | 11
Mean (SD) | 0.1 | 0.2 (3.1) | 0.2 (2.9)
Median (Min-Max) | 0.1 | 0.9 (−7.3 - 3.7) | 0.8 (−7.3 - 3.7)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.1.4.15 Summary of Clinical Laboratory Hematology Measurement by Visit and Discontinuation Phase Treatment Received Group Basophils (%) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 2 | 10 | 12
Mean (SD) | 0.3 (0.1) | 0.5 (0.3) | 0.5 (0.3)
Median (Min-Max) | 0.3 (0.2 - 0.4) | 0.5 (0.0 - 1.2) | 0.4 (0.0 - 1.2)
Week 4
N | 2 | 8 | 10
Mean (SD) | 0.4 (0.1) | 0.5 (0.2) | 0.5 (0.2)
Median (Min-Max) | 0.4 (0.3 - 0.5) | 0.6 (0.1 - 0.8) | 0.5 (0.1 - 0.8)
Week 8
N | 2 | 7 | 9
Mean (SD) | 0.6 (0.4) | 0.4 (0.2) | 0.5 (0.2)
Median (Min-Max) | 0.6 (0.3 - 0.9) | 0.4 (0.2 - 0.7) | 0.4 (0.2 - 0.9)
LOCF
N | 2 | 10 | 12
Mean (SD) | 0.6 (0.4) | 0.4 (0.3) | 0.5 (0.3)
Median (Min-Max) | 0.6 (0.3 - 0.9) | 0.4 (0.2 - 1.0) | 0.4 (0.2 - 1.0)
Change from Baseline to LOCF
N | 1 | 10 | 11
Mean (SD) | 0.1 | −0.1 (0.3) | −0.1 (0.3)
Median (Min-Max) | 0.1 | −0.1 (−0.6 - 0.3) | −0.1 (−0.6 - 0.3)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.2.1.1 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Albumin (g/dL) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 4.3 (0.3) | 4.2 (0.4) | 4.4 (0.4) | 4.3 (0.3) | 4.3 (0.4) | 4.2 (0.4)
Median (Min-Max) | 4.3 (3.8 - 5.0) | 4.1 (3.2 - 5.0) | 4.4 (3.3 - 4.9) | 4.2 (3.9 - 4.8) | 4.3 (3.3 - 5.0) | 4.2 (3.2 - 5.0)
Week 2
N | 13 | 5 | 7 | 3 | 20 | 8
Mean (SD) | 4.2 (0.3) | 4.3 (0.6) | 4.5 (0.7) | 4.3 (0.3) | 4.3 (0.5) | 4.3 (0.5)
Median (Min-Max) | 4.2 (3.8 - 4.8) | 4.0 (3.8 - 5.2) | 4.2 (3.8 - 5.6) | 4.4 (3.9 - 4.5) | 4.2 (3.8 - 5.6) | 4.2 (3.8 - 5.2)
Week 4
N | 26 | 12 | 14 | 10 | 40 | 22
Mean (SD) | 4.4 (0.3) | 4.2 (0.5) | 4.5 (0.5) | 4.2 (0.2) | 4.4 (0.4) | 4.2 (0.4)
Median (Min-Max) | 4.4 (3.8 - 5.2) | 4.1 (3.5 - 5.3) | 4.5 (3.4 - 5.6) | 4.2 (4.0 - 4.6) | 4.4 (3.4 - 5.6) | 4.2 (3.5 - 5.3)
Week 8
N | 29 | 12 | 20 | 10 | 49 | 22
Mean (SD) | 4.3 (0.4) | 4.2 (0.4) | 4.4 (0.4) | 4.2 (0.3) | 4.4 (0.4) | 4.2 (0.4)
Median (Min-Max) | 4.2 (3.7 - 5.0) | 4.2 (3.5 - 5.1) | 4.5 (3.4 - 5.0) | 4.2 (3.7 - 4.7) | 4.4 (3.4 - 5.0) | 4.2 (3.5 - 5.1)
LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 4.3 (0.4) | 4.2 (0.4) | 4.5 (0.5) | 4.2 (0.3) | 4.4 (0.4) | 4.2 (0.4)
Median (Min-Max) | 4.2 (3.7 - 5.0) | 4.2 (3.5 - 5.1) | 4.5 (3.4 - 5.6) | 4.2 (3.7 - 4.7) | 4.4 (3.4 - 5.6) | 4.2 (3.5 - 5.1)
Change from Baseline to LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 0.0 (0.3) | 0.0 (0.3) | 0.1 (0.3) | −0.1 (0.2) | 0.1 (0.3) | 0.0 (0.2)
Median (Min-Max) | 0.0 (−0.4 - 0.7) | −0.1 (−0.3 - 0.6) | 0.1 (−0.4 - 0.7) | 0.0 (−0.5 - 0.1) | 0.0 (−0.4 - 0.7) | 0.0 (−0.5 - 0.6)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.2.1.2 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Alkaline Phosphatase (U/L) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 258.4 (75.4) | 289.2 (104.5) | 166.6 (78.2) | 184.2 (92.9) | 222.0 (88.3) | 248.0 (111.4)
Median (Min-Max) | 257.5 (111.0 - 435.0) | 263.0 (121.0 - 498.0) | 139.0 (74.0 - 329.0) | 210.0 (65.0 - 366.0) | 219.0 (74.0 - 435.0) | 232.0 (65.0 - 498.0)
Week 2
N | 13 | 5 | 7 | 3 | 20 | 8
Mean (SD) | 272.9 (59.5) | 270.4 (103.9) | 188.4 (99.9) | 96.3 (22.5) | 243.4 (84.3) | 205.1 (120.1)
Median (Min-Max) | 257.0 (200.0 - 454.0) | 237.0 (177.0 - 440.0) | 183.0 (72.0 - 337.0) | 104.0 (71.0 - 114.0) | 253.5 (72.0 - 454.0) | 191.5 (71.0 - 440.0)
Week 4
N | 26 | 12 | 14 | 10 | 40 | 22
Mean (SD) | 350.2 (108.3) | 275.2 (80.8) | 175.4 (99.4) | 182.0 (92.7) | 289.0 (133.9) | 232.8 (96.8)
Median (Min-Max) | 337.5 (193.0 - 616.0) | 263.5 (155.0 - 405.0) | 140.0 (77.0 - 384.0) | 207.0 (69.0 - 357.0) | 274.0 (77.0 - 616.0) | 220.5 (69.0 - 405.0)
Week 8
N | 29 | 12 | 20 | 10 | 49 | 22
Mean (SD) | 343.2 (117.2) | 254.3 (71.6) | 185.2 (92.4) | 179.8 (84.5) | 278.7 (132.5) | 220.5 (84.8)
Median (Min-Max) | 317.0 (154.0 - 658.0) | 238.5 (152.0 - 422.0) | 153.5 (84.0 - 396.0) | 197.0 (70.0 - 316.0) | 285.0 (84.0 - 658.0) | 226.0 (70.0 - 422.0)
LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 340.3 (116.6) | 277.3 (85.7) | 183.3 (90.5) | 179.8 (84.5) | 276.9 (131.4) | 239.8 (96.5)
Median (Min-Max) | 317.0 (154.0 - 658.0) | 247.5 (152.0 - 440.0) | 145.0 (84.0 - 396.0) | 197.0 (70.0 - 316.0) | 277.5 (84.0 - 658.0) | 237.0 (70.0 - 440.0)
Change from Baseline to LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 77.2 (76.2) | −10.3 (38.3) | 16.7 (41.8) | −8.3 (30.6) | 52.8 (70.7) | −9.5 (34.9)
Median (Min-Max) | 63.0 (−6.0 - 340.0) | −6.5 (−73.0 - 49.0) | 12.0 (−42.0 - 126.0) | 2.0 (−73.0 - 23.0) | 36.0 (−42.0 - 340.0) | −2.5 (−73.0 - 49.0)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.2.1.3 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Alanine Aminotransferase - ALT (U/L) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 26.2 (12.7) | 28.9 (11.8) | 20.2 (7.9) | 21.0 (8.9) | 23.8 (11.4) | 25.8 (11.3)
Median (Min-Max) | 24.0 (9.0 - 71.0) | 28.0 (9.0 - 48.0) | 18.0 (9.0 - 41.0) | 18.0 (13.0 - 37.0) | 22.0 (9.0 - 71.0) | 22.5 (9.0 - 48.0)
Week 2
N | 13 | 5 | 7 | 3 | 20 | 8
Mean (SD) | 33.6 (14.7) | 19.6 (8.0) | 31.4 (25.4) | 15.0 (1.0) | 32.9 (18.5) | 17.9 (6.5)
Median (Min-Max) | 32.0 (18.0 - 76.0) | 19.0 (10.0 - 31.0) | 24.0 (11.0 - 85.0) | 15.0 (14.0 - 16.0) | 29.5 (11.0 - 85.0) | 15.5 (10.0 - 31.0)
Week 4
N | 26 | 12 | 14 | 10 | 40 | 22
Mean (SD) | 28.8 (9.5) | 30.1 (13.0) | 23.8 (11.3) | 23.5 (10.6) | 27.1 (10.3) | 27.1 (12.2)
Median (Min-Max) | 30.0 (14.0 - 48.0) | 31.0 (6.0 - 50.0) | 23.5 (7.0 - 42.0) | 22.5 (6.0 - 40.0) | 28.0 (7.0 - 48.0) | 25.5 (6.0 - 50.0)
Week 8
N | 29 | 12 | 20 | 10 | 49 | 22
Mean (SD) | 32.3 (19.7) | 25.9 (14.6) | 24.5 (13.4) | 19.2 (6.8) | 29.1 (17.7) | 22.9 (11.9)
Median (Min-Max) | 27.0 (13.0 - 114.0) | 25.0 (7.0 - 63.0) | 20.0 (8.0 - 57.0) | 19.0 (9.0 - 29.0) | 25.0 (8.0 - 114.0) | 23.0 (7.0 - 63.0)
LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 31.5 (19.3) | 27.3 (14.2) | 23.9 (13.4) | 19.2 (6.8) | 28.4 (17.5) | 24.2 (12.4)
Median (Min-Max) | 26.0 (13.0 - 114.0) | 25.0 (7.0 - 63.0) | 19.0 (8.0 - 57.0) | 19.0 (9.0 - 29.0) | 24.5 (8.0 - 114.0) | 23.5 (7.0 - 63.0)
Change from Baseline to LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 4.8 (10.2) | −1.8 (7.5) | 3.7 (13.2) | −2.3 (6.7) | 4.3 (11.4) | −2.0 (7.1)
Median (Min-Max) | 4.0 (−9.0 - 43.0) | −2.0 (−14.0 - 15.0) | 2.0 (−33.0 - 32.0) | −3.0 (−11.0 - 8.0) | 2.0 (−33.0 - 43.0) | −2.0 (−14.0 - 15.0)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.2.1.4 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Aspartate Aminotransferase - AST (U/L) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 24.3 (7.0) | 27.5 (8.2) | 22.1 (6.4) | 21.0 (6.6) | 23.5 (6.8) | 25.0 (8.1)
Median (Min-Max) | 22.5 (10.0 - 41.0) | 27.0 (16.0 - 44.0) | 22.0 (11.0 - 36.0) | 21.0 (10.0 - 32.0) | 22.0 (10.0 - 41.0) | 23.5 (10.0 - 44.0)
Week 2
N | 13 | 5 | 7 | 3 | 20 | 8
Mean (SD) | 26.3 (5.5) | 28.8 (6.1) | 30.6 (11.3) | 19.7 (2.3) | 27.8 (8.0) | 25.4 (6.7)
Median (Min-Max) | 24.0 (17.0 - 38.0) | 26.0 (24.0 - 39.0) | 25.0 (19.0 - 44.0) | 21.0 (17.0 - 21.0) | 24.5 (17.0 - 44.0) | 24.5 (17.0 - 39.0)
Week 4
N | 26 | 12 | 14 | 10 | 40 | 22
Mean (SD) | 25.5 (7.0) | 27.3 (10.5) | 24.8 (10.8) | 24.3 (6.1) | 25.2 (8.4) | 25.9 (8.7)
Median (Min-Max) | 23.5 (17.0 - 51.0) | 25.0 (16.0 - 51.0) | 23.0 (13.0 - 46.0) | 21.5 (18.0 - 35.0) | 23.5 (13.0 - 51.0) | 23.5 (16.0 - 51.0)
Week 8
N | 29 | 12 | 20 | 10 | 49 | 22
Mean (SD) | 27.0 (8.5) | 24.0 (7.7) | 24.0 (8.4) | 21.5 (7.6) | 25.8 (8.5) | 22.9 (7.6)
Median (Min-Max) | 26.0 (14.0 - 54.0) | 24.5 (10.0 - 39.0) | 23.0 (9.0 - 47.0) | 20.5 (12.0 - 35.0) | 25.0 (9.0 - 54.0) | 22.5 (10.0 - 39.0)
LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 26.8 (8.3) | 24.8 (8.2) | 23.9 (8.2) | 21.5 (7.6) | 25.7 (8.3) | 23.5 (7.9)
Median (Min-Max) | 26.0 (14.0 - 54.0) | 25.5 (10.0 - 41.0) | 22.0 (9.0 - 47.0) | 20.5 (12.0 - 35.0) | 25.0 (9.0 - 54.0) | 23.0 (10.0 - 41.0)
Change from Baseline to LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 2.3 (6.0) | −1.9 (4.9) | 1.8 (8.0) | 0.1 (3.6) | 2.1 (6.8) | −1.2 (4.5)
Median (Min-Max) | 3.0 (−8.0 - 22.0) | −2.5 (−12.0 - 7.0) | 2.0 (−18.0 - 25.0) | −1.0 (−4.0 - 5.0) | 2.0 (−18.0 - 25.0) | −2.0 (−12.0 - 7.0)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.2.1.5 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Bicarbonate (mEq/L) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 24.8 (1.9) | 24.6 (2.6) | 26.0 (2.3) | 26.2 (2.4) | 25.3 (2.1) | 25.3 (2.6)
Median (Min-Max) | 25.5 (20.0 - 27.0) | 25.0 (17.0 - 28.0) | 26.0 (20.0 - 29.0) | 26.0 (23.0 - 30.0) | 26.0 (20.0 - 29.0) | 25.0 (17.0 - 30.0)
Week 2
N | 13 | 5 | 7 | 3 | 20 | 8
Mean (SD) | 25.8 (2.1) | 25.6 (2.1) | 26.9 (2.4) | 24.0 (3.6) | 26.2 (2.2) | 25.0 (2.6)
Median (Min-Max) | 25.0 (22.0 - 29.0) | 25.0 (24.0 - 29.0) | 27.0 (22.0 - 29.0) | 23.0 (21.0 - 28.0) | 26.5 (22.0 - 29.0) | 24.5 (21.0 - 29.0)
Week 4
N | 26 | 12 | 14 | 10 | 40 | 22
Mean (SD) | 25.1 (2.1) | 25.2 (2.7) | 25.4 (2.8) | 25.0 (1.7) | 25.2 (2.4) | 25.1 (2.2)
Median (Min-Max) | 24.5 (22.0 - 30.0) | 25.5 (20.0 - 30.0) | 26.0 (20.0 - 30.0) | 24.5 (22.0 - 27.0) | 25.0 (20.0 - 30.0) | 25.0 (20.0 - 30.0)
Week 8
N | 29 | 12 | 20 | 10 | 49 | 22
Mean (SD) | 25.7 (1.9) | 25.1 (3.0) | 25.2 (2.3) | 23.8 (2.5) | 25.5 (2.1) | 24.5 (2.8)
Median (Min-Max) | 26.0 (21.0 - 29.0) | 25.5 (18.0 - 29.0) | 26.0 (21.0 - 29.0) | 23.0 (21.0 - 28.0) | 26.0 (21.0 - 29.0) | 24.5 (18.0 - 29.0)
LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 25.5 (1.9) | 25.3 (2.7) | 25.0 (2.3) | 23.8 (2.5) | 25.3 (2.1) | 24.7 (2.7)
Median (Min-Max) | 26.0 (21.0 - 29.0) | 25.5 (18.0 - 29.0) | 26.0 (21.0 - 29.0) | 23.0 (21.0 - 28.0) | 26.0 (21.0 - 29.0) | 25.0 (18.0 - 29.0)
Change from Baseline to LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 0.6 (2.1) | 0.4 (3.9) | −1.0 (2.2) | −2.0 (2.6) | 0.0 (2.2) | −0.5 (3.6)
Median (Min-Max) | 1.0 (−5.0 - 5.0) | 0.5 (−6.0 - 11.0) | −1.0 (−6.0 - 2.0) | −1.5 (−8.0 - 1.0) | 0.0 (−6.0 - 5.0) | 0.0 (−8.0 - 11.0)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.2.1.6 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Direct Bilirubin (mg/dL) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 31 | 17 | 21 | 11 | 52 | 28
Mean (SD) | 0.1 (0.1) | 0.1 (0.0) | 0.1 (0.0) | 0.1 (0.0) | 0.1 (0.1) | 0.1 (0.0)
Median (Min-Max) | 0.1 (0.0 - 0.3) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 0.2) | 0.1 (0.1 - 0.2) | 0.1 (0.0 - 0.3) | 0.1 (0.0 - 0.2)
Week 2
N | 13 | 5 | 7 | 3 | 20 | 8
Mean (SD) | 0.1 (0.0) | 0.1 (0.1) | 0.1 (0.1) | 0.1 (0.0) | 0.1 (0.1) | 0.1 (0.1)
Median (Min-Max) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 0.2) | 0.1 (0.1 - 0.1) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 0.2)
Week 4
N | 25 | 12 | 13 | 10 | 38 | 22
Mean (SD) | 0.1 (0.1) | 0.1 (0.1) | 0.1 (0.1) | 0.1 (0.1) | 0.1 (0.1) | 0.1 (0.1)
Median (Min-Max) | 0.1 (0.0 - 0.3) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 0.3) | 0.1 (0.0 - 0.2)
Week 8
N | 29 | 12 | 19 | 9 | 48 | 21
Mean (SD) | 0.1 (0.0) | 0.1 (0.1) | 0.1 (0.1) | 0.1 (0.0) | 0.1 (0.0) | 0.1 (0.0)
Median (Min-Max) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 0.2) | 0.1 (0.1 - 0.2) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 0.2)
LOCF
N | 31 | 16 | 20 | 9 | 51 | 25
Mean (SD) | 0.1 (0.0) | 0.1 (0.1) | 0.1 (0.1) | 0.1 (0.0) | 0.1 (0.0) | 0.1 (0.0)
Median (Min-Max) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 0.2) | 0.1 (0.1 - 0.2) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 0.2)
Change from Baseline to LOCF
N | 31 | 16 | 20 | 9 | 51 | 25
Mean (SD) | 0.0 (0.1) | 0.0 (0.0) | 0.0 (0.0) | 0.0 (0.1) | 0.0 (0.1) | 0.0 (0.0)
Median (Min-Max) | 0.0 (−0.2 - 0.1) | 0.0 (−0.1 - 0.1) | 0.0 (0.0 - 0.1) | 0.0 (−0.1 - 0.1) | 0.0 (−0.2 - 0.1) | 0.0 (−0.1 - 0.1)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.2.1.7 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Total Bilirubin (mg/dL) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 31 | 17 | 21 | 11 | 52 | 28
Mean (SD) | 0.4 (0.2) | 0.4 (0.2) | 0.4 (0.2) | 0.5 (0.2) | 0.4 (0.2) | 0.4 (0.2)
Median (Min-Max) | 0.4 (0.2 - 0.8) | 0.3 (0.2 - 0.7) | 0.3 (0.2 - 1.0) | 0.4 (0.2 - 0.8) | 0.4 (0.2 - 1.0) | 0.4 (0.2 - 0.8)
Week 2
N | 12 | 5 | 7 | 3 | 19 | 8
Mean (SD) | 0.4 (0.2) | 0.5 (0.2) | 0.7 (0.3) | 0.4 (0.4) | 0.5 (0.3) | 0.5 (0.3)
Median (Min-Max) | 0.4 (0.2 - 0.8) | 0.4 (0.2 - 0.8) | 0.5 (0.3 - 1.1) | 0.2 (0.2 - 0.9) | 0.5 (0.2 - 1.1) | 0.4 (0.2 - 0.9)
Week 4
N | 26 | 12 | 14 | 10 | 40 | 22
Mean (SD) | 0.4 (0.2) | 0.3 (0.2) | 0.6 (0.3) | 0.5 (0.3) | 0.5 (0.3) | 0.4 (0.2)
Median (Min-Max) | 0.3 (0.2 - 0.8) | 0.3 (0.1 - 0.8) | 0.6 (0.2 - 1.6) | 0.6 (0.1 - 0.9) | 0.4 (0.2 - 1.6) | 0.3 (0.1 - 0.9)
Week 8
N | 29 | 12 | 20 | 10 | 49 | 22
Mean (SD) | 0.4 (0.2) | 0.4 (0.3) | 0.6 (0.3) | 0.5 (0.2) | 0.5 (0.3) | 0.4 (0.2)
Median (Min-Max) | 0.4 (0.2 - 1.3) | 0.3 (0.2 - 0.8) | 0.5 (0.2 - 1.1) | 0.4 (0.3 - 0.8) | 0.5 (0.2 - 1.3) | 0.4 (0.2 - 0.8)
LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 0.5 (0.2) | 0.4 (0.2) | 0.6 (0.3) | 0.5 (0.2) | 0.5 (0.2) | 0.4 (0.2)
Median (Min-Max) | 0.4 (0.2 - 1.3) | 0.3 (0.2 - 0.8) | 0.5 (0.2 - 1.1) | 0.4 (0.3 - 0.8) | 0.5 (0.2 - 1.3) | 0.4 (0.2 - 0.8)
Change from Baseline to LOCF
N | 30 | 16 | 21 | 10 | 51 | 26
Mean (SD) | 0.0 (0.2) | 0.0 (0.1) | 0.1 (0.2) | 0.0 (0.2) | 0.1 (0.2) | 0.0 (0.2)
Median (Min-Max) | 0.0 (−0.3 - 0.6) | 0.0 (−0.2 - 0.2) | 0.1 (−0.2 - 0.4) | 0.0 (−0.3 - 0.4) | 0.0 (−0.3 - 0.6) | 0.0 (−0.3 - 0.4)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.2.1.8 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Calcium (mg/dL) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 9.6 (0.5) | 9.7 (0.4) | 9.6 (0.3) | 9.7 (0.4) | 9.6 (0.4) | 9.7 (0.4)
Median (Min-Max) | 9.6 (8.7 - 10.5) | 9.7 (8.7 - 10.2) | 9.6 (9.1 - 10.2) | 9.8 (9.1 - 10.4) | 9.6 (8.7 - 10.5) | 9.7 (8.7 - 10.4)
Week 2
N | 13 | 5 | 7 | 3 | 20 | 8
Mean (SD) | 9.4 (0.5) | 9.6 (0.4) | 9.6 (0.6) | 9.5 (0.2) | 9.5 (0.5) | 9.6 (0.3)
Median (Min-Max) | 9.5 (8.5 - 10.0) | 9.5 (9.1 - 10.2) | 9.4 (8.9 - 10.4) | 9.4 (9.3 - 9.7) | 9.5 (8.5 - 10.4) | 9.5 (9.1 - 10.2)
Week 4
N | 26 | 12 | 14 | 10 | 40 | 22
Mean (SD) | 9.7 (0.4) | 9.5 (0.5) | 9.9 (0.5) | 9.5 (0.4) | 9.7 (0.5) | 9.5 (0.4)
Median (Min-Max) | 9.5 (9.2 - 10.6) | 9.5 (8.7 - 10.5) | 9.9 (9.3 - 11.1) | 9.5 (8.9 - 10.3) | 9.5 (9.2 - 11.1) | 9.5 (8.7 - 10.5)
Week 8
N | 29 | 12 | 20 | 10 | 49 | 22
Mean (SD) | 9.7 (0.4) | 9.4 (0.4) | 9.7 (0.5) | 9.5 (0.5) | 9.7 (0.4) | 9.5 (0.5)
Median (Min-Max) | 9.8 (8.8 - 10.5) | 9.5 (8.8 - 10.0) | 9.8 (8.9 - 10.5) | 9.6 (8.9 - 10.3) | 9.8 (8.8 - 10.5) | 9.6 (8.8 - 10.3)
LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 9.7 (0.4) | 9.4 (0.4) | 9.7 (0.5) | 9.5 (0.5) | 9.7 (0.4) | 9.5 (0.4)
Median (Min-Max) | 9.8 (8.8 - 10.5) | 9.4 (8.8 - 10.0) | 9.8 (8.9 - 10.5) | 9.6 (8.9 - 10.3) | 9.8 (8.8 - 10.5) | 9.5 (8.8 - 10.3)
Change from Baseline to LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 0.2 (0.3) | −0.2 (0.5) | 0.1 (0.4) | −0.2 (0.3) | 0.2 (0.4) | −0.2 (0.4)
Median (Min-Max) | 0.1 (−0.4 - 0.8) | −0.2 (−0.9 - 0.9) | 0.2 (−0.9 - 0.7) | −0.2 (−0.6 - 0.3) | 0.2 (−0.9 - 0.8) | −0.2 (−0.9 - 0.9)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.2.1.9 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Chloride (mEq/L) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 103.1 (2.9) | 103.3 (2.2) | 103.3 (2.0) | 103.7 (1.7) | 103.2 (2.5) | 103.5 (2.0)
Median (Min-Max) | 103.0 (97.0 - 108.0) | 104.0 (97.0 - 107.0) | 104.0 (99.0 - 107.0) | 104.0 (101.0 - 107.0) | 103.0 (97.0 - 108.0) | 104.0 (97.0 - 107.0)
Week 2
N | 13 | 5 | 7 | 3 | 20 | 8
Mean (SD) | 104.3 (2.5) | 104.4 (1.1) | 104.1 (2.0) | 105.3 (2.1) | 104.3 (2.2) | 104.8 (1.5)
Median (Min-Max) | 104.0 (100.0 - 108.0) | 104.0 (103.0 - 106.0) | 104.0 (102.0 - 108.0) | 106.0 (103.0 - 107.0) | 104.0 (100.0 - 108.0) | 104.5 (103.0 - 107.0)
Week 4
N | 26 | 12 | 14 | 10 | 40 | 22
Mean (SD) | 104.3 (1.9) | 102.4 (2.2) | 103.1 (2.4) | 105.1 (2.4) | 103.9 (2.2) | 103.6 (2.6)
Median (Min-Max) | 104.5 (101.0 - 108.0) | 102.5 (98.0 - 107.0) | 103.0 (100.0 - 107.0) | 104.5 (102.0 - 109.0) | 104.0 (100.0 - 108.0) | 103.0 (98.0 - 109.0)
Week 8
N | 29 | 12 | 20 | 10 | 49 | 22
Mean (SD) | 103.9 (2.2) | 103.3 (2.4) | 103.7 (2.0) | 105.0 (2.8) | 103.8 (2.1) | 104.0 (2.7)
Median (Min-Max) | 104.0 (100.0 - 109.0) | 103.5 (99.0 - 106.0) | 104.0 (99.0 - 107.0) | 105.0 (101.0 - 110.0) | 104.0 (99.0 - 109.0) | 104.5 (99.0 - 110.0)
LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 104.1 (2.3) | 103.3 (2.2) | 103.7 (2.0) | 105.0 (2.8) | 103.9 (2.2) | 103.9 (2.5)
Median (Min-Max) | 104.0 (100.0 - 109.0) | 103.5 (99.0 - 106.0) | 104.0 (99.0 - 107.0) | 105.0 (101.0 - 110.0) | 104.0 (99.0 - 109.0) | 104.0 (99.0 - 110.0)
Change from Baseline to LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 1.2 (2.4) | 0.0 (2.3) | 0.3 (2.6) | 1.0 (2.9) | 0.8 (2.5) | 0.4 (2.6)
Median (Min-Max) | 2.0 (−5.0 - 5.0) | 0.0 (−4.0 - 4.0) | 0.0 (−4.0 - 6.0) | 1.5 (−3.0 - 5.0) | 1.0 (−5.0 - 6.0) | 0.0 (−4.0 - 5.0)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.2.1.10 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Cholesterol (mg/dL) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 158.3 (24.6) | 158.0 (27.2) | 160.3 (24.8) | 158.7 (31.3) | 159.1 (24.4) | 158.3 (28.3)
Median (Min-Max) | 156.5 (101.0 - 222.0) | 157.0 (113.0 - 224.0) | 157.0 (126.0 - 223.0) | 152.0 (120.0 - 215.0) | 157.0 (101.0 - 223.0) | 153.5 (113.0 - 224.0)
Week 2
N | 13 | 5 | 7 | 3 | 20 | 8
Mean (SD) | 154.9 (24.1) | 146.8 (15.9) | 154.9 (25.5) | 143.7 (44.7) | 154.9 (23.9) | 145.6 (26.8)
Median (Min-Max) | 149.0 (117.0 - 201.0) | 141.0 (132.0 - 170.0) | 155.0 (117.0 - 185.0) | 123.0 (113.0 - 195.0) | 152.0 (117.0 - 201.0) | 138.0 (113.0 - 195.0)
Week 4
N | 25 | 12 | 14 | 10 | 39 | 22
Mean (SD) | 166.0 (35.0) | 163.5 (23.2) | 176.4 (28.8) | 167.4 (36.6) | 169.7 (32.9) | 165.3 (29.3)
Median (Min-Max) | 168.0 (115.0 - 258.0) | 168.5 (117.0 - 192.0) | 170.0 (137.0 - 239.0) | 164.5 (116.0 - 254.0) | 169.0 (115.0 - 258.0) | 164.5 (116.0 - 254.0)
Week 8
N | 29 | 12 | 20 | 10 | 49 | 22
Mean (SD) | 162.0 (33.4) | 164.5 (22.5) | 157.5 (34.7) | 165.0 (30.2) | 160.1 (33.7) | 164.7 (25.6)
Median (Min-Max) | 160.0 (98.0 - 233.0) | 164.5 (134.0 - 202.0) | 149.0 (110.0 - 248.0) | 167.0 (112.0 - 228.0) | 155.0 (98.0 - 248.0) | 164.5 (112.0 - 228.0)
LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 161.3 (33.1) | 165.1 (21.6) | 158.8 (34.4) | 165.0 (30.2) | 160.3 (33.3) | 165.0 (24.7)
Median (Min-Max) | 160.0 (98.0 - 233.0) | 164.5 (134.0 - 202.0) | 150.0 (110.0 - 248.0) | 167.0 (112.0 - 228.0) | 155.5 (98.0 - 248.0) | 164.5 (112.0 - 228.0)
Change from Baseline to LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 3.1 (18.1) | 5.4 (14.4) | −1.5 (26.8) | 3.1 (17.2) | 1.2 (21.9) | 4.5 (15.3)
Median (Min-Max) | 4.0 (−27.0 - 35.0) | 3.0 (−22.0 - 31.0) | 2.0 (−51.0 - 48.0) | 1.5 (−29.0 - 29.0) | 3.0 (−51.0 - 48.0) | 3.0 (−29.0 - 31.0)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.2.1.11 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Creatine kinase (U/L) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 31 | 17 | 20 | 11 | 51 | 28
Mean (SD) | 129.3 (58.1) | 151.2 (72.4) | 117.1 (78.4) | 267.0 (392.5) | 124.5 (66.3) | 196.7 (252.0)
Median (Min-Max) | 107.0 (68.0 - 308.0) | 131.0 (64.0 - 303.0) | 85.5 (19.0 - 310.0) | 131.0 (88.0 - 1438) | 102.0 (19.0 - 310.0) | 131.0 (64.0 - 1438)
Week 2
N | 13 | 5 | 7 | 3 | 20 | 8
Mean (SD) | 106.3 (29.9) | 141.4 (69.3) | 92.6 (52.6) | 183.0 (68.5) | 101.5 (38.5) | 157.0 (67.4)
Median (Min-Max) | 109.0 (60.0 - 159.0) | 104.0 (76.0 - 240.0) | 77.0 (39.0 - 200.0) | 202.0 (107.0 - 240.0) | 94.5 (39.0 - 200.0) | 147.0 (76.0 - 240.0)
Week 4
N | 24 | 12 | 13 | 10 | 37 | 22
Mean (SD) | 159.4 (150.7) | 136.7 (51.5) | 146.9 (115.1) | 222.2 (200.2) | 155.0 (137.7) | 175.5 (143.1)
Median (Min-Max) | 110.0 (56.0 - 780.0) | 135.5 (75.0 - 261.0) | 79.0 (22.0 - 334.0) | 164.0 (62.0 - 766.0) | 109.0 (22.0 - 780.0) | 144.0 (62.0 - 766.0)
Week 8
N | 29 | 12 | 18 | 10 | 47 | 22
Mean (SD) | 107.5 (49.8) | 153.0 (70.3) | 127.5 (91.6) | 226.3 (259.8) | 115.2 (68.6) | 186.3 (181.4)
Median (Min-Max) | 101.0 (48.0 - 300.0) | 146.0 (73.0 - 264.0) | 100.5 (28.0 - 382.0) | 132.5 (51.0 - 947.0) | 101.0 (28.0 - 382.0) | 136.0 (51.0 - 947.0)
LOCF
N | 31 | 16 | 19 | 10 | 50 | 26
Mean (SD) | 114.8 (58.5) | 150.4 (62.4) | 124.8 (89.8) | 226.3 (259.8) | 118.6 (71.3) | 179.6 (167.5)
Median (Min-Max) | 107.0 (48.0 - 300.0) | 142.0 (73.0 - 264.0) | 98.0 (28.0 - 382.0) | 132.5 (51.0 - 947.0) | 102.0 (28.0 - 382.0) | 139.5 (51.0 - 947.0)
Change from Baseline to LOCF
N | 31 | 16 | 19 | 10 | 50 | 26
Mean (SD) | −14.5 (39.8) | 2.1 (25.6) | 2.6 (35.3) | −57.0 (163.6) | −8.0 (38.7) | −20.7 (104.4)
Median (Min-Max) | −20.0 (−87.0 - 134.0) | 4.5 (−45.0 - 56.0) | −6.0 (−62.0 - 84.0) | 3.0 (−491 - 70.0) | −10.0 (−87.0 - 134.0) | 4.0 (−491 - 70.0)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.2.1.12 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Creatinine (mg/dL) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 0.5 (0.1) | 0.6 (0.1) | 0.7 (0.2) | 0.7 (0.1) | 0.6 (0.2) | 0.6 (0.2)
Median (Min-Max) | 0.5 (0.3 - 0.7) | 0.6 (0.4 - 0.8) | 0.6 (0.5 - 1.2) | 0.8 (0.5 - 0.9) | 0.6 (0.3 - 1.2) | 0.6 (0.4 - 0.9)
Week 2
N | 13 | 5 | 7 | 3 | 20 | 8
Mean (SD) | 0.6 (0.1) | 0.6 (0.1) | 0.7 (0.1) | 0.8 (0.2) | 0.6 (0.1) | 0.7 (0.2)
Median (Min-Max) | 0.5 (0.4 - 0.8) | 0.6 (0.5 - 0.7) | 0.7 (0.6 - 0.8) | 0.9 (0.5 - 0.9) | 0.6 (0.4 - 0.8) | 0.6 (0.5 - 0.9)
Week 4
N | 26 | 12 | 14 | 10 | 40 | 22
Mean (SD) | 0.6 (0.1) | 0.6 (0.1) | 0.8 (0.2) | 0.7 (0.1) | 0.6 (0.2) | 0.6 (0.1)
Median (Min-Max) | 0.6 (0.5 - 0.8) | 0.6 (0.4 - 0.7) | 0.7 (0.6 - 1.1) | 0.7 (0.6 - 1.0) | 0.6 (0.5 - 1.1) | 0.6 (0.4 - 1.0)
Week 8
N | 29 | 12 | 20 | 10 | 49 | 22
Mean (SD) | 0.6 (0.1) | 0.5 (0.1) | 0.7 (0.2) | 0.8 (0.2) | 0.6 (0.1) | 0.6 (0.2)
Median (Min-Max) | 0.6 (0.4 - 0.8) | 0.5 (0.4 - 0.7) | 0.7 (0.4 - 1.1) | 0.8 (0.5 - 1.2) | 0.6 (0.4 - 1.1) | 0.6 (0.4 - 1.2)
LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 0.6 (0.1) | 0.5 (0.1) | 0.7 (0.2) | 0.8 (0.2) | 0.6 (0.1) | 0.6 (0.2)
Median (Min-Max) | 0.6 (0.4 - 0.8) | 0.5 (0.4 - 0.7) | 0.7 (0.4 - 1.1) | 0.8 (0.5 - 1.2) | 0.6 (0.4 - 1.1) | 0.6 (0.4 - 1.2)
Change from Baseline to LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 0.1 (0.1) | 0.0 (0.1) | 0.0 (0.1) | 0.0 (0.1) | 0.0 (0.1) | 0.0 (0.1)
Median (Min-Max) | 0.1 (−0.2 - 0.2) | 0.0 (−0.3 - 0.2) | 0.1 (−0.2 - 0.2) | 0.0 (−0.2 - 0.3) | 0.1 (−0.2 - 0.2) | 0.0 (−0.3 - 0.3)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.2.1.13 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Gamma-glutamyl Transpeptidase - GGT (U/L) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 20 | 11 | 52 | 28
Mean (SD) | 18.4 (7.4) | 21.7 (11.1) | 18.7 (9.5) | 16.9 (7.5) | 18.5 (8.2) | 19.8 (10.0)
Median (Min-Max) | 17.0 (7.0 - 39.0) | 21.0 (6.0 - 43.0) | 15.5 (5.0 - 42.0) | 15.0 (7.0 - 30.0) | 17.0 (5.0 - 42.0) | 20.0 (6.0 - 43.0)
Week 2
N | 13 | 5 | 6 | 3 | 19 | 8
Mean (SD) | 19.2 (6.1) | 16.8 (7.2) | 15.7 (4.8) | 12.7 (5.0) | 18.1 (5.8) | 15.3 (6.4)
Median (Min-Max) | 18.0 (9.0 - 28.0) | 16.0 (10.0 - 26.0) | 15.0 (11.0 - 24.0) | 12.0 (8.0 - 18.0) | 17.0 (9.0 - 28.0) | 14.0 (8.0 - 26.0)
Week 4
N | 25 | 12 | 14 | 10 | 39 | 22
Mean (SD) | 19.2 (6.4) | 19.1 (8.4) | 17.8 (9.2) | 16.3 (7.3) | 18.7 (7.5) | 17.8 (7.9)
Median (Min-Max) | 20.0 (10.0 - 32.0) | 17.0 (8.0 - 36.0) | 15.0 (9.0 - 44.0) | 12.5 (8.0 - 30.0) | 19.0 (9.0 - 44.0) | 16.0 (8.0 - 36.0)
Week 8
N | 29 | 12 | 20 | 10 | 49 | 22
Mean (SD) | 20.8 (11.9) | 21.3 (12.5) | 17.7 (8.8) | 18.3 (9.2) | 19.5 (10.7) | 20.0 (11.0)
Median (Min-Max) | 18.0 (9.0 - 66.0) | 17.5 (8.0 - 46.0) | 16.0 (7.0 - 47.0) | 18.0 (8.0 - 38.0) | 18.0 (7.0 - 66.0) | 18.0 (8.0 - 46.0)
LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 20.5 (11.6) | 21.4 (10.9) | 18.0 (8.7) | 18.3 (9.2) | 19.5 (10.5) | 20.2 (10.2)
Median (Min-Max) | 18.0 (9.0 - 66.0) | 19.5 (8.0 - 46.0) | 16.0 (7.0 - 47.0) | 18.0 (8.0 - 38.0) | 18.0 (7.0 - 66.0) | 19.5 (8.0 - 46.0)
Change from Baseline to LOCF
N | 31 | 16 | 20 | 10 | 51 | 26
Mean (SD) | 1.7 (7.9) | −0.9 (4.4) | −0.5 (8.3) | 1.1 (5.6) | 0.9 (8.1) | −0.2 (4.9)
Median (Min-Max) | 1.0 (−9.0 - 38.0) | −1.0 (−10.0 - 8.0) | 1.0 (−21.0 - 13.0) | 0.5 (−7.0 - 12.0) | 1.0 (−21.0 - 38.0) | −1.0 (−10.0 - 12.0)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.2.1.14 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Glucose (mg/dL) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 83.3 (10.6) | 86.4 (9.2) | 84.8 (9.3) | 87.2 (11.7) | 83.9 (10.0) | 86.7 (10.1)
Median (Min-Max) | 83.5 (45.0 - 98.0) | 85.0 (74.0 - 106.0) | 88.0 (64.0 - 99.0) | 85.0 (73.0 - 117.0) | 85.0 (45.0 - 99.0) | 85.0 (73.0 - 117.0)
Week 2
N | 13 | 5 | 7 | 3 | 20 | 8
Mean (SD) | 83.8 (10.8) | 90.8 (11.9) | 78.7 (17.0) | 93.7 (9.6) | 82.0 (13.1) | 91.9 (10.4)
Median (Min-Max) | 82.0 (66.0 - 106.0) | 87.0 (80.0 - 111.0) | 79.0 (51.0 - 101.0) | 92.0 (85.0 - 104.0) | 82.0 (51.0 - 106.0) | 88.5 (80.0 - 111.0)
Week 4
N | 26 | 12 | 14 | 10 | 40 | 22
Mean (SD) | 87.3 (12.0) | 86.3 (6.5) | 91.1 (26.0) | 83.6 (13.4) | 88.7 (17.9) | 85.1 (10.0)
Median (Min-Max) | 89.0 (53.0 - 114.0) | 86.0 (78.0 - 99.0) | 88.5 (52.0 - 151.0) | 83.5 (67.0 - 104.0) | 89.0 (52.0 - 151.0) | 85.0 (67.0 - 104.0)
Week 8
N | 29 | 12 | 20 | 10 | 49 | 22
Mean (SD) | 83.1 (10.7) | 80.3 (5.9) | 86.7 (9.8) | 84.4 (18.1) | 84.6 (10.4) | 82.2 (12.7)
Median (Min-Max) | 85.0 (55.0 - 101.0) | 79.5 (73.0 - 93.0) | 89.0 (65.0 - 103.0) | 84.5 (45.0 - 118.0) | 86.0 (55.0 - 103.0) | 82.0 (45.0 - 118.0)
LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 83.4 (10.4) | 80.7 (5.5) | 86.0 (10.0) | 84.4 (18.1) | 84.4 (10.2) | 82.1 (11.8)
Median (Min-Max) | 85.0 (55.0 - 101.0) | 80.0 (73.0 - 93.0) | 87.0 (65.0 - 103.0) | 84.5 (45.0 - 118.0) | 85.5 (55.0 - 103.0) | 81.5 (45.0 - 118.0)
Change from Baseline to LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 0.4 (11.9) | −5.4 (10.5) | 1.2 (9.1) | −3.1 (16.3) | 0.7 (10.8) | −4.5 (12.8)
Median (Min-Max) | −2.0 (−15.0 - 36.0) | −2.0 (−32.0 - 7.0) | 4.0 (−16.0 - 16.0) | −2.5 (−43.0 - 15.0) | 1.0 (−16.0 - 36.0) | −2.5 (−43.0 - 15.0)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.2.1.15 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group High-Density Lipoprotein - HDL (mg/dL) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 53.9 (13.2) | 56.6 (11.0) | 52.6 (16.1) | 48.1 (16.1) | 53.4 (14.3) | 53.3 (13.6)
Median (Min-Max) | 52.0 (33.0 - 98.0) | 54.0 (40.0 - 76.0) | 54.0 (29.0 - 99.0) | 44.0 (22.0 - 77.0) | 52.0 (29.0 - 99.0) | 53.0 (22.0 - 77.0)
Week 2
N | 13 | 5 | 7 | 3 | 20 | 8
Mean (SD) | 53.2 (13.3) | 58.6 (7.5) | 63.9 (15.1) | 41.0 (3.0) | 57.0 (14.5) | 52.0 (10.9)
Median (Min-Max) | 50.0 (36.0 - 88.0) | 56.0 (50.0 - 67.0) | 65.0 (39.0 - 85.0) | 41.0 (38.0 - 44.0) | 54.5 (36.0 - 88.0) | 52.0 (38.0 - 67.0)
Week 4
N | 25 | 12 | 14 | 10 | 39 | 22
Mean (SD) | 53.5 (18.1) | 54.6 (13.2) | 58.4 (16.7) | 50.4 (18.2) | 55.2 (17.6) | 52.7 (15.4)
Median (Min-Max) | 49.0 (28.0 - 112.0) | 54.5 (35.0 - 75.0) | 57.0 (32.0 - 88.0) | 50.0 (22.0 - 84.0) | 52.0 (28.0 - 112.0) | 52.5 (22.0 - 84.0)
Week 8
N | 29 | 12 | 20 | 10 | 49 | 22
Mean (SD) | 50.6 (16.3) | 62.6 (15.4) | 51.7 (14.4) | 51.1 (18.0) | 51.0 (15.4) | 57.4 (17.3)
Median (Min-Max) | 48.0 (28.0 - 113.0) | 60.5 (41.0 - 85.0) | 51.5 (26.0 - 85.0) | 50.5 (23.0 - 78.0) | 50.0 (26.0 - 113.0) | 56.5 (23.0 - 85.0)
LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 51.6 (17.0) | 59.1 (15.0) | 52.6 (14.6) | 51.1 (18.0) | 52.0 (15.9) | 56.0 (16.4)
Median (Min-Max) | 49.0 (28.0 - 113.0) | 56.5 (37.0 - 85.0) | 52.0 (26.0 - 85.0) | 50.5 (23.0 - 78.0) | 50.0 (26.0 - 113.0) | 54.5 (23.0 - 85.0)
Change from Baseline to LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | −2.5 (9.4) | 1.6 (9.9) | 0.0 (8.0) | 1.8 (4.0) | −1.5 (8.9) | 1.7 (8.0)
Median (Min-Max) | −1.0 (−23.0 - 15.0) | 1.5 (−10.0 - 32.0) | 1.0 (−20.0 - 12.0) | 1.0 (−3.0 - 9.0) | −0.5 (−23.0 - 15.0) | 1.0 (−10.0 - 32.0)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.2.1.16 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Cholesterol/HDL Ratio Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 3.1 (0.8) | 2.9 (0.8) | 3.2 (0.9) | 3.7 (1.8) | 3.1 (0.8) | 3.2 (1.3)
Median (Min-Max) | 2.9 (1.9 - 5.3) | 2.9 (1.8 - 4.4) | 3.0 (1.8 - 4.7) | 3.2 (2.0 - 8.1) | 3.0 (1.8 - 5.3) | 3.0 (1.8 - 8.1)
Week 2
N | 13 | 5 | 7 | 3 | 20 | 8
Mean (SD) | 3.0 (0.8) | 2.5 (0.5) | 2.6 (0.6) | 3.5 (1.1) | 2.9 (0.7) | 2.9 (0.9)
Median (Min-Max) | 2.9 (1.9 - 4.3) | 2.6 (2.0 - 3.1) | 2.6 (1.9 - 3.4) | 3.0 (2.8 - 4.8) | 2.9 (1.9 - 4.3) | 2.9 (2.0 - 4.8)
Week 4
N | 25 | 12 | 14 | 10 | 39 | 22
Mean (SD) | 3.4 (1.1) | 3.2 (1.1) | 3.2 (0.9) | 3.7 (1.8) | 3.3 (1.0) | 3.4 (1.5)
Median (Min-Max) | 3.1 (1.5 - 6.5) | 2.6 (2.1 - 5.0) | 3.0 (2.0 - 5.0) | 3.0 (2.0 - 8.1) | 3.1 (1.5 - 6.5) | 2.9 (2.0 - 8.1)
Week 8
N | 29 | 12 | 20 | 10 | 49 | 22
Mean (SD) | 3.4 (1.1) | 2.9 (1.0) | 3.2 (0.8) | 3.6 (1.6) | 3.3 (1.0) | 3.2 (1.4)
Median (Min-Max) | 3.2 (1.9 - 6.5) | 2.6 (1.7 - 4.7) | 3.0 (2.0 - 4.8) | 3.0 (2.0 - 7.5) | 3.1 (1.9 - 6.5) | 2.9 (1.7 - 7.5)
LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 3.4 (1.1) | 3.0 (1.1) | 3.2 (0.8) | 3.6 (1.6) | 3.3 (1.0) | 3.3 (1.3)
Median (Min-Max) | 3.2 (1.5 - 6.5) | 2.8 (1.7 - 5.0) | 3.0 (2.0 - 4.8) | 3.0 (2.0 - 7.5) | 3.1 (1.5 - 6.5) | 2.9 (1.7 - 7.5)
Change from Baseline to LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 0.3 (0.7) | 0.1 (0.4) | −0.1 (0.6) | −0.1 (0.4) | 0.1 (0.7) | 0.0 (0.4)
Median (Min-Max) | 0.2 (−0.4 - 3.2) | 0.1 (−0.5 - 0.9) | 0.0 (−1.6 - 1.1) | 0.0 (−0.8 - 0.3) | 0.1 (−1.6 - 3.2) | 0.1 (−0.8 - 0.9)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.2.1.17 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Low-Density Lipoprotein - LDL (mg/dL) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 89.5 (23.3) | 88.2 (26.9) | 91.4 (22.1) | 93.7 (29.9) | 90.3 (22.6) | 90.4 (27.7)
Median (Min-Max) | 86.5 (32.0 - 150.0) | 89.0 (41.0 - 138.0) | 90.0 (52.0 - 133.0) | 86.0 (62.0 - 157.0) | 88.0 (32.0 - 150.0) | 87.0 (41.0 - 157.0)
Week 2
N | 13 | 5 | 7 | 3 | 20 | 8
Mean (SD) | 77.4 (28.1) | 67.4 (27.3) | 70.3 (16.7) | 79.3 (55.2) | 74.9 (24.5) | 71.9 (36.6)
Median (Min-Max) | 75.0 (25.0 - 125.0) | 75.0 (36.0 - 101.0) | 66.0 (50.0 - 98.0) | 51.0 (44.0 - 143.0) | 71.5 (25.0 - 125.0) | 63.0 (36.0 - 143.0)
Week 4
N | 25 | 12 | 14 | 10 | 39 | 22
Mean (SD) | 87.8 (32.7) | 80.6 (30.8) | 98.6 (24.7) | 93.7 (32.2) | 91.7 (30.2) | 86.5 (31.4)
Median (Min-Max) | 84.0 (26.0 - 182.0) | 84.0 (6.0 - 121.0) | 101.0 (54.0 - 150.0) | 80.0 (52.0 - 146.0) | 90.0 (26.0 - 182.0) | 82.0 (6.0 - 146.0)
Week 8
N | 29 | 12 | 20 | 10 | 49 | 22
Mean (SD) | 92.7 (28.5) | 89.8 (28.4) | 87.6 (26.8) | 99.8 (26.5) | 90.6 (27.6) | 94.3 (27.4)
Median (Min-Max) | 92.0 (43.0 - 181.0) | 95.0 (45.0 - 133.0) | 80.0 (53.0 - 158.0) | 97.5 (65.0 - 138.0) | 85.0 (43.0 - 181.0) | 95.0 (45.0 - 138.0)
LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 91.2 (30.3) | 89.4 (26.3) | 87.4 (26.2) | 99.8 (26.5) | 89.6 (28.5) | 93.4 (26.3)
Median (Min-Max) | 92.0 (26.0 - 181.0) | 88.0 (45.0 - 133.0) | 81.0 (53.0 - 158.0) | 97.5 (65.0 - 138.0) | 84.5 (26.0 - 181.0) | 90.0 (45.0 - 138.0)
Change from Baseline to LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 1.1 (15.6) | 0.3 (16.2) | −4.0 (23.1) | 4.5 (15.9) | −1.0 (19.0) | 1.9 (15.9)
Median (Min-Max) | 2.0 (−29.0 - 46.0) | 2.5 (−42.0 - 23.0) | −2.0 (−49.0 - 34.0) | 5.5 (−26.0 - 24.0) | −1.0 (−49.0 - 46.0) | 3.0 (−42.0 - 24.0)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.2.1.18 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Magnesium (mg/dL) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 20 | 11 | 52 | 28
Mean (SD) | 2.1 (0.2) | 2.1 (0.1) | 2.1 (0.2) | 2.0 (0.1) | 2.1 (0.2) | 2.1 (0.1)
Median (Min-Max) | 2.1 (1.6 - 2.4) | 2.1 (1.9 - 2.2) | 2.1 (1.8 - 2.4) | 2.0 (1.9 - 2.3) | 2.1 (1.6 - 2.4) | 2.1 (1.9 - 2.3)
Week 2
N | 13 | 5 | 7 | 3 | 20 | 8
Mean (SD) | 2.3 (0.3) | 2.1 (0.2) | 2.3 (0.1) | 2.1 (0.2) | 2.3 (0.2) | 2.1 (0.2)
Median (Min-Max) | 2.2 (1.8 - 2.9) | 2.0 (1.9 - 2.3) | 2.3 (2.1 - 2.4) | 2.1 (1.9 - 2.4) | 2.2 (1.8 - 2.9) | 2.1 (1.9 - 2.4)
Week 4
N | 25 | 12 | 14 | 10 | 39 | 22
Mean (SD) | 2.4 (0.3) | 2.1 (0.1) | 2.3 (0.3) | 2.0 (0.1) | 2.4 (0.3) | 2.0 (0.1)
Median (Min-Max) | 2.4 (2.0 - 3.2) | 2.0 (1.9 - 2.4) | 2.3 (1.8 - 2.7) | 2.0 (1.9 - 2.4) | 2.4 (1.8 - 3.2) | 2.0 (1.9 - 2.4)
Week 8
N | 29 | 12 | 20 | 10 | 49 | 22
Mean (SD) | 2.3 (0.3) | 2.1 (0.1) | 2.2 (0.2) | 2.0 (0.2) | 2.3 (0.2) | 2.0 (0.2)
Median (Min-Max) | 2.3 (1.8 - 2.9) | 2.1 (1.9 - 2.2) | 2.3 (1.9 - 2.6) | 2.0 (1.6 - 2.3) | 2.3 (1.8 - 2.9) | 2.0 (1.6 - 2.3)
LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 2.3 (0.3) | 2.0 (0.1) | 2.2 (0.2) | 2.0 (0.2) | 2.3 (0.2) | 2.0 (0.2)
Median (Min-Max) | 2.3 (1.8 - 2.9) | 2.0 (1.9 - 2.2) | 2.2 (1.9 - 2.6) | 2.0 (1.6 - 2.3) | 2.3 (1.8 - 2.9) | 2.0 (1.6 - 2.3)
Change from Baseline to LOCF
N | 31 | 16 | 20 | 10 | 51 | 26
Mean (SD) | 0.3 (0.2) | 0.0 (0.1) | 0.2 (0.2) | 0.0 (0.1) | 0.2 (0.2) | 0.0 (0.1)
Median (Min-Max) | 0.2 (−0.3 - 0.9) | 0.0 (−0.2 - 0.2) | 0.2 (−0.3 - 0.7) | 0.0 (−0.3 - 0.1) | 0.2 (−0.3 - 0.9) | 0.0 (−0.3 - 0.2)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.2.1.19 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Phosphorus (mg/dL) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 31 | 17 | 21 | 11 | 52 | 28
Mean (SD) | 4.6 (0.6) | 4.7 (0.4) | 4.5 (0.7) | 4.1 (0.5) | 4.6 (0.6) | 4.4 (0.5)
Median (Min-Max) | 4.6 (3.3 - 5.6) | 4.6 (4.1 - 5.3) | 4.5 (3.5 - 6.2) | 4.1 (3.0 - 4.8) | 4.6 (3.3 - 6.2) | 4.4 (3.0 - 5.3)
Week 2
N | 13 | 5 | 7 | 3 | 20 | 8
Mean (SD) | 4.9 (0.4) | 4.9 (0.4) | 5.0 (0.7) | 4.0 (0.2) | 4.9 (0.5) | 4.6 (0.6)
Median (Min-Max) | 4.9 (4.3 - 5.7) | 4.8 (4.4 - 5.4) | 4.8 (4.1 - 5.9) | 4.1 (3.8 - 4.2) | 4.9 (4.1 - 5.9) | 4.5 (3.8 - 5.4)
Week 4
N | 25 | 12 | 14 | 10 | 39 | 22
Mean (SD) | 4.5 (0.7) | 4.8 (0.4) | 4.6 (0.8) | 4.1 (0.5) | 4.5 (0.7) | 4.5 (0.6)
Median (Min-Max) | 4.6 (3.3 - 6.5) | 4.7 (4.0 - 5.6) | 4.3 (3.5 - 5.9) | 3.9 (3.6 - 5.0) | 4.5 (3.3 - 6.5) | 4.7 (3.6 - 5.6)
Week 8
N | 29 | 12 | 20 | 10 | 49 | 22
Mean (SD) | 4.7 (0.5) | 4.6 (0.3) | 4.5 (0.8) | 4.2 (0.5) | 4.6 (0.6) | 4.4 (0.4)
Median (Min-Max) | 4.8 (3.9 - 5.9) | 4.6 (4.1 - 5.3) | 4.4 (3.3 - 6.7) | 4.0 (3.8 - 5.2) | 4.6 (3.3 - 6.7) | 4.4 (3.8 - 5.3)
LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 4.8 (0.6) | 4.6 (0.3) | 4.4 (0.7) | 4.2 (0.5) | 4.6 (0.7) | 4.5 (0.4)
Median (Min-Max) | 4.8 (3.9 - 6.5) | 4.6 (4.1 - 5.3) | 4.3 (3.3 - 6.7) | 4.0 (3.8 - 5.2) | 4.6 (3.3 - 6.7) | 4.5 (3.8 - 5.3)
Change from Baseline to LOCF
N | 30 | 16 | 21 | 10 | 51 | 26
Mean (SD) | 0.2 (0.7) | −0.1 (0.5) | −0.1 (0.7) | 0.1 (0.5) | 0.1 (0.7) | 0.0 (0.5)
Median (Min-Max) | 0.2 (−1.5 - 2.1) | −0.1 (−1.1 - 0.9) | −0.1 (−1.1 - 1.2) | 0.2 (−0.9 - 1.0) | 0.1 (−1.5 - 2.1) | −0.1 (−1.1 - 1.0)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.2.1.20 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Potassium (mEq/L) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 4.2 (0.3) | 4.3 (0.3) | 4.2 (0.3) | 4.3 (0.2) | 4.2 (0.3) | 4.3 (0.3)
Median (Min-Max) | 4.3 (3.5 - 4.8) | 4.4 (3.7 - 4.7) | 4.2 (3.5 - 4.7) | 4.3 (3.8 - 4.7) | 4.2 (3.5 - 4.8) | 4.3 (3.7 - 4.7)
Week 2
N | 13 | 5 | 7 | 3 | 20 | 8
Mean (SD) | 4.2 (0.3) | 4.3 (0.3) | 4.1 (0.3) | 4.1 (0.2) | 4.2 (0.3) | 4.2 (0.3)
Median (Min-Max) | 4.3 (3.9 - 4.7) | 4.1 (4.0 - 4.7) | 4.1 (3.7 - 4.4) | 4.1 (3.9 - 4.2) | 4.2 (3.7 - 4.7) | 4.1 (3.9 - 4.7)
Week 4
N | 26 | 12 | 14 | 10 | 40 | 22
Mean (SD) | 4.2 (0.3) | 4.0 (0.2) | 4.2 (0.4) | 4.2 (0.2) | 4.2 (0.3) | 4.1 (0.3)
Median (Min-Max) | 4.2 (3.6 - 4.9) | 4.0 (3.6 - 4.5) | 4.3 (3.6 - 4.8) | 4.2 (3.8 - 4.5) | 4.3 (3.6 - 4.9) | 4.1 (3.6 - 4.5)
Week 8
N | 29 | 12 | 20 | 10 | 49 | 22
Mean (SD) | 4.3 (0.3) | 4.1 (0.3) | 4.2 (0.3) | 4.4 (0.4) | 4.2 (0.3) | 4.2 (0.4)
Median (Min-Max) | 4.2 (3.5 - 5.1) | 4.1 (3.7 - 4.6) | 4.2 (3.8 - 4.9) | 4.3 (3.9 - 5.3) | 4.2 (3.5 - 5.1) | 4.1 (3.7 - 5.3)
LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 4.3 (0.3) | 4.0 (0.2) | 4.2 (0.3) | 4.4 (0.4) | 4.2 (0.3) | 4.2 (0.4)
Median (Min-Max) | 4.3 (3.5 - 5.1) | 4.1 (3.7 - 4.6) | 4.1 (3.7 - 4.9) | 4.3 (3.9 - 5.3) | 4.3 (3.5 - 5.1) | 4.1 (3.7 - 5.3)
Change from Baseline to LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 0.0 (0.4) | −0.3 (0.2) | 0.0 (0.2) | 0.1 (0.4) | 0.0 (0.3) | −0.2 (0.4)
Median (Min-Max) | 0.0 (−0.6 - 1.0) | −0.4 (−0.9 - 0.0) | −0.1 (−0.3 - 0.5) | 0.1 (−0.5 - 1.0) | −0.1 (−0.6 - 1.0) | −0.2 (−0.9 - 1.0)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.2.1.21 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Total Protein (g/dL) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 7.3 (0.5) | 7.3 (0.6) | 7.1 (0.5) | 7.3 (0.2) | 7.3 (0.5) | 7.3 (0.4)
Median (Min-Max) | 7.4 (6.2 - 8.5) | 7.3 (6.2 - 8.5) | 7.2 (6.1 - 8.2) | 7.3 (6.9 - 7.6) | 7.3 (6.1 - 8.5) | 7.3 (6.2 - 8.5)
Week 2
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 7.3 (0.5) | 7.3 (0.6) | 7.1 (0.5) | 7.3 (0.2) | 7.3 (0.5) | 7.3 (0.4)
Median (Min-Max) | 7.4 (6.2 - 8.5) | 7.3 (6.2 - 8.5) | 7.2 (6.1 - 8.2) | 7.3 (6.9 - 7.6) | 7.3 (6.1 - 8.5) | 7.3 (6.2 - 8.5)
Week 4
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 7.3 (0.5) | 7.3 (0.6) | 7.1 (0.5) | 7.3 (0.2) | 7.3 (0.5) | 7.3 (0.4)
Median (Min-Max) | 7.4 (6.2 - 8.5) | 7.3 (6.2 - 8.5) | 7.2 (6.1 - 8.2) | 7.3 (6.9 - 7.6) | 7.3 (6.1 - 8.5) | 7.3 (6.2 - 8.5)
Week 8
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 7.3 (0.5) | 7.3 (0.6) | 7.1 (0.5) | 7.3 (0.2) | 7.3 (0.5) | 7.3 (0.4)
Median (Min-Max) | 7.4 (6.2 - 8.5) | 7.3 (6.2 - 8.5) | 7.2 (6.1 - 8.2) | 7.3 (6.9 - 7.6) | 7.3 (6.1 - 8.5) | 7.3 (6.2 - 8.5)
LOCF
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 7.3 (0.5) | 7.3 (0.6) | 7.1 (0.5) | 7.3 (0.2) | 7.3 (0.5) | 7.3 (0.4)
Median (Min-Max) | 7.4 (6.2 - 8.5) | 7.3 (6.2 - 8.5) | 7.2 (6.1 - 8.2) | 7.3 (6.9 - 7.6) | 7.3 (6.1 - 8.5) | 7.3 (6.2 - 8.5)
Change from Baseline to LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | −0.1 (0.4) | −0.1 (0.6) | 0.0 (0.3) | −0.2 (0.3) | −0.1 (0.4) | −0.1 (0.5)
Median (Min-Max) | −0.2 (−0.6 - 0.7) | −0.2 (−1.2 - 1.4) | 0.1 (−0.7 - 0.8) | −0.2 (−0.7 - 0.4) | −0.1 (−0.7 - 0.8) | −0.2 (−1.2 - 1.4)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.2.1.22 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Sodium (mEq/L) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 138.3 (2.5) | 138.3 (2.1) | 139.4 (2.0) | 138.7 (2.6) | 138.7 (2.3) | 138.5 (2.3)
Median (Min-Max) | 138.5 (134.0 - 143.0) | 138.0 (134.0 - 142.0) | 139.0 (135.0 - 142.0) | 138.0 (135.0 - 144.0) | 139.0 (134.0 - 143.0) | 138.0 (134.0 - 144.0)
Week 2
N | 13 | 5 | 7 | 3 | 20 | 8
Mean (SD) | 138.0 (3.2) | 139.4 (1.7) | 139.7 (3.0) | 139.0 (1.7) | 138.6 (3.2) | 139.3 (1.6)
Median (Min-Max) | 138.0 (134.0 - 145.0) | 139.0 (137.0 - 141.0) | 140.0 (136.0 - 145.0) | 138.0 (138.0 - 141.0) | 138.0 (134.0 - 145.0) | 139.0 (137.0 - 141.0)
Week 4
N | 26 | 12 | 14 | 10 | 40 | 22
Mean (SD) | 137.9 (2.0) | 137.7 (2.0) | 138.9 (2.6) | 139.4 (2.5) | 138.3 (2.2) | 138.5 (2.3)
Median (Min-Max) | 138.0 (134.0 - 142.0) | 138.0 (133.0 - 141.0) | 138.5 (136.0 - 144.0) | 139.0 (137.0 - 145.0) | 138.0 (134.0 - 144.0) | 138.0 (133.0 - 145.0)
Week 8
N | 29 | 12 | 20 | 10 | 49 | 22
Mean (SD) | 137.9 (2.5) | 138.4 (2.4) | 138.6 (2.4) | 139.5 (2.5) | 138.2 (2.5) | 138.9 (2.5)
Median (Min-Max) | 138.0 (132.0 - 141.0) | 138.0 (134.0 - 142.0) | 138.0 (134.0 - 143.0) | 139.0 (134.0 - 143.0) | 138.0 (132.0 - 143.0) | 139.0 (134.0 - 143.0)
LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 138.0 (2.5) | 138.4 (2.3) | 138.5 (2.4) | 139.5 (2.5) | 138.2 (2.4) | 138.8 (2.4)
Median (Min-Max) | 138.0 (132.0 - 141.0) | 138.0 (134.0 - 142.0) | 138.0 (134.0 - 143.0) | 139.0 (134.0 - 143.0) | 138.0 (132.0 - 143.0) | 139.0 (134.0 - 143.0)
Change from Baseline to LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | −0.1 (2.7) | 0.1 (2.8) | −0.9 (2.2) | 0.6 (2.2) | −0.4 (2.5) | 0.3 (2.6)
Median (Min-Max) | 0.0 (−6.0 - 5.0) | 0.0 (−5.0 - 5.0) | −1.0 (−5.0 - 4.0) | 0.0 (−2.0 - 5.0) | 0.0 (−6.0 - 5.0) | 0.0 (−5.0 - 5.0)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.2.1.23 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Triglycerides (mg/dL) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 80.8 (56.0) | 73.1 (38.3) | 89.7 (36.0) | 84.1 (64.5) | 84.3 (48.8) | 77.4 (49.4)
Median (Min-Max) | 56.0 (24.0 - 228.0) | 54.0 (27.0 - 161.0) | 85.0 (38.0 - 154.0) | 64.0 (40.0 - 270.0) | 71.0 (24.0 - 228.0) | 62.0 (27.0 - 270.0)
Week 2
N | 13 | 5 | 7 | 3 | 20 | 8
Mean (SD) | 132.4 (80.7) | 104.8 (39.0) | 103.6 (40.1) | 116.0 (51.6) | 122.3 (69.4) | 109.0 (40.8)
Median (Min-Max) | 117.0 (25.0 - 328.0) | 122.0 (61.0 - 144.0) | 88.0 (60.0 - 167.0) | 138.0 (57.0 - 153.0) | 109.5 (25.0 - 328.0) | 127.0 (57.0 - 153.0)
Week 4
N | 25 | 12 | 14 | 10 | 39 | 22
Mean (SD) | 139.1 (90.6) | 146.0 (119.9) | 108.3 (52.5) | 120.0 (64.9) | 128.0 (79.7) | 134.2 (97.5)
Median (Min-Max) | 107.0 (42.0 - 357.0) | 108.5 (28.0 - 381.0) | 89.0 (62.0 - 240.0) | 112.0 (48.0 - 288.0) | 92.0 (42.0 - 357.0) | 112.0 (28.0 - 381.0)
Week 8
N | 29 | 12 | 20 | 10 | 49 | 22
Mean (SD) | 105.9 (70.6) | 71.0 (42.1) | 101.8 (46.9) | 70.1 (34.5) | 104.2 (61.5) | 70.6 (37.9)
Median (Min-Max) | 70.0 (14.0 - 269.0) | 57.0 (25.0 - 155.0) | 91.0 (47.0 - 208.0) | 55.0 (34.0 - 139.0) | 83.0 (14.0 - 269.0) | 56.0 (25.0 - 155.0)
LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 103.8 (68.7) | 89.6 (78.1) | 104.0 (46.9) | 70.1 (34.5) | 103.9 (60.3) | 82.1 (64.7)
Median (Min-Max) | 72.0 (14.0 - 269.0) | 59.0 (25.0 - 344.0) | 99.0 (47.0 - 208.0) | 55.0 (34.0 - 139.0) | 79.5 (14.0 - 269.0) | 57.0 (25.0 - 344.0)
Change from Baseline to LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 26.5 (49.9) | 17.7 (61.8) | 14.3 (36.4) | −15.7 (55.9) | 21.6 (45.0) | 4.8 (60.8)
Median (Min-Max) | 16.0 (−61.0 - 188.0) | 15.0 (−56.0 - 226.0) | 8.0 (−24.0 - 106.0) | −6.0 (−160 - 49.0) | 14.5 (−61.0 - 188.0) | 4.5 (−160 - 226.0)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.2.1.24 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Urea Nitrogen (mg/dL) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 11.8 (3.0) | 11.2 (2.8) | 10.4 (3.0) | 11.3 (2.6) | 11.2 (3.0) | 11.2 (2.7)
Median (Min-Max) | 11.5 (6.0 - 21.0) | 11.0 (7.0 - 16.0) | 9.0 (5.0 - 17.0) | 11.0 (6.0 - 14.0) | 11.0 (5.0 - 21.0) | 11.0 (6.0 - 16.0)
Week 2
N | 13 | 5 | 7 | 3 | 20 | 8
Mean (SD) | 11.3 (3.1) | 10.6 (3.3) | 7.6 (1.4) | 14.3 (2.1) | 10.0 (3.2) | 12.0 (3.3)
Median (Min-Max) | 11.0 (8.0 - 17.0) | 10.0 (7.0 - 14.0) | 8.0 (6.0 - 10.0) | 15.0 (12.0 - 16.0) | 9.0 (6.0 - 17.0) | 13.0 (7.0 - 16.0)
Week 4
N | 26 | 12 | 14 | 10 | 40 | 22
Mean (SD) | 12.1 (2.9) | 13.7 (3.4) | 16.2 (24.9) | 12.4 (3.2) | 13.6 (14.7) | 13.1 (3.3)
Median (Min-Max) | 11.5 (8.0 - 20.0) | 13.5 (8.0 - 19.0) | 8.5 (6.0 - 102.0) | 13.0 (8.0 - 18.0) | 10.5 (6.0 - 102.0) | 13.0 (8.0 - 19.0)
Week 8
N | 29 | 12 | 20 | 10 | 49 | 22
Mean (SD) | 10.0 (2.8) | 11.7 (3.1) | 9.1 (3.2) | 11.8 (2.5) | 9.6 (2.9) | 11.7 (2.8)
Median (Min-Max) | 10.0 (6.0 - 16.0) | 12.5 (6.0 - 15.0) | 9.0 (5.0 - 18.0) | 11.0 (9.0 - 18.0) | 10.0 (5.0 - 18.0) | 12.0 (6.0 - 18.0)
LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 10.4 (3.0) | 11.7 (2.9) | 9.0 (3.1) | 11.8 (2.5) | 9.8 (3.1) | 11.7 (2.7)
Median (Min-Max) | 11.0 (6.0 - 16.0) | 12.5 (6.0 - 15.0) | 9.0 (5.0 - 18.0) | 11.0 (9.0 - 18.0) | 10.0 (5.0 - 18.0) | 12.0 (6.0 - 18.0)
Change from Baseline to LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | −1.5 (3.3) | 0.4 (3.1) | −1.4 (3.3) | 0.5 (4.2) | −1.4 (3.3) | 0.4 (3.5)
Median (Min-Max) | −1.0 (−9.0 - 7.0) | 0.0 (−4.0 - 5.0) | −1.0 (−7.0 - 4.0) | −1.0 (−4.0 - 7.0) | −1.0 (−9.0 - 7.0) | 0.0 (−4.0 - 7.0)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.2.1.25 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Uric Acid (mg/dL) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 20 | 11 | 52 | 28
Mean (SD) | 4.1 (1.0) | 4.1 (1.4) | 4.4 (1.2) | 4.4 (1.3) | 4.2 (1.1) | 4.2 (1.4)
Median (Min-Max) | 3.8 (2.1 - 6.5) | 3.8 (2.2 - 8.5) | 4.0 (2.5 - 6.9) | 4.2 (2.4 - 6.8) | 3.8 (2.1 - 6.9) | 4.1 (2.2 - 8.5)
Week 2
N | 13 | 5 | 7 | 3 | 20 | 8
Mean (SD) | 5.0 (1.2) | 3.5 (0.7) | 4.8 (1.3) | 4.1 (1.1) | 4.9 (1.2) | 3.7 (0.9)
Median (Min-Max) | 4.6 (3.5 - 6.6) | 3.3 (2.5 - 4.2) | 4.6 (2.9 - 6.8) | 3.9 (3.1 - 5.2) | 4.6 (2.9 - 6.8) | 3.6 (2.5 - 5.2)
Week 4
N | 25 | 12 | 14 | 10 | 39 | 22
Mean (SD) | 4.7 (1.2) | 4.2 (1.2) | 5.4 (1.1) | 4.1 (1.2) | 5.0 (1.2) | 4.2 (1.1)
Median (Min-Max) | 4.5 (3.0 - 8.0) | 4.0 (2.5 - 7.1) | 5.3 (3.5 - 7.5) | 4.0 (2.6 - 6.6) | 4.7 (3.0 - 8.0) | 4.0 (2.5 - 7.1)
Week 8
N | 29 | 12 | 20 | 10 | 49 | 22
Mean (SD) | 4.9 (1.4) | 3.6 (0.9) | 5.4 (1.4) | 4.3 (1.2) | 5.1 (1.4) | 3.9 (1.1)
Median (Min-Max) | 4.8 (2.3 - 7.7) | 3.7 (2.1 - 4.9) | 5.1 (3.7 - 9.3) | 4.2 (2.5 - 6.6) | 4.8 (2.3 - 9.3) | 3.8 (2.1 - 6.6)
LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 4.9 (1.4) | 3.9 (1.2) | 5.4 (1.3) | 4.3 (1.2) | 5.1 (1.4) | 4.1 (1.2)
Median (Min-Max) | 4.8 (2.3 - 7.7) | 4.0 (2.1 - 7.1) | 5.1 (3.7 - 9.3) | 4.2 (2.5 - 6.6) | 4.8 (2.3 - 9.3) | 4.0 (2.1 - 7.1)
Change from Baseline to LOCF
N | 31 | 16 | 20 | 10 | 51 | 26
Mean (SD) | 0.8 (0.8) | −0.1 (0.6) | 1.0 (1.1) | −0.1 (0.5) | 0.9 (0.9) | −0.1 (0.6)
Median (Min-Max) | 0.8 (−0.8 - 2.3) | 0.1 (−1.4 - 0.6) | 1.1 (−1.9 - 3.0) | 0.1 (−1.1 - 0.6) | 0.9 (−1.9 - 3.0) | 0.1 (−1.4 - 0.6)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.2.1.26 Summary of Clinical Laboratory Chemistry Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Creatinine Clearance (mL/min/1.7m^2^) Efficacy Phase - Safety Population

| 7 - 11 yrs | | 12 - 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 153.9 (25.8) | 142.6 (32.1) | 101.8 (26.9) | 111.4 (33.0) | 133.2 (36.6) | 130.3 (35.4)
Median (Min-Max) | 154.0 (103.0 - 216.7) | 136.5 (99.3 - 204.1) | 98.7 (58.2 - 153.9) | 109.1 (63.6 - 171.3) | 136.2 (58.2 - 216.7) | 123.9 (63.6 - 204.1)
Week 2
N | 13 | 5 | 7 | 3 | 20 | 8
Mean (SD) | 142.7 (27.7) | 129.3 (12.8) | 91.2 (23.7) | 86.3 (41.9) | 124.7 (36.0) | 113.2 (33.1)
Median (Min-Max) | 142.7 (102.9 - 190.9) | 130.7 (109.5 - 144.2) | 91.6 (53.6 - 119.5) | 63.8 (60.4 - 134.7) | 119.4 (53.6 - 190.9) | 128.9 (60.4 - 144.2)
Week 4
N | 26 | 12 | 14 | 10 | 40 | 22
Mean (SD) | 136.2 (19.4) | 140.9 (28.9) | 87.7 (21.3) | 109.6 (30.4) | 119.2 (30.6) | 126.7 (33.0)
Median (Min-Max) | 137.5 (99.5 - 178.3) | 140.0 (98.1 - 199.2) | 80.6 (57.1 - 125.4) | 106.6 (64.1 - 157.8) | 119.9 (57.1 - 178.3) | 127.2 (64.1 - 199.2)
Week 8
N | 29 | 12 | 20 | 10 | 49 | 22
Mean (SD) | 142.0 (25.5) | 152.9 (29.4) | 101.3 (33.4) | 107.5 (33.5) | 125.4 (35.1) | 132.3 (38.3)
Median (Min-Max) | 139.0 (98.8 - 213.6) | 148.2 (115.0 - 194.3) | 93.8 (67.6 - 213.0) | 120.0 (47.8 - 143.6) | 127.7 (67.6 - 213.6) | 134.1 (47.8 - 194.3)
LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | 140.7 (25.7) | 151.2 (31.7) | 99.0 (34.2) | 107.5 (33.5) | 123.9 (35.7) | 134.4 (38.4)
Median (Min-Max) | 139.0 (98.8 - 213.6) | 148.2 (109.5 - 199.2) | 85.1 (53.6 - 213.0) | 120.0 (47.8 - 143.6) | 126.2 (53.6 - 213.6) | 134.1 (47.8 - 199.2)
Change from Baseline to LOCF
N | 31 | 16 | 21 | 10 | 52 | 26
Mean (SD) | −14.3 (25.0) | 6.7 (31.0) | −2.8 (24.7) | −4.8 (16.5) | −9.6 (25.3) | 2.3 (26.6)
Median (Min-Max) | −17.3 (−61.8 - 42.3) | 2.2 (−43.8 - 76.2) | −7.5 (−35.8 - 76.8) | −8.0 (−27.6 - 25.9) | −12.5 (−61.8 - 76.8) | 1.4 (−43.8 - 76.2)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.2.2.1A Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata Albumin (g/dL) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 4.4 (0.4) | 4.3 (0.4) | 4.3 (0.4)
Median (Min-Max) | 4.3 (3.7 - 5.1) | 4.4 (3.4 - 4.7) | 4.4 (3.4 - 5.1)
Week 4
N | 24 | 14 | 38
Mean (SD) | 4.3 (0.4) | 4.4 (0.4) | 4.3 (0.4)
Median (Min-Max) | 4.3 (3.6 - 5.1) | 4.5 (3.4 - 4.9) | 4.4 (3.4 - 5.1)
Week 8
N | 24 | 13 | 37
Mean (SD) | 4.4 (0.4) | 4.3 (0.4) | 4.4 (0.4)
Median (Min-Max) | 4.4 (3.7 - 5.0) | 4.4 (3.7 - 5.1) | 4.4 (3.7 - 5.1)
Week 16
N | 21 | 7 | 28
Mean (SD) | 4.4 (0.3) | 4.3 (0.4) | 4.4 (0.3)
Median (Min-Max) | 4.3 (3.8 - 4.9) | 4.5 (3.6 - 4.5) | 4.5 (3.6 - 4.9)
Week 24
N | 17 | 6 | 23
Mean (SD) | 4.4 (0.5) | 4.3 (0.2) | 4.4 (0.4)
Median (Min-Max) | 4.4 (3.7 - 5.4) | 4.4 (4.0 - 4.6) | 4.4 (3.7 - 5.4)
LOCF
N | 27 | 14 | 41
Mean (SD) | 4.4 (0.5) | 4.3 (0.4) | 4.3 (0.4)
Median (Min-Max) | 4.4 (3.3 - 5.4) | 4.4 (3.4 - 5.1) | 4.4 (3.3 - 5.4)
Change from Baseline to LOCF
N | 27 | 14 | 41
Mean (SD) | 0.0 (0.3) | 0.0 (0.3) | 0.0 (0.3)
Median (Min-Max) | 0.0 (−0.5 - 0.6) | 0.0 (−0.5 - 0.5) | 0.0 (−0.5 - 0.6)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.2A Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata Alkaline Phosphatase (U/L) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 323.8 (107.8) | 186.7 (84.7) | 277.1 (119.2)
Median (Min-Max) | 313.0 (152.0 - 658.0) | 195.0 (84.0 - 358.0) | 266.0 (84.0 - 658.0)
Week 4
N | 24 | 14 | 38
Mean (SD) | 326.1 (100.5) | 199.0 (106.9) | 279.3 (119.0)
Median (Min-Max) | 320.0 (151.0 - 535.0) | 203.5 (76.0 - 378.0) | 295.0 (76.0 - 535.0)
Week 8
N | 24 | 13 | 37
Mean (SD) | 314.0 (104.5) | 190.6 (105.9) | 270.6 (119.5)
Median (Min-Max) | 288.5 (132.0 - 545.0) | 149.0 (75.0 - 346.0) | 273.0 (75.0 - 545.0)
Week 16
N | 21 | 7 | 28
Mean (SD) | 306.3 (105.5) | 213.3 (104.9) | 283.0 (111.2)
Median (Min-Max) | 287.0 (136.0 - 587.0) | 251.0 (78.0 - 350.0) | 280.0 (78.0 - 587.0)
Week 24
N | 17 | 6 | 23
Mean (SD) | 296.2 (96.1) | 217.2 (107.6) | 275.6 (103.0)
Median (Min-Max) | 277.0 (131.0 - 477.0) | 249.0 (72.0 - 345.0) | 275.0 (72.0 - 477.0)
LOCF
N | 27 | 14 | 41
Mean (SD) | 285.1 (92.9) | 195.3 (102.2) | 254.4 (104.2)
Median (Min-Max) | 275.0 (131.0 - 477.0) | 187.0 (72.0 - 345.0) | 264.0 (72.0 - 477.0)
Change from Baseline to LOCF
N | 27 | 14 | 41
Mean (SD) | −42.4 (89.6) | 9.1 (31.4) | −24.8 (78.4)
Median (Min-Max) | −20.0 (−328 - 76.0) | 3.5 (−39.0 - 70.0) | −12.0 (−328 - 76.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.3A Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata Alanine Aminotransferase - ALT (U/L) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 27.4 (12.6) | 22.7 (14.0) | 25.8 (13.1)
Median (Min-Max) | 26.0 (7.0 - 65.0) | 18.0 (8.0 - 57.0) | 25.0 (7.0 - 65.0)
Week 4
N | 24 | 14 | 38
Mean (SD) | 27.2 (13.7) | 21.0 (9.7) | 24.9 (12.6)
Median (Min-Max) | 20.0 (9.0 - 59.0) | 19.5 (9.0 - 44.0) | 20.0 (9.0 - 59.0)
Week 8
N | 24 | 13 | 37
Mean (SD) | 23.9 (10.5) | 22.0 (8.9) | 23.2 (9.9)
Median (Min-Max) | 23.0 (6.0 - 49.0) | 20.0 (9.0 - 41.0) | 22.0 (6.0 - 49.0)
Week 16
N | 21 | 7 | 28
Mean (SD) | 27.1 (16.1) | 16.0 (5.5) | 24.3 (14.9)
Median (Min-Max) | 23.0 (11.0 - 65.0) | 14.0 (10.0 - 25.0) | 20.5 (10.0 - 65.0)
Week 24
N | 17 | 6 | 23
Mean (SD) | 24.0 (12.1) | 15.8 (7.8) | 21.9 (11.6)
Median (Min-Max) | 20.0 (13.0 - 61.0) | 14.5 (7.0 - 30.0) | 18.0 (7.0 - 61.0)
LOCF
N | 27 | 14 | 41
Mean (SD) | 25.0 (12.4) | 17.9 (8.0) | 22.6 (11.5)
Median (Min-Max) | 20.0 (13.0 - 61.0) | 16.5 (7.0 - 35.0) | 20.0 (7.0 - 61.0)
Change from Baseline to LOCF
N | 27 | 14 | 41
Mean (SD) | −2.4 (9.2) | −4.6 (7.7) | −3.1 (8.7)
Median (Min-Max) | −2.0 (−18.0 - 29.0) | −2.5 (−22.0 - 3.0) | −2.0 (−22.0 - 29.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.4A Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata Aspartate Aminotransferase - AST (U/L) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 25.6 (6.9) | 22.3 (7.1) | 24.5 (7.0)
Median (Min-Max) | 26.0 (14.0 - 44.0) | 20.0 (9.0 - 35.0) | 25.0 (9.0 - 44.0)
Week 4
N | 24 | 14 | 38
Mean (SD) | 26.4 (8.0) | 22.1 (8.9) | 24.8 (8.5)
Median (Min-Max) | 25.0 (16.0 - 45.0) | 21.5 (10.0 - 41.0) | 23.5 (10.0 - 45.0)
Week 8
N | 24 | 13 | 37
Mean (SD) | 25.1 (8.9) | 22.3 (7.8) | 24.1 (8.5)
Median (Min-Max) | 23.0 (13.0 - 51.0) | 22.0 (10.0 - 33.0) | 22.0 (10.0 - 51.0)
Week 16
N | 21 | 7 | 28
Mean (SD) | 27.1 (11.6) | 21.7 (5.3) | 25.8 (10.5)
Median (Min-Max) | 23.0 (16.0 - 64.0) | 22.0 (11.0 - 26.0) | 23.0 (11.0 - 64.0)
Week 24
N | 17 | 6 | 23
Mean (SD) | 25.0 (8.3) | 20.3 (4.7) | 23.8 (7.7)
Median (Min-Max) | 22.0 (14.0 - 41.0) | 22.0 (14.0 - 25.0) | 22.0 (14.0 - 41.0)
LOCF
N | 27 | 14 | 41
Mean (SD) | 27.1 (19.1) | 19.6 (5.1) | 24.5 (16.1)
Median (Min-Max) | 23.0 (14.0 - 116.0) | 20.0 (12.0 - 30.0) | 22.0 (12.0 - 116.0)
Change from Baseline to LOCF
N | 27 | 14 | 41
Mean (SD) | 1.4 (18.5) | −2.5 (3.2) | 0.1 (15.1)
Median (Min-Max) | −2.0 (−17.0 - 90.0) | −2.5 (−7.0 - 3.0) | −2.0 (−17.0 - 90.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.5A Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata Bicarbonate (mEq/L) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 25.6 (2.5) | 24.9 (2.4) | 25.4 (2.5)
Median (Min-Max) | 26.0 (18.0 - 29.0) | 25.0 (21.0 - 28.0) | 26.0 (18.0 - 29.0)
Week 4
N | 24 | 14 | 38
Mean (SD) | 25.8 (2.5) | 25.6 (2.9) | 25.7 (2.6)
Median (Min-Max) | 26.0 (19.0 - 30.0) | 25.5 (21.0 - 31.0) | 26.0 (19.0 - 31.0)
Week 8
N | 25 | 13 | 38
Mean (SD) | 24.8 (2.0) | 25.5 (2.4) | 25.1 (2.2)
Median (Min-Max) | 25.0 (19.0 - 29.0) | 26.0 (21.0 - 30.0) | 25.0 (19.0 - 30.0)
Week 16
N | 21 | 7 | 28
Mean (SD) | 25.5 (3.1) | 25.7 (1.3) | 25.5 (2.7)
Median (Min-Max) | 25.0 (17.0 - 32.0) | 26.0 (24.0 - 28.0) | 25.5 (17.0 - 32.0)
Week 24
N | 17 | 6 | 23
Mean (SD) | 25.9 (2.4) | 25.2 (1.7) | 25.7 (2.2)
Median (Min-Max) | 26.0 (23.0 - 32.0) | 25.0 (23.0 - 27.0) | 26.0 (23.0 - 32.0)
LOCF
N | 27 | 14 | 41
Mean (SD) | 25.6 (2.1) | 25.8 (2.9) | 25.7 (2.4)
Median (Min-Max) | 26.0 (22.0 - 32.0) | 26.0 (20.0 - 30.0) | 26.0 (20.0 - 32.0)
Change from Baseline to LOCF
N | 27 | 14 | 41
Mean (SD) | 0.1 (2.7) | 0.8 (2.8) | 0.4 (2.7)
Median (Min-Max) | 0.0 (−4.0 - 5.0) | 1.0 (−4.0 - 7.0) | 0.0 (−4.0 - 7.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.6A Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata Direct Bilirubin (mg/dL) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 0.1 (0.0) | 0.1 (0.1) | 0.1 (0.0)
Median (Min-Max) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 0.2)
Week 4
N | 23 | 14 | 37
Mean (SD) | 0.1 (0.0) | 0.1 (0.1) | 0.1 (0.1)
Median (Min-Max) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 0.3) | 0.1 (0.0 - 0.3)
Week 8
N | 25 | 13 | 38
Mean (SD) | 0.1 (0.0) | 0.1 (0.0) | 0.1 (0.0)
Median (Min-Max) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 0.2)
Week 16
N | 21 | 7 | 28
Mean (SD) | 0.1 (0.0) | 0.1 (0.1) | 0.1 (0.1)
Median (Min-Max) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 0.3) | 0.1 (0.0 - 0.3)
Week 24
N | 17 | 6 | 23
Mean (SD) | 0.1 (0.1) | 0.4 (0.7) | 0.2 (0.3)
Median (Min-Max) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 1.7) | 0.1 (0.0 - 1.7)
LOCF
N | 27 | 14 | 41
Mean (SD) | 0.1 (0.0) | 0.2 (0.4) | 0.1 (0.3)
Median (Min-Max) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 1.7) | 0.1 (0.0 - 1.7)
Change from Baseline to LOCF
N | 27 | 14 | 41
Mean (SD) | 0.0 (0.0) | 0.1 (0.4) | 0.0 (0.3)
Median (Min-Max) | 0.0 (−0.1 - 0.1) | 0.0 (−0.1 - 1.6) | 0.0 (−0.1 - 1.6)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.7A Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata Total Bilirubin (mg/dL) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 0.5 (0.2) | 0.6 (0.2) | 0.5 (0.2)
Median (Min-Max) | 0.4 (0.2 - 1.3) | 0.5 (0.2 - 1.1) | 0.5 (0.2 - 1.3)
Week 4
N | 24 | 14 | 38
Mean (SD) | 0.4 (0.3) | 0.6 (0.3) | 0.4 (0.3)
Median (Min-Max) | 0.3 (0.1 - 1.4) | 0.5 (0.2 - 1.1) | 0.3 (0.1 - 1.4)
Week 8
N | 24 | 13 | 37
Mean (SD) | 0.4 (0.2) | 0.4 (0.3) | 0.4 (0.2)
Median (Min-Max) | 0.3 (0.1 - 1.0) | 0.3 (0.3 - 1.2) | 0.3 (0.1 - 1.2)
Week 16
N | 21 | 7 | 28
Mean (SD) | 0.4 (0.2) | 0.6 (0.5) | 0.4 (0.3)
Median (Min-Max) | 0.3 (0.1 - 1.1) | 0.5 (0.1 - 1.4) | 0.3 (0.1 - 1.4)
Week 24
N | 17 | 6 | 23
Mean (SD) | 0.4 (0.2) | 0.5 (0.2) | 0.4 (0.2)
Median (Min-Max) | 0.4 (0.0 - 1.1) | 0.5 (0.2 - 0.7) | 0.4 (0.0 - 1.1)
LOCF
N | 27 | 14 | 41
Mean (SD) | 0.4 (0.2) | 0.4 (0.2) | 0.4 (0.2)
Median (Min-Max) | 0.3 (0.0 - 1.1) | 0.3 (0.2 - 0.7) | 0.3 (0.0 - 1.1)
Change from Baseline to LOCF
N | 27 | 14 | 41
Mean (SD) | −0.1 (0.2) | −0.2 (0.2) | −0.1 (0.2)
Median (Min-Max) | −0.1 (−0.7 - 0.2) | −0.2 (−0.9 - 0.0) | −0.1 (−0.9 - 0.2)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.8A Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata Calcium (mg/dL) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 9.7 (0.5) | 9.7 (0.4) | 9.7 (0.4)
Median (Min-Max) | 9.8 (8.8 - 10.5) | 9.9 (8.9 - 10.2) | 9.8 (8.8 - 10.5)
Week 4
N | 24 | 14 | 38
Mean (SD) | 9.7 (0.3) | 9.7 (0.4) | 9.7 (0.4)
Median (Min-Max) | 9.7 (8.9 - 10.2) | 9.8 (8.7 - 10.3) | 9.7 (8.7 - 10.3)
Week 8
N | 24 | 13 | 37
Mean (SD) | 9.8 (0.3) | 9.7 (0.3) | 9.7 (0.3)
Median (Min-Max) | 9.8 (9.2 - 10.3) | 9.7 (8.9 - 10.4) | 9.8 (8.9 - 10.4)
Week 16
N | 21 | 7 | 28
Mean (SD) | 9.7 (0.3) | 9.8 (0.3) | 9.8 (0.3)
Median (Min-Max) | 9.7 (9.2 - 10.3) | 9.8 (9.4 - 10.2) | 9.8 (9.2 - 10.3)
Week 24
N | 17 | 6 | 23
Mean (SD) | 9.7 (0.4) | 9.9 (0.4) | 9.8 (0.4)
Median (Min-Max) | 9.7 (8.6 - 10.3) | 10.0 (9.3 - 10.3) | 9.8 (8.6 - 10.3)
LOCF
N | 27 | 14 | 41
Mean (SD) | 9.7 (0.4) | 9.8 (0.4) | 9.7 (0.4)
Median (Min-Max) | 9.8 (8.6 - 10.3) | 9.8 (9.3 - 10.4) | 9.8 (8.6 - 10.4)
Change from Baseline to LOCF
N | 27 | 14 | 41
Mean (SD) | 0.0 (0.4) | 0.1 (0.3) | 0.0 (0.4)
Median (Min-Max) | 0.0 (−1.2 - 0.6) | 0.0 (−0.5 - 0.6) | 0.0 (−1.2 - 0.6)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.9A Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata Chloride (mEq/L) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 103.3 (2.2) | 103.7 (2.1) | 103.5 (2.2)
Median (Min-Max) | 103.0 (99.0 - 108.0) | 104.0 (99.0 - 106.0) | 104.0 (99.0 - 108.0)
Week 4
N | 24 | 14 | 38
Mean (SD) | 103.6 (2.0) | 103.9 (3.3) | 103.7 (2.5)
Median (Min-Max) | 103.5 (100.0 - 108.0) | 103.5 (97.0 - 108.0) | 103.5 (97.0 - 108.0)
Week 8
N | 25 | 13 | 38
Mean (SD) | 104.1 (2.1) | 103.8 (2.0) | 104.0 (2.1)
Median (Min-Max) | 104.0 (100.0 - 109.0) | 104.0 (100.0 - 106.0) | 104.0 (100.0 - 109.0)
Week 16
N | 21 | 7 | 28
Mean (SD) | 103.5 (2.3) | 106.0 (2.8) | 104.1 (2.6)
Median (Min-Max) | 103.0 (98.0 - 107.0) | 106.0 (102.0 - 111.0) | 104.0 (98.0 - 111.0)
Week 24
N | 17 | 6 | 23
Mean (SD) | 104.6 (2.5) | 106.2 (1.6) | 105.0 (2.4)
Median (Min-Max) | 105.0 (100.0 - 109.0) | 106.0 (104.0 - 108.0) | 106.0 (100.0 - 109.0)
LOCF
N | 27 | 14 | 41
Mean (SD) | 104.1 (2.5) | 104.9 (1.9) | 104.4 (2.3)
Median (Min-Max) | 105.0 (100.0 - 109.0) | 105.0 (102.0 - 108.0) | 105.0 (100.0 - 109.0)
Change from Baseline to LOCF
N | 27 | 14 | 41
Mean (SD) | 0.8 (3.1) | 1.4 (1.7) | 1.0 (2.7)
Median (Min-Max) | 1.0 (−5.0 - 5.0) | 1.5 (−2.0 - 3.0) | 1.0 (−5.0 - 5.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.10A Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata Cholesterol (mg/dL) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 170.9 (27.1) | 163.5 (29.5) | 168.4 (27.8)
Median (Min-Max) | 166.0 (123.0 - 233.0) | 156.0 (136.0 - 248.0) | 164.5 (123.0 - 248.0)
Week 4
N | 23 | 14 | 37
Mean (SD) | 169.4 (17.5) | 160.6 (16.6) | 166.1 (17.4)
Median (Min-Max) | 168.0 (135.0 - 208.0) | 155.5 (142.0 - 192.0) | 166.0 (135.0 - 208.0)
Week 8
N | 25 | 13 | 38
Mean (SD) | 166.2 (27.8) | 161.2 (21.4) | 164.4 (25.6)
Median (Min-Max) | 160.0 (108.0 - 230.0) | 164.0 (127.0 - 200.0) | 162.0 (108.0 - 230.0)
Week 16
N | 21 | 7 | 28
Mean (SD) | 174.8 (35.0) | 158.9 (21.4) | 170.8 (32.5)
Median (Min-Max) | 161.0 (120.0 - 242.0) | 159.0 (136.0 - 195.0) | 160.5 (120.0 - 242.0)
Week 24
N | 17 | 6 | 23
Mean (SD) | 174.6 (38.3) | 152.5 (22.0) | 168.8 (35.7)
Median (Min-Max) | 181.0 (108.0 - 264.0) | 148.0 (126.0 - 189.0) | 171.0 (108.0 - 264.0)
LOCF
N | 27 | 14 | 41
Mean (SD) | 174.3 (34.9) | 160.6 (19.9) | 169.6 (31.0)
Median (Min-Max) | 177.0 (108.0 - 264.0) | 161.5 (126.0 - 200.0) | 171.0 (108.0 - 264.0)
Change from Baseline to LOCF
N | 27 | 14 | 41
Mean (SD) | 1.1 (25.9) | −2.4 (24.3) | 0.0 (25.1)
Median (Min-Max) | 3.0 (−41.0 - 52.0) | −2.5 (−59.0 - 38.0) | 0.0 (−59.0 - 52.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.11A Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata Creatine kinase (U/L) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 121.0 (68.9) | 173.3 (224.7) | 138.8 (142.0)
Median (Min-Max) | 101.0 (48.0 - 300.0) | 113.0 (28.0 - 947.0) | 106.0 (28.0 - 947.0)
Week 4
N | 21 | 14 | 35
Mean (SD) | 163.8 (92.7) | 107.6 (60.4) | 141.3 (85.1)
Median (Min-Max) | 134.0 (55.0 - 337.0) | 84.5 (25.0 - 239.0) | 116.0 (25.0 - 337.0)
Week 8
N | 25 | 13 | 38
Mean (SD) | 121.3 (80.2) | 125.7 (56.6) | 122.8 (72.2)
Median (Min-Max) | 94.0 (43.0 - 370.0) | 119.0 (25.0 - 224.0) | 107.0 (25.0 - 370.0)
Week 16
N | 21 | 7 | 28
Mean (SD) | 104.9 (94.3) | 122.0 (33.4) | 109.1 (83.1)
Median (Min-Max) | 81.0 (49.0 - 494.0) | 112.0 (83.0 - 170.0) | 89.5 (49.0 - 494.0)
Week 24
N | 17 | 6 | 23
Mean (SD) | 100.6 (60.6) | 94.7 (41.3) | 99.0 (55.4)
Median (Min-Max) | 78.0 (45.0 - 288.0) | 84.5 (50.0 - 171.0) | 83.0 (45.0 - 288.0)
LOCF
N | 26 | 14 | 40
Mean (SD) | 108.9 (69.5) | 117.6 (76.8) | 111.9 (71.3)
Median (Min-Max) | 84.5 (45.0 - 317.0) | 84.5 (25.0 - 320.0) | 84.5 (25.0 - 320.0)
Change from Baseline to LOCF
N | 26 | 14 | 40
Mean (SD) | −6.1 (47.1) | −0.4 (50.9) | −4.1 (47.9)
Median (Min-Max) | −4.0 (−102 - 141.0) | −2.0 (−105 - 137.0) | −3.5 (−105 - 141.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.12A Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata Creatinine (mg/dL) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 0.5 (0.1) | 0.8 (0.1) | 0.6 (0.1)
Median (Min-Max) | 0.5 (0.4 - 0.8) | 0.7 (0.6 - 1.1) | 0.6 (0.4 - 1.1)
Week 4
N | 24 | 14 | 38
Mean (SD) | 0.6 (0.1) | 0.8 (0.1) | 0.6 (0.1)
Median (Min-Max) | 0.6 (0.4 - 0.8) | 0.7 (0.6 - 1.0) | 0.6 (0.4 - 1.0)
Week 8
N | 24 | 13 | 37
Mean (SD) | 0.6 (0.1) | 0.8 (0.1) | 0.6 (0.1)
Median (Min-Max) | 0.6 (0.4 - 0.7) | 0.8 (0.6 - 1.1) | 0.6 (0.4 - 1.1)
Week 16
N | 21 | 7 | 28
Mean (SD) | 0.6 (0.1) | 0.8 (0.2) | 0.6 (0.2)
Median (Min-Max) | 0.6 (0.3 - 0.8) | 0.8 (0.6 - 1.0) | 0.6 (0.3 - 1.0)
Week 24
N | 17 | 6 | 23
Mean (SD) | 0.6 (0.1) | 0.7 (0.2) | 0.6 (0.1)
Median (Min-Max) | 0.6 (0.5 - 0.8) | 0.7 (0.5 - 1.0) | 0.6 (0.5 - 1.0)
LOCF
N | 27 | 14 | 41
Mean (SD) | 0.6 (0.1) | 0.7 (0.2) | 0.6 (0.1)
Median (Min-Max) | 0.6 (0.4 - 0.8) | 0.8 (0.5 - 1.0) | 0.6 (0.4 - 1.0)
Change from Baseline to LOCF
N | 27 | 14 | 41
Mean (SD) | 0.0 (0.1) | 0.0 (0.1) | 0.0 (0.1)
Median (Min-Max) | 0.0 (−0.2 - 0.3) | 0.0 (−0.2 - 0.2) | 0.0 (−0.2 - 0.3)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.13A Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata Gamma-glutamyl Transpeptidase - GGT (U/L) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 21.7 (12.2) | 18.9 (11.3) | 20.7 (11.8)
Median (Min-Max) | 19.0 (8.0 - 66.0) | 16.0 (8.0 - 47.0) | 18.0 (8.0 - 66.0)
Week 4
N | 23 | 14 | 37
Mean (SD) | 19.0 (8.5) | 18.6 (11.7) | 18.8 (9.7)
Median (Min-Max) | 18.0 (8.0 - 43.0) | 14.0 (10.0 - 49.0) | 15.0 (8.0 - 49.0)
Week 8
N | 25 | 12 | 37
Mean (SD) | 17.9 (8.7) | 20.1 (11.8) | 18.6 (9.7)
Median (Min-Max) | 15.0 (10.0 - 51.0) | 15.5 (9.0 - 44.0) | 15.0 (9.0 - 51.0)
Week 16
N | 21 | 7 | 28
Mean (SD) | 18.6 (11.0) | 16.0 (8.4) | 18.0 (10.3)
Median (Min-Max) | 15.0 (6.0 - 54.0) | 13.0 (10.0 - 34.0) | 15.0 (6.0 - 54.0)
Week 24
N | 17 | 6 | 23
Mean (SD) | 19.6 (11.5) | 14.3 (7.3) | 18.3 (10.7)
Median (Min-Max) | 18.0 (8.0 - 59.0) | 12.0 (10.0 - 29.0) | 13.0 (8.0 - 59.0)
LOCF
N | 27 | 13 | 40
Mean (SD) | 20.2 (10.7) | 16.8 (7.7) | 19.1 (9.8)
Median (Min-Max) | 19.0 (7.0 - 59.0) | 13.0 (10.0 - 32.0) | 17.5 (7.0 - 59.0)
Change from Baseline to LOCF
N | 27 | 13 | 40
Mean (SD) | −1.9 (5.4) | −2.6 (5.9) | −2.1 (5.5)
Median (Min-Max) | −1.0 (−16.0 - 8.0) | −1.0 (−18.0 - 3.0) | −1.0 (−18.0 - 8.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.14A Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata Glucose (mg/dL) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 81.5 (8.1) | 84.1 (16.3) | 82.4 (11.4)
Median (Min-Max) | 82.0 (55.0 - 95.0) | 85.0 (45.0 - 118.0) | 82.0 (45.0 - 118.0)
Week 4
N | 24 | 14 | 38
Mean (SD) | 88.2 (19.4) | 83.4 (13.9) | 86.4 (17.5)
Median (Min-Max) | 84.5 (52.0 - 145.0) | 86.0 (55.0 - 109.0) | 85.0 (52.0 - 145.0)
Week 8
N | 24 | 13 | 37
Mean (SD) | 90.5 (23.5) | 85.3 (12.5) | 88.7 (20.3)
Median (Min-Max) | 84.0 (64.0 - 156.0) | 83.0 (71.0 - 110.0) | 83.0 (64.0 - 156.0)
Week 16
N | 21 | 7 | 28
Mean (SD) | 82.8 (14.1) | 85.9 (12.9) | 83.5 (13.7)
Median (Min-Max) | 84.0 (49.0 - 103.0) | 87.0 (60.0 - 101.0) | 84.5 (49.0 - 103.0)
Week 24
N | 17 | 6 | 23
Mean (SD) | 82.7 (9.4) | 92.0 (8.4) | 85.1 (9.9)
Median (Min-Max) | 84.0 (67.0 - 99.0) | 92.5 (77.0 - 103.0) | 85.0 (67.0 - 103.0)
LOCF
N | 27 | 14 | 41
Mean (SD) | 82.7 (9.5) | 92.3 (9.2) | 86.0 (10.4)
Median (Min-Max) | 84.0 (63.0 - 99.0) | 93.5 (71.0 - 104.0) | 86.0 (63.0 - 104.0)
Change from Baseline to LOCF
N | 27 | 14 | 41
Mean (SD) | 1.3 (10.4) | 10.6 (17.4) | 4.5 (13.7)
Median (Min-Max) | 3.0 (−23.0 - 21.0) | 12.0 (−20.0 - 52.0) | 4.0 (−23.0 - 52.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.15A Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata High-Density Lipoprotein - HDL (mg/dL) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 56.1 (17.7) | 49.3 (11.7) | 53.8 (16.1)
Median (Min-Max) | 52.0 (32.0 - 113.0) | 50.0 (23.0 - 67.0) | 50.5 (23.0 - 113.0)
Week 4
N | 22 | 14 | 36
Mean (SD) | 51.8 (15.6) | 51.8 (13.1) | 51.8 (14.5)
Median (Min-Max) | 47.0 (25.0 - 85.0) | 51.0 (34.0 - 74.0) | 47.0 (25.0 - 85.0)
Week 8
N | 25 | 13 | 38
Mean (SD) | 53.9 (15.1) | 48.5 (12.3) | 52.1 (14.3)
Median (Min-Max) | 52.0 (33.0 - 80.0) | 49.0 (32.0 - 75.0) | 50.0 (32.0 - 80.0)
Week 16
N | 21 | 7 | 28
Mean (SD) | 54.8 (15.7) | 46.3 (9.5) | 52.7 (14.7)
Median (Min-Max) | 50.0 (33.0 - 91.0) | 44.0 (35.0 - 62.0) | 47.0 (33.0 - 91.0)
Week 24
N | 17 | 6 | 23
Mean (SD) | 55.2 (14.5) | 46.7 (10.7) | 53.0 (13.9)
Median (Min-Max) | 54.0 (31.0 - 80.0) | 47.5 (32.0 - 58.0) | 54.0 (31.0 - 80.0)
LOCF
N | 27 | 14 | 41
Mean (SD) | 53.0 (13.0) | 50.1 (11.5) | 52.0 (12.4)
Median (Min-Max) | 51.0 (31.0 - 80.0) | 52.5 (32.0 - 75.0) | 51.0 (31.0 - 80.0)
Change from Baseline to LOCF
N | 27 | 14 | 41
Mean (SD) | −2.2 (12.0) | −1.1 (8.0) | −1.8 (10.7)
Median (Min-Max) | 0.0 (−33.0 - 20.0) | −2.5 (−16.0 - 12.0) | −1.0 (−33.0 - 20.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.16A Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata Cholesterol/HDL Ratio Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 3.3 (1.0) | 3.6 (1.3) | 3.4 (1.1)
Median (Min-Max) | 3.2 (1.7 - 5.9) | 3.0 (2.0 - 7.5) | 3.1 (1.7 - 7.5)
Week 4
N | 22 | 14 | 36
Mean (SD) | 3.6 (1.3) | 3.2 (0.8) | 3.5 (1.2)
Median (Min-Max) | 3.5 (2.0 - 7.4) | 3.0 (2.0 - 4.7) | 3.4 (2.0 - 7.4)
Week 8
N | 25 | 13 | 38
Mean (SD) | 3.4 (1.2) | 3.5 (1.0) | 3.4 (1.1)
Median (Min-Max) | 2.9 (1.8 - 6.0) | 3.1 (2.0 - 5.3) | 3.1 (1.8 - 6.0)
Week 16
N | 21 | 7 | 28
Mean (SD) | 3.4 (1.1) | 3.5 (0.8) | 3.4 (1.0)
Median (Min-Max) | 3.1 (1.6 - 5.6) | 3.2 (2.4 - 4.5) | 3.2 (1.6 - 5.6)
Week 24
N | 17 | 6 | 23
Mean (SD) | 3.4 (1.2) | 3.4 (1.0) | 3.4 (1.1)
Median (Min-Max) | 3.1 (1.5 - 5.4) | 3.2 (2.4 - 5.2) | 3.1 (1.5 - 5.4)
LOCF
N | 27 | 14 | 41
Mean (SD) | 3.5 (1.0) | 3.3 (1.0) | 3.4 (1.0)
Median (Min-Max) | 3.2 (1.5 - 5.4) | 3.1 (2.0 - 5.3) | 3.2 (1.5 - 5.4)
Change from Baseline to LOCF
N | 27 | 14 | 41
Mean (SD) | 0.1 (0.5) | 0.1 (0.5) | 0.1 (0.5)
Median (Min-Max) | 0.0 (−1.0 - 1.3) | 0.0 (−0.7 - 1.1) | 0.0 (−1.0 - 1.3)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.17A Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata Low-Density Lipoprotein - LDL (mg/dL) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 97.3 (28.1) | 97.5 (25.6) | 97.4 (27.0)
Median (Min-Max) | 96.0 (45.0 - 181.0) | 89.0 (56.0 - 158.0) | 94.5 (45.0 - 181.0)
Week 4
N | 22 | 14 | 36
Mean (SD) | 95.0 (25.8) | 84.9 (16.4) | 91.1 (22.9)
Median (Min-Max) | 99.0 (54.0 - 139.0) | 81.0 (63.0 - 117.0) | 93.0 (54.0 - 139.0)
Week 8
N | 25 | 13 | 38
Mean (SD) | 90.0 (29.7) | 84.2 (19.7) | 88.0 (26.6)
Median (Min-Max) | 83.0 (50.0 - 165.0) | 88.0 (53.0 - 111.0) | 85.5 (50.0 - 165.0)
Week 16
N | 21 | 7 | 28
Mean (SD) | 100.5 (28.7) | 92.0 (16.5) | 98.4 (26.2)
Median (Min-Max) | 100.0 (48.0 - 160.0) | 91.0 (71.0 - 111.0) | 100.0 (48.0 - 160.0)
Week 24
N | 17 | 6 | 23
Mean (SD) | 102.6 (27.1) | 92.0 (21.3) | 99.9 (25.7)
Median (Min-Max) | 112.0 (53.0 - 134.0) | 88.0 (70.0 - 123.0) | 106.0 (53.0 - 134.0)
LOCF
N | 27 | 14 | 41
Mean (SD) | 104.2 (24.3) | 92.9 (17.6) | 100.3 (22.7)
Median (Min-Max) | 108.0 (53.0 - 136.0) | 92.5 (70.0 - 123.0) | 100.0 (53.0 - 136.0)
Change from Baseline to LOCF
N | 27 | 14 | 41
Mean (SD) | 4.3 (18.0) | −2.6 (17.0) | 1.9 (17.8)
Median (Min-Max) | 7.0 (−49.0 - 37.0) | 0.5 (−35.0 - 36.0) | 1.0 (−49.0 - 37.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.18A Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata Magnesium (mg/dL) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 2.3 (0.3) | 2.2 (0.2) | 2.2 (0.3)
Median (Min-Max) | 2.2 (1.8 - 2.9) | 2.1 (1.9 - 2.6) | 2.2 (1.8 - 2.9)
Week 4
N | 22 | 14 | 36
Mean (SD) | 2.3 (0.2) | 2.3 (0.2) | 2.3 (0.2)
Median (Min-Max) | 2.3 (1.9 - 2.8) | 2.3 (1.9 - 2.6) | 2.3 (1.9 - 2.8)
Week 8
N | 25 | 13 | 38
Mean (SD) | 2.3 (0.2) | 2.3 (0.2) | 2.3 (0.2)
Median (Min-Max) | 2.3 (1.8 - 2.8) | 2.3 (1.9 - 2.6) | 2.3 (1.8 - 2.8)
Week 16
N | 21 | 7 | 28
Mean (SD) | 2.3 (0.2) | 2.3 (0.1) | 2.3 (0.2)
Median (Min-Max) | 2.3 (2.0 - 3.0) | 2.3 (2.1 - 2.4) | 2.3 (2.0 - 3.0)
Week 24
N | 17 | 6 | 23
Mean (SD) | 2.2 (0.3) | 2.3 (0.1) | 2.2 (0.2)
Median (Min-Max) | 2.2 (1.8 - 2.8) | 2.3 (2.1 - 2.4) | 2.2 (1.8 - 2.8)
LOCF
N | 27 | 14 | 41
Mean (SD) | 2.2 (0.2) | 2.2 (0.2) | 2.2 (0.2)
Median (Min-Max) | 2.2 (1.8 - 2.8) | 2.2 (1.9 - 2.4) | 2.2 (1.8 - 2.8)
Change from Baseline to LOCF
N | 27 | 14 | 41
Mean (SD) | −0.1 (0.2) | 0.0 (0.3) | −0.1 (0.2)
Median (Min-Max) | 0.0 (−0.7 - 0.3) | 0.0 (−0.5 - 0.4) | 0.0 (−0.7 - 0.4)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.19A Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata Phosphorus (mg/dL) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 4.7 (0.5) | 4.4 (0.8) | 4.6 (0.6)
Median (Min-Max) | 4.6 (3.9 - 5.9) | 4.1 (3.3 - 6.7) | 4.5 (3.3 - 6.7)
Week 4
N | 22 | 13 | 35
Mean (SD) | 5.0 (0.5) | 4.4 (0.8) | 4.8 (0.7)
Median (Min-Max) | 4.9 (4.1 - 5.9) | 4.3 (3.4 - 5.8) | 4.8 (3.4 - 5.9)
Week 8
N | 25 | 13 | 38
Mean (SD) | 4.8 (0.6) | 4.4 (0.5) | 4.7 (0.6)
Median (Min-Max) | 4.9 (3.9 - 6.2) | 4.5 (3.7 - 5.2) | 4.6 (3.7 - 6.2)
Week 16
N | 21 | 7 | 28
Mean (SD) | 4.9 (0.7) | 4.3 (1.1) | 4.8 (0.8)
Median (Min-Max) | 4.8 (3.8 - 6.4) | 4.5 (2.9 - 5.6) | 4.8 (2.9 - 6.4)
Week 24
N | 17 | 6 | 23
Mean (SD) | 4.7 (0.6) | 4.5 (1.2) | 4.6 (0.8)
Median (Min-Max) | 4.6 (3.6 - 6.1) | 4.0 (3.4 - 6.4) | 4.4 (3.4 - 6.4)
LOCF
N | 27 | 14 | 41
Mean (SD) | 4.8 (0.6) | 4.2 (0.9) | 4.6 (0.8)
Median (Min-Max) | 4.7 (3.6 - 6.2) | 4.0 (2.8 - 6.4) | 4.6 (2.8 - 6.4)
Change from Baseline to LOCF
N | 27 | 14 | 41
Mean (SD) | 0.1 (0.4) | −0.2 (0.5) | 0.0 (0.5)
Median (Min-Max) | 0.0 (−0.7 - 0.9) | −0.3 (−1.5 - 0.6) | 0.0 (−1.5 - 0.9)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.20A Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata Potassium (mEq/L) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 4.2 (0.3) | 4.3 (0.4) | 4.2 (0.4)
Median (Min-Max) | 4.2 (3.5 - 5.1) | 4.4 (3.8 - 5.3) | 4.2 (3.5 - 5.3)
Week 4
N | 24 | 14 | 38
Mean (SD) | 4.2 (0.4) | 4.2 (0.2) | 4.2 (0.3)
Median (Min-Max) | 4.2 (3.3 - 4.8) | 4.2 (3.8 - 4.6) | 4.2 (3.3 - 4.8)
Week 8
N | 25 | 13 | 38
Mean (SD) | 4.3 (0.4) | 4.2 (0.1) | 4.2 (0.4)
Median (Min-Max) | 4.2 (3.6 - 5.2) | 4.2 (4.0 - 4.4) | 4.2 (3.6 - 5.2)
Week 16
N | 21 | 7 | 28
Mean (SD) | 4.3 (0.4) | 4.1 (0.5) | 4.2 (0.4)
Median (Min-Max) | 4.3 (3.4 - 5.1) | 3.9 (3.6 - 4.8) | 4.3 (3.4 - 5.1)
Week 24
N | 17 | 6 | 23
Mean (SD) | 4.2 (0.3) | 4.4 (0.3) | 4.2 (0.3)
Median (Min-Max) | 4.2 (3.6 - 4.7) | 4.4 (4.1 - 4.7) | 4.2 (3.6 - 4.7)
LOCF
N | 27 | 14 | 41
Mean (SD) | 4.2 (0.2) | 4.4 (0.2) | 4.2 (0.2)
Median (Min-Max) | 4.1 (3.6 - 4.7) | 4.4 (4.1 - 4.7) | 4.2 (3.6 - 4.7)
Change from Baseline to LOCF
N | 27 | 14 | 41
Mean (SD) | 0.0 (0.2) | 0.0 (0.3) | 0.0 (0.3)
Median (Min-Max) | 0.0 (−0.7 - 0.3) | 0.1 (−0.7 - 0.3) | 0.0 (−0.7 - 0.3)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.21A Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata Total Protein (g/dL) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 7.4 (0.4) | 7.1 (0.4) | 7.3 (0.4)
Median (Min-Max) | 7.4 (6.6 - 8.2) | 7.1 (6.5 - 7.9) | 7.3 (6.5 - 8.2)
Week 4
N | 29 | 15 | 44
Mean (SD) | 7.4 (0.4) | 7.1 (0.4) | 7.3 (0.4)
Median (Min-Max) | 7.4 (6.6 - 8.2) | 7.1 (6.5 - 7.9) | 7.3 (6.5 - 8.2)
Week 8
N | 29 | 15 | 44
Mean (SD) | 7.4 (0.4) | 7.1 (0.4) | 7.3 (0.4)
Median (Min-Max) | 7.4 (6.6 - 8.2) | 7.1 (6.5 - 7.9) | 7.3 (6.5 - 8.2)
Week 16
N | 29 | 15 | 44
Mean (SD) | 7.4 (0.4) | 7.1 (0.4) | 7.3 (0.4)
Median (Min-Max) | 7.4 (6.6 - 8.2) | 7.1 (6.5 - 7.9) | 7.3 (6.5 - 8.2)
Week 24
N | 29 | 15 | 44
Mean (SD) | 7.4 (0.4) | 7.1 (0.4) | 7.3 (0.4)
Median (Min-Max) | 7.4 (6.6 - 8.2) | 7.1 (6.5 - 7.9) | 7.3 (6.5 - 8.2)
LOCF
N | 29 | 15 | 44
Mean (SD) | 7.4 (0.4) | 7.1 (0.4) | 7.3 (0.4)
Median (Min-Max) | 7.4 (6.6 - 8.2) | 7.1 (6.5 - 7.9) | 7.3 (6.5 - 8.2)
Change from Baseline to LOCF
N | 26 | 14 | 40
Mean (SD) | 0.1 (0.5) | −0.1 (0.5) | 0.0 (0.5)
Median (Min-Max) | −0.1 (−0.7 - 1.1) | 0.0 (−1.0 - 0.7) | −0.1 (−1.0 - 1.1)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.22A Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata Sodium (mEq/L) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 137.8 (2.4) | 139.0 (2.4) | 138.2 (2.5)
Median (Min-Max) | 138.0 (132.0 - 141.0) | 138.0 (134.0 - 143.0) | 138.0 (132.0 - 143.0)
Week 4
N | 24 | 14 | 38
Mean (SD) | 138.0 (2.7) | 139.4 (2.7) | 138.5 (2.7)
Median (Min-Max) | 138.0 (133.0 - 143.0) | 139.0 (134.0 - 143.0) | 139.0 (133.0 - 143.0)
Week 8
N | 25 | 13 | 38
Mean (SD) | 138.8 (2.5) | 139.4 (1.9) | 139.0 (2.3)
Median (Min-Max) | 139.0 (134.0 - 144.0) | 139.0 (136.0 - 142.0) | 139.0 (134.0 - 144.0)
Week 16
N | 21 | 7 | 28
Mean (SD) | 138.2 (2.9) | 140.1 (2.9) | 138.7 (3.0)
Median (Min-Max) | 139.0 (133.0 - 143.0) | 139.0 (136.0 - 144.0) | 139.0 (133.0 - 144.0)
Week 24
N | 17 | 6 | 23
Mean (SD) | 138.6 (2.8) | 139.8 (2.3) | 138.9 (2.7)
Median (Min-Max) | 139.0 (133.0 - 143.0) | 141.0 (136.0 - 142.0) | 139.0 (133.0 - 143.0)
LOCF
N | 27 | 14 | 41
Mean (SD) | 138.5 (2.5) | 140.4 (2.3) | 139.1 (2.6)
Median (Min-Max) | 139.0 (133.0 - 143.0) | 141.0 (136.0 - 144.0) | 139.0 (133.0 - 144.0)
Change from Baseline to LOCF
N | 27 | 14 | 41
Mean (SD) | 0.6 (2.5) | 1.4 (2.9) | 0.9 (2.6)
Median (Min-Max) | 0.0 (−5.0 - 6.0) | 1.5 (−2.0 - 7.0) | 1.0 (−5.0 - 7.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.23A Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata Triglycerides (mg/dL) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 101.3 (66.2) | 83.6 (38.6) | 95.3 (58.4)
Median (Min-Max) | 80.0 (14.0 - 269.0) | 63.0 (45.0 - 144.0) | 75.0 (14.0 - 269.0)
Week 4
N | 22 | 14 | 36
Mean (SD) | 138.7 (79.9) | 122.6 (71.1) | 132.5 (76.0)
Median (Min-Max) | 120.0 (48.0 - 420.0) | 110.5 (48.0 - 312.0) | 118.5 (48.0 - 420.0)
Week 8
N | 25 | 13 | 38
Mean (SD) | 135.8 (91.5) | 140.7 (82.4) | 137.5 (87.4)
Median (Min-Max) | 105.0 (39.0 - 365.0) | 115.0 (33.0 - 326.0) | 109.5 (33.0 - 365.0)
Week 16
N | 21 | 7 | 28
Mean (SD) | 135.2 (69.1) | 103.9 (63.8) | 127.4 (68.1)
Median (Min-Max) | 129.0 (27.0 - 282.0) | 93.0 (45.0 - 231.0) | 116.0 (27.0 - 282.0)
Week 24
N | 17 | 6 | 23
Mean (SD) | 111.6 (99.0) | 68.3 (26.3) | 100.3 (87.5)
Median (Min-Max) | 80.0 (18.0 - 383.0) | 63.5 (38.0 - 114.0) | 73.0 (18.0 - 383.0)
LOCF
N | 27 | 14 | 41
Mean (SD) | 105.7 (84.1) | 92.0 (57.2) | 101.0 (75.5)
Median (Min-Max) | 79.0 (18.0 - 383.0) | 74.0 (38.0 - 268.0) | 78.0 (18.0 - 383.0)
Change from Baseline to LOCF
N | 27 | 14 | 41
Mean (SD) | −0.6 (50.6) | 10.3 (63.8) | 3.1 (54.9)
Median (Min-Max) | −2.0 (−105 - 125.0) | 17.5 (−87.0 - 146.0) | 3.0 (−105 - 146.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.24A Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata Urea Nitrogen (mg/dL) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 10.3 (2.9) | 10.4 (3.1) | 10.4 (2.9)
Median (Min-Max) | 11.0 (6.0 - 15.0) | 11.0 (6.0 - 18.0) | 11.0 (6.0 - 18.0)
Week 4
N | 24 | 14 | 38
Mean (SD) | 11.1 (2.3) | 10.1 (3.5) | 10.7 (2.8)
Median (Min-Max) | 11.0 (6.0 - 15.0) | 9.5 (5.0 - 17.0) | 11.0 (5.0 - 17.0)
Week 8
N | 24 | 13 | 37
Mean (SD) | 11.9 (3.7) | 9.6 (4.8) | 11.1 (4.2)
Median (Min-Max) | 11.5 (4.0 - 19.0) | 8.0 (5.0 - 21.0) | 10.0 (4.0 - 21.0)
Week 16
N | 21 | 7 | 28
Mean (SD) | 12.0 (3.5) | 8.6 (3.8) | 11.1 (3.8)
Median (Min-Max) | 12.0 (3.0 - 18.0) | 7.0 (5.0 - 15.0) | 12.0 (3.0 - 18.0)
Week 24
N | 17 | 6 | 23
Mean (SD) | 11.4 (3.1) | 8.5 (4.7) | 10.6 (3.7)
Median (Min-Max) | 12.0 (5.0 - 17.0) | 8.0 (2.0 - 16.0) | 11.0 (2.0 - 17.0)
LOCF
N | 27 | 14 | 41
Mean (SD) | 11.4 (3.0) | 9.9 (3.9) | 10.9 (3.4)
Median (Min-Max) | 12.0 (5.0 - 17.0) | 9.5 (2.0 - 16.0) | 11.0 (2.0 - 17.0)
Change from Baseline to LOCF
N | 27 | 14 | 41
Mean (SD) | 0.7 (3.3) | −0.6 (3.6) | 0.3 (3.4)
Median (Min-Max) | 0.0 (−6.0 - 9.0) | 0.0 (−8.0 - 5.0) | 0.0 (−8.0 - 9.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.25A Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata Uric Acid (mg/dL) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 4.6 (1.4) | 5.2 (1.4) | 4.8 (1.4)
Median (Min-Max) | 4.2 (2.3 - 7.7) | 4.8 (3.8 - 9.3) | 4.7 (2.3 - 9.3)
Week 4
N | 22 | 14 | 36
Mean (SD) | 5.1 (1.6) | 5.4 (1.3) | 5.2 (1.5)
Median (Min-Max) | 5.2 (2.5 - 9.2) | 5.1 (3.4 - 8.2) | 5.1 (2.5 - 9.2)
Week 8
N | 24 | 13 | 37
Mean (SD) | 4.9 (1.4) | 5.7 (1.7) | 5.2 (1.6)
Median (Min-Max) | 5.3 (2.5 - 7.9) | 5.3 (3.4 - 10.1) | 5.3 (2.5 - 10.1)
Week 16
N | 21 | 7 | 28
Mean (SD) | 5.0 (1.5) | 5.8 (1.5) | 5.2 (1.5)
Median (Min-Max) | 4.8 (2.3 - 8.1) | 5.5 (3.8 - 8.1) | 5.1 (2.3 - 8.1)
Week 24
N | 17 | 6 | 23
Mean (SD) | 5.3 (1.8) | 6.0 (2.8) | 5.5 (2.1)
Median (Min-Max) | 5.2 (2.8 - 9.3) | 5.2 (2.6 - 10.3) | 5.2 (2.6 - 10.3)
LOCF
N | 27 | 14 | 41
Mean (SD) | 4.8 (1.7) | 5.5 (1.9) | 5.1 (1.8)
Median (Min-Max) | 4.7 (2.5 - 9.3) | 5.3 (2.6 - 10.3) | 4.9 (2.5 - 10.3)
Change from Baseline to LOCF
N | 27 | 14 | 41
Mean (SD) | 0.2 (1.0) | 0.4 (1.2) | 0.3 (1.1)
Median (Min-Max) | 0.5 (−2.3 - 2.1) | 0.6 (−2.4 - 2.6) | 0.5 (−2.4 - 2.6)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.26A Summary of Clinical Laboratory Chemistry Measurement by Visit and Age Strata Creatinine Clearance (mL/min/1.7m^2^) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 - 11 yrs; (N=29) | 12 - 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 141.0 (25.5) | 103.7 (27.5) | 128.3 (31.5)
Median (Min-Max) | 138.5 (98.8 - 203.9) | 108.9 (67.3 - 148.6) | 131.3 (67.3 - 203.9)
Week 4
N | 24 | 14 | 38
Mean (SD) | 134.2 (21.5) | 98.3 (25.6) | 121.0 (28.8)
Median (Min-Max) | 134.9 (98.5 - 193.5) | 89.3 (69.3 - 149.0) | 122.0 (69.3 - 193.5)
Week 8
N | 24 | 13 | 37
Mean (SD) | 136.2 (17.3) | 95.6 (26.5) | 121.9 (28.5)
Median (Min-Max) | 130.9 (115.0 - 179.0) | 95.0 (60.4 - 138.6) | 123.5 (60.4 - 179.0)
Week 16
N | 21 | 7 | 28
Mean (SD) | 138.1 (32.7) | 107.6 (25.4) | 130.5 (33.4)
Median (Min-Max) | 134.3 (91.4 - 238.7) | 123.1 (72.6 - 131.4) | 129.8 (72.6 - 238.7)
Week 24
N | 17 | 6 | 23
Mean (SD) | 129.9 (17.6) | 115.9 (28.9) | 126.3 (21.3)
Median (Min-Max) | 129.2 (97.0 - 169.3) | 118.7 (73.9 - 155.4) | 124.8 (73.9 - 169.3)
LOCF
N | 27 | 14 | 41
Mean (SD) | 134.8 (20.0) | 104.0 (31.3) | 124.3 (28.3)
Median (Min-Max) | 130.5 (97.0 - 179.0) | 103.9 (60.4 - 155.4) | 125.9 (60.4 - 179.0)
Change from Baseline to LOCF
N | 27 | 14 | 41
Mean (SD) | −6.0 (27.6) | 2.7 (14.9) | −3.0 (24.2)
Median (Min-Max) | −3.0 (−81.5 - 37.7) | 5.4 (−24.0 - 35.0) | 0.4 (−81.5 - 37.7)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.1B Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Group Albumin (g/dL) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 4.4 (0.4) | 4.2 (0.4) | 4.3 (0.4)
Median (Min-Max) | 4.4 (3.4 - 5.0) | 4.3 (3.7 - 5.1) | 4.4 (3.4 - 5.1)
Week 4
N | 26 | 12 | 38
Mean (SD) | 4.3 (0.4) | 4.3 (0.3) | 4.3 (0.4)
Median (Min-Max) | 4.4 (3.4 - 5.1) | 4.3 (3.8 - 4.9) | 4.4 (3.4 - 5.1)
Week 8
N | 26 | 11 | 37
Mean (SD) | 4.4 (0.3) | 4.2 (0.4) | 4.4 (0.4)
Median (Min-Max) | 4.5 (3.7 - 5.1) | 4.3 (3.7 - 4.9) | 4.4 (3.7 - 5.1)
Week 16
N | 19 | 9 | 28
Mean (SD) | 4.4 (0.3) | 4.3 (0.4) | 4.4 (0.3)
Median (Min-Max) | 4.4 (3.6 - 4.9) | 4.5 (3.8 - 4.9) | 4.5 (3.6 - 4.9)
Week 24
N | 15 | 8 | 23
Mean (SD) | 4.4 (0.3) | 4.3 (0.6) | 4.4 (0.4)
Median (Min-Max) | 4.4 (4.0 - 5.1) | 4.2 (3.7 - 5.4) | 4.4 (3.7 - 5.4)
LOCF
N | 28 | 13 | 41
Mean (SD) | 4.4 (0.4) | 4.2 (0.5) | 4.3 (0.4)
Median (Min-Max) | 4.4 (3.4 - 5.1) | 4.3 (3.3 - 5.4) | 4.4 (3.3 - 5.4)
Change from Baseline to LOCF
N | 28 | 13 | 41
Mean (SD) | 0.0 (0.3) | 0.0 (0.3) | 0.0 (0.3)
Median (Min-Max) | 0.0 (−0.5 - 0.6) | 0.0 (−0.5 - 0.4) | 0.0 (−0.5 - 0.6)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.2B Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Group Alkaline Phosphatase (U/L) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 294.6 (135.3) | 243.2 (71.9) | 277.1 (119.2)
Median (Min-Max) | 312.0 (84.0 - 658.0) | 238.0 (132.0 - 422.0) | 266.0 (84.0 - 658.0)
Week 4
N | 26 | 12 | 38
Mean (SD) | 269.6 (128.5) | 300.3 (97.0) | 279.3 (119.0)
Median (Min-Max) | 295.5 (76.0 - 518.0) | 295.0 (172.0 - 535.0) | 295.0 (76.0 - 535.0)
Week 8
N | 26 | 11 | 37
Mean (SD) | 258.0 (128.0) | 300.4 (95.4) | 270.6 (119.5)
Median (Min-Max) | 262.0 (75.0 - 545.0) | 288.0 (149.0 - 497.0) | 273.0 (75.0 - 545.0)
Week 16
N | 19 | 9 | 28
Mean (SD) | 269.6 (104.9) | 311.4 (125.1) | 283.0 (111.2)
Median (Min-Max) | 276.0 (78.0 - 506.0) | 284.0 (152.0 - 587.0) | 280.0 (78.0 - 587.0)
Week 24
N | 15 | 8 | 23
Mean (SD) | 264.3 (112.1) | 296.8 (86.1) | 275.6 (103.0)
Median (Min-Max) | 275.0 (72.0 - 477.0) | 275.5 (192.0 - 464.0) | 275.0 (72.0 - 477.0)
LOCF
N | 28 | 13 | 41
Mean (SD) | 248.6 (112.5) | 266.8 (86.5) | 254.4 (104.2)
Median (Min-Max) | 258.5 (72.0 - 477.0) | 265.0 (140.0 - 464.0) | 264.0 (72.0 - 477.0)
Change from Baseline to LOCF
N | 28 | 13 | 41
Mean (SD) | −45.3 (84.3) | 19.4 (37.7) | −24.8 (78.4)
Median (Min-Max) | −21.5 (−328 - 64.0) | 12.0 (−55.0 - 76.0) | −12.0 (−328 - 76.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.3B Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Group Alanine Aminotransferase - ALT (U/L) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 28.1 (14.5) | 21.5 (8.9) | 25.8 (13.1)
Median (Min-Max) | 25.0 (8.0 - 65.0) | 25.0 (7.0 - 34.0) | 25.0 (7.0 - 65.0)
Week 4
N | 26 | 12 | 38
Mean (SD) | 24.9 (13.5) | 24.8 (10.9) | 24.9 (12.6)
Median (Min-Max) | 19.5 (9.0 - 59.0) | 23.0 (9.0 - 43.0) | 20.0 (9.0 - 59.0)
Week 8
N | 26 | 11 | 37
Mean (SD) | 22.8 (8.6) | 24.3 (12.8) | 23.2 (9.9)
Median (Min-Max) | 21.5 (9.0 - 44.0) | 22.0 (6.0 - 49.0) | 22.0 (6.0 - 49.0)
Week 16
N | 19 | 9 | 28
Mean (SD) | 25.1 (17.4) | 22.7 (8.5) | 24.3 (14.9)
Median (Min-Max) | 18.0 (10.0 - 65.0) | 21.0 (13.0 - 41.0) | 20.5 (10.0 - 65.0)
Week 24
N | 15 | 8 | 23
Mean (SD) | 22.1 (13.2) | 21.4 (8.6) | 21.9 (11.6)
Median (Min-Max) | 18.0 (7.0 - 61.0) | 18.5 (12.0 - 35.0) | 18.0 (7.0 - 61.0)
LOCF
N | 28 | 13 | 41
Mean (SD) | 22.4 (11.6) | 23.1 (11.7) | 22.6 (11.5)
Median (Min-Max) | 19.0 (7.0 - 61.0) | 20.0 (12.0 - 53.0) | 20.0 (7.0 - 61.0)
Change from Baseline to LOCF
N | 28 | 13 | 41
Mean (SD) | −5.6 (7.5) | 2.2 (8.9) | −3.1 (8.7)
Median (Min-Max) | −4.5 (−22.0 - 5.0) | 1.0 (−5.0 - 29.0) | −2.0 (−22.0 - 29.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.4B Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Group Aspartate Aminotransferase - AST (U/L) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 24.4 (7.2) | 24.5 (7.0) | 24.5 (7.0)
Median (Min-Max) | 25.0 (9.0 - 44.0) | 25.0 (17.0 - 39.0) | 25.0 (9.0 - 44.0)
Week 4
N | 26 | 12 | 38
Mean (SD) | 23.8 (8.4) | 26.9 (8.9) | 24.8 (8.5)
Median (Min-Max) | 22.0 (10.0 - 44.0) | 24.5 (17.0 - 45.0) | 23.5 (10.0 - 45.0)
Week 8
N | 26 | 11 | 37
Mean (SD) | 22.8 (7.4) | 27.1 (10.4) | 24.1 (8.5)
Median (Min-Max) | 22.0 (10.0 - 40.0) | 23.0 (15.0 - 51.0) | 22.0 (10.0 - 51.0)
Week 16
N | 19 | 9 | 28
Mean (SD) | 24.9 (8.4) | 27.6 (14.6) | 25.8 (10.5)
Median (Min-Max) | 23.0 (11.0 - 42.0) | 22.0 (17.0 - 64.0) | 23.0 (11.0 - 64.0)
Week 24
N | 15 | 8 | 23
Mean (SD) | 24.9 (8.2) | 21.6 (6.7) | 23.8 (7.7)
Median (Min-Max) | 24.0 (14.0 - 41.0) | 20.0 (15.0 - 37.0) | 22.0 (14.0 - 41.0)
LOCF
N | 28 | 13 | 41
Mean (SD) | 22.2 (7.2) | 29.5 (26.6) | 24.5 (16.1)
Median (Min-Max) | 22.0 (12.0 - 41.0) | 20.0 (15.0 - 116.0) | 22.0 (12.0 - 116.0)
Change from Baseline to LOCF
N | 28 | 13 | 41
Mean (SD) | −2.3 (5.3) | 5.3 (25.7) | 0.1 (15.1)
Median (Min-Max) | −2.0 (−17.0 - 9.0) | −2.0 (−7.0 - 90.0) | −2.0 (−17.0 - 90.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.5B Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Group Bicarbonate (mEq/L) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 25.6 (2.1) | 25.0 (3.1) | 25.4 (2.5)
Median (Min-Max) | 26.0 (21.0 - 29.0) | 25.0 (18.0 - 29.0) | 26.0 (18.0 - 29.0)
Week 4
N | 26 | 12 | 38
Mean (SD) | 25.6 (2.7) | 25.8 (2.6) | 25.7 (2.6)
Median (Min-Max) | 26.0 (19.0 - 31.0) | 25.5 (21.0 - 30.0) | 26.0 (19.0 - 31.0)
Week 8
N | 27 | 11 | 38
Mean (SD) | 24.9 (2.2) | 25.6 (2.0) | 25.1 (2.2)
Median (Min-Max) | 25.0 (19.0 - 30.0) | 25.0 (22.0 - 29.0) | 25.0 (19.0 - 30.0)
Week 16
N | 19 | 9 | 28
Mean (SD) | 25.2 (2.5) | 26.2 (3.2) | 25.5 (2.7)
Median (Min-Max) | 26.0 (17.0 - 28.0) | 25.0 (23.0 - 32.0) | 25.5 (17.0 - 32.0)
Week 24
N | 15 | 8 | 23
Mean (SD) | 25.5 (2.0) | 26.3 (2.8) | 25.7 (2.2)
Median (Min-Max) | 26.0 (23.0 - 29.0) | 26.0 (23.0 - 32.0) | 26.0 (23.0 - 32.0)
LOCF
N | 28 | 13 | 41
Mean (SD) | 25.5 (2.3) | 26.2 (2.7) | 25.7 (2.4)
Median (Min-Max) | 26.0 (20.0 - 30.0) | 27.0 (22.0 - 32.0) | 26.0 (20.0 - 32.0)
Change from Baseline to LOCF
N | 28 | 13 | 41
Mean (SD) | −0.1 (2.5) | 1.3 (3.0) | 0.4 (2.7)
Median (Min-Max) | 0.0 (−4.0 - 4.0) | 1.0 (−4.0 - 7.0) | 0.0 (−4.0 - 7.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.6B Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Group Direct Bilirubin (mg/dL) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 0.1 (0.0) | 0.1 (0.1) | 0.1 (0.0)
Median (Min-Max) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 0.2)
Week 4
N | 25 | 12 | 37
Mean (SD) | 0.1 (0.1) | 0.1 (0.1) | 0.1 (0.1)
Median (Min-Max) | 0.1 (0.0 - 0.3) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 0.3)
Week 8
N | 27 | 11 | 38
Mean (SD) | 0.1 (0.0) | 0.1 (0.1) | 0.1 (0.0)
Median (Min-Max) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 0.2)
Week 16
N | 19 | 9 | 28
Mean (SD) | 0.1 (0.1) | 0.1 (0.1) | 0.1 (0.1)
Median (Min-Max) | 0.1 (0.0 - 0.3) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 0.3)
Week 24
N | 15 | 8 | 23
Mean (SD) | 0.2 (0.4) | 0.1 (0.1) | 0.2 (0.3)
Median (Min-Max) | 0.1 (0.0 - 1.7) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 1.7)
LOCF
N | 28 | 13 | 41
Mean (SD) | 0.2 (0.3) | 0.1 (0.1) | 0.1 (0.3)
Median (Min-Max) | 0.1 (0.0 - 1.7) | 0.1 (0.0 - 0.2) | 0.1 (0.0 - 1.7)
Change from Baseline to LOCF
N | 28 | 13 | 41
Mean (SD) | 0.1 (0.3) | 0.0 (0.0) | 0.0 (0.3)
Median (Min-Max) | 0.0 (−0.1 - 1.6) | 0.0 (0.0 - 0.1) | 0.0 (−0.1 - 1.6)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.7B Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Group Total Bilirubin (mg/dL) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 0.5 (0.2) | 0.5 (0.2) | 0.5 (0.2)
Median (Min-Max) | 0.5 (0.2 - 1.3) | 0.4 (0.2 - 0.8) | 0.5 (0.2 - 1.3)
Week 4
N | 26 | 12 | 38
Mean (SD) | 0.4 (0.3) | 0.4 (0.2) | 0.4 (0.3)
Median (Min-Max) | 0.3 (0.1 - 1.4) | 0.3 (0.2 - 0.8) | 0.3 (0.1 - 1.4)
Week 8
N | 26 | 11 | 37
Mean (SD) | 0.4 (0.3) | 0.4 (0.2) | 0.4 (0.2)
Median (Min-Max) | 0.3 (0.2 - 1.2) | 0.3 (0.1 - 0.9) | 0.3 (0.1 - 1.2)
Week 16
N | 19 | 9 | 28
Mean (SD) | 0.5 (0.4) | 0.4 (0.1) | 0.4 (0.3)
Median (Min-Max) | 0.3 (0.1 - 1.4) | 0.4 (0.2 - 0.6) | 0.3 (0.1 - 1.4)
Week 24
N | 15 | 8 | 23
Mean (SD) | 0.4 (0.2) | 0.4 (0.2) | 0.4 (0.2)
Median (Min-Max) | 0.4 (0.0 - 1.1) | 0.4 (0.1 - 0.7) | 0.4 (0.0 - 1.1)
LOCF
N | 28 | 13 | 41
Mean (SD) | 0.4 (0.2) | 0.3 (0.2) | 0.4 (0.2)
Median (Min-Max) | 0.3 (0.0 - 1.1) | 0.3 (0.1 - 0.7) | 0.3 (0.0 - 1.1)
Change from Baseline to LOCF
N | 28 | 13 | 41
Mean (SD) | −0.2 (0.2) | −0.1 (0.2) | −0.1 (0.2)
Median (Min-Max) | −0.1 (−0.9 - 0.2) | −0.1 (−0.4 - 0.1) | −0.1 (−0.9 - 0.2)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.8B Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Group Calcium (mg/dL) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 9.8 (0.4) | 9.5 (0.5) | 9.7 (0.4)
Median (Min-Max) | 9.8 (8.9 - 10.5) | 9.6 (8.8 - 10.1) | 9.8 (8.8 - 10.5)
Week 4
N | 26 | 12 | 38
Mean (SD) | 9.7 (0.4) | 9.7 (0.2) | 9.7 (0.4)
Median (Min-Max) | 9.8 (8.7 - 10.3) | 9.7 (9.4 - 10.2) | 9.7 (8.7 - 10.3)
Week 8
N | 26 | 11 | 37
Mean (SD) | 9.8 (0.3) | 9.6 (0.2) | 9.7 (0.3)
Median (Min-Max) | 9.9 (8.9 - 10.4) | 9.7 (9.2 - 9.9) | 9.8 (8.9 - 10.4)
Week 16
N | 19 | 9 | 28
Mean (SD) | 9.8 (0.4) | 9.7 (0.3) | 9.8 (0.3)
Median (Min-Max) | 9.8 (9.2 - 10.3) | 9.7 (9.3 - 10.2) | 9.8 (9.2 - 10.3)
Week 24
N | 15 | 8 | 23
Mean (SD) | 9.8 (0.3) | 9.7 (0.6) | 9.8 (0.4)
Median (Min-Max) | 9.8 (9.3 - 10.3) | 9.8 (8.6 - 10.3) | 9.8 (8.6 - 10.3)
LOCF
N | 28 | 13 | 41
Mean (SD) | 9.7 (0.4) | 9.7 (0.5) | 9.7 (0.4)
Median (Min-Max) | 9.8 (8.7 - 10.4) | 9.7 (8.6 - 10.3) | 9.8 (8.6 - 10.4)
Change from Baseline to LOCF
N | 28 | 13 | 41
Mean (SD) | 0.0 (0.4) | 0.2 (0.3) | 0.0 (0.4)
Median (Min-Max) | 0.0 (−1.2 - 0.6) | 0.2 (−0.5 - 0.6) | 0.0 (−1.2 - 0.6)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.9B Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Group Chloride (mEq/L) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 103.5 (2.1) | 103.4 (2.4) | 103.5 (2.2)
Median (Min-Max) | 104.0 (99.0 - 108.0) | 104.0 (99.0 - 106.0) | 104.0 (99.0 - 108.0)
Week 4
N | 26 | 12 | 38
Mean (SD) | 103.9 (2.5) | 103.3 (2.6) | 103.7 (2.5)
Median (Min-Max) | 104.0 (97.0 - 108.0) | 103.0 (100.0 - 108.0) | 103.5 (97.0 - 108.0)
Week 8
N | 27 | 11 | 38
Mean (SD) | 104.2 (2.1) | 103.5 (2.0) | 104.0 (2.1)
Median (Min-Max) | 105.0 (100.0 - 109.0) | 103.0 (100.0 - 106.0) | 104.0 (100.0 - 109.0)
Week 16
N | 19 | 9 | 28
Mean (SD) | 104.6 (2.5) | 103.1 (2.9) | 104.1 (2.6)
Median (Min-Max) | 104.0 (102.0 - 111.0) | 104.0 (98.0 - 107.0) | 104.0 (98.0 - 111.0)
Week 24
N | 15 | 8 | 23
Mean (SD) | 105.1 (2.3) | 104.8 (2.7) | 105.0 (2.4)
Median (Min-Max) | 105.0 (100.0 - 109.0) | 106.0 (101.0 - 108.0) | 106.0 (100.0 - 109.0)
LOCF
N | 28 | 13 | 41
Mean (SD) | 104.7 (2.1) | 103.8 (2.7) | 104.4 (2.3)
Median (Min-Max) | 105.0 (100.0 - 109.0) | 104.0 (100.0 - 108.0) | 105.0 (100.0 - 109.0)
Change from Baseline to LOCF
N | 28 | 13 | 41
Mean (SD) | 1.2 (2.5) | 0.5 (3.0) | 1.0 (2.7)
Median (Min-Max) | 1.5 (−5.0 - 5.0) | 1.0 (−5.0 - 5.0) | 1.0 (−5.0 - 5.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.10B Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Group Cholesterol (mg/dL) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 170.7 (31.3) | 163.9 (19.6) | 168.4 (27.8)
Median (Min-Max) | 164.0 (123.0 - 248.0) | 165.0 (134.0 - 202.0) | 164.5 (123.0 - 248.0)
Week 4
N | 25 | 12 | 37
Mean (SD) | 167.2 (15.4) | 163.8 (21.6) | 166.1 (17.4)
Median (Min-Max) | 166.0 (142.0 - 196.0) | 161.5 (135.0 - 208.0) | 166.0 (135.0 - 208.0)
Week 8
N | 27 | 11 | 38
Mean (SD) | 170.9 (25.1) | 148.6 (20.0) | 164.4 (25.6)
Median (Min-Max) | 166.0 (129.0 - 230.0) | 151.0 (108.0 - 184.0) | 162.0 (108.0 - 230.0)
Week 16
N | 19 | 9 | 28
Mean (SD) | 181.8 (32.0) | 147.6 (19.2) | 170.8 (32.5)
Median (Min-Max) | 195.0 (140.0 - 242.0) | 154.0 (120.0 - 176.0) | 160.5 (120.0 - 242.0)
Week 24
N | 15 | 8 | 23
Mean (SD) | 178.3 (34.2) | 151.1 (33.6) | 168.8 (35.7)
Median (Min-Max) | 181.0 (126.0 - 264.0) | 154.5 (108.0 - 198.0) | 171.0 (108.0 - 264.0)
LOCF
N | 28 | 13 | 41
Mean (SD) | 174.4 (29.0) | 159.4 (34.0) | 169.6 (31.0)
Median (Min-Max) | 174.0 (126.0 - 264.0) | 161.0 (108.0 - 229.0) | 171.0 (108.0 - 264.0)
Change from Baseline to LOCF
N | 28 | 13 | 41
Mean (SD) | 2.0 (26.2) | −4.4 (22.8) | 0.0 (25.1)
Median (Min-Max) | 3.5 (−59.0 - 52.0) | −6.0 (−39.0 - 27.0) | 0.0 (−59.0 - 52.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.11B Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Group Creatine kinase (U/L) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 106.3 (63.6) | 201.7 (217.7) | 138.8 (142.0)
Median (Min-Max) | 85.0 (28.0 - 300.0) | 139.0 (51.0 - 947.0) | 106.0 (28.0 - 947.0)
Week 4
N | 24 | 11 | 35
Mean (SD) | 132.8 (86.3) | 160.0 (83.2) | 141.3 (85.1)
Median (Min-Max) | 96.0 (25.0 - 337.0) | 138.0 (61.0 - 295.0) | 116.0 (25.0 - 337.0)
Week 8
N | 27 | 11 | 38
Mean (SD) | 115.7 (69.7) | 140.2 (78.7) | 122.8 (72.2)
Median (Min-Max) | 105.0 (25.0 - 370.0) | 119.0 (63.0 - 319.0) | 107.0 (25.0 - 370.0)
Week 16
N | 19 | 9 | 28
Mean (SD) | 110.1 (97.9) | 107.1 (41.1) | 109.1 (83.1)
Median (Min-Max) | 88.0 (49.0 - 494.0) | 112.0 (55.0 - 162.0) | 89.5 (49.0 - 494.0)
Week 24
N | 15 | 8 | 23
Mean (SD) | 101.7 (61.2) | 94.0 (45.7) | 99.0 (55.4)
Median (Min-Max) | 83.0 (45.0 - 288.0) | 82.0 (45.0 - 162.0) | 83.0 (45.0 - 288.0)
LOCF
N | 28 | 12 | 40
Mean (SD) | 112.2 (78.2) | 111.3 (54.9) | 111.9 (71.3)
Median (Min-Max) | 82.0 (25.0 - 320.0) | 97.5 (45.0 - 198.0) | 84.5 (25.0 - 320.0)
Change from Baseline to LOCF
N | 28 | 12 | 40
Mean (SD) | 6.0 (49.0) | −27.8 (36.8) | −4.1 (47.9)
Median (Min-Max) | −1.5 (−105 - 141.0) | −19.5 (−102 - 17.0) | −3.5 (−105 - 141.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.12B Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Group Creatinine (mg/dL) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 0.6 (0.1) | 0.6 (0.2) | 0.6 (0.1)
Median (Min-Max) | 0.6 (0.4 - 1.1) | 0.6 (0.4 - 0.9) | 0.6 (0.4 - 1.1)
Week 4
N | 26 | 12 | 38
Mean (SD) | 0.6 (0.2) | 0.7 (0.1) | 0.6 (0.1)
Median (Min-Max) | 0.6 (0.4 - 1.0) | 0.7 (0.6 - 0.9) | 0.6 (0.4 - 1.0)
Week 8
N | 26 | 11 | 37
Mean (SD) | 0.6 (0.2) | 0.7 (0.1) | 0.6 (0.1)
Median (Min-Max) | 0.6 (0.4 - 1.1) | 0.6 (0.5 - 0.9) | 0.6 (0.4 - 1.1)
Week 16
N | 19 | 9 | 28
Mean (SD) | 0.6 (0.2) | 0.7 (0.1) | 0.6 (0.2)
Median (Min-Max) | 0.6 (0.3 - 1.0) | 0.6 (0.5 - 0.9) | 0.6 (0.3 - 1.0)
Week 24
N | 15 | 8 | 23
Mean (SD) | 0.6 (0.1) | 0.7 (0.2) | 0.6 (0.1)
Median (Min-Max) | 0.6 (0.5 - 1.0) | 0.6 (0.5 - 1.0) | 0.6 (0.5 - 1.0)
LOCF
N | 28 | 13 | 41
Mean (SD) | 0.6 (0.1) | 0.7 (0.2) | 0.6 (0.1)
Median (Min-Max) | 0.6 (0.5 - 1.0) | 0.6 (0.4 - 1.0) | 0.6 (0.4 - 1.0)
Change from Baseline to LOCF
N | 28 | 13 | 41
Mean (SD) | 0.0 (0.1) | 0.1 (0.1) | 0.0 (0.1)
Median (Min-Max) | 0.0 (−0.2 - 0.3) | 0.1 (−0.1 - 0.2) | 0.0 (−0.2 - 0.3)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.13B Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Group Gamma-glutamyl Transpeptidase - GGT (U/L) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 21.4 (12.4) | 19.4 (10.8) | 20.7 (11.8)
Median (Min-Max) | 18.0 (8.0 - 66.0) | 16.0 (8.0 - 42.0) | 18.0 (8.0 - 66.0)
Week 4
N | 25 | 12 | 37
Mean (SD) | 19.3 (9.6) | 17.8 (10.2) | 18.8 (9.7)
Median (Min-Max) | 16.0 (10.0 - 49.0) | 13.5 (8.0 - 39.0) | 15.0 (8.0 - 49.0)
Week 8
N | 26 | 11 | 37
Mean (SD) | 19.7 (10.0) | 16.0 (9.0) | 18.6 (9.7)
Median (Min-Max) | 16.5 (9.0 - 51.0) | 13.0 (9.0 - 40.0) | 15.0 (9.0 - 51.0)
Week 16
N | 19 | 9 | 28
Mean (SD) | 20.5 (11.3) | 12.6 (4.5) | 18.0 (10.3)
Median (Min-Max) | 18.0 (10.0 - 54.0) | 12.0 (6.0 - 21.0) | 15.0 (6.0 - 54.0)
Week 24
N | 15 | 8 | 23
Mean (SD) | 20.9 (12.2) | 13.4 (4.5) | 18.3 (10.7)
Median (Min-Max) | 21.0 (10.0 - 59.0) | 12.0 (8.0 - 22.0) | 13.0 (8.0 - 59.0)
LOCF
N | 27 | 13 | 40
Mean (SD) | 20.0 (9.6) | 17.2 (10.4) | 19.1 (9.8)
Median (Min-Max) | 19.0 (10.0 - 59.0) | 13.0 (7.0 - 41.0) | 17.5 (7.0 - 59.0)
Change from Baseline to LOCF
N | 27 | 13 | 40
Mean (SD) | −2.3 (6.3) | −1.8 (3.2) | −2.1 (5.5)
Median (Min-Max) | −1.0 (−18.0 - 8.0) | −1.0 (−7.0 - 3.0) | −1.0 (−18.0 - 8.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.14B Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Group Glucose (mg/dL) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 83.5 (9.7) | 80.2 (14.4) | 82.4 (11.4)
Median (Min-Max) | 85.0 (55.0 - 98.0) | 80.0 (45.0 - 118.0) | 82.0 (45.0 - 118.0)
Week 4
N | 26 | 12 | 38
Mean (SD) | 90.8 (18.4) | 77.0 (11.0) | 86.4 (17.5)
Median (Min-Max) | 87.5 (52.0 - 145.0) | 76.5 (55.0 - 94.0) | 85.0 (52.0 - 145.0)
Week 8
N | 26 | 11 | 37
Mean (SD) | 87.5 (21.8) | 91.5 (16.8) | 88.7 (20.3)
Median (Min-Max) | 83.0 (69.0 - 156.0) | 91.0 (64.0 - 122.0) | 83.0 (64.0 - 156.0)
Week 16
N | 19 | 9 | 28
Mean (SD) | 83.9 (13.4) | 82.8 (15.0) | 83.5 (13.7)
Median (Min-Max) | 84.0 (57.0 - 103.0) | 85.0 (49.0 - 103.0) | 84.5 (49.0 - 103.0)
Week 24
N | 15 | 8 | 23
Mean (SD) | 83.4 (11.0) | 88.4 (6.8) | 85.1 (9.9)
Median (Min-Max) | 85.0 (67.0 - 99.0) | 86.0 (82.0 - 103.0) | 85.0 (67.0 - 103.0)
LOCF
N | 28 | 13 | 41
Mean (SD) | 84.8 (10.9) | 88.5 (9.1) | 86.0 (10.4)
Median (Min-Max) | 86.0 (63.0 - 99.0) | 87.0 (74.0 - 104.0) | 86.0 (63.0 - 104.0)
Change from Baseline to LOCF
N | 28 | 13 | 41
Mean (SD) | 1.3 (11.7) | 11.3 (15.7) | 4.5 (13.7)
Median (Min-Max) | 0.0 (−23.0 - 21.0) | 9.0 (−10.0 - 52.0) | 4.0 (−23.0 - 52.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.15B Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Group High-Density Lipoprotein - HDL (mg/dL) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 51.4 (15.0) | 58.4 (17.7) | 53.8 (16.1)
Median (Min-Max) | 48.0 (32.0 - 113.0) | 57.0 (23.0 - 85.0) | 50.5 (23.0 - 113.0)
Week 4
N | 24 | 12 | 36
Mean (SD) | 49.8 (14.0) | 55.8 (15.1) | 51.8 (14.5)
Median (Min-Max) | 46.5 (25.0 - 82.0) | 58.0 (34.0 - 85.0) | 47.0 (25.0 - 85.0)
Week 8
N | 27 | 11 | 38
Mean (SD) | 52.0 (13.9) | 52.1 (15.8) | 52.1 (14.3)
Median (Min-Max) | 50.0 (32.0 - 79.0) | 49.0 (34.0 - 80.0) | 50.0 (32.0 - 80.0)
Week 16
N | 19 | 9 | 28
Mean (SD) | 52.6 (15.8) | 52.8 (13.1) | 52.7 (14.7)
Median (Min-Max) | 46.0 (33.0 - 91.0) | 52.0 (33.0 - 74.0) | 47.0 (33.0 - 91.0)
Week 24
N | 15 | 8 | 23
Mean (SD) | 52.1 (13.0) | 54.8 (16.3) | 53.0 (13.9)
Median (Min-Max) | 51.0 (34.0 - 80.0) | 55.5 (31.0 - 77.0) | 54.0 (31.0 - 80.0)
LOCF
N | 28 | 13 | 41
Mean (SD) | 52.2 (12.3) | 51.5 (13.3) | 52.0 (12.4)
Median (Min-Max) | 51.0 (34.0 - 80.0) | 51.0 (31.0 - 77.0) | 51.0 (31.0 - 80.0)
Change from Baseline to LOCF
N | 28 | 13 | 41
Mean (SD) | 0.8 (9.6) | −7.5 (11.2) | −1.8 (10.7)
Median (Min-Max) | 2.0 (−33.0 - 20.0) | −7.0 (−30.0 - 11.0) | −1.0 (−33.0 - 20.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.16B Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Group Cholesterol/HDL Ratio Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 3.5 (0.9) | 3.2 (1.5) | 3.4 (1.1)
Median (Min-Max) | 3.3 (1.9 - 5.9) | 2.9 (1.7 - 7.5) | 3.1 (1.7 - 7.5)
Week 4
N | 24 | 12 | 36
Mean (SD) | 3.6 (1.2) | 3.2 (1.1) | 3.5 (1.2)
Median (Min-Max) | 3.5 (2.0 - 7.4) | 2.8 (2.0 - 5.3) | 3.4 (2.0 - 7.4)
Week 8
N | 27 | 11 | 38
Mean (SD) | 3.5 (1.1) | 3.1 (1.1) | 3.4 (1.1)
Median (Min-Max) | 3.1 (2.0 - 6.0) | 2.9 (1.8 - 5.3) | 3.1 (1.8 - 6.0)
Week 16
N | 19 | 9 | 28
Mean (SD) | 3.6 (0.9) | 3.0 (1.1) | 3.4 (1.0)
Median (Min-Max) | 3.2 (2.3 - 5.6) | 2.7 (1.6 - 4.8) | 3.2 (1.6 - 5.6)
Week 24
N | 15 | 8 | 23
Mean (SD) | 3.6 (1.0) | 3.1 (1.4) | 3.4 (1.1)
Median (Min-Max) | 3.4 (2.2 - 5.4) | 2.8 (1.5 - 5.2) | 3.1 (1.5 - 5.4)
LOCF
N | 28 | 13 | 41
Mean (SD) | 3.5 (0.9) | 3.3 (1.2) | 3.4 (1.0)
Median (Min-Max) | 3.3 (2.0 - 5.4) | 3.1 (1.5 - 5.2) | 3.2 (1.5 - 5.4)
Change from Baseline to LOCF
N | 28 | 13 | 41
Mean (SD) | 0.0 (0.5) | 0.3 (0.4) | 0.1 (0.5)
Median (Min-Max) | −0.1 (−1.0 - 1.3) | 0.4 (−0.4 - 0.9) | 0.0 (−1.0 - 1.3)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.17B Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Group Low-Density Lipoprotein - LDL (mg/dL) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 99.5 (27.5) | 93.3 (26.4) | 97.4 (27.0)
Median (Min-Max) | 94.0 (56.0 - 181.0) | 96.0 (45.0 - 133.0) | 94.5 (45.0 - 181.0)
Week 4
N | 24 | 12 | 36
Mean (SD) | 92.5 (22.8) | 88.2 (23.7) | 91.1 (22.9)
Median (Min-Max) | 96.0 (56.0 - 139.0) | 81.5 (54.0 - 130.0) | 93.0 (54.0 - 139.0)
Week 8
N | 27 | 11 | 38
Mean (SD) | 92.6 (27.4) | 76.9 (21.9) | 88.0 (26.6)
Median (Min-Max) | 92.0 (53.0 - 165.0) | 79.0 (50.0 - 124.0) | 85.5 (50.0 - 165.0)
Week 16
N | 19 | 9 | 28
Mean (SD) | 107.3 (24.4) | 79.6 (19.9) | 98.4 (26.2)
Median (Min-Max) | 109.0 (64.0 - 160.0) | 79.0 (48.0 - 108.0) | 100.0 (48.0 - 160.0)
Week 24
N | 15 | 8 | 23
Mean (SD) | 105.5 (21.1) | 89.4 (31.4) | 99.9 (25.7)
Median (Min-Max) | 106.0 (70.0 - 134.0) | 95.5 (53.0 - 127.0) | 106.0 (53.0 - 134.0)
LOCF
N | 28 | 13 | 41
Mean (SD) | 103.1 (20.1) | 94.3 (27.3) | 100.3 (22.7)
Median (Min-Max) | 102.5 (70.0 - 136.0) | 100.0 (53.0 - 135.0) | 100.0 (53.0 - 136.0)
Change from Baseline to LOCF
N | 28 | 13 | 41
Mean (SD) | 2.3 (20.5) | 1.2 (10.4) | 1.9 (17.8)
Median (Min-Max) | 2.5 (−49.0 - 37.0) | 1.0 (−16.0 - 18.0) | 1.0 (−49.0 - 37.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.18B Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Group Magnesium (mg/dL) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 2.3 (0.3) | 2.0 (0.1) | 2.2 (0.3)
Median (Min-Max) | 2.3 (1.8 - 2.9) | 2.0 (1.9 - 2.2) | 2.2 (1.8 - 2.9)
Week 4
N | 24 | 12 | 36
Mean (SD) | 2.3 (0.2) | 2.4 (0.2) | 2.3 (0.2)
Median (Min-Max) | 2.3 (1.9 - 2.7) | 2.4 (2.1 - 2.8) | 2.3 (1.9 - 2.8)
Week 8
N | 27 | 11 | 38
Mean (SD) | 2.3 (0.2) | 2.2 (0.1) | 2.3 (0.2)
Median (Min-Max) | 2.3 (1.8 - 2.8) | 2.3 (2.0 - 2.4) | 2.3 (1.8 - 2.8)
Week 16
N | 19 | 9 | 28
Mean (SD) | 2.3 (0.2) | 2.3 (0.1) | 2.3 (0.2)
Median (Min-Max) | 2.3 (2.0 - 3.0) | 2.3 (2.1 - 2.5) | 2.3 (2.0 - 3.0)
Week 24
N | 15 | 8 | 23
Mean (SD) | 2.2 (0.3) | 2.2 (0.2) | 2.2 (0.2)
Median (Min-Max) | 2.2 (1.9 - 2.8) | 2.2 (1.8 - 2.3) | 2.2 (1.8 - 2.8)
LOCF
N | 28 | 13 | 41
Mean (SD) | 2.2 (0.2) | 2.2 (0.2) | 2.2 (0.2)
Median (Min-Max) | 2.2 (1.9 - 2.8) | 2.2 (1.8 - 2.5) | 2.2 (1.8 - 2.8)
Change from Baseline to LOCF
N | 28 | 13 | 41
Mean (SD) | −0.1 (0.2) | 0.1 (0.2) | −0.1 (0.2)
Median (Min-Max) | −0.1 (−0.7 - 0.3) | 0.2 (−0.1 - 0.4) | 0.0 (−0.7 - 0.4)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.19B Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Group Phosphorus (mg/dL) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 4.7 (0.7) | 4.4 (0.4) | 4.6 (0.6)
Median (Min-Max) | 4.5 (3.3 - 6.7) | 4.3 (3.8 - 5.3) | 4.5 (3.3 - 6.7)
Week 4
N | 23 | 12 | 35
Mean (SD) | 4.9 (0.7) | 4.7 (0.7) | 4.8 (0.7)
Median (Min-Max) | 4.8 (3.4 - 5.9) | 4.5 (3.6 - 5.7) | 4.8 (3.4 - 5.9)
Week 8
N | 27 | 11 | 38
Mean (SD) | 4.8 (0.6) | 4.5 (0.4) | 4.7 (0.6)
Median (Min-Max) | 4.7 (3.7 - 6.2) | 4.5 (3.9 - 5.4) | 4.6 (3.7 - 6.2)
Week 16
N | 19 | 9 | 28
Mean (SD) | 4.9 (0.9) | 4.6 (0.6) | 4.8 (0.8)
Median (Min-Max) | 5.0 (2.9 - 6.4) | 4.5 (3.6 - 5.6) | 4.8 (2.9 - 6.4)
Week 24
N | 15 | 8 | 23
Mean (SD) | 4.8 (0.8) | 4.3 (0.7) | 4.6 (0.8)
Median (Min-Max) | 4.6 (3.6 - 6.4) | 4.2 (3.4 - 5.6) | 4.4 (3.4 - 6.4)
LOCF
N | 28 | 13 | 41
Mean (SD) | 4.7 (0.8) | 4.4 (0.7) | 4.6 (0.8)
Median (Min-Max) | 4.6 (2.8 - 6.4) | 4.3 (3.4 - 5.6) | 4.6 (2.8 - 6.4)
Change from Baseline to LOCF
N | 28 | 13 | 41
Mean (SD) | 0.0 (0.5) | 0.0 (0.4) | 0.0 (0.5)
Median (Min-Max) | 0.0 (−1.5 - 0.9) | −0.1 (−0.5 - 0.8) | 0.0 (−1.5 - 0.9)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.20B Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Group Potassium (mEq/L) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 4.3 (0.3) | 4.2 (0.4) | 4.2 (0.4)
Median (Min-Max) | 4.2 (3.5 - 5.1) | 4.1 (3.7 - 5.3) | 4.2 (3.5 - 5.3)
Week 4
N | 26 | 12 | 38
Mean (SD) | 4.2 (0.3) | 4.2 (0.4) | 4.2 (0.3)
Median (Min-Max) | 4.2 (3.4 - 4.8) | 4.2 (3.3 - 4.8) | 4.2 (3.3 - 4.8)
Week 8
N | 27 | 11 | 38
Mean (SD) | 4.3 (0.4) | 4.1 (0.2) | 4.2 (0.4)
Median (Min-Max) | 4.2 (3.8 - 5.2) | 4.0 (3.6 - 4.5) | 4.2 (3.6 - 5.2)
Week 16
N | 19 | 9 | 28
Mean (SD) | 4.3 (0.4) | 4.1 (0.4) | 4.2 (0.4)
Median (Min-Max) | 4.3 (3.4 - 5.1) | 4.2 (3.4 - 4.5) | 4.3 (3.4 - 5.1)
Week 24
N | 15 | 8 | 23
Mean (SD) | 4.3 (0.3) | 4.1 (0.3) | 4.2 (0.3)
Median (Min-Max) | 4.2 (3.7 - 4.7) | 4.1 (3.6 - 4.5) | 4.2 (3.6 - 4.7)
LOCF
N | 28 | 13 | 41
Mean (SD) | 4.3 (0.2) | 4.2 (0.3) | 4.2 (0.2)
Median (Min-Max) | 4.2 (3.7 - 4.7) | 4.1 (3.6 - 4.6) | 4.2 (3.6 - 4.7)
Change from Baseline to LOCF
N | 28 | 13 | 41
Mean (SD) | 0.0 (0.3) | 0.0 (0.3) | 0.0 (0.3)
Median (Min-Max) | 0.0 (−0.7 - 0.3) | 0.0 (−0.7 - 0.3) | 0.0 (−0.7 - 0.3)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.21B Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Group Total Protein (g/dL) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 7.3 (0.4) | 7.3 (0.4) | 7.3 (0.4)
Median (Min-Max) | 7.3 (6.5 - 8.0) | 7.3 (6.6 - 8.2) | 7.3 (6.5 - 8.2)
Week 4
N | 29 | 15 | 44
Mean (SD) | 7.3 (0.4) | 7.3 (0.4) | 7.3 (0.4)
Median (Min-Max) | 7.3 (6.5 - 8.0) | 7.3 (6.6 - 8.2) | 7.3 (6.5 - 8.2)
Week 8
N | 29 | 15 | 44
Mean (SD) | 7.3 (0.4) | 7.3 (0.4) | 7.3 (0.4)
Median (Min-Max) | 7.3 (6.5 - 8.0) | 7.3 (6.6 - 8.2) | 7.3 (6.5 - 8.2)
Week 16
N | 29 | 15 | 44
Mean (SD) | 7.3 (0.4) | 7.3 (0.4) | 7.3 (0.4)
Median (Min-Max) | 7.3 (6.5 - 8.0) | 7.3 (6.6 - 8.2) | 7.3 (6.5 - 8.2)
Week 24
N | 29 | 15 | 44
Mean (SD) | 7.3 (0.4) | 7.3 (0.4) | 7.3 (0.4)
Median (Min-Max) | 7.3 (6.5 - 8.0) | 7.3 (6.6 - 8.2) | 7.3 (6.5 - 8.2)
LOCF
N | 29 | 15 | 44
Mean (SD) | 7.3 (0.4) | 7.3 (0.4) | 7.3 (0.4)
Median (Min-Max) | 7.3 (6.5 - 8.0) | 7.3 (6.6 - 8.2) | 7.3 (6.5 - 8.2)
Change from Baseline to LOCF
N | 27 | 13 | 40
Mean (SD) | 0.0 (0.5) | 0.1 (0.5) | 0.0 (0.5)
Median (Min-Max) | −0.1 (−1.0 - 0.8) | 0.2 (−0.5 - 1.1) | −0.1 (−1.0 - 1.1)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.22B Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Group Sodium (mEq/L) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 138.0 (2.6) | 138.7 (2.2) | 138.2 (2.5)
Median (Min-Max) | 138.0 (132.0 - 143.0) | 139.0 (134.0 - 142.0) | 138.0 (132.0 - 143.0)
Week 4
N | 26 | 12 | 38
Mean (SD) | 138.4 (3.0) | 138.8 (2.0) | 138.5 (2.7)
Median (Min-Max) | 138.5 (133.0 - 143.0) | 139.0 (136.0 - 143.0) | 139.0 (133.0 - 143.0)
Week 8
N | 27 | 11 | 38
Mean (SD) | 139.3 (2.5) | 138.3 (1.4) | 139.0 (2.3)
Median (Min-Max) | 139.0 (134.0 - 144.0) | 139.0 (136.0 - 140.0) | 139.0 (134.0 - 144.0)
Week 16
N | 19 | 9 | 28
Mean (SD) | 138.9 (2.7) | 138.2 (3.7) | 138.7 (3.0)
Median (Min-Max) | 139.0 (133.0 - 144.0) | 139.0 (133.0 - 143.0) | 139.0 (133.0 - 144.0)
Week 24
N | 15 | 8 | 23
Mean (SD) | 139.1 (2.6) | 138.5 (3.0) | 138.9 (2.7)
Median (Min-Max) | 139.0 (133.0 - 143.0) | 139.5 (133.0 - 141.0) | 139.0 (133.0 - 143.0)
LOCF
N | 28 | 13 | 41
Mean (SD) | 139.5 (2.4) | 138.4 (2.9) | 139.1 (2.6)
Median (Min-Max) | 139.5 (133.0 - 144.0) | 139.0 (133.0 - 141.0) | 139.0 (133.0 - 144.0)
Change from Baseline to LOCF
N | 28 | 13 | 41
Mean (SD) | 1.4 (2.6) | −0.3 (2.5) | 0.9 (2.6)
Median (Min-Max) | 1.5 (−2.0 - 7.0) | −1.0 (−5.0 - 3.0) | 1.0 (−5.0 - 7.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.23B Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Group Triglycerides (mg/dL) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 109.0 (62.9) | 68.7 (37.8) | 95.3 (58.4)
Median (Min-Max) | 99.0 (14.0 - 269.0) | 51.0 (25.0 - 140.0) | 75.0 (14.0 - 269.0)
Week 4
N | 24 | 12 | 36
Mean (SD) | 142.3 (85.1) | 112.8 (51.0) | 132.5 (76.0)
Median (Min-Max) | 123.0 (52.0 - 420.0) | 113.0 (48.0 - 198.0) | 118.5 (48.0 - 420.0)
Week 8
N | 27 | 11 | 38
Mean (SD) | 146.8 (98.4) | 114.5 (47.3) | 137.5 (87.4)
Median (Min-Max) | 115.0 (33.0 - 365.0) | 105.0 (44.0 - 185.0) | 109.5 (33.0 - 365.0)
Week 16
N | 19 | 9 | 28
Mean (SD) | 130.0 (69.8) | 121.9 (68.1) | 127.4 (68.1)
Median (Min-Max) | 117.0 (27.0 - 282.0) | 115.0 (37.0 - 231.0) | 116.0 (27.0 - 282.0)
Week 24
N | 15 | 8 | 23
Mean (SD) | 119.9 (101.4) | 63.8 (34.0) | 100.3 (87.5)
Median (Min-Max) | 78.0 (33.0 - 383.0) | 58.0 (18.0 - 114.0) | 73.0 (18.0 - 383.0)
LOCF
N | 28 | 13 | 41
Mean (SD) | 108.9 (83.5) | 84.2 (53.8) | 101.0 (75.5)
Median (Min-Max) | 78.5 (33.0 - 383.0) | 76.0 (18.0 - 230.0) | 78.0 (18.0 - 383.0)
Change from Baseline to LOCF
N | 28 | 13 | 41
Mean (SD) | −3.5 (59.9) | 17.2 (40.8) | 3.1 (54.9)
Median (Min-Max) | −2.0 (−105 - 146.0) | 6.0 (−39.0 - 90.0) | 3.0 (−105 - 146.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.24B Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Group Urea Nitrogen (mg/dL) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 9.4 (2.6) | 12.1 (2.9) | 10.4 (2.9)
Median (Min-Max) | 10.0 (6.0 - 14.0) | 12.0 (6.0 - 18.0) | 11.0 (6.0 - 18.0)
Week 4
N | 26 | 12 | 38
Mean (SD) | 10.0 (2.5) | 12.3 (2.9) | 10.7 (2.8)
Median (Min-Max) | 10.0 (5.0 - 15.0) | 13.0 (6.0 - 17.0) | 11.0 (5.0 - 17.0)
Week 8
N | 26 | 11 | 37
Mean (SD) | 11.1 (4.7) | 11.0 (3.2) | 11.1 (4.2)
Median (Min-Max) | 10.0 (4.0 - 21.0) | 11.0 (5.0 - 16.0) | 10.0 (4.0 - 21.0)
Week 16
N | 19 | 9 | 28
Mean (SD) | 10.3 (4.2) | 12.8 (2.0) | 11.1 (3.8)
Median (Min-Max) | 10.0 (3.0 - 18.0) | 13.0 (10.0 - 16.0) | 12.0 (3.0 - 18.0)
Week 24
N | 15 | 8 | 23
Mean (SD) | 10.3 (4.1) | 11.1 (2.9) | 10.6 (3.7)
Median (Min-Max) | 11.0 (2.0 - 17.0) | 11.0 (8.0 - 16.0) | 11.0 (2.0 - 17.0)
LOCF
N | 28 | 13 | 41
Mean (SD) | 10.6 (3.7) | 11.3 (2.8) | 10.9 (3.4)
Median (Min-Max) | 11.0 (2.0 - 17.0) | 11.0 (8.0 - 16.0) | 11.0 (2.0 - 17.0)
Change from Baseline to LOCF
N | 28 | 13 | 41
Mean (SD) | 1.1 (3.3) | −1.5 (3.1) | 0.3 (3.4)
Median (Min-Max) | 1.0 (−8.0 - 9.0) | −2.0 (−6.0 - 5.0) | 0.0 (−8.0 - 9.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.25B Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Group Uric Acid (mg/dL) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 5.1 (1.5) | 4.2 (1.1) | 4.8 (1.4)
Median (Min-Max) | 4.8 (2.3 - 9.3) | 4.2 (2.3 - 6.6) | 4.7 (2.3 - 9.3)
Week 4
N | 24 | 12 | 36
Mean (SD) | 5.2 (1.6) | 5.2 (1.2) | 5.2 (1.5)
Median (Min-Max) | 5.1 (2.5 - 9.2) | 5.3 (3.1 - 7.1) | 5.1 (2.5 - 9.2)
Week 8
N | 26 | 11 | 37
Mean (SD) | 5.1 (1.7) | 5.3 (1.3) | 5.2 (1.6)
Median (Min-Max) | 5.2 (2.5 - 10.1) | 5.3 (3.0 - 7.6) | 5.3 (2.5 - 10.1)
Week 16
N | 19 | 9 | 28
Mean (SD) | 5.3 (1.6) | 5.0 (1.2) | 5.2 (1.5)
Median (Min-Max) | 5.1 (2.3 - 8.1) | 4.8 (3.0 - 7.5) | 5.1 (2.3 - 8.1)
Week 24
N | 15 | 8 | 23
Mean (SD) | 5.8 (2.3) | 4.9 (1.5) | 5.5 (2.1)
Median (Min-Max) | 5.7 (2.6 - 10.3) | 4.9 (3.0 - 8.3) | 5.2 (2.6 - 10.3)
LOCF
N | 28 | 13 | 41
Mean (SD) | 5.2 (1.9) | 4.8 (1.3) | 5.1 (1.8)
Median (Min-Max) | 5.2 (2.5 - 10.3) | 4.8 (3.0 - 8.3) | 4.9 (2.5 - 10.3)
Change from Baseline to LOCF
N | 28 | 13 | 41
Mean (SD) | 0.0 (1.1) | 0.8 (0.9) | 0.3 (1.1)
Median (Min-Max) | 0.1 (−2.4 - 2.1) | 0.9 (−0.7 - 2.6) | 0.5 (−2.4 - 2.6)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.2.26B Summary of Clinical Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Group Creatinine Clearance (mL/min/1.7m^2^) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 123.4 (29.4) | 137.9 (34.1) | 128.3 (31.5)
Median (Min-Max) | 127.7 (67.6 - 203.9) | 136.6 (67.3 - 194.3) | 131.3 (67.3 - 203.9)
Week 4
N | 26 | 12 | 38
Mean (SD) | 124.1 (31.2) | 114.2 (22.3) | 121.0 (28.8)
Median (Min-Max) | 122.6 (69.3 - 193.5) | 120.2 (72.5 - 144.0) | 122.0 (69.3 - 193.5)
Week 8
N | 26 | 11 | 37
Mean (SD) | 122.4 (29.5) | 120.9 (27.3) | 121.9 (28.5)
Median (Min-Max) | 122.9 (60.4 - 179.0) | 125.8 (66.4 - 152.2) | 123.5 (60.4 - 179.0)
Week 16
N | 19 | 9 | 28
Mean (SD) | 134.7 (35.5) | 121.4 (28.0) | 130.5 (33.4)
Median (Min-Max) | 131.4 (77.2 - 238.7) | 125.7 (72.6 - 155.0) | 129.8 (72.6 - 238.7)
Week 24
N | 15 | 8 | 23
Mean (SD) | 125.7 (18.5) | 127.2 (27.2) | 126.3 (21.3)
Median (Min-Max) | 124.4 (95.2 - 163.3) | 130.5 (73.9 - 169.3) | 124.8 (73.9 - 169.3)
LOCF
N | 28 | 13 | 41
Mean (SD) | 124.0 (27.3) | 125.0 (31.4) | 124.3 (28.3)
Median (Min-Max) | 124.6 (60.4 - 163.3) | 129.2 (67.7 - 179.0) | 125.9 (60.4 - 179.0)
Change from Baseline to LOCF
N | 28 | 13 | 41
Mean (SD) | 1.2 (24.6) | −12.1 (21.3) | −3.0 (24.2)
Median (Min-Max) | 3.8 (−81.5 - 37.7) | −11.2 (−64.5 - 25.2) | 0.4 (−81.5 - 37.7)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.2.3.1 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Albumin (g/dL) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 4.4 (0.4) | 4.1 (0.4) | 4.3 (0.4)
Median (Min-Max) | 4.2 (3.9 - 5.4) | 4.2 (3.5 - 4.7) | 4.2 (3.5 - 5.4)
Week 8
N | 13 | 3 | 16
Mean (SD) | 4.4 (0.4) | 4.0 (0.6) | 4.4 (0.5)
Median (Min-Max) | 4.4 (4.0 - 5.3) | 3.7 (3.6 - 4.6) | 4.4 (3.6 - 5.3)
Week 16
N | 12 | 2 | 14
Mean (SD) | 4.3 (0.3) | 4.2 (0.4) | 4.3 (0.3)
Median (Min-Max) | 4.2 (3.9 - 5.0) | 4.2 (3.9 - 4.4) | 4.2 (3.9 - 5.0)
Week 20
N | 8 | 0 | 8
Mean (SD) | 4.2 (0.3) | 0 | 4.2 (0.3)
Median (Min-Max) | 4.3 (3.8 - 4.5) | 0 | 4.3 (3.8 - 4.5)
Week 28
N | 11 | 2 | 13
Mean (SD) | 4.3 (0.4) | 4.1 (0.1) | 4.3 (0.3)
Median (Min-Max) | 4.3 (3.7 - 5.1) | 4.1 (4.0 - 4.2) | 4.3 (3.7 - 5.1)
LOCF
N | 16 | 12 | 28
Mean (SD) | 4.2 (0.4) | 4.2 (0.4) | 4.2 (0.4)
Median (Min-Max) | 4.3 (3.7 - 5.1) | 4.2 (3.4 - 5.0) | 4.2 (3.4 - 5.1)
Change from Baseline to LOCF
N | 16 | 12 | 28
Mean (SD) | −0.1 (0.3) | 0.0 (0.2) | −0.1 (0.3)
Median (Min-Max) | −0.2 (−0.6 - 0.3) | 0.1 (−0.4 - 0.5) | −0.1 (−0.6 - 0.5)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.2.3.2 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Alkaline Phosphatase (U/L) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 296.2 (103.1) | 290.9 (146.0) | 293.8 (122.1)
Median (Min-Max) | 296.0 (92.0 - 486.0) | 293.5 (95.0 - 564.0) | 296.0 (92.0 - 564.0)
Week 8
N | 13 | 3 | 16
Mean (SD) | 258.2 (123.4) | 176.7 (156.5) | 242.9 (128.5)
Median (Min-Max) | 276.0 (5.0 - 496.0) | 97.0 (76.0 - 357.0) | 275.0 (5.0 - 496.0)
Week 16
N | 12 | 2 | 14
Mean (SD) | 264.9 (94.2) | 206.5 (176.1) | 256.6 (101.7)
Median (Min-Max) | 280.5 (96.0 - 428.0) | 206.5 (82.0 - 331.0) | 280.5 (82.0 - 428.0)
Week 20
N | 8 | 0 | 8
Mean (SD) | 261.6 (109.4) | 0 | 261.6 (109.4)
Median (Min-Max) | 260.5 (85.0 - 422.0) | 0 | 260.5 (85.0 - 422.0)
Week 28
N | 11 | 2 | 13
Mean (SD) | 242.7 (102.0) | 219.5 (184.6) | 239.2 (107.6)
Median (Min-Max) | 248.0 (88.0 - 442.0) | 219.5 (89.0 - 350.0) | 248.0 (88.0 - 442.0)
LOCF
N | 16 | 12 | 28
Mean (SD) | 284.8 (130.0) | 226.8 (115.6) | 259.9 (125.3)
Median (Min-Max) | 277.5 (88.0 - 512.0) | 251.5 (80.0 - 447.0) | 266.0 (80.0 - 512.0)
Change from Baseline to LOCF
N | 16 | 12 | 28
Mean (SD) | −12.6 (46.3) | −42.1 (44.5) | −25.2 (47.1)
Median (Min-Max) | −10.0 (−121 - 71.0) | −24.5 (−117 - 20.0) | −19.0 (−121 - 71.0)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.2.3.3 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Alanine Aminotransferase - ALT (U/L) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 22.5 (11.6) | 28.4 (12.2) | 25.2 (12.1)
Median (Min-Max) | 18.0 (9.0 - 55.0) | 28.5 (14.0 - 61.0) | 24.0 (9.0 - 61.0)
Week 8
N | 13 | 3 | 16
Mean (SD) | 21.8 (10.1) | 20.7 (1.5) | 21.6 (9.1)
Median (Min-Max) | 20.0 (9.0 - 45.0) | 21.0 (19.0 - 22.0) | 20.5 (9.0 - 45.0)
Week 16
N | 12 | 2 | 14
Mean (SD) | 20.3 (7.8) | 19.5 (2.1) | 20.1 (7.2)
Median (Min-Max) | 17.0 (10.0 - 36.0) | 19.5 (18.0 - 21.0) | 17.5 (10.0 - 36.0)
Week 20
N | 8 | 0 | 8
Mean (SD) | 22.3 (8.5) | 0 | 22.3 (8.5)
Median (Min-Max) | 19.5 (13.0 - 37.0) | 0 | 19.5 (13.0 - 37.0)
Week 28
N | 11 | 2 | 13
Mean (SD) | 21.8 (8.8) | 23.0 (9.9) | 22.0 (8.5)
Median (Min-Max) | 20.0 (13.0 - 36.0) | 23.0 (16.0 - 30.0) | 20.0 (13.0 - 36.0)
LOCF
N | 16 | 12 | 28
Mean (SD) | 25.4 (12.3) | 29.0 (19.9) | 26.9 (15.8)
Median (Min-Max) | 22.5 (13.0 - 61.0) | 25.0 (15.0 - 88.0) | 24.0 (13.0 - 88.0)
Change from Baseline to LOCF
N | 16 | 12 | 28
Mean (SD) | 2.4 (12.4) | 0.9 (9.0) | 1.8 (10.9)
Median (Min-Max) | 2.0 (−29.0 - 35.0) | 0.0 (−11.0 - 27.0) | 0.0 (−29.0 - 35.0)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.2.3.4 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Aspartate Aminotransferase - AST (U/L) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 22.7 (8.2) | 21.4 (8.1) | 22.1 (8.0)
Median (Min-Max) | 21.0 (11.0 - 42.0) | 20.5 (10.0 - 41.0) | 21.0 (10.0 - 42.0)
Week 8
N | 13 | 3 | 16
Mean (SD) | 24.8 (7.8) | 22.7 (1.5) | 24.4 (7.1)
Median (Min-Max) | 23.0 (15.0 - 47.0) | 23.0 (21.0 - 24.0) | 23.0 (15.0 - 47.0)
Week 16
N | 12 | 2 | 14
Mean (SD) | 27.8 (10.9) | 19.0 (2.8) | 26.5 (10.5)
Median (Min-Max) | 23.5 (17.0 - 51.0) | 19.0 (17.0 - 21.0) | 22.5 (17.0 - 51.0)
Week 20
N | 8 | 0 | 8
Mean (SD) | 21.9 (5.6) | 0 | 21.9 (5.6)
Median (Min-Max) | 20.0 (17.0 - 34.0) | 0 | 20.0 (17.0 - 34.0)
Week 28
N | 11 | 2 | 13
Mean (SD) | 23.7 (6.6) | 19.5 (6.4) | 23.1 (6.5)
Median (Min-Max) | 21.0 (17.0 - 37.0) | 19.5 (15.0 - 24.0) | 21.0 (15.0 - 37.0)
LOCF
N | 16 | 12 | 28
Mean (SD) | 23.9 (7.5) | 21.5 (12.9) | 22.9 (10.0)
Median (Min-Max) | 22.0 (13.0 - 39.0) | 18.5 (11.0 - 60.0) | 20.5 (11.0 - 60.0)
Change from Baseline to LOCF
N | 16 | 12 | 28
Mean (SD) | 0.9 (9.1) | 0.2 (6.5) | 0.6 (8.0)
Median (Min-Max) | 0.5 (−23.0 - 23.0) | −1.0 (−7.0 - 19.0) | 0.0 (−23.0 - 23.0)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.2.3.5 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Bicarbonate (mEq/L) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 25.5 (2.4) | 26.1 (1.5) | 25.7 (2.0)
Median (Min-Max) | 26.0 (18.0 - 28.0) | 26.0 (24.0 - 29.0) | 26.0 (18.0 - 29.0)
Week 8
N | 13 | 3 | 16
Mean (SD) | 24.5 (3.7) | 25.0 (2.6) | 24.6 (3.5)
Median (Min-Max) | 25.0 (15.0 - 30.0) | 24.0 (23.0 - 28.0) | 25.0 (15.0 - 30.0)
Week 16
N | 12 | 2 | 14
Mean (SD) | 24.7 (2.1) | 24.0 (1.4) | 24.6 (1.9)
Median (Min-Max) | 24.5 (21.0 - 28.0) | 24.0 (23.0 - 25.0) | 24.5 (21.0 - 28.0)
Week 20
N | 8 | 0 | 8
Mean (SD) | 24.8 (2.3) | 0 | 24.8 (2.3)
Median (Min-Max) | 24.5 (21.0 - 28.0) | 0 | 24.5 (21.0 - 28.0)
Week 28
N | 11 | 2 | 13
Mean (SD) | 25.1 (2.5) | 25.0 (0.0) | 25.1 (2.3)
Median (Min-Max) | 26.0 (21.0 - 28.0) | 25.0 (25.0 - 25.0) | 25.0 (21.0 - 28.0)
LOCF
N | 16 | 12 | 28
Mean (SD) | 25.3 (2.6) | 26.2 (1.9) | 25.7 (2.3)
Median (Min-Max) | 26.0 (21.0 - 30.0) | 26.0 (23.0 - 29.0) | 26.0 (21.0 - 30.0)
Change from Baseline to LOCF
N | 16 | 12 | 28
Mean (SD) | −0.3 (2.3) | 0.3 (1.6) | 0.0 (2.0)
Median (Min-Max) | 0.0 (−4.0 - 4.0) | 0.5 (−2.0 - 2.0) | 0.0 (−4.0 - 4.0)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.2.3.6 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Direct Bilirubin (mg/dL) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 0.2 (0.4) | 0.1 (0.0) | 0.2 (0.3)
Median (Min-Max) | 0.1 (0.1 - 1.7) | 0.1 (0.1 - 0.2) | 0.1 (0.1 - 1.7)
Week 8
N | 13 | 3 | 16
Mean (SD) | 0.1 (0.1) | 0.1 (0.0) | 0.1 (0.1)
Median (Min-Max) | 0.1 (0.1 - 0.3) | 0.1 (0.1 - 0.1) | 0.1 (0.1 - 0.3)
Week 16
N | 12 | 2 | 14
Mean (SD) | 0.2 (0.2) | 0.1 (0.0) | 0.2 (0.2)
Median (Min-Max) | 0.1 (0.1 - 0.8) | 0.1 (0.1 - 0.1) | 0.1 (0.1 - 0.8)
Week 20
N | 8 | 0 | 8
Mean (SD) | 0.2 (0.1) | 0 | 0.2 (0.1)
Median (Min-Max) | 0.1 (0.1 - 0.3) | 0 | 0.1 (0.1 - 0.3)
Week 28
N | 11 | 2 | 13
Mean (SD) | 0.2 (0.1) | 0.1 (0.0) | 0.2 (0.1)
Median (Min-Max) | 0.1 (0.1 - 0.5) | 0.1 (0.1 - 0.1) | 0.1 (0.1 - 0.5)
LOCF
N | 16 | 12 | 28
Mean (SD) | 0.2 (0.1) | 0.1 (0.0) | 0.1 (0.1)
Median (Min-Max) | 0.1 (0.1 - 0.5) | 0.1 (0.1 - 0.2) | 0.1 (0.1 - 0.5)
Change from Baseline to LOCF
N | 16 | 12 | 28
Mean (SD) | −0.1 (0.4) | 0.0 (0.0) | 0.0 (0.3)
Median (Min-Max) | 0.0 (−1.4 - 0.3) | 0.0 (−0.1 - 0.0) | 0.0 (−1.4 - 0.3)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.2.3.7 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Total Bilirubin (mg/dL) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 0.5 (0.3) | 0.6 (0.2) | 0.5 (0.3)
Median (Min-Max) | 0.5 (0.1 - 1.1) | 0.6 (0.2 - 1.1) | 0.6 (0.1 - 1.1)
Week 8
N | 13 | 3 | 16
Mean (SD) | 0.7 (0.5) | 0.5 (0.1) | 0.6 (0.5)
Median (Min-Max) | 0.5 (0.1 - 1.7) | 0.5 (0.4 - 0.6) | 0.5 (0.1 - 1.7)
Week 16
N | 12 | 2 | 14
Mean (SD) | 0.6 (0.5) | 0.5 (0.1) | 0.6 (0.5)
Median (Min-Max) | 0.3 (0.1 - 1.9) | 0.5 (0.4 - 0.5) | 0.4 (0.1 - 1.9)
Week 20
N | 8 | 0 | 8
Mean (SD) | 0.5 (0.2) | 0 | 0.5 (0.2)
Median (Min-Max) | 0.5 (0.2 - 0.8) | 0 | 0.5 (0.2 - 0.8)
Week 28
N | 11 | 2 | 13
Mean (SD) | 0.7 (0.7) | 0.6 (0.1) | 0.7 (0.6)
Median (Min-Max) | 0.4 (0.2 - 2.6) | 0.6 (0.5 - 0.6) | 0.5 (0.2 - 2.6)
LOCF
N | 16 | 12 | 28
Mean (SD) | 0.6 (0.6) | 0.5 (0.2) | 0.6 (0.5)
Median (Min-Max) | 0.4 (0.1 - 2.6) | 0.6 (0.3 - 0.9) | 0.5 (0.1 - 2.6)
Change from Baseline to LOCF
N | 16 | 12 | 28
Mean (SD) | 0.1 (0.7) | −0.1 (0.1) | 0.0 (0.5)
Median (Min-Max) | 0.1 (−0.4 - 2.4) | −0.1 (−0.3 - 0.2) | −0.1 (−0.4 - 2.4)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.2.3.8 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Calcium (mg/dL) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 9.8 (0.4) | 9.7 (0.4) | 9.7 (0.4)
Median (Min-Max) | 9.6 (9.1 - 10.7) | 9.7 (9.1 - 10.3) | 9.7 (9.1 - 10.7)
Week 8
N | 13 | 3 | 16
Mean (SD) | 9.7 (0.6) | 9.5 (0.6) | 9.7 (0.6)
Median (Min-Max) | 9.6 (8.8 - 10.5) | 9.5 (8.9 - 10.1) | 9.6 (8.8 - 10.5)
Week 16
N | 12 | 2 | 14
Mean (SD) | 9.6 (0.5) | 9.7 (0.2) | 9.6 (0.4)
Median (Min-Max) | 9.6 (8.9 - 10.5) | 9.7 (9.5 - 9.8) | 9.6 (8.9 - 10.5)
Week 20
N | 8 | 0 | 8
Mean (SD) | 9.5 (0.3) | 0 | 9.5 (0.3)
Median (Min-Max) | 9.4 (8.9 - 10.0) | 0 | 9.4 (8.9 - 10.0)
Week 28
N | 11 | 2 | 13
Mean (SD) | 9.8 (0.4) | 9.6 (0.3) | 9.7 (0.4)
Median (Min-Max) | 9.8 (8.9 - 10.4) | 9.6 (9.4 - 9.8) | 9.8 (8.9 - 10.4)
LOCF
N | 16 | 12 | 28
Mean (SD) | 9.7 (0.4) | 9.7 (0.4) | 9.7 (0.4)
Median (Min-Max) | 9.7 (8.9 - 10.4) | 9.8 (9.3 - 10.6) | 9.7 (8.9 - 10.6)
Change from Baseline to LOCF
N | 16 | 12 | 28
Mean (SD) | 0.0 (0.4) | 0.1 (0.4) | 0.0 (0.4)
Median (Min-Max) | 0.0 (−0.8 - 0.5) | 0.1 (−0.5 - 0.7) | 0.0 (−0.8 - 0.7)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.2.3.9 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Chloride (mEq/L) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 104.9 (2.0) | 105.4 (1.8) | 105.1 (1.9)
Median (Min-Max) | 105.0 (101.0 - 109.0) | 106.0 (102.0 - 108.0) | 105.0 (101.0 - 109.0)
Week 8
N | 13 | 3 | 16
Mean (SD) | 105.0 (2.9) | 104.7 (0.6) | 104.9 (2.6)
Median (Min-Max) | 105.0 (101.0 - 112.0) | 105.0 (104.0 - 105.0) | 105.0 (101.0 - 112.0)
Week 16
N | 12 | 2 | 14
Mean (SD) | 104.8 (2.0) | 105.0 (0.0) | 104.9 (1.8)
Median (Min-Max) | 105.0 (102.0 - 108.0) | 105.0 (105.0 - 105.0) | 105.0 (102.0 - 108.0)
Week 20
N | 8 | 0 | 8
Mean (SD) | 104.4 (2.2) | 0 | 104.4 (2.2)
Median (Min-Max) | 104.5 (100.0 - 107.0) | 0 | 104.5 (100.0 - 107.0)
Week 28
N | 11 | 2 | 13
Mean (SD) | 104.5 (2.2) | 102.0 (2.8) | 104.1 (2.3)
Median (Min-Max) | 105.0 (101.0 - 108.0) | 102.0 (100.0 - 104.0) | 104.0 (100.0 - 108.0)
LOCF
N | 16 | 12 | 28
Mean (SD) | 104.4 (2.0) | 103.6 (2.9) | 104.0 (2.4)
Median (Min-Max) | 104.5 (101.0 - 108.0) | 104.5 (99.0 - 107.0) | 104.5 (99.0 - 108.0)
Change from Baseline to LOCF
N | 16 | 12 | 28
Mean (SD) | −0.4 (1.5) | −1.7 (2.9) | −0.9 (2.3)
Median (Min-Max) | 0.0 (−3.0 - 2.0) | −1.5 (−6.0 - 3.0) | −0.5 (−6.0 - 3.0)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.2.3.10 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Cholesterol (mg/dL) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 15 | 14 | 29
Mean (SD) | 166.6 (29.6) | 157.4 (23.0) | 162.2 (26.5)
Median (Min-Max) | 162.0 (103.0 - 214.0) | 163.5 (122.0 - 198.0) | 162.0 (103.0 - 214.0)
Week 8
N | 13 | 3 | 16
Mean (SD) | 153.7 (32.2) | 144.3 (23.5) | 151.9 (30.3)
Median (Min-Max) | 145.0 (108.0 - 224.0) | 146.0 (120.0 - 167.0) | 145.5 (108.0 - 224.0)
Week 16
N | 12 | 2 | 14
Mean (SD) | 149.9 (21.2) | 173.0 (0.0) | 153.2 (21.2)
Median (Min-Max) | 146.5 (123.0 - 192.0) | 173.0 (173.0 - 173.0) | 148.5 (123.0 - 192.0)
Week 20
N | 8 | 0 | 8
Mean (SD) | 141.6 (19.0) | 0 | 141.6 (19.0)
Median (Min-Max) | 143.0 (113.0 - 164.0) | 0 | 143.0 (113.0 - 164.0)
Week 28
N | 11 | 2 | 13
Mean (SD) | 149.4 (29.4) | 175.0 (5.7) | 153.3 (28.6)
Median (Min-Max) | 148.0 (103.0 - 202.0) | 175.0 (171.0 - 179.0) | 156.0 (103.0 - 202.0)
LOCF
N | 16 | 12 | 28
Mean (SD) | 152.1 (28.4) | 165.0 (25.5) | 157.6 (27.5)
Median (Min-Max) | 150.5 (103.0 - 207.0) | 167.0 (121.0 - 199.0) | 153.5 (103.0 - 207.0)
Change from Baseline to LOCF
N | 14 | 12 | 26
Mean (SD) | −13.2 (19.0) | 8.3 (14.8) | −3.3 (20.1)
Median (Min-Max) | −10.0 (−54.0 - 13.0) | 9.5 (−19.0 - 30.0) | −1.5 (−54.0 - 30.0)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.2.3.11 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Creatine kinase (U/L) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 88.0 (33.5) | 119.4 (64.3) | 102.2 (51.4)
Median (Min-Max) | 76.0 (44.0 - 142.0) | 112.0 (31.0 - 218.0) | 93.0 (31.0 - 218.0)
Week 8
N | 12 | 3 | 15
Mean (SD) | 104.3 (64.1) | 186.7 (96.3) | 120.7 (75.6)
Median (Min-Max) | 84.5 (40.0 - 265.0) | 158.0 (108.0 - 294.0) | 93.0 (40.0 - 294.0)
Week 16
N | 11 | 2 | 13
Mean (SD) | 109.5 (46.6) | 209.5 (77.1) | 124.9 (60.9)
Median (Min-Max) | 88.0 (53.0 - 172.0) | 209.5 (155.0 - 264.0) | 131.0 (53.0 - 264.0)
Week 20
N | 8 | 0 | 8
Mean (SD) | 83.6 (33.4) | 0 | 83.6 (33.4)
Median (Min-Max) | 78.0 (40.0 - 152.0) | 0 | 78.0 (40.0 - 152.0)
Week 28
N | 11 | 2 | 13
Mean (SD) | 72.2 (21.4) | 260.0 (116.0) | 101.1 (80.5)
Median (Min-Max) | 74.0 (41.0 - 125.0) | 260.0 (178.0 - 342.0) | 75.0 (41.0 - 342.0)
LOCF
N | 16 | 12 | 28
Mean (SD) | 76.6 (23.8) | 139.8 (82.8) | 103.6 (64.2)
Median (Min-Max) | 74.0 (41.0 - 130.0) | 114.5 (37.0 - 342.0) | 77.0 (37.0 - 342.0)
Change from Baseline to LOCF
N | 16 | 12 | 28
Mean (SD) | −11.6 (29.8) | 23.9 (55.7) | 3.6 (45.6)
Median (Min-Max) | −1.0 (−68.0 - 31.0) | 10.0 (−39.0 - 171.0) | 4.0 (−68.0 - 171.0)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.2.3.12 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Creatinine (mg/dL) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 0.6 (0.1) | 0.7 (0.1) | 0.6 (0.1)
Median (Min-Max) | 0.6 (0.4 - 0.8) | 0.7 (0.5 - 1.0) | 0.6 (0.4 - 1.0)
Week 8
N | 13 | 3 | 16
Mean (SD) | 0.6 (0.1) | 0.7 (0.2) | 0.6 (0.1)
Median (Min-Max) | 0.6 (0.4 - 0.8) | 0.8 (0.5 - 0.9) | 0.6 (0.4 - 0.9)
Week 16
N | 12 | 2 | 14
Mean (SD) | 0.7 (0.1) | 0.7 (0.2) | 0.7 (0.1)
Median (Min-Max) | 0.7 (0.5 - 0.9) | 0.7 (0.6 - 0.9) | 0.7 (0.5 - 0.9)
Week 20
N | 8 | 0 | 8
Mean (SD) | 0.7 (0.1) | 0 | 0.7 (0.1)
Median (Min-Max) | 0.7 (0.6 - 0.8) | 0 | 0.7 (0.6 - 0.8)
Week 28
N | 11 | 2 | 13
Mean (SD) | 0.6 (0.1) | 0.8 (0.1) | 0.6 (0.1)
Median (Min-Max) | 0.6 (0.5 - 0.8) | 0.8 (0.7 - 0.9) | 0.6 (0.5 - 0.9)
LOCF
N | 16 | 12 | 28
Mean (SD) | 0.6 (0.1) | 1.7 (3.4) | 1.1 (2.2)
Median (Min-Max) | 0.6 (0.5 - 0.8) | 0.7 (0.5 - 12.5) | 0.7 (0.5 - 12.5)
Change from Baseline to LOCF
N | 16 | 12 | 28
Mean (SD) | 0.0 (0.2) | 1.0 (3.4) | 0.4 (2.2)
Median (Min-Max) | 0.0 (−0.2 - 0.3) | 0.0 (−0.2 - 11.7) | 0.0 (−0.2 - 11.7)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.2.3.13 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Gamma-glutamyl transpeptidase - GGT (U/L) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 16.9 (5.8) | 22.6 (12.1) | 19.5 (9.5)
Median (Min-Max) | 15.0 (10.0 - 28.0) | 21.5 (9.0 - 59.0) | 17.0 (9.0 - 59.0)
Week 8
N | 13 | 3 | 16
Mean (SD) | 13.8 (4.8) | 26.0 (6.6) | 16.1 (6.9)
Median (Min-Max) | 15.0 (7.0 - 22.0) | 25.0 (20.0 - 33.0) | 16.5 (7.0 - 33.0)
Week 16
N | 12 | 2 | 14
Mean (SD) | 12.7 (4.7) | 24.0 (7.1) | 14.3 (6.3)
Median (Min-Max) | 12.0 (3.0 - 19.0) | 24.0 (19.0 - 29.0) | 13.0 (3.0 - 29.0)
Week 20
N | 8 | 0 | 8
Mean (SD) | 13.5 (5.8) | 0 | 13.5 (5.8)
Median (Min-Max) | 12.0 (6.0 - 23.0) | 0 | 12.0 (6.0 - 23.0)
Week 28
N | 11 | 2 | 13
Mean (SD) | 16.5 (6.7) | 31.0 (11.3) | 18.8 (8.8)
Median (Min-Max) | 16.0 (8.0 - 32.0) | 31.0 (23.0 - 39.0) | 18.0 (8.0 - 39.0)
LOCF
N | 16 | 12 | 28
Mean (SD) | 17.0 (7.3) | 26.4 (17.9) | 21.0 (13.5)
Median (Min-Max) | 15.5 (7.0 - 32.0) | 22.0 (10.0 - 76.0) | 18.5 (7.0 - 76.0)
Change from Baseline to LOCF
N | 16 | 12 | 28
Mean (SD) | −0.3 (4.8) | 3.6 (5.9) | 1.4 (5.5)
Median (Min-Max) | −1.0 (−7.0 - 9.0) | 1.0 (−3.0 - 17.0) | 0.5 (−7.0 - 17.0)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.2.3.14 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Glucose (mg/dL) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 85.9 (10.0) | 88.5 (8.0) | 87.1 (9.1)
Median (Min-Max) | 87.0 (70.0 - 101.0) | 88.0 (76.0 - 103.0) | 87.0 (70.0 - 103.0)
Week 8
N | 13 | 3 | 16
Mean (SD) | 87.8 (11.4) | 76.3 (23.0) | 85.6 (14.0)
Median (Min-Max) | 89.0 (65.0 - 106.0) | 82.0 (51.0 - 96.0) | 88.0 (51.0 - 106.0)
Week 16
N | 12 | 2 | 14
Mean (SD) | 87.6 (14.9) | 93.0 (1.4) | 88.4 (13.9)
Median (Min-Max) | 87.5 (64.0 - 108.0) | 93.0 (92.0 - 94.0) | 92.0 (64.0 - 108.0)
Week 20
N | 8 | 0 | 8
Mean (SD) | 91.4 (16.4) | 0 | 91.4 (16.4)
Median (Min-Max) | 86.5 (76.0 - 128.0) | 0 | 86.5 (76.0 - 128.0)
Week 28
N | 11 | 2 | 13
Mean (SD) | 76.9 (12.2) | 90.5 (0.7) | 79.0 (12.3)
Median (Min-Max) | 79.0 (49.0 - 90.0) | 90.5 (90.0 - 91.0) | 80.0 (49.0 - 91.0)
LOCF
N | 16 | 12 | 28
Mean (SD) | 78.4 (13.7) | 83.0 (13.3) | 80.4 (13.5)
Median (Min-Max) | 82.0 (49.0 - 95.0) | 84.0 (48.0 - 99.0) | 84.0 (48.0 - 99.0)
Change from Baseline to LOCF
N | 16 | 12 | 28
Mean (SD) | −6.7 (14.8) | −5.3 (14.2) | −6.1 (14.3)
Median (Min-Max) | −6.0 (−35.0 - 10.0) | −2.0 (−39.0 - 8.0) | −4.5 (−39.0 - 10.0)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.2.3.15 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group High-Density Lipoprotein - HDL (mg/dL) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 12 | 11 | 23
Mean (SD) | 55.0 (11.8) | 47.5 (12.9) | 51.4 (12.6)
Median (Min-Max) | 54.0 (38.0 - 80.0) | 41.0 (32.0 - 69.0) | 53.0 (32.0 - 80.0)
Week 8
N | 10 | 2 | 12
Mean (SD) | 53.7 (8.6) | 49.0 (14.1) | 52.9 (9.1)
Median (Min-Max) | 55.0 (41.0 - 66.0) | 49.0 (39.0 - 59.0) | 55.0 (39.0 - 66.0)
Week 16
N | 9 | 2 | 11
Mean (SD) | 51.9 (9.8) | 50.5 (9.2) | 51.6 (9.3)
Median (Min-Max) | 54.0 (36.0 - 67.0) | 50.5 (44.0 - 57.0) | 54.0 (36.0 - 67.0)
Week 20
N | 4 | 0 | 4
Mean (SD) | 48.0 (4.3) | 0 | 48.0 (4.3)
Median (Min-Max) | 47.0 (44.0 - 54.0) | 0 | 47.0 (44.0 - 54.0)
Week 28
N | 9 | 2 | 11
Mean (SD) | 50.1 (12.1) | 48.5 (10.6) | 49.8 (11.3)
Median (Min-Max) | 48.0 (35.0 - 70.0) | 48.5 (41.0 - 56.0) | 48.0 (35.0 - 70.0)
LOCF
N | 13 | 10 | 23
Mean (SD) | 48.2 (10.8) | 47.2 (12.0) | 47.8 (11.1)
Median (Min-Max) | 45.0 (35.0 - 70.0) | 50.0 (30.0 - 63.0) | 46.0 (30.0 - 70.0)
Change from Baseline to LOCF
N | 12 | 10 | 22
Mean (SD) | −5.7 (6.1) | 1.9 (8.3) | −2.2 (8.0)
Median (Min-Max) | −5.0 (−15.0 - 5.0) | 0.5 (−9.0 - 19.0) | −3.5 (−15.0 - 19.0)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.2.3.16 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Cholesterol/HDL Ratio Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 12 | 11 | 23
Mean (SD) | 3.2 (0.8) | 3.6 (1.0) | 3.4 (0.9)
Median (Min-Max) | 3.1 (2.2 - 5.4) | 3.2 (2.6 - 5.3) | 3.1 (2.2 - 5.4)
Week 8
N | 10 | 2 | 12
Mean (SD) | 2.9 (0.5) | 3.3 (0.7) | 3.0 (0.5)
Median (Min-Max) | 2.9 (2.3 - 3.7) | 3.3 (2.8 - 3.7) | 2.9 (2.3 - 3.7)
Week 16
N | 9 | 2 | 11
Mean (SD) | 3.0 (0.4) | 3.5 (0.7) | 3.1 (0.5)
Median (Min-Max) | 3.1 (2.3 - 3.4) | 3.5 (3.0 - 3.9) | 3.1 (2.3 - 3.9)
Week 20
N | 4 | 0 | 4
Mean (SD) | 2.9 (0.4) | 0 | 2.9 (0.4)
Median (Min-Max) | 2.9 (2.5 - 3.4) | 0 | 2.9 (2.5 - 3.4)
Week 28
N | 9 | 2 | 11
Mean (SD) | 3.1 (0.4) | 3.7 (0.7) | 3.2 (0.5)
Median (Min-Max) | 3.0 (2.3 - 3.5) | 3.7 (3.2 - 4.2) | 3.2 (2.3 - 4.2)
LOCF
N | 13 | 10 | 23
Mean (SD) | 3.3 (0.6) | 3.8 (1.2) | 3.5 (0.9)
Median (Min-Max) | 3.2 (2.3 - 4.6) | 3.2 (2.4 - 5.6) | 3.2 (2.3 - 5.6)
Change from Baseline to LOCF
N | 12 | 10 | 22
Mean (SD) | 0.1 (0.4) | 0.1 (0.5) | 0.1 (0.5)
Median (Min-Max) | 0.1 (−0.8 - 0.7) | 0.1 (−1.0 - 1.1) | 0.1 (−1.0 - 1.1)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.2.3.17 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Low-Density Lipoprotein - LDL (mg/dL) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 12 | 11 | 23
Mean (SD) | 98.3 (24.0) | 94.5 (19.5) | 96.5 (21.6)
Median (Min-Max) | 98.0 (50.0 - 134.0) | 95.0 (64.0 - 121.0) | 96.0 (50.0 - 134.0)
Week 8
N | 10 | 2 | 12
Mean (SD) | 84.3 (24.3) | 96.5 (3.5) | 86.3 (22.5)
Median (Min-Max) | 77.0 (54.0 - 126.0) | 96.5 (94.0 - 99.0) | 83.5 (54.0 - 126.0)
Week 16
N | 9 | 2 | 11
Mean (SD) | 68.4 (23.2) | 106.0 (7.1) | 75.3 (25.8)
Median (Min-Max) | 68.0 (16.0 - 103.0) | 106.0 (101.0 - 111.0) | 73.0 (16.0 - 111.0)
Week 20
N | 4 | 0 | 4
Mean (SD) | 68.5 (19.1) | 0 | 68.5 (19.1)
Median (Min-Max) | 62.5 (54.0 - 95.0) | 0 | 62.5 (54.0 - 95.0)
Week 28
N | 9 | 2 | 11
Mean (SD) | 85.7 (23.8) | 116.0 (1.4) | 91.2 (24.6)
Median (Min-Max) | 84.0 (54.0 - 127.0) | 116.0 (115.0 - 117.0) | 88.0 (54.0 - 127.0)
LOCF
N | 13 | 10 | 23
Mean (SD) | 87.2 (24.2) | 100.2 (23.9) | 92.8 (24.4)
Median (Min-Max) | 84.0 (54.0 - 130.0) | 106.0 (66.0 - 127.0) | 92.0 (54.0 - 130.0)
Change from Baseline to LOCF
N | 12 | 10 | 22
Mean (SD) | −8.4 (12.8) | 4.1 (12.7) | −2.7 (14.0)
Median (Min-Max) | −10.0 (−34.0 - 13.0) | 4.5 (−18.0 - 22.0) | −4.5 (−34.0 - 22.0)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.2.3.18 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Magnesium (mg/dL) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 2.1 (0.3) | 2.2 (0.3) | 2.1 (0.3)
Median (Min-Max) | 2.1 (1.7 - 2.8) | 2.2 (1.3 - 2.5) | 2.2 (1.3 - 2.8)
Week 8
N | 13 | 3 | 16
Mean (SD) | 2.2 (0.3) | 2.0 (0.2) | 2.1 (0.2)
Median (Min-Max) | 2.2 (1.6 - 2.5) | 2.1 (1.8 - 2.1) | 2.2 (1.6 - 2.5)
Week 16
N | 12 | 2 | 14
Mean (SD) | 2.1 (0.2) | 1.9 (0.1) | 2.1 (0.2)
Median (Min-Max) | 2.1 (1.7 - 2.5) | 1.9 (1.9 - 2.0) | 2.1 (1.7 - 2.5)
Week 20
N | 8 | 0 | 8
Mean (SD) | 2.1 (0.2) | 0 | 2.1 (0.2)
Median (Min-Max) | 2.1 (1.8 - 2.4) | 0 | 2.1 (1.8 - 2.4)
Week 28
N | 11 | 2 | 13
Mean (SD) | 2.0 (0.2) | 1.9 (0.2) | 2.0 (0.2)
Median (Min-Max) | 2.1 (1.8 - 2.3) | 1.9 (1.8 - 2.0) | 2.0 (1.8 - 2.3)
LOCF
N | 16 | 12 | 28
Mean (SD) | 2.1 (0.2) | 2.1 (0.3) | 2.1 (0.2)
Median (Min-Max) | 2.1 (1.8 - 2.3) | 2.2 (1.3 - 2.5) | 2.1 (1.3 - 2.5)
Change from Baseline to LOCF
N | 16 | 12 | 28
Mean (SD) | −0.1 (0.2) | −0.1 (0.4) | −0.1 (0.3)
Median (Min-Max) | 0.0 (−0.6 - 0.2) | −0.2 (−0.5 - 0.8) | 0.0 (−0.6 - 0.8)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.2.3.19 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Phosphorus (mg/dL) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 16 | 14 | 30
Mean (SD) | 5.1 (0.6) | 4.9 (0.8) | 5.0 (0.7)
Median (Min-Max) | 5.1 (3.9 - 6.4) | 4.8 (3.6 - 6.3) | 5.0 (3.6 - 6.4)
Week 8
N | 13 | 3 | 16
Mean (SD) | 5.1 (0.7) | 4.4 (1.0) | 5.0 (0.8)
Median (Min-Max) | 5.0 (4.1 - 6.6) | 4.3 (3.5 - 5.5) | 5.0 (3.5 - 6.6)
Week 16
N | 12 | 2 | 14
Mean (SD) | 4.9 (0.7) | 4.7 (1.1) | 4.9 (0.7)
Median (Min-Max) | 4.9 (3.9 - 6.2) | 4.7 (3.9 - 5.5) | 4.9 (3.9 - 6.2)
Week 20
N | 8 | 0 | 8
Mean (SD) | 4.9 (0.6) | 0 | 4.9 (0.6)
Median (Min-Max) | 4.9 (4.2 - 5.8) | 0 | 4.9 (4.2 - 5.8)
Week 28
N | 11 | 2 | 13
Mean (SD) | 4.9 (0.6) | 4.5 (0.5) | 4.8 (0.6)
Median (Min-Max) | 4.9 (4.1 - 6.2) | 4.5 (4.1 - 4.8) | 4.8 (4.1 - 6.2)
LOCF
N | 16 | 12 | 28
Mean (SD) | 5.1 (0.7) | 4.7 (0.7) | 4.9 (0.7)
Median (Min-Max) | 5.0 (4.1 - 6.3) | 4.8 (3.5 - 6.2) | 4.9 (3.5 - 6.3)
Change from Baseline to LOCF
N | 15 | 12 | 27
Mean (SD) | 0.0 (0.5) | −0.1 (0.4) | −0.1 (0.4)
Median (Min-Max) | 0.1 (−0.8 - 0.8) | −0.2 (−0.8 - 0.5) | −0.2 (−0.8 - 0.8)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.2.3.20 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Potassium (mEq/L) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 4.4 (0.2) | 4.4 (0.3) | 4.4 (0.3)
Median (Min-Max) | 4.4 (4.0 - 4.8) | 4.3 (4.0 - 4.9) | 4.3 (4.0 - 4.9)
Week 8
N | 13 | 3 | 16
Mean (SD) | 4.4 (0.3) | 4.2 (0.2) | 4.4 (0.3)
Median (Min-Max) | 4.4 (4.1 - 5.2) | 4.2 (4.0 - 4.3) | 4.4 (4.0 - 5.2)
Week 16
N | 12 | 2 | 14
Mean (SD) | 4.2 (0.3) | 4.1 (0.3) | 4.1 (0.3)
Median (Min-Max) | 4.1 (3.7 - 4.9) | 4.1 (3.9 - 4.3) | 4.1 (3.7 - 4.9)
Week 20
N | 8 | 0 | 8
Mean (SD) | 8.1 (11.7) | 0 | 8.1 (11.7)
Median (Min-Max) | 3.9 (3.8 - 37.0) | 0 | 3.9 (3.8 - 37.0)
Week 28
N | 11 | 2 | 13
Mean (SD) | 4.3 (0.4) | 4.2 (0.2) | 4.3 (0.3)
Median (Min-Max) | 4.3 (3.7 - 4.9) | 4.2 (4.0 - 4.3) | 4.3 (3.7 - 4.9)
LOCF
N | 16 | 12 | 28
Mean (SD) | 4.3 (0.4) | 4.2 (0.4) | 4.3 (0.4)
Median (Min-Max) | 4.3 (3.7 - 5.2) | 4.3 (3.3 - 4.9) | 4.3 (3.3 - 5.2)
Change from Baseline to LOCF
N | 16 | 12 | 28
Mean (SD) | −0.1 (0.3) | −0.1 (0.3) | −0.1 (0.3)
Median (Min-Max) | −0.2 (−0.4 - 1.0) | −0.1 (−0.8 - 0.3) | −0.1 (−0.8 - 1.0)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.2.3.21 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Total Protein (g/dL) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 7.0 (0.6) | 7.1 (0.5) | 7.0 (0.6)
Median (Min-Max) | 7.1 (6.0 - 8.2) | 7.0 (6.5 - 8.3) | 7.0 (6.0 - 8.3)
Week 8
N | 13 | 3 | 16
Mean (SD) | 7.0 (0.6) | 7.2 (0.4) | 7.1 (0.6)
Median (Min-Max) | 7.0 (6.2 - 8.4) | 7.2 (6.8 - 7.5) | 7.1 (6.2 - 8.4)
Week 16
N | 12 | 2 | 14
Mean (SD) | 6.8 (0.8) | 7.3 (0.1) | 6.9 (0.8)
Median (Min-Max) | 7.0 (4.6 - 7.8) | 7.3 (7.2 - 7.4) | 7.1 (4.6 - 7.8)
Week 20
N | 8 | 0 | 8
Mean (SD) | 6.8 (0.5) | 0 | 6.8 (0.5)
Median (Min-Max) | 6.9 (6.2 - 7.3) | 0 | 6.9 (6.2 - 7.3)
Week 28
N | 11 | 2 | 13
Mean (SD) | 7.0 (0.5) | 7.1 (0.2) | 7.0 (0.4)
Median (Min-Max) | 7.0 (6.2 - 7.8) | 7.1 (6.9 - 7.2) | 7.0 (6.2 - 7.8)
LOCF
N | 16 | 12 | 28
Mean (SD) | 7.0 (0.5) | 7.2 (0.5) | 7.1 (0.5)
Median (Min-Max) | 7.0 (6.2 - 7.8) | 7.2 (6.5 - 8.4) | 7.1 (6.2 - 8.4)
Change from Baseline to LOCF
N | 16 | 12 | 28
Mean (SD) | −0.1 (0.3) | 0.1 (0.2) | 0.0 (0.3)
Median (Min-Max) | −0.1 (−0.5 - 0.5) | 0.1 (−0.3 - 0.6) | 0.0 (−0.5 - 0.6)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.2.3.22 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Sodium (mEq/L) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 139.4 (2.3) | 139.9 (2.0) | 139.6 (2.1)
Median (Min-Max) | 139.0 (136.0 - 144.0) | 140.0 (136.0 - 143.0) | 139.0 (136.0 - 144.0)
Week 8
N | 13 | 3 | 16
Mean (SD) | 140.3 (2.9) | 138.3 (1.2) | 139.9 (2.7)
Median (Min-Max) | 139.0 (138.0 - 148.0) | 139.0 (137.0 - 139.0) | 139.0 (137.0 - 148.0)
Week 16
N | 12 | 2 | 14
Mean (SD) | 138.8 (1.9) | 138.5 (2.1) | 138.7 (1.8)
Median (Min-Max) | 138.5 (135.0 - 142.0) | 138.5 (137.0 - 140.0) | 138.5 (135.0 - 142.0)
Week 20
N | 8 | 0 | 8
Mean (SD) | 138.8 (1.6) | 0 | 138.8 (1.6)
Median (Min-Max) | 139.5 (136.0 - 140.0) | 0 | 139.5 (136.0 - 140.0)
Week 28
N | 11 | 2 | 13
Mean (SD) | 140.1 (2.9) | 138.0 (4.2) | 139.8 (3.0)
Median (Min-Max) | 140.0 (136.0 - 145.0) | 138.0 (135.0 - 141.0) | 140.0 (135.0 - 145.0)
LOCF
N | 16 | 12 | 28
Mean (SD) | 139.8 (2.5) | 128.1 (40.0) | 134.8 (26.3)
Median (Min-Max) | 140.0 (136.0 - 145.0) | 139.5 (1.4 - 144.0) | 140.0 (1.4 - 145.0)
Change from Baseline to LOCF
N | 16 | 12 | 28
Mean (SD) | 0.4 (2.2) | −11.4 (39.9) | −4.6 (26.2)
Median (Min-Max) | 0.0 (−2.0 - 6.0) | 0.0 (−138 - 4.0) | 0.0 (−138 - 6.0)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.2.3.23 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Triglycerides (mg/dL) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 16 | 14 | 30
Mean (SD) | 72.6 (47.5) | 110.9 (74.5) | 90.5 (63.5)
Median (Min-Max) | 55.5 (30.0 - 199.0) | 79.5 (33.0 - 250.0) | 61.0 (30.0 - 250.0)
Week 8
N | 13 | 3 | 16
Mean (SD) | 96.2 (46.3) | 55.7 (11.5) | 88.6 (44.7)
Median (Min-Max) | 75.0 (57.0 - 199.0) | 56.0 (44.0 - 67.0) | 69.5 (44.0 - 199.0)
Week 16
N | 12 | 2 | 14
Mean (SD) | 101.1 (43.4) | 83.5 (12.0) | 98.6 (40.5)
Median (Min-Max) | 86.5 (46.0 - 188.0) | 83.5 (75.0 - 92.0) | 86.0 (46.0 - 188.0)
Week 20
N | 8 | 0 | 8
Mean (SD) | 119.0 (55.0) | 0 | 119.0 (55.0)
Median (Min-Max) | 96.0 (52.0 - 190.0) | 0 | 96.0 (52.0 - 190.0)
Week 28
N | 11 | 2 | 13
Mean (SD) | 68.5 (26.7) | 53.5 (16.3) | 66.2 (25.4)
Median (Min-Max) | 68.0 (29.0 - 100.0) | 53.5 (42.0 - 65.0) | 66.0 (29.0 - 100.0)
LOCF
N | 16 | 12 | 28
Mean (SD) | 86.6 (41.2) | 103.7 (89.6) | 93.9 (65.5)
Median (Min-Max) | 87.0 (29.0 - 160.0) | 66.5 (29.0 - 348.0) | 75.5 (29.0 - 348.0)
Change from Baseline to LOCF
N | 15 | 12 | 27
Mean (SD) | 13.8 (34.8) | 5.5 (44.1) | 10.1 (38.6)
Median (Min-Max) | 15.0 (−51.0 - 67.0) | −6.5 (−57.0 - 98.0) | 1.0 (−57.0 - 98.0)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.2.3.24 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Urea Nitrogen (mg/dL) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 12.0 (4.1) | 9.2 (3.8) | 10.7 (4.1)
Median (Min-Max) | 13.0 (3.0 - 19.0) | 10.5 (2.0 - 14.0) | 11.0 (2.0 - 19.0)
Week 8
N | 13 | 3 | 16
Mean (SD) | 11.5 (3.7) | 9.0 (2.0) | 11.0 (3.5)
Median (Min-Max) | 11.0 (7.0 - 20.0) | 9.0 (7.0 - 11.0) | 10.5 (7.0 - 20.0)
Week 16
N | 12 | 2 | 14
Mean (SD) | 11.8 (3.9) | 11.0 (2.8) | 11.6 (3.7)
Median (Min-Max) | 11.0 (4.0 - 18.0) | 11.0 (9.0 - 13.0) | 11.0 (4.0 - 18.0)
Week 20
N | 8 | 0 | 8
Mean (SD) | 12.1 (5.9) | 0 | 12.1 (5.9)
Median (Min-Max) | 11.0 (6.0 - 25.0) | 0 | 11.0 (6.0 - 25.0)
Week 28
N | 11 | 2 | 13
Mean (SD) | 11.2 (3.1) | 7.0 (2.8) | 10.5 (3.4)
Median (Min-Max) | 11.0 (7.0 - 18.0) | 7.0 (5.0 - 9.0) | 10.0 (5.0 - 18.0)
LOCF
N | 16 | 12 | 28
Mean (SD) | 12.5 (3.9) | 10.5 (3.5) | 11.6 (3.8)
Median (Min-Max) | 11.5 (7.0 - 20.0) | 10.0 (5.0 - 17.0) | 10.5 (5.0 - 20.0)
Change from Baseline to LOCF
N | 16 | 12 | 28
Mean (SD) | 0.6 (2.5) | 0.8 (3.4) | 0.7 (2.9)
Median (Min-Max) | 0.5 (−3.0 - 5.0) | 1.5 (−3.0 - 6.0) | 1.0 (−3.0 - 6.0)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.2.3.25 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Uric Acid (mg/dL) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 16 | 14 | 30
Mean (SD) | 5.6 (2.9) | 5.7 (2.0) | 5.6 (2.5)
Median (Min-Max) | 4.9 (2.8 - 15.4) | 5.3 (3.0 - 10.3) | 4.9 (2.8 - 15.4)
Week 8
N | 13 | 3 | 16
Mean (SD) | 4.6 (1.3) | 4.5 (2.4) | 4.6 (1.4)
Median (Min-Max) | 4.4 (2.7 - 7.6) | 3.8 (2.5 - 7.1) | 4.4 (2.5 - 7.6)
Week 16
N | 11 | 2 | 13
Mean (SD) | 4.4 (1.1) | 4.2 (2.8) | 4.4 (1.3)
Median (Min-Max) | 4.3 (2.8 - 6.5) | 4.2 (2.2 - 6.1) | 4.3 (2.2 - 6.5)
Week 20
N | 8 | 0 | 8
Mean (SD) | 4.8 (0.9) | 0 | 4.8 (0.9)
Median (Min-Max) | 4.9 (3.7 - 6.1) | 0 | 4.9 (3.7 - 6.1)
Week 28
N | 10 | 2 | 12
Mean (SD) | 4.6 (1.4) | 4.5 (3.4) | 4.6 (1.6)
Median (Min-Max) | 4.2 (2.2 - 6.8) | 4.5 (2.1 - 6.9) | 4.2 (2.1 - 6.9)
LOCF
N | 15 | 11 | 26
Mean (SD) | 5.0 (1.5) | 4.8 (1.5) | 5.0 (1.5)
Median (Min-Max) | 5.0 (2.2 - 8.0) | 4.2 (2.1 - 6.9) | 4.7 (2.1 - 8.0)
Change from Baseline to LOCF
N | 15 | 11 | 26
Mean (SD) | −0.6 (2.8) | −0.9 (1.1) | −0.8 (2.2)
Median (Min-Max) | −0.3 (−10.2 - 1.9) | −0.7 (−3.4 - 0.3) | −0.4 (−10.2 - 1.9)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.2.3.26 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Creatinine Clearance (mL/min/1.7m^2^) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 134.6 (36.3) | 124.2 (28.4) | 129.9 (32.8)
Median (Min-Max) | 133.7 (58.4 - 202.8) | 123.6 (68.1 - 171.1) | 130.5 (58.4 - 202.8)
Week 8
N | 13 | 3 | 16
Mean (SD) | 125.7 (26.2) | 136.8 (51.4) | 127.8 (30.4)
Median (Min-Max) | 120.3 (65.6 - 180.3) | 128.4 (90.1 - 191.9) | 123.9 (65.6 - 191.9)
Week 16
N | 12 | 2 | 14
Mean (SD) | 114.4 (25.1) | 146.1 (7.6) | 118.9 (25.9)
Median (Min-Max) | 115.1 (57.2 - 165.0) | 146.1 (140.7 - 151.5) | 118.9 (57.2 - 165.0)
Week 20
N | 8 | 0 | 8
Mean (SD) | 115.8 (24.4) | 0 | 115.8 (24.4)
Median (Min-Max) | 118.7 (65.2 - 139.9) | 0 | 118.7 (65.2 - 139.9)
Week 28
N | 11 | 2 | 13
Mean (SD) | 128.8 (24.8) | 133.7 (9.2) | 129.6 (22.9)
Median (Min-Max) | 127.0 (76.8 - 169.4) | 133.7 (127.2 - 140.2) | 127.2 (76.8 - 169.4)
LOCF
N | 16 | 12 | 28
Mean (SD) | 127.7 (23.7) | 113.3 (41.2) | 121.5 (32.5)
Median (Min-Max) | 121.5 (76.8 - 169.4) | 127.8 (5.7 - 147.4) | 125.0 (5.7 - 169.4)
Change from Baseline to LOCF
N | 16 | 12 | 28
Mean (SD) | −8.7 (37.7) | −8.7 (32.7) | −8.7 (35.0)
Median (Min-Max) | −7.6 (−84.6 - 37.7) | 2.6 (−84.4 - 26.9) | −2.3 (−84.6 - 37.7)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.2.4.1 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Albumin (g/dL) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 4.2 (0.4) | 4.2 (0.5) | 4.2 (0.4)
Median (Min-Max) | 4.2 (3.8 - 4.6) | 4.2 (3.4 - 5.0) | 4.2 (3.4 - 5.0)
Week 4
N | 2 | 8 | 10
Mean (SD) | 4.3 (0.1) | 4.1 (0.3) | 4.1 (0.3)
Median (Min-Max) | 4.3 (4.2 - 4.3) | 4.2 (3.6 - 4.4) | 4.2 (3.6 - 4.4)
Week 8
N | 2 | 7 | 9
Mean (SD) | 4.3 (0.5) | 4.2 (0.3) | 4.2 (0.3)
Median (Min-Max) | 4.3 (3.9 - 4.6) | 4.2 (3.8 - 4.7) | 4.2 (3.8 - 4.7)
LOCF
N | 2 | 10 | 12
Mean (SD) | 4.3 (0.5) | 4.2 (0.4) | 4.2 (0.4)
Median (Min-Max) | 4.3 (3.9 - 4.6) | 4.2 (3.6 - 4.9) | 4.2 (3.6 - 4.9)
Change from Baseline to LOCF
N | 2 | 10 | 12
Mean (SD) | −0.2 (0.2) | 0.0 (0.3) | 0.0 (0.3)
Median (Min-Max) | −0.2 (−0.3 - 0.0) | −0.1 (−0.3 - 0.6) | −0.1 (−0.3 - 0.6)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.2.4.2 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Alkaline Phosphatase (U/L) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 458.7 (78.9) | 228.2 (112.0) | 281.4 (143.7)
Median (Min-Max) | 496.0 (368.0 - 512.0) | 251.5 (80.0 - 447.0) | 267.0 (80.0 - 512.0)
Week 4
N | 2 | 8 | 10
Mean (SD) | 475.5 (58.7) | 249.4 (143.5) | 294.6 (159.7)
Median (Min-Max) | 475.5 (434.0 - 517.0) | 241.0 (87.0 - 536.0) | 259.0 (87.0 - 536.0)
Week 8
N | 2 | 7 | 9
Mean (SD) | 488.0 (25.5) | 278.1 (151.6) | 324.8 (160.9)
Median (Min-Max) | 488.0 (470.0 - 506.0) | 246.0 (89.0 - 550.0) | 331.0 (89.0 - 550.0)
LOCF
N | 2 | 10 | 12
Mean (SD) | 488.0 (25.5) | 264.5 (134.3) | 301.8 (149.6)
Median (Min-Max) | 488.0 (470.0 - 506.0) | 267.0 (89.0 - 550.0) | 290.5 (89.0 - 550.0)
Change from Baseline to LOCF
N | 2 | 10 | 12
Mean (SD) | −16.0 (36.8) | 36.3 (37.1) | 27.6 (40.8)
Median (Min-Max) | −16.0 (−42.0 - 10.0) | 30.0 (−19.0 - 103.0) | 21.5 (−42.0 - 103.0)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.2.4.3 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Alanine Aminotransferase - ALT (U/L) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 28.3 (4.5) | 30.2 (21.5) | 29.8 (18.7)
Median (Min-Max) | 28.0 (24.0 - 33.0) | 25.0 (15.0 - 88.0) | 26.0 (15.0 - 88.0)
Week 4
N | 2 | 8 | 10
Mean (SD) | 31.5 (3.5) | 30.4 (15.9) | 30.6 (14.1)
Median (Min-Max) | 31.5 (29.0 - 34.0) | 29.5 (14.0 - 66.0) | 29.5 (14.0 - 66.0)
Week 8
N | 2 | 7 | 9
Mean (SD) | 32.5 (4.9) | 31.4 (15.0) | 31.7 (13.1)
Median (Min-Max) | 32.5 (29.0 - 36.0) | 33.0 (13.0 - 59.0) | 33.0 (13.0 - 59.0)
LOCF
N | 2 | 10 | 12
Mean (SD) | 32.5 (4.9) | 28.3 (13.3) | 29.0 (12.2)
Median (Min-Max) | 32.5 (29.0 - 36.0) | 27.0 (13.0 - 59.0) | 30.0 (13.0 - 59.0)
Change from Baseline to LOCF
N | 2 | 10 | 12
Mean (SD) | 2.0 (1.4) | −1.9 (10.0) | −1.3 (9.2)
Median (Min-Max) | 2.0 (1.0 - 3.0) | −1.0 (−29.0 - 7.0) | 0.0 (−29.0 - 7.0)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.2.4.4 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Aspartate Aminotransferase - AST (U/L) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 18.7 (6.0) | 21.9 (14.0) | 21.2 (12.5)
Median (Min-Max) | 18.0 (13.0 - 25.0) | 18.5 (11.0 - 60.0) | 18.0 (11.0 - 60.0)
Week 4
N | 2 | 8 | 10
Mean (SD) | 21.0 (2.8) | 20.1 (9.3) | 20.3 (8.3)
Median (Min-Max) | 21.0 (19.0 - 23.0) | 20.5 (8.0 - 35.0) | 20.5 (8.0 - 35.0)
Week 8
N | 2 | 7 | 9
Mean (SD) | 19.5 (3.5) | 22.3 (9.7) | 21.7 (8.6)
Median (Min-Max) | 19.5 (17.0 - 22.0) | 20.0 (9.0 - 38.0) | 20.0 (9.0 - 38.0)
LOCF
N | 2 | 10 | 12
Mean (SD) | 19.5 (3.5) | 22.8 (8.3) | 22.3 (7.7)
Median (Min-Max) | 19.5 (17.0 - 22.0) | 22.5 (9.0 - 38.0) | 21.0 (9.0 - 38.0)
Change from Baseline to LOCF
N | 2 | 10 | 12
Mean (SD) | −2.0 (1.4) | 0.9 (9.3) | 0.4 (8.5)
Median (Min-Max) | −2.0 (−3.0 - −1.0) | 3.5 (−22.0 - 11.0) | 1.0 (−22.0 - 11.0)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.2.4.5 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Bicarbonate (mEq/L) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 27.7 (2.1) | 26.4 (2.0) | 26.7 (2.0)
Median (Min-Max) | 27.0 (26.0 - 30.0) | 26.5 (23.0 - 29.0) | 27.0 (23.0 - 30.0)
Week 4
N | 2 | 8 | 10
Mean (SD) | 28.5 (0.7) | 27.5 (3.3) | 27.7 (2.9)
Median (Min-Max) | 28.5 (28.0 - 29.0) | 28.5 (22.0 - 32.0) | 28.5 (22.0 - 32.0)
Week 8
N | 2 | 7 | 9
Mean (SD) | 26.0 (1.4) | 26.1 (2.7) | 26.1 (2.4)
Median (Min-Max) | 26.0 (25.0 - 27.0) | 27.0 (22.0 - 30.0) | 27.0 (22.0 - 30.0)
LOCF
N | 2 | 10 | 12
Mean (SD) | 26.0 (1.4) | 25.4 (2.5) | 25.5 (2.3)
Median (Min-Max) | 26.0 (25.0 - 27.0) | 24.5 (22.0 - 30.0) | 25.0 (22.0 - 30.0)
Change from Baseline to LOCF
N | 2 | 10 | 12
Mean (SD) | −2.5 (0.7) | −1.0 (2.0) | −1.3 (1.9)
Median (Min-Max) | −2.5 (−3.0 - −2.0) | −1.0 (−4.0 - 3.0) | −1.5 (−4.0 - 3.0)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.2.4.6 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Direct Bilirubin (mg/dL) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 0.2 (0.1) | 0.1 (0.0) | 0.1 (0.1)
Median (Min-Max) | 0.1 (0.1 - 0.3) | 0.1 (0.1 - 0.2) | 0.1 (0.1 - 0.3)
Week 4
N | 2 | 8 | 10
Mean (SD) | 0.2 (0.1) | 0.1 (0.0) | 0.1 (0.1)
Median (Min-Max) | 0.2 (0.1 - 0.3) | 0.1 (0.1 - 0.1) | 0.1 (0.1 - 0.3)
Week 8
N | 2 | 7 | 9
Mean (SD) | 0.2 (0.0) | 0.1 (0.0) | 0.1 (0.1)
Median (Min-Max) | 0.2 (0.2 - 0.2) | 0.1 (0.1 - 0.2) | 0.1 (0.1 - 0.2)
LOCF
N | 2 | 10 | 12
Mean (SD) | 0.2 (0.0) | 0.1 (0.0) | 0.1 (0.0)
Median (Min-Max) | 0.2 (0.2 - 0.2) | 0.1 (0.1 - 0.2) | 0.1 (0.1 - 0.2)
Change from Baseline to LOCF
N | 2 | 10 | 12
Mean (SD) | 0.0 (0.1) | 0.0 (0.1) | 0.0 (0.1)
Median (Min-Max) | 0.0 (−0.1 - 0.1) | 0.0 (−0.1 - 0.1) | 0.0 (−0.1 - 0.1)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.2.4.7 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Total Bilirubin (mg/dL) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 0.5 (0.6) | 0.5 (0.2) | 0.5 (0.3)
Median (Min-Max) | 0.1 (0.1 - 1.2) | 0.6 (0.3 - 0.9) | 0.5 (0.1 - 1.2)
Week 4
N | 2 | 8 | 10
Mean (SD) | 0.5 (0.4) | 0.5 (0.2) | 0.5 (0.2)
Median (Min-Max) | 0.5 (0.2 - 0.8) | 0.6 (0.2 - 0.8) | 0.6 (0.2 - 0.8)
Week 8
N | 2 | 7 | 9
Mean (SD) | 0.9 (0.7) | 0.7 (0.4) | 0.7 (0.4)
Median (Min-Max) | 0.9 (0.4 - 1.4) | 0.6 (0.2 - 1.4) | 0.6 (0.2 - 1.4)
LOCF
N | 2 | 10 | 12
Mean (SD) | 0.9 (0.7) | 0.6 (0.3) | 0.7 (0.4)
Median (Min-Max) | 0.9 (0.4 - 1.4) | 0.6 (0.2 - 1.4) | 0.6 (0.2 - 1.4)
Change from Baseline to LOCF
N | 2 | 10 | 12
Mean (SD) | 0.3 (0.1) | 0.1 (0.2) | 0.1 (0.2)
Median (Min-Max) | 0.3 (0.2 - 0.3) | 0.1 (−0.3 - 0.6) | 0.1 (−0.3 - 0.6)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.2.4.8 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Calcium (mg/dL) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 9.7 (0.5) | 9.8 (0.4) | 9.8 (0.4)
Median (Min-Max) | 9.5 (9.3 - 10.3) | 9.8 (9.3 - 10.6) | 9.7 (9.3 - 10.6)
Week 4
N | 2 | 8 | 10
Mean (SD) | 9.6 (0.4) | 9.6 (0.3) | 9.6 (0.3)
Median (Min-Max) | 9.6 (9.3 - 9.8) | 9.7 (9.1 - 10.1) | 9.7 (9.1 - 10.1)
Week 8
N | 2 | 7 | 9
Mean (SD) | 10.0 (0.8) | 9.8 (0.4) | 9.8 (0.5)
Median (Min-Max) | 10.0 (9.4 - 10.5) | 9.7 (9.1 - 10.3) | 9.7 (9.1 - 10.5)
LOCF
N | 2 | 10 | 12
Mean (SD) | 10.0 (0.8) | 9.8 (0.4) | 9.8 (0.5)
Median (Min-Max) | 10.0 (9.4 - 10.5) | 9.7 (9.1 - 10.3) | 9.7 (9.1 - 10.5)
Change from Baseline to LOCF
N | 2 | 10 | 12
Mean (SD) | 0.1 (0.2) | 0.0 (0.5) | 0.0 (0.4)
Median (Min-Max) | 0.1 (−0.1 - 0.2) | −0.2 (−0.7 - 1.0) | −0.1 (−0.7 - 1.0)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.2.4.9 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Chloride (mEq/L) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 104.0 (2.0) | 103.9 (3.0) | 103.9 (2.7)
Median (Min-Max) | 104.0 (102.0 - 106.0) | 105.0 (99.0 - 107.0) | 105.0 (99.0 - 107.0)
Week 4
N | 2 | 8 | 10
Mean (SD) | 101.0 (0.0) | 103.9 (1.6) | 103.3 (1.9)
Median (Min-Max) | 101.0 (101.0 - 101.0) | 104.0 (101.0 - 106.0) | 104.0 (101.0 - 106.0)
Week 8
N | 2 | 7 | 9
Mean (SD) | 104.0 (1.4) | 103.3 (3.5) | 103.4 (3.1)
Median (Min-Max) | 104.0 (103.0 - 105.0) | 103.0 (99.0 - 108.0) | 103.0 (99.0 - 108.0)
LOCF
N | 2 | 10 | 12
Mean (SD) | 104.0 (1.4) | 104.0 (3.2) | 104.0 (2.9)
Median (Min-Max) | 104.0 (103.0 - 105.0) | 104.0 (99.0 - 108.0) | 104.0 (99.0 - 108.0)
Change from Baseline to LOCF
N | 2 | 10 | 12
Mean (SD) | 0.0 (1.4) | 0.1 (2.4) | 0.1 (2.2)
Median (Min-Max) | 0.0 (−1.0 - 1.0) | 0.0 (−5.0 - 3.0) | 0.0 (−5.0 - 3.0)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.2.4.10 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Cholesterol (mg/dL) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 148.0 (9.5) | 163.0 (27.6) | 159.5 (25.1)
Median (Min-Max) | 153.0 (137.0 - 154.0) | 158.0 (121.0 - 199.0) | 153.0 (121.0 - 199.0)
Week 4
N | 2 | 8 | 10
Mean (SD) | 147.0 (2.8) | 150.8 (20.2) | 150.0 (18.0)
Median (Min-Max) | 147.0 (145.0 - 149.0) | 157.5 (117.0 - 175.0) | 152.0 (117.0 - 175.0)
Week 8
N | 2 | 7 | 9
Mean (SD) | 164.5 (30.4) | 162.6 (24.4) | 163.0 (23.7)
Median (Min-Max) | 164.5 (143.0 - 186.0) | 167.0 (132.0 - 199.0) | 167.0 (132.0 - 199.0)
LOCF
N | 2 | 10 | 12
Mean (SD) | 164.5 (30.4) | 162.1 (24.8) | 162.5 (24.3)
Median (Min-Max) | 164.5 (143.0 - 186.0) | 167.0 (125.0 - 199.0) | 167.0 (125.0 - 199.0)
Change from Baseline to LOCF
N | 2 | 10 | 12
Mean (SD) | 11.0 (29.7) | −0.9 (18.1) | 1.1 (19.2)
Median (Min-Max) | 11.0 (−10.0 - 32.0) | −5.5 (−23.0 - 36.0) | −5.5 (−23.0 - 36.0)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.2.4.11 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Creatine kinase (U/L) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 87.7 (37.4) | 115.7 (55.0) | 109.2 (51.5)
Median (Min-Max) | 74.0 (59.0 - 130.0) | 109.5 (37.0 - 219.0) | 105.0 (37.0 - 219.0)
Week 4
N | 2 | 8 | 10
Mean (SD) | 78.0 (26.9) | 114.9 (77.4) | 107.5 (70.6)
Median (Min-Max) | 78.0 (59.0 - 97.0) | 97.5 (29.0 - 222.0) | 96.0 (29.0 - 222.0)
Week 8
N | 2 | 7 | 9
Mean (SD) | 59.5 (26.2) | 146.4 (125.7) | 127.1 (115.8)
Median (Min-Max) | 59.5 (41.0 - 78.0) | 83.0 (33.0 - 355.0) | 78.0 (33.0 - 355.0)
LOCF
N | 2 | 10 | 12
Mean (SD) | 59.5 (26.2) | 142.2 (109.8) | 128.4 (104.7)
Median (Min-Max) | 59.5 (41.0 - 78.0) | 98.0 (33.0 - 355.0) | 80.5 (33.0 - 355.0)
Change from Baseline to LOCF
N | 2 | 10 | 12
Mean (SD) | −7.0 (15.6) | 26.5 (67.6) | 20.9 (62.7)
Median (Min-Max) | −7.0 (−18.0 - 4.0) | 4.5 (−80.0 - 136.0) | 1.5 (−80.0 - 136.0)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.2.4.12 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Creatinine (mg/dL) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 0.7 (0.0) | 1.9 (3.7) | 1.6 (3.3)
Median (Min-Max) | 0.8 (0.7 - 0.8) | 0.7 (0.5 - 12.5) | 0.7 (0.5 - 12.5)
Week 4
N | 2 | 8 | 10
Mean (SD) | 0.7 (0.0) | 0.7 (0.1) | 0.7 (0.1)
Median (Min-Max) | 0.7 (0.6 - 0.7) | 0.7 (0.6 - 0.9) | 0.7 (0.6 - 0.9)
Week 8
N | 2 | 7 | 9
Mean (SD) | 0.7 (0.1) | 0.7 (0.1) | 0.7 (0.1)
Median (Min-Max) | 0.7 (0.6 - 0.8) | 0.8 (0.6 - 0.8) | 0.8 (0.6 - 0.8)
LOCF
N | 2 | 10 | 12
Mean (SD) | 0.7 (0.1) | 0.7 (0.2) | 0.7 (0.1)
Median (Min-Max) | 0.7 (0.6 - 0.8) | 0.7 (0.5 - 0.9) | 0.7 (0.5 - 0.9)
Change from Baseline to LOCF
N | 2 | 10 | 12
Mean (SD) | −0.1 (0.1) | −1.2 (3.7) | −1.0 (3.3)
Median (Min-Max) | −0.1 (−0.1 - 0.0) | 0.0 (−11.6 - 0.1) | 0.0 (−11.6 - 0.1)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.2.4.13 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Glucose Tolerance Test - GGT (U/L) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 14.7 (8.0) | 25.5 (19.2) | 23.0 (17.6)
Median (Min-Max) | 14.0 (7.0 - 23.0) | 21.5 (10.0 - 76.0) | 21.0 (7.0 - 76.0)
Week 4
N | 2 | 8 | 10
Mean (SD) | 12.0 (1.4) | 26.1 (24.0) | 23.3 (22.0)
Median (Min-Max) | 12.0 (11.0 - 13.0) | 17.5 (10.0 - 84.0) | 16.0 (10.0 - 84.0)
Week 8
N | 2 | 7 | 9
Mean (SD) | 14.0 (1.4) | 27.3 (28.2) | 24.3 (25.2)
Median (Min-Max) | 14.0 (13.0 - 15.0) | 17.0 (13.0 - 91.0) | 16.0 (13.0 - 91.0)
LOCF
N | 2 | 10 | 12
Mean (SD) | 14.0 (1.4) | 26.5 (23.3) | 24.4 (21.6)
Median (Min-Max) | 14.0 (13.0 - 15.0) | 17.5 (13.0 - 91.0) | 17.0 (13.0 - 91.0)
Change from Baseline to LOCF
N | 2 | 10 | 12
Mean (SD) | 3.5 (6.4) | 1.0 (8.3) | 1.4 (7.8)
Median (Min-Max) | 3.5 (−1.0 - 8.0) | 1.0 (−14.0 - 15.0) | 1.0 (−14.0 - 15.0)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.2.4.14 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Glucose (mg/dL) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 89.0 (5.3) | 81.5 (14.1) | 83.2 (12.9)
Median (Min-Max) | 87.0 (85.0 - 95.0) | 83.5 (48.0 - 99.0) | 84.0 (48.0 - 99.0)
Week 4
N | 2 | 8 | 10
Mean (SD) | 78.0 (17.0) | 96.1 (15.9) | 92.5 (16.9)
Median (Min-Max) | 78.0 (66.0 - 90.0) | 91.5 (76.0 - 127.0) | 90.5 (66.0 - 127.0)
Week 8
N | 2 | 7 | 9
Mean (SD) | 87.5 (7.8) | 89.0 (4.4) | 88.7 (4.7)
Median (Min-Max) | 87.5 (82.0 - 93.0) | 87.0 (85.0 - 96.0) | 87.0 (82.0 - 96.0)
LOCF
N | 2 | 10 | 12
Mean (SD) | 87.5 (7.8) | 86.8 (5.8) | 86.9 (5.7)
Median (Min-Max) | 87.5 (82.0 - 93.0) | 86.5 (76.0 - 96.0) | 86.5 (76.0 - 96.0)
Change from Baseline to LOCF
N | 2 | 10 | 12
Mean (SD) | 1.5 (9.2) | 5.3 (15.9) | 4.7 (14.7)
Median (Min-Max) | 1.5 (−5.0 - 8.0) | 3.0 (−12.0 - 45.0) | 3.0 (−12.0 - 45.0)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.2.4.15 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group High Density Lipoprotein - HDL (mg/dL) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 8 | 11
Mean (SD) | 43.7 (8.3) | 46.9 (13.0) | 46.0 (11.6)
Median (Min-Max) | 41.0 (37.0 - 53.0) | 50.0 (30.0 - 63.0) | 46.0 (30.0 - 63.0)
Week 4
N | 2 | 7 | 9
Mean (SD) | 53.5 (7.8) | 47.3 (14.8) | 48.7 (13.4)
Median (Min-Max) | 53.5 (48.0 - 59.0) | 45.0 (32.0 - 67.0) | 48.0 (32.0 - 67.0)
Week 8
N | 2 | 6 | 8
Mean (SD) | 53.5 (16.3) | 47.8 (16.5) | 49.3 (15.5)
Median (Min-Max) | 53.5 (42.0 - 65.0) | 44.0 (30.0 - 73.0) | 45.5 (30.0 - 73.0)
LOCF
N | 2 | 8 | 10
Mean (SD) | 53.5 (16.3) | 46.3 (15.4) | 47.7 (14.9)
Median (Min-Max) | 53.5 (42.0 - 65.0) | 44.0 (30.0 - 73.0) | 45.5 (30.0 - 73.0)
Change from Baseline to LOCF
N | 2 | 7 | 9
Mean (SD) | 6.5 (7.8) | 0.9 (8.9) | 2.1 (8.5)
Median (Min-Max) | 6.5 (1.0 - 12.0) | 0.0 (−7.0 - 19.0) | 1.0 (−7.0 - 19.0)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.2.4.16 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Cholesterol/HDL Ratio Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 8 | 11
Mean (SD) | 3.4 (0.5) | 3.8 (1.4) | 3.7 (1.2)
Median (Min-Max) | 3.7 (2.9 - 3.7) | 3.1 (2.4 - 5.6) | 3.1 (2.4 - 5.6)
Week 4
N | 2 | 7 | 9
Mean (SD) | 2.8 (0.4) | 3.5 (1.0) | 3.3 (0.9)
Median (Min-Max) | 2.8 (2.5 - 3.1) | 3.2 (2.5 - 4.8) | 3.1 (2.5 - 4.8)
Week 8
N | 2 | 6 | 8
Mean (SD) | 3.2 (0.4) | 3.6 (1.1) | 3.5 (1.0)
Median (Min-Max) | 3.2 (2.9 - 3.4) | 3.1 (2.7 - 5.2) | 3.2 (2.7 - 5.2)
LOCF
N | 2 | 7 | 9
Mean (SD) | 3.2 (0.4) | 3.9 (1.3) | 3.7 (1.2)
Median (Min-Max) | 3.2 (2.9 - 3.4) | 3.4 (2.7 - 5.9) | 3.4 (2.7 - 5.9)
Change from Baseline to LOCF
N | 2 | 7 | 9
Mean (SD) | −0.2 (0.2) | 0.0 (0.4) | 0.0 (0.3)
Median (Min-Max) | −0.2 (−0.3 - 0.0) | 0.2 (−0.7 - 0.3) | 0.1 (−0.7 - 0.3)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.2.4.17 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Low Density Lipoprotein - LDL (mg/dL) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 8 | 11
Mean (SD) | 77.3 (12.9) | 96.3 (25.4) | 91.1 (23.8)
Median (Min-Max) | 72.0 (68.0 - 92.0) | 94.5 (66.0 - 127.0) | 92.0 (66.0 - 127.0)
Week 4
N | 2 | 7 | 9
Mean (SD) | 80.5 (13.4) | 83.3 (14.1) | 82.7 (13.2)
Median (Min-Max) | 80.5 (71.0 - 90.0) | 81.0 (69.0 - 109.0) | 81.0 (69.0 - 109.0)
Week 8
N | 2 | 6 | 8
Mean (SD) | 100.0 (15.6) | 87.5 (33.2) | 90.6 (29.2)
Median (Min-Max) | 100.0 (89.0 - 111.0) | 95.0 (29.0 - 116.0) | 97.5 (29.0 - 116.0)
LOCF
N | 2 | 8 | 10
Mean (SD) | 100.0 (15.6) | 93.9 (30.4) | 95.1 (27.4)
Median (Min-Max) | 100.0 (89.0 - 111.0) | 109.0 (29.0 - 116.0) | 108.5 (29.0 - 116.0)
Change from Baseline to LOCF
N | 2 | 7 | 9
Mean (SD) | 18.0 (29.7) | −0.6 (23.0) | 3.6 (23.9)
Median (Min-Max) | 18.0 (−3.0 - 39.0) | 9.0 (−46.0 - 19.0) | 9.0 (−46.0 - 39.0)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.2.4.18 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Magnesium (mg/dL) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 2.0 (0.1) | 2.1 (0.4) | 2.1 (0.3)
Median (Min-Max) | 1.9 (1.9 - 2.1) | 2.2 (1.3 - 2.5) | 2.1 (1.3 - 2.5)
Week 4
N | 2 | 8 | 10
Mean (SD) | 1.9 (0.0) | 2.1 (0.3) | 2.1 (0.3)
Median (Min-Max) | 1.9 (1.9 - 1.9) | 2.1 (1.5 - 2.6) | 2.0 (1.5 - 2.6)
Week 8
N | 2 | 7 | 9
Mean (SD) | 1.9 (0.0) | 2.2 (0.3) | 2.2 (0.3)
Median (Min-Max) | 1.9 (1.9 - 1.9) | 2.2 (1.8 - 2.8) | 2.1 (1.8 - 2.8)
LOCF
N | 2 | 10 | 12
Mean (SD) | 1.9 (0.0) | 2.2 (0.3) | 2.2 (0.3)
Median (Min-Max) | 1.9 (1.9 - 1.9) | 2.2 (1.8 - 2.8) | 2.1 (1.8 - 2.8)
Change from Baseline to LOCF
N | 2 | 10 | 12
Mean (SD) | −0.1 (0.1) | 0.1 (0.2) | 0.1 (0.2)
Median (Min-Max) | −0.1 (−0.2 - 0.0) | 0.1 (−0.1 - 0.5) | 0.1 (−0.2 - 0.5)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.2.4.19 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Phosphorus (mg/dL) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 5.8 (0.6) | 4.7 (0.7) | 5.0 (0.8)
Median (Min-Max) | 5.9 (5.2 - 6.3) | 4.8 (3.5 - 6.2) | 4.9 (3.5 - 6.3)
Week 4
N | 2 | 8 | 10
Mean (SD) | 5.6 (0.9) | 4.7 (0.9) | 4.9 (1.0)
Median (Min-Max) | 5.6 (4.9 - 6.2) | 4.6 (3.5 - 6.1) | 4.9 (3.5 - 6.2)
Week 8
N | 2 | 7 | 9
Mean (SD) | 5.1 (0.3) | 4.7 (0.6) | 4.8 (0.5)
Median (Min-Max) | 5.1 (4.9 - 5.3) | 4.6 (3.9 - 5.7) | 4.7 (3.9 - 5.7)
LOCF
N | 2 | 10 | 12
Mean (SD) | 5.1 (0.3) | 4.6 (0.6) | 4.7 (0.6)
Median (Min-Max) | 5.1 (4.9 - 5.3) | 4.6 (3.9 - 5.7) | 4.7 (3.9 - 5.7)
Change from Baseline to LOCF
N | 2 | 10 | 12
Mean (SD) | −0.5 (0.2) | −0.1 (0.5) | −0.1 (0.5)
Median (Min-Max) | −0.5 (−0.6 - −0.3) | −0.1 (−0.6 - 1.0) | −0.2 (−0.6 - 1.0)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.2.4.20 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Potassium (mEq/L) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 4.7 (0.5) | 4.3 (0.5) | 4.4 (0.5)
Median (Min-Max) | 4.6 (4.2 - 5.2) | 4.3 (3.3 - 4.9) | 4.3 (3.3 - 5.2)
Week 4
N | 2 | 8 | 10
Mean (SD) | 4.2 (0.4) | 4.4 (0.4) | 4.3 (0.4)
Median (Min-Max) | 4.2 (3.9 - 4.4) | 4.4 (3.8 - 5.3) | 4.4 (3.8 - 5.3)
Week 8
N | 2 | 7 | 9
Mean (SD) | 4.4 (0.0) | 4.2 (0.2) | 4.3 (0.2)
Median (Min-Max) | 4.4 (4.4 - 4.4) | 4.2 (4.0 - 4.5) | 4.4 (4.0 - 4.5)
LOCF
N | 2 | 10 | 12
Mean (SD) | 4.4 (0.0) | 4.3 (0.2) | 4.3 (0.2)
Median (Min-Max) | 4.4 (4.4 - 4.4) | 4.2 (4.0 - 4.5) | 4.3 (4.0 - 4.5)
Change from Baseline to LOCF
N | 2 | 10 | 12
Mean (SD) | −0.5 (0.4) | 0.0 (0.5) | −0.1 (0.5)
Median (Min-Max) | −0.5 (−0.8 - −0.2) | −0.1 (−0.9 - 0.9) | −0.2 (−0.9 - 0.9)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.2.4.21 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Total Protein (g/dL) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 6.9 (0.3) | 7.2 (0.6) | 7.1 (0.5)
Median (Min-Max) | 6.9 (6.6 - 7.1) | 7.2 (6.5 - 8.4) | 7.1 (6.5 - 8.4)
Week 4
N | 2 | 8 | 10
Mean (SD) | 7.0 (0.2) | 7.2 (0.8) | 7.2 (0.7)
Median (Min-Max) | 7.0 (6.8 - 7.1) | 7.3 (6.0 - 8.6) | 7.1 (6.0 - 8.6)
Week 8
N | 2 | 7 | 9
Mean (SD) | 7.1 (0.8) | 7.2 (0.8) | 7.2 (0.8)
Median (Min-Max) | 7.1 (6.5 - 7.6) | 7.2 (6.4 - 8.6) | 7.2 (6.4 - 8.6)
LOCF
N | 2 | 10 | 12
Mean (SD) | 7.1 (0.8) | 7.2 (0.7) | 7.2 (0.7)
Median (Min-Max) | 7.1 (6.5 - 7.6) | 7.2 (6.4 - 8.6) | 7.2 (6.4 - 8.6)
Change from Baseline to LOCF
N | 2 | 10 | 12
Mean (SD) | 0.1 (0.6) | −0.1 (0.3) | 0.0 (0.4)
Median (Min-Max) | 0.1 (−0.4 - 0.5) | −0.2 (−0.4 - 0.5) | −0.2 (−0.4 - 0.5)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.2.4.22 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Sodium (mEq/L) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 140.0 (0.0) | 126.1 (43.9) | 129.3 (38.5)
Median (Min-Max) | 140.0 (140.0 - 140.0) | 139.5 (1.4 - 144.0) | 140.0 (1.4 - 144.0)
Week 4
N | 2 | 8 | 10
Mean (SD) | 141.5 (0.7) | 139.1 (3.1) | 139.6 (2.9)
Median (Min-Max) | 141.5 (141.0 - 142.0) | 139.0 (136.0 - 145.0) | 139.0 (136.0 - 145.0)
Week 8
N | 2 | 7 | 9
Mean (SD) | 140.5 (0.7) | 138.7 (2.6) | 139.1 (2.4)
Median (Min-Max) | 140.5 (140.0 - 141.0) | 139.0 (135.0 - 142.0) | 140.0 (135.0 - 142.0)
LOCF
N | 2 | 10 | 12
Mean (SD) | 140.5 (0.7) | 138.3 (2.3) | 138.7 (2.3)
Median (Min-Max) | 140.5 (140.0 - 141.0) | 138.5 (135.0 - 142.0) | 139.0 (135.0 - 142.0)
Change from Baseline to LOCF
N | 2 | 10 | 12
Mean (SD) | 0.5 (0.7) | 12.2 (43.4) | 10.2 (39.5)
Median (Min-Max) | 0.5 (0.0 - 1.0) | −1.5 (−4.0 - 135.6) | −1.0 (−4.0 - 135.6)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.2.4.23 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Triglycerides (mg/dL) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 135.0 (31.2) | 113.7 (95.4) | 118.6 (84.2)
Median (Min-Max) | 145.0 (100.0 – 160.0) | 79.0 (29.0 – 348.0) | 100.0 (29.0 – 348.0)
Week 4
N | 2 | 8 | 10
Mean (SD) | 65.5 (14.8) | 115.9 (65.1) | 105.8 (61.4)
Median (Min-Max) | 65.5 (55.0 – 76.0) | 89.0 (68.0 – 263.0) | 78.0 (55.0 – 263.0)
Week 8
N | 2 | 7 | 9
Mean (SD) | 55.0 (5.7) | 115.6 (96.9) | 102.1 (88.0)
Median (Min-Max) | 55.0 (51.0 – 59.0) | 98.0 (46.0 – 321.0) | 59.0 (46.0 – 321.0)
LOCF
N | 2 | 10 | 12
Mean (SD) | 55.0 (5.7) | 135.1 (127.1) | 121.8 (119.2)
Median (Min-Max) | 55.0 (51.0 – 59.0) | 83.0 (46.0 – 412.0) | 65.0 (46.0 – 412.0)
Change from Baseline to LOCF
N | 2 | 10 | 12
Mean (SD) | −67.5 (37.5) | 21.4 (74.0) | 6.6 (76.2)
Median (Min-Max) | −67.5 (−94.0 – −41.0) | 10.0 (−57.0 – 206.0) | −2.0 (−94.0 – 206.0)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.2.4.24 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Urea Nitrogen (mg/dL) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 15.7 (4.5) | 11.2 (3.3) | 12.2 (3.9)
Median (Min-Max) | 16.0 (11.0 – 20.0) | 10.0 (7.0 – 17.0) | 10.0 (7.0 – 20.0)
Week 4
N | 2 | 8 | 10
Mean (SD) | 15.5 (0.7) | 10.6 (2.8) | 11.6 (3.2)
Median (Min-Max) | 15.5 (15.0 – 16.0) | 11.0 (6.0 – 14.0) | 11.5 (6.0 – 16.0)
Week 8
N | 2 | 7 | 9
Mean (SD) | 14.0 (4.2) | 10.7 (2.2) | 11.4 (2.8)
Median (Min-Max) | 14.0 (11.0 – 17.0) | 11.0 (7.0 – 13.0) | 11.0 (7.0 – 17.0)
LOCF
N | 2 | 10 | 12
Mean (SD) | 14.0 (4.2) | 9.7 (2.7) | 10.4 (3.2)
Median (Min-Max) | 14.0 (11.0 – 17.0) | 10.0 (6.0 – 13.0) | 10.5 (6.0 – 17.0)
Change from Baseline to LOCF
N | 2 | 10 | 12
Mean (SD) | −1.5 (2.1) | −1.5 (2.5) | −1.5 (2.4)
Median (Min-Max) | −1.5 (−3.0 – 0.0) | −2.0 (−5.0 – 3.0) | −2.0 (−5.0 – 3.0)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.2.4.25 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Uric Acid (mg/dL) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 9 | 12
Mean (SD) | 6.1 (1.9) | 4.9 (1.1) | 5.2 (1.3)
Median (Min-Max) | 5.9 (4.3 – 8.0) | 4.2 (3.8 – 6.6) | 4.8 (3.8 – 8.0)
Week 4
N | 2 | 7 | 9
Mean (SD) | 4.8 (1.0) | 5.6 (1.5) | 5.4 (1.4)
Median (Min-Max) | 4.8 (4.1 – 5.5) | 5.1 (4.0 – 8.1) | 5.1 (4.0 – 8.1)
Week 8
N | 2 | 7 | 9
Mean (SD) | 5.7 (0.8) | 6.1 (1.5) | 6.0 (1.4)
Median (Min-Max) | 5.7 (5.1 – 6.3) | 5.4 (4.3 – 8.5) | 5.4 (4.3 – 8.5)
LOCF
N | 2 | 10 | 12
Mean (SD) | 5.7 (0.8) | 5.6 (1.5) | 5.6 (1.4)
Median (Min-Max) | 5.7 (5.1 – 6.3) | 5.3 (3.7 – 8.5) | 5.3 (3.7 – 8.5)
Change from Baseline to LOCF
N | 2 | 9 | 11
Mean (SD) | 0.6 (0.3) | 0.7 (0.9) | 0.7 (0.8)
Median (Min-Max) | 0.6 (0.4 – 0.8) | 0.7 (−0.4 – 2.4) | 0.7 (−0.4 – 2.4)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.2.4.26 Summary of Clinical Laboratory Chemistry Measurement by Visit and Discontinuation Phase Treatment Received Group Creatinine Clearance (mL/min/1.7m^2^) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 115.1 (7.8) | 109.2 (44.2) | 110.6 (38.5)
Median (Min-Max) | 114.7 (107.4 – 123.1) | 118.6 (5.7 – 147.4) | 114.7 (5.7 – 147.4)
Week 4
N | 2 | 8 | 10
Mean (SD) | 127.9 (17.9) | 111.8 (22.6) | 115.1 (21.9)
Median (Min-Max) | 127.9 (115.3 – 140.6) | 116.3 (78.6 – 135.3) | 119.6 (78.6 – 140.6)
Week 8
N | 2 | 7 | 9
Mean (SD) | 122.9 (14.0) | 112.6 (26.3) | 114.9 (23.7)
Median (Min-Max) | 122.9 (113.0 – 132.8) | 116.9 (65.8 – 137.9) | 116.9 (65.8 – 137.9)
LOCF
N | 2 | 10 | 12
Mean (SD) | 122.9 (14.0) | 117.9 (31.4) | 118.7 (28.7)
Median (Min-Max) | 122.9 (113.0 – 132.8) | 124.5 (65.8 – 161.5) | 124.5 (65.8 – 161.5)
Change from Baseline to LOCF
N | 2 | 10 | 12
Mean (SD) | 11.9 (19.2) | 8.7 (25.2) | 9.2 (23.6)
Median (Min-Max) | 11.9 (−1.7 – 25.5) | 1.6 (−12.8 – 73.0) | 1.6 (−12.8 – 73.0)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.3.1.1 Summary of Clinical Thyroid Panel by Visit, Age Strata and Efficacy Phase Treatment Received Group Thyroid Stimulating Hormone - TSH (mIU/L) Efficacy Phase - Safety Population

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 2.0 (1.1) | 1.9 (0.9) | 2.3 (1.4) | 1.9 (0.9) | 2.1 (1.2) | 1.9 (0.9)
Median (Min-Max) | 1.7 (0.7 – 4.9) | 2.0 (0.5 – 4.3) | 1.8 (0.8 – 5.7) | 1.5 (1.1 – 3.6) | 1.7 (0.7 – 5.7) | 1.9 (0.5 – 4.3)
Week 2
N | 11 | 10 | 10 | 7 | 21 | 17
Mean (SD) | 4.5 (2.4) | 1.5 (0.7) | 3.7 (1.7) | 1.1 (0.3) | 4.1 (2.1) | 1.4 (0.6)
Median (Min-Max) | 4.2 (1.0 – 8.7) | 1.6 (0.5 – 2.4) | 3.4 (1.5 – 6.9) | 1.0 (0.8 – 1.8) | 3.5 (1.0 – 8.7) | 1.2 (0.5 – 2.4)
Week 4
N | 26 | 12 | 14 | 10 | 40 | 22
Mean (SD) | 5.6 (3.2) | 2.0 (0.9) | 5.5 (4.4) | 1.5 (0.5) | 5.5 (3.6) | 1.8 (0.8)
Median (Min-Max) | 5.0 (0.7 – 12.1) | 2.0 (0.8 – 3.9) | 4.1 (2.5 – 17.4) | 1.4 (0.7 – 2.2) | 4.3 (0.7 – 17.4) | 1.6 (0.7 – 3.9)
Week 8
N | 29 | 12 | 20 | 10 | 49 | 22
Mean (SD) | 5.1 (3.5) | 1.9 (0.6) | 4.9 (2.9) | 1.8 (1.2) | 5.0 (3.3) | 1.9 (0.9)
Median (Min-Max) | 4.0 (1.1 – 17.0) | 2.0 (0.9 – 3.0) | 4.5 (1.0 – 11.7) | 1.5 (0.9 – 5.2) | 4.2 (1.0 – 17.0) | 1.8 (0.9 – 5.2)
LOCF
N | 31 | 15 | 20 | 10 | 51 | 25
Mean (SD) | 5.1 (3.5) | 1.9 (0.6) | 4.9 (2.9) | 1.8 (1.2) | 5.0 (3.3) | 1.9 (0.9)
Median (Min-Max) | 4.0 (1.1 – 17.0) | 2.0 (0.9 – 3.0) | 4.5 (1.0 – 11.7) | 1.5 (0.9 – 5.2) | 4.2 (1.0 – 17.0) | 1.7 (0.9 – 5.2)
Change from Baseline to LOCF
N | 31 | 15 | 20 | 10 | 51 | 25
Mean (SD) | 3.1 (3.5) | 0.0 (0.9) | 2.7 (2.5) | 0.0 (1.0) | 3.0 (3.1) | 0.0 (0.9)
Median (Min-Max) | 2.1 (−1.6 – 15.8) | −0.1 (−2.2 – 1.4) | 2.2 (−0.5 – 9.0) | −0.1 (−1.8 – 1.9) | 2.1 (−1.6 – 15.8) | −0.1 (−2.2 – 1.9)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.3.1.2 Summary of Clinical Thyroid Panel by Visit, Age Strata and Efficacy Phase Treatment Received Group Total T3 (ng/dL) Efficacy Phase - Safety Population

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 30 | 17 | 21 | 11 | 51 | 28
Mean (SD) | 160.6 (23.7) | 162.8 (23.8) | 131.1 (35.4) | 147.9 (32.6) | 148.4 (32.3) | 156.9 (28.0)
Median (Min-Max) | 162.5 (118.0 – 206.0) | 168.0 (117.0 – 192.0) | 140.0 (27.0 – 185.0) | 154.0 (90.0 – 217.0) | 150.0 (27.0 – 206.0) | 157.0 (90.0 – 217.0)
Week 2
N | 11 | 10 | 10 | 7 | 21 | 17
Mean (SD) | 137.3 (25.8) | 155.7 (23.2) | 126.9 (19.7) | 162.7 (27.7) | 132.3 (23.1) | 158.6 (24.6)
Median (Min-Max) | 132.0 (99.0 – 185.0) | 154.0 (118.0 – 192.0) | 120.0 (100.0 – 153.0) | 158.0 (121.0 – 211.0) | 126.0 (99.0 – 185.0) | 158.0 (118.0 – 211.0)
Week 4
N | 26 | 12 | 14 | 10 | 40 | 22
Mean (SD) | 142.1 (22.0) | 146.6 (20.6) | 130.5 (26.5) | 142.6 (42.1) | 138.0 (24.0) | 144.8 (31.4)
Median (Min-Max) | 137.0 (99.0 – 191.0) | 148.5 (114.0 – 174.0) | 134.5 (60.0 – 179.0) | 136.5 (71.0 – 210.0) | 137.0 (60.0 – 191.0) | 140.0 (71.0 – 210.0)
Week 8
N | 28 | 12 | 20 | 10 | 48 | 22
Mean (SD) | 149.2 (27.7) | 152.3 (36.8) | 125.4 (24.9) | 139.1 (25.9) | 139.3 (28.8) | 146.3 (32.3)
Median (Min-Max) | 148.0 (107.0 – 219.0) | 145.5 (102.0 – 214.0) | 129.5 (59.0 – 169.0) | 135.0 (107.0 – 184.0) | 137.0 (59.0 – 219.0) | 140.0 (102.0 – 214.0)
LOCF
N | 30 | 15 | 20 | 10 | 50 | 25
Mean (SD) | 149.9 (27.7) | 151.5 (32.8) | 125.4 (24.9) | 139.1 (25.9) | 140.1 (29.0) | 146.6 (30.3)
Median (Min-Max) | 148.0 (107.0 – 219.0) | 150.0 (102.0 – 214.0) | 129.5 (59.0 – 169.0) | 135.0 (107.0 – 184.0) | 137.0 (59.0 – 219.0) | 143.0 (102.0 – 214.0)
Change from Baseline to LOCF
N | 29 | 15 | 20 | 10 | 49 | 25
Mean (SD) | −11.2 (30.3) | −10.3 (31.0) | −5.8 (37.6) | −8.1 (20.4) | −9.0 (33.2) | −9.4 (26.8)
Median (Min-Max) | −17.0 (−61.0 – 61.0) | −29.0 (−45.0 – 42.0) | −8.0 (−55.0 – 109.0) | −9.5 (−38.0 – 22.0) | −12.0 (−61.0 – 109.0) | −11.0 (−45.0 – 42.0)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.3.1.3 Summary of Clinical Thyroid Panel by Visit, Age Strata and Efficacy Phase Treatment Received Group Total T4 (μg/dL) Efficacy Phase - Safety Population

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 8.4 (2.2) | 9.2 (1.0) | 7.0 (1.4) | 7.8 (1.7) | 7.9 (2.0) | 8.7 (1.5)
Median (Min-Max) | 8.5 (1.1 – 12.4) | 9.3 (7.7 – 10.9) | 7.2 (4.2 – 9.6) | 7.5 (5.8 – 10.7) | 7.8 (1.1 – 12.4) | 8.8 (5.8 – 10.9)
Week 2
N | 11 | 10 | 10 | 7 | 21 | 17
Mean (SD) | 7.5 (1.2) | 8.6 (1.0) | 6.4 (1.1) | 8.1 (2.2) | 6.9 (1.3) | 8.4 (1.6)
Median (Min-Max) | 7.3 (6.1 – 10.4) | 8.4 (6.8 – 10.5) | 6.5 (4.3 – 8.1) | 6.8 (6.4 – 12.0) | 7.0 (4.3 – 10.4) | 8.2 (6.4 – 12.0)
Week 4
N | 26 | 12 | 14 | 10 | 40 | 22
Mean (SD) | 7.6 (1.2) | 8.8 (1.2) | 6.7 (1.6) | 7.6 (1.9) | 7.3 (1.4) | 8.2 (1.6)
Median (Min-Max) | 7.6 (5.8 – 10.0) | 8.3 (7.6 – 10.6) | 6.6 (4.5 – 10.5) | 6.9 (5.6 – 10.8) | 7.4 (4.5 – 10.5) | 7.9 (5.6 – 10.8)
Week 8
N | 29 | 12 | 20 | 10 | 49 | 22
Mean (SD) | 8.1 (1.8) | 8.4 (1.4) | 6.6 (1.3) | 7.4 (2.2) | 7.5 (1.8) | 7.9 (1.8)
Median (Min-Max) | 7.4 (5.5 – 11.6) | 8.4 (6.5 – 11.6) | 6.7 (4.7 – 9.4) | 6.8 (5.3 – 10.4) | 7.0 (4.7 – 11.6) | 8.0 (5.3 – 11.6)
LOCF
N | 31 | 15 | 20 | 10 | 51 | 25
Mean (SD) | 8.1 (1.8) | 8.5 (1.4) | 6.6 (1.3) | 7.4 (2.2) | 7.5 (1.8) | 8.0 (1.8)
Median (Min-Max) | 7.4 (5.5 – 11.6) | 8.5 (6.5 – 11.6) | 6.7 (4.7 – 9.4) | 6.8 (5.3 – 10.4) | 7.0 (4.7 – 11.6) | 8.1 (5.3 – 11.6)
Change from Baseline to LOCF
N | 31 | 15 | 20 | 10 | 51 | 25
Mean (SD) | −0.4 (2.6) | −0.5 (1.2) | −0.4 (1.1) | −0.5 (0.8) | −0.4 (2.1) | −0.5 (1.1)
Median (Min-Max) | −0.3 (−4.0 – 10.5) | −0.7 (−2.0 – 2.7) | −0.4 (−2.8 – 2.0) | −0.4 (−1.8 – 1.0) | −0.4 (−4.0 – 10.5) | −0.7 (−2.0 – 2.7)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.3.1.4 Summary of Clinical Thyroid Panel by Visit, Age Strata and Efficacy Phase Treatment Received Group Antithyroglobulin Ab (IU/mL) Efficacy Phase - Safety Population

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 31 | 17 | 18 | 11 | 49 | 28
Mean (SD) | 20.4 (1.6) | 20.0 (0.0) | 192.6 (701.3) | 196.1 (584.0) | 83.6 (425.7) | 89.2 (366.1)
Median (Min-Max) | 20.0 (20.0 – 28.2) | 20.0 (20.0 – 20.0) | 20.0 (20.0 – 3000) | 20.0 (20.0 – 1957) | 20.0 (20.0 – 3000) | 20.0 (20.0 – 1957)
Week 2
N | 11 | 10 | 8 | 7 | 19 | 17
Mean (SD) | 21.6 (5.2) | 20.0 (0.0) | 20.0 (0.0) | 20.0 (0.0) | 20.9 (3.9) | 20.0 (0.0)
Median (Min-Max) | 20.0 (20.0 – 37.2) | 20.0 (20.0 – 20.0) | 20.0 (20.0 – 20.0) | 20.0 (20.0 – 20.0) | 20.0 (20.0 – 37.2) | 20.0 (20.0 – 20.0)
Week 4
N | 25 | 12 | 13 | 10 | 38 | 22
Mean (SD) | 20.3 (1.4) | 20.0 (0.0) | 32.2 (43.8) | 222.0 (638.8) | 24.3 (25.6) | 111.8 (430.7)
Median (Min-Max) | 20.0 (20.0 – 27.0) | 20.0 (20.0 – 20.0) | 20.0 (20.0 – 178.0) | 20.0 (20.0 – 2040) | 20.0 (20.0 – 178.0) | 20.0 (20.0 – 2040)
Week 8
N | 29 | 12 | 18 | 9 | 47 | 21
Mean (SD) | 20.1 (0.7) | 20.0 (0.0) | 24.7 (19.8) | 280.9 (782.7) | 21.9 (12.3) | 131.8 (512.4)
Median (Min-Max) | 20.0 (20.0 – 23.9) | 20.0 (20.0 – 20.0) | 20.0 (20.0 – 104.0) | 20.0 (20.0 – 2368) | 20.0 (20.0 – 104.0) | 20.0 (20.0 – 2368)
LOCF
N | 31 | 15 | 18 | 9 | 49 | 24
Mean (SD) | 20.1 (0.7) | 20.0 (0.0) | 24.7 (19.8) | 280.9 (782.7) | 21.8 (12.0) | 117.8 (479.3)
Median (Min-Max) | 20.0 (20.0 – 23.9) | 20.0 (20.0 – 20.0) | 20.0 (20.0 – 104.0) | 20.0 (20.0 – 2368) | 20.0 (20.0 – 104.0) | 20.0 (20.0 – 2368)
Change from Baseline to LOCF
N | 31 | 15 | 17 | 9 | 48 | 24
Mean (SD) | −0.2 (1.0) | 0.0 (0.0) | −178 (722.2) | 45.7 (137.0) | −63.1 (430.0) | 17.1 (83.9)
Median (Min-Max) | 0.0 (−4.3 – 0.0) | 0.0 (0.0 – 0.0) | 0.0 (−2980 – 0.0) | 0.0 (0.0 – 411.0) | 0.0 (−2980 – 0.0) | 0.0 (0.0 – 411.0)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.3.1.5 Summary of Clinical Thyroid Panel by Visit, Age Strata and Efficacy Phase Treatment Received Group Thyroid Peroxidase Ab (IU/mL) Efficacy Phase - Safety Population

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 31 | 17 | 19 | 11 | 50 | 28
Mean (SD) | 16.8 (19.0) | 13.6 (7.7) | 17.2 (14.5) | 17.3 (14.4) | 17.0 (17.3) | 15.1 (10.7)
Median (Min-Max) | 10.0 (10.0 – 113.0) | 10.0 (10.0 – 37.6) | 10.0 (10.0 – 55.8) | 10.0 (10.0 – 56.5) | 10.0 (10.0 – 113.0) | 10.0 (10.0 – 56.5)
Week 2
N | 10 | 10 | 8 | 7 | 18 | 17
Mean (SD) | 20.6 (26.2) | 14.7 (8.1) | 22.2 (21.2) | 13.1 (5.6) | 21.3 (23.4) | 14.0 (7.0)
Median (Min-Max) | 10.0 (10.0 – 94.4) | 11.3 (10.0 – 35.3) | 10.0 (10.0 – 61.9) | 10.0 (10.0 – 24.0) | 10.0 (10.0 – 94.4) | 10.0 (10.0 – 35.3)
Week 4
N | 26 | 12 | 13 | 10 | 39 | 22
Mean (SD) | 15.0 (17.0) | 14.2 (6.6) | 15.0 (15.2) | 23.1 (33.2) | 15.0 (16.2) | 18.3 (22.7)
Median (Min-Max) | 10.0 (10.0 – 95.2) | 10.0 (10.0 – 31.3) | 10.0 (10.0 – 64.6) | 10.0 (10.0 – 116.0) | 10.0 (10.0 – 95.2) | 10.0 (10.0 – 116.0)
Week 8
N | 29 | 12 | 19 | 9 | 48 | 21
Mean (SD) | 15.2 (16.3) | 13.4 (5.4) | 14.8 (11.1) | 29.9 (46.4) | 15.0 (14.3) | 20.5 (30.8)
Median (Min-Max) | 10.0 (10.0 – 95.4) | 10.0 (10.0 – 27.2) | 10.0 (10.0 – 48.0) | 10.0 (10.0 – 152.0) | 10.0 (10.0 – 95.4) | 10.0 (10.0 – 152.0)
LOCF
N | 31 | 15 | 19 | 9 | 50 | 24
Mean (SD) | 14.8 (15.8) | 13.2 (5.1) | 14.8 (11.1) | 29.9 (46.4) | 14.8 (14.1) | 19.5 (28.9)
Median (Min-Max) | 10.0 (10.0 – 95.4) | 10.0 (10.0 – 27.2) | 10.0 (10.0 – 48.0) | 10.0 (10.0 – 152.0) | 10.0 (10.0 – 95.4) | 10.0 (10.0 – 152.0)
Change from Baseline to LOCF
N | 31 | 15 | 18 | 9 | 49 | 24
Mean (SD) | −2.0 (5.3) | −0.9 (3.7) | −2.5 (6.3) | 11.0 (32.1) | −2.2 (5.6) | 3.6 (20.1)
Median (Min-Max) | 0.0 (−21.0 – 3.6) | 0.0 (−10.4 – 3.1) | 0.0 (−19.2 – 8.2) | 0.0 (−5.0 – 95.5) | 0.0 (−21.0 – 8.2) | 0.0 (−10.4 – 95.5)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.3.2.1A Summary of Clinical Thyroid Panel by Visit and Age Strata Thyroid Stimulating Hormone - TSH (mIU/L) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 4.3 (2.9) | 4.3 (3.5) | 4.3 (3.1)
Median (Min-Max) | 3.2 (0.9 – 12.0) | 2.4 (0.9 – 11.7) | 3.2 (0.9 – 12.0)
Week 4
N | 10 | 6 | 16
Mean (SD) | 5.2 (2.5) | 2.6 (1.3) | 4.2 (2.5)
Median (Min-Max) | 4.9 (1.4 – 9.2) | 2.9 (0.6 – 4.3) | 3.8 (0.6 – 9.2)
Week 8
N | 25 | 13 | 38
Mean (SD) | 4.7 (2.5) | 3.7 (2.4) | 4.4 (2.5)
Median (Min-Max) | 4.5 (0.8 – 13.0) | 2.8 (0.0 – 7.8) | 4.2 (0.0 – 13.0)
Week 16
N | 21 | 7 | 28
Mean (SD) | 4.7 (2.4) | 3.8 (1.8) | 4.5 (2.2)
Median (Min-Max) | 4.3 (1.0 – 10.0) | 3.3 (1.7 – 6.5) | 3.9 (1.0 – 10.0)
Week 24
N | 17 | 6 | 23
Mean (SD) | 4.7 (2.8) | 3.1 (1.6) | 4.3 (2.6)
Median (Min-Max) | 4.0 (1.1 – 10.5) | 2.9 (1.4 – 6.1) | 3.3 (1.1 – 10.5)
LOCF
N | 26 | 14 | 40
Mean (SD) | 4.5 (2.6) | 4.3 (3.0) | 4.4 (2.7)
Median (Min-Max) | 3.8 (1.1 – 10.5) | 3.0 (1.2 – 11.4) | 3.3 (1.1 – 11.4)
Change from Baseline to LOCF
N | 26 | 14 | 40
Mean (SD) | 0.0 (3.0) | −0.3 (5.1) | −0.1 (3.8)
Median (Min-Max) | −0.6 (−4.7 – 6.2) | 0.2 (−8.9 – 7.4) | −0.1 (−8.9 – 7.4)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.3.2.2A Summary of Clinical Thyroid Panel by Visit and Age Strata Total T3 (ng/dL) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 146.3 (29.8) | 133.8 (31.3) | 142.0 (30.5)
Median (Min-Max) | 147.0 (102.0 – 219.0) | 129.0 (59.0 – 184.0) | 139.5 (59.0 – 219.0)
Week 4
N | 10 | 6 | 16
Mean (SD) | 138.6 (23.7) | 151.8 (41.2) | 143.6 (30.7)
Median (Min-Max) | 136.5 (97.0 – 177.0) | 135.5 (118.0 – 227.0) | 136.0 (97.0 – 227.0)
Week 8
N | 23 | 13 | 36
Mean (SD) | 132.6 (20.8) | 135.8 (24.6) | 133.8 (22.0)
Median (Min-Max) | 136.0 (86.0 – 159.0) | 135.0 (74.0 – 172.0) | 135.5 (74.0 – 172.0)
Week 16
N | 21 | 7 | 28
Mean (SD) | 138.0 (30.1) | 141.9 (40.3) | 138.9 (32.2)
Median (Min-Max) | 137.0 (71.0 – 200.0) | 142.0 (71.0 – 200.0) | 139.5 (71.0 – 200.0)
Week 24
N | 17 | 6 | 23
Mean (SD) | 145.7 (20.7) | 133.7 (36.6) | 142.6 (25.4)
Median (Min-Max) | 141.0 (110.0 – 177.0) | 133.0 (74.0 – 172.0) | 139.0 (74.0 – 177.0)
LOCF
N | 26 | 14 | 40
Mean (SD) | 143.9 (22.7) | 141.8 (31.4) | 143.2 (25.7)
Median (Min-Max) | 138.5 (110.0 – 183.0) | 139.5 (74.0 – 205.0) | 139.0 (74.0 – 205.0)
Change from Baseline to LOCF
N | 26 | 14 | 40
Mean (SD) | −0.6 (21.2) | 7.1 (20.8) | 2.1 (21.1)
Median (Min-Max) | 5.0 (−41.0 – 28.0) | 15.5 (−35.0 – 28.0) | 7.5 (−41.0 – 28.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.3.2.3A Summary of Clinical Thyroid Panel by Visit and Age Strata Total T4 (μg/dL) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 8.2 (1.8) | 7.4 (1.7) | 7.9 (1.8)
Median (Min-Max) | 7.7 (5.5 – 11.6) | 6.8 (5.3 – 10.4) | 7.4 (5.3 – 11.6)
Week 4
N | 10 | 6 | 16
Mean (SD) | 7.2 (1.2) | 7.2 (1.5) | 7.2 (1.3)
Median (Min-Max) | 7.4 (5.1 – 9.2) | 6.8 (5.5 – 9.4) | 7.3 (5.1 – 9.4)
Week 8
N | 25 | 13 | 38
Mean (SD) | 7.6 (1.4) | 8.2 (2.2) | 7.8 (1.7)
Median (Min-Max) | 7.6 (5.8 – 10.8) | 7.9 (4.6 – 11.6) | 7.7 (4.6 – 11.6)
Week 16
N | 21 | 7 | 28
Mean (SD) | 7.4 (1.4) | 6.6 (1.2) | 7.2 (1.4)
Median (Min-Max) | 7.2 (4.9 – 11.1) | 6.9 (5.0 – 8.1) | 7.1 (4.9 – 11.1)
Week 24
N | 17 | 6 | 23
Mean (SD) | 7.6 (1.0) | 6.9 (1.3) | 7.4 (1.1)
Median (Min-Max) | 7.4 (5.5 – 9.1) | 6.7 (5.4 – 8.9) | 7.3 (5.4 – 9.1)
LOCF
N | 26 | 14 | 40
Mean (SD) | 8.1 (1.5) | 7.7 (1.9) | 7.9 (1.6)
Median (Min-Max) | 8.1 (5.5 – 12.3) | 7.7 (5.4 – 11.6) | 7.8 (5.4 – 12.3)
Change from Baseline to LOCF
N | 26 | 14 | 40
Mean (SD) | 0.1 (1.3) | 0.2 (1.3) | 0.1 (1.3)
Median (Min-Max) | 0.2 (−4.0 – 2.6) | 0.1 (−2.7 – 2.7) | 0.2 (−4.0 – 2.7)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.3.2.4A Summary of Clinical Thyroid Panel by Visit and Age Strata Antithyroglobulin Ab (IU/mL) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 20.1 (0.7) | 182.1 (605.1) | 75.4 (353.9)
Median (Min-Max) | 20.0 (20.0 – 23.9) | 20.0 (20.0 – 2368) | 20.0 (20.0 – 2368)
Week 4
N | 10 | 6 | 16
Mean (SD) | 20.0 (0.0) | 413.0 (962.6) | 167.4 (589.5)
Median (Min-Max) | 20.0 (20.0 – 20.0) | 20.0 (20.0 – 2378) | 20.0 (20.0 – 2378)
Week 8
N | 25 | 13 | 38
Mean (SD) | 20.1 (0.3) | 207.9 (660.9) | 84.3 (387.1)
Median (Min-Max) | 20.0 (20.0 – 21.4) | 20.0 (20.0 – 2407) | 20.0 (20.0 – 2407)
Week 16
N | 21 | 7 | 28
Mean (SD) | 20.0 (0.0) | 20.0 (0.0) | 20.0 (0.0)
Median (Min-Max) | 20.0 (20.0 – 20.0) | 20.0 (20.0 – 20.0) | 20.0 (20.0 – 20.0)
Week 24
N | 17 | 6 | 23
Mean (SD) | 20.3 (1.1) | 20.0 (0.0) | 20.2 (0.9)
Median (Min-Max) | 20.0 (20.0 – 24.5) | 20.0 (20.0 – 20.0) | 20.0 (20.0 – 24.5)
LOCF
N | 26 | 14 | 40
Mean (SD) | 20.2 (0.9) | 213.5 (708.1) | 87.8 (419.3)
Median (Min-Max) | 20.0 (20.0 – 24.5) | 20.0 (20.0 – 2673) | 20.0 (20.0 – 2673)
Change from Baseline to LOCF
N | 26 | 14 | 40
Mean (SD) | 0.0 (1.2) | 19.8 (82.4) | 6.9 (48.5)
Median (Min-Max) | 0.0 (−3.9 – 4.5) | 0.0 (−28.0 – 305.0) | 0.0 (−28.0 – 305.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.3.2.5A Summary of Clinical Thyroid Panel by Visit and Age Strata Thyroid Peroxidase Ab (IU/mL) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 16.2 (16.4) | 21.5 (36.4) | 18.0 (24.7)
Median (Min-Max) | 10.0 (10.0 – 95.4) | 10.0 (10.0 – 152.0) | 10.0 (10.0 – 152.0)
Week 4
N | 10 | 6 | 16
Mean (SD) | 13.3 (5.5) | 45.5 (87.0) | 25.4 (52.9)
Median (Min-Max) | 10.0 (10.0 – 23.9) | 10.0 (10.0 – 223.0) | 10.0 (10.0 – 223.0)
Week 8
N | 25 | 13 | 38
Mean (SD) | 16.2 (18.5) | 28.3 (62.8) | 20.4 (39.2)
Median (Min-Max) | 10.0 (10.0 – 102.0) | 10.0 (10.0 – 237.0) | 10.0 (10.0 – 237.0)
Week 16
N | 21 | 7 | 28
Mean (SD) | 13.9 (11.2) | 10.0 (0.0) | 13.0 (9.8)
Median (Min-Max) | 10.0 (10.0 – 60.0) | 10.0 (10.0 – 10.0) | 10.0 (10.0 – 60.0)
Week 24
N | 17 | 6 | 23
Mean (SD) | 14.2 (10.2) | 11.7 (4.1) | 13.5 (8.9)
Median (Min-Max) | 10.0 (10.0 – 51.3) | 10.0 (10.0 – 20.0) | 10.0 (10.0 – 51.3)
LOCF
N | 26 | 14 | 40
Mean (SD) | 13.9 (9.1) | 28.5 (63.3) | 19.0 (37.9)
Median (Min-Max) | 10.0 (10.0 – 51.3) | 10.0 (10.0 – 248.0) | 10.0 (10.0 – 248.0)
Change from Baseline to LOCF
N | 26 | 14 | 40
Mean (SD) | −3.0 (10.0) | 7.2 (25.8) | 0.6 (17.6)
Median (Min-Max) | 0.0 (−44.1 – 12.0) | 0.0 (−8.2 – 96.0) | 0.0 (−44.1 – 96.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.3.2.1B Summary of Clinical Thyroid Panel by Visit and Efficacy Phase Treatment Received Group Thyroid Stimulating Hormone - TSH (mIU/L) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 5.6 (3.0) | 1.8 (0.6) | 4.3 (3.1)
Median (Min-Max) | 4.8 (1.0 – 12.0) | 1.8 (0.9 – 3.0) | 3.2 (0.9 – 12.0)
Week 4
N | 4 | 12 | 16
Mean (SD) | 3.6 (2.5) | 4.4 (2.5) | 4.2 (2.5)
Median (Min-Max) | 2.9 (1.4 – 7.2) | 4.1 (0.6 – 9.2) | 3.8 (0.6 – 9.2)
Week 8
N | 27 | 11 | 38
Mean (SD) | 4.3 (2.6) | 4.5 (2.3) | 4.4 (2.5)
Median (Min-Max) | 3.3 (0.8 – 13.0) | 4.5 (0.0 – 7.5) | 4.2 (0.0 – 13.0)
Week 16
N | 19 | 9 | 28
Mean (SD) | 4.5 (2.4) | 4.5 (2.0) | 4.5 (2.2)
Median (Min-Max) | 3.8 (1.0 – 10.0) | 4.3 (2.2 – 7.3) | 3.9 (1.0 – 10.0)
Week 24
N | 15 | 8 | 23
Mean (SD) | 4.2 (2.8) | 4.4 (2.3) | 4.3 (2.6)
Median (Min-Max) | 3.3 (1.1 – 10.5) | 3.6 (2.1 – 8.2) | 3.3 (1.1 – 10.5)
LOCF
N | 27 | 13 | 40
Mean (SD) | 4.3 (2.7) | 4.6 (2.6) | 4.4 (2.7)
Median (Min-Max) | 3.3 (1.1 – 11.4) | 4.0 (1.2 – 9.1) | 3.3 (1.1 – 11.4)
Change from Baseline to LOCF
N | 27 | 13 | 40
Mean (SD) | −1.5 (3.5) | 2.8 (2.5) | −0.1 (3.8)
Median (Min-Max) | −1.2 (−8.9 – 5.9) | 2.0 (−0.1 – 7.4) | −0.1 (−8.9 – 7.4)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.3.2.2B Summary of Clinical Thyroid Panel by Visit and Efficacy Phase Treatment Received Group Total T3 (ng/dL) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 139.8 (28.7) | 146.3 (34.5) | 142.0 (30.5)
Median (Min-Max) | 141.0 (59.0 – 219.0) | 137.0 (102.0 – 214.0) | 139.5 (59.0 – 219.0)
Week 4
N | 4 | 12 | 16
Mean (SD) | 143.5 (18.3) | 143.6 (34.6) | 143.6 (30.7)
Median (Min-Max) | 134.5 (134.0 – 171.0) | 137.5 (97.0 – 227.0) | 136.0 (97.0 – 227.0)
Week 8
N | 25 | 11 | 36
Mean (SD) | 134.8 (22.5) | 131.5 (21.7) | 133.8 (22.0)
Median (Min-Max) | 136.0 (74.0 – 172.0) | 129.0 (86.0 – 159.0) | 135.5 (74.0 – 172.0)
Week 16
N | 19 | 9 | 28
Mean (SD) | 139.5 (31.2) | 137.8 (36.1) | 138.9 (32.2)
Median (Min-Max) | 142.0 (71.0 – 200.0) | 135.0 (71.0 – 200.0) | 139.5 (71.0 – 200.0)
Week 24
N | 15 | 8 | 23
Mean (SD) | 142.8 (28.2) | 142.1 (21.0) | 142.6 (25.4)
Median (Min-Max) | 139.0 (74.0 – 177.0) | 140.0 (110.0 – 172.0) | 139.0 (74.0 – 177.0)
LOCF
N | 27 | 13 | 40
Mean (SD) | 141.7 (26.6) | 146.3 (24.4) | 143.2 (25.7)
Median (Min-Max) | 139.0 (74.0 – 183.0) | 139.0 (110.0 – 205.0) | 139.0 (74.0 – 205.0)
Change from Baseline to LOCF
N | 27 | 13 | 40
Mean (SD) | 1.5 (19.2) | 3.3 (25.4) | 2.1 (21.1)
Median (Min-Max) | 5.0 (−37.0 – 28.0) | 18.0 (−41.0 – 28.0) | 7.5 (−41.0 – 28.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.3.2.3B Summary of Clinical Thyroid Panel by Visit and Efficacy Phase Treatment Received Group Total T4 (μg/dL) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 7.7 (1.8) | 8.3 (1.7) | 7.9 (1.8)
Median (Min-Max) | 7.0 (5.5 – 11.6) | 8.2 (5.3 – 11.6) | 7.4 (5.3 – 11.6)
Week 4
N | 4 | 12 | 16
Mean (SD) | 6.2 (1.3) | 7.5 (1.2) | 7.2 (1.3)
Median (Min-Max) | 5.8 (5.1 – 8.0) | 7.4 (6.1 – 9.4) | 7.3 (5.1 – 9.4)
Week 8
N | 27 | 11 | 38
Mean (SD) | 7.7 (1.7) | 8.0 (1.7) | 7.8 (1.7)
Median (Min-Max) | 7.6 (4.6 – 11.6) | 7.9 (5.8 – 10.8) | 7.7 (4.6 – 11.6)
Week 16
N | 19 | 9 | 28
Mean (SD) | 7.2 (1.6) | 7.1 (0.7) | 7.2 (1.4)
Median (Min-Max) | 7.3 (4.9 – 11.1) | 7.0 (6.2 – 8.3) | 7.1 (4.9 – 11.1)
Week 24
N | 15 | 8 | 23
Mean (SD) | 7.1 (1.1) | 8.0 (0.8) | 7.4 (1.1)
Median (Min-Max) | 7.1 (5.4 – 9.0) | 8.1 (6.7 – 9.1) | 7.3 (5.4 – 9.1)
LOCF
N | 27 | 13 | 40
Mean (SD) | 7.9 (1.8) | 8.1 (1.2) | 7.9 (1.6)
Median (Min-Max) | 7.3 (5.4 – 12.3) | 8.2 (5.6 – 9.7) | 7.8 (5.4 – 12.3)
Change from Baseline to LOCF
N | 27 | 13 | 40
Mean (SD) | 0.3 (1.4) | −0.1 (1.2) | 0.1 (1.3)
Median (Min-Max) | 0.3 (−4.0 – 2.7) | −0.1 (−2.7 – 2.6) | 0.2 (−4.0 – 2.7)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.3.2.4B Summary of Clinical Thyroid Panel by Visit and Efficacy Phase Treatment Received Group Antithyroglobulin Ab (IU/mL) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 23.0 (15.6) | 176.5 (606.3) | 75.4 (353.9)
Median (Min-Max) | 20.0 (20.0 – 104.0) | 20.0 (20.0 – 2368) | 20.0 (20.0 – 2368)
Week 4
N | 4 | 12 | 16
Mean (SD) | 20.0 (0.0) | 216.5 (680.7) | 167.4 (589.5)
Median (Min-Max) | 20.0 (20.0 – 20.0) | 20.0 (20.0 – 2378) | 20.0 (20.0 – 2378)
Week 8
N | 27 | 11 | 38
Mean (SD) | 22.1 (10.8) | 237.1 (719.7) | 84.3 (387.1)
Median (Min-Max) | 20.0 (20.0 – 76.0) | 20.0 (20.0 – 2407) | 20.0 (20.0 – 2407)
Week 16
N | 19 | 9 | 28
Mean (SD) | 20.0 (0.0) | 20.0 (0.0) | 20.0 (0.0)
Median (Min-Max) | 20.0 (20.0 – 20.0) | 20.0 (20.0 – 20.0) | 20.0 (20.0 – 20.0)
Week 24
N | 15 | 8 | 23
Mean (SD) | 20.0 (0.0) | 20.6 (1.6) | 20.2 (0.9)
Median (Min-Max) | 20.0 (20.0 – 20.0) | 20.0 (20.0 – 24.5) | 20.0 (20.0 – 24.5)
LOCF
N | 27 | 13 | 40
Mean (SD) | 22.1 (10.8) | 224.4 (735.7) | 87.8 (419.3)
Median (Min-Max) | 20.0 (20.0 – 76.0) | 20.0 (20.0 – 2673) | 20.0 (20.0 – 2673)
Change from Baseline to LOCF
N | 27 | 13 | 40
Mean (SD) | −1.2 (5.4) | 23.8 (84.5) | 6.9 (48.5)
Median (Min-Max) | 0.0 (−28.0 – 0.0) | 0.0 (0.0 – 305.0) | 0.0 (−28.0 – 305.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.3.2.5B Summary of Clinical Thyroid Panel by Visit and Efficacy Phase Treatment Received Group Thyroid Peroxidase Ab (IU/mL) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 15.4 (16.3) | 23.0 (36.2) | 18.0 (24.7)
Median (Min-Max) | 10.0 (10.0 – 95.4) | 10.0 (10.0 – 152.0) | 10.0 (10.0 – 152.0)
Week 4
N | 4 | 12 | 16
Mean (SD) | 10.0 (0.0) | 30.5 (60.8) | 25.4 (52.9)
Median (Min-Max) | 10.0 (10.0 – 10.0) | 10.0 (10.0 – 223.0) | 10.0 (10.0 – 223.0)
Week 8
N | 27 | 11 | 38
Mean (SD) | 15.4 (17.9) | 32.5 (68.0) | 20.4 (39.2)
Median (Min-Max) | 10.0 (10.0 – 102.0) | 10.0 (10.0 – 237.0) | 10.0 (10.0 – 237.0)
Week 16
N | 19 | 9 | 28
Mean (SD) | 13.7 (11.8) | 11.4 (2.8) | 13.0 (9.8)
Median (Min-Max) | 10.0 (10.0 – 60.0) | 10.0 (10.0 – 16.8) | 10.0 (10.0 – 60.0)
Week 24
N | 15 | 8 | 23
Mean (SD) | 14.8 (10.9) | 11.1 (1.9) | 13.5 (8.9)
Median (Min-Max) | 10.0 (10.0 – 51.3) | 10.0 (10.0 – 14.2) | 10.0 (10.0 – 51.3)
LOCF
N | 27 | 13 | 40
Mean (SD) | 13.2 (8.5) | 31.1 (65.4) | 19.0 (37.9)
Median (Min-Max) | 10.0 (10.0 – 51.3) | 10.0 (10.0 – 248.0) | 10.0 (10.0 – 248.0)
Change from Baseline to LOCF
N | 27 | 13 | 40
Mean (SD) | −2.7 (9.4) | 7.3 (27.2) | 0.6 (17.6)
Median (Min-Max) | 0.0 (−44.1 – 10.0) | 0.0 (−13.0 – 96.0) | 0.0 (−44.1 – 96.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.3.3.1 Summary of Clinical Laboratory Thyroid Panel by Visit and Discontinuation Phase Treatment Received Group Thyroid Stimulating Hormone - TSH (mIU/L) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 5.1 (3.2) | 4.2 (2.5) | 4.7 (2.9)
Median (Min-Max) | 4.5 (1.4 – 11.4) | 3.3 (1.4 – 9.1) | 4.3 (1.4 – 11.4)
Week 8
N | 13 | 3 | 16
Mean (SD) | 3.7 (2.9) | 1.5 (0.4) | 3.3 (2.8)
Median (Min-Max) | 2.8 (1.2 – 11.4) | 1.7 (1.1 – 1.8) | 2.4 (1.1 – 11.4)
Week 16
N | 12 | 2 | 14
Mean (SD) | 3.5 (2.4) | 1.7 (0.0) | 3.3 (2.3)
Median (Min-Max) | 3.1 (1.0 – 8.5) | 1.7 (1.7 – 1.7) | 2.2 (1.0 – 8.5)
Week 20
N | 8 | 0 | 8
Mean (SD) | 3.7 (2.4) | 0 | 3.7 (2.4)
Median (Min-Max) | 3.2 (1.8 – 9.4) | 0 | 3.2 (1.8 – 9.4)
Week 28
N | 10 | 2 | 12
Mean (SD) | 3.4 (2.4) | 1.5 (0.2) | 3.1 (2.3)
Median (Min-Max) | 2.7 (0.8 – 8.4) | 1.5 (1.3 – 1.6) | 2.4 (0.8 – 8.4)
LOCF
N | 15 | 12 | 27
Mean (SD) | 4.5 (3.2) | 1.6 (0.6) | 3.2 (2.8)
Median (Min-Max) | 3.4 (0.8 – 12.8) | 1.8 (0.6 – 2.3) | 2.2 (0.6 – 12.8)
Change from Baseline to LOCF
N | 15 | 12 | 27
Mean (SD) | −0.6 (1.6) | −2.9 (2.4) | −1.6 (2.3)
Median (Min-Max) | −1.0 (−2.9 – 2.2) | −1.8 (−7.9 – −0.5) | −1.2 (−7.9 – 2.2)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.3.3.2 Summary of Clinical Laboratory Thyroid Panel by Visit and Discontinuation Phase Treatment Received Group Total T3 (ng/dL) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 128.8 (66.6) | 124.9 (58.3) | 127.0 (62.0)
Median (Min-Max) | 155.0 (32.2 – 225.0) | 147.0 (38.7 – 193.0) | 155.0 (32.2 – 225.0)
Week 8
N | 12 | 3 | 15
Mean (SD) | 112.6 (50.3) | 162.0 (10.4) | 122.5 (49.2)
Median (Min-Max) | 125.0 (37.0 – 180.0) | 157.0 (155.0 – 174.0) | 128.0 (37.0 – 180.0)
Week 16
N | 12 | 2 | 14
Mean (SD) | 116.4 (51.5) | 154.0 (1.4) | 121.8 (49.3)
Median (Min-Max) | 132.0 (37.5 – 183.0) | 154.0 (153.0 – 155.0) | 136.5 (37.5 – 183.0)
Week 20
N | 8 | 0 | 8
Mean (SD) | 104.5 (56.9) | 0 | 104.5 (56.9)
Median (Min-Max) | 130.5 (35.7 – 165.0) | 0 | 130.5 (35.7 – 165.0)
Week 28
N | 9 | 2 | 11
Mean (SD) | 129.6 (60.1) | 145.5 (13.4) | 132.5 (54.3)
Median (Min-Max) | 133.0 (38.1 – 202.0) | 145.5 (136.0 – 155.0) | 136.0 (38.1 – 202.0)
LOCF
N | 14 | 12 | 26
Mean (SD) | 139.8 (53.3) | 137.6 (62.2) | 138.8 (56.4)
Median (Min-Max) | 139.5 (38.1 – 212.0) | 159.5 (37.8 – 210.0) | 144.0 (37.8 – 212.0)
Change from Baseline to LOCF
N | 14 | 12 | 26
Mean (SD) | −0.2 (36.9) | 6.5 (23.0) | 2.9 (30.8)
Median (Min-Max) | −2.0 (−58.0 – 103.4) | 4.9 (−36.0 – 44.0) | 1.6 (−58.0 – 103.4)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.3.3.3 Summary of Clinical Laboratory Thyroid Panel by Visit and Discontinuation Phase Treatment Received Group Total T4 (μg/dL) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 16 | 14 | 30
Mean (SD) | 7.0 (1.1) | 7.5 (1.4) | 7.2 (1.3)
Median (Min-Max) | 7.0 (4.6 – 9.1) | 7.4 (5.8 – 11.0) | 7.2 (4.6 – 11.0)
Week 8
N | 13 | 3 | 16
Mean (SD) | 6.9 (1.3) | 8.4 (1.6) | 7.2 (1.5)
Median (Min-Max) | 6.7 (4.1 – 8.7) | 9.3 (6.6 – 9.4) | 7.0 (4.1 – 9.4)
Week 16
N | 12 | 2 | 14
Mean (SD) | 6.6 (1.1) | 8.4 (0.0) | 6.9 (1.2)
Median (Min-Max) | 6.9 (4.8 – 8.1) | 8.4 (8.4 – 8.4) | 7.1 (4.8 – 8.4)
Week 20
N | 8 | 0 | 8
Mean (SD) | 6.7 (1.1) | 0 | 6.7 (1.1)
Median (Min-Max) | 6.4 (5.4 – 8.6) | 0 | 6.4 (5.4 – 8.6)
Week 28
N | 9 | 2 | 11
Mean (SD) | 7.1 (0.7) | 8.9 (0.2) | 7.4 (0.9)
Median (Min-Max) | 7.1 (6.2 – 7.9) | 8.9 (8.7 – 9.0) | 7.3 (6.2 – 9.0)
LOCF
N | 14 | 12 | 26
Mean (SD) | 6.9 (0.9) | 8.2 (1.9) | 7.5 (1.5)
Median (Min-Max) | 6.9 (5.2 – 8.5) | 8.3 (5.1 – 12.7) | 7.5 (5.1 – 12.7)
Change from Baseline to LOCF
N | 13 | 12 | 25
Mean (SD) | −0.1 (1.2) | 0.5 (0.8) | 0.2 (1.1)
Median (Min-Max) | −0.1 (−3.0 – 2.0) | 0.4 (−0.7 – 1.7) | 0.1 (−3.0 – 2.0)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.3.3.4 Summary of Clinical Laboratory Thyroid Panel by Visit and Discontinuation Phase Treatment Received Group Antithyroglobulin Ab (IU/mL) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 21.8 (7.3) | 235.1 (795.8) | 118.1 (534.9)
Median (Min-Max) | 20.0 (20.0 – 50.0) | 20.0 (20.0 – 3000) | 20.0 (20.0 – 3000)
Week 8
N | 13 | 3 | 16
Mean (SD) | 21.2 (2.9) | 20.0 (0.0) | 20.9 (2.6)
Median (Min-Max) | 20.0 (20.0 – 29.0) | 20.0 (20.0 – 20.0) | 20.0 (20.0 – 29.0)
Week 16
N | 12 | 2 | 14
Mean (SD) | 24.1 (14.1) | 20.0 (0.0) | 23.5 (13.1)
Median (Min-Max) | 20.0 (20.0 – 69.0) | 20.0 (20.0 – 20.0) | 20.0 (20.0 – 69.0)
Week 20
N | 8 | 0 | 8
Mean (SD) | 32.3 (33.5) | 0 | 32.3 (33.5)
Median (Min-Max) | 20.0 (20.0 – 115.0) | 0 | 20.0 (20.0 – 115.0)
Week 28
N | 10 | 2 | 12
Mean (SD) | 40.6 (65.1) | 20.0 (0.0) | 37.2 (59.5)
Median (Min-Max) | 20.0 (20.0 – 226.0) | 20.0 (20.0 – 20.0) | 20.0 (20.0 – 226.0)
LOCF
N | 15 | 12 | 27
Mean (SD) | 33.7 (53.2) | 270.4 (859.6) | 138.9 (573.2)
Median (Min-Max) | 20.0 (20.0 – 226.0) | 20.0 (20.0 – 3000) | 20.0 (20.0 – 3000)
Change from Baseline to LOCF
N | 15 | 12 | 27
Mean (SD) | 11.7 (45.4) | −0.6 (2.0) | 6.3 (33.9)
Median (Min-Max) | 0.0 (0.0 – 176.0) | 0.0 (−6.8 – 0.0) | 0.0 (−6.8 – 176.0)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.3.3.5 Summary of Clinical Laboratory Thyroid Panel by Visit and Discontinuation Phase Treatment Received Group Thyroid Peroxidase Ab (IU/mL) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 13.0 (6.1) | 30.1 (60.2) | 20.7 (40.8)
Median (Min-Max) | 10.0 (10.0 – 31.0) | 10.0 (10.0 – 238.0) | 10.0 (10.0 – 238.0)
Week 8
N | 13 | 3 | 16
Mean (SD) | 13.8 (7.4) | 10.0 (0.0) | 13.1 (6.8)
Median (Min-Max) | 10.0 (10.0 – 30.0) | 10.0 (10.0 – 10.0) | 10.0 (10.0 – 30.0)
Week 16
N | 12 | 2 | 14
Mean (SD) | 13.7 (7.5) | 10.0 (0.0) | 13.1 (7.1)
Median (Min-Max) | 10.0 (10.0 – 30.0) | 10.0 (10.0 – 10.0) | 10.0 (10.0 – 30.0)
Week 20
N | 8 | 0 | 8
Mean (SD) | 14.8 (8.8) | 0 | 14.8 (8.8)
Median (Min-Max) | 10.0 (10.0 – 30.0) | 0 | 10.0 (10.0 – 30.0)
Week 28
N | 10 | 2 | 12
Mean (SD) | 15.7 (9.9) | 10.0 (0.0) | 14.8 (9.2)
Median (Min-Max) | 10.0 (10.0 – 38.0) | 10.0 (10.0 – 10.0) | 10.0 (10.0 – 38.0)
LOCF
N | 15 | 12 | 27
Mean (SD) | 14.1 (8.3) | 29.8 (53.8) | 21.0 (36.4)
Median (Min-Max) | 10.0 (10.0 – 38.0) | 10.0 (10.0 – 199.0) | 10.0 (10.0 – 199.0)
Change from Baseline to LOCF
N | 15 | 12 | 27
Mean (SD) | 0.7 (2.9) | −3.7 (11.6) | −1.3 (8.2)
Median (Min-Max) | 0.0 (−5.0 – 7.0) | 0.0 (−39.0 – 8.0) | 0.0 (−39.0 – 8.0)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.3.4.1 Summary of Clinical Laboratory Thyroid Panel by Visit and Discontinuation Phase Treatment Received Group Thyroid Stimulating Hormone – TSH (mIU/L) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 8.1 (4.2) | 1.6 (0.7) | 3.1 (3.4)
Median (Min-Max) | 6.5 (4.9 – 12.8) | 2.0 (0.6 – 2.3) | 2.1 (0.6 – 12.8)
Week 4
N | 2 | 8 | 10
Mean (SD) | 4.3 (1.0) | 2.7 (1.2) | 3.0 (1.3)
Median (Min-Max) | 4.3 (3.6 – 5.0) | 2.3 (1.4 – 4.5) | 3.0 (1.4 – 5.0)
Week 8
N | 2 | 7 | 9
Mean (SD) | 5.0 (1.3) | 3.7 (1.0) | 4.0 (1.1)
Median (Min-Max) | 5.0 (4.1 – 5.9) | 4.0 (2.1 – 4.7) | 4.1 (2.1 – 5.9)
LOCF
N | 2 | 10 | 12
Mean (SD) | 5.0 (1.3) | 3.6 (1.1) | 3.8 (1.2)
Median (Min-Max) | 5.0 (4.1 – 5.9) | 3.9 (1.4 – 4.7) | 4.0 (1.4 – 5.9)
Change from Baseline to LOCF
N | 2 | 10 | 12
Mean (SD) | −0.7 (2.4) | 1.9 (0.7) | 1.5 (1.4)
Median (Min-Max) | −0.7 (−2.4 – 1.0) | 1.8 (0.8 – 3.3) | 1.7 (−2.4 – 3.3)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.3.4.2 Summary of Clinical Laboratory Thyroid Panel by Visit and Discontinuation Phase Treatment Received Group Total T3 (ng/dL) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 170.7 (46.1) | 136.0 (68.5) | 144.0 (64.1)
Median (Min-Max) | 179.0 (121.0 – 212.0) | 167.0 (37.8 – 210.0) | 170.0 (37.8 – 212.0)
Week 4
N | 2 | 8 | 10
Mean (SD) | 153.5 (2.1) | 120.6 (50.8) | 127.2 (46.9)
Median (Min-Max) | 153.5 (152.0 – 155.0) | 138.5 (40.3 – 166.0) | 145.5 (40.3 – 166.0)
Week 8
N | 2 | 7 | 9
Mean (SD) | 157.5 (41.7) | 142.2 (51.9) | 145.6 (47.8)
Median (Min-Max) | 157.5 (128.0 – 187.0) | 144.0 (41.7 – 210.0) | 144.0 (41.7 – 210.0)
LOCF
N | 2 | 10 | 12
Mean (SD) | 157.5 (41.7) | 125.4 (62.5) | 130.8 (59.2)
Median (Min-Max) | 157.5 (128.0 – 187.0) | 142.0 (40.7 – 210.0) | 142.0 (40.7 – 210.0)
Change from Baseline to LOCF
N | 2 | 10 | 12
Mean (SD) | 7.5 (0.7) | −10.6 (18.5) | −7.6 (18.2)
Median (Min-Max) | 7.5 (7.0 – 8.0) | −2.2 (−43.0 – 7.0) | −0.7 (−43.0 – 8.0)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.3.4.3 Summary of Clinical Laboratory Thyroid Panel by Visit and Discontinuation Phase Treatment Received Group Total T4l (μg/dL) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 6.2 (0.9) | 8.1 (2.0) | 7.6 (2.0)
Median (Min-Max) | 6.7 (5.2 – 6.7) | 7.8 (5.1 – 12.7) | 7.7 (5.1 – 12.7)
Week 4
N | 2 | 8 | 10
Mean (SD) | 5.9 (0.9) | 7.6 (2.1) | 7.2 (2.0)
Median (Min-Max) | 5.9 (5.2 – 6.5) | 7.2 (5.1 – 11.9) | 6.9 (5.1 – 11.9)
Week 8
N | 2 | 7 | 9
Mean (SD) | 6.3 (1.7) | 7.8 (2.7) | 7.5 (2.5)
Median (Min-Max) | 6.3 (5.1 – 7.5) | 7.3 (4.8 – 13.2) | 7.3 (4.8 – 13.2)
LOCF
N | 2 | 10 | 12
Mean (SD) | 6.3 (1.7) | 7.6 (2.3) | 7.4 (2.2)
Median (Min-Max) | 6.3 (5.1 – 7.5) | 7.3 (4.8 – 13.2) | 7.3 (4.8 – 13.2)
Change from Baseline to LOCF
N | 2 | 10 | 12
Mean (SD) | 0.4 (0.6) | −0.5 (1.2) | −0.3 (1.1)
Median (Min-Max) | 0.4 (−0.1 – 0.8) | −0.7 (−2.0 – 1.5) | −0.4 (−2.0 – 1.5)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.3.4.4 Summary of Clinical Laboratory Thyroid Panel by Visit and Discontinuation Phase Treatment Received Group Antithyroglobulin Ab (IU/mL) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 20.0 (0.0) | 320.5 (941.5) | 251.1 (826.0)
Median (Min-Max) | 20.0 (20.0 – 20.0) | 20.0 (20.0 – 3000) | 20.0 (20.0 – 3000)
Week 4
N | 2 | 8 | 10
Mean (SD) | 20.0 (0.0) | 395.1 (1053) | 320.1 (941.7)
Median (Min-Max) | 20.0 (20.0 – 20.0) | 20.0 (20.0 – 3000) | 20.0 (20.0 – 3000)
Week 8
N | 1 | 7 | 8
Mean (SD) | 20.0 | 450.5 (1124) | 396.7 (1052)
Median (Min-Max) | 20.0 | 20.0 (20.0 – 3000) | 20.0 (20.0 – 3000)
LOCF
N | 1 | 10 | 11
Mean (SD) | 20.0 | 321.4 (941.2) | 294.0 (897.5)
Median (Min-Max) | 20.0 | 20.0 (20.0 – 3000) | 20.0 (20.0 – 3000)
Change from Baseline to LOCF
N | 1 | 10 | 11
Mean (SD) | 0.0 | 0.9 (2.9) | 0.8 (2.7)
Median (Min-Max) | 0.0 | 0.0 (0.0 – 9.1) | 0.0 (0.0 – 9.1)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.3.4.5 Summary of Clinical Laboratory Thyroid Panel by Visit and Discontinuation Phase Treatment Received Group Thyroid Peroxidase Ab (IU/mL) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 11.3 (2.3) | 33.7 (58.7) | 28.6 (51.7)
Median (Min-Max) | 10.0 (10.0 – 14.0) | 10.5 (10.0 – 199.0) | 10.0 (10.0 – 199.0)
Week 4
N | 2 | 8 | 10
Mean (SD) | 12.5 (3.5) | 48.5 (89.9) | 41.3 (80.8)
Median (Min-Max) | 12.5 (10.0 – 15.0) | 15.0 (10.0 – 270.0) | 12.5 (10.0 – 270.0)
Week 8
N | 2 | 7 | 9
Mean (SD) | 12.5 (3.5) | 49.0 (79.6) | 40.9 (70.8)
Median (Min-Max) | 12.5 (10.0 – 15.0) | 21.0 (10.0 – 228.0) | 15.0 (10.0 – 228.0)
LOCF
N | 2 | 10 | 12
Mean (SD) | 12.5 (3.5) | 37.6 (67.6) | 33.4 (61.9)
Median (Min-Max) | 12.5 (10.0 – 15.0) | 11.5 (10.0 – 228.0) | 11.5 (10.0 – 228.0)
Change from Baseline to LOCF
N | 2 | 10 | 12
Mean (SD) | 0.5 (0.7) | 3.9 (9.9) | 3.3 (9.0)
Median (Min-Max) | 0.5 (0.0 – 1.0) | 0.0 (−7.0 – 29.0) | 0.0 (−7.0 – 29.0)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.4.1.1 Summary of Clinical Laboratory Urinalysis Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group pH Safety Population Efficacy Phase

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 6.02 (0.76) | 5.82 (0.58) | 6.38 (0.80) | 5.55 (0.61) | 6.16 (0.79) | 5.71 (0.60)
Median (Min-Max) | 6.00 (5.00, 7.50) | 6.00 (5.00, 7.00) | 6.50 (5.00, 7.50) | 5.50 (5.00, 6.50) | 6.00 (5.00, 7.50) | 5.75 (5.00, 7.00)
Week 2
N | 11 | 5 | 8 | 3 | 19 | 8
Mean (SD) | 7.05 (0.61) | 5.70 (0.84) | 6.88 (0.79) | 6.83 (1.04) | 6.97 (0.68) | 6.13 (1.03)
Median (Min-Max) | 7.00 (6.00, 8.00) | 5.50 (5.00, 7.00) | 6.75 (5.50, 8.00) | 6.50 (6.00, 8.00) | 7.00 (5.50, 8.00) | 6.00 (5.00, 8.00)
Week 4
N | 24 | 11 | 14 | 9 | 38 | 20
Mean (SD) | 6.79 (0.57) | 6.41 (0.86) | 6.86 (0.84) | 6.28 (0.44) | 6.82 (0.67) | 6.35 (0.69)
Median (Min-Max) | 7.00 (5.00, 8.00) | 6.50 (5.00, 8.00) | 7.00 (5.50, 8.00) | 6.50 (5.50, 7.00) | 7.00 (5.00, 8.00) | 6.50 (5.00, 8.00)
Week 8
N | 28 | 13 | 20 | 10 | 48 | 23
Mean (SD) | 6.71 (0.75) | 6.38 (0.94) | 6.83 (0.78) | 5.90 (0.70) | 6.76 (0.76) | 6.17 (0.86)
Median (Min-Max) | 7.00 (5.50, 8.00) | 6.00 (5.50, 8.00) | 7.00 (5.00, 8.00) | 6.00 (5.00, 7.00) | 7.00 (5.00, 8.00) | 6.00 (5.00, 8.00)
LOCF
N | 31 | 17 | 21 | 10 | 52 | 27
Mean (SD) | 6.66 (0.78) | 6.35 (0.86) | 6.88 (0.80) | 5.90 (0.70) | 6.75 (0.79) | 6.19 (0.82)
Median (Min-Max) | 7.00 (5.00, 8.00) | 6.00 (5.50, 8.00) | 7.00 (5.00, 8.00) | 6.00 (5.00, 7.00) | 7.00 (5.00, 8.00) | 6.00 (5.00, 8.00)
Change from Baseline to LOCF
N | 31 | 17 | 21 | 10 | 52 | 27
Mean (SD) | 0.65 (1.05) | 0.53 (0.89) | 0.50 (0.97) | 0.45 (0.93) | 0.59 (1.01) | 0.50 (0.89)
Median (Min-Max) | 1.00 (−1.50, 3.00) | 0.50 (−0.50, 3.00) | 0.50 (−1.00, 2.00) | 0.00 (−0.50, 2.00) | 0.50 (−1.50, 3.00) | 0.00 (−0.50, 3.00)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.4.1.2 Summary of Clinical Laboratory Urinalysis Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Specific Gravity Safety Population Efficacy Phase

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 1.020 (0.006) | 1.018 (0.007) | 1.019 (0.007) | 1.019 (0.009) | 1.020 (0.006) | 1.019 (0.008)
Median (Min-Max) | 1.021 (1.006, 1.032) | 1.018 (1.006, 1.031) | 1.020 (1.005, 1.031) | 1.017 (1.002, 1.033) | 1.020 (1.005, 1.032) | 1.018 (1.002, 1.033)
Week 2
N | 11 | 5 | 8 | 3 | 19 | 8
Mean (SD) | 1.016 (0.005) | 1.019 (0.007) | 1.014 (0.004) | 1.023 (0.002) | 1.015 (0.004) | 1.021 (0.006)
Median (Min-Max) | 1.015 (1.007, 1.024) | 1.019 (1.008, 1.028) | 1.015 (1.007, 1.022) | 1.023 (1.022, 1.025) | 1.015 (1.007, 1.024) | 1.022 (1.008, 1.028)
Week 4
N | 24 | 11 | 14 | 9 | 38 | 20
Mean (SD) | 1.013 (0.007) | 1.023 (0.007) | 1.011 (0.005) | 1.016 (0.010) | 1.012 (0.006) | 1.020 (0.009)
Median (Min-Max) | 1.010 (1.002, 1.031) | 1.024 (1.011, 1.030) | 1.010 (1.002, 1.018) | 1.013 (1.001, 1.037) | 1.010 (1.002, 1.031) | 1.020 (1.001, 1.037)
Week 8
N | 28 | 13 | 20 | 10 | 48 | 23
Mean (SD) | 1.014 (0.007) | 1.019 (0.004) | 1.013 (0.004) | 1.019 (0.006) | 1.013 (0.006) | 1.019 (0.005)
Median (Min-Max) | 1.015 (1.001, 1.024) | 1.019 (1.014, 1.026) | 1.014 (1.005, 1.021) | 1.020 (1.010, 1.027) | 1.015 (1.001, 1.024) | 1.019 (1.010, 1.027)
LOCF
N | 31 | 17 | 21 | 10 | 52 | 27
Mean (SD) | 1.014 (0.007) | 1.020 (0.005) | 1.013 (0.004) | 1.019 (0.006) | 1.014 (0.006) | 1.020 (0.005)
Median (Min-Max) | 1.015 (1.001, 1.031) | 1.020 (1.014, 1.030) | 1.014 (1.005, 1.021) | 1.020 (1.010, 1.027) | 1.015 (1.001, 1.031) | 1.020 (1.010, 1.030)
Change from Baseline to LOCF
N | 31 | 17 | 21 | 10 | 52 | 27
Mean (SD) | −.006 (0.009) | 0.002 (0.007) | −.006 (0.006) | 0.002 (0.010) | −.006 (0.008) | 0.002 (0.008)
Median (Min-Max) | −.004 (−.023, 0.016) | 0.001 (−.017, 0.013) | −.005 (−.016, 0.003) | 0.001 (−.013, 0.023) | −.005 (−.023, 0.016) | 0.001 (−.017, 0.023)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.4.1.3 Summary of Clinical Laboratory Urinalysis Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Protein Safety Population Efficacy Phase

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
Negative | 24 (75.0%) | 15 (88.2%) | 19 (90.5%) | 9 (81.8%) | 43 (81.1%) | 24 (85.7%)
Trace | 5 (15.6%) | 1 (5.9%) | 2 (9.5%) | 0 | 7 (13.2%) | 1 (3.6%)
1+ | 2 (6.3%) | 1 (5.9%) | 0 | 1 (9.1%) | 2 (3.8%) | 2 (7.1%)
2+ | 0 | 0 | 0 | 0 | 0 | 0
3+ | 0 | 0 | 0 | 0 | 0 | 0
4+ | 1 (3.1%) | 0 | 0 | 1 (9.1%) | 1 (1.9%) | 1 (3.6%)
Week 2
Negative | 9 (81.8%) | 4 (80.0%) | 7 (87.5%) | 3 (100.0%) | 16 (84.2%) | 7 (87.5%)
Trace | 2 (18.2%) | 0 | 1 (12.5%) | 0 | 3 (15.8%) | 0
1+ | 0 | 1 (20.0%) | 0 | 0 | 0 | 1 (12.5%)
2+ | 0 | 0 | 0 | 0 | 0 | 0
3+ | 0 | 0 | 0 | 0 | 0 | 0
4+ | 0 | 0 | 0 | 0 | 0 | 0
Week 4
Negative | 22 (91.7%) | 7 (63.6%) | 13 (92.9%) | 8 (88.9%) | 35 (92.1%) | 15 (75.0%)
Trace | 1 (4.2%) | 2 (18.2%) | 1 (7.1%) | 1 (11.1%) | 2 (5.3%) | 3 (15.0%)
1+ | 1 (4.2%) | 2 (18.2%) | 0 | 0 | 1 (2.6%) | 2 (10.0%)
2+ | 0 | 0 | 0 | 0 | 0 | 0
3+ | 0 | 0 | 0 | 0 | 0 | 0
4+ | 0 | 0 | 0 | 0 | 0 | 0
Week 8
Negative | 24 (85.7%) | 9 (69.2%) | 17 (85.0%) | 7 (70.0%) | 41 (85.4%) | 16 (69.6%)
Trace | 2 (7.1%) | 2 (15.4%) | 1 (5.0%) | 3 (30.0%) | 3 (6.3%) | 5 (21.7%)
1+ | 2 (7.1%) | 1 (7.7%) | 1 (5.0%) | 0 | 3 (6.3%) | 1 (4.3%)
2+ | 0 | 1 (7.7%) | 1 (5.0%) | 0 | 1 (2.1%) | 1 (4.3%)
3+ | 0 | 0 | 0 | 0 | 0 | 0
4+ | 0 | 0 | 0 | 0 | 0 | 0
LOCF
Negative | 27 (87.1%) | 12 (70.6%) | 18 (85.7%) | 7 (70.0%) | 45 (86.5%) | 19 (70.4%)
Trace | 2 (6.5%) | 2 (11.8%) | 1 (4.8%) | 3 (30.0%) | 3 (5.8%) | 5 (18.5%)
1+ | 2 (6.5%) | 2 (11.8%) | 1 (4.8%) | 0 | 3 (5.8%) | 2 (7.4%)
2+ | 0 | 1 (5.9%) | 1 (4.8%) | 0 | 1 (1.9%) | 1 (3.7%)
3+ | 0 | 0 | 0 | 0 | 0 | 0
4+ | 0 | 0 | 0 | 0 | 0 | 0

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.4.1.4 Summary of Clinical Laboratory Urinalysis Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Glucose Safety Population Efficacy Phase

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
Negative | 32 (100.0%) | 17 (100.0%) | 21 (100.0%) | 11 (100.0%) | 53 (100.0%) | 28 (100.0%)
Trace | 0 | 0 | 0 | 0 | 0 | 0
1+ | 0 | 0 | 0 | 0 | 0 | 0
2+ | 0 | 0 | 0 | 0 | 0 | 0
3+ | 0 | 0 | 0 | 0 | 0 | 0
4+ | 0 | 0 | 0 | 0 | 0 | 0
Week 2
Negative | 11 (100.0%) | 5 (100.0%) | 8 (100.0%) | 3 (100.0%) | 19 (100.0%) | 8 (100.0%)
Trace | 0 | 0 | 0 | 0 | 0 | 0
1+ | 0 | 0 | 0 | 0 | 0 | 0
2+ | 0 | 0 | 0 | 0 | 0 | 0
3+ | 0 | 0 | 0 | 0 | 0 | 0
4+ | 0 | 0 | 0 | 0 | 0 | 0
Week 4
Negative | 23 (95.8%) | 11 (100.0%) | 14 (100.0%) | 9 (100.0%) | 37 (97.4%) | 20 (100.0%)
4+ | 1 (4.2%) | 0 | 0 | 0 | 1 (2.6%) | 0
Trace | 0 | 0 | 0 | 0 | 0 | 0
1+ | 0 | 0 | 0 | 0 | 0 | 0
2+ | 0 | 0 | 0 | 0 | 0 | 0
3+ | 0 | 0 | 0 | 0 | 0 | 0
Week 8
Negative | 28 (100.0%) | 13 (100.0%) | 20 (100.0%) | 10 (100.0%) | 48 (100.0%) | 23 (100.0%)
Trace | 0 | 0 | 0 | 0 | 0 | 0
1+ | 0 | 0 | 0 | 0 | 0 | 0
2+ | 0 | 0 | 0 | 0 | 0 | 0
3+ | 0 | 0 | 0 | 0 | 0 | 0
4+ | 0 | 0 | 0 | 0 | 0 | 0
LOCF
Negative | 30 (96.8%) | 17 (100.0%) | 21 (100.0%) | 10 (100.0%) | 51 (98.1%) | 27 (100.0%)
Trace | 0 | 0 | 0 | 0 | 0 | 0
1+ | 0 | 0 | 0 | 0 | 0 | 0
2+ | 0 | 0 | 0 | 0 | 0 | 0
3+ | 0 | 0 | 0 | 0 | 0 | 0
4+ | 1 (3.2%) | 0 | 0 | 0 | 1 (1.9%) | 0

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.4.1.5 Summary of Clinical Laboratory Urinalysis Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Ketones Safety Population Efficacy Phase

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
Negative | 28 (87.5%) | 17 (100.0%) | 19 (90.5%) | 10 (90.9%) | 47 (88.7%) | 27 (96.4%)
Trace | 4 (12.5%) | 0 | 2 (9.5%) | 1 (9.1%) | 6 (11.3%) | 1 (3.6%)
1+ | 0 | 0 | 0 | 0 | 0 | 0
2+ | 0 | 0 | 0 | 0 | 0 | 0
3+ | 0 | 0 | 0 | 0 | 0 | 0
4+ | 0 | 0 | 0 | 0 | 0 | 0
Week 2
Negative | 10 (90.9%) | 5 (100.0%) | 8 (100.0%) | 3 (100.0%) | 18 (94.7%) | 8 (100.0%)
Trace | 1 (9.1%) | 0 | 0 | 0 | 1 (5.3%) | 0
1+ | 0 | 0 | 0 | 0 | 0 | 0
2+ | 0 | 0 | 0 | 0 | 0 | 0
3+ | 0 | 0 | 0 | 0 | 0 | 0
4+ | 0 | 0 | 0 | 0 | 0 | 0
Week 4
Negative | 24 (100.0%) | 11 (100.0%) | 14 (100.0%) | 9 (100.0%) | 38 (100.0%) | 20 (100.0%)
Trace | 0 | 0 | 0 | 0 | 0 | 0
1+ | 0 | 0 | 0 | 0 | 0 | 0
2+ | 0 | 0 | 0 | 0 | 0 | 0
3+ | 0 | 0 | 0 | 0 | 0 | 0
4+ | 0 | 0 | 0 | 0 | 0 | 0
Week 8
Negative | 26 (92.9%) | 11 (84.6%) | 20 (100.0%) | 10 (100.0%) | 46 (95.8%) | 21 (91.3%)
Trace | 2 (7.1%) | 2 (15.4%) | 0 | 0 | 2 (4.2%) | 2 (8.7%)
1+ | 0 | 0 | 0 | 0 | 0 | 0
2+ | 0 | 0 | 0 | 0 | 0 | 0
3+ | 0 | 0 | 0 | 0 | 0 | 0
4+ | 0 | 0 | 0 | 0 | 0 | 0
LOCF
Negative | 29 (93.5%) | 15 (88.2%) | 21 (100.0%) | 10 (100.0%) | 50 (96.2%) | 25 (92.6%)
Trace | 2 (6.5%) | 2 (11.8%) | 0 | 0 | 2 (3.8%) | 2 (7.4%)
1+ | 0 | 0 | 0 | 0 | 0 | 0
2+ | 0 | 0 | 0 | 0 | 0 | 0
3+ | 0 | 0 | 0 | 0 | 0 | 0
4+ | 0 | 0 | 0 | 0 | 0 | 0

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.4.1.6 Summary of Clinical Laboratory Urinalysis Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Nitrite Safety Population Efficacy Phase

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
Negative | 32 (100.0%) | 17 (100.0%) | 21 (100.0%) | 11 (100.0%) | 53 (100.0%) | 28 (100.0%)
Trace | 0 | 0 | 0 | 0 | 0 | 0
2+ | 0 | 0 | 0 | 0 | 0 | 0
3+ | 0 | 0 | 0 | 0 | 0 | 0
4+ | 0 | 0 | 0 | 0 | 0 | 0
Week 2
Negative | 11 (100.0%) | 5 (100.0%) | 8 (100.0%) | 3 (100.0%) | 19 (100.0%) | 8 (100.0%)
Trace | 0 | 0 | 0 | 0 | 0 | 0
1+ | 0 | 0 | 0 | 0 | 0 | 0
2+ | 0 | 0 | 0 | 0 | 0 | 0
3+ | 0 | 0 | 0 | 0 | 0 | 0
4+ | 0 | 0 | 0 | 0 | 0 | 0
Week 4
Negative | 24 (100.0%) | 11 (100.0%) | 14 (100.0%) | 9 (100.0%) | 38 (100.0%) | 20 (100.0%)
Trace | 0 | 0 | 0 | 0 | 0 | 0
1+ | 0 | 0 | 0 | 0 | 0 | 0
2+ | 0 | 0 | 0 | 0 | 0 | 0
3+ | 0 | 0 | 0 | 0 | 0 | 0
4+ | 0 | 0 | 0 | 0 | 0 | 0
Week 8
Negative | 28 (100.0%) | 13 (100.0%) | 20 (100.0%) | 10 (100.0%) | 48 (100.0%) | 23 (100.0%)
Trace | 0 | 0 | 0 | 0 | 0 | 0
1+ | 0 | 0 | 0 | 0 | 0 | 0
2+ | 0 | 0 | 0 | 0 | 0 | 0
3+ | 0 | 0 | 0 | 0 | 0 | 0
4+ | 0 | 0 | 0 | 0 | 0 | 0
LOCF
Negative | 31 (100.0%) | 17 (100.0%) | 21 (100.0%) | 10 (100.0%) | 52 (100.0%) | 27 (100.0%)
Trace | 0 | 0 | 0 | 0 | 0 | 0
1+ | 0 | 0 | 0 | 0 | 0 | 0
2+ | 0 | 0 | 0 | 0 | 0 | 0
3+ | 0 | 0 | 0 | 0 | 0 | 0
4+ | 0 | 0 | 0 | 0 | 0 | 0

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.4.1.7 Summary of Clinical Laboratory Urinalysis Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Leukocyte Esterase Safety Population Efficacy Phase

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
Negative | 28 (87.5%) | 13 (76.5%) | 17 (81.0%) | 9 (81.8%) | 45 (84.9%) | 22 (78.6%)
Trace | 1 (3.1%) | 2 (11.8%) | 2 (9.5%) | 1 (9.1%) | 3 (5.7%) | 3 (10.7%)
1+ | 1 (3.1%) | 1 (5.9%) | 1 (4.8%) | 1 (9.1%) | 2 (3.8%) | 2 (7.1%)
2+ | 2 (6.3%) | 1 (5.9%) | 1 (4.8%) | 0 | 3 (5.7%) | 1 (3.6%)
3+ | 0 | 0 | 0 | 0 | 0 | 0
4+ | 0 | 0 | 0 | 0 | 0 | 0
Week 2
Negative | 9 (81.8%) | 5 (100.0%) | 7 (87.5%) | 3 (100.0%) | 16 (84.2%) | 8 (100.0%)
Trace | 1 (9.1%) | 0 | 0 | 0 | 1 (5.3%) | 0
2+ | 0 | 0 | 1 (12.5%) | 0 | 1 (5.3%) | 0
1+ | 0 | 0 | 0 | 0 | 0 | 0
3+ | 1 (9.1%) | 0 | 0 | 0 | 1 (5.3%) | 0
4+ | 0 | 0 | 0 | 0 | 0 | 0
Week 4
Negative | 22 (91.7%) | 9 (81.8%) | 14 (100.0%) | 8 (88.9%) | 36 (94.7%) | 17 (85.0%)
Trace | 2 (8.3%) | 0 | 0 | 1 (11.1%) | 2 (5.3%) | 1 (5.0%)
1+ | 0 | 1 (9.1%) | 0 | 0 | 0 | 1 (5.0%)
2+ | 0 | 1 (9.1%) | 0 | 0 | 0 | 1 (5.0%)
3+ | 0 | 0 | 0 | 0 | 0 | 0
4+ | 0 | 0 | 0 | 0 | 0 | 0
Week 8
Negative | 25 (89.3%) | 11 (84.6%) | 16 (80.0%) | 9 (90.0%) | 41 (85.4%) | 20 (87.0%)
Trace | 0 | 1 (7.7%) | 3 (15.0%) | 0 | 3 (6.3%) | 1 (4.3%)
1+ | 2 (7.1%) | 0 | 1 (5.0%) | 0 | 3 (6.3%) | 0
2+ | 0 | 1 (7.7%) | 0 | 1 (10.0%) | 0 | 2 (8.7%)
3+ | 1 (3.6%) | 0 | 0 | 0 | 1 (2.1%) | 0
4+ | 0 | 0 | 0 | 0 | 0 | 0
LOCF
Negative | 27 (87.1%) | 14 (82.4%) | 16 (76.2%) | 9 (90.0%) | 43 (82.7%) | 23 (85.2%)
Trace | 0 | 1 (5.9%) | 3 (14.3%) | 0 | 3 (5.8%) | 1 (3.7%)
1+ | 3 (9.7%) | 0 | 1 (4.8%) | 0 | 4 (7.7%) | 0
2+ | 0 | 2 (11.8%) | 1 (4.8%) | 1 (10.0%) | 1 (1.9%) | 3 (11.1%)
3+ | 1 (3.2%) | 0 | 0 | 0 | 1 (1.9%) | 0
4+ | 0 | 0 | 0 | 0 | 0 | 0

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.4.1.8 Summary of Clinical Laboratory Urinalysis Measurement by Visit, Age Strata and Efficacy Phase Treatment Received Group Blood Safety Population Efficacy Phase

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
Negative | 29 (90.6%) | 16 (94.1%) | 17 (81.0%) | 11 (100.0%) | 46 (86.8%) | 27 (96.4%)
Trace | 1 (3.1%) | 0 | 1 (4.8%) | 0 | 2 (3.8%) | 0
1+ | 0 | 0 | 0 | 0 | 0 | 0
2+ | 1 (3.1%) | 1 (5.9%) | 1 (4.8%) | 0 | 2 (3.8%) | 1 (3.6%)
3+ | 1 (3.1%) | 0 | 2 (9.5%) | 0 | 3 (5.7%) | 0
4+ | 0 | 0 | 0 | 0 | 0 | 0
Week 2
Negative | 11 (100.0%) | 5 (100.0%) | 8 (100.0%) | 2 (66.7%) | 19 (100.0%) | 7 (87.5%)
Trace | 0 | 0 | 0 | 1 (33.3%) | 0 | 1 (12.5%)
1+ | 0 | 0 | 0 | 0 | 0 | 0
2+ | 0 | 0 | 0 | 0 | 0 | 0
3+ | 0 | 0 | 0 | 0 | 0 | 0
4+ | 0 | 0 | 0 | 0 | 0 | 0
Week 4
Negative | 21 (87.5%) | 11 (100.0%) | 12 (85.7%) | 8 (88.9%) | 33 (86.8%) | 19 (95.0%)
Trace | 2 (8.3%) | 0 | 1 (7.1%) | 0 | 3 (7.9%) | 0
2+ | 1 (4.2%) | 0 | 1 (7.1%) | 0 | 2 (5.3%) | 0
1+ | 0 | 0 | 0 | 0 | 0 | 0
3+ | 0 | 0 | 0 | 1 (11.1%) | 0 | 1 (5.0%)
4+ | 0 | 0 | 0 | 0 | 0 | 0
Week 8
Negative | 26 (92.9%) | 13 (100.0%) | 18 (90.0%) | 8 (80.0%) | 44 (91.7%) | 21 (91.3%)
Trace | 0 | 0 | 2 (10.0%) | 1 (10.0%) | 2 (4.2%) | 1 (4.3%)
1+ | 1 (3.6%) | 0 | 0 | 0 | 1 (2.1%) | 0
3+ | 1 (3.6%) | 0 | 0 | 0 | 1 (2.1%) | 0
2+ | 0 | 0 | 0 | 0 | 0 | 0
4+ | 0 | 0 | 0 | 1 (10.0%) | 0 | 1 (4.3%)
LOCF
Negative | 29 (93.5%) | 17 (100.0%) | 19 (90.5%) | 8 (80.0%) | 48 (92.3%) | 25 (92.6%)
Trace | 0 | 0 | 2 (9.5%) | 1 (10.0%) | 2 (3.8%) | 1 (3.7%)
1+ | 1 (3.2%) | 0 | 0 | 0 | 1 (1.9%) | 0
3+ | 1 (3.2%) | 0 | 0 | 0 | 1 (1.9%) | 0
4+ | 0 | 0 | 0 | 1 (10.0%) | 0 | 1 (3.7%)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.4.2.1A Summary of Clinical Laboratory Urinalysis Measurement by Visit and Age Strata pH Safety Population Long-Term Effectiveness Phase

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 6.67 (0.88) | 6.33 (0.88) | 6.56 (0.88)
Median (Min-Max) | 7.00 (5.50, 8.00) | 7.00 (5.00, 7.50) | 7.00 (5.00, 8.00)
Week 4
N | 10 | 6 | 16
Mean (SD) | 6.60 (0.66) | 6.83 (0.82) | 6.69 (0.70)
Median (Min-Max) | 6.75 (5.50, 7.50) | 7.00 (5.50, 8.00) | 7.00 (5.50, 8.00)
Week 8
N | 23 | 13 | 36
Mean (SD) | 6.80 (0.56) | 6.54 (0.80) | 6.71 (0.66)
Median (Min-Max) | 7.00 (5.00, 7.50) | 6.50 (5.00, 8.00) | 7.00 (5.00, 8.00)
Week 16
N | 21 | 7 | 28
Mean (SD) | 6.93 (0.68) | 6.64 (0.38) | 6.86 (0.62)
Median (Min-Max) | 7.00 (5.50, 8.00) | 6.50 (6.00, 7.00) | 7.00 (5.50, 8.00)
Week 24
N | 16 | 6 | 22
Mean (SD) | 6.81 (0.51) | 6.92 (0.38) | 6.84 (0.47)
Median (Min-Max) | 7.00 (6.00, 7.50) | 7.00 (6.50, 7.50) | 7.00 (6.00, 7.50)
LOCF
N | 26 | 14 | 40
Mean (SD) | 6.81 (0.78) | 6.79 (0.83) | 6.80 (0.78)
Median (Min-Max) | 7.00 (5.00, 8.50) | 7.00 (5.00, 8.00) | 7.00 (5.00, 8.50)
Change from Baseline to LOCF
N | 26 | 14 | 40
Mean (SD) | 0.12 (0.78) | 0.36 (1.12) | 0.20 (0.90)
Median (Min-Max) | 0.00 (−2.00, 1.50) | 0.25 (−2.00, 2.50) | 0.00 (−2.00, 2.50)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.4.2.2A Summary of Clinical Laboratory Urinalysis Measurement by Visit and Age Strata Specific Gravity Safety Population Long-Term Effectiveness Phase

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 1.014 (0.006) | 1.015 (0.007) | 1.014 (0.007)
Median (Min-Max) | 1.015 (1.001, 1.024) | 1.015 (1.005, 1.025) | 1.015 (1.001, 1.025)
Week 4
N | 10 | 6 | 16
Mean (SD) | 1.011 (0.006) | 1.011 (0.004) | 1.011 (0.005)
Median (Min-Max) | 1.011 (1.002, 1.021) | 1.011 (1.006, 1.017) | 1.011 (1.002, 1.021)
Week 8
N | 23 | 13 | 36
Mean (SD) | 1.012 (0.007) | 1.010 (0.007) | 1.011 (0.007)
Median (Min-Max) | 1.010 (1.002, 1.025) | 1.009 (1.002, 1.024) | 1.010 (1.002, 1.025)
Week 16
N | 21 | 7 | 28
Mean (SD) | 1.011 (0.008) | 1.005 (0.001) | 1.010 (0.007)
Median (Min-Max) | 1.010 (1.002, 1.033) | 1.005 (1.003, 1.007) | 1.008 (1.002, 1.033)
Week 24
N | 16 | 6 | 22
Mean (SD) | 1.013 (0.006) | 1.011 (0.005) | 1.013 (0.006)
Median (Min-Max) | 1.013 (1.004, 1.025) | 1.010 (1.005, 1.020) | 1.013 (1.004, 1.025)
LOCF
N | 26 | 14 | 40
Mean (SD) | 1.014 (0.006) | 1.012 (0.006) | 1.013 (0.006)
Median (Min-Max) | 1.013 (1.003, 1.025) | 1.012 (1.005, 1.024) | 1.013 (1.003, 1.025)
Change from Baseline to LOCF
N | 26 | 14 | 40
Mean (SD) | 0.000 (0.006) | −.002 (0.009) | −.000 (0.007)
Median (Min-Max) | 0.000 (−.012, 0.014) | −.001 (−.014, 0.015) | 0.000 (−.014, 0.015)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.4.2.3A Summary of Clinical Laboratory Urinalysis Measurement by Visit and Age Strata Protein Safety Population Long-Term Effectiveness Phase

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline
Negative | 25 (86.2%) | 12 (80.0%) | 37 (84.1%)
Trace | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
1+ | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
2+ | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 4
Negative | 9 (90.0%) | 6 (100.0%) | 15 (93.8%)
Trace | 0 | 0 | 0
1+ | 1 (10.0%) | 0 | 1 (6.3%)
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 8
Negative | 20 (87.0%) | 10 (76.9%) | 30 (83.3%)
Trace | 2 (8.7%) | 2 (15.4%) | 4 (11.1%)
1+ | 1 (4.3%) | 0 | 1 (2.8%)
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 1 (7.7%) | 1 (2.8%)
Week 16
Negative | 18 (85.7%) | 6 (85.7%) | 24 (85.7%)
Trace | 1 (4.8%) | 0 | 1 (3.6%)
1+ | 1 (4.8%) | 1 (14.3%) | 2 (7.1%)
2+ | 0 | 0 | 0
3+ | 1 (4.8%) | 0 | 1 (3.6%)
4+ | 0 | 0 | 0
Week 24
Negative | 13 (81.3%) | 5 (83.3%) | 18 (81.8%)
Trace | 1 (6.3%) | 0 | 1 (4.5%)
1+ | 1 (6.3%) | 0 | 1 (4.5%)
2+ | 0 | 1 (16.7%) | 1 (4.5%)
3+ | 1 (6.3%) | 0 | 1 (4.5%)
4+ | 0 | 0 | 0
LOCF
Negative | 18 (69.2%) | 11 (78.6%) | 29 (72.5%)
Trace | 3 (11.5%) | 2 (14.3%) | 5 (12.5%)
1+ | 4 (15.4%) | 0 | 4 (10.0%)
2+ | 0 | 1 (7.1%) | 1 (2.5%)
3+ | 1 (3.8%) | 0 | 1 (2.5%)
4+ | 0 | 0 | 0

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.4.2.4A Summary of Clinical Laboratory Urinalysis Measurement by Visit and Age Strata Glucose Safety Population Long-Term Effectiveness Phase

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline
Negative | 29 (100.0%) | 15 (100.0%) | 44 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 4
Negative | 10 (100.0%) | 6 (100.0%) | 16 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 8
Negative | 23 (100.0%) | 13 (100.0%) | 36 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 16
Negative | 21 (100.0%) | 7 (100.0%) | 28 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 24
Negative | 16 (100.0%) | 6 (100.0%) | 22 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
LOCF
Negative | 26 (100.0%) | 14 (100.0%) | 40 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.4.2.5A Summary of Clinical Laboratory Urinalysis Measurement by Visit and Age Strata Ketones Safety Population Long-Term Effectiveness Phase

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline
Negative | 28 (96.6%) | 14 (93.3%) | 42 (95.5%)
Trace | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 4
Negative | 10 (100.0%) | 6 (100.0%) | 16 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 8
Negative | 23 (100.0%) | 11 (84.6%) | 34 (94.4%)
Trace | 0 | 2 (15.4%) | 2 (5.6%)
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 16
Negative | 20 (95.2%) | 7 (100.0%) | 27 (96.4%)
Trace | 1 (4.8%) | 0 | 1 (3.6%)
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 24
Negative | 16 (100.0%) | 6 (100.0%) | 22 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
LOCF
Negative | 25 (96.2%) | 13 (92.9%) | 38 (95.0%)
Trace | 1 (3.8%) | 1 (7.1%) | 2 (5.0%)
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.4.2.6A Summary of Clinical Laboratory Urinalysis Measurement by Visit and Age Strata Nitrite Safety Population Long-Term Effectiveness Phase

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline
Negative | 29 (100.0%) | 15 (100.0%) | 44 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 4
Negative | 10 (100.0%) | 6 (100.0%) | 16 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 8
Negative | 23 (100.0%) | 13 (100.0%) | 36 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 16
Negative | 21 (100.0%) | 7 (100.0%) | 28 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 24
Negative | 16 (100.0%) | 6 (100.0%) | 22 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
LOCF
Negative | 26 (100.0%) | 14 (100.0%) | 40 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.4.2.7A Summary of Clinical Laboratory Urinalysis Measurement by Visit and Age Strata Leukocyte Esterase Safety Population Long-Term Effectiveness Phase

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline
Negative | 26 (89.7%) | 12 (80.0%) | 38 (86.4%)
Trace | 1 (3.4%) | 2 (13.3%) | 3 (6.8%)
1+ | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 4
Negative | 9 (90.0%) | 6 (100.0%) | 15 (93.8%)
Trace | 1 (10.0%) | 0 | 1 (6.3%)
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 8
Negative | 19 (82.6%) | 11 (84.6%) | 30 (83.3%)
Trace | 2 (8.7%) | 1 (7.7%) | 3 (8.3%)
1+ | 1 (4.3%) | 1 (7.7%) | 2 (5.6%)
2+ | 0 | 0 | 0
3+ | 1 (4.3%) | 0 | 1 (2.8%)
4+ | 0 | 0 | 0
Week 16
Negative | 15 (71.4%) | 6 (85.7%) | 21 (75.0%)
Trace | 3 (14.3%) | 1 (14.3%) | 4 (14.3%)
1+ | 2 (9.5%) | 0 | 2 (7.1%)
2+ | 0 | 0 | 0
3+ | 1 (4.8%) | 0 | 1 (3.6%)
4+ | 0 | 0 | 0
Week 24
Negative | 13 (81.3%) | 6 (100.0%) | 19 (86.4%)
Trace | 1 (6.3%) | 0 | 1 (4.5%)
1+ | 1 (6.3%) | 0 | 1 (4.5%)
2+ | 1 (6.3%) | 0 | 1 (4.5%)
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
LOCF
Negative | 21 (80.8%) | 14 (100.0%) | 35 (87.5%)
Trace | 2 (7.7%) | 0 | 2 (5.0%)
1+ | 2 (7.7%) | 0 | 2 (5.0%)
2+ | 1 (3.8%) | 0 | 1 (2.5%)
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.4.2.8A Summary of Clinical Laboratory Urinalysis Measurement by Visit and Age Strata Blood Safety Population Long-Term Effectiveness Phase

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline
Negative | 29 (100.0%) | 12 (80.0%) | 41 (93.2%)
Trace | 0 | 1 (6.7%) | 1 (2.3%)
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 1 (6.7%) | 1 (2.3%)
4+ | 0 | 1 (6.7%) | 1 (2.3%)
Week 4
Negative | 10 (100.0%) | 5 (83.3%) | 15 (93.8%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 1 (16.7%) | 1 (6.3%)
4+ | 0 | 0 | 0
Week 8
Negative | 23 (100.0%) | 11 (84.6%) | 34 (94.4%)
Trace | 0 | 1 (7.7%) | 1 (2.8%)
1+ | 0 | 1 (7.7%) | 1 (2.8%)
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 16
Negative | 20 (95.2%) | 6 (85.7%) | 26 (92.9%)
Trace | 1 (4.8%) | 0 | 1 (3.6%)
1+ | 0 | 0 | 0
2+ | 0 | 1 (14.3%) | 1 (3.6%)
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 24
Negative | 16 (100.0%) | 6 (100.0%) | 22 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
LOCF
Negative | 25 (96.2%) | 13 (92.9%) | 38 (95.0%)
Trace | 1 (3.8%) | 0 | 1 (2.5%)
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 1 (7.1%) | 1 (2.5%)
4+ | 0 | 0 | 0

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.4.2.1B Summary of Clinical Laboratory Urinalysis Measurement by Visit and Efficacy Phase Treatment Received Group pH Safety Population Long-Term Effectiveness Phase

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 6.74 (0.77) | 6.20 (1.00) | 6.56 (0.88)
Median (Min-Max) | 7.00 (5.00, 8.00) | 6.00 (5.00, 8.00) | 7.00 (5.00, 8.00)
Week 4
N | 4 | 12 | 16
Mean (SD) | 6.88 (0.25) | 6.63 (0.80) | 6.69 (0.70)
Median (Min-Max) | 7.00 (6.50, 7.00) | 6.75 (5.50, 8.00) | 7.00 (5.50, 8.00)
Week 8
N | 25 | 11 | 36
Mean (SD) | 6.72 (0.74) | 6.68 (0.46) | 6.71 (0.66)
Median (Min-Max) | 7.00 (5.00, 8.00) | 7.00 (5.50, 7.00) | 7.00 (5.00, 8.00)
Week 16
N | 19 | 9 | 28
Mean (SD) | 6.79 (0.67) | 7.00 (0.50) | 6.86 (0.62)
Median (Min-Max) | 7.00 (5.50, 8.00) | 7.00 (6.50, 8.00) | 7.00 (5.50, 8.00)
Week 24
N | 14 | 8 | 22
Mean (SD) | 6.86 (0.50) | 6.81 (0.46) | 6.84 (0.47)
Median (Min-Max) | 7.00 (6.00, 7.50) | 7.00 (6.00, 7.50) | 7.00 (6.00, 7.50)
LOCF
N | 27 | 13 | 40
Mean (SD) | 6.70 (0.75) | 7.00 (0.84) | 6.80 (0.78)
Median (Min-Max) | 7.00 (5.00, 8.00) | 7.00 (5.50, 8.50) | 7.00 (5.00, 8.50)
Change from Baseline to LOCF
N | 27 | 13 | 40
Mean (SD) | −0.07 (0.84) | 0.77 (0.78) | 0.20 (0.90)
Median (Min-Max) | 0.00 (−2.00, 1.50) | 0.50 (−0.50, 2.50) | 0.00 (−2.00, 2.50)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.4.2.2B Summary of Clinical Laboratory Urinalysis Measurement by Visit and Efficacy Phase Treatment Received Group Specific Gravity Safety Population Long-Term Effectiveness Phase

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 1.012 (0.006) | 1.019 (0.005) | 1.014 (0.007)
Median (Min-Max) | 1.011 (1.001, 1.023) | 1.020 (1.010, 1.025) | 1.015 (1.001, 1.025)
Week 4
N | 4 | 12 | 16
Mean (SD) | 1.007 (0.004) | 1.012 (0.005) | 1.011 (0.005)
Median (Min-Max) | 1.008 (1.002, 1.011) | 1.012 (1.006, 1.021) | 1.011 (1.002, 1.021)
Week 8
N | 25 | 11 | 36
Mean (SD) | 1.011 (0.008) | 1.010 (0.006) | 1.011 (0.007)
Median (Min-Max) | 1.010 (1.002, 1.025) | 1.009 (1.003, 1.021) | 1.010 (1.002, 1.025)
Week 16
N | 19 | 9 | 28
Mean (SD) | 1.009 (0.008) | 1.011 (0.005) | 1.010 (0.007)
Median (Min-Max) | 1.007 (1.002, 1.033) | 1.010 (1.006, 1.022) | 1.008 (1.002, 1.033)
Week 24
N | 14 | 8 | 22
Mean (SD) | 1.012 (0.006) | 1.014 (0.006) | 1.013 (0.006)
Median (Min-Max) | 1.012 (1.004, 1.025) | 1.013 (1.004, 1.020) | 1.013 (1.004, 1.025)
LOCF
N | 27 | 13 | 40
Mean (SD) | 1.012 (0.006) | 1.016 (0.006) | 1.013 (0.006)
Median (Min-Max) | 1.011 (1.003, 1.025) | 1.016 (1.004, 1.023) | 1.013 (1.003, 1.025)
Change from Baseline to LOCF
N | 27 | 13 | 40
Mean (SD) | 0.001 (0.007) | −.003 (0.006) | −.000 (0.007)
Median (Min-Max) | 0.001 (−.014, 0.015) | −.001 (−.012, 0.008) | 0.000 (−.014, 0.015)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.4.2.3B Summary of Clinical Laboratory Urinalysis Measurement by Visit and Efficacy Phase Treatment Received Group Protein Safety Population Long-Term Effectiveness Phase

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
Negative | 25 (86.2%) | 12 (80.0%) | 37 (84.1%)
Trace | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
1+ | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
2+ | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 4
Negative | 4 (100.0%) | 11 (91.7%) | 15 (93.8%)
Trace | 0 | 0 | 0
1+ | 0 | 1 (8.3%) | 1 (6.3%)
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 8
Negative | 21 (84.0%) | 9 (81.8%) | 30 (83.3%)
Trace | 3 (12.0%) | 1 (9.1%) | 4 (11.1%)
1+ | 1 (4.0%) | 0 | 1 (2.8%)
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 1 (9.1%) | 1 (2.8%)
Week 16
Negative | 17 (89.5%) | 7 (77.8%) | 24 (85.7%)
Trace | 0 | 1 (11.1%) | 1 (3.6%)
1+ | 2 (10.5%) | 0 | 2 (7.1%)
2+ | 0 | 0 | 0
3+ | 0 | 1 (11.1%) | 1 (3.6%)
4+ | 0 | 0 | 0
Week 24
Negative | 12 (85.7%) | 6 (75.0%) | 18 (81.8%)
Trace | 0 | 1 (12.5%) | 1 (4.5%)
1+ | 1 (7.1%) | 0 | 1 (4.5%)
2+ | 1 (7.1%) | 0 | 1 (4.5%)
3+ | 0 | 1 (12.5%) | 1 (4.5%)
4+ | 0 | 0 | 0
LOCF
Negative | 20 (74.1%) | 9 (69.2%) | 29 (72.5%)
Trace | 2 (7.4%) | 3 (23.1%) | 5 (12.5%)
1+ | 4 (14.8%) | 0 | 4 (10.0%)
2+ | 1 (3.7%) | 0 | 1 (2.5%)
3+ | 0 | 1 (7.7%) | 1 (2.5%)
4+ | 0 | 0 | 0

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.4.2.4B Summary of Clinical Laboratory Urinalysis Measurement by Visit and Efficacy Phase Treatment Received Group Glucose Safety Population Long-Term Effectiveness Phase

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
Negative | 29 (100.0%) | 15 (100.0%) | 44 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 4
Negative | 4 (100.0%) | 12 (100.0%) | 16 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 8
Negative | 25 (100.0%) | 11 (100.0%) | 36 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 16
Negative | 19 (100.0%) | 9 (100.0%) | 28 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 24
Negative | 14 (100.0%) | 8 (100.0%) | 22 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
LOCF
Negative | 27 (100.0%) | 13 (100.0%) | 40 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.4.2.5B Summary of Clinical Laboratory Urinalysis Measurement by Visit and Efficacy Phase Treatment Received Group Ketones Safety Population Long-Term Effectiveness Phase

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
Negative | 28 (96.6%) | 14 (93.3%) | 42 (95.5%)
Trace | 1 (3.4%) | 1 (6.7%) | 2 (4.5%)
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 4
Negative | 4 (100.0%) | 12 (100.0%) | 16 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 8
Negative | 24 (96.0%) | 10 (90.9%) | 34 (94.4%)
Trace | 1 (4.0%) | 1 (9.1%) | 2 (5.6%)
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 16
Negative | 19 (100.0%) | 8 (88.9%) | 27 (96.4%)
Trace | 0 | 1 (11.1%) | 1 (3.6%)
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 24
Negative | 14 (100.0%) | 8 (100.0%) | 22 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
LOCF
Negative | 26 (96.3%) | 12 (92.3%) | 38 (95.0%)
Trace | 1 (3.7%) | 1 (7.7%) | 2 (5.0%)
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.4.2.6B Summary of Clinical Laboratory Urinalysis Measurement by Visit and Efficacy Phase Treatment Received Group Nitrite Safety Population Long-Term Effectiveness Phase

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
Negative | 29 (100.0%) | 15 (100.0%) | 44 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 4
Negative | 4 (100.0%) | 12 (100.0%) | 16 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 8
Negative | 25 (100.0%) | 11 (100.0%) | 36 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 16
Negative | 19 (100.0%) | 9 (100.0%) | 28 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 24
Negative | 14 (100.0%) | 8 (100.0%) | 22 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
LOCF
Negative | 27 (100.0%) | 13 (100.0%) | 40 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.4.2.7B Summary of Clinical Laboratory Urinalysis Measurement by Visit and Efficacy Phase Treatment Received Group Leukocyte Esterase Safety Population Long-Term Effectiveness Phase

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
Negative | 24 (82.8%) | 14 (93.3%) | 38 (86.4%)
Trace | 2 (6.9%) | 1 (6.7%) | 3 (6.8%)
1+ | 3 (10.3%) | 0 | 3 (6.8%)
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 4
Negative | 4 (100.0%) | 11 (91.7%) | 15 (93.8%)
Trace | 0 | 1 (8.3%) | 1 (6.3%)
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 8
Negative | 19 (76.0%) | 11 (100.0%) | 30 (83.3%)
Trace | 3 (12.0%) | 0 | 3 (8.3%)
1+ | 2 (8.0%) | 0 | 2 (5.6%)
2+ | 0 | 0 | 0
3+ | 1 (4.0%) | 0 | 1 (2.8%)
4+ | 0 | 0 | 0
Week 16
Negative | 13 (68.4%) | 8 (88.9%) | 21 (75.0%)
Trace | 4 (21.1%) | 0 | 4 (14.3%)
1+ | 1 (5.3%) | 1 (11.1%) | 2 (7.1%)
2+ | 0 | 0 | 0
3+ | 1 (5.3%) | 0 | 1 (3.6%)
4+ | 0 | 0 | 0
Week 24
Negative | 12 (85.7%) | 7 (87.5%) | 19 (86.4%)
Trace | 1 (7.1%) | 0 | 1 (4.5%)
1+ | 0 | 1 (12.5%) | 1 (4.5%)
2+ | 1 (7.1%) | 0 | 1 (4.5%)
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
LOCF
Negative | 23 (85.2%) | 12 (92.3%) | 35 (87.5%)
Trace | 2 (7.4%) | 0 | 2 (5.0%)
1+ | 1 (3.7%) | 1 (7.7%) | 2 (5.0%)
2+ | 1 (3.7%) | 0 | 1 (2.5%)
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.4.2.8B Summary of Clinical Laboratory Urinalysis Measurement by Visit and Efficacy Phase Treatment Received Group Blood Safety Population Long-Term Effectiveness Phase

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
Negative | 27 (93.1%) | 14 (93.3%) | 41 (93.2%)
Trace | 1 (3.4%) | 0 | 1 (2.3%)
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 1 (3.4%) | 0 | 1 (2.3%)
4+ | 0 | 1 (6.7%) | 1 (2.3%)
Week 4
Negative | 3 (75.0%) | 12 (100.0%) | 15 (93.8%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 1 (25.0%) | 0 | 1 (6.3%)
4+ | 0 | 0 | 0
Week 8
Negative | 24 (96.0%) | 10 (90.9%) | 34 (94.4%)
Trace | 1 (4.0%) | 0 | 1 (2.8%)
1+ | 0 | 1 (9.1%) | 1 (2.8%)
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 16
Negative | 17 (89.5%) | 9 (100.0%) | 26 (92.9%)
Trace | 1 (5.3%) | 0 | 1 (3.6%)
1+ | 0 | 0 | 0
2+ | 1 (5.3%) | 0 | 1 (3.6%)
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 24
Negative | 14 (100.0%) | 8 (100.0%) | 22 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
LOCF
Negative | 25 (92.6%) | 13 (100.0%) | 38 (95.0%)
Trace | 1 (3.7%) | 0 | 1 (2.5%)
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 1 (3.7%) | 0 | 1 (2.5%)
4+ | 0 | 0 | 0

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.4.3.1 Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received Group pH Safety Population Discontinuation Phase

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 6.76 (0.85) | 6.93 (0.43) | 6.84 (0.69)
Median (Min-Max) | 7.00 (5.00, 8.00) | 7.00 (6.00, 7.50) | 7.00 (5.00, 8.00)
Week 8
N | 13 | 3 | 16
Mean (SD) | 7.12 (0.46) | 5.67 (0.29) | 6.84 (0.72)
Median (Min-Max) | 7.00 (6.50, 8.00) | 5.50 (5.50, 6.00) | 7.00 (5.50, 8.00)
Week 16
N | 12 | 2 | 14
Mean (SD) | 6.96 (0.66) | 6.00 (0.00) | 6.82 (0.70)
Median (Min-Max) | 7.00 (5.50, 8.00) | 6.00 (6.00, 6.00) | 7.00 (5.50, 8.00)
Week 20
N | 8 | 0 | 8
Mean (SD) | 6.63 (0.69) | 0 | 6.63 (0.69)
Median (Min-Max) | 7.00 (5.00, 7.00) | 0 | 7.00 (5.00, 7.00)
Week 28
N | 11 | 2 | 13
Mean (SD) | 6.45 (0.65) | 5.50 (0.00) | 6.31 (0.69)
Median (Min-Max) | 6.50 (5.00, 7.00) | 5.50 (5.50, 5.50) | 6.50 (5.00, 7.00)
LOCF
N | 16 | 11 | 27
Mean (SD) | 6.53 (0.78) | 6.32 (0.84) | 6.44 (0.80)
Median (Min-Max) | 6.50 (5.00, 8.00) | 6.50 (5.00, 7.50) | 6.50 (5.00, 8.00)
Change from Baseline to LOCF
N | 16 | 11 | 27
Mean (SD) | −0.25 (0.95) | −0.59 (0.92) | −0.39 (0.93)
Median (Min-Max) | 0.00 (−2.00, 2.00) | 0.00 (−2.50, 0.50) | 0.00 (−2.50, 2.00)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Leukocyte Esterase and Blood Samples have not been collected for Colt 1 Study.

Table 14.3.3.4.3.2 Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received Group Specific Gravity Safety Population Discontinuation Phase

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 13 | 30
Mean (SD) | 1.014 (0.005) | 1.012 (0.005) | 1.013 (0.005)
Median (Min-Max) | 1.014 (1.005, 1.025) | 1.013 (1.004, 1.020) | 1.014 (1.004, 1.025)
Week 8
N | 13 | 3 | 16
Mean (SD) | 1.014 (0.007) | 1.016 (0.007) | 1.015 (0.006)
Median (Min-Max) | 1.015 (1.003, 1.028) | 1.014 (1.010, 1.023) | 1.015 (1.003, 1.028)
Week 16
N | 12 | 2 | 14
Mean (SD) | 1.015 (0.006) | 1.012 (0.005) | 1.014 (0.006)
Median (Min-Max) | 1.018 (1.004, 1.025) | 1.012 (1.008, 1.015) | 1.016 (1.004, 1.025)
Week 20
N | 8 | 0 | 8
Mean (SD) | 1.015 (0.007) | 0 | 1.015 (0.007)
Median (Min-Max) | 1.015 (1.005, 1.028) | 0 | 1.015 (1.005, 1.028)
Week 28
N | 11 | 2 | 13
Mean (SD) | 1.014 (0.009) | 1.009 (0.006) | 1.014 (0.008)
Median (Min-Max) | 1.015 (1.003, 1.026) | 1.009 (1.005, 1.013) | 1.013 (1.003, 1.026)
LOCF
N | 16 | 11 | 27
Mean (SD) | 1.016 (0.008) | 1.014 (0.008) | 1.015 (0.008)
Median (Min-Max) | 1.015 (1.003, 1.026) | 1.013 (1.005, 1.027) | 1.015 (1.003, 1.027)
Change from Baseline to LOCF
N | 16 | 10 | 26
Mean (SD) | 0.001 (0.007) | 0.003 (0.008) | 0.002 (0.007)
Median (Min-Max) | 0.000 (−.010, 0.013) | 0.003 (−.008, 0.020) | 0.000 (−.010, 0.020)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Leukocyte Esterase and Blood Samples have not been collected for Colt 1 Study.

Table 14.3.3.4.3.3 Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received Group Protein Safety Population Discontinuation Phase

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
Negative | 12 (70.6%) | 11 (78.6%) | 23 (74.2%)
Trace | 2 (11.8%) | 1 (7.1%) | 3 (9.7%)
1+ | 1 (5.9%) | 1 (7.1%) | 2 (6.5%)
2+ | 1 (5.9%) | 1 (7.1%) | 2 (6.5%)
3+ | 0 | 0 | 0
4+ | 1 (5.9%) | 0 | 1 (3.2%)
Week 8
Negative | 11 (84.6%) | 3 (100.0%) | 14 (87.5%)
Trace | 2 (15.4%) | 0 | 2 (12.5%)
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 16
Negative | 11 (91.7%) | 2 (100.0%) | 13 (92.9%)
Trace | 1 (8.3%) | 0 | 1 (7.1%)
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 20
3+ | 0 | 0 | 0
Negative | 7 (87.5%) | 0 | 7 (87.5%)
Trace | 1 (12.5%) | 0 | 1 (12.5%)
1+ | 0 | 0 | 0
4+ | 0 | 0 | 0
2+ | 0 | 0 | 0
Week 28
Negative | 9 (81.8%) | 2 (100.0%) | 11 (84.6%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 1 (9.1%) | 0 | 1 (7.7%)
3+ | 0 | 0 | 0
4+ | 1 (9.1%) | 0 | 1 (7.7%)
LOCF
Negative | 14 (87.5%) | 11 (100.0%) | 25 (92.6%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 1 (6.3%) | 0 | 1 (3.7%)
3+ | 0 | 0 | 0
4+ | 1 (6.3%) | 0 | 1 (3.7%)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Leukocyte Esterase and Blood Samples have not been collected for Colt 1 Study.

Table 14.3.3.4.3.4 Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received Group Glucose Safety Population Discontinuation Phase

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
Negative | 17 (100.0%) | 13 (92.9%) | 30 (96.8%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 1 (7.1%) | 1 (3.2%)
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 8
Negative | 13 (100.0%) | 3 (100.0%) | 16 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 16
Negative | 12 (100.0%) | 2 (100.0%) | 14 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 20
Negative | 8 (100.0%) | 0 | 8 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 28
Negative | 11 (100.0%) | 2 (100.0%) | 13 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
LOCF
Negative | 16 (100.0%) | 11 (100.0%) | 27 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Leukocyte Esterase and Blood Samples have not been collected for Colt 1 Study.

Table 14.3.3.4.3.5 Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received Group Ketones Safety Population Discontinuation Phase

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
Negative | 16 (94.1%) | 14 (100.0%) | 30 (96.8%)
Trace | 1 (5.9%) | 0 | 1 (3.2%)
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 8
Negative | 13 (100.0%) | 3 (100.0%) | 16 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 16
Negative | 12 (100.0%) | 2 (100.0%) | 14 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 20
Negative | 8 (100.0%) | 0 | 8 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 28
Negative | 9 (81.8%) | 2 (100.0%) | 11 (84.6%)
Trace | 1 (9.1%) | 0 | 1 (7.7%)
4+ | 1 (9.1%) | 0 | 1 (7.7%)
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
LOCF
Negative | 14 (87.5%) | 9 (81.8%) | 23 (85.2%)
Trace | 1 (6.3%) | 1 (9.1%) | 2 (7.4%)
1+ | 0 | 1 (9.1%) | 1 (3.7%)
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 1 (6.3%) | 0 | 1 (3.7%)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Leukocyte Esterase and Blood Samples have not been collected for Colt 1 Study.

Table 14.3.3.4.3.6 Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received Group Nitrite Safety Population Discontinuation Phase

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
Negative | 17 (100.0%) | 14 (100.0%) | 31 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 8
Negative | 13 (100.0%) | 3 (100.0%) | 16 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 16
Negative | 12 (100.0%) | 2 (100.0%) | 14 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 20
Negative | 8 (100.0%) | 0 | 8 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 28
Negative | 11 (100.0%) | 2 (100.0%) | 13 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
LOCF
Negative | 16 (100.0%) | 11 (100.0%) | 27 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Leukocyte Esterase and Blood Samples have not been collected for Colt 1 Study.

Table 14.3.3.4.3.7 Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received Group Leukocyte Esterase Safety Population Discontinuation Phase

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
Negative | 5 (29.4%) | 4 (28.6%) | 9 (29.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 1 (7.1%) | 1 (3.2%)
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 8
Negative | 2 (15.4%) | 2 (66.7%) | 4 (25.0%)
Trace | 2 (15.4%) | 0 | 2 (12.5%)
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 16
Negative | 2 (16.7%) | 2 (100.0%) | 4 (28.6%)
Trace | 2 (16.7%) | 0 | 2 (14.3%)
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 28
Negative | 4 (36.4%) | 2 (100.0%) | 6 (46.2%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
LOCF
Negative | 5 (31.3%) | 4 (36.4%) | 9 (33.3%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Leukocyte Esterase and Blood Samples have not been collected for Colt 1 Study.

Table 14.3.3.4.3.8 Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received Group Blood Safety Population Discontinuation Phase

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
Negative | 5 (29.4%) | 5 (35.7%) | 10 (32.3%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 8
Negative | 4 (30.8%) | 2 (66.7%) | 6 (37.5%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 16
Negative | 4 (33.3%) | 2 (100.0%) | 6 (42.9%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 28
Negative | 4 (36.4%) | 2 (100.0%) | 6 (46.2%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
LOCF
Negative | 5 (31.3%) | 4 (36.4%) | 9 (33.3%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Leukocyte Esterase and Blood Samples have not been collected for Colt 1 Study.

Table 14.3.3.4.4.1 Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received Group pH Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 9 | 12
Mean (SD) | 7.33 (0.58) | 6.50 (0.83) | 6.71 (0.84)
Median (Min-Max) | 7.00 (7.00, 8.00) | 7.00 (5.00, 7.50) | 7.00 (5.00, 8.00)
Week 4
N | 2 | 7 | 9
Mean (SD) | 7.00 (0.00) | 6.86 (0.24) | 6.89 (0.22)
Median (Min-Max) | 7.00 (7.00, 7.00) | 7.00 (6.50, 7.00) | 7.00 (6.50, 7.00)
Week 8
N | 2 | 7 | 9
Mean (SD) | 7.00 (0.00) | 7.14 (0.69) | 7.11 (0.60)
Median (Min-Max) | 7.00 (7.00, 7.00) | 7.00 (6.00, 8.00) | 7.00 (6.00, 8.00)
LOCF
N | 2 | 9 | 11
Mean (SD) | 7.00 (0.00) | 7.11 (0.65) | 7.09 (0.58)
Median (Min-Max) | 7.00 (7.00, 7.00) | 7.00 (6.00, 8.00) | 7.00 (6.00, 8.00)
Change from Baseline to LOCF
N | 2 | 9 | 11
Mean (SD) | 0.00 (0.00) | 0.61 (0.78) | 0.50 (0.74)
Median (Min-Max) | 0.00 (0.00, 0.00) | 1.00 (−1.00, 1.50) | 1.00 (−1.00, 1.50)

Note: Baseline is defined as last visit of Discontinuation Phase.

Leukocyte Esterase and Blood Samples have not been collected for Colt 1 Study.

Table 14.3.3.4.4.2 Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received Group Specific Gravity Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 9 | 12
Mean (SD) | 1.0180 (0.0070) | 1.0154 (0.0078) | 1.0161 (0.0074)
Median (Min-Max) | 1.0150 (1.0130, 1.0260) | 1.0140 (1.0070, 1.0270) | 1.0145 (1.0070, 1.0270)
Week 4
N | 2 | 7 | 9
Mean (SD) | 1.0095 (0.0021) | 1.0121 (0.0068) | 1.0116 (0.0061)
Median (Min-Max) | 1.0095 (1.0080, 1.0110) | 1.0100 (1.0070, 1.0270) | 1.0100 (1.0070, 1.0270)
Week 8
N | 2 | 7 | 9
Mean (SD) | 1.0175 (0.0078) | 1.0146 (0.0046) | 1.0152 (0.0050)
Median (Min-Max) | 1.0175 (1.0120, 1.0230) | 1.0160 (1.0060, 1.0190) | 1.0160 (1.0060, 1.0230)
LOCF
N | 2 | 8 | 10
Mean (SD) | 1.0175 (0.0078) | 1.0136 (0.0051) | 1.0144 (0.0054)
Median (Min-Max) | 1.0175 (1.0120, 1.0230) | 1.0145 (1.0060, 1.0190) | 1.0145 (1.0060, 1.0230)
Change from Baseline to LOCF
N | 2 | 8 | 10
Mean (SD) | −0.0020 (0.0014) | −0.0019 (0.0042) | −0.0019 (0.0038)
Median (Min-Max) | −0.0020 (−0.0030, −0.0010) | −0.0005 (−0.0080, 0.0030) | −0.0010 (−0.0080, 0.0030)

Note: Baseline is defined as last visit of Discontinuation Phase.

Leukocyte Esterase and Blood Samples have not been collected for Colt 1 Study.

Table 14.3.3.4.4.3 Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received Group Protein Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
Negative | 3 (100.0%) | 9 (90.0%) | 12 (92.3%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 4
Negative | 1 (50.0%) | 6 (85.7%) | 7 (77.8%)
Trace | 0 | 0 | 0
1+ | 1 (50.0%) | 1 (14.3%) | 2 (22.2%)
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 8
Negative | 2 (100.0%) | 7 (100.0%) | 9 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
LOCF
Negative | 2 (100.0%) | 9 (100.0%) | 11 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0

Note: Baseline is defined as last visit of Discontinuation Phase.

Leukocyte Esterase and Blood Samples have not been collected for Colt 1 Study.

Table 14.3.3.4.4.4 Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received Group Glucose Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
Negative | 3 (100.0%) | 9 (90.0%) | 12 (92.3%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 4
Negative | 2 (100.0%) | 7 (100.0%) | 9 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 8
Negative | 2 (100.0%) | 7 (100.0%) | 9 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
LOCF
Negative | 2 (100.0%) | 9 (100.0%) | 11 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0

Note: Baseline is defined as last visit of Discontinuation Phase.

Leukocyte Esterase and Blood Samples have not been collected for Colt 1 Study.

Table 14.3.3.4.4.5 Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received Group Ketones Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
Negative | 3 (100.0%) | 7 (70.0%) | 10 (76.9%)
Trace | 0 | 1 (10.0%) | 1 (7.7%)
1+ | 0 | 1 (10.0%) | 1 (7.7%)
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 4
Negative | 2 (100.0%) | 7 (100.0%) | 9 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 8
Negative | 2 (100.0%) | 7 (100.0%) | 9 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
LOCF
Negative | 2 (100.0%) | 9 (100.0%) | 11 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0

Note: Baseline is defined as last visit of Discontinuation Phase.

Leukocyte Esterase and Blood Samples have not been collected for Colt 1 Study.

Table 14.3.3.4.4.6 Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received Group Nitrite Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
Negative | 3 (100.0%) | 9 (90.0%) | 12 (92.3%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 4
Negative | 2 (100.0%) | 7 (100.0%) | 9 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 8
Negative | 2 (100.0%) | 7 (100.0%) | 9 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
LOCF
Negative | 2 (100.0%) | 9 (100.0%) | 11 (100.0%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0

Note: Baseline is defined as last visit of Discontinuation Phase.

Leukocyte Esterase and Blood Samples have not been collected for Colt 1 Study.

Table 14.3.3.4.4.7 Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received Group Leukocyte Esterase Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
Negative | 0 | 2 (20.0%) | 2 (15.4%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 4
Negative | 0 | 1 (14.3%) | 1 (11.1%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 8
Negative | 0 | 2 (28.6%) | 2 (22.2%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
LOCF
Negative | 0 | 2 (22.2%) | 2 (18.2%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0

Note: Baseline is defined as last visit of Discontinuation Phase.

Leukocyte Esterase and Blood Samples have not been collected for Colt 1 Study.

Table 14.3.3.4.4.8 Summary of Clinical Laboratory Urinalysis Measurement by Visit and Discontinuation Phase Treatment Received Group Blood Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
Negative | 0 | 2 (20.0%) | 2 (15.4%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 4
Negative | 0 | 1 (14.3%) | 1 (11.1%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
Week 8
Negative | 0 | 2 (28.6%) | 2 (22.2%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0
LOCF
Negative | 0 | 2 (22.2%) | 2 (18.2%)
Trace | 0 | 0 | 0
1+ | 0 | 0 | 0
2+ | 0 | 0 | 0
3+ | 0 | 0 | 0
4+ | 0 | 0 | 0

Note: Baseline is defined as last visit of Discontinuation Phase.

Leukocyte Esterase and Blood Samples have not been collected for Colt 1 Study.

Table 14.3.3.5.1.1 Summary of Clinical Laboratory Coagulation Measurements by Visit, Age Strata and Efficacy Phase Treatment Received Group Fibrinogen (mg/dL) Efficacy Phase - Safety Population

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 31 | 16 | 19 | 11 | 50 | 27
Mean (SD) | 290.5 (94.0) | 295.9 (94.5) | 305.5 (105.2) | 322.6 (45.9) | 296.2 (97.7) | 306.8 (78.3)
Median (Min-Max) | 277.0 (158.0 – 641.0) | 276.0 (144.0 – 582.0) | 307.0 (164.0 – 509.0) | 314.0 (263.0 – 424.0) | 281.5 (158.0 – 641.0) | 308.0 (144.0 – 582.0)
LOCF
N | 27 | 12 | 16 | 9 | 43 | 21
Mean (SD) | 281.7 (62.0) | 264.8 (63.9) | 336.7 (117.5) | 319.9 (36.2) | 302.1 (89.6) | 288.4 (59.6)
Median (Min-Max) | 283.0 (187.0 – 434.0) | 259.0 (134.0 – 389.0) | 364.5 (171.0 – 595.0) | 313.0 (270.0 – 384.0) | 286.0 (171.0 – 595.0) | 291.0 (134.0 – 389.0)
Change from Baseline to LOCF
N | 27 | 11 | 16 | 9 | 43 | 20
Mean (SD) | −17.2 (83.6) | −32.5 (66.6) | 20.0 (146.5) | −7.9 (42.8) | −3.4 (111.0) | −21.4 (57.2)
Median (Min-Max) | −15.0 (−356 – 106.0) | −10.0 (−193 – 39.0) | −9.0 (−328 – 361.0) | 0.0 (−111 – 32.0) | −13.0 (−356 – 361.0) | −5.5 (−193 – 39.0)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.5.1.2 Summary of Clinical Laboratory Coagulation Measurements by Visit, Age Strata and Efficacy Phase Treatment Received Group Prothrombin Time - PT (Seconds) Efficacy Phase - Safety Population

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 20 | 11 | 52 | 28
Mean (SD) | 12.5 (1.6) | 12.2 (1.6) | 12.4 (1.4) | 12.5 (1.4) | 12.4 (1.5) | 12.4 (1.5)
Median (Min-Max) | 12.7 (10.1 – 15.0) | 11.3 (10.5 – 16.1) | 12.3 (10.4 – 14.6) | 12.4 (10.6 – 14.5) | 12.6 (10.1 – 15.0) | 11.8 (10.5 – 16.1)
LOCF
N | 27 | 12 | 18 | 9 | 45 | 21
Mean (SD) | 12.3 (1.5) | 12.1 (1.3) | 12.2 (1.5) | 13.0 (1.2) | 12.3 (1.5) | 12.5 (1.3)
Median (Min-Max) | 12.0 (9.2 – 14.8) | 12.0 (10.3 – 14.0) | 12.3 (10.1 – 14.4) | 12.5 (10.9 – 14.7) | 12.2 (9.2 – 14.8) | 12.5 (10.3 – 14.7)
Change from Baseline to LOCF
N | 27 | 12 | 17 | 9 | 44 | 21
Mean (SD) | −0.2 (0.9) | −0.4 (1.1) | −0.1 (0.5) | 0.2 (0.6) | −0.2 (0.8) | −0.1 (1.0)
Median (Min-Max) | −0.1 (−3.2 – 1.0) | −0.3 (−3.7 – 0.6) | −0.1 (−1.3 – 0.5) | 0.0 (−0.6 – 1.4) | −0.1 (−3.2 – 1.0) | −0.1 (−3.7 – 1.4)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.5.1.3 Summary of Clinical Laboratory Coagulation Measurements by Visit, Age Strata and Efficacy Phase Treatment Received Group Partial Thromboplastin Time - PTT (Seconds) Efficacy Phase - Safety Population

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 20 | 11 | 52 | 28
Mean (SD) | 31.1 (2.8) | 31.9 (3.1) | 31.7 (3.8) | 32.3 (3.2) | 31.3 (3.2) | 32.0 (3.1)
Median (Min-Max) | 31.0 (24.7 – 36.5) | 32.1 (26.4 – 37.6) | 31.1 (23.8 – 39.4) | 34.0 (25.9 – 36.1) | 31.0 (23.8 – 39.4) | 32.7 (25.9 – 37.6)
LOCF
N | 27 | 12 | 17 | 9 | 44 | 21
Mean (SD) | 30.7 (3.3) | 31.1 (4.9) | 31.1 (3.0) | 32.9 (2.2) | 30.9 (3.2) | 31.9 (4.0)
Median (Min-Max) | 30.8 (25.6 – 38.0) | 31.5 (20.0 – 37.0) | 31.6 (23.0 – 36.0) | 33.0 (29.0 – 36.5) | 30.9 (23.0 – 38.0) | 32.0 (20.0 – 37.0)
Change from Baseline to LOCF
N | 27 | 12 | 16 | 9 | 43 | 21
Mean (SD) | −0.4 (1.8) | −1.4 (3.4) | −0.8 (3.1) | −0.5 (1.0) | −0.6 (2.3) | −1.0 (2.6)
Median (Min-Max) | −1.0 (−3.9 – 3.0) | −0.9 (−11.3 – 2.0) | −0.7 (−11.0 – 2.0) | −0.3 (−2.0 – 1.0) | −0.8 (−11.0 – 3.0) | −0.8 (−11.3 – 2.0)

Note: Baseline laboratory values were drawn during the Screening Phase.

Table 14.3.3.5.2.1A Summary of Clinical Laboratory Coagulation Measurements by Visit and Age Strata Fibrinogen (mg/dL) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 28 | 15 | 43
Mean (SD) | 278.9 (69.3) | 343.2 (106.0) | 301.3 (88.3)
Median (Min-Max) | 280.0 (134.0 – 434.0) | 345.0 (181.0 – 595.0) | 294.0 (134.0 – 595.0)
LOCF
N | 26 | 12 | 38
Mean (SD) | 297.0 (88.2) | 307.8 (92.6) | 300.4 (88.5)
Median (Min-Max) | 293.5 (111.0 – 510.0) | 288.0 (168.0 – 558.0) | 293.0 (111.0 – 558.0)
Change from Baseline to LOCF
N | 25 | 12 | 37
Mean (SD) | 11.6 (59.8) | −40.3 (100.9) | −5.2 (78.1)
Median (Min-Max) | 17.0 (−106 – 111.0) | −31.5 (−312 – 88.0) | −6.0 (−312 – 111.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.5.2.2A Summary of Clinical Laboratory Coagulation Measurements by Visit and Age Strata Prothrombin Time - PT (Seconds) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 28 | 15 | 43
Mean (SD) | 12.1 (1.3) | 12.8 (1.5) | 12.4 (1.4)
Median (Min-Max) | 11.8 (9.2 – 14.2) | 13.2 (10.1 – 14.7) | 12.5 (9.2 – 14.7)
LOCF
N | 26 | 12 | 38
Mean (SD) | 12.1 (1.2) | 13.1 (1.2) | 12.4 (1.3)
Median (Min-Max) | 11.8 (10.0 – 14.3) | 13.3 (10.7 – 14.7) | 12.6 (10.0 – 14.7)
Change from Baseline to LOCF
N | 25 | 12 | 37
Mean (SD) | −0.1 (0.5) | 0.1 (0.6) | −0.1 (0.6)
Median (Min-Max) | 0.0 (−2.0 – 0.8) | 0.1 (−1.1 – 1.6) | 0.0 (−2.0 – 1.6)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.5.2.3A Summary of Clinical Laboratory Coagulation Measurements by Visit and Age Strata Partial Thromboplastin Time - PTT (Seconds) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 28 | 15 | 43
Mean (SD) | 30.8 (3.9) | 31.9 (2.4) | 31.2 (3.5)
Median (Min-Max) | 31.0 (20.0 – 37.0) | 32.0 (28.0 – 36.0) | 31.3 (20.0 – 37.0)
LOCF
N | 26 | 12 | 38
Mean (SD) | 31.0 (4.2) | 31.1 (3.3) | 31.0 (3.9)
Median (Min-Max) | 30.5 (23.1 – 41.9) | 30.0 (26.6 – 36.8) | 30.0 (23.1 – 41.9)
Change from Baseline to LOCF
N | 25 | 12 | 37
Mean (SD) | 0.3 (3.4) | −0.9 (1.8) | 0.0 (3.0)
Median (Min-Max) | −0.3 (−8.9 – 8.9) | −1.3 (−3.0 – 2.0) | −0.3 (−8.9 – 8.9)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.5.2.1B Summary of Clinical Laboratory Coagulation Measurements by Visit and Efficacy Phase Treatment Received Group Fibrinogen (mg/dL) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 28 | 15 | 43
Mean (SD) | 310.5 (100.0) | 284.3 (60.2) | 301.3 (88.3)
Median (Min-Max) | 298.5 (181.0 – 595.0) | 283.0 (134.0 – 389.0) | 294.0 (134.0 – 595.0)
LOCF
N | 26 | 12 | 38
Mean (SD) | 293.9 (90.5) | 314.5 (86.2) | 300.4 (88.5)
Median (Min-Max) | 283.0 (111.0 – 558.0) | 303.5 (163.0 – 500.0) | 293.0 (111.0 – 558.0)
Change from Baseline to LOCF
N | 25 | 12 | 37
Mean (SD) | −21.0 (81.1) | 27.8 (62.2) | −5.2 (78.1)
Median (Min-Max) | −20.0 (−312 – 88.0) | 29.0 (−87.0 – 111.0) | −6.0 (−312 – 111.0)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.5.2.2B Summary of Clinical Laboratory Coagulation Measurements by Visit and Efficacy Phase Treatment Received Group Prothrombin Time - PT (Seconds) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 28 | 15 | 43
Mean (SD) | 12.2 (1.5) | 12.7 (1.2) | 12.4 (1.4)
Median (Min-Max) | 12.2 (9.2 – 14.2) | 12.9 (10.6 – 14.7) | 12.5 (9.2 – 14.7)
LOCF
N | 26 | 12 | 38
Mean (SD) | 12.2 (1.3) | 12.8 (1.2) | 12.4 (1.3)
Median (Min-Max) | 12.3 (10.0 – 14.4) | 12.8 (11.0 – 14.7) | 12.6 (10.0 – 14.7)
Change from Baseline to LOCF
N | 25 | 12 | 37
Mean (SD) | −0.1 (0.6) | −0.1 (0.4) | −0.1 (0.6)
Median (Min-Max) | 0.0 (−2.0 – 1.6) | 0.0 (−0.8 – 0.4) | 0.0 (−2.0 – 1.6)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.5.2.3B Summary of Clinical Laboratory Coagulation Measurements by Visit and Efficacy Phase Treatment Received Group Partial Thromboplastin Time - PTT (Seconds) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 28 | 15 | 43
Mean (SD) | 30.7 (2.9) | 32.1 (4.3) | 31.2 (3.5)
Median (Min-Max) | 30.9 (25.6 – 37.0) | 33.7 (20.0 – 37.0) | 31.3 (20.0 – 37.0)
LOCF
N | 26 | 12 | 38
Mean (SD) | 30.3 (3.1) | 32.5 (5.0) | 31.0 (3.9)
Median (Min-Max) | 29.9 (25.8 – 36.8) | 34.1 (23.1 – 41.9) | 30.0 (23.1 – 41.9)
Change from Baseline to LOCF
N | 25 | 12 | 37
Mean (SD) | −0.2 (1.9) | 0.3 (4.7) | 0.0 (3.0)
Median (Min-Max) | 0.0 (−4.0 – 3.0) | −0.6 (−8.9 – 8.9) | −0.3 (−8.9 – 8.9)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.3.5.3.1 Summary of Clinical Laboratory Coagulation Measurements by Visit and Discontinuation Phase Treatment Received Group Fibrinogen (mg/dL) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 16 | 14 | 30
Mean (SD) | 243.3 (47.7) | 294.5 (74.8) | 267.2 (66.1)
Median (Min-Max) | 245.5 (111.0 – 307.0) | 311.0 (131.0 – 400.0) | 276.5 (111.0 – 400.0)
Week 8
N | 13 | 3 | 16
Mean (SD) | 260.1 (39.4) | 307.0 (30.4) | 268.9 (41.5)
Median (Min-Max) | 259.0 (191.0 – 316.0) | 322.0 (272.0 – 327.0) | 265.0 (191.0 – 327.0)
Week 16
N | 12 | 2 | 14
Mean (SD) | 252.8 (58.3) | 312.5 (79.9) | 261.3 (61.9)
Median (Min-Max) | 243.0 (131.0 – 332.0) | 312.5 (256.0 – 369.0) | 251.5 (131.0 – 369.0)
Week 20
N | 7 | 0 | 7
Mean (SD) | 278.9 (43.9) | 0 | 278.9 (43.9)
Median (Min-Max) | 275.0 (235.0 – 360.0) | 0 | 275.0 (235.0 – 360.0)
Week 28
N | 10 | 2 | 12
Mean (SD) | 305.8 (33.0) | 345.5 (74.2) | 312.4 (40.4)
Median (Min-Max) | 308.0 (255.0 – 354.0) | 345.5 (293.0 – 398.0) | 308.0 (255.0 – 398.0)
LOCF
N | 15 | 11 | 26
Mean (SD) | 285.7 (51.4) | 288.4 (61.4) | 286.8 (54.7)
Median (Min-Max) | 297.0 (153.0 – 354.0) | 275.0 (193.0 – 398.0) | 289.0 (153.0 – 398.0)
Change from Baseline to LOCF
N | 14 | 11 | 25
Mean (SD) | 32.1 (23.8) | −8.9 (59.8) | 14.0 (47.2)
Median (Min-Max) | 36.5 (−24.0 – 65.0) | −11.0 (−119 – 90.0) | 23.0 (−119 – 90.0)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.5.3.2 Summary of Clinical Laboratory Coagulation Measurements by Visit and Discontinuation Phase Treatment Received Group Prothrombin Time - PT (Seconds) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 16 | 14 | 30
Mean (SD) | 12.1 (2.0) | 12.3 (1.8) | 12.2 (1.9)
Median (Min-Max) | 11.3 (9.9 – 15.5) | 11.4 (10.0 – 14.7) | 11.4 (9.9 – 15.5)
Week 8
N | 13 | 3 | 16
Mean (SD) | 12.3 (2.0) | 12.6 (2.2) | 12.3 (1.9)
Median (Min-Max) | 11.9 (9.7 – 15.5) | 13.7 (10.0 – 14.0) | 12.0 (9.7 – 15.5)
Week 16
N | 12 | 2 | 14
Mean (SD) | 12.5 (1.8) | 12.2 (1.7) | 12.5 (1.7)
Median (Min-Max) | 12.1 (10.2 – 15.2) | 12.2 (11.0 – 13.4) | 12.1 (10.2 – 15.2)
Week 20
N | 7 | 0 | 7
Mean (SD) | 12.7 (2.0) | 0 | 12.7 (2.0)
Median (Min-Max) | 12.9 (10.0 – 15.0) | 0 | 12.9 (10.0 – 15.0)
Week 28
N | 11 | 2 | 13
Mean (SD) | 12.1 (1.6) | 12.3 (2.3) | 12.2 (1.6)
Median (Min-Max) | 11.9 (10.3 – 14.7) | 12.3 (10.7 – 13.9) | 11.9 (10.3 – 14.7)
LOCF
N | 16 | 12 | 28
Mean (SD) | 11.8 (1.6) | 12.2 (1.8) | 11.9 (1.7)
Median (Min-Max) | 11.2 (9.7 – 14.7) | 11.3 (10.0 – 14.6) | 11.3 (9.7 – 14.7)
Change from Baseline to LOCF
N | 15 | 12 | 27
Mean (SD) | −0.2 (0.6) | 0.1 (0.3) | −0.1 (0.5)
Median (Min-Max) | −0.1 (−1.1 – 0.7) | 0.1 (−0.5 – 0.9) | 0.0 (−1.1 – 0.9)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.5.3.3 Summary of Clinical Laboratory Coagulation Measurements by Visit and Discontinuation Phase Treatment Received Group Partial Thromboplastin Time - PTT (Seconds) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 16 | 14 | 30
Mean (SD) | 29.6 (2.6) | 30.2 (3.5) | 29.9 (3.0)
Median (Min-Max) | 29.9 (23.1 – 34.0) | 28.5 (26.7 – 36.0) | 29.4 (23.1 – 36.0)
Week 8
N | 13 | 3 | 16
Mean (SD) | 30.5 (2.1) | 32.9 (2.8) | 30.9 (2.3)
Median (Min-Max) | 30.0 (27.3 – 34.0) | 34.0 (29.7 – 35.0) | 30.4 (27.3 – 35.0)
Week 16
N | 12 | 2 | 14
Mean (SD) | 30.9 (1.2) | 34.0 (0.0) | 31.3 (1.6)
Median (Min-Max) | 30.9 (28.7 – 32.7) | 34.0 (34.0 – 34.0) | 31.1 (28.7 – 34.0)
Week 20
N | 7 | 0 | 7
Mean (SD) | 30.1 (1.8) | 0 | 30.1 (1.8)
Median (Min-Max) | 30.0 (27.5 – 33.5) | 0 | 30.0 (27.5 – 33.5)
Week 28
N | 11 | 2 | 13
Mean (SD) | 30.5 (1.6) | 35.5 (0.7) | 31.3 (2.4)
Median (Min-Max) | 31.0 (27.8 – 32.3) | 35.5 (35.0 – 36.0) | 31.0 (27.8 – 36.0)
LOCF
N | 16 | 12 | 28
Mean (SD) | 30.0 (1.6) | 30.3 (3.3) | 30.1 (2.4)
Median (Min-Max) | 29.8 (27.8 – 32.3) | 29.2 (26.2 – 36.0) | 29.3 (26.2 – 36.0)
Change from Baseline to LOCF
N | 15 | 12 | 27
Mean (SD) | 0.5 (2.0) | 0.5 (2.2) | 0.5 (2.1)
Median (Min-Max) | 1.0 (−5.0 – 4.7) | 0.2 (−2.0 – 6.0) | 0.6 (−5.0 – 6.0)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

COLT2 Week 20 Laboratory measurements were discontinued with Protocol Amendment 5.

Table 14.3.3.5.4.1 Summary of Clinical Laboratory Coagulation Measurements by Visit and Discontinuation Phase Treatment Received Group Fibrinogen (mg/dL) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 9 | 12
Mean (SD) | 263.7 (45.4) | 275.7 (55.0) | 272.7 (51.0)
Median (Min-Max) | 247.0 (229.0 – 315.0) | 256.0 (193.0 – 344.0) | 256.0 (193.0 – 344.0)
Week 4
N | 2 | 7 | 9
Mean (SD) | 250.5 (7.8) | 290.1 (54.2) | 281.3 (50.2)
Median (Min-Max) | 250.5 (245.0 – 256.0) | 270.0 (242.0 – 394.0) | 267.0 (242.0 – 394.0)
Week 8
N | 2 | 7 | 9
Mean (SD) | 285.5 (64.3) | 275.9 (46.9) | 278.0 (46.8)
Median (Min-Max) | 285.5 (240.0 – 331.0) | 260.0 (239.0 – 380.0) | 260.0 (239.0 – 380.0)
LOCF
N | 2 | 10 | 12
Mean (SD) | 285.5 (64.3) | 293.6 (53.9) | 292.3 (52.6)
Median (Min-Max) | 285.5 (240.0 – 331.0) | 267.0 (239.0 – 394.0) | 267.0 (239.0 – 394.0)
Change from Baseline to LOCF
N | 2 | 9 | 11
Mean (SD) | 4.5 (16.3) | 15.1 (36.5) | 13.2 (33.4)
Median (Min-Max) | 4.5 (−7.0 – 16.0) | 15.0 (−52.0 – 67.0) | 15.0 (−52.0 – 67.0)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.5.4.2 Summary of Clinical Laboratory Coagulation Measurements by Visit and Discontinuation Phase Treatment Received Group Prothrombin Time - PT (Seconds) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 10.2 (0.6) | 12.2 (1.8) | 11.7 (1.8)
Median (Min-Max) | 10.2 (9.7 – 10.8) | 11.3 (10.0 – 14.6) | 10.9 (9.7 – 14.6)
Week 4
N | 2 | 7 | 9
Mean (SD) | 10.5 (0.6) | 12.3 (2.2) | 11.9 (2.1)
Median (Min-Max) | 10.5 (10.0 – 10.9) | 11.2 (9.7 – 15.2) | 10.9 (9.7 – 15.2)
Week 8
N | 2 | 7 | 9
Mean (SD) | 10.5 (0.6) | 11.7 (2.1) | 11.4 (1.9)
Median (Min-Max) | 10.5 (10.0 – 10.9) | 11.1 (9.7 – 14.9) | 10.9 (9.7 – 14.9)
LOCF
N | 2 | 10 | 12
Mean (SD) | 10.5 (0.6) | 12.1 (2.0) | 11.8 (1.9)
Median (Min-Max) | 10.5 (10.0 – 10.9) | 11.3 (9.7 – 14.9) | 11.0 (9.7 – 14.9)
Change from Baseline to LOCF
N | 2 | 10 | 12
Mean (SD) | 0.2 (0.1) | −0.1 (0.3) | 0.0 (0.3)
Median (Min-Max) | 0.2 (0.1 – 0.3) | −0.1 (−0.6 – 0.3) | 0.1 (−0.6 – 0.3)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.3.5.4.3 Summary of Clinical Laboratory Coagulation Measurements by Visit and Discontinuation Phase Treatment Received Group Partial Thromboplastin Time - PTT (Seconds) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 28.7 (0.6) | 29.2 (2.5) | 29.1 (2.2)
Median (Min-Max) | 29.0 (28.0 – 29.0) | 29.0 (26.2 – 35.0) | 29.0 (26.2 – 35.0)
Week 4
N | 2 | 7 | 9
Mean (SD) | 27.5 (0.7) | 30.1 (3.4) | 29.5 (3.1)
Median (Min-Max) | 27.5 (27.0 – 28.0) | 29.0 (27.0 – 35.4) | 28.0 (27.0 – 35.4)
Week 8
N | 2 | 6 | 8
Mean (SD) | 28.0 (1.4) | 29.4 (2.6) | 29.1 (2.3)
Median (Min-Max) | 28.0 (27.0 – 29.0) | 28.4 (27.0 – 34.0) | 28.4 (27.0 – 34.0)
LOCF
N | 2 | 9 | 11
Mean (SD) | 28.0 (1.4) | 29.2 (2.2) | 29.0 (2.1)
Median (Min-Max) | 28.0 (27.0 – 29.0) | 28.8 (27.0 – 34.0) | 28.8 (27.0 – 34.0)
Change from Baseline to LOCF
N | 2 | 9 | 11
Mean (SD) | −0.5 (0.7) | 0.0 (1.1) | −0.1 (1.0)
Median (Min-Max) | −0.5 (−1.0 – 0.0) | −0.2 (−1.0 – 2.1) | −0.2 (−1.0 – 2.1)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.4.1.1 Summary of Vital Signs by Visit, Age Strata and Efficacy Phase Treatment Received Group Heart Rate (beats/min) Efficacy Phase - Safety Population

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 82.4 (15.8) | 80.8 (14.4) | 78.8 (16.7) | 77.3 (10.4) | 81.0 (16.1) | 79.4 (12.9)
Median (Min-Max) | 83.0 (47.0, 120.0) | 83.0 (59.0, 111.0) | 77.0 (58.0, 127.0) | 77.0 (64.0, 95.0) | 81.0 (47.0, 127.0) | 80.5 (59.0, 111.0)
Week 1
N | 31 | 17 | 21 | 11 | 52 | 28
Mean (SD) | 85.8 (14.6) | 85.8 (10.9) | 83.0 (14.4) | 72.8 (12.5) | 84.7 (14.4) | 80.7 (13.1)
Median (Min-Max) | 87.0 (54.0, 114.0) | 87.0 (63.0, 104.0) | 85.0 (57.0, 110.0) | 70.0 (55.0, 97.0) | 86.0 (54.0, 114.0) | 83.5 (55.0, 104.0)
Week 2
N | 28 | 17 | 19 | 10 | 47 | 27
Mean (SD) | 87.9 (16.0) | 86.5 (16.5) | 83.7 (12.4) | 78.9 (11.5) | 86.2 (14.6) | 83.7 (15.0)
Median (Min-Max) | 92.5 (55.0, 115.0) | 89.0 (59.0, 116.0) | 84.0 (61.0, 103.0) | 80.0 (61.0, 94.0) | 88.0 (55.0, 115.0) | 84.0 (59.0, 116.0)
Week 3
N | 27 | 14 | 15 | 9 | 42 | 23
Mean (SD) | 85.7 (17.1) | 88.4 (15.0) | 86.2 (12.9) | 79.6 (12.8) | 85.9 (15.5) | 84.9 (14.6)
Median (Min-Max) | 87.0 (53.0, 128.0) | 94.5 (56.0, 104.0) | 92.0 (63.0, 100.0) | 80.0 (56.0, 96.0) | 87.5 (53.0, 128.0) | 86.0 (56.0, 104.0)
Week 4
N | 27 | 13 | 17 | 10 | 44 | 23
Mean (SD) | 85.3 (16.1) | 88.5 (14.4) | 85.9 (13.2) | 73.8 (12.1) | 85.5 (14.9) | 82.1 (15.1)
Median (Min-Max) | 88.0 (53.0, 118.0) | 89.0 (63.0, 112.0) | 88.0 (53.0, 108.0) | 72.5 (59.0, 92.0) | 88.0 (53.0, 118.0) | 86.0 (59.0, 112.0)
Week 5
N | 13 | 4 | 7 | 4 | 20 | 8
Mean (SD) | 84.5 (14.1) | 93.0 (12.6) | 81.7 (10.8) | 73.0 (12.5) | 83.5 (12.8) | 83.0 (15.8)
Median (Min-Max) | 85.0 (48.0, 108.0) | 97.0 (75.0, 103.0) | 88.0 (64.0, 92.0) | 74.0 (58.0, 86.0) | 85.5 (48.0, 108.0) | 83.0 (58.0, 103.0)
Week 6
N | 26 | 13 | 13 | 10 | 39 | 23
Mean (SD) | 83.5 (14.1) | 87.7 (12.1) | 80.7 (8.2) | 82.5 (9.5) | 82.5 (12.4) | 85.4 (11.1)
Median (Min-Max) | 83.0 (54.0, 112.0) | 92.0 (65.0, 99.0) | 84.0 (63.0, 88.0) | 82.0 (72.0, 103.0) | 84.0 (54.0, 112.0) | 88.0 (65.0, 103.0)
Week 7
N | 12 | 4 | 8 | 4 | 20 | 8
Mean (SD) | 82.9 (12.8) | 94.8 (11.1) | 81.9 (13.4) | 69.8 (9.3) | 82.5 (12.7) | 82.3 (16.4)
Median (Min-Max) | 84.0 (52.0, 104.0) | 91.5 (86.0, 110.0) | 81.5 (62.0, 104.0) | 70.5 (58.0, 80.0) | 84.0 (52.0, 104.0) | 83.0 (58.0, 110.0)
Week 8
N | 24 | 11 | 13 | 10 | 37 | 21
Mean (SD) | 82.2 (15.6) | 84.3 (9.4) | 79.2 (12.8) | 72.9 (8.3) | 81.1 (14.6) | 78.9 (10.5)
Median (Min-Max) | 82.5 (51.0, 112.0) | 84.0 (64.0, 102.0) | 81.0 (57.0, 101.0) | 72.0 (62.0, 84.0) | 82.0 (51.0, 112.0) | 82.0 (62.0, 102.0)
LOCF
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 81.9 (15.9) | 83.1 (13.0) | 82.6 (13.0) | 71.3 (9.6) | 82.2 (14.7) | 78.4 (13.0)
Median (Min-Max) | 82.5 (51.0, 112.0) | 84.0 (63.0, 105.0) | 82.0 (57.0, 103.0) | 69.0 (55.0, 84.0) | 82.0 (51.0, 112.0) | 81.0 (55.0, 105.0)
Change from Baseline to LOCF
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | −0.5 (12.9) | 2.2 (13.5) | 3.8 (14.8) | −6.0 (13.8) | 1.2 (13.7) | −1.0 (14.0)
Median (Min-Max) | 0.0 (−25.0, 31.0) | 5.0 (−32.0, 21.0) | 5.0 (−36.0, 24.0) | −2.0 (−31.0, 16.0) | 0.0 (−36.0, 31.0) | 0.0 (−32.0, 21.0)

Note: Baseline is defined as first visit of Efficacy phase.

Protocol amendment 5 changed weeks 5 and 7 to phone visits with no physical exam completed.

Table 14.3.4.1.2 Summary of Vital Signs by Visit, Age Strata and Efficacy Phase Treatment Received Group Systolic Blood Pressure (mmHg) Efficacy Phase - Safety Population

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 110.2 (11.6) | 112.0 (13.6) | 109.8 (11.0) | 121.1 (13.6) | 110.0 (11.2) | 115.6 (14.1)
Median (Min-Max) | 109.0 (91.0, 137.0) | 115.0 (80.0, 133.0) | 110.0 (95.0, 144.0) | 117.0 (96.0, 141.0) | 110.0 (91.0, 144.0) | 116.5 (80.0, 141.0)
Week 1
N | 31 | 17 | 21 | 11 | 52 | 28
Mean (SD) | 110.3 (14.0) | 110.8 (12.1) | 108.9 (11.7) | 113.5 (9.1) | 109.7 (13.0) | 111.9 (10.9)
Median (Min-Max) | 106.0 (88.0, 142.0) | 110.0 (88.0, 144.0) | 110.0 (88.0, 133.0) | 115.0 (95.0, 124.0) | 107.5 (88.0, 142.0) | 111.0 (88.0, 144.0)
Week 2
N | 28 | 17 | 19 | 10 | 47 | 27
Mean (SD) | 111.8 (11.4) | 113.1 (11.9) | 112.3 (12.4) | 119.3 (13.9) | 112.0 (11.7) | 115.4 (12.8)
Median (Min-Max) | 111.0 (90.0, 134.0) | 111.0 (99.0, 145.0) | 112.0 (88.0, 139.0) | 124.5 (96.0, 136.0) | 112.0 (88.0, 139.0) | 114.0 (96.0, 145.0)
Week 3
N | 27 | 14 | 15 | 9 | 42 | 23
Mean (SD) | 115.8 (13.8) | 108.9 (12.7) | 111.1 (10.3) | 118.7 (11.2) | 114.1 (12.7) | 112.7 (12.8)
Median (Min-Max) | 114.0 (92.0, 150.0) | 109.0 (85.0, 129.0) | 110.0 (90.0, 127.0) | 118.0 (102.0, 139.0) | 114.0 (90.0, 150.0) | 112.0 (85.0, 139.0)
Week 4
N | 27 | 13 | 17 | 10 | 44 | 23
Mean (SD) | 113.3 (11.0) | 112.6 (11.9) | 113.9 (12.1) | 118.0 (13.2) | 113.5 (11.3) | 115.0 (12.5)
Median (Min-Max) | 111.0 (91.0, 135.0) | 110.0 (96.0, 134.0) | 116.0 (92.0, 142.0) | 123.0 (95.0, 133.0) | 112.5 (91.0, 142.0) | 114.0 (95.0, 134.0)
Week 5
N | 13 | 4 | 7 | 4 | 20 | 8
Mean (SD) | 112.1 (14.1) | 102.5 (5.3) | 110.3 (13.8) | 111.5 (12.4) | 111.5 (13.7) | 107.0 (10.0)
Median (Min-Max) | 110.0 (94.0, 134.0) | 101.0 (98.0, 110.0) | 104.0 (98.0, 132.0) | 110.0 (98.0, 128.0) | 107.0 (94.0, 134.0) | 106.0 (98.0, 128.0)
Week 6
N | 26 | 13 | 13 | 10 | 39 | 23
Mean (SD) | 111.3 (11.6) | 110.2 (15.3) | 115.0 (14.8) | 111.1 (6.9) | 112.6 (12.7) | 110.6 (12.2)
Median (Min-Max) | 110.5 (89.0, 141.0) | 107.0 (87.0, 145.0) | 115.0 (88.0, 141.0) | 111.0 (99.0, 124.0) | 113.0 (88.0, 141.0) | 109.0 (87.0, 145.0)
Week 7
N | 12 | 4 | 8 | 4 | 20 | 8
Mean (SD) | 108.0 (11.0) | 100.8 (13.7) | 107.3 (13.6) | 121.0 (17.7) | 107.7 (11.8) | 110.9 (18.2)
Median (Min-Max) | 106.5 (89.0, 124.0) | 105.5 (81.0, 111.0) | 111.5 (82.0, 127.0) | 120.5 (100.0, 143.0) | 109.5 (82.0, 127.0) | 110.0 (81.0, 143.0)
Week 8
N | 24 | 11 | 13 | 10 | 37 | 21
Mean (SD) | 108.9 (13.6) | 107.1 (11.1) | 110.6 (17.3) | 115.6 (13.2) | 109.5 (14.8) | 111.1 (12.6)
Median (Min-Max) | 109.0 (88.0, 135.0) | 107.0 (86.0, 125.0) | 107.0 (90.0, 151.0) | 113.5 (98.0, 139.0) | 107.0 (88.0, 151.0) | 110.0 (86.0, 139.0)
LOCF
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 109.4 (12.4) | 111.4 (13.2) | 111.1 (14.3) | 115.5 (12.6) | 110.1 (13.1) | 113.0 (12.9)
Median (Min-Max) | 110.5 (88.0, 135.0) | 110.0 (86.0, 145.0) | 107.0 (90.0, 151.0) | 114.0 (98.0, 139.0) | 109.0 (88.0, 151.0) | 111.5 (86.0, 145.0)
Change from Baseline to LOCF
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | −0.8 (11.1) | −0.6 (10.2) | 1.4 (10.0) | −5.6 (9.4) | 0.1 (10.6) | −2.6 (10.0)
Median (Min-Max) | −2.0 (−25.0, 24.0) | 1.0 (−21.0, 17.0) | 4.0 (−15.0, 17.0) | −3.0 (−26.0, 5.0) | 0.0 (−25.0, 24.0) | −2.0 (−26.0, 17.0)

Note: Baseline is defined as first visit of Efficacy phase.

Protocol amendment 5 changed weeks 5 and 7 to phone visits with no physical exam completed.

Table 14.3.4.1.3 Summary of Vital Signs by Visit, Age Strata and Efficacy Phase Treatment Received Group Systolic Blood Pressure Z Score Efficacy Phase - Safety Population

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 0.76 (0.93) | 0.93 (1.23) | 0.03 (0.98) | 0.93 (1.22) | 0.47 (1.01) | 0.93 (1.21)
Median (Min-Max) | 0.78 (−0.89, 2.94) | 1.17 (−1.87, 2.96) | −0.04 (−1.33, 2.68) | 0.70 (−1.19, 2.80) | 0.32 (−1.33, 2.94) | 1.06 (−1.87, 2.96)
Week 1
N | 31 | 17 | 21 | 11 | 52 | 28
Mean (SD) | 0.75 (1.20) | 0.80 (1.14) | −0.05 (1.10) | 0.31 (0.80) | 0.43 (1.22) | 0.61 (1.04)
Median (Min-Max) | 0.45 (−1.08, 3.82) | 0.55 (−0.95, 4.01) | −0.29 (−2.06, 1.65) | 0.19 (−0.89, 1.28) | 0.24 (−2.06, 3.82) | 0.52 (−0.95, 4.01)
Week 2
N | 28 | 17 | 19 | 10 | 47 | 27
Mean (SD) | 0.92 (0.90) | 1.02 (1.18) | 0.27 (1.22) | 0.81 (1.27) | 0.66 (1.08) | 0.95 (1.19)
Median (Min-Max) | 0.89 (−0.60, 3.14) | 0.89 (−0.47, 4.10) | 0.19 (−2.03, 2.89) | 1.57 (−1.27, 2.04) | 0.65 (−2.03, 3.14) | 0.96 (−1.27, 4.10)
Week 3
N | 27 | 14 | 15 | 9 | 42 | 23
Mean (SD) | 1.26 (1.20) | 0.62 (1.18) | 0.11 (0.96) | 0.81 (0.95) | 0.85 (1.24) | 0.69 (1.08)
Median (Min-Max) | 1.28 (−0.91, 4.66) | 0.72 (−1.84, 2.57) | 0.01 (−1.84, 1.53) | 0.75 (−0.33, 2.32) | 0.86 (−1.84, 4.66) | 0.75 (−1.84, 2.57)
Week 4
N | 27 | 13 | 17 | 10 | 44 | 23
Mean (SD) | 1.02 (0.91) | 0.93 (1.14) | 0.36 (1.14) | 0.76 (1.11) | 0.77 (1.04) | 0.86 (1.11)
Median (Min-Max) | 1.10 (−0.64, 2.74) | 0.69 (−0.35, 3.04) | 0.56 (−1.70, 2.48) | 1.28 (−1.30, 1.93) | 0.83 (−1.70, 2.74) | 0.86 (−1.30, 3.04)
Week 5
N | 13 | 4 | 7 | 4 | 20 | 8
Mean (SD) | 0.95 (1.12) | 0.10 (0.94) | 0.13 (1.37) | 0.08 (1.04) | 0.66 (1.24) | 0.09 (0.92)
Median (Min-Max) | 0.48 (−0.28, 3.03) | −0.07 (−0.86, 1.38) | −0.67 (−1.15, 2.10) | −0.08 (−1.02, 1.49) | 0.42 (−1.15, 3.03) | −0.07 (−1.02, 1.49)
Week 6
N | 26 | 13 | 13 | 10 | 39 | 23
Mean (SD) | 0.83 (1.01) | 0.73 (1.48) | 0.45 (1.33) | 0.04 (0.66) | 0.70 (1.13) | 0.43 (1.23)
Median (Min-Max) | 0.78 (−1.39, 3.49) | 0.32 (−1.23, 4.08) | 0.54 (−2.03, 2.38) | 0.13 (−1.13, 1.28) | 0.68 (−2.03, 3.49) | 0.15 (−1.23, 4.08)
Week 7
N | 12 | 4 | 8 | 4 | 20 | 8
Mean (SD) | 0.55 (0.90) | −0.07 (1.37) | −0.22 (1.29) | 1.03 (1.54) | 0.24 (1.11) | 0.48 (1.47)
Median (Min-Max) | 0.49 (−0.71, 1.89) | 0.11 (−1.80, 1.28) | 0.13 (−2.60, 1.62) | 1.01 (−0.83, 2.91) | 0.22 (−2.60, 1.89) | 0.73 (−1.80, 2.91)
Week 8
N | 24 | 11 | 13 | 10 | 37 | 21
Mean (SD) | 0.64 (1.23) | 0.43 (1.11) | 0.06 (1.55) | 0.50 (1.14) | 0.44 (1.36) | 0.47 (1.10)
Median (Min-Max) | 0.41 (−1.07, 3.24) | 0.74 (−1.37, 2.04) | −0.38 (−1.88, 3.28) | 0.45 (−1.01, 2.56) | 0.03 (−1.88, 3.28) | 0.74 (−1.37, 2.56)
LOCF
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 0.67 (1.09) | 0.85 (1.27) | 0.15 (1.35) | 0.42 (1.12) | 0.46 (1.21) | 0.68 (1.21)
Median (Min-Max) | 0.71 (−1.07, 3.24) | 0.89 (−1.37, 4.08) | −0.09 (−1.88, 3.28) | −0.02 (−1.01, 2.56) | 0.65 (−1.88, 3.28) | 0.87 (−1.37, 4.08)
Change from Baseline to LOCF
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | −0.09 (1.05) | −0.08 (0.96) | 0.11 (0.95) | −0.51 (0.93) | −0.01 (1.00) | −0.25 (0.96)
Median (Min-Max) | −0.22 (−2.39, 2.18) | 0.06 (−2.02, 1.58) | 0.33 (−1.47, 1.56) | −0.24 (−2.44, 0.61) | −0.02 (−2.39, 2.18) | −0.21 (−2.44, 1.58)

Note: Baseline is defined as first visit of Efficacy phase.

Protocol amendment 5 changed weeks 5 and 7 to phone visits with no physical exam completed.

Height at Efficacy Phase day 1 is used to calculate all BP Z scores except at Early Termination/Week 08/LOCF visit, which used the height collected at that visit.

Table 14.3.4.1.4 Summary of Vital Signs by Visit, Age Strata and Efficacy Phase Treatment Received Group Diastolic Blood Pressure (mmHg) Efficacy Phase - Safety Population

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 66.0 (10.3) | 61.1 (8.5) | 67.7 (11.2) | 67.4 (8.0) | 66.7 (10.6) | 63.5 (8.7)
Median (Min-Max) | 66.5 (45.0, 90.0) | 62.0 (45.0, 77.0) | 65.0 (46.0, 99.0) | 69.0 (55.0, 77.0) | 66.0 (45.0, 99.0) | 64.5 (45.0, 77.0)
Week 1
N | 31 | 17 | 21 | 11 | 52 | 28
Mean (SD) | 61.8 (10.9) | 65.2 (9.1) | 66.4 (9.7) | 64.0 (6.3) | 63.7 (10.6) | 64.8 (8.0)
Median (Min-Max) | 63.0 (41.0, 82.0) | 64.0 (47.0, 81.0) | 64.0 (55.0, 92.0) | 64.0 (52.0, 73.0) | 63.5 (41.0, 92.0) | 64.0 (47.0, 81.0)
Week 2
N | 28 | 17 | 19 | 10 | 47 | 27
Mean (SD) | 67.0 (10.0) | 65.9 (9.8) | 67.8 (11.3) | 71.2 (8.5) | 67.3 (10.4) | 67.9 (9.5)
Median (Min-Max) | 65.5 (52.0, 92.0) | 66.0 (46.0, 81.0) | 67.0 (51.0, 98.0) | 70.5 (58.0, 82.0) | 66.0 (51.0, 98.0) | 67.0 (46.0, 82.0)
Week 3
N | 27 | 14 | 15 | 9 | 42 | 23
Mean (SD) | 68.4 (9.7) | 62.5 (11.6) | 70.6 (10.1) | 68.2 (9.1) | 69.2 (9.7) | 64.7 (10.8)
Median (Min-Max) | 68.0 (52.0, 90.0) | 66.5 (41.0, 80.0) | 70.0 (55.0, 90.0) | 66.0 (56.0, 89.0) | 68.5 (52.0, 90.0) | 66.0 (41.0, 89.0)
Week 4
N | 27 | 13 | 17 | 10 | 44 | 23
Mean (SD) | 66.9 (9.3) | 67.8 (7.1) | 71.2 (10.1) | 66.3 (4.4) | 68.6 (9.8) | 67.1 (6.0)
Median (Min-Max) | 67.0 (45.0, 87.0) | 67.0 (58.0, 82.0) | 72.0 (56.0, 95.0) | 66.0 (58.0, 73.0) | 68.0 (45.0, 95.0) | 67.0 (58.0, 82.0)
Week 5
N | 13 | 4 | 7 | 4 | 20 | 8
Mean (SD) | 65.2 (10.4) | 63.5 (2.1) | 68.0 (11.5) | 63.5 (7.1) | 66.2 (10.6) | 63.5 (4.9)
Median (Min-Max) | 66.0 (42.0, 80.0) | 63.5 (61.0, 66.0) | 70.0 (53.0, 85.0) | 66.5 (53.0, 68.0) | 66.0 (42.0, 85.0) | 64.5 (53.0, 68.0)
Week 6
N | 26 | 13 | 13 | 10 | 39 | 23
Mean (SD) | 66.7 (8.7) | 67.8 (10.7) | 70.1 (8.0) | 65.0 (7.0) | 67.8 (8.5) | 66.6 (9.2)
Median (Min-Max) | 67.5 (49.0, 85.0) | 63.0 (56.0, 92.0) | 72.0 (58.0, 80.0) | 64.5 (54.0, 78.0) | 69.0 (49.0, 85.0) | 64.0 (54.0, 92.0)
Week 7
N | 12 | 4 | 8 | 4 | 20 | 8
Mean (SD) | 66.3 (10.8) | 64.8 (7.3) | 63.3 (9.2) | 64.3 (10.2) | 65.1 (10.1) | 64.5 (8.2)
Median (Min-Max) | 67.0 (41.0, 85.0) | 66.0 (55.0, 72.0) | 59.5 (56.0, 82.0) | 62.5 (54.0, 78.0) | 64.5 (41.0, 85.0) | 64.5 (54.0, 78.0)
Week 8
N | 24 | 11 | 13 | 10 | 37 | 21
Mean (SD) | 64.5 (11.1) | 63.4 (9.0) | 70.3 (8.5) | 68.5 (10.9) | 66.5 (10.5) | 65.8 (10.0)
Median (Min-Max) | 65.0 (39.0, 90.0) | 61.0 (48.0, 76.0) | 69.0 (58.0, 87.0) | 69.0 (48.0, 84.0) | 67.0 (39.0, 90.0) | 65.0 (48.0, 84.0)
LOCF
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 64.8 (10.0) | 66.2 (10.3) | 69.8 (10.1) | 68.3 (10.3) | 66.8 (10.2) | 67.0 (10.2)
Median (Min-Max) | 65.0 (39.0, 90.0) | 64.0 (48.0, 92.0) | 68.0 (58.0, 98.0) | 68.0 (48.0, 84.0) | 67.0 (39.0, 98.0) | 67.0 (48.0, 92.0)
Change from Baseline to LOCF
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | −1.2 (11.5) | 5.1 (10.3) | 2.1 (11.5) | 0.9 (12.6) | 0.1 (11.5) | 3.5 (11.2)
Median (Min-Max) | −0.5 (−35.0, 22.0) | 7.0 (−14.0, 24.0) | 2.0 (−24.0, 21.0) | 1.0 (−26.0, 16.0) | 1.0 (−35.0, 22.0) | 5.0 (−26.0, 24.0)

Note: Baseline is defined as first visit of Efficacy phase.

Protocol amendment 5 changed weeks 5 and 7 to phone visits with no physical exam completed.

Table 14.3.4.1.5 Summary of Vital Signs by Visit, Age Strata and Efficacy Phase Treatment Received Group Diastolic Blood Pressure Z Score Efficacy Phase - Safety Population

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 0.47 (0.81) | 0.02 (0.69) | 0.32 (0.95) | 0.22 (0.68) | 0.41 (0.86) | 0.10 (0.68)
Median (Min-Max) | 0.53 (−1.55, 2.42) | 0.11 (−1.19, 1.48) | 0.10 (−1.42, 2.88) | 0.27 (−1.02, 0.99) | 0.45 (−1.55, 2.88) | 0.18 (−1.19, 1.48)
Week 1
N | 31 | 17 | 21 | 11 | 52 | 28
Mean (SD) | 0.08 (0.92) | 0.38 (0.82) | 0.19 (0.84) | −0.08 (0.51) | 0.13 (0.89) | 0.20 (0.74)
Median (Min-Max) | 0.20 (−1.88, 1.61) | 0.19 (−1.05, 1.84) | −0.04 (−0.82, 2.47) | −0.10 (−0.79, 0.62) | 0.19 (−1.88, 2.47) | 0.14 (−1.05, 1.84)
Week 2
N | 28 | 17 | 19 | 10 | 47 | 27
Mean (SD) | 0.56 (0.89) | 0.44 (0.90) | 0.34 (1.02) | 0.57 (0.76) | 0.47 (0.94) | 0.49 (0.84)
Median (Min-Max) | 0.47 (−0.88, 2.91) | 0.49 (−1.41, 1.84) | 0.24 (−1.01, 3.18) | 0.48 (−0.56, 1.47) | 0.44 (−1.01, 3.18) | 0.49 (−1.41, 1.84)
Week 3
N | 27 | 14 | 15 | 9 | 42 | 23
Mean (SD) | 0.67 (0.81) | 0.15 (1.05) | 0.55 (0.88) | 0.30 (0.81) | 0.63 (0.83) | 0.21 (0.94)
Median (Min-Max) | 0.51 (−0.64, 2.72) | 0.56 (−1.79, 1.62) | 0.37 (−0.83, 2.33) | 0.26 (−0.97, 2.07) | 0.41 (−0.83, 2.72) | 0.28 (−1.79, 2.07)
Week 4
N | 27 | 13 | 17 | 10 | 44 | 23
Mean (SD) | 0.53 (0.80) | 0.58 (0.67) | 0.60 (0.89) | 0.14 (0.43) | 0.55 (0.82) | 0.39 (0.61)
Median (Min-Max) | 0.65 (−1.25, 2.37) | 0.73 (−0.29, 1.93) | 0.71 (−0.83, 2.53) | 0.08 (−0.79, 0.66) | 0.65 (−1.25, 2.53) | 0.23 (−0.79, 1.93)
Week 5
N | 13 | 4 | 7 | 4 | 20 | 8
Mean (SD) | 0.42 (0.87) | 0.26 (0.29) | 0.37 (0.97) | −0.19 (0.71) | 0.40 (0.88) | 0.03 (0.56)
Median (Min-Max) | 0.43 (−1.44, 1.77) | 0.23 (−0.03, 0.61) | 0.37 (−0.80, 1.79) | 0.05 (−1.20, 0.34) | 0.41 (−1.44, 1.79) | 0.17 (−1.20, 0.61)
Week 6
N | 26 | 13 | 13 | 10 | 39 | 23
Mean (SD) | 0.52 (0.79) | 0.60 (0.99) | 0.48 (0.72) | 0.03 (0.60) | 0.50 (0.75) | 0.35 (0.87)
Median (Min-Max) | 0.63 (−1.11, 2.20) | 0.10 (−0.26, 2.83) | 0.87 (−0.65, 1.41) | 0.08 (−1.16, 1.07) | 0.64 (−1.11, 2.20) | 0.10 (−1.16, 2.83)
Week 7
N | 12 | 4 | 8 | 4 | 20 | 8
Mean (SD) | 0.50 (0.92) | 0.37 (0.67) | −0.05 (0.79) | −0.13 (0.91) | 0.28 (0.89) | 0.12 (0.79)
Median (Min-Max) | 0.69 (−1.60, 2.22) | 0.47 (−0.43, 0.95) | −0.32 (−0.90, 1.52) | −0.36 (−0.94, 1.16) | 0.18 (−1.60, 2.22) | −0.05 (−0.94, 1.16)
Week 8
N | 24 | 11 | 13 | 10 | 37 | 21
Mean (SD) | 0.33 (0.93) | 0.20 (0.83) | 0.49 (0.76) | 0.35 (0.90) | 0.39 (0.86) | 0.27 (0.85)
Median (Min-Max) | 0.42 (−2.07, 2.63) | 0.12 (−1.05, 1.29) | 0.37 (−0.59, 1.97) | 0.37 (−1.52, 1.59) | 0.40 (−2.07, 2.63) | 0.22 (−1.52, 1.59)
LOCF
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 0.35 (0.85) | 0.46 (0.93) | 0.50 (0.93) | 0.31 (0.87) | 0.41 (0.88) | 0.40 (0.89)
Median (Min-Max) | 0.42 (−2.07, 2.63) | 0.24 (−1.05, 2.83) | 0.37 (−0.75, 3.18) | 0.32 (−1.52, 1.59) | 0.40 (−2.07, 3.18) | 0.28 (−1.52, 2.83)
Change from Baseline to LOCF
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | −0.12 (1.03) | 0.44 (0.90) | 0.18 (1.03) | 0.08 (1.12) | −0.00 (1.03) | 0.30 (0.99)
Median (Min-Max) | −0.05 (−3.20, 1.89) | 0.58 (−1.23, 2.04) | 0.17 (−2.11, 1.93) | 0.08 (−2.24, 1.45) | 0.09 (−3.20, 1.93) | 0.45 (−2.24, 2.04)

Note: Baseline is defined as first visit of Efficacy phase.

Protocol amendment 5 changed weeks 5 and 7 to phone visits with no physical exam completed.

Height at Efficacy Phase day 1 is used to calculate all BP Z scores except at Early Termination/Week 08/LOCF visit, which used the height collected at that visit.

Table 14.3.4.1.6 Summary of Vital Signs by Visit, Age Strata and Efficacy Phase Treatment Received Group Weight (kg) Efficacy Phase - Safety Population

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 43.9 (20.3) | 42.5 (12.9) | 61.8 (22.1) | 66.3 (18.9) | 51.0 (22.6) | 51.9 (19.3)
Median (Min-Max) | 39.6 (19.5, 94.0) | 42.0 (25.6, 68.6) | 54.6 (36.7, 114.8) | 60.5 (36.8, 103.4) | 46.7 (19.5, 114.8) | 49.8 (25.6, 103.4)
Week 1
N | 31 | 17 | 21 | 11 | 52 | 28
Mean (SD) | 44.6 (20.2) | 42.6 (13.0) | 61.9 (21.8) | 66.4 (19.3) | 51.6 (22.4) | 51.9 (19.5)
Median (Min-Max) | 39.5 (20.4, 94.4) | 41.6 (25.6, 69.1) | 54.8 (37.1, 114.6) | 58.1 (38.0, 105.2) | 47.6 (20.4, 114.6) | 49.9 (25.6, 105.2)
Week 2
N | 28 | 17 | 19 | 10 | 47 | 27
Mean (SD) | 44.2 (20.4) | 42.7 (12.9) | 62.2 (23.3) | 67.6 (20.5) | 51.4 (23.2) | 51.9 (19.9)
Median (Min-Max) | 38.8 (19.5, 94.4) | 43.0 (26.2, 69.1) | 51.5 (37.3, 115.5) | 60.0 (37.7, 106.1) | 47.2 (19.5, 115.5) | 49.8 (26.2, 106.1)
Week 3
N | 27 | 14 | 15 | 9 | 42 | 23
Mean (SD) | 45.2 (19.9) | 43.0 (13.6) | 67.5 (23.6) | 68.8 (21.4) | 53.1 (23.6) | 53.1 (21.0)
Median (Min-Max) | 39.9 (23.0, 94.5) | 43.0 (25.9, 70.0) | 62.8 (37.0, 115.4) | 60.4 (38.0, 106.1) | 48.2 (23.0, 115.4) | 50.9 (25.9, 106.1)
Week 4
N | 27 | 13 | 17 | 10 | 44 | 23
Mean (SD) | 45.6 (20.7) | 43.3 (13.9) | 65.9 (23.0) | 68.3 (20.5) | 53.4 (23.6) | 54.2 (20.9)
Median (Min-Max) | 41.2 (23.5, 93.8) | 43.4 (25.6, 70.0) | 62.1 (37.1, 115.2) | 60.2 (38.4, 105.2) | 48.4 (23.5, 115.2) | 54.0 (25.6, 105.2)
Week 5
N | 13 | 4 | 7 | 4 | 20 | 8
Mean (SD) | 47.2 (21.9) | 33.5 (9.8) | 52.2 (10.8) | 63.8 (9.8) | 48.9 (18.6) | 48.6 (18.6)
Median (Min-Max) | 41.3 (24.7, 82.5) | 29.9 (26.4, 47.7) | 48.1 (37.2, 66.4) | 59.7 (57.7, 78.2) | 47.2 (24.7, 82.5) | 52.7 (26.4, 78.2)
Week 6
N | 26 | 13 | 13 | 10 | 39 | 23
Mean (SD) | 45.7 (20.2) | 40.3 (12.0) | 67.4 (24.0) | 68.7 (20.9) | 53.0 (23.6) | 52.7 (21.5)
Median (Min-Max) | 40.4 (23.8, 94.1) | 41.5 (26.6, 59.4) | 61.8 (44.5, 117.1) | 60.3 (38.9, 108.0) | 47.1 (23.8, 117.1) | 50.9 (26.6, 108.0)
Week 7
N | 12 | 4 | 8 | 4 | 20 | 8
Mean (SD) | 47.4 (23.0) | 33.9 (9.2) | 52.0 (10.6) | 64.3 (10.6) | 49.2 (18.8) | 49.1 (18.7)
Median (Min-Max) | 39.9 (25.6, 83.2) | 30.4 (27.4, 47.2) | 47.8 (36.3, 68.2) | 60.1 (57.2, 80.0) | 47.5 (25.6, 83.2) | 52.2 (27.4, 80.0)
Week 8
N | 24 | 11 | 13 | 10 | 37 | 21
Mean (SD) | 45.4 (20.8) | 38.9 (12.4) | 66.9 (23.7) | 68.7 (20.3) | 53.0 (23.9) | 53.1 (22.3)
Median (Min-Max) | 40.0 (24.0, 95.2) | 31.9 (25.8, 59.9) | 63.0 (45.0, 115.7) | 60.6 (39.2, 105.7) | 46.8 (24.0, 115.7) | 51.3 (25.8, 105.7)
LOCF
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 45.0 (20.4) | 42.8 (12.9) | 62.2 (22.0) | 67.8 (19.6) | 51.8 (22.5) | 52.6 (19.9)
Median (Min-Max) | 40.0 (19.5, 95.2) | 43.4 (25.8, 70.0) | 54.3 (36.3, 115.7) | 60.3 (39.2, 105.7) | 47.2 (19.5, 115.7) | 50.5 (25.8, 105.7)
Change from Baseline to LOCF
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 1.2 (1.6) | 0.3 (1.7) | 0.4 (1.6) | 1.5 (2.0) | 0.9 (1.6) | 0.8 (1.8)
Median (Min-Max) | 1.3 (−1.6, 5.2) | 0.5 (−2.5, 4.2) | 0.5 (−3.1, 3.0) | 2.1 (−2.4, 4.4) | 0.9 (−3.1, 5.2) | 1.0 (−2.5, 4.4)

Note: Baseline is defined as first visit of Efficacy phase.

Protocol amendment 5 changed weeks 5 and 7 to phone visits with no physical exam completed.

Table 14.3.4.1.7 Summary of Vital Signs by Visit, Age Strata and Efficacy Phase Treatment Received Group Weight Z Score Efficacy Phase - Safety Population

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 0.92 (1.45) | 1.40 (0.97) | 0.50 (1.29) | 0.98 (1.20) | 0.75 (1.39) | 1.23 (1.07)
Median (Min-Max) | 1.06 (−2.46, 3.25) | 1.37 (−0.21, 3.07) | 0.25 (−1.51, 2.75) | 0.97 (−1.44, 2.99) | 0.74 (−2.46, 3.25) | 1.09 (−1.44, 3.07)
Week 1
N | 31 | 17 | 21 | 11 | 52 | 28
Mean (SD) | 0.97 (1.42) | 1.40 (0.97) | 0.51 (1.29) | 0.98 (1.21) | 0.78 (1.37) | 1.23 (1.07)
Median (Min-Max) | 1.16 (−2.42, 3.24) | 1.25 (−0.21, 3.11) | 0.32 (−1.54, 2.73) | 0.97 (−1.25, 3.03) | 0.88 (−2.42, 3.24) | 1.06 (−1.25, 3.11)
Week 2
N | 28 | 17 | 19 | 10 | 47 | 27
Mean (SD) | 1.08 (1.33) | 1.41 (0.95) | 0.48 (1.35) | 1.14 (1.17) | 0.84 (1.36) | 1.31 (1.02)
Median (Min-Max) | 1.15 (−2.30, 3.23) | 1.14 (−0.06, 3.09) | 0.32 (−1.58, 2.76) | 1.07 (−1.29, 3.06) | 0.54 (−2.30, 3.23) | 1.14 (−1.29, 3.09)
Week 3
N | 27 | 14 | 15 | 9 | 42 | 23
Mean (SD) | 1.17 (1.19) | 1.36 (0.98) | 0.84 (1.26) | 1.15 (1.25) | 1.05 (1.21) | 1.28 (1.07)
Median (Min-Max) | 1.21 (−0.41, 3.23) | 1.20 (0.05, 3.10) | 0.98 (−1.29, 2.75) | 1.15 (−1.30, 3.06) | 1.13 (−1.29, 3.23) | 1.15 (−1.30, 3.10)
Week 4
N | 27 | 13 | 17 | 10 | 44 | 23
Mean (SD) | 1.15 (1.19) | 1.41 (1.01) | 0.70 (1.33) | 1.17 (1.16) | 0.97 (1.25) | 1.31 (1.06)
Median (Min-Max) | 1.12 (−0.32, 3.24) | 1.41 (0.07, 3.07) | 1.02 (−1.43, 2.75) | 1.03 (−1.24, 3.01) | 1.03 (−1.43, 3.24) | 1.06 (−1.24, 3.07)
Week 5
N | 13 | 4 | 7 | 4 | 20 | 8
Mean (SD) | 1.45 (1.36) | 0.52 (0.25) | −0.11 (0.96) | 0.99 (0.53) | 0.90 (1.43) | 0.76 (0.46)
Median (Min-Max) | 1.70 (−0.25, 3.24) | 0.49 (0.25, 0.85) | −0.41 (−1.26, 1.08) | 0.83 (0.57, 1.74) | 0.49 (−1.26, 3.24) | 0.61 (0.25, 1.74)
Week 6
N | 26 | 13 | 13 | 10 | 39 | 23
Mean (SD) | 1.19 (1.19) | 1.17 (0.89) | 0.76 (1.32) | 1.18 (1.16) | 1.05 (1.24) | 1.18 (0.99)
Median (Min-Max) | 1.18 (−0.25, 3.22) | 0.83 (0.15, 3.08) | 1.02 (−1.35, 2.79) | 1.09 (−1.16, 3.10) | 1.05 (−1.35, 3.22) | 0.96 (−1.16, 3.10)
Week 7
N | 12 | 4 | 8 | 4 | 20 | 8
Mean (SD) | 1.41 (1.38) | 0.58 (0.20) | −0.06 (0.95) | 1.01 (0.55) | 0.82 (1.41) | 0.80 (0.45)
Median (Min-Max) | 1.04 (−0.21, 3.24) | 0.63 (0.30, 0.77) | −0.03 (−1.46, 1.16) | 0.81 (0.62, 1.80) | 0.34 (−1.46, 3.24) | 0.65 (0.30, 1.80)
Week 8
N | 24 | 11 | 13 | 10 | 37 | 21
Mean (SD) | 1.21 (1.21) | 0.97 (0.75) | 0.72 (1.33) | 1.18 (1.14) | 1.04 (1.26) | 1.07 (0.94)
Median (Min-Max) | 1.00 (−0.20, 3.26) | 0.59 (0.24, 2.51) | 1.01 (−1.29, 2.74) | 1.14 (−1.17, 3.01) | 1.01 (−1.29, 3.26) | 0.73 (−1.17, 3.01)
LOCF
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 1.01 (1.41) | 1.38 (0.94) | 0.49 (1.32) | 1.02 (1.21) | 0.80 (1.38) | 1.24 (1.05)
Median (Min-Max) | 1.03 (−2.42, 3.26) | 1.14 (0.24, 3.08) | 0.47 (−1.58, 2.74) | 1.01 (−1.17, 3.01) | 0.89 (−2.42, 3.26) | 1.08 (−1.17, 3.08)
Change from Baseline to LOCF
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 0.09 (0.25) | −0.01 (0.20) | −0.01 (0.14) | 0.04 (0.15) | 0.05 (0.22) | 0.01 (0.18)
Median (Min-Max) | 0.02 (−0.29, 0.87) | −0.04 (−0.31, 0.45) | −0.01 (−0.33, 0.29) | 0.05 (−0.26, 0.27) | 0.01 (−0.33, 0.87) | 0.01 (−0.31, 0.45)

Note: Baseline is defined as first visit of Efficacy phase.

Protocol amendment 5 changed weeks 5 and 7 to phone visits with no physical exam completed.

Table 14.3.4.1.8 Summary of Vital Signs by Visit, Age Strata and Efficacy Phase Treatment Received Group Height (cm) Efficacy Phase - Safety Population

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 139.3 (13.8) | 138.5 (10.0) | 158.7 (6.2) | 163.7 (9.3) | 147.0 (14.9) | 148.4 (15.8)
Median (Min-Max) | 137.4 (117.7, 164.8) | 139.4 (118.8, 155.0) | 159.6 (138.5, 172.1) | 162.5 (145.0, 178.2) | 152.4 (117.7, 172.1) | 146.3 (118.8, 178.2)
LOCF
N | 30 | 13 | 20 | 10 | 50 | 23
Mean (SD) | 139.6 (13.7) | 139.1 (11.5) | 160.3 (4.4) | 163.5 (8.9) | 147.9 (14.9) | 149.7 (16.0)
Median (Min-Max) | 137.8 (117.5, 164.9) | 139.5 (120.0, 156.3) | 160.0 (154.5, 173.0) | 163.2 (145.6, 178.1) | 153.1 (117.5, 173.0) | 149.3 (120.0, 178.1)
Change from Baseline to LOCF
N | 30 | 13 | 20 | 10 | 50 | 23
Mean (SD) | 0.3 (0.6) | 0.9 (1.0) | 0.5 (0.9) | 0.8 (0.9) | 0.4 (0.8) | 0.8 (1.0)
Median (Min-Max) | 0.2 (−1.3, 1.8) | 1.0 (−0.6, 3.0) | 0.5 (−1.1, 2.9) | 0.5 (−0.1, 2.4) | 0.3 (−1.3, 2.9) | 0.6 (−0.6, 3.0)

Note: Baseline is defined as first visit of Efficacy phase.

Table 14.3.4.1.9 Summary of Vital Signs by Visit, Age Strata and Efficacy Phase Treatment Received Group Height Z Score Efficacy Phase - Safety Population

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 0.39 (1.17) | 0.65 (0.94) | −0.49 (0.78) | 0.25 (0.89) | 0.04 (1.11) | 0.49 (0.92)
Median (Min-Max) | 0.45 (−2.15, 2.24) | 0.95 (−1.18, 2.32) | −0.39 (−3.22, 0.57) | −0.05 (−1.75, 1.52) | −0.20 (−3.22, 2.24) | 0.43 (−1.75, 2.32)
LOCF
N | 30 | 13 | 20 | 10 | 50 | 23
Mean (SD) | 0.31 (1.22) | 0.50 (0.92) | −0.33 (0.47) | 0.31 (0.91) | 0.05 (1.03) | 0.42 (0.90)
Median (Min-Max) | 0.36 (−2.21, 2.11) | 0.42 (−1.35, 1.77) | −0.45 (−1.15, 0.77) | 0.29 (−1.82, 1.38) | −0.21 (−2.21, 2.11) | 0.41 (−1.82, 1.77)
Change from Baseline to LOCF
N | 30 | 13 | 20 | 10 | 50 | 23
Mean (SD) | −0.07 (0.10) | 0.02 (0.14) | 0.02 (0.11) | 0.03 (0.14) | −0.04 (0.12) | 0.02 (0.14)
Median (Min-Max) | −0.09 (−0.31, 0.16) | 0.04 (−0.25, 0.31) | 0.02 (−0.17, 0.22) | 0.01 (−0.16, 0.22) | −0.07 (−0.31, 0.22) | 0.02 (−0.25, 0.31)

Note: Baseline is defined as first visit of Efficacy phase.

Table 14.3.4.1.10 Summary of Vital Signs by Visit, Age Strata and Efficacy Phase Treatment Received Group BMI Efficacy Phase - Safety Population

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 21.6 (6.6) | 21.8 (5.1) | 24.2 (7.6) | 24.4 (5.4) | 22.6 (7.1) | 22.9 (5.3)
Median (Min-Max) | 19.4 (13.8, 36.2) | 20.9 (14.9, 31.5) | 20.8 (15.4, 41.2) | 22.0 (17.5, 34.7) | 20.4 (13.8, 41.2) | 21.9 (14.9, 34.7)
LOCF
N | 30 | 13 | 20 | 10 | 50 | 23
Mean (SD) | 22.1 (6.7) | 20.9 (5.2) | 24.5 (7.7) | 25.3 (5.6) | 23.0 (7.1) | 22.8 (5.7)
Median (Min-Max) | 20.2 (14.1, 37.0) | 19.2 (15.8, 32.0) | 22.2 (15.2, 41.8) | 22.8 (18.5, 35.3) | 20.7 (14.1, 41.8) | 22.4 (15.8, 35.3)
Change from Baseline to LOCF
N | 30 | 13 | 20 | 10 | 50 | 23
Mean (SD) | 0.5 (0.9) | 0.0 (0.8) | 0.0 (0.7) | 0.4 (0.6) | 0.3 (0.8) | 0.2 (0.8)
Median (Min-Max) | 0.6 (−1.1, 2.2) | −0.1 (−1.1, 1.8) | 0.0 (−1.4, 1.5) | 0.5 (−0.6, 1.6) | 0.3 (−1.4, 2.2) | 0.4 (−1.1, 1.8)

Note: Baseline is defined as first visit of Efficacy phase.

Table 14.3.4.1.11 Summary of Vital Signs by Visit, Age Strata and Efficacy Phase Treatment Received Group BMI Z Score Efficacy Phase - Safety Population

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline
N | 32 | 17 | 21 | 11 | 53 | 28
Mean (SD) | 0.93 (1.22) | 1.32 (1.00) | 0.69 (1.21) | 0.97 (0.91) | 0.84 (1.21) | 1.18 (0.96)
Median (Min-Max) | 1.09 (−1.63, 2.70) | 1.48 (−0.67, 2.57) | 0.49 (−1.69, 2.76) | 0.92 (−0.53, 2.44) | 0.96 (−1.69, 2.76) | 1.22 (−0.67, 2.57)
LOCF
N | 30 | 13 | 20 | 10 | 50 | 23
Mean (SD) | 1.06 (1.16) | 1.07 (0.93) | 0.69 (1.28) | 1.18 (0.76) | 0.91 (1.21) | 1.12 (0.84)
Median (Min-Max) | 1.14 (−1.35, 2.70) | 0.54 (−0.06, 2.49) | 0.65 (−1.93, 2.75) | 1.03 (−0.12, 2.47) | 1.07 (−1.93, 2.75) | 1.00 (−0.12, 2.49)
Change from Baseline to LOCF
N | 30 | 13 | 20 | 10 | 50 | 23
Mean (SD) | 0.16 (0.33) | 0.01 (0.24) | −0.02 (0.18) | 0.07 (0.16) | 0.09 (0.29) | 0.03 (0.21)
Median (Min-Max) | 0.08 (−0.44, 1.03) | −0.05 (−0.36, 0.61) | −0.02 (−0.36, 0.45) | 0.05 (−0.15, 0.41) | 0.01 (−0.44, 1.03) | 0.03 (−0.36, 0.61)

Note: Baseline is defined as first visit of Efficacy phase.

Table 14.3.4.2.1A Summary of Vital Signs by Visit and Age Strata Heart Rate (beats/min) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 82.5 (14.2) | 79.9 (12.7) | 81.6 (13.6)
Median (Min-Max) | 83.0 (51.0, 112.0) | 82.0 (57.0, 101.0) | 83.0 (51.0, 112.0)
Week 1
N | 24 | 13 | 37
Mean (SD) | 87.7 (12.2) | 81.9 (15.2) | 85.6 (13.4)
Median (Min-Max) | 89.0 (50.0, 104.0) | 80.0 (58.0, 112.0) | 86.0 (50.0, 112.0)
Week 2
N | 29 | 14 | 43
Mean (SD) | 86.1 (14.3) | 85.0 (12.8) | 85.7 (13.7)
Median (Min-Max) | 84.0 (48.0, 110.0) | 88.0 (60.0, 109.0) | 86.0 (48.0, 110.0)
Week 4
N | 24 | 13 | 37
Mean (SD) | 87.5 (14.1) | 79.4 (10.5) | 84.6 (13.4)
Median (Min-Max) | 90.5 (50.0, 110.0) | 80.0 (60.0, 94.0) | 88.0 (50.0, 110.0)
Week 6
N | 25 | 13 | 38
Mean (SD) | 85.3 (15.4) | 81.6 (10.8) | 84.0 (14.0)
Median (Min-Max) | 86.0 (51.0, 108.0) | 80.0 (62.0, 100.0) | 83.5 (51.0, 108.0)
Week 8
N | 24 | 12 | 36
Mean (SD) | 85.8 (16.2) | 84.2 (12.7) | 85.3 (15.0)
Median (Min-Max) | 90.0 (50.0, 110.0) | 88.5 (61.0, 98.0) | 90.0 (50.0, 110.0)
Week 10
N | 23 | 9 | 32
Mean (SD) | 85.5 (16.7) | 88.8 (19.7) | 86.4 (17.3)
Median (Min-Max) | 85.0 (54.0, 117.0) | 97.0 (60.0, 108.0) | 87.5 (54.0, 117.0)
Week 12
N | 24 | 7 | 31
Mean (SD) | 81.5 (14.8) | 83.9 (14.2) | 82.1 (14.5)
Median (Min-Max) | 84.0 (50.0, 110.0) | 89.0 (64.0, 100.0) | 84.0 (50.0, 110.0)
Week 14
N | 20 | 7 | 27
Mean (SD) | 84.4 (14.6) | 80.0 (18.3) | 83.2 (15.4)
Median (Min-Max) | 85.5 (47.0, 108.0) | 76.0 (55.0, 106.0) | 84.0 (47.0, 108.0)
Week 16
N | 20 | 7 | 27
Mean (SD) | 87.7 (17.2) | 82.0 (18.4) | 86.2 (17.3)
Median (Min-Max) | 89.5 (42.0, 122.0) | 84.0 (54.0, 108.0) | 88.0 (42.0, 122.0)
Week 18
N | 20 | 7 | 27
Mean (SD) | 86.2 (15.7) | 79.3 (13.8) | 84.4 (15.3)
Median (Min-Max) | 87.5 (49.0, 107.0) | 83.0 (49.0, 90.0) | 85.0 (49.0, 107.0)
Week 20
N | 18 | 6 | 24
Mean (SD) | 83.7 (14.9) | 89.7 (16.6) | 85.2 (15.2)
Median (Min-Max) | 88.0 (56.0, 112.0) | 94.5 (58.0, 104.0) | 88.0 (56.0, 112.0)
Week 22
N | 17 | 5 | 22
Mean (SD) | 85.8 (17.4) | 79.0 (13.6) | 84.3 (16.6)
Median (Min-Max) | 86.0 (58.0, 113.0) | 84.0 (64.0, 96.0) | 84.5 (58.0, 113.0)
Week 24
N | 17 | 6 | 23
Mean (SD) | 80.3 (18.2) | 72.7 (13.4) | 78.3 (17.1)
Median (Min-Max) | 88.0 (45.0, 109.0) | 75.5 (49.0, 84.0) | 84.0 (45.0, 109.0)
LOCF
N | 28 | 14 | 42
Mean (SD) | 83.7 (17.7) | 77.6 (15.2) | 81.7 (17.0)
Median (Min-Max) | 88.0 (45.0, 112.0) | 79.5 (49.0, 118.0) | 84.0 (45.0, 118.0)
Change from Baseline to LOCF
N | 28 | 14 | 42
Mean (SD) | 1.3 (13.3) | −2.0 (13.4) | 0.2 (13.3)
Median (Min-Max) | 0.5 (−26.0, 26.0) | −3.0 (−20.0, 22.0) | 0.0 (−26.0, 26.0)

Note: Baseline is defined as Last visit of Efficacy phase.

Table 14.3.4.2.2A Summary of Vital Signs by Visit and Age Strata Systolic Blood Pressure (mmHg) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 108.3 (13.0) | 112.1 (16.9) | 109.6 (14.3)
Median (Min-Max) | 107.0 (86.0, 135.0) | 110.0 (90.0, 151.0) | 109.0 (86.0, 151.0)
Week 1
N | 24 | 13 | 37
Mean (SD) | 109.3 (9.9) | 109.4 (11.4) | 109.3 (10.3)
Median (Min-Max) | 107.0 (96.0, 133.0) | 110.0 (90.0, 133.0) | 110.0 (90.0, 133.0)
Week 2
N | 29 | 14 | 43
Mean (SD) | 108.6 (9.6) | 110.9 (14.3) | 109.3 (11.2)
Median (Min-Max) | 110.0 (92.0, 130.0) | 111.0 (88.0, 137.0) | 110.0 (88.0, 137.0)
Week 4
N | 24 | 13 | 37
Mean (SD) | 108.5 (10.2) | 107.4 (11.1) | 108.1 (10.4)
Median (Min-Max) | 110.0 (91.0, 126.0) | 108.0 (88.0, 125.0) | 108.0 (88.0, 126.0)
Week 6
N | 25 | 13 | 38
Mean (SD) | 108.2 (12.0) | 109.3 (12.2) | 108.6 (11.9)
Median (Min-Max) | 114.0 (82.0, 125.0) | 110.0 (95.0, 134.0) | 111.0 (82.0, 134.0)
Week 8
N | 24 | 12 | 36
Mean (SD) | 110.0 (12.5) | 114.3 (13.7) | 111.5 (12.9)
Median (Min-Max) | 112.0 (80.0, 133.0) | 115.0 (98.0, 142.0) | 113.5 (80.0, 142.0)
Week 10
N | 23 | 9 | 32
Mean (SD) | 109.1 (9.9) | 117.2 (16.5) | 111.4 (12.4)
Median (Min-Max) | 110.0 (87.0, 127.0) | 110.0 (100.0, 139.0) | 110.0 (87.0, 139.0)
Week 12
N | 24 | 7 | 31
Mean (SD) | 106.8 (13.7) | 115.1 (18.1) | 108.7 (14.9)
Median (Min-Max) | 106.5 (75.0, 126.0) | 121.0 (93.0, 140.0) | 107.0 (75.0, 140.0)
Week 14
N | 20 | 7 | 27
Mean (SD) | 108.6 (9.6) | 111.3 (19.8) | 109.3 (12.6)
Median (Min-Max) | 109.5 (91.0, 125.0) | 110.0 (88.0, 143.0) | 110.0 (88.0, 143.0)
Week 16
N | 20 | 7 | 27
Mean (SD) | 106.9 (10.0) | 119.3 (22.3) | 110.1 (14.8)
Median (Min-Max) | 105.0 (84.0, 123.0) | 113.0 (96.0, 158.0) | 108.0 (84.0, 158.0)
Week 18
N | 20 | 7 | 27
Mean (SD) | 109.2 (10.5) | 115.9 (19.2) | 110.9 (13.2)
Median (Min-Max) | 110.0 (86.0, 128.0) | 113.0 (90.0, 144.0) | 111.0 (86.0, 144.0)
Week 20
N | 18 | 6 | 24
Mean (SD) | 110.4 (9.7) | 110.5 (17.6) | 110.5 (11.7)
Median (Min-Max) | 112.5 (85.0, 128.0) | 105.0 (90.0, 138.0) | 111.5 (85.0, 138.0)
Week 22
N | 17 | 5 | 22
Mean (SD) | 109.6 (9.8) | 109.2 (10.4) | 109.5 (9.6)
Median (Min-Max) | 109.0 (93.0, 132.0) | 107.0 (96.0, 122.0) | 109.0 (93.0, 132.0)
Week 24
N | 17 | 6 | 23
Mean (SD) | 108.4 (13.0) | 114.7 (14.3) | 110.0 (13.3)
Median (Min-Max) | 110.0 (84.0, 128.0) | 115.0 (92.0, 132.0) | 111.0 (84.0, 132.0)
LOCF
N | 28 | 14 | 42
Mean (SD) | 110.5 (12.0) | 113.6 (12.6) | 111.5 (12.1)
Median (Min-Max) | 114.5 (84.0, 128.0) | 114.0 (92.0, 135.0) | 114.5 (84.0, 135.0)
Change from Baseline to LOCF
N | 28 | 14 | 42
Mean (SD) | 2.4 (14.0) | 1.1 (12.6) | 2.0 (13.4)
Median (Min-Max) | 2.0 (−38.0, 36.0) | 2.0 (−25.0, 25.0) | 2.0 (−38.0, 36.0)

Note: Baseline is defined as Last visit of Efficacy phase.

Table 14.3.4.2.3A Summary of Vital Signs by Visit and Age Strata Systolic Blood Pressure Z Score Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 0.62 (1.14) | 0.11 (1.46) | 0.45 (1.26)
Median (Min-Max) | 0.74 (−1.37, 3.24) | −0.02 (−1.88, 3.28) | 0.40 (−1.88, 3.28)
Week 1
N | 24 | 13 | 37
Mean (SD) | 0.68 (0.86) | −0.13 (0.98) | 0.40 (0.97)
Median (Min-Max) | 0.54 (−0.53, 2.80) | 0.09 (−1.86, 1.58) | 0.34 (−1.86, 2.80)
Week 2
N | 29 | 14 | 43
Mean (SD) | 0.61 (0.80) | 0.01 (1.17) | 0.41 (0.96)
Median (Min-Max) | 0.52 (−0.62, 2.51) | 0.19 (−2.05, 1.96) | 0.36 (−2.05, 2.51)
Week 4
N | 24 | 13 | 37
Mean (SD) | 0.56 (0.90) | −0.34 (0.88) | 0.25 (0.98)
Median (Min-Max) | 0.67 (−0.91, 2.37) | −0.27 (−2.09, 0.82) | 0.20 (−2.09, 2.37)
Week 6
N | 25 | 13 | 38
Mean (SD) | 0.57 (1.11) | −0.17 (0.99) | 0.32 (1.11)
Median (Min-Max) | 0.97 (−1.76, 2.48) | −0.04 (−1.50, 1.66) | 0.22 (−1.76, 2.48)
Week 8
N | 24 | 12 | 36
Mean (SD) | 0.76 (1.15) | 0.29 (1.10) | 0.60 (1.14)
Median (Min-Max) | 0.90 (−1.95, 2.72) | 0.54 (−1.12, 2.39) | 0.63 (−1.95, 2.72)
Week 10
N | 23 | 9 | 32
Mean (SD) | 0.63 (0.98) | 0.50 (1.32) | 0.60 (1.06)
Median (Min-Max) | 0.56 (−1.30, 2.48) | −0.03 (−0.99, 2.12) | 0.55 (−1.30, 2.48)
Week 12
N | 24 | 7 | 31
Mean (SD) | 0.41 (1.22) | 0.29 (1.50) | 0.38 (1.26)
Median (Min-Max) | 0.37 (−2.28, 2.47) | 1.13 (−1.68, 2.20) | 0.40 (−2.28, 2.47)
Week 14
N | 20 | 7 | 27
Mean (SD) | 0.58 (0.90) | −0.08 (1.60) | 0.41 (1.13)
Median (Min-Max) | 0.50 (−0.94, 2.24) | 0.09 (−2.14, 2.46) | 0.30 (−2.14, 2.46)
Week 16
N | 20 | 7 | 27
Mean (SD) | 0.45 (0.90) | 0.66 (1.87) | 0.51 (1.19)
Median (Min-Max) | 0.30 (−1.60, 2.04) | 0.22 (−1.40, 3.85) | 0.30 (−1.60, 3.85)
Week 18
N | 20 | 7 | 27
Mean (SD) | 0.61 (0.92) | 0.34 (1.54) | 0.54 (1.09)
Median (Min-Max) | 0.56 (−1.42, 2.51) | 0.38 (−1.97, 2.53) | 0.52 (−1.97, 2.53)
Week 20
N | 18 | 6 | 24
Mean (SD) | 0.70 (0.89) | −0.22 (1.39) | 0.47 (1.08)
Median (Min-Max) | 0.72 (−1.52, 2.45) | −0.52 (−1.97, 1.96) | 0.60 (−1.97, 2.45)
Week 22
N | 17 | 5 | 22
Mean (SD) | 0.61 (0.82) | −0.36 (0.71) | 0.39 (0.89)
Median (Min-Max) | 0.54 (−0.78, 2.65) | −0.34 (−1.43, 0.48) | 0.29 (−1.43, 2.65)
Week 24
N | 17 | 6 | 23
Mean (SD) | 0.50 (1.17) | 0.18 (1.15) | 0.42 (1.15)
Median (Min-Max) | 0.27 (−1.55, 2.89) | 0.37 (−1.82, 1.41) | 0.27 (−1.82, 2.89)
LOCF
N | 28 | 14 | 42
Mean (SD) | 0.77 (1.09) | 0.23 (1.07) | 0.59 (1.10)
Median (Min-Max) | 1.03 (−1.55, 2.89) | 0.42 (−1.82, 2.13) | 0.65 (−1.82, 2.89)
Change from Baseline to LOCF
N | 28 | 14 | 42
Mean (SD) | 0.18 (1.33) | 0.07 (1.21) | 0.14 (1.28)
Median (Min-Max) | 0.12 (−3.60, 3.42) | 0.12 (−2.40, 2.44) | 0.12 (−3.60, 3.42)

Note: Baseline is defined as Last visit of Efficacy phase.

Baseline Height is used to calculate all BP Z scores except LOCF visit, which used the height collected at that visit.

Table 14.3.4.2.4A Summary of Vital Signs by Visit and Age Strata Diastolic Blood Pressure (mmHg) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 63.6 (11.0) | 68.7 (9.6) | 65.4 (10.7)
Median (Min-Max) | 64.0 (39.0, 90.0) | 68.0 (48.0, 87.0) | 65.5 (39.0, 90.0)
Week 1
N | 24 | 13 | 37
Mean (SD) | 65.3 (8.3) | 66.5 (7.9) | 65.7 (8.1)
Median (Min-Max) | 66.5 (44.0, 78.0) | 68.0 (48.0, 78.0) | 67.0 (44.0, 78.0)
Week 2
N | 29 | 14 | 43
Mean (SD) | 67.4 (12.7) | 67.1 (8.5) | 67.3 (11.4)
Median (Min-Max) | 68.0 (48.0, 112.0) | 66.0 (56.0, 85.0) | 68.0 (48.0, 112.0)
Week 4
N | 24 | 13 | 37
Mean (SD) | 64.6 (8.7) | 68.5 (6.9) | 66.0 (8.2)
Median (Min-Max) | 64.0 (41.0, 80.0) | 66.0 (60.0, 81.0) | 65.0 (41.0, 81.0)
Week 6
N | 25 | 13 | 38
Mean (SD) | 65.8 (10.6) | 67.3 (8.6) | 66.3 (9.9)
Median (Min-Max) | 68.0 (44.0, 90.0) | 67.0 (56.0, 83.0) | 67.5 (44.0, 90.0)
Week 8
N | 24 | 12 | 36
Mean (SD) | 65.9 (10.9) | 71.7 (8.5) | 67.8 (10.4)
Median (Min-Max) | 64.5 (50.0, 86.0) | 70.0 (60.0, 83.0) | 67.5 (50.0, 86.0)
Week 10
N | 23 | 9 | 32
Mean (SD) | 65.9 (9.8) | 69.9 (11.4) | 67.0 (10.3)
Median (Min-Max) | 65.0 (47.0, 85.0) | 69.0 (56.0, 92.0) | 66.5 (47.0, 92.0)
Week 12
N | 24 | 7 | 31
Mean (SD) | 66.4 (12.2) | 69.6 (10.5) | 67.1 (11.8)
Median (Min-Max) | 67.5 (38.0, 90.0) | 70.0 (59.0, 84.0) | 68.0 (38.0, 90.0)
Week 14
N | 20 | 7 | 27
Mean (SD) | 65.5 (10.7) | 65.3 (11.5) | 65.4 (10.7)
Median (Min-Max) | 68.0 (37.0, 80.0) | 70.0 (48.0, 83.0) | 68.0 (37.0, 83.0)
Week 16
N | 20 | 7 | 27
Mean (SD) | 65.8 (8.7) | 69.7 (7.7) | 66.8 (8.5)
Median (Min-Max) | 68.0 (50.0, 80.0) | 69.0 (58.0, 81.0) | 68.0 (50.0, 81.0)
Week 18
N | 20 | 7 | 27
Mean (SD) | 67.7 (9.7) | 69.0 (9.7) | 68.0 (9.5)
Median (Min-Max) | 70.0 (48.0, 84.0) | 70.0 (58.0, 82.0) | 70.0 (48.0, 84.0)
Week 20
N | 18 | 6 | 24
Mean (SD) | 67.8 (8.1) | 67.0 (8.3) | 67.6 (8.0)
Median (Min-Max) | 66.5 (54.0, 80.0) | 68.5 (57.0, 79.0) | 67.5 (54.0, 80.0)
Week 22
N | 17 | 5 | 22
Mean (SD) | 67.3 (8.2) | 70.2 (6.5) | 68.0 (7.8)
Median (Min-Max) | 67.0 (53.0, 86.0) | 68.0 (64.0, 79.0) | 67.5 (53.0, 86.0)
Week 24
N | 17 | 6 | 23
Mean (SD) | 63.8 (8.6) | 71.7 (9.2) | 65.9 (9.3)
Median (Min-Max) | 62.0 (52.0, 80.0) | 72.5 (56.0, 81.0) | 68.0 (52.0, 81.0)
LOCF
N | 28 | 14 | 42
Mean (SD) | 65.8 (9.2) | 70.9 (8.2) | 67.5 (9.1)
Median (Min-Max) | 68.0 (50.0, 80.0) | 70.5 (56.0, 83.0) | 69.5 (50.0, 83.0)
Change from Baseline to LOCF
N | 28 | 14 | 42
Mean (SD) | 2.4 (8.5) | 1.9 (10.6) | 2.2 (9.1)
Median (Min-Max) | 1.5 (−13.0, 23.0) | −1.0 (−13.0, 26.0) | 1.0 (−13.0, 26.0)

Note: Baseline is defined as Last visit of Efficacy phase.

Table 14.3.4.2.5A Summary of Vital Signs by Visit and Age Strata Diastolic Blood Pressure Z Score Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 0.27 (0.96) | 0.37 (0.87) | 0.30 (0.92)
Median (Min-Max) | 0.32 (−2.07, 2.63) | 0.32 (−1.52, 1.97) | 0.32 (−2.07, 2.63)
Week 1
N | 24 | 13 | 37
Mean (SD) | 0.41 (0.72) | 0.16 (0.68) | 0.32 (0.70)
Median (Min-Max) | 0.37 (−1.33, 1.66) | 0.28 (−1.28, 1.18) | 0.34 (−1.33, 1.66)
Week 2
N | 29 | 14 | 43
Mean (SD) | 0.58 (1.10) | 0.21 (0.73) | 0.46 (1.00)
Median (Min-Max) | 0.43 (−0.99, 4.46) | 0.28 (−0.78, 1.63) | 0.43 (−0.99, 4.46)
Week 4
N | 24 | 13 | 37
Mean (SD) | 0.32 (0.77) | 0.34 (0.55) | 0.33 (0.70)
Median (Min-Max) | 0.23 (−1.59, 1.76) | 0.15 (−0.49, 1.33) | 0.15 (−1.59, 1.76)
Week 6
N | 25 | 13 | 38
Mean (SD) | 0.45 (0.94) | 0.22 (0.76) | 0.37 (0.88)
Median (Min-Max) | 0.43 (−1.34, 2.62) | 0.19 (−0.60, 1.81) | 0.40 (−1.34, 2.62)
Week 8
N | 24 | 12 | 36
Mean (SD) | 0.46 (0.97) | 0.62 (0.67) | 0.51 (0.88)
Median (Min-Max) | 0.32 (−1.05, 2.30) | 0.45 (−0.30, 1.58) | 0.44 (−1.05, 2.30)
Week 10
N | 23 | 9 | 32
Mean (SD) | 0.44 (0.87) | 0.44 (0.93) | 0.44 (0.87)
Median (Min-Max) | 0.39 (−1.21, 2.19) | 0.44 (−0.60, 2.20) | 0.42 (−1.21, 2.20)
Week 12
N | 24 | 7 | 31
Mean (SD) | 0.48 (1.05) | 0.40 (0.86) | 0.47 (1.00)
Median (Min-Max) | 0.55 (−1.86, 2.61) | 0.53 (−0.61, 1.51) | 0.54 (−1.86, 2.61)
Week 14
N | 20 | 7 | 27
Mean (SD) | 0.41 (0.91) | 0.03 (0.90) | 0.31 (0.90)
Median (Min-Max) | 0.48 (−1.95, 1.75) | 0.35 (−1.30, 1.41) | 0.40 (−1.95, 1.75)
Week 16
N | 20 | 7 | 27
Mean (SD) | 0.45 (0.84) | 0.42 (0.63) | 0.44 (0.78)
Median (Min-Max) | 0.50 (−0.98, 1.96) | 0.38 (−0.60, 1.23) | 0.41 (−0.98, 1.96)
Week 18
N | 20 | 7 | 27
Mean (SD) | 0.59 (0.84) | 0.35 (0.75) | 0.53 (0.81)
Median (Min-Max) | 0.75 (−1.01, 1.86) | 0.48 (−0.51, 1.37) | 0.55 (−1.01, 1.86)
Week 20
N | 18 | 6 | 24
Mean (SD) | 0.59 (0.77) | 0.15 (0.70) | 0.48 (0.76)
Median (Min-Max) | 0.47 (−0.57, 1.92) | 0.42 (−0.78, 1.04) | 0.43 (−0.78, 1.92)
Week 22
N | 17 | 5 | 22
Mean (SD) | 0.53 (0.72) | 0.43 (0.49) | 0.51 (0.67)
Median (Min-Max) | 0.48 (−0.73, 2.08) | 0.30 (−0.10, 1.03) | 0.47 (−0.73, 2.08)
Week 24
N | 17 | 6 | 23
Mean (SD) | 0.23 (0.78) | 0.59 (0.71) | 0.32 (0.76)
Median (Min-Max) | 0.31 (−1.06, 2.03) | 0.64 (−0.63, 1.34) | 0.33 (−1.06, 2.03)
LOCF
N | 28 | 14 | 42
Mean (SD) | 0.43 (0.83) | 0.55 (0.67) | 0.47 (0.77)
Median (Min-Max) | 0.51 (−1.07, 2.03) | 0.53 (−0.63, 1.60) | 0.53 (−1.07, 2.03)
Change from Baseline to LOCF
N | 28 | 14 | 42
Mean (SD) | 0.19 (0.76) | 0.15 (0.93) | 0.18 (0.81)
Median (Min-Max) | 0.10 (−1.16, 2.03) | −0.10 (−1.16, 2.21) | 0.07 (−1.16, 2.21)

Note: Baseline is defined as Last visit of Efficacy phase.

Baseline Height is used to calculate all BP Z scores except LOCF visit, which used the height collected at that visit.

Table 14.3.4.2.6A Summary of Vital Signs by Visit and Age Strata Weight (kg) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 41.7 (18.4) | 67.5 (21.7) | 50.5 (23.0)
Median (Min-Max) | 38.5 (24.0, 95.2) | 60.3 (45.0, 115.7) | 46.2 (24.0, 115.7)
Week 1
N | 24 | 13 | 37
Mean (SD) | 43.4 (19.7) | 67.4 (19.6) | 51.8 (22.6)
Median (Min-Max) | 39.8 (25.0, 98.9) | 63.0 (45.5, 115.7) | 46.3 (25.0, 115.7)
Week 2
N | 29 | 14 | 43
Mean (SD) | 42.2 (18.8) | 66.3 (20.0) | 50.1 (22.2)
Median (Min-Max) | 38.3 (25.0, 97.7) | 62.8 (43.6, 117.5) | 46.5 (25.0, 117.5)
Week 4
N | 24 | 13 | 37
Mean (SD) | 45.4 (19.4) | 66.3 (20.2) | 52.8 (21.9)
Median (Min-Max) | 40.2 (26.3, 98.4) | 63.0 (45.4, 117.1) | 48.8 (26.3, 117.1)
Week 6
N | 25 | 13 | 38
Mean (SD) | 44.1 (19.0) | 67.0 (20.3) | 51.9 (22.1)
Median (Min-Max) | 39.3 (24.3, 95.0) | 63.7 (45.5, 118.8) | 47.8 (24.3, 118.8)
Week 8
N | 24 | 12 | 36
Mean (SD) | 43.6 (19.5) | 67.0 (20.7) | 51.4 (22.6)
Median (Min-Max) | 38.7 (25.0, 97.3) | 62.9 (45.0, 117.9) | 47.4 (25.0, 117.9)
Week 10
N | 23 | 9 | 32
Mean (SD) | 44.3 (19.2) | 71.6 (21.4) | 52.0 (23.2)
Median (Min-Max) | 39.4 (26.0, 96.8) | 63.5 (51.2, 117.5) | 47.0 (26.0, 117.5)
Week 12
N | 24 | 7 | 31
Mean (SD) | 45.2 (19.2) | 73.5 (24.7) | 51.6 (23.4)
Median (Min-Max) | 39.9 (26.5, 96.8) | 62.1 (50.9, 118.2) | 46.9 (26.5, 118.2)
Week 14
N | 20 | 7 | 27
Mean (SD) | 45.1 (20.2) | 73.6 (23.8) | 52.5 (24.3)
Median (Min-Max) | 38.7 (25.3, 97.4) | 61.6 (52.3, 116.4) | 47.1 (25.3, 116.4)
Week 16
N | 20 | 7 | 27
Mean (SD) | 43.4 (17.1) | 74.6 (24.1) | 51.5 (23.3)
Median (Min-Max) | 38.5 (25.4, 88.4) | 62.5 (52.4, 117.6) | 47.3 (25.4, 117.6)
Week 18
N | 20 | 7 | 27
Mean (SD) | 47.0 (20.5) | 74.4 (23.5) | 54.1 (24.2)
Median (Min-Max) | 43.4 (25.1, 94.5) | 62.5 (52.8, 116.1) | 48.4 (25.1, 116.1)
Week 20
N | 18 | 6 | 24
Mean (SD) | 48.8 (21.4) | 72.3 (25.1) | 54.7 (24.1)
Median (Min-Max) | 46.8 (24.9, 94.1) | 62.6 (51.2, 116.4) | 50.3 (24.9, 116.4)
Week 22
N | 17 | 5 | 22
Mean (SD) | 48.8 (21.9) | 76.4 (26.2) | 55.1 (25.3)
Median (Min-Max) | 45.6 (25.0, 94.1) | 63.7 (51.4, 116.7) | 48.7 (25.0, 116.7)
Week 24
N | 17 | 6 | 23
Mean (SD) | 48.8 (22.3) | 72.1 (24.7) | 54.9 (24.7)
Median (Min-Max) | 46.0 (24.9, 94.8) | 62.9 (51.7, 115.3) | 50.0 (24.9, 115.3)
LOCF
N | 28 | 14 | 42
Mean (SD) | 43.8 (19.4) | 67.6 (18.6) | 51.7 (22.1)
Median (Min-Max) | 38.1 (23.8, 94.8) | 64.5 (45.0, 115.3) | 48.0 (23.8, 115.3)
Change from Baseline to LOCF
N | 28 | 14 | 42
Mean (SD) | 1.6 (3.0) | 2.8 (2.6) | 2.0 (2.9)
Median (Min-Max) | 2.0 (−5.3, 10.2) | 3.7 (−2.8, 6.0) | 2.3 (−5.3, 10.2)

Note: Baseline is defined as Last visit of Efficacy phase.

Table 14.3.4.2.7A Summary of Vital Signs by Visit and Age Strata Weight Z Score Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 1.09 (1.11) | 1.03 (1.22) | 1.07 (1.14)
Median (Min-Max) | 0.57 (−0.20, 3.26) | 1.01 (−0.97, 3.01) | 0.77 (−0.97, 3.26)
Week 1
N | 24 | 13 | 37
Mean (SD) | 1.11 (1.13) | 1.03 (1.13) | 1.08 (1.12)
Median (Min-Max) | 0.89 (−0.36, 3.25) | 1.12 (−0.86, 2.74) | 1.03 (−0.86, 3.25)
Week 2
N | 29 | 14 | 43
Mean (SD) | 1.11 (1.13) | 0.98 (1.16) | 1.07 (1.12)
Median (Min-Max) | 0.85 (−0.57, 3.29) | 1.09 (−1.11, 2.78) | 0.93 (−1.11, 3.29)
Week 4
N | 24 | 13 | 37
Mean (SD) | 1.29 (1.13) | 0.92 (1.11) | 1.16 (1.12)
Median (Min-Max) | 0.95 (−0.14, 3.26) | 1.02 (−0.92, 2.77) | 1.02 (−0.92, 3.26)
Week 6
N | 25 | 13 | 38
Mean (SD) | 1.19 (1.15) | 0.95 (1.10) | 1.11 (1.12)
Median (Min-Max) | 0.93 (−0.31, 3.24) | 1.03 (−0.91, 2.80) | 1.02 (−0.91, 3.24)
Week 8
N | 24 | 12 | 36
Mean (SD) | 1.12 (1.15) | 0.92 (1.15) | 1.05 (1.14)
Median (Min-Max) | 0.80 (−0.39, 3.24) | 1.01 (−1.03, 2.78) | 0.90 (−1.03, 3.24)
Week 10
N | 23 | 9 | 32
Mean (SD) | 1.14 (1.14) | 1.30 (0.89) | 1.19 (1.07)
Median (Min-Max) | 0.79 (−0.58, 3.27) | 0.96 (−0.01, 2.77) | 0.96 (−0.58, 3.27)
Week 12
N | 24 | 7 | 31
Mean (SD) | 1.21 (1.14) | 1.29 (1.05) | 1.23 (1.10)
Median (Min-Max) | 0.98 (−0.44, 3.26) | 1.00 (−0.08, 2.77) | 1.00 (−0.44, 3.26)
Week 14
N | 20 | 7 | 27
Mean (SD) | 1.18 (1.06) | 1.31 (1.00) | 1.21 (1.03)
Median (Min-Max) | 1.01 (−0.37, 3.24) | 1.05 (0.09, 2.72) | 1.05 (−0.37, 3.24)
Week 16
N | 20 | 7 | 27
Mean (SD) | 1.16 (1.07) | 1.34 (1.01) | 1.21 (1.04)
Median (Min-Max) | 0.91 (−0.34, 3.27) | 1.13 (0.03, 2.74) | 1.03 (−0.34, 3.27)
Week 18
N | 20 | 7 | 27
Mean (SD) | 1.29 (1.18) | 1.33 (0.99) | 1.30 (1.11)
Median (Min-Max) | 1.17 (−0.44, 3.27) | 1.17 (0.07, 2.69) | 1.17 (−0.44, 3.27)
Week 20
N | 18 | 6 | 24
Mean (SD) | 1.31 (1.23) | 1.18 (1.05) | 1.28 (1.17)
Median (Min-Max) | 1.18 (−0.50, 3.31) | 0.93 (−0.14, 2.69) | 1.18 (−0.50, 3.31)
Week 22
N | 17 | 5 | 22
Mean (SD) | 1.23 (1.28) | 1.33 (1.12) | 1.25 (1.22)
Median (Min-Max) | 1.06 (−0.53, 3.27) | 1.20 (−0.12, 2.69) | 1.13 (−0.53, 3.27)
Week 24
N | 17 | 6 | 23
Mean (SD) | 1.21 (1.26) | 1.15 (1.04) | 1.20 (1.19)
Median (Min-Max) | 1.13 (−0.57, 3.27) | 0.94 (−0.13, 2.64) | 1.13 (−0.57, 3.27)
LOCF
N | 28 | 14 | 42
Mean (SD) | 1.07 (1.13) | 1.01 (1.09) | 1.05 (1.11)
Median (Min-Max) | 0.86 (−0.57, 3.27) | 1.20 (−1.03, 2.64) | 1.01 (−1.03, 3.27)
Change from Baseline to LOCF
N | 28 | 14 | 42
Mean (SD) | −0.04 (0.33) | 0.12 (0.16) | 0.01 (0.29)
Median (Min-Max) | −0.04 (−0.62, 0.77) | 0.17 (−0.13, 0.34) | 0.02 (−0.62, 0.77)

Note: Baseline is defined as Last visit of Efficacy phase.

Table 14.3.4.2.8A Summary of Vital Signs by Visit and Age Strata Height (cm) Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 137.3 (10.9) | 162.8 (6.2) | 146.0 (15.5)
Median (Min-Max) | 136.7 (120.0, 164.9) | 161.1 (155.7, 178.1) | 144.5 (120.0, 178.1)
Week 24
N | 17 | 6 | 23
Mean (SD) | 141.5 (12.1) | 166.6 (7.4) | 148.0 (15.7)
Median (Min-Max) | 140.9 (123.5, 168.8) | 166.0 (157.9, 179.3) | 142.5 (123.5, 179.3)
LOCF
N | 27 | 12 | 39
Mean (SD) | 139.3 (10.9) | 163.6 (6.5) | 146.8 (14.9)
Median (Min-Max) | 138.0 (123.5, 168.8) | 162.0 (156.4, 179.3) | 142.5 (123.5, 179.3)
Change from Baseline to LOCF
N | 27 | 12 | 39
Mean (SD) | 1.8 (1.2) | 1.0 (1.8) | 1.6 (1.4)
Median (Min-Max) | 2.0 (−0.8, 3.9) | 0.6 (−1.6, 4.7) | 1.7 (−1.6, 4.7)

Note: Baseline is defined as Last visit of Efficacy phase.

Table 14.3.4.2.9A Summary of Vital Signs by Visit and Age Strata Height Z Score Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 0.44 (1.02) | 0.09 (0.90) | 0.32 (0.98)
Median (Min-Max) | 0.35 (−1.32, 2.11) | −0.08 (−1.15, 1.46) | 0.33 (−1.32, 2.11)
Week 24
N | 17 | 6 | 23
Mean (SD) | 0.31 (1.12) | 0.08 (0.86) | 0.25 (1.05)
Median (Min-Max) | 0.11 (−1.48, 2.21) | 0.04 (−0.89, 1.21) | 0.11 (−1.48, 2.21)
LOCF
N | 27 | 12 | 39
Mean (SD) | 0.37 (1.01) | 0.05 (0.90) | 0.27 (0.97)
Median (Min-Max) | 0.16 (−1.48, 2.21) | −0.18 (−0.98, 1.44) | 0.11 (−1.48, 2.21)
Change from Baseline to LOCF
N | 27 | 12 | 39
Mean (SD) | −0.08 (0.17) | −0.05 (0.11) | −0.07 (0.16)
Median (Min-Max) | −0.05 (−0.35, 0.26) | −0.05 (−0.26, 0.10) | −0.05 (−0.35, 0.26)

Note: Baseline is defined as Last visit of Efficacy phase.

Table 14.3.4.2.10A Summary of Vital Signs by Visit and Age Strata BMI Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 21.3 (6.2) | 25.2 (6.9) | 22.6 (6.6)
Median (Min-Max) | 18.9 (15.3, 37.0) | 23.6 (18.1, 40.5) | 21.1 (15.3, 40.5)
Week 24
N | 17 | 6 | 23
Mean (SD) | 23.4 (7.1) | 25.8 (7.9) | 24.0 (7.2)
Median (Min-Max) | 21.7 (14.9, 37.8) | 24.7 (18.9, 40.4) | 23.2 (14.9, 40.4)
LOCF
N | 27 | 12 | 39
Mean (SD) | 21.8 (6.5) | 25.9 (6.4) | 23.1 (6.7)
Median (Min-Max) | 19.1 (14.9, 37.8) | 24.9 (18.9, 40.4) | 21.7 (14.9, 40.4)
Change from Baseline to LOCF
N | 27 | 12 | 39
Mean (SD) | 0.4 (1.4) | 1.0 (0.9) | 0.6 (1.3)
Median (Min-Max) | 0.5 (−1.7, 4.0) | 1.2 (−1.0, 2.0) | 0.6 (−1.7, 4.0)

Note: Baseline is defined as Last visit of Efficacy phase.

Table 14.3.4.2.11A Summary of Vital Signs by Visit and Age Strata BMI Z Score Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 1.10 (0.97) | 1.03 (1.05) | 1.07 (0.99)
Median (Min-Max) | 0.87 (−0.30, 2.70) | 1.07 (−0.48, 2.75) | 1.03 (−0.48, 2.75)
Week 24
N | 17 | 6 | 23
Mean (SD) | 1.27 (1.11) | 1.09 (1.07) | 1.22 (1.08)
Median (Min-Max) | 1.69 (−0.81, 2.69) | 1.11 (−0.13, 2.75) | 1.18 (−0.81, 2.75)
LOCF
N | 27 | 12 | 39
Mean (SD) | 1.08 (1.05) | 1.18 (0.93) | 1.11 (1.00)
Median (Min-Max) | 0.91 (−0.81, 2.69) | 1.28 (−0.29, 2.75) | 1.11 (−0.81, 2.75)
Change from Baseline to LOCF
N | 27 | 12 | 39
Mean (SD) | 0.00 (0.42) | 0.17 (0.14) | 0.05 (0.36)
Median (Min-Max) | −0.01 (−0.82, 0.93) | 0.19 (−0.08, 0.39) | 0.06 (−0.82, 0.93)

Note: Baseline is defined as Last visit of Efficacy phase.

Table 14.3.4.2.1B Summary of Vital Signs by Visit and Efficacy Phase Treatment Received Group Heart Rate (beats/min) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 82.0 (15.3) | 80.9 (10.0) | 81.6 (13.6)
Median (Min-Max) | 83.0 (51.0, 112.0) | 83.0 (64.0, 102.0) | 83.0 (51.0, 112.0)
Week 1
N | 26 | 11 | 37
Mean (SD) | 86.4 (13.9) | 83.9 (12.9) | 85.6 (13.4)
Median (Min-Max) | 87.0 (50.0, 112.0) | 78.0 (68.0, 104.0) | 86.0 (50.0, 112.0)
Week 2
N | 29 | 14 | 43
Mean (SD) | 84.5 (15.1) | 88.3 (10.0) | 85.7 (13.7)
Median (Min-Max) | 85.0 (48.0, 110.0) | 88.0 (74.0, 106.0) | 86.0 (48.0, 110.0)
Week 4
N | 25 | 12 | 37
Mean (SD) | 84.1 (14.8) | 85.8 (10.2) | 84.6 (13.4)
Median (Min-Max) | 88.0 (50.0, 110.0) | 86.5 (68.0, 101.0) | 88.0 (50.0, 110.0)
Week 6
N | 26 | 12 | 38
Mean (SD) | 83.8 (14.2) | 84.4 (14.0) | 84.0 (14.0)
Median (Min-Max) | 82.0 (51.0, 108.0) | 85.5 (62.0, 108.0) | 83.5 (51.0, 108.0)
Week 8
N | 25 | 11 | 36
Mean (SD) | 86.4 (16.4) | 82.7 (11.3) | 85.3 (15.0)
Median (Min-Max) | 91.0 (50.0, 110.0) | 84.0 (61.0, 95.0) | 90.0 (50.0, 110.0)
Week 10
N | 21 | 11 | 32
Mean (SD) | 89.7 (17.2) | 80.2 (16.6) | 86.4 (17.3)
Median (Min-Max) | 92.0 (54.0, 117.0) | 78.0 (60.0, 106.0) | 87.5 (54.0, 117.0)
Week 12
N | 21 | 10 | 31
Mean (SD) | 83.6 (15.5) | 78.9 (12.3) | 82.1 (14.5)
Median (Min-Max) | 84.0 (50.0, 110.0) | 84.5 (64.0, 92.0) | 84.0 (50.0, 110.0)
Week 14
N | 18 | 9 | 27
Mean (SD) | 84.7 (16.0) | 80.3 (14.7) | 83.2 (15.4)
Median (Min-Max) | 84.0 (47.0, 108.0) | 72.0 (65.0, 106.0) | 84.0 (47.0, 108.0)
Week 16
N | 18 | 9 | 27
Mean (SD) | 89.1 (18.2) | 80.4 (14.8) | 86.2 (17.3)
Median (Min-Max) | 89.5 (42.0, 122.0) | 79.0 (65.0, 108.0) | 88.0 (42.0, 122.0)
Week 18
N | 19 | 8 | 27
Mean (SD) | 87.4 (14.8) | 77.1 (14.6) | 84.4 (15.3)
Median (Min-Max) | 88.0 (49.0, 107.0) | 81.5 (49.0, 92.0) | 85.0 (49.0, 107.0)
Week 20
N | 16 | 8 | 24
Mean (SD) | 88.3 (15.0) | 79.0 (14.5) | 85.2 (15.2)
Median (Min-Max) | 89.0 (56.0, 112.0) | 83.5 (57.0, 95.0) | 88.0 (56.0, 112.0)
Week 22
N | 14 | 8 | 22
Mean (SD) | 89.4 (15.8) | 75.3 (14.8) | 84.3 (16.6)
Median (Min-Max) | 90.0 (58.0, 113.0) | 73.0 (59.0, 102.0) | 84.5 (58.0, 113.0)
Week 24
N | 15 | 8 | 23
Mean (SD) | 82.6 (16.2) | 70.3 (16.9) | 78.3 (17.1)
Median (Min-Max) | 84.0 (45.0, 109.0) | 65.5 (49.0, 91.0) | 84.0 (45.0, 109.0)
LOCF
N | 29 | 13 | 42
Mean (SD) | 84.4 (16.8) | 75.6 (16.2) | 81.7 (17.0)
Median (Min-Max) | 84.0 (45.0, 118.0) | 86.0 (49.0, 94.0) | 84.0 (45.0, 118.0)
Change from Baseline to LOCF
N | 29 | 13 | 42
Mean (SD) | 2.4 (12.6) | −4.8 (13.8) | 0.2 (13.3)
Median (Min-Max) | 1.0 (−24.0, 26.0) | −4.0 (−26.0, 22.0) | 0.0 (−26.0, 26.0)

Note: Baseline is defined as Last visit of Efficacy phase.

Table 14.3.4.2.2B Summary of Vital Signs by Visit and Efficacy Phase Treatment Received Group Systolic Blood Pressure (mmHg) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 109.5 (16.0) | 109.9 (10.9) | 109.6 (14.3)
Median (Min-Max) | 106.0 (88.0, 151.0) | 110.0 (86.0, 129.0) | 109.0 (86.0, 151.0)
Week 1
N | 26 | 11 | 37
Mean (SD) | 106.8 (8.7) | 115.4 (11.7) | 109.3 (10.3)
Median (Min-Max) | 108.0 (90.0, 123.0) | 114.0 (100.0, 133.0) | 110.0 (90.0, 133.0)
Week 2
N | 29 | 14 | 43
Mean (SD) | 107.2 (10.7) | 113.7 (11.3) | 109.3 (11.2)
Median (Min-Max) | 110.0 (88.0, 137.0) | 113.0 (100.0, 136.0) | 110.0 (88.0, 137.0)
Week 4
N | 25 | 12 | 37
Mean (SD) | 106.7 (10.2) | 111.0 (10.6) | 108.1 (10.4)
Median (Min-Max) | 108.0 (88.0, 126.0) | 113.0 (91.0, 125.0) | 108.0 (88.0, 126.0)
Week 6
N | 26 | 12 | 38
Mean (SD) | 108.1 (12.0) | 109.5 (12.2) | 108.6 (11.9)
Median (Min-Max) | 107.5 (88.0, 134.0) | 113.5 (82.0, 124.0) | 111.0 (82.0, 134.0)
Week 8
N | 25 | 11 | 36
Mean (SD) | 113.1 (10.2) | 107.8 (17.7) | 111.5 (12.9)
Median (Min-Max) | 115.0 (97.0, 133.0) | 102.0 (80.0, 142.0) | 113.5 (80.0, 142.0)
Week 10
N | 21 | 11 | 32
Mean (SD) | 112.1 (10.3) | 110.0 (16.2) | 111.4 (12.4)
Median (Min-Max) | 110.0 (96.0, 139.0) | 104.0 (87.0, 139.0) | 110.0 (87.0, 139.0)
Week 12
N | 21 | 10 | 31
Mean (SD) | 109.7 (15.1) | 106.6 (14.9) | 108.7 (14.9)
Median (Min-Max) | 110.0 (75.0, 140.0) | 104.0 (79.0, 129.0) | 107.0 (75.0, 140.0)
Week 14
N | 18 | 9 | 27
Mean (SD) | 108.9 (11.2) | 109.9 (15.8) | 109.3 (12.6)
Median (Min-Max) | 110.0 (88.0, 130.0) | 106.0 (91.0, 143.0) | 110.0 (88.0, 143.0)
Week 16
N | 18 | 9 | 27
Mean (SD) | 110.6 (10.5) | 109.2 (21.8) | 110.1 (14.8)
Median (Min-Max) | 109.0 (96.0, 135.0) | 105.0 (84.0, 158.0) | 108.0 (84.0, 158.0)
Week 18
N | 19 | 8 | 27
Mean (SD) | 111.1 (11.9) | 110.6 (16.8) | 110.9 (13.2)
Median (Min-Max) | 112.0 (90.0, 137.0) | 110.0 (86.0, 144.0) | 111.0 (86.0, 144.0)
Week 20
N | 16 | 8 | 24
Mean (SD) | 111.0 (10.2) | 109.4 (15.1) | 110.5 (11.7)
Median (Min-Max) | 113.0 (90.0, 128.0) | 107.0 (85.0, 138.0) | 111.5 (85.0, 138.0)
Week 22
N | 14 | 8 | 22
Mean (SD) | 111.9 (9.6) | 105.4 (8.8) | 109.5 (9.6)
Median (Min-Max) | 114.5 (96.0, 132.0) | 106.0 (93.0, 117.0) | 109.0 (93.0, 132.0)
Week 24
N | 15 | 8 | 23
Mean (SD) | 111.4 (12.8) | 107.4 (14.7) | 110.0 (13.3)
Median (Min-Max) | 114.0 (92.0, 128.0) | 106.0 (84.0, 132.0) | 111.0 (84.0, 132.0)
LOCF
N | 29 | 13 | 42
Mean (SD) | 111.4 (11.5) | 111.9 (14.0) | 111.5 (12.1)
Median (Min-Max) | 115.0 (92.0, 128.0) | 112.0 (84.0, 135.0) | 114.5 (84.0, 135.0)
Change from Baseline to LOCF
N | 29 | 13 | 42
Mean (SD) | 1.9 (15.4) | 2.1 (7.8) | 2.0 (13.4)
Median (Min-Max) | 2.0 (−38.0, 36.0) | 3.0 (−9.0, 15.0) | 2.0 (−38.0, 36.0)

Note: Baseline is defined as Last visit of Efficacy phase.

Table 14.3.4.2.3B Summary of Vital Signs by Visit and Efficacy Phase Treatment Received Group Systolic Blood Pressure Z Score Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 0.46 (1.41) | 0.43 (0.98) | 0.45 (1.26)
Median (Min-Max) | 0.06 (−1.88, 3.28) | 0.74 (−1.37, 2.04) | 0.40 (−1.88, 3.28)
Week 1
N | 26 | 11 | 37
Mean (SD) | 0.20 (0.91) | 0.86 (1.00) | 0.40 (0.97)
Median (Min-Max) | 0.14 (−1.86, 2.09) | 0.92 (−0.98, 2.80) | 0.34 (−1.86, 2.80)
Week 2
N | 29 | 14 | 43
Mean (SD) | 0.24 (0.88) | 0.77 (1.07) | 0.41 (0.96)
Median (Min-Max) | 0.28 (−2.05, 1.96) | 0.62 (−0.98, 2.51) | 0.36 (−2.05, 2.51)
Week 4
N | 25 | 12 | 37
Mean (SD) | 0.13 (1.01) | 0.49 (0.92) | 0.25 (0.98)
Median (Min-Max) | −0.00 (−2.09, 2.37) | 0.78 (−0.91, 1.90) | 0.20 (−2.09, 2.37)
Week 6
N | 26 | 12 | 38
Mean (SD) | 0.31 (1.13) | 0.34 (1.13) | 0.32 (1.11)
Median (Min-Max) | 0.22 (−1.50, 2.48) | 0.26 (−1.76, 1.75) | 0.22 (−1.76, 2.48)
Week 8
N | 25 | 11 | 36
Mean (SD) | 0.80 (0.98) | 0.16 (1.40) | 0.60 (1.14)
Median (Min-Max) | 0.76 (−1.12, 2.72) | −0.31 (−1.95, 2.39) | 0.63 (−1.95, 2.72)
Week 10
N | 21 | 11 | 32
Mean (SD) | 0.72 (1.00) | 0.36 (1.19) | 0.60 (1.06)
Median (Min-Max) | 0.63 (−0.99, 2.48) | −0.03 (−1.30, 2.12) | 0.55 (−1.30, 2.48)
Week 12
N | 21 | 10 | 31
Mean (SD) | 0.49 (1.28) | 0.16 (1.26) | 0.38 (1.26)
Median (Min-Max) | 0.43 (−2.28, 2.47) | 0.23 (−2.06, 1.98) | 0.40 (−2.28, 2.47)
Week 14
N | 18 | 9 | 27
Mean (SD) | 0.39 (1.17) | 0.44 (1.11) | 0.41 (1.13)
Median (Min-Max) | 0.48 (−2.14, 2.24) | 0.30 (−0.94, 2.46) | 0.30 (−2.14, 2.46)
Week 16
N | 18 | 9 | 27
Mean (SD) | 0.57 (0.87) | 0.38 (1.72) | 0.51 (1.19)
Median (Min-Max) | 0.30 (−1.40, 2.19) | −0.25 (−1.60, 3.85) | 0.30 (−1.60, 3.85)
Week 18
N | 19 | 8 | 27
Mean (SD) | 0.58 (1.06) | 0.45 (1.21) | 0.54 (1.09)
Median (Min-Max) | 0.50 (−1.97, 2.51) | 0.64 (−1.42, 2.53) | 0.52 (−1.97, 2.53)
Week 20
N | 16 | 8 | 24
Mean (SD) | 0.54 (1.12) | 0.33 (1.04) | 0.47 (1.08)
Median (Min-Max) | 0.76 (−1.97, 2.45) | 0.42 (−1.52, 1.96) | 0.60 (−1.97, 2.45)
Week 22
N | 14 | 8 | 22
Mean (SD) | 0.64 (0.94) | −0.06 (0.59) | 0.39 (0.89)
Median (Min-Max) | 0.55 (−1.43, 2.65) | −0.15 (−0.78, 1.16) | 0.29 (−1.43, 2.65)
Week 24
N | 15 | 8 | 23
Mean (SD) | 0.56 (1.21) | 0.16 (1.05) | 0.42 (1.15)
Median (Min-Max) | 0.85 (−1.82, 2.89) | 0.04 (−1.55, 1.41) | 0.27 (−1.82, 2.89)
LOCF
N | 29 | 13 | 42
Mean (SD) | 0.59 (1.12) | 0.58 (1.09) | 0.59 (1.10)
Median (Min-Max) | 0.54 (−1.82, 2.89) | 0.77 (−1.55, 2.13) | 0.65 (−1.82, 2.89)
Change from Baseline to LOCF
N | 29 | 13 | 42
Mean (SD) | 0.13 (1.47) | 0.17 (0.72) | 0.14 (1.28)
Median (Min-Max) | 0.12 (−3.60, 3.42) | 0.20 (−0.90, 1.36) | 0.12 (−3.60, 3.42)

Note: Baseline is defined as Last visit of Efficacy phase.

Baseline Height is used to calculate all BP Z scores except LOCF visit, which used the height collected at that visit.

Table 14.3.4.2.4B Summary of Vital Signs by Visit and Efficacy Phase Treatment Received Group Diastolic Blood Pressure (mmHg) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 66.0 (11.4) | 64.1 (9.4) | 65.4 (10.7)
Median (Min-Max) | 66.0 (39.0, 90.0) | 65.0 (48.0, 76.0) | 65.5 (39.0, 90.0)
Week 1
N | 26 | 11 | 37
Mean (SD) | 65.4 (8.2) | 66.4 (8.2) | 65.7 (8.1)
Median (Min-Max) | 67.0 (44.0, 78.0) | 66.0 (56.0, 78.0) | 67.0 (44.0, 78.0)
Week 2
N | 29 | 14 | 43
Mean (SD) | 65.9 (10.0) | 70.2 (13.9) | 67.3 (11.4)
Median (Min-Max) | 65.0 (48.0, 85.0) | 70.0 (58.0, 112.0) | 68.0 (48.0, 112.0)
Week 4
N | 25 | 12 | 37
Mean (SD) | 66.1 (9.4) | 65.8 (5.4) | 66.0 (8.2)
Median (Min-Max) | 65.0 (41.0, 81.0) | 64.5 (59.0, 74.0) | 65.0 (41.0, 81.0)
Week 6
N | 26 | 12 | 38
Mean (SD) | 66.8 (11.2) | 65.3 (6.5) | 66.3 (9.9)
Median (Min-Max) | 68.0 (44.0, 90.0) | 66.0 (52.0, 76.0) | 67.5 (44.0, 90.0)
Week 8
N | 25 | 11 | 36
Mean (SD) | 69.3 (10.0) | 64.5 (11.1) | 67.8 (10.4)
Median (Min-Max) | 68.0 (51.0, 86.0) | 66.0 (50.0, 82.0) | 67.5 (50.0, 86.0)
Week 10
N | 21 | 11 | 32
Mean (SD) | 68.0 (11.2) | 65.3 (8.3) | 67.0 (10.3)
Median (Min-Max) | 69.0 (47.0, 92.0) | 63.0 (54.0, 80.0) | 66.5 (47.0, 92.0)
Week 12
N | 21 | 10 | 31
Mean (SD) | 67.0 (13.1) | 67.5 (9.0) | 67.1 (11.8)
Median (Min-Max) | 68.0 (38.0, 90.0) | 67.0 (52.0, 82.0) | 68.0 (38.0, 90.0)
Week 14
N | 18 | 9 | 27
Mean (SD) | 65.4 (12.4) | 65.4 (6.6) | 65.4 (10.7)
Median (Min-Max) | 68.0 (37.0, 83.0) | 68.0 (50.0, 70.0) | 68.0 (37.0, 83.0)
Week 16
N | 18 | 9 | 27
Mean (SD) | 70.4 (7.4) | 59.6 (5.5) | 66.8 (8.5)
Median (Min-Max) | 69.5 (50.0, 81.0) | 58.0 (53.0, 71.0) | 68.0 (50.0, 81.0)
Week 18
N | 19 | 8 | 27
Mean (SD) | 70.1 (9.3) | 63.1 (8.7) | 68.0 (9.5)
Median (Min-Max) | 71.0 (48.0, 84.0) | 63.0 (53.0, 82.0) | 70.0 (48.0, 84.0)
Week 20
N | 16 | 8 | 24
Mean (SD) | 70.8 (7.4) | 61.4 (5.2) | 67.6 (8.0)
Median (Min-Max) | 69.5 (57.0, 80.0) | 60.5 (54.0, 71.0) | 67.5 (54.0, 80.0)
Week 22
N | 14 | 8 | 22
Mean (SD) | 71.4 (7.1) | 61.9 (4.7) | 68.0 (7.8)
Median (Min-Max) | 71.0 (59.0, 86.0) | 62.0 (53.0, 68.0) | 67.5 (53.0, 86.0)
Week 24
N | 15 | 8 | 23
Mean (SD) | 68.1 (8.9) | 61.8 (9.1) | 65.9 (9.3)
Median (Min-Max) | 68.0 (53.0, 81.0) | 60.0 (52.0, 74.0) | 68.0 (52.0, 81.0)
LOCF
N | 29 | 13 | 42
Mean (SD) | 68.0 (9.1) | 66.2 (9.4) | 67.5 (9.1)
Median (Min-Max) | 68.0 (50.0, 83.0) | 71.0 (52.0, 80.0) | 69.5 (50.0, 83.0)
Change from Baseline to LOCF
N | 29 | 13 | 42
Mean (SD) | 2.0 (9.4) | 2.5 (8.8) | 2.2 (9.1)
Median (Min-Max) | 0.0 (−13.0, 23.0) | 3.0 (−7.0, 26.0) | 1.0 (−13.0, 26.0)

Note: Baseline is defined as Last visit of Efficacy phase.

Table 14.3.4.2.5B Summary of Vital Signs by Visit and Efficacy Phase Treatment Received Group Diastolic Blood Pressure Z Score Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 0.37 (0.96) | 0.18 (0.86) | 0.30 (0.92)
Median (Min-Max) | 0.40 (−2.07, 2.63) | 0.22 (−1.52, 1.29) | 0.32 (−2.07, 2.63)
Week 1
N | 26 | 11 | 37
Mean (SD) | 0.32 (0.71) | 0.33 (0.73) | 0.32 (0.70)
Median (Min-Max) | 0.39 (−1.33, 1.66) | 0.24 (−0.67, 1.54) | 0.34 (−1.33, 1.66)
Week 2
N | 29 | 14 | 43
Mean (SD) | 0.35 (0.85) | 0.68 (1.28) | 0.46 (1.00)
Median (Min-Max) | 0.42 (−0.99, 2.20) | 0.52 (−0.67, 4.46) | 0.43 (−0.99, 4.46)
Week 4
N | 25 | 12 | 37
Mean (SD) | 0.35 (0.78) | 0.28 (0.49) | 0.33 (0.70)
Median (Min-Max) | 0.13 (−1.59, 1.76) | 0.24 (−0.49, 1.19) | 0.15 (−1.59, 1.76)
Week 6
N | 26 | 12 | 38
Mean (SD) | 0.43 (1.00) | 0.24 (0.55) | 0.37 (0.88)
Median (Min-Max) | 0.42 (−1.34, 2.62) | 0.26 (−0.80, 1.24) | 0.40 (−1.34, 2.62)
Week 8
N | 25 | 11 | 36
Mean (SD) | 0.67 (0.86) | 0.16 (0.86) | 0.51 (0.88)
Median (Min-Max) | 0.58 (−0.74, 2.30) | 0.14 (−1.05, 1.39) | 0.44 (−1.05, 2.30)
Week 10
N | 21 | 11 | 32
Mean (SD) | 0.55 (0.95) | 0.23 (0.69) | 0.44 (0.87)
Median (Min-Max) | 0.45 (−1.21, 2.20) | −0.08 (−0.66, 1.35) | 0.42 (−1.21, 2.20)
Week 12
N | 21 | 10 | 31
Mean (SD) | 0.46 (1.12) | 0.47 (0.73) | 0.47 (1.00)
Median (Min-Max) | 0.56 (−1.86, 2.61) | 0.53 (−0.73, 1.38) | 0.54 (−1.86, 2.61)
Week 14
N | 18 | 9 | 27
Mean (SD) | 0.32 (1.06) | 0.28 (0.50) | 0.31 (0.90)
Median (Min-Max) | 0.40 (−1.95, 1.75) | 0.39 (−0.78, 0.83) | 0.40 (−1.95, 1.75)
Week 16
N | 18 | 9 | 27
Mean (SD) | 0.78 (0.66) | −0.24 (0.52) | 0.44 (0.78)
Median (Min-Max) | 0.75 (−0.83, 1.96) | −0.33 (−0.98, 0.94) | 0.41 (−0.98, 1.96)
Week 18
N | 19 | 8 | 27
Mean (SD) | 0.73 (0.81) | 0.05 (0.63) | 0.53 (0.81)
Median (Min-Max) | 0.96 (−1.01, 1.86) | −0.02 (−0.65, 1.37) | 0.55 (−1.01, 1.86)
Week 20
N | 16 | 8 | 24
Mean (SD) | 0.77 (0.72) | −0.11 (0.44) | 0.48 (0.76)
Median (Min-Max) | 0.62 (−0.78, 1.92) | −0.16 (−0.61, 0.50) | 0.43 (−0.78, 1.92)
Week 22
N | 14 | 8 | 22
Mean (SD) | 0.83 (0.58) | −0.06 (0.37) | 0.51 (0.67)
Median (Min-Max) | 0.79 (−0.07, 2.08) | −0.06 (−0.73, 0.46) | 0.47 (−0.73, 2.08)
Week 24
N | 15 | 8 | 23
Mean (SD) | 0.53 (0.74) | −0.06 (0.69) | 0.32 (0.76)
Median (Min-Max) | 0.36 (−0.63, 2.03) | −0.18 (−1.06, 0.80) | 0.33 (−1.06, 2.03)
LOCF
N | 29 | 13 | 42
Mean (SD) | 0.53 (0.79) | 0.33 (0.75) | 0.47 (0.77)
Median (Min-Max) | 0.42 (−1.07, 2.03) | 0.66 (−1.06, 1.33) | 0.53 (−1.07, 2.03)
Change from Baseline to LOCF
N | 29 | 13 | 42
Mean (SD) | 0.16 (0.84) | 0.20 (0.77) | 0.18 (0.81)
Median (Min-Max) | −0.03 (−1.16, 2.03) | 0.23 (−0.66, 2.21) | 0.07 (−1.16, 2.21)

Note: Baseline is defined as Last visit of Efficacy phase.

Baseline Height is used to calculate all BP Z scores except LOCF visit, which used the height collected at that visit.

Table 14.3.4.2.6B Summary of Vital Signs by Visit and Efficacy Phase Treatment Received Group Weight (kg) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 50.8 (23.4) | 49.8 (22.9) | 50.5 (23.0)
Median (Min-Max) | 46.8 (24.0, 115.7) | 45.7 (25.8, 105.7) | 46.2 (24.0, 115.7)
Week 1
N | 26 | 11 | 37
Mean (SD) | 52.1 (24.7) | 51.1 (17.5) | 51.8 (22.6)
Median (Min-Max) | 45.9 (25.0, 115.7) | 57.3 (26.0, 84.3) | 46.3 (25.0, 115.7)
Week 2
N | 29 | 14 | 43
Mean (SD) | 51.4 (24.2) | 47.2 (17.9) | 50.1 (22.2)
Median (Min-Max) | 47.0 (25.0, 117.5) | 44.0 (27.3, 84.7) | 46.5 (25.0, 117.5)
Week 4
N | 25 | 12 | 37
Mean (SD) | 54.2 (23.7) | 49.8 (18.0) | 52.8 (21.9)
Median (Min-Max) | 48.8 (26.3, 117.1) | 51.8 (27.5, 84.4) | 48.8 (26.3, 117.1)
Week 6
N | 26 | 12 | 38
Mean (SD) | 52.6 (24.3) | 50.3 (17.5) | 51.9 (22.1)
Median (Min-Max) | 47.8 (24.3, 118.8) | 52.2 (28.0, 84.1) | 47.8 (24.3, 118.8)
Week 8
N | 25 | 11 | 36
Mean (SD) | 52.1 (24.5) | 49.8 (18.4) | 51.4 (22.6)
Median (Min-Max) | 47.9 (25.0, 117.9) | 46.8 (27.5, 85.4) | 47.4 (25.0, 117.9)
Week 10
N | 21 | 11 | 32
Mean (SD) | 53.0 (25.7) | 49.9 (18.3) | 52.0 (23.2)
Median (Min-Max) | 47.2 (26.0, 117.5) | 46.7 (27.4, 84.1) | 47.0 (26.0, 117.5)
Week 12
N | 21 | 10 | 31
Mean (SD) | 53.1 (25.6) | 48.4 (18.7) | 51.6 (23.4)
Median (Min-Max) | 47.7 (26.5, 118.2) | 46.7 (27.4, 87.3) | 46.9 (26.5, 118.2)
Week 14
N | 18 | 9 | 27
Mean (SD) | 55.0 (26.4) | 47.4 (19.9) | 52.5 (24.3)
Median (Min-Max) | 48.8 (25.3, 116.4) | 46.4 (26.1, 87.3) | 47.1 (25.3, 116.4)
Week 16
N | 18 | 9 | 27
Mean (SD) | 53.5 (24.9) | 47.4 (20.5) | 51.5 (23.3)
Median (Min-Max) | 49.4 (25.4, 117.6) | 46.4 (26.4, 88.7) | 47.3 (25.4, 117.6)
Week 18
N | 19 | 8 | 27
Mean (SD) | 56.1 (25.9) | 49.4 (20.3) | 54.1 (24.2)
Median (Min-Max) | 51.3 (25.1, 116.1) | 46.8 (26.8, 86.5) | 48.4 (25.1, 116.1)
Week 20
N | 16 | 8 | 24
Mean (SD) | 57.3 (26.0) | 49.6 (20.5) | 54.7 (24.1)
Median (Min-Max) | 51.0 (24.9, 116.4) | 46.8 (26.4, 87.3) | 50.3 (24.9, 116.4)
Week 22
N | 14 | 8 | 22
Mean (SD) | 58.2 (27.7) | 49.5 (20.9) | 55.1 (25.3)
Median (Min-Max) | 51.0 (25.0, 116.7) | 46.0 (26.0, 88.0) | 48.7 (25.0, 116.7)
Week 24
N | 15 | 8 | 23
Mean (SD) | 57.9 (26.9) | 49.1 (20.4) | 54.9 (24.7)
Median (Min-Max) | 51.7 (24.9, 115.3) | 46.1 (26.5, 86.8) | 50.0 (24.9, 115.3)
LOCF
N | 29 | 13 | 42
Mean (SD) | 52.6 (23.8) | 49.6 (18.5) | 51.7 (22.1)
Median (Min-Max) | 48.5 (23.8, 115.3) | 46.1 (26.5, 86.8) | 48.0 (23.8, 115.3)
Change from Baseline to LOCF
N | 29 | 13 | 42
Mean (SD) | 1.8 (3.2) | 2.4 (2.2) | 2.0 (2.9)
Median (Min-Max) | 1.8 (−5.3, 10.2) | 2.3 (−1.5, 6.0) | 2.3 (−5.3, 10.2)

Note: Baseline is defined as Last visit of Efficacy phase.

Table 14.3.4.2.7B Summary of Vital Signs by Visit and Efficacy Phase Treatment Received Group Weight Z Score Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 1.01 (1.27) | 1.19 (0.86) | 1.07 (1.14)
Median (Min-Max) | 0.47 (−0.97, 3.26) | 0.93 (0.24, 3.01) | 0.77 (−0.97, 3.26)
Week 1
N | 26 | 11 | 37
Mean (SD) | 1.00 (1.25) | 1.27 (0.74) | 1.08 (1.12)
Median (Min-Max) | 0.81 (−0.86, 3.25) | 1.03 (0.11, 2.56) | 1.03 (−0.86, 3.25)
Week 2
N | 29 | 14 | 43
Mean (SD) | 1.02 (1.28) | 1.17 (0.72) | 1.07 (1.12)
Median (Min-Max) | 0.59 (−1.11, 3.29) | 0.98 (0.11, 2.60) | 0.93 (−1.11, 3.29)
Week 4
N | 25 | 12 | 37
Mean (SD) | 1.14 (1.27) | 1.19 (0.77) | 1.16 (1.12)
Median (Min-Max) | 1.06 (−0.92, 3.26) | 0.99 (0.13, 2.58) | 1.02 (−0.92, 3.26)
Week 6
N | 26 | 12 | 38
Mean (SD) | 1.05 (1.28) | 1.24 (0.69) | 1.11 (1.12)
Median (Min-Max) | 0.69 (−0.91, 3.24) | 1.03 (0.23, 2.52) | 1.02 (−0.91, 3.24)
Week 8
N | 25 | 11 | 36
Mean (SD) | 1.02 (1.31) | 1.13 (0.63) | 1.05 (1.14)
Median (Min-Max) | 0.63 (−1.03, 3.24) | 1.06 (0.04, 2.09) | 0.90 (−1.03, 3.24)
Week 10
N | 21 | 11 | 32
Mean (SD) | 1.22 (1.25) | 1.12 (0.61) | 1.19 (1.07)
Median (Min-Max) | 0.75 (−0.58, 3.27) | 0.96 (0.02, 2.03) | 0.96 (−0.58, 3.27)
Week 12
N | 21 | 10 | 31
Mean (SD) | 1.22 (1.25) | 1.26 (0.78) | 1.23 (1.10)
Median (Min-Max) | 0.79 (−0.44, 3.26) | 1.01 (−0.06, 2.41) | 1.00 (−0.44, 3.26)
Week 14
N | 18 | 9 | 27
Mean (SD) | 1.28 (1.15) | 1.08 (0.79) | 1.21 (1.03)
Median (Min-Max) | 1.06 (−0.34, 3.24) | 1.05 (−0.37, 2.15) | 1.05 (−0.37, 3.24)
Week 16
N | 18 | 9 | 27
Mean (SD) | 1.29 (1.16) | 1.05 (0.78) | 1.21 (1.04)
Median (Min-Max) | 1.10 (−0.34, 3.27) | 0.78 (−0.30, 2.19) | 1.03 (−0.34, 3.27)
Week 18
N | 19 | 8 | 27
Mean (SD) | 1.39 (1.23) | 1.09 (0.79) | 1.30 (1.11)
Median (Min-Max) | 1.18 (−0.44, 3.27) | 1.07 (−0.25, 2.09) | 1.17 (−0.44, 3.27)
Week 20
N | 16 | 8 | 24
Mean (SD) | 1.37 (1.33) | 1.10 (0.80) | 1.28 (1.17)
Median (Min-Max) | 1.18 (−0.50, 3.31) | 1.10 (−0.37, 2.10) | 1.18 (−0.50, 3.31)
Week 22
N | 14 | 8 | 22
Mean (SD) | 1.37 (1.39) | 1.04 (0.89) | 1.25 (1.22)
Median (Min-Max) | 1.18 (−0.53, 3.27) | 1.11 (−0.51, 2.14) | 1.13 (−0.53, 3.27)
Week 24
N | 15 | 8 | 23
Mean (SD) | 1.29 (1.36) | 1.02 (0.81) | 1.20 (1.19)
Median (Min-Max) | 1.13 (−0.57, 3.27) | 0.97 (−0.39, 2.06) | 1.13 (−0.57, 3.27)
LOCF
N | 29 | 13 | 42
Mean (SD) | 1.02 (1.24) | 1.13 (0.75) | 1.05 (1.11)
Median (Min-Max) | 1.06 (−1.03, 3.27) | 0.96 (−0.39, 2.41) | 1.01 (−1.03, 3.27)
Change from Baseline to LOCF
N | 29 | 13 | 42
Mean (SD) | 0.01 (0.31) | 0.03 (0.25) | 0.01 (0.29)
Median (Min-Max) | 0.01 (−0.62, 0.77) | 0.04 (−0.62, 0.34) | 0.02 (−0.62, 0.77)

Note: Baseline is defined as Last visit of Efficacy phase.

Table 14.3.4.2.8B Summary of Vital Signs by Visit and Efficacy Phase Treatment Received Group Height (cm) Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 145.0 (14.7) | 147.8 (17.3) | 146.0 (15.5)
Median (Min-Max) | 145.0 (122.0, 169.1) | 144.0 (120.0, 178.1) | 144.5 (120.0, 178.1)
Week 24
N | 15 | 8 | 23
Mean (SD) | 147.5 (15.7) | 149.0 (16.8) | 148.0 (15.7)
Median (Min-Max) | 142.5 (123.5, 169.0) | 146.3 (127.4, 179.3) | 142.5 (123.5, 179.3)
LOCF
N | 26 | 13 | 39
Mean (SD) | 145.6 (14.9) | 149.1 (15.3) | 146.8 (14.9)
Median (Min-Max) | 142.0 (123.5, 169.0) | 143.2 (127.4, 179.3) | 142.5 (123.5, 179.3)
Change from Baseline to LOCF
N | 26 | 13 | 39
Mean (SD) | 1.8 (1.6) | 1.1 (1.0) | 1.6 (1.4)
Median (Min-Max) | 2.0 (−1.6, 4.7) | 1.2 (−0.8, 2.3) | 1.7 (−1.6, 4.7)

Note: Baseline is defined as Last visit of Efficacy phase.

Table 14.3.4.2.9B Summary of Vital Signs by Visit and Efficacy Phase Treatment Received Group Height Z Score Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 0.16 (1.07) | 0.63 (0.73) | 0.32 (0.98)
Median (Min-Max) | −0.24 (−1.32, 2.11) | 0.42 (−1.10, 1.77) | 0.33 (−1.32, 2.11)
Week 24
N | 15 | 8 | 23
Mean (SD) | 0.14 (1.25) | 0.46 (0.51) | 0.25 (1.05)
Median (Min-Max) | −0.21 (−1.48, 2.21) | 0.30 (−0.29, 1.21) | 0.11 (−1.48, 2.21)
LOCF
N | 26 | 13 | 39
Mean (SD) | 0.12 (1.09) | 0.58 (0.62) | 0.27 (0.97)
Median (Min-Max) | −0.21 (−1.48, 2.21) | 0.31 (−0.29, 1.82) | 0.11 (−1.48, 2.21)
Change from Baseline to LOCF
N | 26 | 13 | 39
Mean (SD) | −0.03 (0.16) | −0.15 (0.11) | −0.07 (0.16)
Median (Min-Max) | −0.00 (−0.35, 0.26) | −0.17 (−0.32, 0.05) | −0.05 (−0.35, 0.26)

Note: Baseline is defined as Last visit of Efficacy phase.

Table 14.3.4.2.10B Summary of Vital Signs by Visit and Efficacy Phase Treatment Received Group BMI Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 23.2 (7.2) | 21.7 (5.5) | 22.6 (6.6)
Median (Min-Max) | 20.6 (15.3, 40.5) | 22.0 (15.8, 35.3) | 21.1 (15.3, 40.5)
Week 24
N | 15 | 8 | 23
Mean (SD) | 25.5 (8.1) | 21.2 (4.3) | 24.0 (7.2)
Median (Min-Max) | 24.6 (15.0, 40.4) | 21.7 (14.9, 27.0) | 23.2 (14.9, 40.4)
LOCF
N | 26 | 13 | 39
Mean (SD) | 23.9 (7.5) | 21.5 (4.4) | 23.1 (6.7)
Median (Min-Max) | 21.3 (15.0, 40.4) | 23.2 (14.9, 28.5) | 21.7 (14.9, 40.4)
Change from Baseline to LOCF
N | 26 | 13 | 39
Mean (SD) | 0.5 (1.4) | 0.7 (0.9) | 0.6 (1.3)
Median (Min-Max) | 0.5 (−1.7, 4.0) | 0.8 (−0.9, 2.0) | 0.6 (−1.7, 4.0)

Note: Baseline is defined as Last visit of Efficacy phase.

Table 14.3.4.2.11B Summary of Vital Signs by Visit and Efficacy Phase Treatment Received Group BMI Z Score Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline
N | 29 | 15 | 44
Mean (SD) | 1.08 (1.07) | 1.06 (0.83) | 1.07 (0.99)
Median (Min-Max) | 1.14 (−0.48, 2.75) | 1.00 (−0.06, 2.47) | 1.03 (−0.48, 2.75)
Week 24
N | 15 | 8 | 23
Mean (SD) | 1.37 (1.18) | 0.95 (0.86) | 1.22 (1.08)
Median (Min-Max) | 1.76 (−0.59, 2.75) | 1.02 (−0.81, 1.80) | 1.18 (−0.81, 2.75)
LOCF
N | 26 | 13 | 39
Mean (SD) | 1.16 (1.09) | 1.02 (0.83) | 1.11 (1.00)
Median (Min-Max) | 1.16 (−0.59, 2.75) | 1.11 (−0.81, 2.32) | 1.11 (−0.81, 2.75)
Change from Baseline to LOCF
N | 26 | 13 | 39
Mean (SD) | 0.04 (0.38) | 0.09 (0.32) | 0.05 (0.36)
Median (Min-Max) | 0.01 (−0.82, 0.93) | 0.10 (−0.75, 0.49) | 0.06 (−0.82, 0.93)

Note: Baseline is defined as Last visit of Efficacy phase.

Table 14.3.4.3.1 Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received Group Heart Rate (beats/min) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 79.5 (14.4) | 79.6 (11.7) | 79.5 (13.1)
Median (Min-Max) | 80.0 (52.0, 109.0) | 79.0 (60.0, 103.0) | 79.0 (52.0, 109.0)
Week 1
N | 17 | 13 | 30
Mean (SD) | 87.1 (14.0) | 85.5 (7.6) | 86.4 (11.5)
Median (Min-Max) | 83.0 (66.0, 111.0) | 85.0 (73.0, 99.0) | 84.0 (66.0, 111.0)
Week 2
N | 16 | 14 | 30
Mean (SD) | 82.4 (12.7) | 86.1 (8.7) | 84.2 (11.0)
Median (Min-Max) | 82.0 (55.0, 109.0) | 85.5 (76.0, 106.0) | 82.5 (55.0, 109.0)
Week 3
N | 13 | 9 | 22
Mean (SD) | 88.0 (15.8) | 80.6 (6.9) | 85.0 (13.2)
Median (Min-Max) | 86.0 (59.0, 106.0) | 80.0 (70.0, 92.0) | 84.5 (59.0, 106.0)
Week 4
N | 13 | 12 | 25
Mean (SD) | 89.0 (16.9) | 77.4 (9.7) | 83.4 (14.9)
Median (Min-Max) | 91.0 (64.0, 120.0) | 76.5 (57.0, 94.0) | 82.0 (57.0, 120.0)
Week 6
N | 13 | 8 | 21
Mean (SD) | 87.2 (10.0) | 78.3 (8.2) | 83.8 (10.2)
Median (Min-Max) | 85.0 (67.0, 103.0) | 80.0 (67.0, 88.0) | 84.0 (67.0, 103.0)
Week 8
N | 13 | 3 | 16
Mean (SD) | 86.1 (13.5) | 75.3 (20.2) | 84.1 (14.8)
Median (Min-Max) | 90.0 (60.0, 103.0) | 86.0 (52.0, 88.0) | 88.5 (52.0, 103.0)
Week 10
N | 11 | 2 | 13
Mean (SD) | 89.8 (15.3) | 89.5 (27.6) | 89.8 (16.1)
Median (Min-Max) | 94.0 (68.0, 114.0) | 89.5 (70.0, 109.0) | 94.0 (68.0, 114.0)
Week 12
N | 12 | 2 | 14
Mean (SD) | 85.9 (10.8) | 101.5 (17.7) | 88.1 (12.5)
Median (Min-Max) | 84.0 (73.0, 108.0) | 101.5 (89.0, 114.0) | 88.0 (73.0, 114.0)
Week 16
N | 12 | 2 | 14
Mean (SD) | 88.8 (12.0) | 76.5 (2.1) | 87.1 (11.9)
Median (Min-Max) | 92.0 (62.0, 101.0) | 76.5 (75.0, 78.0) | 90.5 (62.0, 101.0)
Week 20
N | 12 | 2 | 14
Mean (SD) | 89.6 (13.4) | 79.5 (7.8) | 88.1 (13.0)
Median (Min-Max) | 93.5 (64.0, 114.0) | 79.5 (74.0, 85.0) | 89.0 (64.0, 114.0)
Week 24
N | 11 | 2 | 13
Mean (SD) | 90.7 (17.3) | 85.0 (22.6) | 89.8 (17.2)
Median (Min-Max) | 91.0 (64.0, 121.0) | 85.0 (69.0, 101.0) | 91.0 (64.0, 121.0)
Week 28
N | 11 | 2 | 13
Mean (SD) | 82.1 (14.1) | 79.0 (7.1) | 81.6 (13.1)
Median (Min-Max) | 82.0 (56.0, 104.0) | 79.0 (74.0, 84.0) | 82.0 (56.0, 104.0)
LOCF
N | 17 | 14 | 31
Mean (SD) | 77.5 (13.6) | 78.4 (10.8) | 77.9 (12.2)
Median (Min-Max) | 78.0 (56.0, 104.0) | 80.5 (57.0, 92.0) | 78.0 (56.0, 104.0)
Change from Baseline to LOCF
N | 17 | 14 | 31
Mean (SD) | −1.9 (11.7) | −1.2 (11.4) | −1.6 (11.4)
Median (Min-Max) | 0.0 (−30.0, 12.0) | −0.5 (−15.0, 25.0) | 0.0 (−30.0, 25.0)

Note: Baseline is defined as Last visit of Long-Term Effectiveness Phase.

Table 14.3.4.3.2 Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received Group Systolic Blood Pressure (mmHg) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 108.8 (8.7) | 115.1 (11.1) | 111.6 (10.2)
Median (Min-Max) | 110.0 (95.0, 127.0) | 114.0 (98.0, 132.0) | 111.0 (95.0, 132.0)
Week 1
N | 17 | 13 | 30
Mean (SD) | 108.6 (10.3) | 120.5 (9.6) | 113.8 (11.5)
Median (Min-Max) | 110.0 (90.0, 123.0) | 122.0 (100.0, 132.0) | 114.0 (90.0, 132.0)
Week 2
N | 16 | 14 | 30
Mean (SD) | 107.4 (12.8) | 116.1 (6.2) | 111.4 (11.0)
Median (Min-Max) | 108.0 (86.0, 127.0) | 115.5 (108.0, 131.0) | 112.0 (86.0, 131.0)
Week 3
N | 13 | 9 | 22
Mean (SD) | 108.8 (14.0) | 124.8 (12.5) | 115.4 (15.3)
Median (Min-Max) | 104.0 (90.0, 143.0) | 123.0 (108.0, 148.0) | 115.0 (90.0, 148.0)
Week 4
N | 13 | 12 | 25
Mean (SD) | 110.5 (10.6) | 116.2 (8.0) | 113.2 (9.7)
Median (Min-Max) | 111.0 (97.0, 132.0) | 114.0 (107.0, 134.0) | 113.0 (97.0, 134.0)
Week 6
N | 13 | 8 | 21
Mean (SD) | 107.7 (8.4) | 112.0 (13.5) | 109.3 (10.5)
Median (Min-Max) | 107.0 (92.0, 121.0) | 112.0 (93.0, 129.0) | 109.0 (92.0, 129.0)
Week 8
N | 13 | 3 | 16
Mean (SD) | 110.5 (13.9) | 115.7 (18.7) | 111.5 (14.3)
Median (Min-Max) | 111.0 (80.0, 138.0) | 108.0 (102.0, 137.0) | 109.5 (80.0, 138.0)
Week 10
N | 11 | 2 | 13
Mean (SD) | 111.9 (12.2) | 130.5 (20.5) | 114.8 (14.4)
Median (Min-Max) | 114.0 (90.0, 128.0) | 130.5 (116.0, 145.0) | 116.0 (90.0, 145.0)
Week 12
N | 12 | 2 | 14
Mean (SD) | 110.5 (9.4) | 122.0 (8.5) | 112.1 (9.9)
Median (Min-Max) | 113.0 (93.0, 123.0) | 122.0 (116.0, 128.0) | 113.5 (93.0, 128.0)
Week 16
N | 12 | 2 | 14
Mean (SD) | 110.5 (9.0) | 128.0 (11.3) | 113.0 (10.9)
Median (Min-Max) | 112.0 (90.0, 123.0) | 128.0 (120.0, 136.0) | 112.5 (90.0, 136.0)
Week 20
N | 12 | 2 | 14
Mean (SD) | 111.8 (16.7) | 120.0 (17.0) | 112.9 (16.3)
Median (Min-Max) | 111.5 (80.0, 134.0) | 120.0 (108.0, 132.0) | 111.5 (80.0, 134.0)
Week 24
N | 11 | 2 | 13
Mean (SD) | 111.6 (13.7) | 123.0 (5.7) | 113.4 (13.3)
Median (Min-Max) | 110.0 (96.0, 136.0) | 123.0 (119.0, 127.0) | 118.0 (96.0, 136.0)
Week 28
N | 11 | 2 | 13
Mean (SD) | 110.4 (12.3) | 132.0 (12.7) | 113.7 (14.4)
Median (Min-Max) | 108.0 (96.0, 137.0) | 132.0 (123.0, 141.0) | 111.0 (96.0, 141.0)
LOCF
N | 17 | 14 | 31
Mean (SD) | 110.2 (11.7) | 116.3 (10.7) | 112.9 (11.5)
Median (Min-Max) | 107.0 (96.0, 137.0) | 114.0 (103.0, 141.0) | 111.0 (96.0, 141.0)
Change from Baseline to LOCF
N | 17 | 14 | 31
Mean (SD) | 1.4 (11.2) | 1.1 (14.7) | 1.3 (12.7)
Median (Min-Max) | −1.0 (−14.0, 26.0) | 1.0 (−20.0, 25.0) | 0.0 (−20.0, 26.0)

Note: Baseline is defined as Last visit of Long-Term Effectiveness Phase.

Table 14.3.4.3.3 Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received Group Systolic Blood Pressure Z Score Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 0.27 (1.04) | 0.57 (1.02) | 0.40 (1.03)
Median (Min-Max) | 0.26 (−1.60, 2.89) | 0.48 (−0.90, 2.68) | 0.38 (−1.60, 2.89)
Week 1
N | 17 | 13 | 30
Mean (SD) | 0.25 (0.98) | 1.03 (0.69) | 0.59 (0.94)
Median (Min-Max) | 0.62 (−1.50, 1.47) | 0.97 (−0.77, 2.23) | 0.87 (−1.50, 2.23)
Week 2
N | 16 | 14 | 30
Mean (SD) | 0.11 (1.22) | 0.65 (0.52) | 0.37 (0.98)
Median (Min-Max) | −0.03 (−2.15, 2.24) | 0.59 (−0.39, 1.51) | 0.44 (−2.15, 2.24)
Week 3
N | 13 | 9 | 22
Mean (SD) | 0.33 (1.40) | 1.37 (1.03) | 0.76 (1.34)
Median (Min-Max) | −0.08 (−1.04, 3.52) | 1.68 (−0.19, 2.92) | 0.80 (−1.04, 3.52)
Week 4
N | 13 | 12 | 25
Mean (SD) | 0.54 (1.03) | 0.54 (0.67) | 0.54 (0.86)
Median (Min-Max) | 0.52 (−1.23, 2.49) | 0.49 (−0.30, 1.61) | 0.52 (−1.23, 2.49)
Week 6
N | 13 | 8 | 21
Mean (SD) | 0.24 (0.95) | 0.08 (1.29) | 0.18 (1.06)
Median (Min-Max) | 0.14 (−1.52, 1.60) | −0.02 (−1.73, 1.98) | 0.13 (−1.73, 1.98)
Week 8
N | 13 | 3 | 16
Mean (SD) | 0.49 (1.24) | 0.28 (1.38) | 0.45 (1.22)
Median (Min-Max) | 0.43 (−2.48, 2.37) | −0.49 (−0.54, 1.88) | 0.39 (−2.48, 2.37)
Week 10
N | 11 | 2 | 13
Mean (SD) | 0.52 (1.17) | 1.70 (1.29) | 0.71 (1.21)
Median (Min-Max) | 0.59 (−1.53, 2.01) | 1.70 (0.78, 2.61) | 0.78 (−1.53, 2.61)
Week 12
N | 12 | 2 | 14
Mean (SD) | 0.46 (0.64) | 0.90 (0.17) | 0.52 (0.61)
Median (Min-Max) | 0.68 (−0.78, 1.23) | 0.90 (0.78, 1.02) | 0.78 (−0.78, 1.23)
Week 16
N | 12 | 2 | 14
Mean (SD) | 0.45 (0.80) | 1.45 (0.43) | 0.59 (0.83)
Median (Min-Max) | 0.59 (−0.87, 1.62) | 1.45 (1.15, 1.76) | 0.74 (−0.87, 1.76)
Week 20
N | 12 | 2 | 14
Mean (SD) | 0.55 (1.50) | 0.68 (0.98) | 0.57 (1.41)
Median (Min-Max) | 0.77 (−2.52, 2.46) | 0.68 (−0.01, 1.37) | 0.77 (−2.52, 2.46)
Week 24
N | 11 | 2 | 13
Mean (SD) | 0.55 (1.44) | 0.95 (0.09) | 0.61 (1.33)
Median (Min-Max) | 0.43 (−1.23, 3.49) | 0.95 (0.89, 1.02) | 0.89 (−1.23, 3.49)
Week 28
N | 11 | 2 | 13
Mean (SD) | 0.40 (1.12) | 1.87 (0.45) | 0.63 (1.17)
Median (Min-Max) | 0.46 (−1.06, 2.14) | 1.87 (1.55, 2.19) | 0.60 (−1.06, 2.19)
LOCF
N | 17 | 14 | 31
Mean (SD) | 0.32 (1.09) | 0.67 (0.97) | 0.48 (1.04)
Median (Min-Max) | 0.29 (−1.06, 2.14) | 0.74 (−0.94, 2.19) | 0.34 (−1.06, 2.19)
Change from Baseline to LOCF
N | 17 | 14 | 31
Mean (SD) | 0.05 (1.04) | 0.10 (1.38) | 0.07 (1.19)
Median (Min-Max) | −0.24 (−1.45, 2.24) | 0.09 (−1.89, 2.45) | −0.01 (−1.89, 2.45)

Note: Baseline is defined as Last visit of Long-Term Effectiveness Phase.

Height Z score at baseline is used to calculate blood pressure Z scores at all visits except week 28 and LOCF.

Table 14.3.4.3.4 Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received Group Diastolic Blood Pressure (mmHg) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 65.8 (10.8) | 66.6 (8.6) | 66.1 (9.7)
Median (Min-Max) | 63.0 (49.0, 85.0) | 66.5 (52.0, 81.0) | 65.0 (49.0, 85.0)
Week 1
N | 17 | 13 | 30
Mean (SD) | 65.1 (6.3) | 69.2 (8.0) | 66.9 (7.2)
Median (Min-Max) | 64.0 (52.0, 76.0) | 67.0 (58.0, 81.0) | 66.0 (52.0, 81.0)
Week 2
N | 16 | 14 | 30
Mean (SD) | 61.8 (8.9) | 71.1 (8.8) | 66.2 (9.9)
Median (Min-Max) | 63.0 (42.0, 74.0) | 71.5 (48.0, 82.0) | 69.0 (42.0, 82.0)
Week 3
N | 13 | 9 | 22
Mean (SD) | 64.6 (9.4) | 69.1 (7.8) | 66.5 (8.9)
Median (Min-Max) | 64.0 (50.0, 85.0) | 68.0 (58.0, 85.0) | 66.0 (50.0, 85.0)
Week 4
N | 13 | 12 | 25
Mean (SD) | 63.9 (4.9) | 68.4 (10.3) | 66.1 (8.1)
Median (Min-Max) | 64.0 (57.0, 75.0) | 67.5 (46.0, 84.0) | 66.0 (46.0, 84.0)
Week 6
N | 13 | 8 | 21
Mean (SD) | 62.5 (6.9) | 68.5 (8.4) | 64.8 (7.9)
Median (Min-Max) | 64.0 (50.0, 73.0) | 69.0 (57.0, 78.0) | 64.0 (50.0, 78.0)
Week 8
N | 13 | 3 | 16
Mean (SD) | 64.5 (8.4) | 71.0 (12.5) | 65.7 (9.2)
Median (Min-Max) | 66.0 (50.0, 76.0) | 70.0 (59.0, 84.0) | 66.0 (50.0, 84.0)
Week 10
N | 11 | 2 | 13
Mean (SD) | 64.8 (9.4) | 69.0 (14.1) | 65.5 (9.6)
Median (Min-Max) | 67.0 (50.0, 80.0) | 69.0 (59.0, 79.0) | 67.0 (50.0, 80.0)
Week 12
N | 12 | 2 | 14
Mean (SD) | 66.6 (8.8) | 70.5 (19.1) | 67.1 (9.8)
Median (Min-Max) | 68.5 (50.0, 80.0) | 70.5 (57.0, 84.0) | 68.5 (50.0, 84.0)
Week 16
N | 12 | 2 | 14
Mean (SD) | 67.0 (6.8) | 74.0 (12.7) | 68.0 (7.6)
Median (Min-Max) | 66.5 (58.0, 79.0) | 74.0 (65.0, 83.0) | 66.5 (58.0, 83.0)
Week 20
N | 12 | 2 | 14
Mean (SD) | 65.6 (7.7) | 72.5 (10.6) | 66.6 (8.1)
Median (Min-Max) | 65.0 (54.0, 78.0) | 72.5 (65.0, 80.0) | 65.5 (54.0, 80.0)
Week 24
N | 11 | 2 | 13
Mean (SD) | 70.7 (14.9) | 81.5 (3.5) | 72.4 (14.3)
Median (Min-Max) | 71.0 (53.0, 110.0) | 81.5 (79.0, 84.0) | 71.0 (53.0, 110.0)
Week 28
N | 11 | 2 | 13
Mean (SD) | 66.5 (7.4) | 78.0 (9.9) | 68.3 (8.5)
Median (Min-Max) | 64.0 (58.0, 81.0) | 78.0 (71.0, 85.0) | 65.0 (58.0, 85.0)
LOCF
N | 17 | 14 | 31
Mean (SD) | 64.9 (8.3) | 70.8 (7.6) | 67.5 (8.4)
Median (Min-Max) | 64.0 (50.0, 81.0) | 71.5 (58.0, 85.0) | 67.0 (50.0, 85.0)
Change from Baseline to LOCF
N | 17 | 14 | 31
Mean (SD) | −0.9 (9.2) | 4.2 (7.0) | 1.4 (8.5)
Median (Min-Max) | 0.0 (−20.0, 20.0) | 3.5 (−6.0, 19.0) | 1.0 (−20.0, 20.0)

Note: Baseline is defined as Last visit of Long-Term Effectiveness Phase.

Table 14.3.4.3.5 Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received Group Diastolic Blood Pressure Z Score Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 0.31 (1.05) | 0.23 (0.74) | 0.28 (0.91)
Median (Min-Max) | 0.31 (−1.12, 2.05) | 0.36 (−1.06, 1.28) | 0.33 (−1.12, 2.05)
Week 1
N | 17 | 13 | 30
Mean (SD) | 0.26 (0.59) | 0.45 (0.59) | 0.34 (0.59)
Median (Min-Max) | 0.07 (−0.86, 1.44) | 0.44 (−0.56, 1.45) | 0.38 (−0.86, 1.45)
Week 2
N | 16 | 14 | 30
Mean (SD) | −0.03 (0.88) | 0.64 (0.77) | 0.28 (0.88)
Median (Min-Max) | −0.05 (−1.72, 1.12) | 0.67 (−1.14, 1.62) | 0.46 (−1.72, 1.62)
Week 3
N | 13 | 9 | 22
Mean (SD) | 0.25 (0.92) | 0.41 (0.69) | 0.32 (0.82)
Median (Min-Max) | 0.11 (−1.04, 2.48) | 0.71 (−0.61, 1.54) | 0.27 (−1.04, 2.48)
Week 4
N | 13 | 12 | 25
Mean (SD) | 0.18 (0.43) | 0.34 (1.00) | 0.25 (0.75)
Median (Min-Max) | 0.17 (−0.42, 1.03) | 0.24 (−1.93, 2.16) | 0.17 (−1.93, 2.16)
Week 6
N | 13 | 8 | 21
Mean (SD) | 0.05 (0.71) | 0.34 (0.82) | 0.16 (0.75)
Median (Min-Max) | 0.06 (−1.19, 1.38) | 0.41 (−0.93, 1.62) | 0.11 (−1.19, 1.62)
Week 8
N | 13 | 3 | 16
Mean (SD) | 0.21 (0.81) | 0.42 (0.94) | 0.25 (0.81)
Median (Min-Max) | 0.25 (−1.16, 1.47) | 0.25 (−0.43, 1.44) | 0.25 (−1.16, 1.47)
Week 10
N | 11 | 2 | 13
Mean (SD) | 0.20 (0.89) | 0.28 (1.01) | 0.21 (0.86)
Median (Min-Max) | 0.44 (−1.20, 1.77) | 0.28 (−0.44, 0.99) | 0.44 (−1.20, 1.77)
Week 12
N | 12 | 2 | 14
Mean (SD) | 0.39 (0.77) | 0.40 (1.44) | 0.39 (0.81)
Median (Min-Max) | 0.45 (−1.17, 1.74) | 0.40 (−0.62, 1.42) | 0.45 (−1.17, 1.74)
Week 16
N | 12 | 2 | 14
Mean (SD) | 0.42 (0.67) | 0.71 (0.86) | 0.46 (0.67)
Median (Min-Max) | 0.22 (−0.44, 1.68) | 0.71 (0.10, 1.32) | 0.22 (−0.44, 1.68)
Week 20
N | 12 | 2 | 14
Mean (SD) | 0.29 (0.76) | 0.56 (0.67) | 0.33 (0.73)
Median (Min-Max) | 0.22 (−0.95, 1.45) | 0.56 (0.09, 1.04) | 0.24 (−0.95, 1.45)
Week 24
N | 11 | 2 | 13
Mean (SD) | 0.76 (1.46) | 1.36 (0.00) | 0.85 (1.35)
Median (Min-Max) | 0.66 (−1.04, 4.64) | 1.36 (1.36, 1.36) | 0.82 (−1.04, 4.64)
Week 28
N | 11 | 2 | 13
Mean (SD) | 0.37 (0.74) | 1.08 (0.51) | 0.48 (0.74)
Median (Min-Max) | 0.18 (−0.61, 2.07) | 1.08 (0.72, 1.44) | 0.31 (−0.61, 2.07)
LOCF
N | 17 | 14 | 31
Mean (SD) | 0.21 (0.78) | 0.60 (0.71) | 0.38 (0.76)
Median (Min-Max) | 0.06 (−1.04, 2.07) | 0.74 (−0.82, 1.62) | 0.30 (−1.04, 2.07)
Change from Baseline to LOCF
N | 17 | 14 | 31
Mean (SD) | −0.11 (0.79) | 0.37 (0.63) | 0.11 (0.75)
Median (Min-Max) | −0.01 (−1.74, 1.70) | 0.24 (−0.54, 1.78) | 0.08 (−1.74, 1.78)

Note: Baseline is defined as Last visit of Long-Term Effectiveness Phase.

Height Z score at baseline is used to calculate blood pressure Z scores at all visits except week 28 and LOCF.

Table 14.3.4.3.6 Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received Group Weight (kg) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 45.7 (12.0) | 65.7 (27.2) | 54.7 (22.3)
Median (Min-Max) | 47.3 (24.5, 60.8) | 63.7 (31.8, 115.3) | 52.8 (24.5, 115.3)
Week 1
N | 17 | 13 | 30
Mean (SD) | 46.2 (12.3) | 68.8 (27.0) | 56.0 (22.7)
Median (Min-Max) | 46.8 (24.2, 61.8) | 66.1 (31.9, 118.6) | 53.9 (24.2, 118.6)
Week 2
N | 16 | 14 | 30
Mean (SD) | 45.2 (12.3) | 66.2 (27.5) | 55.0 (23.0)
Median (Min-Max) | 45.7 (24.1, 61.8) | 64.3 (31.5, 116.4) | 52.0 (24.1, 116.4)
Week 3
N | 13 | 9 | 22
Mean (SD) | 42.4 (11.7) | 76.4 (24.6) | 56.3 (24.5)
Median (Min-Max) | 42.5 (24.4, 59.4) | 69.5 (44.3, 117.3) | 49.8 (24.4, 117.3)
Week 4
N | 13 | 12 | 25
Mean (SD) | 44.4 (12.9) | 71.9 (25.4) | 57.6 (24.0)
Median (Min-Max) | 45.1 (24.2, 61.2) | 67.6 (32.2, 116.5) | 54.0 (24.2, 116.5)
Week 6
N | 13 | 8 | 21
Mean (SD) | 43.0 (11.9) | 76.9 (25.0) | 55.9 (24.3)
Median (Min-Max) | 43.1 (24.5, 58.8) | 76.2 (44.5, 116.3) | 48.9 (24.5, 116.3)
Week 8
N | 13 | 3 | 16
Mean (SD) | 43.2 (12.0) | 89.3 (25.9) | 51.8 (23.5)
Median (Min-Max) | 43.2 (24.4, 58.6) | 84.5 (66.2, 117.3) | 46.1 (24.4, 117.3)
Week 10
N | 11 | 2 | 13
Mean (SD) | 44.7 (12.7) | 92.2 (38.0) | 52.0 (23.9)
Median (Min-Max) | 43.7 (24.8, 58.4) | 92.2 (65.3, 119.0) | 49.2 (24.8, 119.0)
Week 12
N | 12 | 2 | 14
Mean (SD) | 44.2 (12.7) | 92.1 (37.9) | 51.0 (23.4)
Median (Min-Max) | 44.0 (24.4, 59.5) | 92.1 (65.3, 118.9) | 46.3 (24.4, 118.9)
Week 16
N | 12 | 2 | 14
Mean (SD) | 44.5 (12.9) | 94.4 (37.4) | 51.6 (24.0)
Median (Min-Max) | 44.2 (24.5, 60.2) | 94.4 (68.0, 120.9) | 47.4 (24.5, 120.9)
Week 20
N | 12 | 2 | 14
Mean (SD) | 44.4 (12.9) | 97.2 (36.8) | 52.0 (24.7)
Median (Min-Max) | 44.4 (24.3, 59.7) | 97.2 (71.2, 123.3) | 48.2 (24.3, 123.3)
Week 24
N | 11 | 2 | 13
Mean (SD) | 44.6 (13.2) | 97.7 (36.2) | 52.7 (25.6)
Median (Min-Max) | 43.0 (24.7, 60.2) | 97.7 (72.1, 123.3) | 53.0 (24.7, 123.3)
Week 28
N | 11 | 2 | 13
Mean (SD) | 44.7 (13.2) | 99.7 (37.0) | 53.2 (26.2)
Median (Min-Max) | 44.0 (24.9, 62.0) | 99.7 (73.5, 125.8) | 52.0 (24.9, 125.8)
LOCF
N | 17 | 14 | 31
Mean (SD) | 47.5 (12.2) | 67.4 (28.3) | 56.5 (23.0)
Median (Min-Max) | 51.9 (24.9, 62.0) | 67.0 (31.5, 125.8) | 52.3 (24.9, 125.8)
Change from Baseline to LOCF
N | 17 | 14 | 31
Mean (SD) | 1.8 (3.5) | 1.7 (4.1) | 1.8 (3.7)
Median (Min-Max) | 1.6 (−8.8, 7.6) | 0.4 (−2.8, 11.4) | 1.4 (−8.8, 11.4)

Note: Baseline is defined as Last visit of Long-Term Effectiveness Phase.

Table 14.3.4.3.7 Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received Group Weight Z Score Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 0.70 (0.99) | 1.32 (1.20) | 0.98 (1.12)
Median (Min-Max) | 0.92 (−0.87, 2.98) | 1.35 (−0.58, 3.27) | 1.03 (−0.87, 3.27)
Week 1
N | 17 | 13 | 30
Mean (SD) | 0.73 (1.00) | 1.50 (1.11) | 1.07 (1.10)
Median (Min-Max) | 0.96 (−0.96, 2.98) | 1.41 (0.00, 3.27) | 1.11 (−0.96, 3.27)
Week 2
N | 16 | 14 | 30
Mean (SD) | 0.56 (0.87) | 1.33 (1.23) | 0.92 (1.10)
Median (Min-Max) | 0.87 (−0.99, 1.56) | 1.37 (−0.57, 3.29) | 0.99 (−0.99, 3.29)
Week 3
N | 13 | 9 | 22
Mean (SD) | 0.43 (0.86) | 1.88 (0.94) | 1.02 (1.14)
Median (Min-Max) | 0.86 (−0.88, 1.47) | 1.86 (0.37, 3.27) | 1.06 (−0.88, 3.27)
Week 4
N | 13 | 12 | 25
Mean (SD) | 0.78 (1.07) | 1.61 (1.06) | 1.18 (1.12)
Median (Min-Max) | 0.95 (−0.84, 3.02) | 1.63 (−0.02, 3.31) | 1.15 (−0.84, 3.31)
Week 6
N | 13 | 8 | 21
Mean (SD) | 0.52 (0.86) | 1.78 (0.82) | 1.00 (1.04)
Median (Min-Max) | 0.88 (−0.90, 1.44) | 1.89 (0.34, 2.87) | 1.13 (−0.90, 2.87)
Week 8
N | 13 | 3 | 16
Mean (SD) | 0.50 (0.90) | 2.18 (0.43) | 0.82 (1.06)
Median (Min-Max) | 0.91 (−1.02, 1.50) | 1.96 (1.91, 2.67) | 1.04 (−1.02, 2.67)
Week 10
N | 11 | 2 | 13
Mean (SD) | 0.46 (0.94) | 2.31 (0.57) | 0.75 (1.12)
Median (Min-Max) | 0.88 (−0.95, 1.52) | 2.31 (1.91, 2.72) | 0.94 (−0.95, 2.72)
Week 12
N | 12 | 2 | 14
Mean (SD) | 0.53 (0.95) | 2.30 (0.59) | 0.78 (1.10)
Median (Min-Max) | 0.93 (−1.02, 1.47) | 2.30 (1.88, 2.71) | 1.05 (−1.02, 2.71)
Week 16
N | 12 | 2 | 14
Mean (SD) | 0.52 (0.96) | 2.37 (0.54) | 0.78 (1.12)
Median (Min-Max) | 0.94 (−1.00, 1.55) | 2.37 (1.99, 2.76) | 1.04 (−1.00, 2.76)
Week 20
N | 12 | 2 | 14
Mean (SD) | 0.47 (0.98) | 2.46 (0.49) | 0.75 (1.17)
Median (Min-Max) | 0.85 (−1.07, 1.57) | 2.46 (2.11, 2.81) | 0.93 (−1.07, 2.81)
Week 24
N | 11 | 2 | 13
Mean (SD) | 0.49 (1.05) | 2.46 (0.48) | 0.80 (1.21)
Median (Min-Max) | 0.88 (−1.17, 1.67) | 2.46 (2.12, 2.80) | 0.92 (−1.17, 2.80)
Week 28
N | 11 | 2 | 13
Mean (SD) | 0.49 (1.01) | 2.50 (0.49) | 0.80 (1.20)
Median (Min-Max) | 0.76 (−1.12, 1.59) | 2.50 (2.16, 2.85) | 0.80 (−1.12, 2.85)
LOCF
N | 17 | 14 | 31
Mean (SD) | 0.67 (1.07) | 1.36 (1.21) | 0.98 (1.17)
Median (Min-Max) | 0.76 (−1.12, 3.02) | 1.34 (−0.57, 3.28) | 1.05 (−1.12, 3.28)
Change from Baseline to LOCF
N | 17 | 14 | 31
Mean (SD) | −0.03 (0.28) | 0.04 (0.14) | 0.00 (0.22)
Median (Min-Max) | 0.05 (−0.82, 0.28) | 0.01 (−0.12, 0.35) | 0.01 (−0.82, 0.35)

Note: Baseline is defined as Last visit of Long-Term Effectiveness Phase.

Table 14.3.4.3.8 Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received Group Height (cm) Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 149.5 (14.3) | 157.5 (15.1) | 153.1 (15.0)
Median (Min-Max) | 151.0 (123.5, 167.6) | 159.2 (133.6, 179.3) | 155.0 (123.5, 179.3)
LOCF
N | 16 | 12 | 28
Mean (SD) | 151.6 (15.0) | 157.0 (15.0) | 153.9 (15.0)
Median (Min-Max) | 150.8 (127.0, 172.9) | 158.2 (133.4, 178.5) | 155.0 (127.0, 178.5)
Change from Baseline to LOCF
N | 16 | 12 | 28
Mean (SD) | 2.6 (2.3) | −0.3 (0.7) | 1.4 (2.3)
Median (Min-Max) | 2.5 (0.0, 7.8) | 0.0 (−2.0, 0.5) | 0.5 (−2.0, 7.8)

Note: Baseline is defined as Last visit of Long-Term Effectiveness Phase.

Table 14.3.4.3.9 Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received Group Height Z Score Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 0.42 (1.07) | 0.43 (0.98) | 0.42 (1.02)
Median (Min-Max) | 0.25 (−1.16, 2.24) | 0.73 (−1.35, 2.13) | 0.35 (−1.35, 2.24)
LOCF
N | 16 | 12 | 28
Mean (SD) | 0.54 (1.06) | 0.31 (0.98) | 0.44 (1.01)
Median (Min-Max) | 0.49 (−0.82, 2.23) | 0.43 (−1.42, 2.13) | 0.48 (−1.42, 2.23)
Change from Baseline to LOCF
N | 16 | 12 | 28
Mean (SD) | 0.03 (0.21) | −0.13 (0.23) | −0.04 (0.23)
Median (Min-Max) | 0.01 (−0.44, 0.49) | −0.06 (−0.82, 0.01) | −0.02 (−0.82, 0.49)

Note: Baseline is defined as Last visit of Long-Term Effectiveness Phase.

Table 14.3.4.3.10 Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received Group BMI Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 20.2 (3.9) | 25.7 (7.8) | 22.7 (6.5)
Median (Min-Max) | 19.4 (14.6, 30.0) | 25.8 (16.6, 40.4) | 20.6 (14.6, 40.4)
LOCF
N | 16 | 12 | 28
Mean (SD) | 20.4 (3.9) | 26.6 (8.3) | 23.0 (6.8)
Median (Min-Max) | 20.3 (14.3, 30.4) | 26.8 (16.8, 43.8) | 21.0 (14.3, 43.8)
Change from Baseline to LOCF
N | 16 | 12 | 28
Mean (SD) | 0.1 (1.3) | 0.9 (1.7) | 0.5 (1.5)
Median (Min-Max) | 0.5 (−3.9, 1.5) | 0.3 (−0.3, 5.4) | 0.4 (−3.9, 5.4)

Note: Baseline is defined as Last visit of Long-Term Effectiveness Phase.

Table 14.3.4.3.11 Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received Group BMI Z Score Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline
N | 17 | 14 | 31
Mean (SD) | 0.64 (0.96) | 1.25 (1.10) | 0.91 (1.05)
Median (Min-Max) | 0.58 (−1.00, 2.58) | 1.57 (−0.46, 2.75) | 0.75 (−1.00, 2.75)
LOCF
N | 16 | 12 | 28
Mean (SD) | 0.60 (1.05) | 1.38 (1.05) | 0.93 (1.10)
Median (Min-Max) | 0.70 (−1.24, 2.60) | 1.58 (−0.49, 2.93) | 0.80 (−1.24, 2.93)
Change from Baseline to LOCF
N | 16 | 12 | 28
Mean (SD) | −0.06 (0.30) | 0.09 (0.18) | 0.00 (0.26)
Median (Min-Max) | 0.08 (−0.66, 0.32) | 0.03 (−0.13, 0.48) | 0.06 (−0.66, 0.48)

Note: Baseline is defined as Last visit of Long-Term Effectiveness Phase.

Table 14.3.4.4.1 Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received Group Heart Rate (beats/min) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 68.3 (8.5) | 77.9 (11.4) | 75.7 (11.3)
Median (Min-Max) | 68.0 (60.0, 77.0) | 81.5 (57.0, 88.0) | 77.0 (57.0, 88.0)
Week 1
N | 3 | 9 | 12
Mean (SD) | 75.7 (3.8) | 83.7 (5.6) | 81.7 (6.2)
Median (Min-Max) | 74.0 (73.0, 80.0) | 83.0 (76.0, 96.0) | 81.5 (73.0, 96.0)
Week 2
N | 3 | 9 | 12
Mean (SD) | 80.7 (9.1) | 82.3 (9.0) | 81.9 (8.6)
Median (Min-Max) | 82.0 (71.0, 89.0) | 82.0 (67.0, 100.0) | 82.0 (67.0, 100.0)
Week 3
N | 2 | 8 | 10
Mean (SD) | 69.0 (0.0) | 87.0 (10.4) | 83.4 (11.9)
Median (Min-Max) | 69.0 (69.0, 69.0) | 87.0 (74.0, 106.0) | 83.5 (69.0, 106.0)
Week 4
N | 2 | 8 | 10
Mean (SD) | 79.5 (0.7) | 84.8 (10.5) | 83.7 (9.5)
Median (Min-Max) | 79.5 (79.0, 80.0) | 86.0 (64.0, 97.0) | 83.0 (64.0, 97.0)
Week 6
N | 2 | 8 | 10
Mean (SD) | 81.0 (1.4) | 78.5 (8.0) | 79.0 (7.2)
Median (Min-Max) | 81.0 (80.0, 82.0) | 78.5 (65.0, 91.0) | 79.5 (65.0, 91.0)
Week 8
N | 2 | 7 | 9
Mean (SD) | 81.5 (3.5) | 81.3 (16.3) | 81.3 (14.2)
Median (Min-Max) | 81.5 (79.0, 84.0) | 83.0 (61.0, 105.0) | 83.0 (61.0, 105.0)
LOCF
N | 3 | 10 | 13
Mean (SD) | 81.7 (2.5) | 83.4 (14.9) | 83.0 (13.0)
Median (Min-Max) | 82.0 (79.0, 84.0) | 85.5 (61.0, 105.0) | 83.0 (61.0, 105.0)
Change from Baseline to LOCF
N | 3 | 10 | 13
Mean (SD) | 13.3 (7.4) | 5.5 (9.5) | 7.3 (9.4)
Median (Min-Max) | 16.0 (5.0, 19.0) | 8.0 (−7.0, 19.0) | 8.0 (−7.0, 19.0)

Note: Baseline is defined as Last visit of Discontinuation Phase.

Table 14.3.4.4.2 Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received Group Systolic Blood Pressure (mmHg) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 108.3 (5.1) | 112.5 (7.3) | 111.5 (6.9)
Median (Min-Max) | 107.0 (104.0, 114.0) | 112.5 (103.0, 125.0) | 112.0 (103.0, 125.0)
Week 1
N | 3 | 9 | 12
Mean (SD) | 115.3 (9.5) | 114.8 (11.3) | 114.9 (10.5)
Median (Min-Max) | 112.0 (108.0, 126.0) | 111.0 (103.0, 134.0) | 111.5 (103.0, 134.0)
Week 2
N | 3 | 9 | 12
Mean (SD) | 115.0 (5.3) | 110.9 (11.2) | 111.9 (10.0)
Median (Min-Max) | 117.0 (109.0, 119.0) | 112.0 (92.0, 126.0) | 113.0 (92.0, 126.0)
Week 3
N | 2 | 8 | 10
Mean (SD) | 109.0 (2.8) | 116.0 (10.5) | 114.6 (9.7)
Median (Min-Max) | 109.0 (107.0, 111.0) | 117.0 (100.0, 137.0) | 114.0 (100.0, 137.0)
Week 4
N | 2 | 8 | 10
Mean (SD) | 110.0 (7.1) | 112.5 (12.8) | 112.0 (11.6)
Median (Min-Max) | 110.0 (105.0, 115.0) | 106.5 (99.0, 133.0) | 106.5 (99.0, 133.0)
Week 6
N | 2 | 8 | 10
Mean (SD) | 116.0 (5.7) | 112.9 (9.8) | 113.5 (9.0)
Median (Min-Max) | 116.0 (112.0, 120.0) | 114.5 (97.0, 129.0) | 114.5 (97.0, 129.0)
Week 8
N | 2 | 7 | 9
Mean (SD) | 108.5 (4.9) | 114.0 (6.6) | 112.8 (6.5)
Median (Min-Max) | 108.5 (105.0, 112.0) | 116.0 (104.0, 122.0) | 114.0 (104.0, 122.0)
LOCF
N | 3 | 10 | 13
Mean (SD) | 111.3 (6.0) | 112.5 (6.0) | 112.2 (5.8)
Median (Min-Max) | 112.0 (105.0, 117.0) | 112.0 (104.0, 122.0) | 112.0 (104.0, 122.0)
Change from Baseline to LOCF
N | 3 | 10 | 13
Mean (SD) | 3.0 (2.0) | 0.0 (10.4) | 0.7 (9.2)
Median (Min-Max) | 3.0 (1.0, 5.0) | −2.5 (−12.0, 18.0) | 1.0 (−12.0, 18.0)

Note: Baseline is defined as Last visit of Discontinuation Phase.

Table 14.3.4.4.3 Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received Group Systolic Blood Pressure Z Score Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | −0.07 (0.60) | 0.38 (0.94) | 0.28 (0.87)
Median (Min-Max) | 0.21 (−0.75, 0.34) | −0.02 (−0.94, 1.98) | −0.01 (−0.94, 1.98)
Week 1
N | 3 | 9 | 12
Mean (SD) | 0.59 (0.88) | 0.51 (0.88) | 0.53 (0.84)
Median (Min-Max) | 0.81 (−0.38, 1.33) | 0.58 (−0.87, 1.96) | 0.70 (−0.87, 1.96)
Week 2
N | 3 | 9 | 12
Mean (SD) | 0.55 (0.08) | 0.13 (1.11) | 0.24 (0.97)
Median (Min-Max) | 0.53 (0.48, 0.64) | −0.23 (−1.35, 1.88) | 0.29 (−1.35, 1.88)
Week 3
N | 2 | 8 | 10
Mean (SD) | 0.11 (0.85) | 0.84 (0.78) | 0.69 (0.80)
Median (Min-Max) | 0.11 (−0.49, 0.71) | 0.73 (−0.21, 2.30) | 0.69 (−0.49, 2.30)
Week 4
N | 2 | 8 | 10
Mean (SD) | 0.21 (1.25) | 0.18 (1.06) | 0.18 (1.02)
Median (Min-Max) | 0.21 (−0.68, 1.09) | −0.18 (−1.35, 1.49) | −0.18 (−1.35, 1.49)
Week 6
N | 2 | 8 | 10
Mean (SD) | 0.76 (1.13) | 0.21 (0.90) | 0.32 (0.91)
Median (Min-Max) | 0.76 (−0.03, 1.56) | 0.12 (−0.78, 1.80) | 0.30 (−0.78, 1.80)
Week 8
N | 2 | 7 | 9
Mean (SD) | 0.07 (1.06) | 0.33 (0.69) | 0.27 (0.71)
Median (Min-Max) | 0.07 (−0.68, 0.82) | 0.13 (−0.69, 1.33) | 0.13 (−0.69, 1.33)
LOCF
N | 3 | 10 | 13
Mean (SD) | 0.21 (0.79) | 0.33 (0.68) | 0.30 (0.67)
Median (Min-Max) | 0.48 (−0.68, 0.82) | 0.44 (−0.69, 1.33) | 0.48 (−0.69, 1.33)
Change from Baseline to LOCF
N | 3 | 10 | 13
Mean (SD) | 0.27 (0.20) | −0.04 (0.99) | 0.03 (0.88)
Median (Min-Max) | 0.27 (0.07, 0.48) | −0.32 (−1.16, 1.64) | 0.07 (−1.16, 1.64)

Note: Baseline is defined as Last visit of Discontinuation Phase.

Table 14.3.4.4.4 Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received Group Diastolic Blood Pressure (mmHg) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 59.7 (4.6) | 70.4 (7.1) | 67.9 (7.9)
Median (Min-Max) | 57.0 (57.0, 65.0) | 72.5 (58.0, 78.0) | 68.0 (57.0, 78.0)
Week 1
N | 3 | 9 | 12
Mean (SD) | 64.7 (5.5) | 65.6 (7.7) | 65.3 (7.0)
Median (Min-Max) | 62.0 (61.0, 71.0) | 63.0 (55.0, 80.0) | 62.5 (55.0, 80.0)
Week 2
N | 3 | 9 | 12
Mean (SD) | 68.7 (4.9) | 67.3 (4.3) | 67.7 (4.2)
Median (Min-Max) | 71.0 (63.0, 72.0) | 67.0 (60.0, 73.0) | 67.5 (60.0, 73.0)
Week 3
N | 2 | 8 | 10
Mean (SD) | 59.0 (7.1) | 68.4 (6.1) | 66.5 (7.1)
Median (Min-Max) | 59.0 (54.0, 64.0) | 68.0 (61.0, 78.0) | 65.0 (54.0, 78.0)
Week 4
N | 2 | 8 | 10
Mean (SD) | 63.0 (0.0) | 69.9 (6.6) | 68.5 (6.5)
Median (Min-Max) | 63.0 (63.0, 63.0) | 69.5 (62.0, 79.0) | 66.5 (62.0, 79.0)
Week 6
N | 2 | 8 | 10
Mean (SD) | 65.0 (9.9) | 71.6 (9.2) | 70.3 (9.2)
Median (Min-Max) | 65.0 (58.0, 72.0) | 70.5 (59.0, 85.0) | 70.5 (58.0, 85.0)
Week 8
N | 2 | 7 | 9
Mean (SD) | 64.0 (1.4) | 72.3 (7.9) | 70.4 (7.7)
Median (Min-Max) | 64.0 (63.0, 65.0) | 72.0 (63.0, 84.0) | 67.0 (63.0, 84.0)
LOCF
N | 3 | 10 | 13
Mean (SD) | 66.7 (4.7) | 71.2 (7.3) | 70.2 (6.9)
Median (Min-Max) | 65.0 (63.0, 72.0) | 70.5 (62.0, 84.0) | 69.0 (62.0, 84.0)
Change from Baseline to LOCF
N | 3 | 10 | 13
Mean (SD) | 7.0 (1.0) | 0.8 (7.1) | 2.2 (6.7)
Median (Min-Max) | 7.0 (6.0, 8.0) | 1.0 (−12.0, 12.0) | 2.0 (−12.0, 12.0)

Note: Baseline is defined as Last visit of Discontinuation Phase.

Table 14.3.4.4.5 Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received Group Diastolic Blood Pressure Z Score Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | −0.34 (0.32) | 0.58 (0.74) | 0.37 (0.76)
Median (Min-Max) | −0.39 (−0.62, 0.00) | 0.74 (−0.82, 1.62) | 0.30 (−0.82, 1.62)
Week 1
N | 3 | 9 | 12
Mean (SD) | 0.10 (0.40) | 0.12 (0.57) | 0.12 (0.52)
Median (Min-Max) | 0.06 (−0.28, 0.52) | −0.09 (−0.42, 1.35) | −0.02 (−0.42, 1.35)
Week 2
N | 3 | 9 | 12
Mean (SD) | 0.45 (0.25) | 0.27 (0.45) | 0.32 (0.41)
Median (Min-Max) | 0.58 (0.15, 0.60) | 0.09 (−0.20, 1.07) | 0.26 (−0.20, 1.07)
Week 3
N | 2 | 8 | 10
Mean (SD) | −0.32 (0.80) | 0.46 (0.58) | 0.31 (0.67)
Median (Min-Max) | −0.32 (−0.89, 0.24) | 0.35 (−0.30, 1.61) | 0.26 (−0.89, 1.61)
Week 4
N | 2 | 8 | 10
Mean (SD) | 0.02 (0.18) | 0.45 (0.59) | 0.36 (0.56)
Median (Min-Max) | 0.02 (−0.11, 0.15) | 0.39 (−0.29, 1.30) | 0.26 (−0.29, 1.30)
Week 6
N | 2 | 8 | 10
Mean (SD) | 0.21 (1.07) | 0.59 (0.83) | 0.52 (0.83)
Median (Min-Max) | 0.21 (−0.54, 0.97) | 0.44 (−0.39, 1.88) | 0.44 (−0.54, 1.88)
Week 8
N | 2 | 7 | 9
Mean (SD) | 0.12 (0.32) | 0.67 (0.71) | 0.55 (0.67)
Median (Min-Max) | 0.12 (−0.11, 0.34) | 0.50 (−0.02, 1.80) | 0.34 (−0.11, 1.80)
LOCF
N | 3 | 10 | 13
Mean (SD) | 0.28 (0.36) | 0.63 (0.67) | 0.55 (0.62)
Median (Min-Max) | 0.34 (−0.11, 0.60) | 0.34 (−0.02, 1.80) | 0.34 (−0.11, 1.80)
Change from Baseline to LOCF
N | 3 | 10 | 13
Mean (SD) | 0.62 (0.11) | 0.05 (0.64) | 0.18 (0.61)
Median (Min-Max) | 0.60 (0.52, 0.73) | 0.08 (−1.10, 1.03) | 0.17 (−1.10, 1.03)

Note: Baseline is defined as Last visit of Discontinuation Phase.

Table 14.3.4.4.6 Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received Group Weight (kg) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 52.5 (11.8) | 60.9 (21.9) | 58.9 (19.9)
Median (Min-Max) | 59.2 (38.9, 59.4) | 59.8 (31.5, 91.3) | 59.2 (31.5, 91.3)
Week 1
N | 3 | 9 | 12
Mean (SD) | 52.8 (12.3) | 62.4 (23.2) | 60.0 (20.9)
Median (Min-Max) | 59.5 (38.6, 60.2) | 65.5 (30.8, 91.6) | 59.9 (30.8, 91.6)
Week 2
N | 3 | 9 | 12
Mean (SD) | 52.6 (12.2) | 64.9 (20.5) | 61.8 (19.0)
Median (Min-Max) | 59.3 (38.6, 60.0) | 65.7 (33.1, 93.0) | 59.7 (33.1, 93.0)
Week 3
N | 2 | 8 | 10
Mean (SD) | 50.4 (17.6) | 59.7 (22.8) | 57.8 (21.3)
Median (Min-Max) | 50.4 (38.0, 62.8) | 58.7 (32.2, 93.3) | 56.8 (32.2, 93.3)
Week 4
N | 2 | 8 | 10
Mean (SD) | 50.3 (17.0) | 67.1 (21.7) | 63.8 (21.2)
Median (Min-Max) | 50.3 (38.3, 62.4) | 68.9 (33.2, 94.6) | 64.4 (33.2, 94.6)
Week 6
N | 2 | 8 | 10
Mean (SD) | 50.1 (15.0) | 67.2 (21.7) | 63.8 (21.0)
Median (Min-Max) | 50.1 (39.5, 60.7) | 68.9 (33.3, 95.0) | 63.3 (33.3, 95.0)
Week 8
N | 2 | 7 | 9
Mean (SD) | 49.0 (15.8) | 65.1 (23.0) | 61.6 (21.9)
Median (Min-Max) | 49.0 (37.8, 60.2) | 65.5 (32.6, 97.0) | 60.2 (32.6, 97.0)
LOCF
N | 3 | 10 | 13
Mean (SD) | 52.4 (12.7) | 62.2 (22.7) | 59.9 (20.8)
Median (Min-Max) | 59.3 (37.8, 60.2) | 58.9 (32.2, 97.0) | 59.3 (32.2, 97.0)
Change from Baseline to LOCF
N | 3 | 10 | 13
Mean (SD) | −0.1 (1.0) | 1.3 (2.3) | 1.0 (2.1)
Median (Min-Max) | 0.1 (−1.1, 0.8) | 1.0 (−1.7, 5.7) | 0.7 (−1.7, 5.7)

Note: Baseline is defined as Last visit of Discontinuation Phase.

Table 14.3.4.4.7 Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received Group Weight Z Score Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 1.06 (0.47) | 1.18 (1.05) | 1.15 (0.93)
Median (Min-Max) | 1.05 (0.58, 1.53) | 1.26 (−0.05, 3.28) | 1.20 (−0.05, 3.28)
Week 1
N | 3 | 9 | 12
Mean (SD) | 1.04 (0.53) | 1.16 (1.16) | 1.13 (1.02)
Median (Min-Max) | 1.06 (0.49, 1.56) | 1.33 (−0.23, 3.28) | 1.20 (−0.23, 3.28)
Week 2
N | 3 | 9 | 12
Mean (SD) | 1.03 (0.51) | 1.35 (1.02) | 1.27 (0.91)
Median (Min-Max) | 1.10 (0.49, 1.50) | 1.35 (−0.11, 3.31) | 1.31 (−0.11, 3.31)
Week 3
N | 2 | 8 | 10
Mean (SD) | 0.84 (0.60) | 1.28 (1.04) | 1.19 (0.96)
Median (Min-Max) | 0.84 (0.42, 1.26) | 1.36 (0.02, 3.31) | 1.29 (0.02, 3.31)
Week 4
N | 2 | 8 | 10
Mean (SD) | 0.84 (0.55) | 1.36 (1.11) | 1.26 (1.02)
Median (Min-Max) | 0.84 (0.46, 1.23) | 1.42 (−0.13, 3.32) | 1.29 (−0.13, 3.32)
Week 6
N | 2 | 8 | 10
Mean (SD) | 0.83 (0.39) | 1.35 (1.12) | 1.25 (1.02)
Median (Min-Max) | 0.83 (0.55, 1.11) | 1.41 (−0.13, 3.33) | 1.22 (−0.13, 3.33)
Week 8
N | 2 | 7 | 9
Mean (SD) | 0.69 (0.49) | 1.25 (1.22) | 1.13 (1.10)
Median (Min-Max) | 0.69 (0.35, 1.04) | 1.26 (−0.25, 3.35) | 1.04 (−0.25, 3.35)
LOCF
N | 3 | 10 | 13
Mean (SD) | 0.96 (0.58) | 1.19 (1.09) | 1.14 (0.98)
Median (Min-Max) | 1.04 (0.35, 1.50) | 1.29 (−0.25, 3.35) | 1.26 (−0.25, 3.35)
Change from Baseline to LOCF
N | 3 | 10 | 13
Mean (SD) | −0.09 (0.12) | 0.01 (0.12) | −0.01 (0.12)
Median (Min-Max) | −0.03 (−0.24, −0.02) | 0.03 (−0.23, 0.20) | −0.02 (−0.24, 0.20)

Note: Baseline is defined as Last visit of Discontinuation Phase.

Table 14.3.4.4.8 Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received Group Height (cm) Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 159.1 (14.4) | 156.0 (16.0) | 156.7 (15.1)
Median (Min-Max) | 166.9 (142.5, 167.8) | 158.2 (133.4, 178.5) | 161.3 (133.4, 178.5)
Week 8
N | 2 | 7 | 9
Mean (SD) | 155.1 (17.7) | 161.9 (13.2) | 160.4 (13.4)
Median (Min-Max) | 155.1 (142.5, 167.6) | 161.3 (139.5, 179.6) | 161.3 (139.5, 179.6)
LOCF
N | 2 | 9 | 11
Mean (SD) | 155.1 (17.7) | 156.2 (16.2) | 156.0 (15.5)
Median (Min-Max) | 155.1 (142.5, 167.6) | 156.2 (135.1, 179.6) | 156.2 (135.1, 179.6)
Change from Baseline to LOCF
N | 2 | 9 | 11
Mean (SD) | 0.3 (0.5) | 1.4 (1.3) | 1.2 (1.2)
Median (Min-Max) | 0.3 (0.0, 0.7) | 1.1 (0.0, 3.5) | 1.1 (0.0, 3.5)

Note: Baseline is defined as Last visit of Discontinuation Phase.

Table 14.3.4.4.9 Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received Group Height Z Score Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 1.17 (0.92) | 0.44 (1.00) | 0.61 (1.00)
Median (Min-Max) | 0.99 (0.35, 2.17) | 0.69 (−1.42, 2.13) | 0.78 (−1.42, 2.17)
Week 8
N | 2 | 7 | 9
Mean (SD) | 0.56 (0.50) | 0.89 (0.74) | 0.81 (0.68)
Median (Min-Max) | 0.56 (0.21, 0.91) | 0.79 (−0.05, 2.20) | 0.79 (−0.05, 2.20)
LOCF
N | 2 | 9 | 11
Mean (SD) | 0.56 (0.50) | 0.50 (1.04) | 0.51 (0.94)
Median (Min-Max) | 0.56 (0.21, 0.91) | 0.59 (−1.41, 2.20) | 0.59 (−1.41, 2.20)
Change from Baseline to LOCF
N | 2 | 9 | 11
Mean (SD) | −0.11 (0.05) | 0.10 (0.17) | 0.06 (0.17)
Median (Min-Max) | −0.11 (−0.14, −0.08) | 0.05 (−0.03, 0.48) | 0.01 (−0.14, 0.48)

Note: Baseline is defined as Last visit of Discontinuation Phase.

Table 14.3.4.4.10 Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received Group BMI Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 20.5 (1.2) | 24.5 (6.7) | 23.5 (6.0)
Median (Min-Max) | 21.1 (19.2, 21.3) | 24.6 (16.8, 38.2) | 21.3 (16.8, 38.2)
Week 8
N | 2 | 7 | 9
Mean (SD) | 20.0 (2.0) | 24.5 (8.0) | 23.5 (7.2)
Median (Min-Max) | 20.0 (18.6, 21.4) | 21.9 (16.7, 39.8) | 21.4 (16.7, 39.8)
LOCF
N | 2 | 9 | 11
Mean (SD) | 20.0 (2.0) | 24.1 (7.5) | 23.4 (6.9)
Median (Min-Max) | 20.0 (18.6, 21.4) | 21.9 (16.7, 39.8) | 21.4 (16.7, 39.8)
Change from Baseline to LOCF
N | 2 | 9 | 11
Mean (SD) | −0.3 (0.5) | 0.3 (0.9) | 0.2 (0.9)
Median (Min-Max) | −0.3 (−0.6, 0.1) | 0.1 (−0.9, 1.6) | 0.1 (−0.9, 1.6)

Note: Baseline is defined as Last visit of Discontinuation Phase.

Table 14.3.4.4.11 Summary of Vital Signs by Visit and Discontinuation Phase Treatment Received Group BMI Z Score Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline
N | 3 | 10 | 13
Mean (SD) | 0.86 (0.12) | 1.14 (0.97) | 1.08 (0.85)
Median (Min-Max) | 0.84 (0.74, 0.99) | 1.29 (−0.49, 2.69) | 0.99 (−0.49, 2.69)
Week 8
N | 2 | 7 | 9
Mean (SD) | 0.68 (0.22) | 0.97 (1.16) | 0.91 (1.02)
Median (Min-Max) | 0.68 (0.53, 0.84) | 0.88 (−0.79, 2.72) | 0.84 (−0.79, 2.72)
LOCF
N | 2 | 9 | 11
Mean (SD) | 0.68 (0.22) | 1.02 (1.11) | 0.96 (1.00)
Median (Min-Max) | 0.68 (0.53, 0.84) | 0.88 (−0.79, 2.72) | 0.84 (−0.79, 2.72)
Change from Baseline to LOCF
N | 2 | 9 | 11
Mean (SD) | −0.11 (0.14) | −0.06 (0.17) | −0.07 (0.16)
Median (Min-Max) | −0.11 (−0.21, −0.01) | −0.01 (−0.29, 0.20) | −0.01 (−0.29, 0.20)

Note: Baseline is defined as Last visit of Discontinuation Phase.

Table 14.3.5.1 Summary of ECG Results by Age Strata and Efficacy Phase Treatment Received Group Efficacy Phase - Safety Population

Week 8/LOCF | 7 – 11 yrs | | 12 – 17 yrs | | Total
Week 8/LOCF | Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Heart Rate (bpm)
N | 30 | 14 | 20 | 10 | 50 | 24
Mean (SD) | 77.3 (10.6) | 76.1 (11.0) | 72.7 (13.5) | 61.8 (6.0) | 75.5 (11.9) | 70.2 (11.6)
Median (Min-Max) | 77.5 (54.0 – 98.0) | 74.5 (60.0 – 92.0) | 74.5 (50.0 – 98.0) | 61.0 (53.0 – 72.0) | 76.0 (50.0 – 98.0) | 67.0 (53.0 – 92.0)
PR Interval (ms)
N | 30 | 14 | 20 | 10 | 50 | 24
Mean (SD) | 158.4 (24.4) | 134.3 (16.6) | 146.8 (19.6) | 130.8 (10.7) | 153.8 (23.1) | 132.8 (14.3)
Median (Min-Max) | 155.0 (116.0 – 234.0) | 134.0 (112.0 – 172.0) | 145.0 (116.0 – 180.0) | 128.0 (118.0 – 152.0) | 153.0 (116.0 – 234.0) | 130.0 (112.0 – 172.0)
QRS (ms)
N | 30 | 14 | 20 | 10 | 50 | 24
Mean (SD) | 84.8 (8.4) | 81.9 (6.6) | 89.9 (12.0) | 88.5 (10.3) | 86.9 (10.2) | 84.6 (8.8)
Median (Min-Max) | 84.5 (66.0 – 101.0) | 83.0 (70.0 – 90.0) | 88.5 (72.0 – 118.0) | 89.0 (69.0 – 102.0) | 86.0 (66.0 – 118.0) | 84.0 (69.0 – 102.0)
QT (ms)
N | 30 | 14 | 20 | 10 | 50 | 24
Mean (SD) | 377.9 (22.5) | 371.0 (26.6) | 385.7 (35.8) | 396.6 (23.1) | 381.0 (28.5) | 381.7 (27.8)
Median (Min-Max) | 371.0 (344.0 – 430.0) | 373.0 (330.0 – 420.0) | 388.0 (300.0 – 462.0) | 402.0 (346.0 – 420.0) | 378.0 (300.0 – 462.0) | 388.0 (330.0 – 420.0)
QTC (ms)
N | 30 | 14 | 20 | 10 | 50 | 24
Mean (SD) | 417.4 (20.6) | 404.1 (16.4) | 416.6 (27.7) | 398.6 (19.4) | 417.1 (23.5) | 401.8 (17.5)
Median (Min-Max) | 411.0 (389.0 – 473.0) | 404.5 (380.0 – 437.0) | 413.0 (378.0 – 468.0) | 402.5 (354.0 – 421.0) | 411.0 (378.0 – 473.0) | 402.5 (354.0 – 437.0)
Investigator Interpretation
Normal | 26 (81.3%) | 10 (58.8%) | 13 (61.9%) | 8 (72.7%) | 39 (73.6%) | 18 (64.3%)
Abnormal - Not clinically significant | 4 (12.5%) | 4 (23.5%) | 7 (33.3%) | 2 (18.2%) | 11 (20.8%) | 6 (21.4%)
Abnormal - Clinically significant | 0 | 0 | 0 | 0 | 0 | 0
ECG Not Completed | 2 (6.3%) | 3 (17.6%) | 1 (4.8%) | 1 (9.1%) | 3 (5.7%) | 4 (14.3%)

Table 14.3.5.2A Summary of ECG Results by Age Strata Long-Term Effectiveness Phase - Safety Population

Week 24/LOCF | Age Strata | | Total; (N=44)
Week 24/LOCF | 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Heart Rate (bpm)
N | 26 | 13 | 39
Mean (SD) | 79.8 (15.2) | 73.1 (13.9) | 77.6 (15.0)
Median (Min-Max) | 80.0 (46.0 – 110.0) | 73.0 (50.0 – 98.0) | 77.0 (46.0 – 110.0)
PR Interval (ms)
N | 25 | 13 | 38
Mean (SD) | 152.6 (23.0) | 153.7 (27.8) | 153.0 (24.4)
Median (Min-Max) | 152.0 (114.0 – 196.0) | 148.0 (118.0 – 198.0) | 151.0 (114.0 – 198.0)
QRS (ms)
N | 26 | 13 | 39
Mean (SD) | 84.5 (8.7) | 90.3 (10.3) | 86.5 (9.5)
Median (Min-Max) | 84.0 (70.0 – 104.0) | 90.0 (74.0 – 108.0) | 86.0 (70.0 – 108.0)
QT (ms)
N | 26 | 13 | 39
Mean (SD) | 369.7 (29.9) | 393.8 (28.4) | 377.7 (31.2)
Median (Min-Max) | 371.0 (320.0 – 446.0) | 394.0 (350.0 – 450.0) | 376.0 (320.0 – 450.0)
QTC (ms)
N | 26 | 13 | 39
Mean (SD) | 411.8 (20.8) | 421.2 (16.5) | 415.0 (19.8)
Median (Min-Max) | 409.0 (376.0 – 463.0) | 416.0 (402.0 – 456.0) | 413.0 (376.0 – 463.0)
Investigator Interpretation
Normal | 21 (72.4%) | 10 (66.7%) | 31 (70.5%)
Abnormal - Not clinically significant | 5 (17.2%) | 3 (20.0%) | 8 (18.2%)
Abnormal - Clinically significant | 0 | 0 | 0
ECG Not Completed | 3 (10.3%) | 2 (13.3%) | 5 (11.4%)

Table 14.3.5.2B Summary of ECG Results by Efficacy Phase Treatment Received Group Long-Term Effectiveness Phase - Safety Population

Week 24/LOCF | Efficacy Phase Treatment Received Group | | Total; (N=44)
Week 24/LOCF | Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Heart Rate (bpm)
N | 26 | 13 | 39
Mean (SD) | 79.8 (16.5) | 73.1 (10.6) | 77.6 (15.0)
Median (Min-Max) | 80.0 (46.0 – 110.0) | 73.0 (54.0 – 91.0) | 77.0 (46.0 – 110.0)
PR Interval (ms)
N | 25 | 13 | 38
Mean (SD) | 157.4 (26.5) | 144.6 (17.9) | 153.0 (24.4)
Median (Min-Max) | 156.0 (114.0 – 198.0) | 142.0 (118.0 – 180.0) | 151.0 (114.0 – 198.0)
QRS (ms)
N | 26 | 13 | 39
Mean (SD) | 86.5 (10.5) | 86.3 (7.6) | 86.5 (9.5)
Median (Min-Max) | 85.0 (70.0 – 108.0) | 86.0 (70.0 – 104.0) | 86.0 (70.0 – 108.0)
QT (ms)
N | 26 | 13 | 39
Mean (SD) | 374.5 (34.6) | 384.3 (22.7) | 377.7 (31.2)
Median (Min-Max) | 368.0 (320.0 – 450.0) | 380.0 (340.0 – 428.0) | 376.0 (320.0 – 450.0)
QTC (ms)
N | 26 | 13 | 39
Mean (SD) | 417.5 (22.6) | 409.9 (11.3) | 415.0 (19.8)
Median (Min-Max) | 416.5 (376.0 – 463.0) | 409.0 (390.0 – 431.0) | 413.0 (376.0 – 463.0)
Investigator Interpretation
Normal | 20 (69.0%) | 11 (73.3%) | 31 (70.5%)
Abnormal - Not clinically significant | 6 (20.7%) | 2 (13.3%) | 8 (18.2%)
Abnormal - Clinically significant | 0 | 0 | 0
ECG Not Completed | 3 (10.3%) | 2 (13.3%) | 5 (11.4%)

Table 14.3.5.3 Summary of ECG Results by Discontinuation Phase Treatment Received Group Discontinuation phase - Safety Population

Week 28/LOCF | Discontinuation Phase Treatment Received Group | | Total; (N=31)
Week 28/LOCF | Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Heart Rate (bpm)
N | 16 | 12 | 28
Mean (SD) | 71.4 (13.6) | 74.3 (11.2) | 72.7 (12.5)
Median (Min-Max) | 71.0 (50.0 – 99.0) | 76.0 (58.0 – 94.0) | 72.5 (50.0 – 99.0)
PR Interval (ms)
N | 16 | 12 | 28
Mean (SD) | 147.0 (21.1) | 151.5 (20.0) | 148.9 (20.4)
Median (Min-Max) | 154.0 (114.0 – 182.0) | 149.0 (124.0 – 184.0) | 151.0 (114.0 – 184.0)
QRS (ms)
N | 16 | 12 | 28
Mean (SD) | 87.8 (9.7) | 81.8 (15.3) | 85.2 (12.5)
Median (Min-Max) | 88.0 (74.0 – 112.0) | 81.0 (49.0 – 106.0) | 86.0 (49.0 – 112.0)
QT (ms)
N | 16 | 12 | 28
Mean (SD) | 389.0 (32.0) | 378.9 (21.4) | 384.7 (28.0)
Median (Min-Max) | 394.0 (326.0 – 442.0) | 381.0 (348.0 – 414.0) | 384.5 (326.0 – 442.0)
QTC (ms)
N | 16 | 12 | 28
Mean (SD) | 412.5 (22.4) | 408.8 (13.0) | 410.9 (18.7)
Median (Min-Max) | 409.0 (375.0 – 462.0) | 406.0 (390.0 – 435.0) | 408.0 (375.0 – 462.0)
Investigator Interpretation
Normal | 12 (70.6%) | 9 (64.3%) | 21 (67.7%)
Abnormal - Not clinically significant | 4 (23.5%) | 3 (21.4%) | 7 (22.6%)
Abnormal - Clinically significant | 0 | 0 | 0
ECG Not Completed | 1 (5.9%) | 2 (14.3%) | 3 (9.7%)

Table 14.3.5.4 Summary of ECG Results by Discontinuation Phase Treatment Received Group Restabilization Phase - Safety Population

Week 8/LOCF | Discontinuation Phase Treatment Received Group | | Total; (N=13)
Week 8/LOCF | Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Heart Rate (bpm)
N | 2 | 9 | 11
Mean (SD) | 72.0 (7.1) | 78.7 (13.2) | 77.5 (12.3)
Median (Min-Max) | 72.0 (67.0 – 77.0) | 77.0 (60.0 – 99.0) | 77.0 (60.0 – 99.0)
PR Interval (ms)
N | 2 | 9 | 11
Mean (SD) | 188.0 (11.3) | 158.9 (15.5) | 164.2 (18.6)
Median (Min-Max) | 188.0 (180.0 – 196.0) | 158.0 (138.0 – 186.0) | 162.0 (138.0 – 196.0)
QRS (ms)
N | 2 | 9 | 11
Mean (SD) | 84.0 (14.1) | 85.6 (10.3) | 85.3 (10.3)
Median (Min-Max) | 84.0 (74.0 – 94.0) | 84.0 (72.0 – 104.0) | 84.0 (72.0 – 104.0)
QT (ms)
N | 2 | 9 | 11
Mean (SD) | 391.0 (18.4) | 379.8 (19.2) | 381.8 (18.7)
Median (Min-Max) | 391.0 (378.0 – 404.0) | 388.0 (348.0 – 406.0) | 388.0 (348.0 – 406.0)
QTC (ms)
N | 2 | 9 | 11
Mean (SD) | 411.5 (6.4) | 419.9 (19.8) | 418.4 (18.2)
Median (Min-Max) | 411.5 (407.0 – 416.0) | 420.0 (391.0 – 447.0) | 417.0 (391.0 – 447.0)
Investigator Interpretation
Normal | 2 (66.7%) | 8 (80.0%) | 10 (76.9%)
Abnormal - Not clinically significant | 0 | 1 (10.0%) | 1 (7.7%)
Abnormal - Clinically significant | 0 | 0 | 0
ECG Not Completed | 1 (33.3%) | 1 (10.0%) | 2 (15.4%)

Table 14.3.6.1 Summary of Neurologic Rating Scale by Age Strata and Efficacy Phase Treatment Received Group Efficacy Phase - Safety Population

NRS | 7 – 11 yrs | | 12 – 17 yrs | | Total
NRS | Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline Score
0 | 31 (96.9%) | 17 (100.0%) | 17 (81.0%) | 11 (100.0%) | 48 (90.6%) | 28 (100.0%)
1 | 0 | 0 | 2 (9.5%) | 0 | 2 (3.8%) | 0
2 | 0 | 0 | 0 | 0 | 0 | 0
3 | 1 (3.1%) | 0 | 1 (4.8%) | 0 | 2 (3.8%) | 0
4 | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Week 1 Score
0 | 28 (93.3%) | 16 (94.1%) | 19 (86.4%) | 11 (100.0%) | 47 (90.4%) | 27 (96.4%)
1 | 2 (6.7%) | 1 (5.9%) | 2 (9.1%) | 0 | 4 (7.7%) | 1 (3.6%)
2 | 0 | 0 | 1 (4.5%) | 0 | 1 (1.9%) | 0
Week 2 Score
0 | 26 (92.9%) | 17 (100.0%) | 16 (88.9%) | 10 (100.0%) | 42 (91.3%) | 27 (100.0%)
1 | 2 (7.1%) | 0 | 1 (5.6%) | 0 | 3 (6.5%) | 0
2 | 0 | 0 | 1 (5.6%) | 0 | 1 (2.2%) | 0
Week 3 Score
0 | 26 (92.9%) | 13 (92.9%) | 13 (86.7%) | 9 (100.0%) | 39 (90.7%) | 22 (95.7%)
1 | 2 (7.1%) | 1 (7.1%) | 2 (13.3%) | 0 | 4 (9.3%) | 1 (4.3%)
Week 4 Score
0 | 27 (100.0%) | 12 (92.3%) | 13 (76.5%) | 10 (100.0%) | 40 (90.9%) | 22 (95.7%)
1 | 0 | 1 (7.7%) | 3 (17.6%) | 0 | 3 (6.8%) | 1 (4.3%)
2 | 0 | 0 | 1 (5.9%) | 0 | 1 (2.3%) | 0
Week 5 Score
0 | 13 (100.0%) | 4 (100.0%) | 5 (71.4%) | 4 (100.0%) | 18 (90.0%) | 8 (100.0%)
1 | 0 | 0 | 2 (28.6%) | 0 | 2 (10.0%) | 0
Week 6 Score
0 | 25 (96.2%) | 11 (91.7%) | 10 (76.9%) | 10 (100.0%) | 35 (89.7%) | 21 (95.5%)
1 | 1 (3.8%) | 1 (8.3%) | 3 (23.1%) | 0 | 4 (10.3%) | 1 (4.5%)
Week 7 Score
0 | 12 (100.0%) | 4 (100.0%) | 5 (62.5%) | 4 (100.0%) | 17 (85.0%) | 8 (100.0%)
1 | 0 | 0 | 2 (25.0%) | 0 | 2 (10.0%) | 0
2 | 0 | 0 | 0 | 0 | 0 | 0
3 | 0 | 0 | 0 | 0 | 0 | 0
4 | 0 | 0 | 0 | 0 | 0 | 0
>4 | 0 | 0 | 1 (12.5%) | 0 | 1 (5.0%) | 0
Week 8 Score
0 | 24 (100.0%) | 11 (100.0%) | 9 (69.2%) | 10 (100.0%) | 33 (89.2%) | 21 (100.0%)
1 | 0 | 0 | 3 (23.1%) | 0 | 3 (8.1%) | 0
2 | 0 | 0 | 0 | 0 | 0 | 0
3 | 0 | 0 | 0 | 0 | 0 | 0
4 | 0 | 0 | 0 | 0 | 0 | 0
>4 | 0 | 0 | 1 (7.7%) | 0 | 1 (2.7%) | 0
LOCF Score
0 | 31 (96.9%) | 16 (94.1%) | 16 (76.2%) | 11 (100.0%) | 47 (88.7%) | 27 (96.4%)
1 | 1 (3.1%) | 1 (5.9%) | 3 (14.3%) | 0 | 4 (7.5%) | 1 (3.6%)
2 | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
3 | 0 | 0 | 0 | 0 | 0 | 0
>4 | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0

Note: Baseline is defined as first visit of Efficacy phase.

Participant [▬] had a NRS total score of 10 at Week 7 and 5 at Week 8.

Table 14.3.6.2A Summary of Neurologic Rating Scale by Age Strata Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline Score
0 | 29 (100.0%) | 13 (86.7%) | 42 (95.5%)
1 | 0 | 2 (13.3%) | 2 (4.5%)
Week 1 Score
0 | 24 (96.0%) | 11 (84.6%) | 35 (92.1%)
1 | 1 (4.0%) | 1 (7.7%) | 2 (5.3%)
2 | 0 | 1 (7.7%) | 1 (2.6%)
Week 2 Score
0 | 28 (100.0%) | 12 (85.7%) | 40 (95.2%)
1 | 0 | 1 (7.1%) | 1 (2.4%)
2 | 0 | 1 (7.1%) | 1 (2.4%)
Week 4 Score
0 | 24 (100.0%) | 12 (92.3%) | 36 (97.3%)
1 | 0 | 0 | 0
2 | 0 | 1 (7.7%) | 1 (2.7%)
Week 6 Score
0 | 25 (100.0%) | 12 (92.3%) | 37 (97.4%)
1 | 0 | 0 | 0
2 | 0 | 1 (7.7%) | 1 (2.6%)
Week 8 Score
0 | 24 (100.0%) | 10 (83.3%) | 34 (94.4%)
1 | 0 | 1 (8.3%) | 1 (2.8%)
2 | 0 | 1 (8.3%) | 1 (2.8%)
Week 10 Score
0 | 23 (100.0%) | 9 (100.0%) | 32 (100.0%)
Week 12 Score
0 | 24 (100.0%) | 6 (85.7%) | 30 (96.8%)
1 | 0 | 0 | 0
2 | 0 | 1 (14.3%) | 1 (3.2%)
Week 14 Score
0 | 20 (100.0%) | 6 (85.7%) | 26 (96.3%)
1 | 0 | 0 | 0
2 | 0 | 1 (14.3%) | 1 (3.7%)
Week 16 Score
0 | 19 (95.0%) | 7 (100.0%) | 26 (96.3%)
1 | 1 (5.0%) | 0 | 1 (3.7%)
Week 18 Score
0 | 19 (100.0%) | 6 (85.7%) | 25 (96.2%)
1 | 0 | 0 | 0
2 | 0 | 1 (14.3%) | 1 (3.8%)
Week 20 Score
0 | 18 (100.0%) | 5 (83.3%) | 23 (95.8%)
1 | 0 | 1 (16.7%) | 1 (4.2%)
Week 22 Score
0 | 16 (100.0%) | 5 (100.0%) | 21 (100.0%)
Week 24 Score
0 | 16 (94.1%) | 6 (100.0%) | 22 (95.7%)
1 | 0 | 0 | 0
2 | 1 (5.9%) | 0 | 1 (4.3%)
LOCF Score
0 | 26 (92.9%) | 13 (92.9%) | 39 (92.9%)
1 | 1 (3.6%) | 1 (7.1%) | 2 (4.8%)
2 | 1 (3.6%) | 0 | 1 (2.4%)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.6.2B Summary of Neurologic Rating Scale by Efficacy Phase Treatment Received Group Long-Term Effectiveness Phase - Safety Population

NRS | Efficacy Phase Treatment Received Group | | Total; (N=81)
NRS | Lithium; (N=53) | Placebo; (N=28) | Total; (N=81)
Baseline Score
0 | 27 (93.1%) | 15 (100.0%) | 42 (95.5%)
1 | 2 (6.9%) | 0 | 2 (4.5%)
Week 1 Score
0 | 23 (88.5%) | 12 (100.0%) | 35 (92.1%)
1 | 2 (7.7%) | 0 | 2 (5.3%)
2 | 1 (3.8%) | 0 | 1 (2.6%)
Week 2 Score
0 | 27 (93.1%) | 13 (100.0%) | 40 (95.2%)
1 | 1 (3.4%) | 0 | 1 (2.4%)
2 | 1 (3.4%) | 0 | 1 (2.4%)
Week 4 Score
0 | 24 (96.0%) | 12 (100.0%) | 36 (97.3%)
1 | 0 | 0 | 0
2 | 1 (4.0%) | 0 | 1 (2.7%)
Week 6 Score
0 | 25 (96.2%) | 12 (100.0%) | 37 (97.4%)
1 | 0 | 0 | 0
2 | 1 (3.8%) | 0 | 1 (2.6%)
Week 8 Score
0 | 23 (92.0%) | 11 (100.0%) | 34 (94.4%)
1 | 1 (4.0%) | 0 | 1 (2.8%)
2 | 1 (4.0%) | 0 | 1 (2.8%)
Week 10 Score
0 | 21 (100.0%) | 11 (100.0%) | 32 (100.0%)
Week 12 Score
0 | 20 (95.2%) | 10 (100.0%) | 30 (96.8%)
1 | 0 | 0 | 0
2 | 1 (4.8%) | 0 | 1 (3.2%)
Week 14 Score
0 | 17 (94.4%) | 9 (100.0%) | 26 (96.3%)
1 | 0 | 0 | 0
2 | 1 (5.6%) | 0 | 1 (3.7%)
Week 16 Score
0 | 18 (100.0%) | 8 (88.9%) | 26 (96.3%)
1 | 0 | 1 (11.1%) | 1 (3.7%)
Week 18 Score
0 | 17 (94.4%) | 8 (100.0%) | 25 (96.2%)
1 | 0 | 0 | 0
2 | 1 (5.6%) | 0 | 1 (3.8%)
Week 20 Score
0 | 15 (93.8%) | 8 (100.0%) | 23 (95.8%)
1 | 1 (6.3%) | 0 | 1 (4.2%)
Week 22 Score
0 | 14 (100.0%) | 7 (100.0%) | 21 (100.0%)
Week 24 Score
0 | 14 (93.3%) | 8 (100.0%) | 22 (95.7%)
1 | 0 | 0 | 0
2 | 1 (6.7%) | 0 | 1 (4.3%)
LOCF Score
0 | 27 (93.1%) | 12 (92.3%) | 39 (92.9%)
1 | 1 (3.4%) | 1 (7.7%) | 2 (4.8%)
2 | 1 (3.4%) | 0 | 1 (2.4%)

Note: Baseline is defined as last visit of Efficacy Phase.

Table 14.3.6.3 Summary of Neurologic Rating Scale by Discontinuation Phase Treatment Received Group Discontinuation Phase - Safety Population

NRS | Discontinuation Phase Treatment Received Group | | Total; (N=31)
NRS | Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline Score
0 | 16 (94.1%) | 14 (100.0%) | 30 (96.8%)
1 | 1 (5.9%) | 0 | 1 (3.2%)
Week 1 Score
0 | 16 (94.1%) | 13 (100.0%) | 29 (96.7%)
1 | 0 | 0 | 0
2 | 0 | 0 | 0
3 | 1 (5.9%) | 0 | 1 (3.3%)
Week 2 Score
0 | 15 (93.8%) | 14 (100.0%) | 29 (96.7%)
1 | 0 | 0 | 0
2 | 0 | 0 | 0
3 | 1 (6.3%) | 0 | 1 (3.3%)
Week 3 Score
0 | 14 (100.0%) | 9 (100.0%) | 23 (100.0%)
Week 4 Score
0 | 13 (100.0%) | 12 (100.0%) | 25 (100.0%)
Week 6 Score
0 | 13 (100.0%) | 8 (100.0%) | 21 (100.0%)
Week 8 Score
0 | 12 (92.3%) | 3 (100.0%) | 15 (93.8%)
1 | 1 (7.7%) | 0 | 1 (6.3%)
Week 10 Score
0 | 11 (100.0%) | 2 (100.0%) | 13 (100.0%)
Week 12 Score
0 | 11 (91.7%) | 2 (100.0%) | 13 (92.9%)
1 | 1 (8.3%) | 0 | 1 (7.1%)
Week 16 Score
0 | 12 (100.0%) | 2 (100.0%) | 14 (100.0%)
Week 20 Score
0 | 11 (91.7%) | 2 (100.0%) | 13 (92.9%)
1 | 1 (8.3%) | 0 | 1 (7.1%)
Week 24 Score
0 | 10 (90.9%) | 2 (100.0%) | 12 (92.3%)
1 | 0 | 0 | 0
2 | 1 (9.1%) | 0 | 1 (7.7%)
Week 28 Score
0 | 10 (100.0%) | 1 (100.0%) | 11 (100.0%)
LOCF Score
0 | 17 (100.0%) | 14 (100.0%) | 31 (100.0%)

Note: Baseline is defined as last visit of Long-Term Effectiveness Phase.

Table 14.3.6.4 Summary of Neurologic Rating Scale by Discontinuation Phase Treatment Received Group Restabilization Phase - Safety Population

NRS | Discontinuation Phase Treatment Received Group | | Total; (N=13)
NRS | Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline Score
0 | 3 (100.0%) | 10 (100.0%) | 13 (100.0%)
Week 1 Score
0 | 3 (100.0%) | 9 (100.0%) | 12 (100.0%)
Week 2 Score
0 | 3 (100.0%) | 9 (100.0%) | 12 (100.0%)
Week 3 Score
0 | 2 (100.0%) | 9 (100.0%) | 11 (100.0%)
Week 4 Score
0 | 2 (100.0%) | 8 (100.0%) | 10 (100.0%)
Week 6 Score
0 | 2 (100.0%) | 8 (100.0%) | 10 (100.0%)
Week 8 Score
0 | 2 (100.0%) | 7 (100.0%) | 9 (100.0%)
LOCF Score
0 | 3 (100.0%) | 10 (100.0%) | 13 (100.0%)

Note: Baseline is defined as last visit of Discontinuation Phase.

Table 14.3.7.1.1 Summary of SSRS-C: Columbia Suicide Severity Rating Scale by Age Strata and Efficacy Phase Treatment Received Group Suicidal Behavior Efficacy Phase - Safety Population

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline Suicidal Behavior | N = 32 | N = 17 | N = 21 | N = 11 | N = 53 | N = 28
Actual attempt | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Interrupted attempt | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Aborted attempt | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Preparatory acts or behavior | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Non-suicidal self-injurious behavior | 0 | 1 (5.9%) | 4 (19.0%) | 0 | 4 (7.5%) | 1 (3.6%)
Week 1 Suicidal Behavior | N = 30 | N = 17 | N = 22 | N = 11 | N = 52 | N = 28
Actual attempt | 0 | 0 | 1 (4.5%) | 0 | 1 (1.9%) | 0
Interrupted attempt | 0 | 0 | 2 (9.1%) | 0 | 2 (3.8%) | 0
Aborted attempt | 0 | 0 | 0 | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0 | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 1 (5.9%) | 5 (22.7%) | 0 | 5 (9.6%) | 1 (3.6%)
Week 2 Suicidal Behavior | N = 29 | N = 17 | N = 18 | N = 10 | N = 47 | N = 27
Actual attempt | 0 | 0 | 0 | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0 | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0 | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0 | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 1 (5.9%) | 0 | 0 | 0 | 1 (3.7%)
Week 3 Suicidal Behavior | N = 28 | N = 14 | N = 15 | N = 10 | N = 43 | N = 24
Actual attempt | 0 | 0 | 0 | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0 | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0 | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0 | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 0 | 0 | 0 | 0 | 0
Week 4 Suicidal Behavior | N = 27 | N = 13 | N = 17 | N = 10 | N = 44 | N = 23
Actual attempt | 0 | 0 | 1 (5.9%) | 0 | 1 (2.3%) | 0
Interrupted attempt | 0 | 0 | 0 | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0 | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0 | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 0 | 0 | 0 | 0 | 0
Week 6 Suicidal Behavior | N = 26 | N = 13 | N = 13 | N = 10 | N = 39 | N = 23
Actual attempt | 0 | 0 | 0 | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0 | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0 | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0 | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 0 | 0 | 0 | 0 | 0
Week 8 Suicidal Behavior | N = 24 | N = 12 | N = 13 | N = 10 | N = 37 | N = 22
Actual attempt | 0 | 0 | 0 | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0 | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0 | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0 | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 0 | 0 | 0 | 0 | 0
LOCF Suicidal Behavior | N = 32 | N = 17 | N = 21 | N = 11 | N = 53 | N = 28
Actual attempt | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Interrupted attempt | 0 | 0 | 0 | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0 | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0 | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 1 (5.9%) | 1 (4.8%) | 0 | 1 (1.9%) | 1 (3.6%)

Note: Baseline is the first visit of the Efficacy Phase.

Frequency of Suicidal Behavior is since last assessment or baseline.

Table 14.3.7.1.2 Summary of SSRS-C: Columbia Suicide Severity Rating Scale by Age Strata and Efficacy Phase Treatment Received Group Suicidal Ideation Efficacy Phase - Safety Population

| 7 – 11 yrs | | 12 – 17 yrs | | Total
| Lithium; (N=32) | Placebo; (N=17) | Lithium; (N=21) | Placebo; (N=11) | Lithium; (N=53) | Placebo; (N=28)
Baseline Suicidal Ideation | N = 32 | N = 17 | N = 21 | N = 11 | N = 53 | N = 28
Wish to be dead | 5 (15.6%) | 3 (17.6%) | 7 (33.3%) | 3 (27.3%) | 12 (22.6%) | 6 (21.4%)
Non-specific active suicidal thoughts | 2 (6.3%) | 0 | 5 (23.8%) | 0 | 7 (13.2%) | 0
Ideation without intent to act | 0 | 0 | 3 (14.3%) | 1 (9.1%) | 3 (5.7%) | 1 (3.6%)
Ideation with intent to act, no specific plan | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Ideation with plan and intent | 0 | 0 | 0 | 0 | 0 | 0
Week 1 Suicidal Ideation | N = 30 | N = 17 | N = 22 | N = 11 | N = 52 | N = 28
Wish to be dead | 2 (6.7%) | 3 (17.6%) | 7 (31.8%) | 0 | 9 (17.3%) | 3 (10.7%)
Non-specific active suicidal thoughts | 0 | 0 | 5 (22.7%) | 0 | 5 (9.6%) | 0
Ideation without intent to act | 0 | 0 | 5 (22.7%) | 0 | 5 (9.6%) | 0
Ideation with intent to act, no specific plan | 0 | 0 | 2 (9.1%) | 0 | 2 (3.8%) | 0
Ideation with plan and intent | 0 | 0 | 1 (4.5%) | 0 | 1 (1.9%) | 0
Week 2 Suicidal Ideation | N = 29 | N = 17 | N = 18 | N = 10 | N = 47 | N = 27
Wish to be dead | 1 (3.4%) | 5 (29.4%) | 6 (33.3%) | 0 | 7 (14.9%) | 5 (18.5%)
Non-specific active suicidal thoughts | 0 | 0 | 2 (11.1%) | 0 | 2 (4.3%) | 0
Ideation without intent to act | 0 | 0 | 1 (5.6%) | 0 | 1 (2.1%) | 0
Ideation with intent to act, no specific plan | 0 | 0 | 1 (5.6%) | 0 | 1 (2.1%) | 0
Ideation with plan and intent | 0 | 0 | 0 | 0 | 0 | 0
Week 3 Suicidal Ideation | N = 28 | N = 14 | N = 15 | N = 10 | N = 43 | N = 24
Wish to be dead | 1 (3.6%) | 0 | 2 (13.3%) | 0 | 3 (7.0%) | 0
Non-specific active suicidal thoughts | 0 | 0 | 1 (6.7%) | 0 | 1 (2.3%) | 0
Ideation without intent to act | 0 | 0 | 1 (6.7%) | 0 | 1 (2.3%) | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0 | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0 | 0 | 0 | 0
Week 4 Suicidal Ideation | N = 27 | N = 13 | N = 17 | N = 10 | N = 44 | N = 23
Wish to be dead | 1 (3.7%) | 1 (7.7%) | 3 (17.6%) | 0 | 4 (9.1%) | 1 (4.3%)
Non-specific active suicidal thoughts | 0 | 0 | 0 | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 1 (5.9%) | 0 | 1 (2.3%) | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0 | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0 | 0 | 0 | 0
Week 6 Suicidal Ideation | N = 26 | N = 13 | N = 13 | N = 10 | N = 39 | N = 23
Wish to be dead | 1 (3.8%) | 0 | 0 | 0 | 1 (2.6%) | 0
Non-specific active suicidal thoughts | 0 | 0 | 0 | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0 | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0 | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0 | 0 | 0 | 0
Week 8 Suicidal Ideation | N = 24 | N = 12 | N = 13 | N = 10 | N = 37 | N = 22
Wish to be dead | 1 (4.2%) | 0 | 1 (7.7%) | 0 | 2 (5.4%) | 0
Non-specific active suicidal thoughts | 0 | 1 (8.3%) | 0 | 0 | 0 | 1 (4.5%)
Ideation without intent to act | 0 | 0 | 0 | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0 | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0 | 0 | 0 | 0
LOCF Suicidal Ideation | N = 32 | N = 17 | N = 21 | N = 11 | N = 53 | N = 28
Wish to be dead | 3 (9.4%) | 1 (5.9%) | 4 (19.0%) | 0 | 7 (13.2%) | 1 (3.6%)
Non-specific active suicidal thoughts | 0 | 1 (5.9%) | 2 (9.5%) | 0 | 2 (3.8%) | 1 (3.6%)
Ideation without intent to act | 0 | 0 | 3 (14.3%) | 0 | 3 (5.7%) | 0
Ideation with intent to act, no specific plan | 0 | 0 | 1 (4.8%) | 0 | 1 (1.9%) | 0
Ideation with plan and intent | 0 | 0 | 0 | 0 | 0 | 0

Note: Baseline is the first visit of the Efficacy Phase.

Frequency of Suicidal Ideation is since last assessment or baseline.

Table 14.3.7.2.1A Summary of SSRS-C: Columbia Suicide Severity Rating Scale by Age Strata Suicidal Behavior Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline Suicidal Behavior | N = 29 | N = 15 | N = 44
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 0 | 0
Week 1 Suicidal Behavior | N = 26 | N = 12 | N = 38
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 0 | 0
Week 2 Suicidal Behavior | N = 29 | N = 13 | N = 42
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 0 | 0
Week 4 Suicidal Behavior | N = 25 | N = 12 | N = 37
Actual attempt | 1 (4.0%) | 0 | 1 (2.7%)
Interrupted attempt | 1 (4.0%) | 0 | 1 (2.7%)
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 1 (4.0%) | 0 | 1 (2.7%)
Week 6 Suicidal Behavior | N = 26 | N = 12 | N = 38
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 1 (3.8%) | 0 | 1 (2.6%)
Week 8 Suicidal Behavior | N = 25 | N = 11 | N = 36
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 0 | 0
Week 10 Suicidal Behavior | N = 21 | N = 11 | N = 32
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 0 | 0
Week 12 Suicidal Behavior | N = 21 | N = 10 | N = 31
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 0 | 0
Week 14 Suicidal Behavior | N = 18 | N = 9 | N = 27
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 0 | 0
Week 16 Suicidal Behavior | N = 18 | N = 9 | N = 27
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 0 | 0
Week 18 Suicidal Behavior | N = 19 | N = 8 | N = 27
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 0 | 0
Week 20 Suicidal Behavior | N = 16 | N = 8 | N = 24
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 0 | 0
Week 22 Suicidal Behavior | N = 14 | N = 7 | N = 21
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 0 | 0
Week 24 Suicidal Behavior | N = 15 | N = 8 | N = 23
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 0 | 0
LOCF Suicidal Behavior | N = 29 | N = 13 | N = 42
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 1 (3.4%) | 0 | 1 (2.4%)

Note: Baseline is the last visit of the Efficacy Phase.

Frequency of Suicidal Behavior is since last assessment.

Table 14.3.7.2.2A Summary of SSRS-C: Columbia Suicide Severity Rating Scale by Age Strata Suicidal Ideation Long-Term Effectiveness Phase - Safety Population

| Age Strata | | Total; (N=44)
| 7 – 11 yrs; (N=29) | 12 – 17 yrs; (N=15) | Total; (N=44)
Baseline Suicidal Ideation | N = 29 | N = 15 | N = 44
Wish to be dead | 2 (6.9%) | 0 | 2 (4.5%)
Non-specific active suicidal thoughts | 0 | 1 (6.7%) | 1 (2.3%)
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 1 Suicidal Ideation | N = 26 | N = 12 | N = 38
Wish to be dead | 1 (3.8%) | 0 | 1 (2.6%)
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 2 Suicidal Ideation | N = 29 | N = 13 | N = 42
Wish to be dead | 2 (6.9%) | 0 | 2 (4.8%)
Non-specific active suicidal thoughts | 1 (3.4%) | 0 | 1 (2.4%)
Ideation without intent to act | 1 (3.4%) | 0 | 1 (2.4%)
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 4 Suicidal Ideation | N = 25 | N = 12 | N = 37
Wish to be dead | 1 (4.0%) | 0 | 1 (2.7%)
Non-specific active suicidal thoughts | 1 (4.0%) | 0 | 1 (2.7%)
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 1 (4.0%) | 0 | 1 (2.7%)
Week 6 Suicidal Ideation | N = 26 | N = 12 | N = 38
Wish to be dead | 2 (7.7%) | 0 | 2 (5.3%)
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 8 Suicidal Ideation | N = 25 | N = 11 | N = 36
Wish to be dead | 2 (8.0%) | 0 | 2 (5.6%)
Non-specific active suicidal thoughts | 1 (4.0%) | 0 | 1 (2.8%)
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 10 Suicidal Ideation | N = 21 | N = 11 | N = 32
Wish to be dead | 1 (4.8%) | 1 (9.1%) | 2 (6.3%)
Non-specific active suicidal thoughts | 0 | 1 (9.1%) | 1 (3.1%)
Ideation without intent to act | 0 | 1 (9.1%) | 1 (3.1%)
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 12 Suicidal Ideation | N = 21 | N = 10 | N = 31
Wish to be dead | 2 (9.5%) | 1 (10.0%) | 3 (9.7%)
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 14 Suicidal Ideation | N = 18 | N = 9 | N = 27
Wish to be dead | 1 (5.6%) | 0 | 1 (3.7%)
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 16 Suicidal Ideation | N = 18 | N = 9 | N = 27
Wish to be dead | 0 | 0 | 0
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 18 Suicidal Ideation | N = 19 | N = 8 | N = 27
Wish to be dead | 0 | 0 | 0
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 20 Suicidal Ideation | N = 16 | N = 8 | N = 24
Wish to be dead | 1 (6.3%) | 0 | 1 (4.2%)
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 22 Suicidal Ideation | N = 14 | N = 7 | N = 21
Wish to be dead | 0 | 0 | 0
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 24 Suicidal Ideation | N = 15 | N = 8 | N = 23
Wish to be dead | 1 (6.7%) | 0 | 1 (4.3%)
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
LOCF Suicidal Ideation | N = 29 | N = 13 | N = 42
Wish to be dead | 3 (10.3%) | 0 | 3 (7.1%)
Non-specific active suicidal thoughts | 1 (3.4%) | 0 | 1 (2.4%)
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0

Note: Baseline is the last visit of the Efficacy Phase.

Frequency of Suicidal Ideation is since last assessment.

Table 14.3.7.2.1B Summary of SSRS-C: Columbia Suicide Severity Rating Scale by Efficacy Phase Treatment Received Group Suicidal Behavior Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline Suicidal Behavior | N = 29 | N = 15 | N = 44
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 0 | 0
Week 1 Suicidal Behavior | N = 26 | N = 12 | N = 38
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 0 | 0
Week 2 Suicidal Behavior | N = 29 | N = 13 | N = 42
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 0 | 0
Week 4 Suicidal Behavior | N = 25 | N = 12 | N = 37
Actual attempt | 1 (4.0%) | 0 | 1 (2.7%)
Interrupted attempt | 1 (4.0%) | 0 | 1 (2.7%)
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 1 (4.0%) | 0 | 1 (2.7%)
Week 6 Suicidal Behavior | N = 26 | N = 12 | N = 38
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 1 (3.8%) | 0 | 1 (2.6%)
Week 8 Suicidal Behavior | N = 25 | N = 11 | N = 36
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 0 | 0
Week 10 Suicidal Behavior | N = 21 | N = 11 | N = 32
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 0 | 0
Week 12 Suicidal Behavior | N = 21 | N = 10 | N = 31
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 0 | 0
Week 14 Suicidal Behavior | N = 18 | N = 9 | N = 27
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 0 | 0
Week 16 Suicidal Behavior | N = 18 | N = 9 | N = 27
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 0 | 0
Week 18 Suicidal Behavior | N = 19 | N = 8 | N = 27
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 0 | 0
Week 20 Suicidal Behavior | N = 16 | N = 8 | N = 24
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 0 | 0
Week 22 Suicidal Behavior | N = 14 | N = 7 | N = 21
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 0 | 0
Week 24 Suicidal Behavior | N = 15 | N = 8 | N = 23
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 0 | 0 | 0
LOCF Suicidal Behavior | N = 29 | N = 13 | N = 42
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Non-suicidal self-injurious behavior | 1 (3.4%) | 0 | 1 (2.4%)

Note: Baseline is the last visit of the Efficacy Phase.

Frequency of Suicidal Behavior is since last assessment.

Table 14.3.7.2.2B Summary of SSRS-C: Columbia Suicide Severity Rating Scale by Efficacy Phase Treatment Received Group Suicidal Ideation Long-Term Effectiveness Phase - Safety Population

| Efficacy Phase Treatment Received Group | | Total; (N=44)
| Lithium; (N=29) | Placebo; (N=15) | Total; (N=44)
Baseline Suicidal Ideation | N = 29 | N = 15 | N = 44
Wish to be dead | 2 (6.9%) | 0 | 2 (4.5%)
Non-specific active suicidal thoughts | 0 | 1 (6.7%) | 1 (2.3%)
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 1 Suicidal Ideation | N = 26 | N = 12 | N = 38
Wish to be dead | 1 (3.8%) | 0 | 1 (2.6%)
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 2 Suicidal Ideation | N = 29 | N = 13 | N = 42
Wish to be dead | 2 (6.9%) | 0 | 2 (4.8%)
Non-specific active suicidal thoughts | 1 (3.4%) | 0 | 1 (2.4%)
Ideation without intent to act | 1 (3.4%) | 0 | 1 (2.4%)
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 4 Suicidal Ideation | N = 25 | N = 12 | N = 37
Wish to be dead | 1 (4.0%) | 0 | 1 (2.7%)
Non-specific active suicidal thoughts | 1 (4.0%) | 0 | 1 (2.7%)
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 1 (4.0%) | 0 | 1 (2.7%)
Week 6 Suicidal Ideation | N = 26 | N = 12 | N = 38
Wish to be dead | 2 (7.7%) | 0 | 2 (5.3%)
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 8 Suicidal Ideation | N = 25 | N = 11 | N = 36
Wish to be dead | 2 (8.0%) | 0 | 2 (5.6%)
Non-specific active suicidal thoughts | 1 (4.0%) | 0 | 1 (2.8%)
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 10 Suicidal Ideation | N = 21 | N = 11 | N = 32
Wish to be dead | 1 (4.8%) | 1 (9.1%) | 2 (6.3%)
Non-specific active suicidal thoughts | 0 | 1 (9.1%) | 1 (3.1%)
Ideation without intent to act | 0 | 1 (9.1%) | 1 (3.1%)
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 12 Suicidal Ideation | N = 21 | N = 10 | N = 31
Wish to be dead | 2 (9.5%) | 1 (10.0%) | 3 (9.7%)
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 14 Suicidal Ideation | N = 18 | N = 9 | N = 27
Wish to be dead | 1 (5.6%) | 0 | 1 (3.7%)
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 16 Suicidal Ideation | N = 18 | N = 9 | N = 27
Wish to be dead | 0 | 0 | 0
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 18 Suicidal Ideation | N = 19 | N = 8 | N = 27
Wish to be dead | 0 | 0 | 0
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 20 Suicidal Ideation | N = 16 | N = 8 | N = 24
Wish to be dead | 1 (6.3%) | 0 | 1 (4.2%)
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 22 Suicidal Ideation | N = 14 | N = 7 | N = 21
Wish to be dead | 0 | 0 | 0
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 24 Suicidal Ideation | N = 15 | N = 8 | N = 23
Wish to be dead | 1 (6.7%) | 0 | 1 (4.3%)
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
LOCF Suicidal Ideation | N = 29 | N = 13 | N = 42
Wish to be dead | 3 (10.3%) | 0 | 3 (7.1%)
Non-specific active suicidal thoughts | 1 (3.4%) | 0 | 1 (2.4%)
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0

Note: Baseline is the last visit of the Efficacy Phase.

Frequency of Suicidal Ideation is since last assessment.

Table 14.3.7.3.1 Summary of SSRS-C: Columbia Suicide Severity Rating Scale by Discontinuation Phase Treatment Received Group Suicidal Behavior Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline Suicidal Behavior | N = 17 | N = 14 | N = 31
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Week 1 Suicidal Behavior | N = 17 | N = 13 | N = 30
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Week 2 Suicidal Behavior | N = 16 | N = 14 | N = 30
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Week 3 Suicidal Behavior | N = 14 | N = 9 | N = 23
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Week 4 Suicidal Behavior | N = 13 | N = 12 | N = 25
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Week 6 Suicidal Behavior | N = 13 | N = 8 | N = 21
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Week 8 Suicidal Behavior | N = 13 | N = 3 | N = 16
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Week 10 Suicidal Behavior | N = 11 | N = 2 | N = 13
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Week 12 Suicidal Behavior | N = 12 | N = 2 | N = 14
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Week 16 Suicidal Behavior | N = 12 | N = 2 | N = 14
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Week 20 Suicidal Behavior | N = 12 | N = 2 | N = 14
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Week 24 Suicidal Behavior | N = 11 | N = 2 | N = 13
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Week 28 Suicidal Behavior | N = 10 | N = 2 | N = 12
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
LOCF Suicidal Behavior | N = 17 | N = 14 | N = 31
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0

Note: Baseline is the last visit of the Long-Term Effectiveness Phase.

Frequency of Suicidal Behavior is since last assessment or baseline.

Table 14.3.7.3.2 Summary of SSRS-C: Columbia Suicide Severity Rating Scale by Discontinuation Phase Treatment Received Group Suicidal Ideation Discontinuation Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=31)
| Lithium; (N=17) | Placebo; (N=14) | Total; (N=31)
Baseline Suicidal Ideation | N = 17 | N = 14 | N = 31
Wish to be dead | 0 | 0 | 0
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 1 Suicidal Ideation | N = 17 | N = 13 | N = 30
Wish to be dead | 0 | 0 | 0
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 2 Suicidal Ideation | N = 16 | N = 14 | N = 30
Wish to be dead | 0 | 0 | 0
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 3 Suicidal Ideation | N = 14 | N = 9 | N = 23
Wish to be dead | 0 | 1 (11.1%) | 1 (4.3%)
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 4 Suicidal Ideation | N = 13 | N = 12 | N = 25
Wish to be dead | 0 | 0 | 0
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 6 Suicidal Ideation | N = 13 | N = 8 | N = 21
Wish to be dead | 0 | 0 | 0
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 8 Suicidal Ideation | N = 13 | N = 3 | N = 16
Wish to be dead | 0 | 0 | 0
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 10 Suicidal Ideation | N = 11 | N = 2 | N = 13
Wish to be dead | 0 | 0 | 0
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 12 Suicidal Ideation | N = 12 | N = 2 | N = 14
Wish to be dead | 0 | 0 | 0
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 16 Suicidal Ideation | N = 12 | N = 2 | N = 14
Wish to be dead | 0 | 0 | 0
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 20 Suicidal Ideation | N = 12 | N = 2 | N = 14
Wish to be dead | 0 | 0 | 0
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 24 Suicidal Ideation | N = 11 | N = 2 | N = 13
Wish to be dead | 0 | 0 | 0
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 28 Suicidal Ideation | N = 10 | N = 2 | N = 12
Wish to be dead | 0 | 0 | 0
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
LOCF Suicidal Ideation | N = 17 | N = 14 | N = 31
Wish to be dead | 0 | 0 | 0
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0

Note: Baseline is the last visit of the Long-Term Effectiveness Phase.

Frequency of Suicidal Ideation is since last assessment or baseline.

Table 14.3.7.4.1 Summary of SSRS-C: Columbia Suicide Severity Rating Scale by Discontinuation Phase Treatment Received Group Suicidal Behavior Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline Suicidal Behavior | N = 3 | N = 10 | N = 13
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Week 1 Suicidal Behavior | N = 3 | N = 9 | N = 12
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Week 2 Suicidal Behavior | N = 3 | N = 9 | N = 12
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Week 3 Suicidal Behavior | N = 2 | N = 9 | N = 11
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Week 4 Suicidal Behavior | N = 2 | N = 8 | N = 10
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Week 6 Suicidal Behavior | N = 2 | N = 8 | N = 10
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
Week 8 Suicidal Behavior | N = 2 | N = 7 | N = 9
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0
LOCF Suicidal Behavior | N = 3 | N = 10 | N = 13
Actual attempt | 0 | 0 | 0
Interrupted attempt | 0 | 0 | 0
Aborted attempt | 0 | 0 | 0
Preparatory acts or behavior | 0 | 0 | 0

Note: Baseline is the last visit of the Discontinuation Phase.

Frequency of Suicidal Behavior is since last assessment or baseline.

Table 14.3.7.4.2 Summary of SSRS-C: Columbia Suicide Severity Rating Scale by Discontinuation Phase Treatment Received Group Suicidal Ideation Restabilization Phase - Safety Population

| Discontinuation Phase Treatment Received Group | | Total; (N=13)
| Lithium; (N=3) | Placebo; (N=10) | Total; (N=13)
Baseline Suicidal Ideation | N = 3 | N = 10 | N = 13
Wish to be dead | 0 | 0 | 0
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 1 Suicidal Ideation | N = 3 | N = 9 | N = 12
Wish to be dead | 0 | 0 | 0
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 2 Suicidal Ideation | N = 3 | N = 9 | N = 12
Wish to be dead | 0 | 0 | 0
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 3 Suicidal Ideation | N = 2 | N = 9 | N = 11
Wish to be dead | 0 | 0 | 0
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 4 Suicidal Ideation | N = 2 | N = 8 | N = 10
Wish to be dead | 0 | 0 | 0
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 6 Suicidal Ideation | N = 2 | N = 8 | N = 10
Wish to be dead | 0 | 0 | 0
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
Week 8 Suicidal Ideation | N = 2 | N = 7 | N = 9
Wish to be dead | 0 | 0 | 0
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0
LOCF Suicidal Ideation | N = 3 | N = 10 | N = 13
Wish to be dead | 0 | 0 | 0
Non-specific active suicidal thoughts | 0 | 0 | 0
Ideation without intent to act | 0 | 0 | 0
Ideation with intent to act, no specific plan | 0 | 0 | 0
Ideation with plan and intent | 0 | 0 | 0

Note: Baseline is the last visit of the Discontinuation Phase.

Frequency of Suicidal Ideation is since last assessment or baseline.

Figure 14.2.1.1.1 Young Mania Rating Scale (YMRS) by Visit and Randomized Treatment Group Efficacy Phase - Efficacy Population

Note: Baseline is defined as the first visit of Efficacy Phase.

Week 5 & 7 visits were changed to phone calls with protocol amendment 5 (with no YMRS collected).

Figure 14.2.1.1.2 Change in Young Mania Rating Scale (YMRS) by Visit and Randomized Treatment Group Efficacy Phase - Efficacy Population

Note: Baseline is defined as the first visit of Efficacy Phase.

Week 5 & 7 visits were changed to phone calls with protocol amendment 5 (with no YMRS collected).

Figure 14.2.1.1.3 Young Mania Rating Scale (YMRS) by Visit and Randomized Treatment Group Efficacy Phase - Per Protocol Population

Note: Baseline is defined as the first visit of Efficacy Phase.

Figure 14.2.1.1.4 Change in Young Mania Rating Scale (YMRS) by Visit and Randomized Treatment Group Efficacy Phase - Per Protocol Population

Note: Change score is week value minus baseline value, baseline is defined as the first visit of Efficacy Phase.

Figure 14.2.1.1.5 YMRS Summary Score by Visit and Randomized Treatment Group Efficacy Phase - Revised Per Protocol Population

Note: Baseline is defined as the first visit of Efficacy Phase.

Figure 14.2.1.1.6 Change in YMRS Summary Score by Visit and Randomized Treatment Group Efficacy Phase - Revised Per Protocol Population

Note: Change score is week value minus baseline value, baseline is defined as the first visit of Efficacy Phase.

Figure 14.2.1.2.1 Time to Discontinuation for Any Reason by Randomized Treatment Group Efficacy Phase - Efficacy Population

Figure 14.2.1.2.2 Time to discontinuation Due to Lack of Efficacy by Randomized Treatment Group Efficacy Phase - Efficacy Population

Figure 14.2.2.1.1 Young Mania Rating Scale (YMRS) by Visit and Efficacy Phase Randomized Treatment Group Long Term Effectiveness Phase - Efficacy Population

Note: Baseline is defined as the last visit of Efficacy Phase.

Figure 14.2.2.1.2 Change in Young Mania Rating Scale (YMRS) by Visit and Efficacy Phase Randomized Treatment Group Long Term Effectiveness Phase - Efficacy Population

Note: Baseline is defined as the last visit of Efficacy Phase.

Figure 14.2.2.2A Time to Discontinuation for Any Reason by Age Strata Long Term Effectiveness Phase - Efficacy Population

Figure 14.2.2.2B Time to Discontinuation for Any Reason by Efficacy Phase Randomized Treatment Group Long Term Effectiveness Phase - Efficacy Population

Figure 14.2.3.1.1 Time to Discontinuation for Any Reason by Randomized Treatment Discontinuation Phase - Efficacy Population

Figure 14.2.3.1.2 Time to Discontinuation for Any Reason by Randomized Treatment Group Discontinuation Phase - Per Protocol Population

Figure 14.2.3.1.3 Time to Discontinuation for Any Reason by Randomized Treatment Group Discontinuation Phase - Revised Per Protocol Population

Figure 14.2.3.1.4 Time to Discontinuation for Any Reason by Treatment Received Discontinuation Phase - Efficacy Population

Figure 14.2.3.2.1 Time to Recurrence of Mood Episodes by Randomized Treatment Group Discontinuation Phase - Efficacy Population

Figure 14.2.3.2.2 Young Mania Rating Scale (YMRS) by Visit and Randomized Treatment Group Discontinuation Phase - Efficacy Population

Note: Baseline is defined as the last visit of the Long-Term Effectiveness Phase.

Figure 14.2.3.2.3 Change in Young Mania Rating Scale (YMRS) by Visit and Randomized Treatment Group Discontinuation Phase - Efficacy Population

Note: Baseline is defined as the last visit of the Long-Term Effectiveness Phase.

Figure 14.2.4.1.1 Young Mania Rating Scale (YMRS) by Visit Restabilization Phase

Note: Baseline is defined as the last visit of Discontinuation Phase.

Figure 14.2.4.1.2 Change in Young Mania Rating Scale (YMRS) by Visit Restabilization Phase

Note: Baseline is defined as the last visit of Discontinuation Phase.

Figure 14.2.4.2 Time to Discontinuation for Any Reason Restabilization Phase -- Efficacy Population

Figure 14.3.1.1 Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received White Blood Count (×10^3^/μL) Safety Population Efficacy Phase

Note: Baseline laboratory values were drawn during the Screening Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.1.2 Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Neutrophils (%) Safety Population Efficacy Phase

Note: Baseline laboratory values were drawn during the Screening Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.1.3 Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Lymphocytes (%) Safety Population Efficacy Phase

Note: Baseline laboratory values were drawn during the Screening Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.1.4 Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Monocytes (%) Safety Population Efficacy Phase

Note: Baseline laboratory values were drawn during the Screening Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.1.5 Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Eosinophils (%) Safety Population Efficacy Phase

Note: Baseline laboratory values were drawn during the Screening Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.1.6 Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Basophils (%) Safety Population Efficacy Phase

Note: Baseline laboratory values were drawn during the Screening Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.1.7 Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Creatinine (mg/dL) Safety Population Efficacy Phase

Note: Baseline laboratory values were drawn during the Screening Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.1.8 Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Creatinine Clearance (mL/min/1.7m^2^) Safety Population Efficacy Phase

Note: Baseline laboratory values were drawn during the Screening Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.1.9 Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Thyroid Stimulating Hormone - TSH (mIU/L) Safety Population Efficacy Phase

Note: Baseline laboratory values were drawn during the Screening Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.1.10 Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Total T3 (ng/dL) Safety Population Efficacy Phase

Note: Baseline laboratory values were drawn during the Screening Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.1.11 Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Total T4 (μg/dL) Safety Population Efficacy Phase

Note: Baseline laboratory values were drawn during the Screening Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.1.12 Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Antithyroglobulin Ab (IU/mL) Safety Population Efficacy Phase

Note: Baseline laboratory values were drawn during the Screening Phase.

BQL values are counted as 20 IU/mL. Any value below 20 IU/mL is counted as 20 IU/mL.

Values outside of axis limits are not shown on the graph but are counted in the statistics: [▬] 3000 at baseline & -2980 change; [▬] 1957 at baseline, 2368 at last & 411 change; Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.1.13 Thyroid Panel Measurement by Visit and Efficacy Phase Treatment Received Thyroid Peroxidase Ab (IU/mL) Safety Population Efficacy Phase

Note: Baseline laboratory values were drawn during the Screening Phase.

BQL values are counted as 10 IU/mL. Any value below 10 IU/mL is counted as 10 IU/mL.

Values outside of axis limits are not shown on the graph but are counted in the statistics: [▬] 113 at baseline visit & 95.4 at last visit; [▬] 152 at last visit & 95.5 change value; Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.2.1A Laboratory Chemistry Measurement by Visit and Age Strata White Blood Count (×10^3^/μL) Safety Population Long Term Effectiveness Phase

Note: Baseline laboratory values were drawn at the last visit of the Efficacy Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.2.1B Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received White Blood Count (×10^3^/μL) Safety Population Long Term Effectiveness Phase

Note: Baseline laboratory values were drawn at the last visit of the Efficacy Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.2.2A Laboratory Chemistry Measurement by Visit and Age Strata Neutrophils (%) Safety Population Long Term Effectiveness Phase

Note: Baseline laboratory values were drawn at the last visit of the Efficacy Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.2.2B Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Neutrophils (%) Safety Population Long Term Effectiveness Phase

Note: Baseline laboratory values were drawn at the last visit of the Efficacy Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.2.3A Laboratory Chemistry Measurement by Visit and Age Strata Lymphocytes (%) Safety Population Long Term Effectiveness Phase

Note: Baseline laboratory values were drawn at the last visit of the Efficacy Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.2.3B Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Lymphocytes (%) Safety Population Long Term Effectiveness Phase

Note: Baseline laboratory values were drawn at the last visit of the Efficacy Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.2.4A Laboratory Chemistry Measurement by Visit and Age Strata Monocytes (%) Safety Population Long Term Effectiveness Phase

Note: Baseline laboratory values were drawn at the last visit of the Efficacy Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.2.4B Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Monocytes (%) Safety Population Long Term Effectiveness Phase

Note: Baseline laboratory values were drawn at the last visit of the Efficacy Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.2.5A Laboratory Chemistry Measurement by Visit and Age Strata Eosinophils (%) Safety Population Long Term Effectiveness Phase

Note: Baseline laboratory values were drawn at the last visit of the Efficacy Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.2.5B Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Eosinophils (%) Safety Population Long Term Effectiveness Phase

Note: Baseline laboratory values were drawn at the last visit of the Efficacy Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.2.6A Laboratory Chemistry Measurement by Visit and Age Strata Basophils (%) Safety Population Long Term Effectiveness Phase

Note: Baseline laboratory values were drawn at the last visit of the Efficacy Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.2.6B Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Basophils (%) Safety Population Long Term Effectiveness Phase

Note: Baseline laboratory values were drawn at the last visit of the Efficacy Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.2.7A Laboratory Chemistry Measurement by Visit and Age Strata Creatinine (mg/dL) Safety Population Long Term Effectiveness Phase

Note: Baseline laboratory values were drawn at the last visit of the Efficacy Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.2.7B Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Creatinine (mg/dL) Safety Population Long Term Effectiveness Phase

Note: Baseline laboratory values were drawn at the last visit of the Efficacy Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.2.8A Laboratory Chemistry Measurement by Visit and Age Strata Creatinine Clearance (mL/min/1.7m^2^) Safety Population Long Term Effectiveness Phase

Note: Baseline laboratory values were drawn at the last visit of the Efficacy Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.2.8B Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Creatinine Clearance (mL/min/1.7m^2^) Safety Population Long Term Effectiveness Phase

Note: Baseline laboratory values were drawn at the last visit of the Efficacy Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.2.9A Laboratory Chemistry Measurement by Visit and Age Strata Thyroid Stimulating Hormone - TSH (mIU/L) Safety Population Long Term Effectiveness Phase

Note: Baseline laboratory values were drawn at the last visit of the Efficacy Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.2.9B Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Thyroid Stimulating Hormone - TSH (mIU/L) Safety Population Long Term Effectiveness Phase

Note: Baseline laboratory values were drawn at the last visit of the Efficacy Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.2.10A Laboratory Chemistry Measurement by Visit and Age Strata Total T3 (ng/dL) Safety Population Long Term Effectiveness Phase

Note: Baseline laboratory values were drawn at the last visit of the Efficacy Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.2.10B Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Total T3 (ng/dL) Safety Population Long Term Effectiveness Phase

Note: Baseline laboratory values were drawn at the last visit of the Efficacy Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.2.11A Laboratory Chemistry Measurement by Visit and Age Strata Total T4 (μg/dL) Safety Population Long Term Effectiveness Phase

Note: Baseline laboratory values were drawn at the last visit of the Efficacy Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.2.11B Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Total T4 (μg/dL) Safety Population Long Term Effectiveness Phase

Note: Baseline laboratory values were drawn at the last visit of the Efficacy Phase.

Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.2.12A Laboratory Chemistry Measurement by Visit and Age Strata Antithyroglobulin Ab (IU/mL) Safety Population Long Term Effectiveness Phase

Note: Baseline laboratory values were drawn at the last visit of the Efficacy Phase.

BQL values are counted as 20 IU/mL. Any value below 20 IU/mL is counted as 20 IU/mL.

Values outside of axis limits are not shown on the graph but are counted in the statistics: [▬] 2368 at baseline, 2673 at last visit & 305 change value; Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.2.12B Laboratory Chemistry Measurement by Visit and Efficacy Phase Treatment Received Antithyroglobulin Ab (IU/mL) Safety Population Long Term Effectiveness Phase

Note: Baseline laboratory values were drawn at the last visit of the Efficacy Phase.

BQL values are counted as 20 IU/mL. Any value below 20 IU/mL is counted as 20 IU/mL.

Values outside of axis limits are not shown on the graph but are counted in the statistics: [▬] 2368 at baseline, 2673 at last visit & 305 change value; Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.2.13A Laboratory Chemistry Measurement by Visit and Age Strata Thyroid Peroxidase Ab (IU/mL) Safety Population Long Term Effectiveness Phase

Note: Baseline laboratory values were drawn at the last visit of the Efficacy Phase.

BQL values are counted as 10 IU/mL. Any value below 10 IU/mL is counted as 10 IU/mL.

Values outside of axis limits are not shown on the graph but are counted in the statistics: [▬] 95.4 at baseline visit; [▬] 152 at baseline visit, 248 at last visit & 96 change value; Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.3.2.13B Thyroid Panel Measurement by Visit and Efficacy Phase Treatment Received Thyroid Peroxidase Ab (IU/mL) Safety Population Long Term Effectiveness Phase

Note: Baseline laboratory values were drawn at the last visit of the Efficacy Phase.

BQL values are counted as 10 IU/mL. Any value below 10 IU/mL is counted as 10 IU/mL.

Values outside of axis limits are not shown on the graph but are counted in the statistics: [▬] 95.4 at baseline visit; ▬] 152 at baseline visit, 248 at last visit & 96 change value; Box represents 75th and 25th percentiles. Upper/lower whiskers represent 95th and 5th percentiles. The horizontal line is the median and the triangle is the mean value.

Figure 14.4.1 Efficacy Phase Participant Profiles

1. Lithium serum level <0.20 mEq/L is defined as Below Quantifiable Limits < 0.20 mEq/L (BQL).

2. The baseline creatinine clearance value is carried over from Screening Phase. Unit for Creatinine Clearance is mL/min/1.7m^2^.

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID ▬), Randomized Treatment: Placebo

Clinical Outcomes over Time ID ▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Placebo

Clinical Outcomes over Time ID (▬, Randomized Treatment: Placebo

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Placebo

Clinical Outcomes over Time ID (▬), Randomized Treatment: Placebo

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Placebo

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Placebo

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Placebo

Clinical Outcomes over Time ID (▬), Randomized Treatment: Placebo

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Placebo

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Placebo

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Placebo

Clinical Outcomes over Time ID (▬), Randomized Treatment: Placebo

Clinical Outcomes over Time ID (▬), Randomized Treatment: Placebo

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Placebo

Clinical Outcomes over Time ID (▬), Randomized Treatment: Placebo

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Placebo

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Placebo

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Placebo

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Placebo

Clinical Outcomes over Time ID (▬), Randomized Treatment: Placebo

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Placebo

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Placebo

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Placebo

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID ▬, Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Placebo

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬, Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Lithium

Clinical Outcomes over Time ID (▬), Randomized Treatment: Placebo

Clinical Outcomes over Time ID (▬), Randomized Treatment: Placebo

Figure 14.4.2 Long-Term Effectiveness Phase Participant Profiles

1. Lithium doses are in blue, Placebo doses are in green. Overall study doses in mg/kg/day are in red.

2. Lithium serum level <0.20 mEq/L is defined as Below Quantifiable Limits < 0.20 mEq/L (BQL).

3. The baseline creatinine clearance value is carried over from Screening Phase. Unit for Creatinine Clearance is mL/min/1.7m^2^.

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID (▬)

Long Term Effectiveness Phase - Clinical Outcomes over Time ID ▬