# 5 ETHICS

## 5.1 Institutional Review Board (IRB)

Institutional Review Board (IRB) approval of the protocol, informed consent, and participant information and/or advertising as relevant was obtained prior to the authorization of drug shipment to a study site. Any amendments to the protocol received IRB approval prior to implementation of any changes made to the study design. Detailed IRB information is provided in Appendix 16.1.3.

## 5.2 Ethical Conduct of the Study

This study was conducted in accordance with the ethical principles originating from the Declaration of Helsinki and current GCP and in compliance with local regulatory requirements and 21 CFR 312.

## 5.3 Participant Information, Consent, and Assent

All participants in this study were minors (under the age of 17 years). The investigator or designated representative explained the nature of the study to the participant and the participant’s parents or legal guardian, to the extent compatible with the participant’s understanding, and answered all questions regarding this study. Prior to any study related screening procedures being performed on the participant, the informed consent (parental permission) statement was signed and dated by the participant’s parent or legal guardian and by the person who administered the informed consent. In accordance with each clinical site’s IRB requirements, children who could read and understand the assent form were asked to give written assent. A copy of the informed consent and assent forms (ICF) were given to the participant, or the participant’s parents or legal guardian, and the originals were placed in the participant’s medical record. An entry was also made in the participant’s source documents to confirm that informed consent/assent was obtained prior to any study-related procedures and that the participant, or the participant’s parents or legal guardian, received signed copies. During study visits, children and their guardians were asked whether they wish to continue participation in the study and reminded that they may withdraw their consent at any time without consequence. In addition, the Health Insurance Portability and Accountability Act (HIPAA) statement was reviewed, signed, and dated by the participant’s parent or legal guardian. A sample ICF is provided in Appendix 16.1.3.