# 16 APPENDICES

16.1 Study Information (COLT2)
  16.1.1 Protocol and Protocol Amendments
  16.1.2 Sample Case Report Forms
  16.1.3 Institutional Review Boards (IRBs) and Participant Consents and Information
  16.1.4 Description of Investigators
  16.1.5 CSR Signature Pages
  16.1.6 Batch Numbers
  16.1.7 Randomization Information
  16.1.8 Audit Certificates
  16.1.9 Statistical Analysis Plan
  16.1.10 Documentation of Inter-laboratory Standardization Methods and Quality Assurance Procedures
  16.1.11 Publication Based on the Study
  16.1.12 Important Publications Referenced in the Report
  16.1.13 FDA Written Request for Lithium
16.2 Participant Data Listings (COLT2)
16.3 Case Report Forms for Participants with SAEs/Stopped Study Meds Due to AE (COLT2)
16.4 Miscellaneous
  16.4.1 COLT2 Interim Analyses
  16.4.2 COLT1 Discontinuation Phase Unblinding Information
    16.4.2.1 COLT1 Treatments Assignments (Unblinded) and MedDRA Updates for AEs (datasets and define.pdf)
    16.4.2.2 COLT1 Unblinded Protocol Deviations
    16.4.2.3 COLT1 Randomization Errors (Unblinded)
16.5 Datasets and Define.pdf (COLT2)
  16.5.1 Define.pdf
  16.5.2 Datasets
  16.5.3 SAS Programs for Efficacy Results

For documents listed but not available for download, please check the DASH repository at https://dash.nichd.nih.gov/study/16020