# 4 GLOSSARY OF ABBREVIATIONS AND TERMS

AE: Adverse Event
ALT: Alanine Transaminase
AST: Aspartate Transaminase
AUC: Area Under the Concentration Time Curve
BPCA: Best Pharmaceuticals for Children Act
BMI: Body Mass Index
CDC: Centers for Disease Control and Prevention
CFR: Code of Federal Regulations
CL: Clearance
Cl/F: Oral Apparent Clearance
CRF: Case Report Form
CYP: Cytochrome
DCC: Data Coordinating Center
DCRI: Duke Clinical Research Institute
DMC: Data Monitoring Committee
ECLS: Extracorporeal Life Support
EDC: Electronic Data Capture
FDA: Food and Drug Administration
FFM: Free Fat Mass
NFM: Normal Fat Mass
GCP: Good Clinical Practice
HIPAA: Health Insurance Portability and Accountability Act
IBW: Ideal Body Weight
ICH: International Conference on Harmonisation
ICMJE: International Committee of Medical Journal Editors
IND: Investigational New Drug Application
IRB: Institutional Review Board
IV: Intravenous
kg: Kilogram
LBW: Lean Body Weight
MedDRA: Medical Dictionary for Regulatory Activities
MIC: Minimum Inhibitory Concentration
mg: Milligram
MOP: Manual of Procedures
MRSA: Methicillin-resistant Staphylococcus aureus
N: Number (typically refers to participants)
NFM: Normal Fat Mass
NICHD: National Institute of Child Health and Human Development
NIH: National Institutes of Health
NPO: Nothing by Mouth
PD: Pharmacodynamics
PG: Pharmacogenomic
PK: Pharmacokinetics
PO: Oral
PTN: Pediatric Trials Network
SAE: Serious Adverse Event
T½: Half-life
V: Volume of Distribution
WT: Total Body Weight