# 13 DISCUSSION AND OVERALL CONCLUSIONS

## 13.1 Primary Endpoint: PK

The final population PK model is:

CL ( L / h ) = 13.8 * ( WT / 70 )^0.75^ * ( PMA^2.83^ / ( 39.5^2.83^ + PMA^2.83^ ) )

V ( L ) = 63.6 * ( WT / 70 ) * ( ALB / 3.3 )^− 0.83^ * ( AAG / 2.4 )^− 0.25^

After accounting for size-based differences using total body weight and physiologic differences using age, only V and terminal elimination half-life were significantly different between obese and non-obese children. V normalized by body weight did not differ between obese and non-obese children. Clindamycin may be dosed based on total body weight (max dose 2.7 g/day) without dose adjustment based solely on obesity.

At the following doses, simulated clindamycin exposures for children and adolescents using total body weight match exposures known to be efficacious in adults (600 mg every 8 hours):

- 12 mg/kg every 8 hours in children 2-6 years
- 10 mg/kg every 8 hours in children and adolescents >6-18 years

## 13.2 Secondary Endpoint: Safety

Overall, clindamycin was very well tolerated in this open-label study. Three AEs (one of which was an SAE) were reported in 2 (9%) of 22 participants, none of which were considered related to study drug.

## 13.3 Overall Conclusions

Clindamycin may be dosed based on total body weight (max 2.7 g/day) without adjustment for obesity.