# 12 SAFETY EVALUATION

## 12.1 Demographic and Other Baseline Characteristics

Baseline demographics for the safety population are presented in Table 12-1. and Table 14.1.2.1.1 Median and mean age of the participants was 13.2 years. Eighteen (82%) participants were male. Eighteen (82%) were of Caucasian descent, 2 (9%) were Black and 2 (9%) were not reported. Two (9%) participants were reported to be of Hispanic or Latino ethnicity.

Table 12-1 Participant Demographics (Safety Population)

Demographics | Age 2 - <12 years | | Age 12 - <18 years | | Total; (N=22)
Demographics | BMI 85^th^ - <95^th^ percentile; (N=4) | BMI ≥95^th^ percentile; (N=3) | BMI 85^th^ - <95^th^ percentile; (N=4) | BMI ≥95^th^ percentile; (N=11) | Total; (N=22)
Age (years)
N | 4 | 3 | 4 | 11 | 22
Mean (SD) | 9.4 (2.7) | 10.6 (1.4) | 14.6 (1.7) | 14.8 (1.7) | 13.2 (2.9)
Median (Min, Max) | 9.5 (6.5, 11.9) | 10.7 (9.1, 11.9) | 14.5 (12.6, 16.8) | 14.9 (12.5, 17.4) | 13.2 (6.5, 17.4)
Gender
Male | 2 (50%) | 3 (100%) | 3 (75%) | 10 (91%) | 18 (82%)
Female | 2 (50%) | 0 | 1 (25%) | 1 (9%) | 4 (18%)
Race
White or Caucasian | 4 (100%) | 2 (67%) | 2 (50%) | 10 (91%) | 18 (82%)
Black or African American | 0 | 0 | 1 (25%) | 1 (9%) | 2 (9%)
Not Reported | 0 | 1 (33%) | 1 (25%) | 0 | 2 (9%)
Ethnicity
Hispanic or Latino | 1 (25%) | 0 | 0 | 1 (9%) | 2 (9%)
Not Hispanic or Latino | 3 (75%) | 2 (67%) | 3 (75%) | 10 (91%) | 18 (82%)
Not Reported | 0 | 1 (33%) | 1 (25%) | 0 | 2 (9%)

Source: Table 14.1.2.1.1

Growth parameters including weight, height, BMI, waist, hip and waist/hip ratio are summarized in Table 14.1.2.1.2 and Table 12-2. Median (range) BMI percentile for the 22 participants was 97.0 (86.0 - >99.9). Median waist to hip ratio was 0.94 (0.73 - 1.10).

Table 12-2 Growth Parameters (Safety Population)

Demographics | Age 2 - <12 years | | Age 12 - <18 years | | Total; (N=22)
Demographics | BMI 85^th^ - <95^th^ percentile; (N=4) | BMI ≥95^th^ percentile; (N=3) | BMI 85^th^ - <95^th^ percentile; (N=4) | BMI ≥95^th^ percentile; (N=11) | Total; (N=22)
BMI percentile
N | 4 | 3 | 4 | 11 | 22
Mean (SD) | 90.5 (3.6) | 97.4 (1.2) | 91.7 (3.0) | 98.3 (1.3) | 95.5 (4.0)
Median (Min, Max) | 90.8 (86.0, 94.2) | 97.6 (96.1, 98.4) | 92.1 (87.8, 94.8) | 98.9 (95.7, >99.9) | 97.0 (86.0, >99.9)
Waist/hip ratio
N | 4 | 3 | 4 | 11 | 22
Mean (SD) | 0.86 (0.05) | 0.91 (0.16) | 0.90 (0.08) | 0.99 (0.07) | 0.94 (0.09)
Median (Min, Max) | 0.87 (0.80, 0.90) | 1.00 (0.73, 1.00) | 0.90 (0.80, 1.00) | 1.00 (0.90, 1.10) | 0.94 (0.73, 1.10)

Source: Table 14.1.2.1.2

Baseline medical history is presented in Table 12-3 and Table 14.1.2.2 by MedDRA system - (versions 14.1 – 17.1) organ class and preferred term. Table 14.1.2.2 shows the diversity in the medical history of this group of participants. Table 12-3 lists the most frequently occurring preferred terms (in >10% of the participants). Six (27%) participants had a history of cellulitis, 4 (18%) each had a history anaemia and/or pyrexia, and 3 (14%) each had a history of abdominal pain, convulsions and/or staph infections.

Table 12-3 Baseline Medical History, Most Frequently Occurring (>10% of the Participants) Preferred Terms (Safety Population)

System Organ Class; Preferred Term | Age 2 - <12 years | | Age 12 - <18 years | | Total; (N=22)
System Organ Class; Preferred Term | BMI 85^th^ - <95^th^ percentile; (N=4) | BMI ≥95^th^ percentile; (N=3) | BMI 85^th^ - <95^th^ percentile; (N=4) | BMI ≥95^th^ percentile; (N=11) | Total; (N=22)
Infections and infestations
Cellulitis | 1 (25%) | 2 (67%) | 1 (25%) | 2 (18%) | 6 (27%)
Blood & lymphatic system disorders
Anaemia | 1 (25%) | 1 (33%) | 0 | 2 (18%) | 4 (18%)
General Disorders
Pyrexia | 1 (25%) | 1 (33%) | 1 (25%) | 1 (9%) | 4 (18%)
Gastrointestinal disorders
Abdominal pain | 0 | 1 (33%) | 0 | 3 (27%) | 3 (14%)
Nervous system disorders
Convulsion | 0 | 0 | 0 | 3 (27%) | 3 (14%)
Infections and infestations
Staphylococcal infection | 1 (25%) | 0 | 2 (50%) | 0 | 3 (14%)

Source: Table 14.1.2.2

## 12.2 Extent of Exposure

The extent of exposure to study medication is summarized along with PK results, in Section 11. Listings of study drug administration for individual participants are provided in Section 16, Listing 16.2.6. Table 12-4 presents a summary of time on Study IV clindamycin by age/BMI group. Participants were receiving study doses of clindamycin for a median of 12.5 hours with a range of 5.6 hours to 198.2 hours (or 8.3 days). The participant who went on to PO dosing received IV study clindamycin for 5.9 hours and PO clindamycin for 4 days. The median duration of IV clindamycin was approximately half in participants in the 85^th^ - <95^th^ percentile cohorts across both age groups compared to participants with BMI >= 95^th^ percentile.

Table 12-4 Time on Study IV Clindamycin (Safety Population)

Hours on IV study clindamycin | Age 2 - <12 years | | Age 12 - <18 years | | Total; (N=22)
Hours on IV study clindamycin | BMI 85^th^ - <95^th^ percentile; (N=4) | BMI ≥95^th^ percentile; (n=3) | BMI 85^th^ - <95^th^ percentile; (N=4) | BMI ≥95^th^ percentile; (N=11) | Total; (N=22)
Hours on-study
N | 4 | 3 | 4 | 11 | 22
Mean (SD) | 11.6 (8.9) | 14.5 (8.1) | 15.6 (16.6) | 48.9 (63.6) | 31.4 (48.0)
Median (Min, Max) | 8.1 (5.6, 24.8) | 15.9 (5.9, 198.2) | 7.9 (6.1, 40.4) | 16.3 (5.9, 198.2) | 12.5 (5.6, 198.2)

Source: Listing 16.2.6

## 12.3 Adverse Events

For this study, safety was assessed from the time of informed consent through 72 hours after completion of the last study dose. All adverse events were coded using MedDRA version 17.0.

### 12.3.1 Summary of Adverse Events

An overall summary of tolerability is shown in Table 14.3.1.1 and Table 12-5.. Overall, 3 AEs were reported in 2 (9%) of the 22 safety participants during the study. The maximum severity of any AE was moderate for 1 participant and severe for 1 participant.

Table 12-5 Overall Summary of Tolerability (Safety Population)

| Age 2 - <12 years | | Age 12 - <18 years | | Total; (N=22)
| BMI 85^th^ - <95^th^ percentile; (N=4) | BMI ≥95^th^ percentile; (N=3) | BMI 85^th^ - <95^th^ percentile; (N=4) | BMI ≥95^th^ percentile; (N=11) | Total; (N=22)
Number of AEs | 1 | 0 | 0 | 2 | 3
Participants with at least 1 AE | 1 (25%) | 0 | 0 | 1 (9%) | 2 (9%)
Participants with at Least One AE by Severity^1^
No reported AEs | 3 (75%) | 3 (100%) | 4 (100%) | 10 (91%) | 20 (91%)
Moderate | 0 | 0 | 0 | 1 (9%) | 1 (5%)
Severe | 1 (25%) | 0 | 0 | 0 | 1 (5%)
Participants with at Least One AE by Causality^2^
No reported AEs | 3 (75%) | 3 (100%) | 4 (100%) | 10 (91%) | 20 (91%)
Not Related | 1 (25%) | 0 | 0 | 1 (9%) | 2 (9%)

1 Participants are counted only once at the greatest severity.

2 Participants are counted only once at the strongest relationship to study drug (causality).

Source: Table 14.3.1.1

### 12.3.2 Display of Adverse Events

AE and SAE data are presented in the following tables:

- Overall summary of AEs by Age/BMI Stratum in Section 14, Table 14.3.1.1.
- Summary of AEs by MedDRA System Organ Class, Preferred Term and Age/BMI Stratum in Section 14, Table 14.3.1.2.1
- Summary of SAEs by MedDRA System Organ Class, Preferred Term and Age/BMI Stratum in Section 14, Table 14.3.1.2.2.
- Summary of AEs by MedDRA System Organ Class, Preferred Term, Severity and Age/BMI Stratum in Section 14, Table 14.3.1.3.
- Summary of AEs by MedDRA System Organ Class, Preferred Term, Relationship to study medication and Age/BMI Stratum in Section 14, Table 14.3.1.4.

Individual patient data associated with AEs are listed in Section 16 as follows:

- All AEs (Listing 16.2.7.1),
- All SAEs (Listing 16.2.7.2),
- AEs resulting in death (Listing 16.2.7.3)

### 12.3.3 Analysis of Adverse Events

This study reported 3 adverse events in 2 participants:

- Participant ▬ reported severe apnea, unrelated to study drug. This event occurred and resolved after consent but before the first dose of study drug. It was deemed an important medical event and therefore an SAE.
- Participant ▬ reported after first study dose, a moderate worsening of rash on coccyx area of buttock, unrelated to study drug. This AE was resolved by convention when the safety follow-up was completed. This participant also reported moderate thrombus of right internal jugular, after first study dose and unrelated to study drug. This AE was also resolved by convention when the safety follow-up was completed.

### 12.3.4 Listing of Adverse Events by Participant

All AEs for each participant are provided in Listing 16.2.7. The listing includes SOC, preferred term, start and stop date for each AE, relationship to study drug, action taken, severity, outcome, treatment given, and a column for indicating seriousness (SAEs).

## 12.4 Deaths, Other Serious Adverse Events, and Other Significant Adverse Events

### 12.4.1 Listing of Deaths, Other Serious Adverse Events and Other Significant Adverse Events

#### 12.4.1.1 Deaths

There have been no deaths reported on this study.

#### 12.4.1.2 Other Serious Adverse Events

There has been 1 SAE reported for this study, described above. The SAE narrative is included in Section 14.5.

## 12.5 Clinical Laboratory Evaluation

Laboratory values were collected within 72 hours prior to the first dose of study drug through 3 days (+/− 1 day) after the last dose of study drug. Laboratory values were required at baseline (72 hour prior to the first dose of study drug) and at end of therapy (± 24 hours of discontinuation of study drug). During study days 1-14 and during the follow-up period laboratory values obtained per standard of care were recorded.

Descriptive summaries (mean, standard deviation (SD), median, minimum, and maximum) of observed values at baseline, during treatment, end of study drug and post treatment follow-up by Age/BMI stratum in tables. Box plots present the overall summary of laboratory values from baseline, end of study drug visit and change from baseline to end of study drug.

Hematology measurements include hematocrit, hemoglobin, platelet count and white blood count and are summarized in Tables 14.3.2.1.1 through 14.3.2.1.4 and Figures 14.4.2.1 through 14.4.2.4 and Table 12-6 below. Participants had a median hemoglobin value of 12.3 g/dL at baseline and 12.0 g/dL at end of study dose. The median change (from baseline to end of dose) was −0.3 g/dL. Median WBC value was 9.7 10^3^/µL at baseline and 8.2 at end of study, with a change of −2.1 10^3^/µL.

Table 12-6 Clinical Laboratory Hematology Measurements (Safety Population)

Hematology | Baseline visit (pre-dose) | End of Study Dose Visit | Change from Baseline to End of Study Dose Visit
Hemoglobin (g/dL)
N | 21 | 20 | 19
Mean (SD) | 11.8 (1.9) | 11.7 (1.8) | −0.2 (0.9)
Median (Min, Max) | 12.3 (8.1, 15.4) | 12.0 (8.2, 15.2) | −0.3 (−2.3, 1.1)
White Blood Count (10^3^/µL)
N | 21 | 20 | 19
Mean (SD) | 12.2 (7.4) | 8.5 (3.8) | −3.4 (6.7)
Median (Min, Max) | 9.7 (0.2, 36.3) | 8.2 (0.3, 17.2) | −2.1 (−28.2, 5.6)

Source: Section 14, Tables 14.3.2.1.1–14.3.2.1.4 and Figures 14.4.2.1–14.4.2.4

Chemistry measurements include albumin, ALT, AST, bicarbonate, total bilirubin, BUN, calcium, chloride, creatinine, glucose, potassium, total protein and sodium. These are summarized in Tables 14.3.2.2.1 through 14.3.2.2.13 and Figures 14.4.3.1 through 14.4.3.13 and Table 12-7. ALT and AST changed little from baseline to last study dose, median ALT change was 2 U/L and median AST change was 0 U/L. Median decline in total bilirubin was −0.2 mg/dL and creatinine did not change (median change 0 mg/dL).

Table 12-7 Clinical Laboratory Chemistry Measurements (Safety Population)

Chemistry | Baseline visit (pre-dose) | End of Study Dose visit | Change from baseline to end of Study dose visit
ALT (U/L)
N | 21 | 20 | 19
Mean (SD) | 33 (25) | 30 (11) | 0 (15)
Median (Min, Max) | 27 (10, 114) | 31 (10, 51) | 2 (−46, 27)
AST (U/L)
N | 21 | 20 | 19
Mean (SD) | 33 (30) | 25 (8) | −2 (12)
Median (Min, Max) | 25 (8, 151) | 24 (7, 36) | 0 (−43, 14)
Total Bilirubin (mg/dL)
N | 20 | 20 | 19
Mean (SD) | 0.8 (0.9) | 0.4 (0.2) | −0.3 (0.5)
Median (Min, Max) | 0.6 (0.2, 3.8) | 0.4 (0.1, 0.7) | −0.2 (−2.1, 0.2)
Creatinine (mg/dL)
N | 21 | 20 | 19
Mean (SD) | 0.62 (0.28) | 0.58 (0.17) | −0.05 (0.17)
Median (Min, Max) | 0.60 (0.24, 1.54) | 0.58 (0.30, 0.95) | 0.00 (−0.59, 0.10)

Source: Section 14, Tables 14.3.2.2.1–14.3.2.2.13 and Figures 14.4.3.1–14.4.3.13

## 12.6 Other Observations Related to Safety

### Microbiology Cultures

All microbiology cultures obtained per standard of care within the 72 hours prior to first dose of study drug until the end of study dose visit were collected and are summarized in Table 14.3.3. Thirty five (35) culture results were obtained from 18 participants, a median of 1.5 cultures per participant; minimum was 0 cultures and maximum was 5 cultures.

Forty-nine percent (17/35) were blood cultures, 34% (12/35) were abscess cultures, 11% (4/35) were urine cultures and 1 culture each from joint aspirate and swab sternoclavical joint. Most frequent method of acquisition was peripheral (11/35) and cutaneous swab (9/35). Culture result was positive in 51% (18/35). Positive cultures, reported in Table 12-8, include 10 methicillin resistant Staphylococcus aureus and 3 Staphylococcus aureus with unknown susceptibility (2 other cultures were positive for Staphylococcus epidermidis and Staphylococcus sp. coagulase negative).

Table 12-8 Microbiology Culture Results (Safety Population)

Microbiology results | Results
Negative | 17 (49%)
Positive | 18 (51%)
Positive Results
MRSA | 9
MRSA/gram + cocci in clusters | 1
Staphylococcus aureus, susceptibility unknown | 3
Bacillus sp./gram + cocci in chains/Enterococcus sp./group F beta hemolytic streptococci/Escherichia coli | 1
Staphylococcus epidermis | 1
Staphylococcus sp. (coagulase -) | 1
Bacteroides fragilis group beta/lactamase + | 1
Gram + cocci in pairs | 1

Source Listing 16.2

### Concomitant Medications

All concomitant medications of interest as specified in Appendix II of the protocol were required to be reported if administered within 7 days prior to first study dose and during the period of administration of study drug. There were no reported concomitant medications of interest administered during this study.

### Physical Examination

Physical examination was completed at baseline (pre-dose) and end of study dose visit. Each body system was recorded as normal, abnormal not clinically significant or abnormal clinically significant. At baseline (Table 14.3.4.1) all 22 participants completed the physical examination. There were 5 participants with skin coded as abnormal clinically significant, 2 participants with musculoskeletal system coded as abnormal clinically significant and 1 each with head, abdomen and nervous systems abnormal clinically significant. At the end of study visit (Table 14.3.4.2), 21 participants completed the physical examination. Systems coded as abnormal clinically significant included 5 participants with skin, 2 participants with musculoskeletal system and 1 participant with nervous system.

## 12.7 Safety Conclusions

Clindamycin was well tolerated in this open-label study of 22 children and adolescents. Overall, 3 AEs were reported in 2 (9%) of the 22 participants. None of these were considered related to study drug. One participant had an SAE.