# 9 INVESTIGATIONAL PLAN

## 9.1 Overall Design and Plan Description

NICHD-2012-CLN01 was a prospective, open-label safety and PK study of multiple doses of IV and oral clindamycin in overweight and obese children 2 to < 18 years of age. Figure 9-1 presents the timeline for study participation. Duration of therapy was up to 14 days for children who receive the first dose of IV clindamycin as the study drug. The total duration of therapy with clindamycin was determined by the treating physician for those children who were receiving clindamycin as part of routine care; however, only 14 days of therapy was considered as study drug period. Study follow-up occurred 3 days (+/− 1 day) after the last dose of study drug. Patients who were receiving antimicrobial agents other than clindamycin were allowed to enroll in this study and to receive up to 3 doses of IV clindamycin and 4 doses of oral clindamycin in addition to their standard of care therapy. Participants who transitioned to oral clindamycin were asked return as outpatients to complete the PK portion of the study.

Total duration of study participation was up to 18 days. This was comprised of a 1-day screening period; a maximum 14-day treatment period; and a 3-day post-study observation period to monitor for serious adverse events. The 3-day post-treatment visit could be a phone follow-up. Participants could continue clindamycin per their physician’s recommendation after they completed study participation.

Figure 9-1 Study Participation Timeline

* Minimum of 1 dose of IV clindamycin before IV PK period

**Minimum of 3 doses of PO clindamycin before PO PK period

Participant enrollment occurred in two age strata – Age 2 ≤ 12 years and Age 12 ≤ 18 years. Enrollment was further stratified based on Body Mass Index (BMI) of participants. Figure 9-2 presents a schematic description of the planned study design.

Figure 9-2 Schematic Description of Planned Study Design

* IV participants who transitioned to oral clindamycin also participated in the oral PK study.

** Minimum of 3 participants with BMI > 97^th^ percentile in each age group.

## 9.2 Discussion of Study Design

Limited PK data on clindamycin are available for obese children. Clinically, drug dosing in pediatrics is individualized to age by basing the drug dose on a patient’s body weight and the dose interval on the functional capacity of the drug’s clearance pathways. This approach assumes, though inaccurately, that a drug’s V and body CL are directly proportional to a patient’s body weight. Complicating this paradigm are the substantially increasing numbers of children and adolescents who are obese, and even morbidly obese, and the lack of data on disposition in the obese population.

## 9.3 Selection of Study Population

Eligible participants ages 2 to <18 years were identified through the inpatient units at each participating site. The study was expected to enroll 12 (24 total) evaluable participants in each of the following age groups: 2 to <12 years and 12 to < 18 years of age; evaluable participants are those with at least one evaluable PK sample. If dosing changes had been suggested by the interim PK analysis, approximately 8 additional participants were to be enrolled for a total of 32 evaluable participants. Based on the interim analysis results (Appendix 16.4.5), it was determined that no additional subjects need to be enrolled in the NICHD-2012-CLN01 study and 22 enrolled participants would be sufficient for the final analyses. Participants were further stratified into 1 of 2 groups based on their BMI (85^th^ to <95th percentile, and ≥95th percentile). No more than 3 participants with BMI in the 85^th^ to <95th percentile were expected to be enrolled in each age group. Participating sites prioritized enrollment of participants with BMI >97^th^ percentile in each age group.

The investigator or other study site personnel documented in the source documents (e.g., the hospital chart) that informed consent and assent (if applicable) were obtained. Laboratory tests or non-pharmacologic treatment procedures that were performed and considered “routine care” within 72 hours of first dose of study drug could be used for screening procedures instead of a study specific blood draw to fulfill protocol requirements and was recorded in the case report form (CRF).

### 9.3.1 Inclusion Criteria

1. 2 years – < 18 years of age at the time of first dose of study drug
2. Suspected or confirmed infection OR receiving IV clindamycin per routine care
3. Negative serum pregnancy test (if female and has reached menarche) within 24 hours prior to first dose of study drug and agreement to practice appropriate contraceptive measures, including abstinence, from the time of the initial pregnancy test through the last dose of study drug
4. BMI ≥ 85th percentile for age and sex, based on CDC recommendations
5. Obtained informed consent/HIPAA from the parent/legal guardian and assent (if applicable)

### 9.3.2 Exclusion Criteria

1. The following apply only to those who are NOT already receiving clindamycin per routine care:
  a. History of hypersensitivity or allergic reaction to clindamycin or lincomycin
  b. History of C. difficile colitis with previous administration of clindamycin
  c. AST > 120 units/L
  d. ALT > 210 units/L
  e. Total bilirubin > 3 mg/dL
  f. Serum creatinine > 2 mg/dL
  g. Receiving a neuromuscular blocker as part of their therapy
2. Previous participation in the study
3. Current exposure to medication listed in Appendix IIA of the protocol (Appendix 16.1.1)
4. Participant is receiving extracorporeal life support (ECLS)
5. Participant is post-cardiac bypass (within 24 hours)
6. Participant on inotropes/pressors
7. Any other condition or chronic illness that, in the opinion of the principal investigator, makes participation unadvised or unsafe

### 9.3.3 Removal of Participants from Therapy or Assessment

Participants in the IV portion of this study who were unable to provide at least 3 timed PK samples would have been replaced; no participants were replaced.

## 9.4 Treatments

### 9.4.1 Treatments Administered

Clindamycin phosphate, USP (IV) was supplied in vials with clindamycin 150 mg/mL and was diluted prior to IV administration. The concentration of clindamycin in diluent for infusion did not exceed 18 mg/mL. The drug was infused over 30 (+/− 5) minutes. Infusion rates did not exceed 30 mg/minute. The pharmacy prepared the IV formulation, and the dose administered was based on WT.

Clindamycin hydrochloride, USP (PO capsules) was available as 150 mg and 300 mg capsules, and the dose was dispensed based on WT. See protocol (Appendix 16.1.1–Apx III).

Clindamycin palmitate hydrochloride, USP for oral solution was available in 100 mL bottles and was prepared in the pharmacy at each site based on the reconstitution recommendation in the package insert. The dose administered was based on WT.

### 9.4.2 Identity of Investigational Products

All study drugs were standard formulations of clindamycin. Each product was “off the shelf” as determined by the site. The pharmacist at each site prepared and dispensed the study drug. Intravenous (IV) study drug was dispensed by the pharmacy in appropriately sized syringes. If participant received study drug as part of clinical care, the dose and frequency was recorded. The order for the study drug was written by the site PI or a qualified designee. The lot number and manufacturer name for each dose of study clindamycin administered was recorded when available (Appendix 16.1.6).

### 9.4.3 Method of Assigning Participants to Treatment Groups

This was an open-label safety and PK study. Participants were assigned to age groups based on age upon first dose of study drug and to a BMI group based on BMI obtained at baseline (Day 0). The study drug was defined as dose(s) given post-consent after all inclusion and exclusion criteria were met.

### 9.4.4 Selection of Doses in the Study

A dose of 30–40 mg/kg/day divided q6h or q8h with a maximum dose of 2.7 g/day was selected based on current labeling. Patients who were receiving clindamycin as part of their routine care were also eligible to participate if their dose could have been adjusted to be at least 30 mg/kg/day upon enrollment. Dosing greater than 2.7 g/day was allowed for children receiving clindamycin as part of clinical care. The dose administered was based on total body weight (WT). Because bioavailability is estimated at 85%, the same dose was used for oral administration as was used for IV dosing. Both solution and capsule preparations were included in this study because both oral formulations were used in clinical practice, and it was expected to allow the inclusion of those patients who could not swallow pills. In the absence of PK data, we assumed that drug clearance would be comparable in obese pediatric patients compared to non-obese pediatric patients. Therefore, a dosing regimen 30–40 mg/kg per day and a maximum dose of 2.7 g/day was expected to provide exposures similar to those used in children and adolescents with a normal BMI. It was predicted to be safe in the obese population because similar doses are currently used per routine care.

### 9.4.5 Selection and Timing of Dose for Each Participant

Both q6h and q8h dosing were allowed for both oral and IV dosing of clindamycin. For participants receiving clindamycin as part of clinical care, the protocol did not prescribe a route of administration or dosing interval; the dose, route of administration, and dosing interval prescribed by the treating physician were recorded. However, if the prescribed dose was less than the lowest dose for this study (30 mg/kg/day), the dose of clindamycin was increased to comply with the protocol defined study dose. Pre-study IV dose could count towards a PK sampling dose if it was the same dose as specified by the protocol.

### 9.4.6 Blinding

This was an open-label study.

### 9.4.7 Prior and Concomitant Therapy

Concomitant medications of interest are listed in the protocol (Appendix 16.1.1–Apx III).

### 9.4.8 Treatment Compliance

All participants were inpatients in the hospital. Therefore, each dose of study drug administration was given and monitored by hospital staff, then reviewed by study personnel. The protocol provided requirements for study medication dosing. For those participants who were discharged on oral clindamycin and had not completed the PO PK visit, the participant or parent/guardian kept a drug administration diary and all drugs were accounted for at the outpatient PK study visit.

## 9.5 Efficacy and Safety Variables

### 9.5.1 Efficacy, Pharmacokinetic, and Safety Measurements Assessed and Flow Chart

#### 9.5.1.1 Efficacy Variables

No Efficacy variables were collected in this study.

#### 9.5.1.2 Safety Variables

##### 9.5.1.2.1 Specification of Safety Parameters

Results were tabulated by MedDRA System Organ Class and Preferred Term.

##### 9.5.1.2.2 Methods and Timing for Assessing, Recording, and Analyzing Safety Parameters

Adverse Events (AEs) were collected from the time of consent, throughout the period of study drug administration, and for 3 days following end of therapy with clindamycin. Safety was assessed by frequency and incidence of AEs and SAEs. The Best Pharmaceuticals for Children Act (BPCA) safety monitoring committee (DMC) convened by NICHD reviewed data and safety information from study participants.

###### 9.5.1.2.2.1 Adverse Event

An adverse event (AE) is any untoward medical occurrence in humans, whether or not considered drug-related, which occurs during the conduct of a clinical trial. Any change in clinical status, ECGs, routine labs, x-rays, physical examinations, etc., that is considered clinically significant by the study investigator is considered an AE.

A suspected adverse reaction is any adverse event for which there is a reasonable possibility that the drug caused the adverse event. A reasonable possibility implies that there is evidence that the drug caused the event.

An adverse reaction is any adverse event caused by the drug.

A serious adverse event or serious suspected adverse reaction or serious adverse reaction as determined by the investigator or the sponsor is any event that results in any of the following outcomes:

1. Death
2. Life-threatening AE (“life-threatening” means that the study participant was, in the opinion of the investigator or sponsor, at immediate risk of death from the reaction as it occurred and required immediate intervention)
3. Persistent or significant incapacity or substantial disruption of the ability to conduct normal life functions
4. Inpatient hospitalization or prolongation of existing hospitalization
5. Congenital abnormality or birth defect
6. Important medical event that may not result in one of the above outcomes, but may jeopardize the health of the study participant or require medical or surgical intervention to prevent one of the outcomes listed in the above definition of serious event

###### 9.5.1.2.2.2 Unexpected Adverse Event

This is defined as any adverse event, the specificity or severity of which is not consistent with the package insert, investigational plan, or informed consent.

###### 9.5.1.2.2.3 Identification of Events and Timeframe for Reporting

As all participants in this study had pre-existing medical conditions and were hospitalized at the time of the study, those pre-existing conditions were not considered as adverse events. New events that occurred or pre-existing conditions that worsened in terms of frequency or intensity were reported as adverse events.

All reportable events as defined above, determined to be an AE based on physical examination, laboratory findings, or other means, were recorded in the source documents and entered in the CRF. Each event was recorded on an AE CRF starting after consent had been obtained. The investigator provided the date of onset and resolution, intensity, action(s) taken, changes in study drug dosing, relationship to study drug, and outcome. Any event that began more than 3 days after the last dose of study drug was not captured.

###### 9.5.1.2.2.4 Follow-up of Adverse Events

AEs ongoing at the time of the last dose of study drug were followed up to 3 days after the last dose of study drug. AEs that resolved during the study or follow-up period had the resolution date documented in the CRF. Adverse events that were identified at the last assessment visit/phone contact (or at the early termination visit) were recorded on the AE CRF, with the status of the AE noted. Any events that were identified at the last assessment visit/phone contact were followed for an additional 3 days for AEs and 10 days for SAEs and if still ongoing were “resolved by convention”. All serious suspected adverse reactions were followed until resolution. All enrolled participants in both cohorts who received at least 1 dose of clindamycin were followed for safety.

##### 9.5.1.2.3 Guidelines for Assessing Intensity of an Adverse Event

The investigator used the following definitions when assessing intensity of an adverse event:

1. MILD: Participant is aware of symptoms or has minor findings but tolerates them well, and no or minimal intervention required
2. MODERATE: Participant experiences enough symptoms or findings to require intervention
3. SEVERE: Participant experiences symptoms or findings that require significant intervention

##### 9.5.1.2.4 Guidelines for Determining Causality

The investigator used the following question when assessing causality of an adverse event to study drug: Is there a reasonable possibility that the drug caused the event? An affirmative answer designates the event as a suspected adverse reaction. ‘‘Reasonable possibility’’ means that there is evidence to suggest a causal relationship between the drug and the adverse event.

##### 9.5.1.2.5 Reporting Procedures and Timeframe for Reporting

All AEs were entered into the data system within 72 business hours of identification. All serious events were entered into the data system within 24 hours of identification. If there were technical difficulties encountered when entering the event into the electronic data capture (EDC) system, the SAE was reported to the data coordinating center (DCC) by telephone or FAX communication. Investigators submitted safety reports as required by their local IRB, independent of the reporting requirements specified in the protocol.

###### 9.5.1.2.5.1 Serious Adverse Events

Any serious adverse event entered in the EDC system generated an automatic email notification to the DCC, IND sponsor, protocol chair, and funding sponsor (NICHD). The BPCA DCC medical monitor reviewed all SAEs at the time that they were reported. Investigators also submitted safety reports locally as required by their IRB.

###### 9.5.1.2.5.2 Regulatory Reporting

Any event that required expedited reporting based on federal regulations were forwarded to the IND sponsor. The sponsor or his representative submitted expedited safety reports (IND safety reports) to the FDA and other regulatory agencies as necessary, and informed the DMC and investigators of such regulatory reports. Site investigators submitted IND safety reports as required by their IRB. Documentation of the submission to and receipt by the IRB was retained for each IND safety report. The sponsor submitted a progress report of the investigation annually, which included a summary showing the most frequent and most serious adverse events by body system.

##### 9.5.1.2.6 Type and Duration of Follow-up of Participants after Adverse Events

Adverse events were followed by the investigator or a clinician member of the study team in person if the participant was hospitalized for an AE or SAE. If the participant was not hospitalized, the investigator or a clinician may review the participant’s medical record, contact the participant by phone, or contact the participant’s primary care physician for follow-up.

Participants withdrawn from the study due to an AE, whether serious or non-serious, were followed by the investigator. The medical monitor or study principal investigator was notified if the AE related to overdose of study treatment.

##### 9.5.1.2.7 Halting Rules

Participant safety data were reviewed on an ongoing basis to monitor for halting criteria.

The study enrollment and dosing would have been halted for a safety review by the BPCA DMC if serious adverse reactions occur in ≥ 2 participants.

Furthermore, the NICHD, the IND sponsor, protocol chair, the DMC, and the investigators had the right to recommend termination of this study at their discretion. Possible reasons for termination of the study included, but are not limited to:

1. Adverse events
2. Unsatisfactory enrollment with respect to quantity or quality

The study would have been placed on hold or terminated at a site(s) for the following reasons:

1. Inaccurate or incomplete data collection
2. Falsification of records
3. Failure to adhere to the protocol

##### 9.5.1.2.8 Safety Oversight

This study was overseen by the BPCA DMC, the NICHD, and the FDA. The DMC reviewed data from individual study participants on a quarterly basis to evaluate the progress of the study and the safety and confidentiality of study participants. This evaluation also assessed data quality and timeliness, participant recruitment, accrual, and retention. These reviews allowed the DMC to determine whether there was any change to the anticipated benefit-to-risk ratio of study participation. These reviews allowed the DMC to determine whether the study should: 1) continue as originally designed; 2) implement a protocol change; or 3) be terminated. If a recommendation is made to change the research study design, an adequate rationale for this decision was provided.

#### 9.5.1.3 Schedule of Assessments

Table 9-1 presents the schedule of assessments for this study.

Table 9-1 Schedule of Assessments

Study Event/Day | Baseline/Day 0 | Study Days 1–14 | End of Therapy (Day 14) or Early Withdrawal or Discontinuation | 3-Day Post-Treatment Phone Follow-up
Informed consent/; assent & HIPAA | X
Medical history | X
Demographics | X
Concomitant medications of interest | X | X | X | X
Culture results (if available) | X | X
Physical examination | X | | X
Weight | X
Height | X
BMI | X
Waist:hip ratio | X
Laboratory evaluation^a^ | X | | X
α-1 glycoprotein^b^ | X
Laboratory evaluation (if obtained as part of routine care) | | X | | X
Serum pregnancy test (female only) | X
Feeding status (during PO PK portion only) | | X
Discarded scavenged plasma^c^ | | X | X
Clindamycin IV or PO^d^ | X | X^f^
PK samples^e^ | | X
AE/SAE | X | X | X | X

a Hemoglobin, hematocrit, platelets, white blood cells, sodium, potassium, chloride, bicarbonate, total calcium, glucose, creatinine, blood urea nitrogen, total protein, albumin, aspartate aminotransferase, alanine aminotransferase, bilirubin.

b Central laboratory measured this from plasma sample collected per PK schedule.

c Discarded plasma samples were sometimes collected [underlined: after the first dose of study drug through 24 hours after the last dose of study drug].

d Group assignment.

e PK sampling

f IV clindamycin was continued per treating physician; when switched to PO, participant participated in PO PK study.

Note: Day 0 and Day 1 can be same date, i.e., if consent obtained on same date as first study dose administration.

### 9.5.2 Appropriateness of Measurements

All the safety and PK assessments used in the study were standard assessments.

### 9.5.3 Primary Efficacy Variables

No efficacy variables were collected in this study.

### 9.5.4 Drug Concentration Measurements

The following primary PK parameters were assessed after multiple IV doses of clindamycin:

1. Clearance (CL)
2. Volume of distribution (V)
3. Area under the curve (AUCτ)

The following secondary PK parameters of patients transitioned to oral clindamycin were obtained:

1. Oral apparent clearance (Cl/F)
2. Oral apparent volume of distribution (V/F)

Blood (0.5 mL) was collected with scheduled IV and oral doses of clindamycin for clindamycin plasma concentration determinations. In participants receiving IV clindamycin, PK samples were collected from a site separate from the site of administration. The PK samples were drawn according to the following schedule (Table 9-2) relative to the end of flush (IV PK) or actual time of oral administration (PO PK).

Table 9-2 PK Sample Collection Schedule

| Scheduled PK Sampling Times
Optimal Time (hours)^*^ | Allowable Time^*^ | IV Dose^*^ | | PO Dose
Optimal Time (hours)^*^ | Allowable Time^*^ | Q6h | Q8h | Q6h | Q8h
Pre-dose 0 (within 15 minutes prior to the dose for the timed PK samples) | None | X^**^ | X^**^ | X^**^ | X^**^
0.5 (± 5 minutes) | 5 min to 35 min | X^**^ | X^**^ | N/A | N/A
1–1.5 | >35 min to < 3 hrs | X | X | X^**^ | X^**^
3–4 | 3 hrs to 5 hrs | X^**^ | X^**^ | X^**^ | --
5–6 | 5 hrs to 7 hrs | -- | X | -- | X^**^
Within 60 minutes prior to any subsequent dose (depends on q6h or q8h dose schedule) | None | X^**^ | X^**^ | X^**^ | X^**^
Total number of samples | | 5 | 6 | 4 | 4

* Sampling time starts at end of flush after the 30-minute IV infusion or after actual PO administration time.

** Priority samples (see paragraph below).

Every effort was made to collect all PK samples for each participant. Collection of PK samples were timed with collection of laboratory tests per standard of care to minimize blood draws specifically for the study. If it was impractical to collect all PK samples during the same dosing interval, samples were obtained at different dosing intervals. If it was impossible to obtain all PK samples for each participant, PK samples were prioritized to include:

a) For IV administration: pre-dose, 0.5 hours, 3–4 hours, and pre-next dose
b) For oral administration: pre-dose, 1–1.5 hours, 3–4 hours (q6h dosing), 5–6 hours (q8h dosing), and pre-next dose

Clindamycin concentrations in plasma were measured at a central laboratory using a validated bioanalytical assay. The assay validation report is presented in Appendix 16.4.4. In addition, scavenged samples were obtained. A maximum of 10 scavenged plasma samples were collected per participant. Collections sometimes began with any specimen collected after the first dose of study drug through 24 hours after the last dose of study drug.

#### Minimizing Blood Loss

To minimize the amount of blood sampling, laboratory values were obtained only at baseline and end of study. If they had been obtained as part of routine care within 72 hours prior to first dose of study drug, the baseline laboratory values did not need to be repeated. The PK sampling scheme was employed such that no more than a total of 8 mL (< 3 mL/kg) of blood was obtained from each participant for PK analysis.

### 9.6 Data Quality Assurance

The principal investigator provided direct access to all trial-related sites, source data/documents, data collection forms, and reports for the purpose of monitoring and auditing by the sponsor, and inspection by local and regulatory authorities. The principal investigator ensured that all study personnel were appropriately trained and applicable documentations were maintained on site.

DCC-designated clinical monitors verified that the clinical trial was conducted and data were generated, documented (recorded), and reported in compliance with the protocol, GCP, and the applicable regulatory requirements. Clinical monitoring reports were submitted to the principal investigator, Pediatric Trials Network, and NIH/NICHD.

The DCC implemented quality control procedures beginning with the data entry system and generated data quality control checks that were run on the database. Any missing data or data anomalies were communicated to the site(s) for prompt clarification and resolution.

## 9.7 Statistical Methods and Determination of Sample Size

### 9.7.1 Statistical and Analytical Plans

Descriptive statistics, such as number of observations, mean, median, 95% confidence interval, standard deviation, standard error, minimum, and maximum, are presented by cohort for continuous variables (such as age, weight, and BMI). Other descriptive statistics, such as counts, proportions, and/or percentages, are presented by cohort group to summarize discrete variables (such as race and sex). No inferential statistical tests have been performed in this study.

All analyses and data summaries were produced using SAS^®^ Software version 9.2 or higher.

A complete Statistical Analysis Plan (SAP) was finalized prior to locking the database for the study, and can be found in Appendix 16.1.9.

#### 9.7.1.1 Population for Analysis

All participants that received at least 1 dose of study drug were included in the safety analysis. All participants with at least 1 evaluable PK sample were included in the PK analysis.

Participants that consented and had study procedures completed, but did not receive any study doses or PK draws, were reported separately.

#### 9.7.1.2 Statistical Methodology

Descriptive statistics, such as number of observations, mean, median, standard deviation, standard error, minimum, and maximum, are presented by cohort for continuous variables (such as age, weight, and BMI). Other descriptive statistics, such as counts, proportions, and/or percentages, are presented by cohort group to summarize discrete variables (such as race and sex).

#### 9.7.1.3 Demographics and Baseline Characteristics

The number of participants completed and discontinued early from study, and the reasons for discontinuation, are summarized. Demographic and baseline characteristics are also summarized. Variables include race, ethnicity, age, sex, and selected clinical variables recorded prior to initiation of study drug. Study drug administration is summarized by age and BMI cohorts.

Laboratory data, such as hematology and serum chemistry data, are tabulated by age and BMI cohorts. Continuous laboratory measurements are described using univariate descriptive statistics (mean, median, etc.); observed values and changes from baseline are summarized.

#### 9.7.1.4 Interim PK Analyses

An interim PK analysis was performed to assess whether a sample size of 24 evaluable participants would be sufficient to evaluate the effect of obesity on clindamycin disposition. The analysis included 11 CLN01 obesity participants with 47 PK samples. Based on the interim analysis results, no additional participants were needed for enrollment. Please see Section 11.5.2.3 for further details. In addition, the interim analysis report is presented in Appendix 16.4.5.

#### 9.7.1.5 PK Analysis

A population PK analysis using non-linear mixed effects modeling (NONMEM software, version 7.2) was used to estimate population PK parameters and their variance. The influence of covariates (i.e., total body weight [WT], lean body weight [LBW], normal fat mass [NFM], obese status, etc.) on PK parameters was explored. Post-hoc Bayesian individual PK parameters were estimated for each participant. Descriptive statistics were presented for continuous and categorical variables. Monte Carlo simulations were performed using the final model parameters to assess optimal clindamycin dosing. The proportion of virtual subjects with an unbound concentration at half the dosing interval (fC_50,SS_) greater than a minimum inhibitory concentration of 0.12 mcg/mL (MIC_90_ for Staphylococcus aureus) following optimal dosing was calculated [28].

A detailed description of PK/PD analyses can be found in the PK analysis plan. PK parameters from this study of obese children were compared to non-obese children.

### 9.7.2 Determination of Sample Size

A sample size of 24 was planned with 12 children enrolled and treated in each of the age strata for IV clindamycin. The expectation was that a sample size of 24 participants will provide adequate precision in the Cl/F PK parameter estimate. Assuming an inter-individual 40% coefficient of variation in the population Cl parameter estimate after weight-based allometric scaling, a sample size of 24 participants would provide a margin of error of ± 16% in the 95% confidence interval of the Cl estimate.

## 9.8 Changes in the Conduct of the Study or the Planned Analyses

### 9.8.1 Changes in Conduct of study

The original protocol (Version 1.0) dated October 21, 2012 went through five iterations, which were submitted to FDA. The original protocol and the 5 updated versions along with summary of changes between protocol versions are provided in Appendix 16.1.1. The amendments to the protocol are summarized below.

#### 9.8.1.1 Protocol Version 2.0

Version 2.0, dated December 3, 2012, was issued mainly to change the objectives and clarify a few sections to the study protocol.

Section Heading | Section Number(s) | Changes
Entire Document | Global Change | Changed protocol version from 1.0 dated 21 October 2012 to version 2.0 dated 03 December 2012
Entire Document | Global Change | Updated reference numbering
Entire Document | Global Change | Changed urine pregnancy test to serum pregnancy test
| Cover Page | Updated IND holder to P. Brian Smith
| Protocol Synopsis | Removed obese comparison from Objectives; clarified that dosing greater than 2.7g/day will be allowed for children receiving clindamycin as standard of care.
| Study Event Table | Added waist:hip ratio; updated discarded scavenged samples
Key Roles | Section 1.0 | Added IND Holder, P. Brian Smith contact information
Objectives | Section 3.0 | Removed obese/non-obese comparison from secondary aims
Duration of Study Participation | Section 5.2.1 | Clarified duration of study participation
Summary of Procedures | Section 6.1 | Added waist:hip ratio
Screening | Section 6.2 | Added language about site recruitment prior to IRB approval
Enrolment/Baseline | Section 6.3 | Added waist:hip ratio
Rationale for Dose Selection | Section 7.1.1 | Clarified dose adjustment minimum for standard of care subjects
Dose and Timing | Section 7.1.2 | Clarified dose adjustment limit to allow for standard of care subjects
Institutional Review Board | Section 15.2 | Added that protocol should be reviewed in accordance with subpart D of 45CFR46

#### 9.8.1.2 Protocol Version 3.0

Version 3.0, dated January 18, 2013, was issued to include some minor changes to the study protocol.

Section Heading | Section Number(s) | Changes
Entire Document | Global Change | Changed protocol version from 2.0 dated 03 December 2012 to version 3.0 dated 18 January 2013
| Cover Page | Changed protocol number from NICHD—2012-CLN01 to NICHD—2012-CLIN01
| Study Schematic (Figure 1) | Replaced schematic with updated figure
Screening | Section 6.2 | Added language about the waiver of informed consent and HIPAA authorization

#### 9.8.1.3 Protocol Version 4.0

Version 4.0, dated March 06, 2013, was issued to include some minor changes to the study protocol.

Section Heading | Section Number(s) | Changes
Entire Document | Global Change | Changed protocol version from 3.0 dated 18 January 2013 to version 4.0 dated 06 March 2013
Entire Document | Global Change | Changed trial identifier from CLIN01 to CLN01
Entire Document | Global Change | Changed “subject” to “participant”
| Cover Page | Study title changed to: Pharmacokinetics and Safety Profile of Multiple-Dose Intravenous and Oral Clindamycin in Pediatric Subjects with BMI ≥ 85th Percentile
| Protocol Synopsis | Exclusion criteria 3 reworded as: Current exposure to medication listed in Appendix II.A
| Study Event Table | Row header changed to: Concomitant medications of interest
| Study Event Table | Row header changed to: α-1 glycoprotein (will be done by OpAns at their lab)^b^
| Study Event Table | Footnotes a and b updated.
Inclusion/Exclusion Criteria | Section 5.1 | Exclusion criteria 3 reworded as: Current exposure to medication listed in Appendix II.A
Duration of Study Participation | Section 5.2.1 | Changed as follows: If therapy extends beyond 14 days, the study follow-up visit/call will occur on approximately day 18 (+/− 1 day) (after completion of 3 safety observational days).
Summary of Procedures | Section 6.1 | Summary point #2 changed to: Concomitant medications of interest administered within 7 days prior to first study dose…
Summary of Procedures | Section 6.1 | Following note added: The initial physical examination information (except the height, weight, and waist/hip measurements) may be obtained from the medical record but must have been performed within 24 hours prior to enrollment.; Also refers to CDC website for BMI calculation.
Summary of Procedures | Section 6.1 | Summary point #4 changed to: Baseline laboratory values may be used…. Also added: Alpha-1-glycoprotein will be measured by OpAns at their laboratory using plasma already collected as part of the PK sample collection.
Summary of Procedures | Section 6.1 | Summary point #5 changed to: PK samples will be obtained after at least 2 IV doses of clindamycin are completed…
Screening | Section 6.2 | Removed language about waiver of informed consent and HIPAA authorization. Changed to: Research staff at sites will screen potential subjects for eligibility requirements per local institutional policies.
Enrollment/Baseline | Section 6.3 | Changed baseline assessment #4 to: Concomitant medications of interest (7 days prior to first dose of study drug) (see Appendix II)
Enrollment/Baseline | Section 6.3 | Under Assessments/Procedures (Days 1–14): Participants who transition to oral therapy will also participate in the oral-dose PK portion.
Follow-up Safety Phone call | Section 6.5 | Changed follow-up phone call assessment #2 to: Concomitant medications of interest (Appendix II)
Clinical Laboratory Evaluations | Section 6.6.1 | Changed as follows: Laboratory testing (Table 2) will be collected on all participants and be performed in the local laboratory at each site. Laboratory values will be collected within 72 hours prior to enrollment. Laboratory values performed as part of routine care within 72 hours prior to enrollment may be used for baseline laboratory tests. Laboratory values will also be obtained at the end of therapy. Laboratory values obtained within ± 24 hours of discontinuation of study drug or within ± 24 hours of completion of 14 days of study drug (if they are continuing clindamycin beyond 14 days) may be used as end-of-treatment laboratory values. If these laboratory tests have not been performed as part of routine care, they will be performed for the study per the protocol schedule. The serum pregnancy test will also be performed at the local laboratory. Alpha (α)-1-glycoprotein will be measured from one of the PK samples by the central laboratory once during the study using an ELISA kit (central laboratory). Sites do not need to collect an extra sample to measure α-1-glycoprotein.
| Table 2 | “α-1-glycoprotein (central laboratory)” deleted from table
Special Assays or Procedures | Section 6.6.2 | Changed to: PK samples will be collected after the fourth dose…
Special Assays or Procedures | Section 6.6.2 | Under Minimizing Blood Loss, changed to: … laboratory values will be obtained only at baseline and end of study. If they have been obtained as part of routine care within 72 hours prior to enrollment into the study, the baseline laboratory values do not need to be repeated.
Rationale for Dose Selection | Section 7.1.1 | Clarified dose adjustment minimum for standard of care subjects
Dose and Timing | Section 7.1.2 | Drug admin time changes to 30 (+/− 5) minutes. Changed to: The venous access line will be flushed per local practice after completion of IV administration.; Also added: It is preferred that the flush be equal to or less than 1 minute after the end of infusion.
Dose and Timing | Section 7.1.2 | Under Oral Dosing, changed to: PK samples should be obtained after the fourth dose of PO clindamycin…
Preparation and Administration of Study Intervention/Study Drug | Section 7.2 | Changed to: The drug will be infused over 30 (+/− 5) minutes.
Assessment of Participant Compliance w/Study Intervention | Section 7.5 | Parent/guardian added as accountable for drug administration diary
Assessment of Participant Compliance w/Study Intervention | Section 7.5 | Text changed to: Concomitant medications of interest are listed in Appendix II. Children who are prescribed one of these medications after enrollment may continue in the study.
Concomitant Medications of Interest/Treatments | Section 7.6 | Subheader changed to: Concomitant Medications of Interest
Reporting Procedures and Timeframe for Reporting | Section 8.5 | Protocol chair added to SAE review
Halting Rules | Section 8.7 | Protocol chair added to halting discussion
Assent Process (e.g., Minor) | Section 12.1 | Changed to: Assent forms do not substitute for the consent form signed by the participant’s legal guardian.
Data Capture Methods | Section 16.2 | Clinical data changed to include concomitant medications of interest
Drugs of Interest | Appendix II | Title changed to Medications of Interest
Drugs of Interest | Appendix II | Drug group A changed to: Exclusion for ALL participants at the time of enrollment
Drugs of Interest | Appendix II | Drug group B changed to: Exclusion at the time of enrollment (unless the participant was receiving these drugs prior to enrollment AND was receiving clindamycin as part of routine care prior to enrollment).; Also added: The above drugs are only excluded at the time of enrollment; if a participant begins taking any of the drugs while on-study, he/she will not be discontinued.

#### 9.8.1.4 Protocol Version 5.0

Version 5.0, dated March 22, 2013, was issued to include some minor changes to the study protocol.

Section Heading | Section Number(s) | Changes
Entire Document | Global Change | Changed protocol version from version 4.0 dated 06 March 2013 to version 5.0 dated 22 March 2013
| Cover Page | Study title changed to: Safety and Pharmacokinetics of Multiple-Dose Intravenous and Oral Clindamycin in Pediatric Subjects with BMI ≥ 85th Percentile
Duration of Study Participation | Section 5.2.1 | Changed “If therapy extends beyond 14 days, the study follow-up visit/call will occur on approximately day 18 (+/− 1 day) (after completion of 3 safety observational days)” to “Study follow-up will occur 3 days (+/− 1 day) after the last dose of study drug”.
Duration of Study Participation | Section 5.2.1 | Removed “a minimum 2 doses of IV and 4 doses of oral clindamycin before PK sampling begins for IV and oral routes, repectively;”
Duration of Study Participation | Section 5.2.1 | Footnote for Figure 2 Timeline: Changed from minimum 2 doses of IV to minimum of 1 dose; Also changed minimum of 4 doses of PO to minimum of 3 doses.
Summary of Procedures | Section 6.1 | Removed “will be obtained after at least 2 IV doses of clindamycin are completed and after 4 doses of oral clindamycin”
Follow-up Safety Phone Call | Section 6.5 | Changed follow-up phone call assessment #2 to: Concomitant medications of interest (Appendix II)
Special Assays or Procedures | Section 6.6.2 | Changed from “PK samples…and, for PO clindamycin, PK samples will be collected after the fourth dose or any dose after the fourth dose” to “PK samples…and, for PO clindamycin, PK samples with any dose after the 3^rd^ dose of study drug (excluding the 3^rd^ dose).”
Dose and Timing | Section 7.1.2 | Under Oral Dosing, removed “During the PO phase of the study, PK samples should be obtained after the fourth dose of PO clindamycin (but may be collected with a later dose if unable to do the fourth dose)”.

#### 9.8.1.5 Protocol Version 6.0

Version 6.0, dated May 08, 2014, was issued to include some major changes to the study protocol.

Section Heading | Section Number(s) | Changes
Entire Document | Global Change | Changed protocol version from version 5.0 dated 22 March 2013 to version 6.0 dated 08 May 2014
| Cover Page | Principal Investigator’s faculty role change from “Assistant” to “Associate”
Entire Document | Global Change | - Deleted “Site” from Principal Investigator Signature line.
| Protocol Synopsis | - Number of Sites: Changed from 6 to 8.; - Duration of Subject Participation: Deleted “minimum of 2 doses prior to PK samples and” and “after study drug administration to monitor for serious adverse events”.; - Inclusion Criteria, #3: Changed “within 24 hours of first dose of study drug” to “within 24 hours prior to first dose of study drug”.; - Inclusion Criteria, #5: Changed from “Signed informed consent/HIPAA documents by the parent/legal guardian and assent (if applicable)” to “Obtained informed consent/HIPAA from the parent/legal guardian and assent (if applicable).”
| Table 1. Study Event Table | - Table Header:; - Changed second column header from “Screening/study day 0” to “Baseline/Day 0”.; - Changed third column header from “Study day 1 (any dose after the 1^st^ dose of IV clindamycin) oral PK with 4^th^ dose of later” to “Study days 1–14”.; - Deleted fourth column header “Study day 2–14”. This deleted entire column.; - Table Row:; - Changed “Infection history” to “Culture results (if available)”.; - Changed “Discarded scavenged samples^c^” to “Discarded scavenged plasma^c^”.; - Added reference to footnote ‘f’ in “Clindamycin IV or PO” Study days 1–14 column.; - Table Footnote:; - Clarification of footnote ‘c’. Changed “Discarded blood cells may be collected at any time during the study” to “Discarded plasma may be collected after the first dose of study drug through 24 hours after the last dose of study drug”.; - Added statement footnote. “Note: Day 0 and Day 1 can be same date, i.e., if consent obtained on same date as first study dose administration”.
Study Design | Section 4 | Deleted from second sentence “may be as short as 2 days”.
Inclusion/Exclusion Criteria | Section 5.1 | - Inclusion Criteria:; - 3) Changed “within 24 hours of first dose” to “within 24 hours prior to first dose”.; - 5) Changed “Signed informed consent/HIPAA documents by the parent/legal guardian and assent (if applicable)” to “Obtained Informed consent/HIPAA from the parent/legal guardian and assent (if applicable)”.
Treatment Assigned Procedures | Section 5.2 | - Changed end of second sentence from “on BMI at study entry” to “on BMI obtained at baseline (Day 0)”.; - Added third sentence, “The study drug is defined as dose(s) given after consent”.
Duration of Study Participation | Section 5.2.1 | - Added “IV” in first sentence before “clindamycin as the study drug”.; - Deleted second sentence, “All participants will begin on IV therapy and must receive at least 2 doses of IV clindamycin to participate in the study”.; - Deleted in third sentence, “from the time of enrollment”.; - Figure 2. Timeline. Added reference in first footnote, “(see Section 6.6.2 for further details)”.
Duration of Study Participation | Section 5.2.1 | Footnote for Figure 2 Timeline: Changed from minimum 2 doses of IV to minimum of 1 dose; Also changed minimum of 4 doses of PO to minimum of 3 doses.
Summary of Procedures | Section 6.1 | - Deleted most of #3. Item now reads as “Physical examination, including abnormal physical findings, height (measured standing if possible), weight and waist:hip ratio will be obtained (see Section 6.3 #2)”.; - Deleted most of #4. Item now reads as “Safety laboratory testing (see Section 6.6.1)”.
Enrollment/Baseline | Section 6.3 | - Changed “Baseline/Pre-Dose Assessment (Day 0) to “Baseline Assessment (Day 0)”.; - Changed first sentence from “After the parent or legal guardian has signed the IRB-approved informed consent form/HIPAA documents, the participant has signed assent (if applicable)…” to “After the parent or legal guardian has provided informed consent/HIPAA, the participant has provided assent (if applicable)…”.; - #2. Changed “Physical examination, including weight, height, waist:hip ratio, and BMI” to “Physical examination. NOTE: The initial physical examination information ([underlined: except the height, weight, and waist/hip measurements]) may be obtained from the medical record but must have been performed within 24 hours prior to first study dose. Height, weight and waist/hip measurements must be performed after consent. BMI will be calculated from height and weight using the following formula: BMI = [weight (kg) / (stature (cm))^2^] × 10,000. Refer to the Centers for Disease Control (CDC) pediatric BMI calculator (http://apps.nccd.cdc.gov/dnpabmi/) to determine the BMI percentile. The BMI percentile will be obtained using the BMI calculator and verified using the age- and sex-specific CDC BMI charts (see Appendix I)”.; - #8. Changed “within 24 hours of study enrollment” to “within 24 hours prior to first dose of study drug”.; - Assessments/Procedures (Days 1–14): 1^st^ paragraph - changed first 3 sentences from “The participant will start study drug upon completion of the pre-assessment, or, if s/he was already receiving clindamycin (at the study-recommended dose), s/he will continue receiving that dose of clindamycin. If s/he was receiving clindamycin at a dose lower than the study-recommended dose, the dose will be changed to be in compliance with the protocol. Total body weight will be used to calculate the absolute dose administered. Refer to Section 7.1.2 for dosing.” to “The participant will start study drug upon completion of the baseline procedures. Standard of care dosing may need to be increased to comply with the protocol. Refer to Section 7.1.2 for specific dosing information”.; - 2^nd^ paragraph - changed “The following assessments will be conducted after the participant receives the first dose of clindamycin after study enrollment and throughout therapy up to day 14” to “The following assessments will begin with the first dose of study drug and continue throughout therapy up to day 14:”
Follow-up Safety Phone Call | Section 6.5 | - Added at end of first sentence, “in which case an in-person visit or chart review may be performed”.; - Added to end of second sentence, “(i.e. end of therapy or early withdrawal/discontinuation).”; - Changed #3 from “Any labs collected” to “Results for laboratory tests of interest (see Section 6.6.1)”.
Clinical Laboratory Evaluations | Section 6.6.1 | - Changed from: “Laboratory testing (Table 2) will be collected on all participants and be performed in the local laboratory at each site. Laboratory values will be collected within 72 hours prior to enrollment. Laboratory values performed as part of routine care within 72 hours prior to enrollment may be used for baseline laboratory tests. Laboratory values will also be obtained at the end of therapy. Laboratory values obtained within ± 24 hours of discontinuation of study drug or within ± 24 hours of completion of 14 days of study drug (if they are continuing clindamycin beyond 14 days) may be used as end-of-treatment laboratory values. If these laboratory tests have not been performed as part of routine care, they will be performed for the study per the protocol schedule. The serum pregnancy test will also be performed at the local laboratory. Alpha (α)-1-glycoprotein will be measured from one of the PK samples by the central laboratory once during the study using an ELISA kit (central laboratory). Sites do not need to collect an extra sample to measure α-1-glycoprotein.”; To: “Laboratory testing (Table 2) will be collected on all participants and be performed in the local laboratory at each site. Laboratory values will be collected within 72 hours prior to the first dose of study drug through 3 days (+/− 1 day) after the last dose of study drug. If multiple values for a laboratory are obtained in the 72 hours prior to start of first study dose, record the value closest to the start of first study dose. Laboratory values performed as part of routine care within 72 hours prior to the first dose of study drug may be used for baseline laboratory tests. Laboratory values will also be obtained at the end of therapy. Laboratory values obtained within ± 24 hours of discontinuation of study drug or within ± 24 hours of completion of 14 days of study drug (if participant is continuing clindamycin beyond 14 days) may be used as end-of-treatment laboratory values. If the baseline and end of therapy laboratory tests have not been performed as part of routine care, they will be performed for the study per the protocol schedule. The serum pregnancy test will also be performed at the local laboratory. Alpha (α)-1-glycoprotein will be measured from one of the PK samples by the central laboratory once during the study using an ELISA kit (central laboratory). Sites do not need to collect an extra sample to measure α-1-glycoprotein.”
Special Assays or Procedures | Section 6.6.2 | Added the following:; - PK samples (#1–6) will be obtained at any point after the first study dose. For PO clindamycin, PK samples will begin with any dose after the 3^rd^ dose of PO study drug (first PK sample obtained within 15 minutes prior to PO study dose #4 or later).; - However, if each of the following criteria are met, PK samples (#1–6) can be obtained any point after consent:; - The most recent pre-consent standard of care dose is the same dose/interval/route as post-consent on-study doses,; - Exact start and stop times of the pre-consent dose are clearly documented (estimated times are not acceptable), AND; - Exact flush time of the pre-consent dose is clearly documented. Estimated flush times are not acceptable unless there is documentation of site standards for infusion/flush periods.; Last sentence of this section changed to, “The PK samples will be drawn according to the following schedule relative to the end of flush (IV PK) or actual time of oral administration (PO PK).”; - Minimizing Blood Loss; - Changed second sentence from “72 hours prior to enrollment into the study” to “72 hours prior to first dose of study drug”.
| Table 3. PK Schedule | - Added first column of “PK Sample” and listed as sample “1”, sample “2”, etc.
Dose and Timing | Section 7.1.2 | - Moved sentence three to sentence four; no content change.; - IV dosing: Changed the first sentence from, “A minimum of 2 doses” to “A minimum of 2 study doses”.
Accountability Procedures for the Study Intervention/Study Drugs | Section 7.4 | - Changed second sentence from “The study product accountability records will be maintained in the pharmacy study binder for clindamycin phosphate (IV), clindamycin hydrochloride (PO capsules) and clindamycin palmitate (PO oral solution)” to “The drug accountability records will be maintained according to sites’ pharmacy policies and procedures for clindamycin phosphate (IV), clindamycin hydrochloride (PO capsules) and clindamycin palmitate (PO oral solution).”
Assessment of Participant Compliance with Study Intervention | Section 7.5 | - Changed first sentence from “Compliance with dosing will be determined using the pharmacy accountability logs and the participant’s medication administration record” to “Compliance with dosing will be determined using the participant’s medication administration record and other applicable site supporting documentation”. Added last sentence, “Outpatient study visits should be scheduled around the participant’s oral dosing schedule to ensure that pre-dose samples are drawn at the study visit”.
Concomitant Medications of Interest/Treatment | Section 7.6 | - Changed in second sentence, “enrollment” to “receipt of study drug”.
Informed Consent Process | Section 12 | - First paragraph, fifth sentence: Changed “sign and date the informed consent document prior to” to “provide informed consent prior to”.; - Third paragraph, changed “an informed consent form must be signed” to “an informed consent must be obtained”.
Informed Consent | Section 15.3 | - Second sentence, changed “parent/legal guardian will sign one informed consent” to “parent/legal guardian will provide informed consent”.; - Third sentence, changed “parents/legal guardians must sign an informed consent form that complies” to “parents/legal guardians must provide informed consent based on consent form that complies”.

### 9.8.2 Changes in Planned Analyses

There have been no changes to the analyses planned in the SAP.